# Introduction

## Background

Infantile hemangiomas (IH) are the most common tumors of childhood. IH are benign but possess potential for local tissue damage, ulceration, infection, bleeding, functional impact, and pain. The International Society for the Study of Vascular Anomalies classifies IH as vascular tumors that are differentiated from vascular malformations in several ways including natural history, cellular composition, immunohistochemical expression, and pathology.1 Due to historical inconsistencies in naming conventions, it is difficult to know the true prevalence of IH, but it is estimated that they affect about 4 to 5 percent of children,2 with higher prevalence in females and Caucasians.3,4 The most common locations of IH are the head, neck, and trunk, but they can occur almost anywhere throughout the body, including the extremities, the spine, and visceral organs.5–7 IH also can be associated with a constellation of congenital anomalies such as PHACES (posterior fossa malformations, hemangiomas, arterial anomalies, cardiac defects, eye abnormalities, sternal cleft and supraumbilical raphe) PELVIS (perineal hemangioma, external genitalia malformations, lipomyelomeningocele, vesicorenal abnormalities, imperforate anus, and skin tag) and LUMBAR (lower-body hemangioma and other cutaneous defects, urogenital anomalies, ulceration, myelopathy, bony deformities, anorectal malformations, arterial anomalies, and renal anomalies) syndromes.

IH tend to go through growth and involution phases, although the complete natural history of IH has not been described. In most children, IH will become apparent in the first few weeks of life and reach 80 percent of total size by around 3 to 5 months.8,9 With expectant observation, many patients may experience a complete or near complete involution without significant sequelae; however, IH frequently occur in cosmetically and functionally sensitive areas. Even with complete involution, some patients have permanent disfigurement and functional compromise.10 Early assessment of the extent of the hemangioma, and early, appropriate treatment of IH may potentially mitigate these complications; however, in one large multicenter treatment analysis, the first specialist visit for infants and children in the study did not occur until a mean of 5 months of age.9

Furthermore, some lesions are particularly aggressive or morbid and can cause severe pain, ulceration, and bleeding even in early stages.11,12 The rapid growth of IH leaves little time for prospective observation to determine which IH will lead to complications and require specialist attention and treatment before complications begin to manifest. Some types of IH, specifically segmental IH such as those associated with related syndromes like PHACES, LUMBAR, or PELVIS, are recognized as high risk, but no consensus exists on which non-segmental lesions warrant referral for appropriate treatment to mitigate future complications (e.g., bleeding, ulceration) of the hemangioma or long-term sequelae (e.g., scarring, anatomical disfigurement, functional complications).5,7,13

### Diagnosis and Treatment Decisions

Evaluation through the use of various diagnostic imaging modalities has generally been reserved for deep lesions to help understand their extent or to confirm the diagnosis of IH. Purely cutaneous lesions do not require imaging, but opinions regarding the initial diagnostic test of choice for more extensive IH, including deep, segmental, and syndromic lesions, are conflicting. Furthermore, different disease sites or extents may be best handled with different imaging modalities. The questions of imaging necessity and type are especially important because many imaging studies in infants often require general anesthesia and may be associated with adverse effects. Modalities such as computed tomography also involve exposure to radiation.

Specific disease characteristics, such as lesion size, location, rate of growth, and persistence as well as modifiers such as patient age, functional impact, and IH subtype influence whether children are treated with pharmacologic agents or surgically. Many lesions can be treated with pharmacologic agents; however, refractory lesions that possess immediate risk for morbidity or mortality, such as hemangiomas obstructing the airway or visual axis, may require more immediate surgical intervention. Lesion characteristics such as size, location, and type (e.g., superficial, deep) also influence the choice of specific pharmacologic agents. For example, small, superficial lesions may respond well to topical agents such as timolol, while deep lesions are less likely to respond.14 Both medical and surgical treatment paradigms contain significant variability and lack of consensus.

Contraindications to specific treatments vary. Contraindications to beta-blockers include asthma, significant bradycardia, heart block, concurrent illness such s viral gastroenteritis or respiratory infection, history of reactive airway disease, and hypoglycemia.15 Contraindications to steroids include diabetes, chronic or untreated infections, decreased bone density, immunodeficiency, and active wound healing, and contraindications to surgical approaches include personal or family history of adverse reactions to anesthesia.

In many cases of IH, early referral and intervention are crucial to a satisfactory outcome, such as ocular IH disrupting the development of neural pathways during infancy. Further, some lesions, such as nasal tip IH, may cause permanent structural changes to adjacent structures. This may result in severe functional and disfiguring sequelae, even with complete resolution of the IH itself. In addition to structural damage, the psychological complications of having facial differences must be considered when determining the need for referral or treatment. While well-recognized clinical signs such as ulceration, airway obstruction, or vision-threatening involvement indicate need for urgent referral, there are no discrete guidelines that help direct primary care providers when to refer patients with IH for subspecialty care.

### Interventions

The beta-blocker propranolol was approved by the U.S. Food and Drug Administration (FDA) for use in IH in March 2014.^16–18^ Propranolol was historically used in children for cardiac conditions and off-label to treat IH after the serendipitous discovery of its effects on IH lesions in 2008.^19^ Prior to this, corticosteroids were the drug of choice, but propranolol has become the typical choice for initial medical management in children without contraindications to beta-blockers. Steroids may be used in children with contraindications to beta-blockers or who do not respond to beta-blockers. Additionally, there is no clear consensus as to when alternative or adjunctive or historically used medications such as chemotherapeutic drugs are appropriate if first-line treatment is unsuccessful.20,21

Surgical interventions for IH can be used for primary management of high risk lesions and include resection or ablation using laser or radiofrequency. Some confusion and disagreement exists about what type of surgical treatment to use, when in the disease course to treat, and how the disease site informs treatment decisions. Interventions for IH are varied, involved, and not without risk (e.g., risk of permanent hypopigmentation, scarring from pulsed dye laser therapy, potential harms of anesthesia); therefore, universal treatment is not recommended.22

## Scope and Key Questions

### Scope of Review

This systematic review addresses the evidence for benefits and harms of commonly used treatments for children (ages 0–18 years) with IH: beta-blockers, corticosteroids, “second-line” drugs used after the failure of beta-blockers or steroids, and laser and surgical treatment. The decisional dilemmas that this review addresses are whether imaging modalities are useful both in diagnosis and for guiding treatment, and the expected comparative effectiveness (benefits and harms) of pharmacologic and surgical treatments, relative to observation or other active treatments. While pharmacologic and surgical interventions cannot be directly compared because of their inherent confounding by indication, we assess the comparative effectiveness of different options within both pharmacologic and surgical approaches.

We include both contextual and Key Questions. We systematically reviewed and assessed the risk of bias of the literature meeting our inclusion criteria for Key Questions, which address the comparative effectiveness of interventions. We provide a narrative review of relevant literature for contextual questions as few effectiveness studies address these questions, which are related to natural history of IH and markers for occult IH.

### Key Questions

Key Questions (KQs) and Contextual Questions (CQs) were developed in consultation with Key Informants and the Task Order Officer and were posted for review to the AHRQ Effective Health Care Web site. Questions were as follows:

CQ1 What is known about the natural history of infantile hemangiomas, by hemangioma site and subtype? What are the adverse outcomes of untreated infantile hemangiomas? What characteristics of the hemangioma (e.g., subtype, size, location, number of lesions) indicate risk of significant medical complications that would prompt immediate medical or surgical intervention?
CQ2 What is the evidence that five or more cutaneous hemangiomas are associated with an increased risk of occult hemangiomas?
KQ1 Among newborns, infants, and children up to 18 years of age with known or suspected infantile hemangiomas, what is the comparative effectiveness (benefits/harms) of various imaging modalities for identifying and characterizing hemangiomas?
  a. Does the comparative effectiveness differ by location and subtype of the hemangioma?
KQ2 Among newborns, infants, and children up to 18 years of age with infantile hemangiomas who have been referred for pharmacologic intervention, what is the comparative effectiveness (benefits/harms) of corticosteroids or beta-blockers?
KQ3 Among newborns, infants, and children up to 18 years of age with infantile hemangiomas for whom treatment with corticosteroids or beta-blockers is unsuccessful what is the comparative effectiveness of second line therapies including immunomodulators and angiotensin-converting enzyme inhibitors?
KQ4 Among newborns, infants, and children up to 18 years of age with infantile hemangiomas who have been referred for surgical intervention, what is the comparative effectiveness (benefits/harms) of various types of surgical interventions (including laser and resection)?

## Analytic Framework

The analytic frameworks illustrate the population, interventions, and outcomes that guided the literature search and synthesis (Figures 1–3). The frameworks depict the Key Questions within the context of the population, intervention, comparator, outcomes, timing, and setting (PICOTS) parameters described in the review. In general, the figures illustrate how imaging modalities or interventions such as magnetic resonance imaging (MRI), beta-blockers, or laser may result in intermediate outcomes such as change in hemangioma size or change in vision and/or in final health outcomes such as detection of IH for imaging modalities or resolution of hemangioma or changes in quality of life for medical or surgical treatments. Also, adverse events may occur at any point after the intervention is received.

Figure 1 Analytic framework for KQ1

IH = infantile hemangioma; KQ = Key Question

Figure 1 depicts Key Question 1 within the context of the PICOTS described in the document. The figure examines imaging modalities for newborns, infants, and children up to 18 years of age with known or suspected infantile hemangioma. Modes of imaging include magnetic resonance imaging, computed tomography, magnetic resonance angiography, echocardiography, ultrasonography, and endoscopy for diagnosing and characterizing known or suspected visceral hemangiomas. Outcomes include the ability to identify presence, number, and extent of hemangiomas and associated structural anomalies (sensitivity and specificity). Harms may occur at any point after the intervention is received.

Figure 2 Analytic framework for KQ2 and KQ3

IH = infantile hemangioma; KQ = Key Question

Figure 2 depicts Key Questions 2 and 3 within the context of the PICOTS described in the document. The figure examines interventions for newborns, infants, and children up to 18 years of age with infantile hemangiomas who have been referred for pharmacologic therapy (e.g., beta-blockers, corticosteroids) or for adjuvant medical therapy (e.g., immunosuppressants, immunomodulators, antineoplastics, angiotensin-converting enzyme inhibitors, antiangiogenic agents) when treatment with beta-blockers or corticosteroids is unsuccessful. Intermediate outcomes include size / volume of hemangioma; impact on vision; aesthetic appearance as assessed by clinician or parent; degree of ulceration; harms; and quality of life. Final outcomes include marked improvement of hemangiomas; prevention of disfigurement; resolution of airway obstruction; preservation of vision; preservation of organ function (e.g., thyroid function, cardiac function); resolution of ulceration, and psychological impact on the patient. Harms (e.g., pain, bleeding, sequelae of scarring, skin atrophy, venous prominence, disfigurement, distortion of anatomic landmarks, ulceration, infection, hypopigmentation) may occur at any point after the intervention is received.

Figure 3 Analytic framework for KQ4

IH = infantile hemangioma; KQ = Key Question; Nd:YAG = neodymium yttrium aluminum garnet

Figure 3 depicts Key Question 4 within the context of the PICOTS described in the document. The figure examines interventions for newborns infants, and children up to 18 years of age with infantile hemangiomas who have been referred for surgical interventions including either laser therapy (e.g., pulsed dye, fractionated laser, argon, carbon dioxide, neodymium (Nd): YAG or erbium) or surgery (e.g., cryotherapy, resection, embolization, or radiofrequency ablation therapy). Intermediate outcomes include size / volume of hemangioma; impact on vision; aesthetic appearance as assessed by clinician or parent; degree of ulceration; harms; and quality of life. Final outcomes include marked improvement of hemangioma; prevention of disfigurement; resolution of airway obstruction; preservation of vision; preservation of organ function (e.g., thyroid function, cardiac function); resolution of ulceration, and psychological impact on the patient. Harms (e.g., pain, bleeding, sequelae of scarring, skin atrophy, venous prominence, disfigurement, distortion of anatomic landmarks, ulceration, infection, hypopigmentation) may occur at any point after the intervention is received.

## Organization of This Report

The Methods section describes the review processes including search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, methods for extraction of data, and compiling evidence. We also describe our approach to grading the quality of the literature and describing the strength of the body of evidence.

The Results section presents the findings of the literature search and the review of the evidence by Key Question, synthesizing the findings across strategies. We present findings for the Contextual Questions followed by findings of the network meta-analysis, followed by findings for each Key Question organized by intervention and outcome area where possible. Summary tables for each Key Question outline key outcomes.

The Discussion section of the report discusses the results and expands on methodologic considerations relevant to each Key Question. We also outline the current state of the literature and challenges for future research in the field. The report includes a number of appendices to provide further detail on our methods and the studies assessed. The appendices are as follows:

- Appendix A: Search Strategies
- Appendix B: Screening and Quality Assessment Forms
- Appendix C: Excluded Studies
- Appendix D: Methods for Network Meta-Analysis
- Appendix E: Study Design Classification Algorithm
- Appendix F: Quality/Risk of Bias Ratings
- Appendix G: Applicability Tables
- Appendix H: Harms Reported in Package Insert Data and Other Sources

We also provide a list of abbreviations and acronyms at the end of the report.

## Uses of This Evidence Report

We anticipate this report will be of primary value to organizations that develop guidelines for managing IH, to clinicians who provide care for children with IH, and for families making treatment decisions. IH is diagnosed and treated by clinicians including pediatricians, dermatologists, otolaryngologists, family physicians, nurses, nurse-practitioners, physician assistants, hematologists, and general and plastic surgeons. This report supplies practitioners and researchers up-to-date information about the current state of evidence, and assesses the quality of studies that aim to determine the outcomes and safety of treatments for IH.

Researchers can obtain a concise analysis of the current state of knowledge of interventions in this field. They will be poised to pursue further investigations that are needed to advance research methods, develop new treatment strategies, and optimize the effectiveness and safety of clinical care for children with this condition.