# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rongwei (Rochelle) Fu, Ph.D.
  School of Public Health
  Oregon Health and Science University
  Portland, OR
- Amy Jo Nopper, M.D.
  University of Missouri-Kansas City
  Kansas City, MO
- Marco Sciveres, M.D.
  IsMeTT-University of Pittsburgh Medical Center Italy
  Palermo, Italy
- Anne Zajicek, MD, Pharm.D.
  Obstetric and Pediatric Pharmacology and Therapeutics Branch
  Eunice Kennedy Shriver National Institute of Child Health and Human Development
  Washington, DC