# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows.

- Denise M. Adams, M.D.^*^
  * Individuals marked with an asterisk also peer reviewed the report.
  Cincinnati Children’s Medical Center
  Cincinnati, OH
- David Darrow, M.D.^*^
  Children’s Hospital of The King’s Daughters
  Norfolk, VA
- Ilona J. Frieden, M.D.^*^
  University of California
  San Francisco, CA
- Arin K. Greene, M.D.
  Boston Children’s Hospital
  Boston, MA
- Marcia Hogeling, M.D.^*^
  Phoenix Children’s Hospital
  Phoenix, AZ
- Dana Janssen, M.D.
  Monroe Carell Jr. Children’s Hospital at Vanderbilt
  Nashville, TN
- Anthony J. Mancini, M.D.^*^
  Ann & Robert H. Lurie Children’s Hospital
  Chicago, IL