# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Mamata Raj and Shanthi Krishnaswami assisted with data extraction and review of the data. Jessica Kimber and Sanura Latham assisted with locating papers, formatting of materials, and scheduling meetings. Annette Williams and Katherine Worley managed the topic refinement phase of the review. Our AHRQ Task Order Officer and Associate Editor and our Key Informants and Technical Expert Panel members provided invaluable input on structuring the report.