# Conclusions

Corticosteroids demonstrate some effectiveness at reducing IH size/volume, but may be associated with clinically important side effects. Propranolol is effective at reducing the size of IH, with high strength of evidence for effects on reducing lesion size, and compared with placebo, observation, and other treatment methods including steroids in most, but not all, studies. In a network meta-analysis, the largest mean estimate of expected clearance was for oral propranolol (95%, 95% BCI: 88% to 99%), followed by timolol (62%, 95% BCI: 39% to 83%) and triamcinolone (58%, 95% BCI: 22% to 93%). The mean rate was 43 percent for oral steroids (95% BCI: 21% to 66%). With fairly wide confidence bounds and limited data in some areas, the relative differences among these estimates are of greater importance than the absolute effects. The estimates provide a relative ranking of anticipated rates of lesion clearance among treatment options. Families and clinicians making treatment decisions should also factor in elements such as lesion size, location, type, and number, which may affect choice of treatment modality, as well as patient/family preferences. Evidence pointed to substantial side effects for corticosteroids; harms were also noted with beta-blockers, but overall, these were well tolerated in the short term. Few studies have assessed potential long-term harms associated with beta-blocker use in infants and children. Laser studies generally found PDL more effective than other types of laser, but effects remain unclear as studies are heterogeneous and the role of laser vis-a-vis beta-blockers is not clearly described in the literature. Data are inadequate to address the role of imaging in guiding treatment.