# Harms Reported in Package Insert Data and Other Sources

## Infantile Hemangioma Package Insert and FDA Harms Data

The harms data provided in this section were gathered from analyzing available gray literature (i.e., package inserts and FDA review packages). FDA approval packages were limited to those available on the FDA website that contained a “Medical Review” section of the document. Many of the review packages did not contain pediatric data and therefore the adult data was used. Table 1 includes the relevant indications for pediatric medications referenced in the clinical studies included in this review. Medications that have not been approved as safe and effective in pediatric patients and therefore are only FDA approved in adults are referenced in Table 2. Notable contraindications and warnings/precautions that would be relevant to consider in the pediatric population were included in the tables (drug interactions were not included). As a result, the data provided in this chart is not an all-inclusive list of these package insert sections. For complete data please see the corresponding package insert.

Table H-1 FDA Approved Pediatric Medications Included in Literature Review

Drug | Dosage Form | FDA Approved Indication | Contraindications | Warnings/Precautions
Hemangeol® (propranolol hydrochloride)1 | Oral solution | Beta-adrenergic blocker indicated for the treatment of proliferating infantile hemangioma requiring systemic therapy | - Premature infants with corrected age <5 weeks; - Infants weighing less than 2 kg; - Asthma or history of bronchospasm; - Bradycardia (<80 beats per minute), greater than first degree heart block, decompensated heart failure; - Blood pressure <50/30 mmHg; - Pheochromocytoma | - Hypoglycemia: Administer during or after feeding. Do not use in patients who are not able to feed or are vomiting.; - Bradycardia and hypotension; - Bronchospasm: Avoid use in patients with asthma or lower respiratory infection.; - Increased risk of stroke in PHACE syndrome
Flo-pred® (prednisolone acetate)2 Orapred ODT (prednisolone sodium phosphate) 3 Rayos® (prednisone)4 | Oral suspension ODT tablet Delayed release tablet | - Allergic Conditions: Control of severe or incapacitating allergic conditions intractable to adequate trials of conventional treatment in adults and pediatric populations with:; ○ Atopic dermatitis; ○ Drug hypersensitivity reactions; ○ Seasonal or perennial allergic rhinitis; ○ Serum sickness; - Dermatologic Diseases; ○ Bullous dermatitis herpetiformis; ○ Contact dermatitis; ○ Exfoliative erythroderma; ○ Mycosis fungoides; ○ Pemphigus; ○ Severe erythema multiforme (Stevens-Johnson syndrome); - Endocrine Conditions; ○ Congenital adrenal hyperplasia; ○ Hypercalcemia of malignancy; ○ Nonsuppurative thyroiditis; ○ Primary or secondary adrenocortical insufficiency: hydrocortisone or cortisone is the first choice: synthetic analogs may be used in conjunction with mineralocorticoids where applicable; - Gastrointestinal Diseases: During acute episodes in:; ○ Crohn’s Disease; ○ Ulcerative colitis; - Hematologic Diseases; ○ Acquired (autoimmune) hemolytic anemia; ○ Diamond-Blackfan anemia; ○ Pure red cell aplasia; - Neoplastic Conditions:; ○ Acute leukemia; ○ Aggressive lymphomas; - Nervous System Conditions; ○ Acute exacerbations of multiple sclerosis; ○ Cerebral edema associated with primary or metastatic brain tumor, craniotomy or head injury; - Ophthalmic Conditions; ○ Sympathetic ophthalmia; ○ Uveitis and ocular inflammatory conditions unresponsive to topical steroids; - Conditions Related to Organ Transplantation; ○ Acute or chronic solid organ rejection; - Pulmonary Diseases; ○ Allergic bronchopulmonary aspergillosis; ○ Aspiration pneumonitis; ○ Asthma; ○ Fulminating or disseminated pulmonary tuberculosis when used concurrently with appropriate chemotherapy; ○ Hypersensitivity pneumonitis; ○ Idiopathic bronchiolitis obliterans with organizing pneumonia; ○ Idiopathic eosinophilic pneumonias; ○ Idiopathic pulmonary fibrosis; ○ Pneumocystis carinii pneumonia (PCP) associated with hypoxemia occurring in an HIV(+) individual who is also under treatment with appropriate anti-PCP antibiotics.; ○ Symptomatic sarcoidosis; - Renal Conditions; ○ To induce a diuresis or remission of proteinuria in nephrotic syndrome, without uremia, of the idiopathic type or that due to lupus erythematosus; - Rheumatologic Conditions: As adjunctive therapy for short-term administration (to tide the patient over an acute episode or exacerbation) in:; ○ Acute gouty arthritis; - During an exacerbation or as maintenance therapy in selected cases of:; ○ Ankylosing spondylitis; ○ Dermatomyositis/polymyositis; ○ Polymyalgia rheumatica; ○ Psoriatic arthritis; ○ Relapsing polychondritis; ○ Rheumatoid arthritis, including juvenile rheumatoid arthritis (selected cases may require low dose maintenance therapy); ○ Systemic lupus erythematosus; ○ Vasculitis; - Specific Infectious Diseases; ○ Trichinosis with neurologic or myocardial involvement.; ○ Tuberculous meningitis with subarachnoid block or impending block used concurrently with appropriate antituberculous chemotherapy. | --- | - Hypothalamic-pituitary-adrenal (HPA) axis suppression, Cushing’s syndrome and hyperglycemia: Monitor patients for these conditions with chronic use. Taper doses gradually for withdrawal after chronic use.; - Infections: Increased susceptibility to new infection and increased risk of exacerbation, dissemination, or reactivation of latent infection. Signs and symptoms of infection may be masked; - Elevated blood pressure, salt and water retention and hypokalemia: Monitor blood pressure and sodium, potassium serum levels; - GI perforation: increased risk in patients with certain GI disorders. Signs and symptoms may be masked; - Behavioral and mood disturbances: May Include euphoria, insomnia, mood swings, personality changes, severe depression, and psychosis. Existing conditions may be aggravated.; - Decreases in bone density: Monitor bone density in patients receiving long-term corticosteroid therapy.; - Ophthalmic effects: May include cataracts, infections and glaucoma. Monitor intraocular pressure if corticosteroid therapy is continued for more than 6 weeks.; - Live or live attenuated vaccines: Do not administer to patients receiving immunosuppressive doses of corticosteroids.; - Negative effects on growth and development: Monitor pediatric patients on long-term corticosteroid therapy.; - Kaposi’s sarcoma has been reported to occur in patients receiving corticosteroid therapy, most often for chronic conditions. Discontinuation of corticosteroids may result in clinical improvement.; - Although controlled clinical trials have shown corticosteroids to be effective in speeding the resolution of acute exacerbations of multiple sclerosis, they do not show that corticosteroids affect the ultimate outcome or natural history of the disease. The studies do show that relatively high doses of corticosteroids are necessary to demonstrate a significant effect.; - An acute myopathy has been observed with the use of high doses of corticosteroids, most often occurring in patients with disorders of neuromuscular transmission (e.g., myasthenia gravis), or in patients receiving concomitant therapy with neuromuscular blocking drugs (e.g., pancuronium). This acute myopathy is generalized, may involve ocular and respiratory muscles, and may result in quadriparesis. Elevation of creatinine kinase may occur. Clinical improvement or recovery after stopping corticosteroids may require weeks to years.
Medrol® (methylprednisolone)5 Depo-Medrol® (methylprednisolone acetate)6 Solu-Medrol® (methylprednisolone sodium succinate)7 | Oral tablet Intramuscular injection Intravenous or intramuscular injection | - Similar Indications as listed in the prednisolone row with the following additional:; ○ Acute and subacute bursitis; ○ Synovitis of osteoarthritis; ○ Acute nonspecific tenosynovitis; ○ Post-traumatic osteoarthritis; ○ Epicondylitis; ○ Severe seborrheic dermatitis; ○ Severe psoriasis; ○ Allergic corneal marginal ulcers; ○ Herpes zoster ophthalmicus; ○ Loeffler’s syndrome not manageable by other means; ○ Erythroblastopenia; - Not indicated for:; ○ Crohn’s Disease; ○ Transfusion reactions; ○ Pure red cell aplasia; ○ Vasculitis; ○ Allergic bronchopulmonary aspergillosis; ○ Aspiration pneumonitis; ○ Hypersensitivity pneumonitis; ○ Idiopathic bronchiolitis obliterans with organizing pneumonia; ○ Idiopathic pulmonary fibrosis; ○ Pneumocystis carinii pneumonia (PCP) associated with hypoxemia occurring in an HIV(+) individual who is also under treatment with appropriate anti-PCP antibiotics.; ○ Polymyalgia rheumatica; ○ Relapsing polychondritis | - Systemic fungal infections; - Injectable formulation: NOT FOR USE IN NEWBORNS | Similar Warnings/Precautions the prednisolone with the following additional:; - In patients on corticosteroid therapy subjected to unusual stress, increased dosage of rapidly acting corticosteroids before, during, and after the stressful situation is indicated.; - The use of methylprednisolone tablets in active tuberculosis should be restricted to those cases of fulminating or disseminated tuberculosis in which the corticosteroid is used for the management of the disease in conjunction with an appropriate antituberculous regimen.; - If corticosteroids are indicated in patients with latent tuberculosis or tuberculin reactivity, close observation is necessary as reactivation of the disease may occur. During prolonged corticosteroid therapy, these patients should receive chemoprophylaxis.; - Persons who are on drugs which suppress the immune system are more susceptible to infections than healthy individuals. Drug-induced secondary adrenocortical insufficiency may be minimized by gradual reduction of dosage. This type of relative insufficiency may persist for months after discontinuation of therapy; therefore, in any situation of stress occurring during that period, hormone therapy should be reinstituted. Since mineralocorticoid secretion may be impaired, salt and/or a mineralocorticoid should be administered concurrently.; - There is an enhanced effect of corticosteroids on patients with hypothyroidism and in those with cirrhosis.; - Corticosteroids should be used cautiously in patients with ocular herpes simplex because of possible corneal perforation.; - The lowest possible dose of corticosteroid should be used to control the condition under treatment, and when reduction in dosage is possiathyble, the reduction should be gradual.; - Steroids should be used with caution in nonspecific ulcerative colitis, if there is a probability of impending perforation, abscess or other pyogenic infection; diverticulitis; fresh intestinal anastomoses; active or latent peptic ulcer; renal insufficiency; hypertension; osteoporosis; and myasthenia gravis.; - Since complications of treatment with glucocorticoids are dependent on the size of the dose and the duration of treatment, a risk/benefit decision must be made in each individual case as to dose and duration of treatment and as to whether daily or intermittent therapy should be used.; Injection Specific:; - This product contains benzyl alcohol. Benzyl alcohol has been associated with a fatal “Gasping Syndrome” in premature infants and infants of low birth weight. Exposure to excessive amounts of benzyl alcohol has been associated with toxicity (hypotension, metabolic acidosis), particularly in neonates, and an increased incidence of kernicterus, particularly in small preterm infants. There have been rare reports of deaths, primarily in preterm infants, associated with exposure to excessive amounts of benzyl alcohol.; - Rare instances of anaphylactoid reactions have occurred in patients receiving corticosteroid therapy; - Increased dosage of rapidly acting corticosteroids is indicated in patients on corticosteroid therapy subjected to any unusual stress before, during, and after the stressful situation.; - Literature reports suggest an apparent association between use of corticosteroids and left ventricular free wall rupture after a recent myocardial infarction; therefore, therapy with corticosteroids should be used with great caution in these patients.; - Metabolic clearance of corticosteroids is decreased in hypothyroid patients and increased in hyperthyroid patients. Changes in thyroid status of the patient may necessitate adjustment in dosage.; - Fungal Infections: Corticosteroids may exacerbate systemic fungal infections and therefore should not be used in the presence of such infections unless they are needed to control drug reactions. Corticosteroids should not be used in cerebral malaria.; - Latent disease may be activated or there may be an exacerbation of intercurrent infections due to pathogens, including those caused by Amoeba, Candida, Cryptococcus, Mycobacterium, Nocardia, Pneumocystis, and Toxoplasma.; - Tuberculosis: If corticosteroids are indicated in patients with latent tuberculosis or tuberculin reactivity, close observation is necessary as reactivation of the disease may occur. During prolonged corticosteroid therapy, these patients should receive chemoprophylaxis.; - Viral Infections: Chicken pox and measles can have a more serious or even fatal course in pediatric and adult patients on corticosteroids; - This product, like many other steroid formulations, is sensitive to heat. Therefore, it should not be autoclaved when it is desirable to sterilize the exterior of the vial.; - The lowest possible dose of corticosteroid should be used to control the condition under treatment. When reduction in dosage is possible, the reduction must be gradual.; - Cardio-renal: As sodium retention with resultant edema and potassium loss may occur in patients receiving corticosteroids, these agents should be used with caution in patients with congestive heart failure, hypertension, or renal insufficiency.; - Endocrine: Drug-induced secondary adrenocortical insufficiency may be minimized by gradual reduction of dosage.; - Although controlled clinical trials have shown corticosteroids to be effective in speeding the resolution of acute exacerbations of multiple sclerosis, they do not show that they affect the ultimate outcome or natural history of the disease.; - An acute myopathy has been observed with the use of high doses of corticosteroids, most often occurring in patients with disorders of neuromuscular transmission (e.g., myasthenia gravis), or in patients receiving concomitant therapy with neuromuscular blocking drugs (e.g., pancuronium).; - Corticosteroids may suppress reactions to skin tests.; - Vaccines: Patients on prolonged corticosteroid therapy may exhibit a diminished response to toxoids and live or inactivated vaccines due to inhibition of antibody response. Corticosteroids may also potentiate the replication of some organisms contained in live attenuated vaccines. Routine administration of vaccines or toxoids should be deferred until corticosteroid therapy is discontinued if possible
Aristospan® (triamcinolone hexacetonide)8 Kenalog-10® (triamcinolone acetonide)9 | Intralesional injection | The intralesional administration of triamcinolone hexacetonide injectable suspension is indicated for:; - alopecia areata; - discoid lupus erythematosus; - keloids; - localized hypertrophic; - infiltrated; - inflammatory lesions of granuloma annulare; - lichen planus; - lichen simplex chronicus (neurodermatitis); - psoriatic plaques; - necrobiosis lipoidica diabeticorum; - cystic tumors of an aponeurosis or tendon (ganglia) | NOT FOR USE IN NEWBORNS | Similar Warnings/Precautions the prednisolone with injection specific warnings in the methylprednisolone row.
Celestone Soluspan® (betamethasone)10 | Intralesional injection | Intralesional injection has similar indications as listed in the triamcinolone row. | NOT FOR USE IN NEWBORNS | Similar Warnings/Precautions the prednisolone with injection specific warnings in the methylprednisolone row.
Elocon® (mometasone furoate)11 | Topical cream | Corticosteroid indicated for the relief of the inflammatory and pruritic manifestations of corticosteroid-responsive dermatoses in patients 2 years of age or older | --- | - Reversible HPA axis suppression with the potential for glucocorticosteroid insufficiency after withdrawal of treatment, Cushing’s syndrome, and hyperglycemia may occur due to systemic absorption. Patients applying a topical steroid to a large surface area or to areas under occlusion should be evaluated periodically for evidence of HPA axis suppression. Modify use should HPA axis suppression develop.; - Pediatric patients may be more susceptible to systemic toxicity.; - Allergic Contact Dermatitis: If irritation develops, mometasone furoate should be discontinued and appropriate therapy instituted.; - Concomitant Skin Infections: If concomitant skin infections are present or develop, an appropriate antifungal or antibacterial agent should be used. If a favorable response does not occur promptly, mometasone furoate use of should be discontinued until the infection has been adequately controlled.
Zyclara® (imiquimod)12 Aldara® (imiquimod)13 | 2.5% to 3.75% Topical cream 5% Topical cream | Indicated for the treatment of external genital and perianal warts (EGW)/condyloma acuminata in patients 12 years or older. | --- | - Local Skin Reactions: Intense local skin reactions including skin weeping or erosion can occur after a few applications and may require an interruption of dosing. Imiquimod has the potential to exacerbate inflammatory conditions of the skin, including chronic graft versus host disease.; Severe local inflammatory reactions of the female external genitalia can lead to severe vulvar swelling. Severe vulvar swelling can lead to urinary retention. Dosing should be interrupted or discontinued for severe vulvar swelling.; Administration of imiquimod is not recommended until the skin is healed from any previous drug or surgical treatment.; - Systemic Reactions Flu-like signs and symptoms may accompany, or even precede, local skin reactions and may include fatigue, nausea, fever, myalgias, arthralgias, malaise and chills.; - Ultraviolet Light Exposure Risks: Exposure to sunlight (including sunlamps) should be avoided or minimized during use of imiquimod.; - Increased Risk of Adverse Reactions with Concomitant Imiquimod Use; - Immune Cell Activation in Autoimmune Disease: Imiquimod should be used with caution in patients with pre-existing autoimmune conditions because imiquimod activates immune cells

Table H-2 FDA Approved Adult Medications (Prescribed Off-Label in Pediatric Patients) Included in Literature Review

Drug | Dosage Form | FDA Approved Indication | Contraindications | Warnings/Precautions
Tenormin® (atenolol)14 | Oral tablet | - Treatment of hypertension, to lower blood pressure; - Long-term management of patients with angina pectoris.; - Management of hemodynamically stable patients with definite or suspected acute myocardial infarction to reduce cardiovascular mortality | - Sinus bradycardia; - Heart block greater than first degree; - Cardiogenic shock; - Overt cardiac failure | - Cardiac Failure: Sympathetic stimulation is necessary in supporting circulatory function in congestive heart failure, and beta blockade carries the potential hazard of further depressing myocardial contractility and precipitating more severe failure.; - In Patients Without a History of Cardiac Failure: Continued depression of the myocardium with beta-blocking agents over a period of time can, in some cases, lead to cardiac failure; - Cessation of Therapy with Atenolol: Patients with coronary artery disease, who are being treated with atenolol, should be advised against abrupt discontinuation of therapy.; - Concomitant Use of Calcium Channel Blockers: Bradycardia and heart block can occur and the left ventricular end diastolic pressure can rise when beta-blockers are administered with verapamil or diltiazem. Patients with pre-existing conduction abnormalities or left ventricular dysfunction are particularly susceptible.; - Bronchospastic Diseases: Patients with bronchospastic disease should, in general, not receive beta blockers. Because of its relative beta1 selectivity, however, atenolol may be used with caution in patients with bronchospastic disease who do not respond to, or cannot tolerate, other antihypertensive treatment.; - Major Surgery: Chronically administered beta-blocking therapy should not be routinely withdrawn prior to major surgery, however the impaired ability of the heart to respond to reflex adrenergic stimuli may augment the risks of general anesthesia and surgical procedures.; - Diabetes and Hypoglycemia: atenolol should be used with caution in diabetic patients if a beta-blocking agent is required. Beta blockers may mask tachycardia occurring with hypoglycemia, but other manifestations such as dizziness and sweating may not be significantly affected.; - Thyrotoxicosis: Beta-adrenergic blockade may mask certain clinical signs (eg, tachycardia) of hyperthyroidism. Abrupt withdrawal of beta blockade might precipitate a thyroid storm; therefore, patients suspected of developing thyrotoxicosis from whom atenolol therapy is to be withdrawn should be monitored closely.; - Untreated Pheochromocytoma: atenolol should not be given to patients with untreated pheochromocytoma.
Timoptic® (timolol maleate)15 Timoptic-XE® (timolol maleate)16 Betimol® (timolol)17 | Ophthalmic Solution | Treatment of elevated intraocular pressure in patients with ocular hypertension or open-angle glaucoma. | - Bronchial asthma; - A history of bronchial asthma; - Severe chronic obstructive pulmonary disease; - Sinus bradycardia; - Second or third degree atrioventricular block; - Overt cardiac failure; - Cardiogenic shock. | - Cardiac Failure: sympathetic stimulation may be essential for support of the circulation in individuals with diminished myocardial contractility, and its inhibition of beta-adrenergic receptor blockade may precipitate more severe failure.; - In Patients Without a History of Cardiac Failure: continued depression of the myocardium with beta-blocking agents over a period of time can, in some cases, lead to cardiac failure. At the first sign or symptom of cardiac failure, timolol should be discontinued.; - Major Surgery: Beta-adrenergic receptor blockade impairs the ability of the heart to respond to beta-adrenergically mediated reflex stimuli. This may augment the risk of general anesthesia in surgical procedures. In patients undergoing elective surgery, some authorities recommend gradual withdrawal of beta-adrenergic receptor blocking agents.; - Diabetes Mellitus: Beta-adrenergic blocking agents should be administered with caution in patients subject to spontaneous hypoglycemia or to diabetic patients (especially those with labile diabetes) who are receiving insulin or oral hypoglycemic agents. Beta-adrenergic receptor blocking agents may mask the signs and symptoms of acute hypoglycemia.; - Thyrotoxicosis: Beta-adrenergic blocking agents may mask certain clinical signs (e.g., tachycardia) of hyperthyroidism.:; - Because of potential effects of beta-adrenergic blocking agents on blood pressure and pulse, these agents should be used with caution in patients with cerebrovascular insufficiency; - There have been reports of bacterial keratitis associated with the use of multiple-dose containers of topical ophthalmic products.; - Choroidal detachment after filtration procedures has been reported with the administration of aqueous suppressant therapy (e.g. timolol).; - Angle-closure glaucoma: In patients with angle-closure glaucoma, the immediate objective of treatment is to reopen the angle. This requires constricting the pupil. Timolol maleate has little or no effect on the pupil. Timolol should not be used alone in the treatment of angle-closure glaucoma.; - Anaphylaxis: While taking beta-blockers, patients with a history of atopy or a history of severe anaphylactic reactions to a variety of allergens may be more reactive to repeated accidental, diagnostic, or therapeutic challenge with such allergens.; - Muscle Weakness: Beta-adrenergic blockade has been reported to potentiate muscle weakness consistent with certain myasthenic symptoms (e.g., diplopia, ptosis, and generalized weakness). Timolol has been reported rarely to increase muscle weakness in some patients with myasthenia gravis or myasthenic symptoms.

## Harms Data for Medications Included in the Analysis

The following sections provide an overview of the common and notable adverse events of each medication. When possible, adverse event data specific for pediatric patients have been included. It is important to note that the information provided in this section is not an all-inclusive list of adverse events. Consult the corresponding package insert for complete information. Many of the adverse events reported are from various clinical trials used in support of the medication’s FDA approval. As a result, these trials many have been conducted under varying conditions and the adverse event rates may not reflect what is observed in clinical practice. In addition, these rates may not necessarily be able to be compared to the rates observed in the clinical trials of different drugs. Post-marketing adverse events are reported on a voluntary basis and therefore do not represent complete patient data.

### Hemangeol® (propranolol hydrochloride)

Hemangeol® is the only medication included in this review that has an FDA approved indication for infantile hemangioma. The safety of Hemageol® in pediatric patients has been reported in the medication package insert.1 FDA medical review packages were not available for this medication.

The most common adverse events, occurring in greater than 10% of infants, were sleep disorders, aggravated respiratory tract infections such as bronchitis and bronchiolitis associated with cough and fever, diarrhea, and vomiting.1 In a study of pooled safety data (n=424), infants (63% aged 91–150 days) were treated with Hemangeol® 1.2 mg/kg/day or 3.4 mg/kg/day for 3 or 6 months. Treatment emergent adverse events occurring in 3% or greater in infants receiving the Hemangeol® 1.2 mg/kg/day (n=200) or Hemangeol® 3.4 mg/kg/day (n=224) compared to placebo were provided. Adverse events and frequencies for patients receiving Hemangeol® 1.2 mg/kg/day included: sleep disorders (17.5%), bronchitis (8%), peripheral coldness (8%), agitation (8.5%), diarrhea (4.5%), somnolence (5.0%), nightmare (2.0%), irritability (5.5%), decreased appetite (2.5%), and abdominal pain (3.5%). Adverse events and frequencies for patients receiving Hemangeol® 3.4 mg/kg/day (n=224) included: sleep disorders (16.1%), bronchitis (13.4%), peripheral coldness (6.7%), agitation (4.5%), diarrhea (6.3%), somnolence (0.9%), nightmare (6.3%), irritability (1.3%), decreased appetite (3.6%), and abdominal pain (0.4%). Additional adverse events reported in less than 1% of patients participating in clinical trials included: second degree atrioventricular heart block (occurring in a patient with underlying conduction disorder), urticaria, alopecia, decreased blood glucose, and decreased heart rate.

#### Additional Formulations

The safety and efficacy of the oral tablet, oral capsule, and injectable formulations of propranolol have not been investigated in pediatric patients.18–20 The package inserts for these formulations state that reports of bronchospasm and congestive heart failure have been reported in pediatric patients receiving propranolol.

#### Post-marketing Adverse Events

Additional adverse events revealed during post-marketing surveillance include: agranulocytosis, hallucination and purpura.1

### Corticosteroids

The safety and efficacy of pediatric use of corticosteroids has been studied in the literature for the treatment of nephrotic syndrome (>2 years of age), and aggressive lymphomas and leukemias (>1 month of age).2–4,6,7,10 It has been reported that the adverse events identified in pediatric patients were similar to the events experienced in adults. Monitoring pediatric patients for blood pressure, weight, height, intraocular pressure, and clinical evaluation for the presence of infection, psychosocial disturbances, thromboembolism, peptic ulcers, cataracts, and osteoporosis is recommended. Specifically, pediatric patients may have a decrease in growth velocity after taking corticosteroids by any route of administration. Therefore, children should be titrated to the lowest effective dose.

Common adverse events of corticosteroids include: fluid retention, alteration in glucose tolerance, elevation in blood pressure, behavioral and mood changes, increased appetite and weight gain.2–10 Additional adverse events include: anaphylactoid reaction, anaphylaxis, angioedema, bradycardia, cardiac arrest, cardiac arrhythmias, cardiac enlargement, circulatory collapse, congestive heart failure, fat embolism, hypertension, hypertrophic cardiomyopathy in premature infants, myocardial rupture following recent myocardial infarction, pulmonary edema, syncope, tachycardia, thromboembolism, thrombophlebitis, vasculitis, acne, allergic dermatitis, cutaneous and subcutaneous atrophy, dry scalp, edema, facial erythema, hyper or hypopigmentation, impaired wound healing, increased sweating, petechiae and ecchymoses, rash, sterile abscess, striae, suppressed reactions to skin tests, thin fragile skin, thinning scalp hair, urticaria, abnormal fat deposits, decreased carbohydrate tolerance, development of Cushingoid state, hirsutism, manifestations of latent diabetes mellitus and increased requirements for insulin or oral hypoglycemic agents in diabetics, menstrual irregularities, moon faces, secondary adrenocortical and pituitary unresponsiveness (particularly in times of stress, as in trauma, surgery or illness), suppression of growth in children, potassium loss, hypokalemic alkalosis, sodium retention, abdominal distention, elevation in serum liver enzymes levels (usually reversible upon discontinuation), hepatomegaly, hiccups, malaise, nausea, pancreatitis, peptic ulcer with possible perforation and hemorrhage, ulcerative esophagitis, osteonecrosis of femoral and humeral heads, charcot-like arthropathy, loss of muscle mass, muscle weakness, osteoporosis, pathologic fracture of long bones, steroid myopathy, tendon rupture, vertebral compression fractures, arachnoiditis, convulsions, depression, emotional instability, euphoria, headache, increased intracranial pressure with papilledema (pseudo-tumor cerebri) usually following discontinuation of treatment, insomnia, meningitis, mood swings, neuritis, neuropathy, paraparesis/paraplegia, paresthesia, personality changes, sensory disturbances, vertigo, exophthalmos, glaucoma, increased intraocular pressure, posterior subcapsular cataracts, alteration in motility and number of spermatozoa.

### Flo-pred® (prednisolone acetate), Orapred ODT (prednisolone sodium phosphate)

The adverse events reported for Flo-pred® and Orapred ODT® in adult patients has been compiled from the package insert and the original FDA approval package assessing the safety of adult patients with rheumatoid arthritis.2,3,21 Common adverse events for Flo-pred and Orapred ODT have been reported in the common adverse events for corticosteroids in general (see above).2,3 Bioequivalence studies conducted in healthy volunteers assessing prednisolone oral suspension, prednisolone syrup, and prednisolone tablet were reported in the Flo-pred® original FDA approval document.21 The following adverse events were reported across 3 of these studies (see table 3).

Table H-3 Adverse Events from Flo-pred® Bioequivalence Studies21

Study # | 1 | 1 | 1 | 2 | 2 | 2 | 3 | 3 | 3
Dosage form | Suspension (n=24) | Syrup (n=24) | Tablet (n=24) | Suspension (n=24) | Syrup (n=23) | Tablet (n=24) | Suspension (n=24) | Syrup (n=23) | Tablet (n=23)
Arthralgia | 0 | 0 | 1 (4%) | 0 | 0 | 1 (4%) | 0 | 0 | 1 (4%)
Headache | 1 (4%) | 0 | 0 | 3 (13%) | 1 (4%) | 6 (25%) | 1 (4%) | 1 (4%) | 1 (4%)
Somnolence | 0 | 1 (4%) | 0 | 1 (4%) | 0 | 0 | 0 | 0 | 1 (4%)
Dyspepsia | 1 (4%) | 1 (4%) | 1 (4%) | 1 (4%) | 1 (4%) | 0 | --- | --- | ---
Fatigue | 1 (4%) | 0 | 0 | 1 (4%) | 0 | 1 (4%) | --- | --- | ---
Hot Flash | 0 | 1 (4%) | 0 | 1 (4%) | 1 (4%) | 0 | --- | --- | --
Venipuncture site pain | 1 (4%) | 0 | 1 (4%) | 0 | 1 (4%) | 0 | --- | --- | ---
Lymphocyte count increased | 2 (8%) | 2 (8%) | 2 (8%) | 1 (4%) | 1 (4%) | 1 (4%) | --- | --- | ---
Neutrophil count decreased | 1 (4%) | 1 (4%) | 1 (4%) | --- | --- | --- | 2 (8%) | 2 (9%) | 2 (9%)
Ocular hyperaemia | --- | --- | --- | 1 (4%) | 0 | 1 (4%) | 0 | 0 | 1 (4%)
Lip dry | --- | --- | --- | 1 (4%) | 1 (4%) | 0 | 0 | 0 | 1 (4%)
Nausea | --- | --- | --- | 2 (8%) | 1 (4%) | 1 (4%) | 1 (4%) | 0 | 0
Dizziness | --- | --- | --- | 1 (4%) | 1 (4%) | 0 | 0 | 1 (4%) | 0
Venipuncture site swelling | 1 (4%) | 0 | 0 | --- | --- | --- | --- | --- | ---
Blood Bilirubin increase | 1 (4%) | 1 (4%) | 1 (4%) | --- | --- | --- | --- | --- | ---
Increased appetite | 0 | 0 | 1 (4%) | --- | --- | --- | --- | --- | ---
Pharyngolaryngeal Pain | 0 | 0 | 1 (4%) | --- | --- | --- | --- | --- | ---
Blister | 1 (4%) | 0 | 0
Abdominal distension | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | ---
Abdominal pain | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | ---
Upper abdominal pain | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | ---
Diarrhea | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | --
Dry mouth | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Flatulence | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Vomiting | --- | --- | --- | 1 (4%) | 0 | 1 (4%) | --- | --- | ---
Vessel puncture site bruise | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Tremor | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Metrorrhagia | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Nasal congestion | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | ---
Rhinorrhea | --- | --- | --- | 0 | 0 | 1 (4%) | --- | --- | ---
Fixed eruption | --- | --- | --- | 1 (4%) | 0 | 0 | --- | --- | ---
Catheter site pain | --- | --- | --- | --- | --- | --- | 1 (4%) | 0 | 0
Catheter site reaction | --- | --- | --- | --- | --- | --- | 1 (4%) | 0 | 0
Shivering | --- | --- | --- | --- | --- | --- | 1 (4%) | 0 | 0
Blood potassium | --- | --- | --- | --- | --- | --- | 1 (4%) | 1 (4%) | 1 (4%)
Hypoaesthesia | --- | --- | --- | --- | --- | --- | 0 | 1 (4%) | 0

Bioavailability studies were also conducted for Orapred ODT® in 24 health patients each receiving Orapred ODT® 30mg tablet, Pediapred® oral solution 30mg and Orapred® oral solution 30mg. Adverse events reported in patients taking Oprapred ODT® included: face edema/swelling face, pharyngolaryngeal pain, blood in stool, eye irritation, and eyelid edema.

A search of the literature for adverse events associated with prednisolone was conducted by Taro Pharmaceuticals and reported in the FDA review package.21 The most common adverse events reported in 4 pediatric studies (mean age <2 years) using prednisolone 1–2 mg/kg/day (n=187) for less than 1 week included: vomiting-nausea (5%), diarrhea (3%), restlessness (2%), rash-exanthema (1%), and jittery (1%). The most common adverse events reported in 6 adult studies (mean age 40–60 years) using prednisolone 5–60 mg/day (n=189) for 2 weeks to 2 years included: vomiting-nausea (5%), rash-exanthema (5%), headache (9%), gastric distress (8%), insomnia (6%), weight gain (6%), abdominal pain (5%), mood swings (4%), aggravated RA (3%), and hypertension (3%).

#### Post-marketing Adverse Events

Data specifically from pediatric patients reported in the Orapred ODT® original FDA approval documents included: urticaria (6), dyspea (1), wheezing (2), coughing (1), congestion (1), lethargy (1), confusion (1), could not stand or hold up head (1), back pain (1), double vision (1), slurred words (1), dizziness (1), difficulty breathing (1), tremor (1), dysphemia (1), head banging (1), and leukocytosis(1).22 Serious adverse events included: depression, headache, abdominal pain and malaise which occurred in 1 patient. Four patients experienced hypersensitivity reactions: rash, swelling, itching, redness in the mouth, pain, and difficulty swallowing. Other events reported included: hyperchlesterolemia and lack of response, audea, emesis, diarrhea and bluding fontanelle, increased heart rate, psychiatric events, erythema, pruritis and rash.

### Rayos® (prednisone)

The adverse events reported for Rayos® in adult patients has been compiled from the package insert and the original FDA approval package assessing the safety of adult patients with rheumatoid arthritis.4,23

Adverse events reported for Rayos® were similar to the common adverse events for corticosteroids in general (see above)4 An additional common adverse event specifically listed in the Rayos® package insert was central serous chorioretinopathy.

The medical review document for Rayos® reported adverse events occurring in >2% of patients participating in phase 3 clinical studies.23 These patients were treated with prednisone extended release (XL) (n=375) and prednisone immediate release tablets (IR) (n=144). Adverse events included: abdominal pain upper: XL=6 (<2%), IR=8 (6%); diarrhea: XL=4 (1%), IR=4 (3%); nausea: XL=8 (2%), IR=4 (3%); dyspepsia: XL=0, IR=3 (2%); nasopharyngitis: XL=16 (4%), IR=8 (6%); bronchitis: XL=5 (1%), IR=5 (4%); upper respiratory tract infection: XL=2 (<1%), IR=3 (2%); rheumatoid arthritis: XL=48 (13%), IR=14 (10%); vertigo: XL=4 (1%), IR=5 (4%); Headache: XL=15 (4%), IR=5 (4%); and chest pain: XL=2 (<1%), IR=0. In addition, hematology reference range changes have been reported in phase 3 clinical studies (see table 4).

Table H-4 Hematology Changes23

| Prednisone XL (n=375) | Prednisone IR (n=144)
Hemoglobin (g/L)
Shift from Normal to Low | 10 (3%) | 11 (8%)
Shift from Normal to High | 1 (1%) | 0
Shift from High to Low | 1 (0%) | 0
WBC (×10^3^/mcl)
Shift from Normal to Low | 3 (1%) | 0
Shift from Normal to High | 18 (5%) | 16 (11%)
Basophils (%)
Shift from Normal to High | 11 (3%) | ---
Eosinophils (%)
Shift from Normal to High | 2 (1%) | ---
Lymphocytes (%)
Shift from Normal to Low | 32 (9%) | ---
Shift from Normal to High | 1 (0%) | ---
Monocytes (%)
Shift from Normal to Low | 23 (6%) | ---
Shift from Normal to High | 3 (1%) | ---
Shift from High to Low | 1 (0%) | ---
Neutrophils (%)
Shift from Normal to Low | 1 (0%) | ---
Shift from Normal to High | 41 (11%) | ---
Platelets (×10^3^/mcl)
Shift from Normal to Low | 1 (0%) | 1 (1%)
Shift from Normal to High | 24 (6%) | 3 (2%)

Chemistry reference range shifts from normal at baseline to high after treatment with prednisone extended release (XL) (n=375) and prednisone immediate release (IR) (n=144) in phase 3 studies included: alk phos (U/L): XL=6 (2%), IR=2 (1%); ALT/SGPT (U/L): XL=13 (4%), IR=5 (4%); AST/SGOT (U/L): XL=13 (4%), IR=7 (5%); GGT (U/L): XL=15 (4%), IR=8 (5%); bilirubin (umg/dL): XL=2 (<1%), IR=0; albumin (g/L): XL=2 (<1%), IR=0 (0%); protein (g/L): XL=3 (1%), IR=1 (<1%); cholesterol (mmol/L): XL=54 (14%), IR=15 (10%); triglycerides (mmol/L): XL=17 (5%), IR=15 (10%); BUN (mmol/L): XL=7 (2%), IR=0; creatinine (umol/L): XL=9 (2%), IR=3 (2%); glucose (mmol/L): XL=28 (8%), IR=18 (13%); calcium (mmol/L): XL=1 (<1%), IR=0; chloride (mmol/L): XL=3 (1%), IR=2 (1%); potassium (mmol/L): XL=6 (2%), IR=1 (<1%); and sodium (mmol/L): XL=8 (2%), IR=1 (<1%).23

#### Serious Adverse Events

Serious adverse events from controlled phase 3 studies reported in the FDA review document for extended release prednisone (XL) (n=375) and immediate release prednisone (IR) (n=144) include: myocardial infarction: XL=1 (<1%), IR=0; abdominal pain: XL=0, IR=1 (<1%); chest pain: XL=1 (<1%), IR=1 (<1%); sudden death: XL=0, IR=1 (<1%); tendon rupture: XL=0, IR=1 (<1%); osteoarthritis: XL=1 (<1%), IR=0; synovial cyst: XL=1 (<1%), IR = 0; squamous cell carcinoma: XL=1 (<1%), IR= 0; depressed level of consciousness: XL=0, IR=1 (<1%); pulmonary embolism: XL=0, IR=1 (<1%); hospitalization: XL=1 (<1%), IR=0; and limb operation: XL=1 (<1%), IR=0.^23^

An additional clinical trial assessing the safety of prednisone extended release was conducted in Germany and included 2676 patients in the safety analysis.23 Serious adverse events reported included: gastrointestinal disorders (5 events, <1%), general disorders and administration site conditions (4 events; <1%), injury, poisoning and procedural complications (3 events; <1%) and skin and subcutaneous disorders (3 events; <1%), GI bleeding (1 event), hemorrhagic proctitis (1 event), stomach pain/ache (1 event), and red skin (1 event).

#### Discontinuations

The following adverse events led to discontinuation in patients taking extended release prednisone (XL) (n=375) and immediate release prednisone (IR) (n=144) in phase 3 clinical trials: palpitations: XL=1 (<1%), IR=0; vertigo: XL=0, IR=1 (1%); glaucoma: XL=1 (<1%), IR=0; abdominal pain: XL=1 (<1%), IR=0; upper abdominal pain: XL=0, IR=2 (1%); constipation: XL=1 (<1%), IR=0; dyspepsia: XL=1 (<1%), IR=0; gastroesophageal reflux disease: XL=0, IR=1 (1%); intestinal functional disorder: XL=0, IR=1 (1%); nausea: XL=0, IR=2 (1%); vomiting: XL=1 (<1%), IR=0; sudden death: XL=0, IR=1 (1%); rheumatoid arthritis: XL=5 (1%), IR=2 (1%); aphasia: XL=0, IR=1 (1%); depressed level of consciousness: XL=0, IR=1 (1%); dizziness: XL=0, IR=1 (1%); headache: XL=2 (1%), IR=1 (1%); anxiety: XL=1 (<1%), IR=0; insomnia: XL=2 (1%), IR = 0; sleep disorder: XL=1 (<1%), IR=0; renal pain: XL=0, IR=1 (1%); and secondary hypertension: XL=1 (<1%), IR=0.^23^

Reasons for discontinuation in the German clinical trial (n=2676) assessing prednisone extended release included: nausea (22; 1%), upper abdominal pain (18; 1%), sleep disorders (16; 1%), RA (11; <1%), headache (9; <1%), dizziness (6; <1%) and glucose metabolism (3 patients with diabetes; <1%, and 3 patients with blood glucose increased; <1%).23

#### Post-marketing Adverse Events

Horizon Pharma completed a search of the FDA’s Spontanous Reporting system and the Adverse Event Reporting System for prednisone (date range: January 1, 1969 through March 31, 2010) and identified a total of 965,454 adverse events.23 Adverse events reported at a frequency of >0.5% included: diarrhea: 5293 (0.5%), nausea: 8419 (0.9%), vomiting: 4889 (0.5%), asthenia: 5541 (0.6%), condition aggravated: 5774 (0.6%), drug ineffective: 6078 (0.6%), fatigue: 5877 (0.6%), pyrexia: 11692 (1.2%), pneumonia: 6305 (0.7%), arthralgia: 5240 (0.5%), and dyspnea: 7570 (0.8%).

### Medrol® (methylprednisolone), Depo-Medrol® (methylprednisolone acetate), Solu-Medrol® (methylprednisolone sodium succinate)

Adverse event data for Medrol®, Depo-Medrol®, and Solu-Medrol® was gathered from the corresponding package inserts.5–7 FDA approval packages were not available for any of the methylprednisolone products.

The use of Medrol® for pediatric patients was not included in the package inert.5 The adverse events for Medrol® included all of the adverse events listed in general for corticosteroids (see above) with the addition of: negative nitrogen balance due to protein catabolism.5 The following adverse events have been reported for general corticosteroids but were [underlined: NOT] included as adverse events for Medrol®: alteration in glucose tolerance, not behavioral and mood changes, mood swings, increased appetite and weight gain, bradycardia, cardiac arrest, cardiac arrhythmias, cardiac enlargement, circulatory collapse, fat embolism, abnormal fat deposits, hypertrophic cardiomyopathy in premature infants, myocardial rupture following recent myocardial infarction, pulmonary edema, syncope, tachycardia, thromboembolism, thrombophlebitis, vasculitis, acne, cutaneous and subcutaneous atrophy, dry scalp, edema, hyper or hypopigmentation, sterile abscess, striae, thinning scalp hair, hirsutism, moon faces, hepatomegaly, hiccups, malaise, nausea, charcot-like arthropathy, arachnoiditis, depression, emotional instability, euphoria, insomnia, meningitis, neuritis, neuropathy, paraparesis/paraplegia, paresthesia, personality changes, sensory disturbances, and alteration in motility/number of spermatozoa.

Warnings for the use of Depo-Medrol® and Solu-Medrol® in pediatric patients due to the presence of benzyl alcohol have been described above (see table 1).6,7

Adverse events for Depo-Medrol® and Solu-Medrol® were similar to those listed in general for corticosteroids (see above) with the addition of: dry scaly skin, glycosuria, hypertrichosis, negative nitrogen balance due to protein catabolism, injection site infections following non-sterile administration, postinjection flare (following intra-articular use), temporary/permanent visual impairment including blindness associated with periocular injections and decreased resistance to infection.6,7

Depo-Medrol® has unique adverse events reported in addition to those listed above: calcinosis (following intra-articular or intra-lesional use), seizures, ocular and periocular inflammation including allergic reactions, and residue or slough at injection site.6

Additional adverse events reported for Solu-Medrol® included: rhinitis and burning or tingling (especially in the perineal area after intravenous injection).7

### Aristospan® (triamcinolone hexacetonide), Kenalog-10® (triamcinolone acetonide)

Aristospan® (triamcinolone hexacetonide), Kenalog-10® (triamcinolone acetonide) includes pediatric dosing in the FDA approved labeling.8,9 FDA review packages were not available for this medication. Warnings for the use of Aristospan® and Kenalog-10® in pediatric patients due to the presence of benzyl alcohol have been described above (see table 1).

Adverse events for Aristospan® and Kenalog-10® were similar to those listed in general for corticosteroids (see above) with the addition of: dry scaly skin, glucosuria, hypertrichosis, negative nitrogen balance due to protein catabolism, calcinosis (following intra-articular or intralesional use), postinjection flare (following intra-articular use), rare instances of blindness associated with periocular injections, and decreased resistance to infection.8,9 FDA medical review packages were not available for these medications.

### Celestone Soluspan® (betamethasone)

Adverse event data for Celestone Soluspan® was gathered from the package insert.10 FDA approval packages were not available for review.

Adverse events for Celestone Soluspan® were similar to those listed in general for corticosteroids (see above) with the addition of: dry scaly skin, glucosuria, hypertrichosis, negative nitrogen balance due to protein catabolism, calcinosis (following intra-articular or intralesional use), postinjection flare (following intra-articular use), rare instances of blindness associated with periocular injections, and decreased resistance to infection.10 The following adverse events have been reported for general corticosteroids but were [underlined: NOT] included as adverse events for Celestone Soluspan®: manifestations of latent diabetes mellitus and menstrual irregularities.

### Elocon® (mometasone furoate)

The use of this medication in pediatric patients (≥2 years) is recommended for less than 3 weeks.11 This medication is administered topically and pediatric patients will have an increase in the skin surface area to body mass ratio. As a result, adverse events such as HPA axis suppression, Cushing’s syndrome, adrenal insufficiency upon withdraw, skin atrophy, striae, linear growth retardation, delayed weight gain, and intracranial hypertension are more likely to occur in pediatric patients.

The adverse event data for Elocon® was obtained from the package insert.11 FDA approval packages were not available for this medication. The package insert notes that rates of adverse events may differ in clinical practice because clinical trials for Elocon® were conducted under variable conditions. In pediatric studies (n=74), 7% of patients experienced adverse events including: stinging, pruritus, and furunculosis. In a pediatric trial, 24 patients (age 6 to 23 months) used Elcon® cream for 3 weeks covering a mean body surface area of 41%. Sixteen percent of patients reported HPA axis suppression after treatment. Additional adverse events reported in pediatric (age 6 months to 2 years) trials (n=182) included: decreased glucocorticoid levels (2), paresthesia (2), folliculitis (1) moniliasis (1), bacterial infection (1), skin depigmentation (1). Ninety seven patients, participating in a clinical trial, experienced skin atrophy including: shininess (4), telangiectasia (1), loss of elasticity (4), loss of normal skin markings (4), thinness (1), and bruising (1). Adverse events that have been reported for topical corticosteroids in general include: irritation, dryness, folliculitis, hypertrichosis, acneiform eruptions, hypopigmentation, perioral dermatitis, allergic contact dermatitis, secondary infection, striae, and miliaria.

### Aldara® (imiquimod), Zyclara® (imiquimod)

Package inserts and original FDA approval packages were utilized to gather safety information for these medications.12,13,24

It has been reported that the pediatric patients applying Aldara® for molluscum contagiosum experienced application site reactions most often.12,13,25 Additional adverse events reported in these trials were similar to those reported in adult patient with the addition of: otitis media (5%) and conjunctivitis (3%). Local skin reactions reported in pediatric patients and considered severe include: erythema (28%), edema (8%), scabbing/crusting (5%), flaking/scaling (5%), erosion (2%) and weeping/exudate (2%).

The Aldara® package insert notes that rates of adverse events may differ in clinical practice because clinical trials were conducted under variable conditions.13 The following adverse events were reported in >1% of adult patients applying Aldara® to the face or scalp 2 times a week for 16 weeks for actinic keratosis (n=215): application site reaction: 71 (33%), upper respiratory tract infection: 33 (15%), sinusitis: 16 (7%), headache: 11 (5%), carcinoma squamous: 8 (4%), diarrhea: 6 (3%), eczema: 4 (2%), back pain: 3 (1%), fatigue: 3 (1%), atrial fibrillation: 3 (1%), viral infection: 3 (1%), dizziness: 3 (1%), vomiting: 3 (1%), UTI: 3 (1%), fever: 3 (1%), rigors: 3 (1%), and alopecia: 3 (1%). Specific application site reactions that were reported in >1% of adult patients taking Aldara® for actinic keratosis (n=215) included: itching: 44 (20%), burning: 13 (6%), bleeding: 7 (3%), stinging: 6 (3%), pain: 6 (3%), induration: 5 (2%), tenderness: 4 (2%), and irritation: 4 (2%). The following local skin reactions have been reported in adult patients applying Aldara® for actinic keratosis (n=215): erythema (all grades): 209 (97%), erythema (severe): 38 (18%), flaking/scaling/dryness (all grades): 199 (93%), flaking/scaling/dryness (severe): 16 (7%), scabbing/crusting (all grades): 169 (79%), scabbing/crusting (severe): 18 (8%), edema (all grades): 106 (49%), erosion/ulceration (all grades): 103 (48%), erosion/ulceration (severe): 5 (2%), weeping/exudate (all grades): 45 (22%), and vesicles (all grades): 19 (9%). Increased scarring scores were reported in 2.9% (6/206) patients with a baseline and 8-week post treatment scarring assessment.

In patients applying Aldara® for genital warts, female patients reported severe skin reactions including: erythema (3%), ulceration (2%), and edema (1%); and for males, erosion (2%), and erythema (1%), edema (1%), induration (1%), and excoriation/flaking (1%).13 The following adverse reactions were reported by >1% of patients: burning, hypopigmentation, irritation, itching, pain, rash, sensitivity, soreness, stinging, tenderness, bleeding, burning, itching, pain, tenderness, tinea cruris, fatigue, fever, influenza-like symptoms, headache, diarrhea and myalgia. Aldara® was studied in male and female patients (n=784) aged 15–77 (mean age 31.5) with genital warts. Patients applied Aldara® three times a week for 16 weeks.25 Some patients were treated for up to 32 weeks if their warts were not cleared after the initial 16 week treatment. Common adverse events reported in >2% of patients included: application site reactions 26.7%, infection 3.8%, upper respiratory infection 3.3%, headache 2.5%, fatigue 2.1%, nausea 2.1%, herpes simplex 2.1%, and myalgia 2.0%. In a similar study of male and female patients (n=943) age 16–78 (mean 31.2) with genital warts, adverse events reported in >2% of patients included: application site reactions 27.7%, infection 4.5%, headache 2.9%, respiratory infection 2.1%, and myalgia 2%.

Similar to the Aldara® package insert, Zyclara® adverse events may differ in clinical practice because clinical trials were conducted under variable conditions.12 Adult patients with actinic keratosis completing clinical trials applied Zyclara® daily for 2 weeks to their entire face or blading scalp. Treatment cycles were separated by 2 weeks of no treatment. Adverse reactions reported in clinical trials are listed below (see table 5). In addition to the adverse events included in the chart, the following events have been reported: application site bleeding, application site swelling, chills, dermatitis, herpes zoster, insomnia, lethargy, myalgia, pancytopenia, pruritus, squamous cell carcinoma, and vomiting.

Table H-5 Zyclara® Adverse Event Data

| Zyclara® 2.5% (n=160) | Zyclara® 3.75% (n=160)
Adverse Events reported in ≥2% of Patients
Headache | 3(2%) | 10(6%)
Application site pruritus | 6(4%) | 7(4%)
Fatigue | 2(1%) | 7(4%)
Nausea | 1(1%) | 6(4%)
Influenza like illness | 6(4%) | 1(<1%)
Application site irritation | 4(3%) | 5(3%)
Pyrexia | 0 | 5(3%)
Anorexia | 0 | 4(3%)
Dizziness | 1(<1%) | 4(3%)
Herpes simplex | 0 | 4(3%)
Application site pain | 2(1%) | 5(3%)
Lymphadenopathy | 4(3%) | 3(2%)
Oral herpes | 4(3%) | 0
Arthralgia | 4(3%) | 2(1%)
Cheilitis | 3(2%) | 0
Diarrhea | 2(1%) | 3(2%)
Local Skin Reactions
Erythema (Mild, moderate or severe) | 96% | 96%
Severe erythema | 14% | 25%
Scabbing/Crusting (mild, moderate or severe) | 84% | 93%
Severe scabbing/crusting | 9% | 14%
Edema (mild, moderate or severe) | 63% | 75%
Severe edema | 4% | 6%
Erosion/Ulceration (mild, moderate or severe) | 52% | 62%
Severe erosion/ulceration | 9% | 11%
Exudate (mild, moderate or severe) | 39% | 51%
Severe Exudate | 1% | 6%
Flaking/Scaling/Dryness (mild, moderate or severe): | 88% | 91%
Severe Flaking/Scaling/Dryness | 4% | 8%

An additional database review of Zyclara® (n=779) across two clinical trials, revealed the following adverse events reported in >1% of patients (see table 6).25

Tablet H-6 Common Adverse Events Reported in >1% of Patients

| Zyclara® 3.75% (n=400) | Zyclara® 2.5% (n=379)
Application site pain | 28 (7.0%) | 20 (5.3%)
Application site irritation | 24 (6.0%) | 13 (3.4%)
Nasopharyngitis | 16 (4.0%) | 21 (5.5%)
Upper respiratory tract infection | 12 (3.0%) | 7 (1.8%)
Application site pruritus | 11 (2.8%) | 17 (4.5%)
Headache | 9 (2.3%) | 8 (2.1%)
Vaginitis bacterial | 8 (2.0%) | 6 (1.6%)
Nausea | 7 (1.8%) | 4 (1.1%)
Back pain | 7 (1.8%) | 4 (1.1%)
Urinary tract infection | 6 (1.5%) | 6 (1.6%)
Sinusitis | 6 (1.5%) | 4 (1.1%)
Sinus congestion | 6 (1.5%) | 1 (0.3%)
Cough | 5 (1.3%) | 5 (1.3%)
Rash | 5 (1.3%) | 2 (0.5%)
Vomiting | 5 (1.3%) | 1 (0.3%)
Skin laceration | 5 (1.3%) | 1 (0.3%)

In patients applying Zyclara® 3.75% for genital warts (n=400) for up to 8 weeks, adverse events occurring in greater than ≥2% included: application site pain: 28 (7%), application site irritation: 24 (6%), application site pruritus: 11 (3%), vaginitis bacterial: 6/216 (3%), and headache: 6(2%). Additional local skin reactions that required medical attention, caused patients to discontinue the study or extended beyond the treatment area included: erythema (mild, moderate or severe): 70%, severe erythema: 9%, edema (mild, moderate or severe): 41%, severe edema: 2%, erosion/ulceration (mild, moderate or severe): 36%, severe erosion/ulceration: 11%, exudate (mild, moderate or severe): 34%, and severe exudate: 2%. In addition to the adverse events included above, these events have been reported: rash, back pain, application site rash, application site cellulitis, application site excoriation, application site bleeding, scrotal pain, scrotal erythema, scrotal ulcer, scrotal edema, sinusitis, nausea, pyrexia, and influenza-like symptoms.

Adverse events reported for Zyclara® from the sponsor’s clinical trial safety database include: anginal pain (angia pectoris, prinzmetal angina): 3 (Rate=0.035%), arrhythmia: 15 (Rate=0.177%), ventricular arrthythmia: 2 (Rate=0.024%), cardiac arrest: 1 (Rate=0.012%), cardiac failure: 7 (Rate=0.083%), chest pain: 12 (Rate=0.142%), dizziness: 66 (Rate=0.780%), dyspnea: 2 (Rate=0.024%), fibrillation atrial: 12 (Rate=0.142%), hypotension: 2 (Rate=0.024%), acute myocardial infarction: 3 (Rate=0.035%), palpitation: 9 (Rate=0.106%), pulmonary edema: 1 (Rate=0.012%), syncope: 7 (Rate=0.083%), tachycardia: 8 (Rate=0.095%), presyncope: 1 (Rate=0.012%), and tachycardia ventricular: 2 (Rate=0.024%).24 It is important to note that the original FDA approval document only contains data for adult patients. Across five clinical trials, patients applying the medication for 2 to 3 week cycles (n=665) experienced the following adverse events most often: headache, local site reactions, fatigue and nausea. Patients using the higher dose (3.75%) of Zyclara experienced local cite reactions more often.

Two clinical trials assessing the use of Zyclara® 2.5% and 3.75% in adult patients with actinic keratosis were submitted in the original FDA approval document.24 Patients age 36 to 90 applied the medication using one of two treatment cycles: 1) 3 weeks of treatment followed by 3 weeks of rest, 2) 3 weeks of treatment followed by 8 weeks of rest. Adverse events reported most often in patients applying Zyclara® included: application site adverse events, fatigue, headache, lymphadenopathy and influenza like illness.

#### Serious Adverse Events

Aldara® was studied in male and female patients (n=784) aged 15–77 (mean age 31.5) with genital warts. Patients applied Aldara® three times a week for 16 weeks.25 Some patients were treated for up to 32 weeks if their warts were not cleared after the initial 16 weeks. Serious adverse events reported in this study included: acute appendicititis (1), skull fracture (1), increased depression/suicide attempt (1), suicide attempt/drug overdose (1), inferior mypcardial infarction (1), pyelonephritis (1), pacemaker generator exchange (1), pancreatitis (1), cervical cancer (1), exacerbation of depression (1), incomplete abortion (1), possible infection of GI tract (1), and heroin addiction (1). In a similar study of male and female patients (n=943) age 16–78 (mean 31.2) with genital warts, 14 patients experienced serious adverse events including: alteration in speech and sensation of spaciness (1), fracture of left clavicle (1); exacerbation of eczema at non-wart site (1), rectal pain due to internal warts-remote site (1), nephrotic syndrome (1), carcinoma of vulva (1), vulval pain (with anorexia and fatigue) (1), depression (1), lymphangitis due to dog bite (1), axillary abscess (1), laryngeal cancer (1), vomiting and abdominal pain (1), cholecystectomy (1), flu (1), tonsil abscess (1), metrorrhagia (1), and act fetal distress (1).

The first clinical trial reviewed in the original FDA approval document for Zyclara® (GW01-0702) had 227 patients complete the study.24 Severe adverse events reported in patients applying the 3.75% cream included: cerebrovascular accident, gout, and atrial fibrillation. Severe adverse events reported in patients applying the 2.5% cream included: oral herpes, sinusitis, pneumonia, application site infection, bacterial pneumonia, application site irritation, pruritic rash, procedural pain, and cartilage injury. The second clinical trial (GW01-704) reported the following severe adverse events in patients applying the 3.75% cream: influenza-like illness, chest pain, diarrhea, vascular graft, and anxiety. Severe adverse events reported in patients applying the 2.75% cream included: bronchiectasis, influenza-like illness twice, cheilitis, lymphadenopathy twice, angina pectoris, atrial fibrillation, and arteriosclerosis.

Serious Adverse events reported across trials (n=160) of adult patients (mean age 64.4) applying Zyclara® 2.5% cream for 2 weeks included: atrial fibrillation (1), chest pain (1), pneumonia (2), acute myocardial infarction (1), non-cardiac chest pain (1), and ventricular tachycardia (1).24 Events reported in adult patients (n=160) applying Zyclara® 3.75% cream for 2 weeks included: cerebrovascular accident (1), atrial fibrillation (1), small intestine obstruction (1), chest pain (1), anxiety (1), and diarrhea (1).

Serious Adverse events reported across trials (n=160) of adult patients (mean age 64.7) applying Zyclara® 2.5% cream for 3 weeks included: chest pain (1), pneumonia (1), aortic valve stenosis (1), syncope (1), and bronchitis (1).24 Events reported in adult patients (n=160) applying Zyclara® 3.75% cream for 3 weeks included: pneumonia (1), breast cancer (1), surgery (1), dyspnea (1), hip fracture (1), arthralgia (1), wound infection (1), coronary artery disease (1), Non Hodgkin lymphoma (1), and pancytopenia (1).

An additional database review of Zyclara® (n=779) across two clinical trials revealed the following severe adverse events (see table 7).25

Table H-7 Severe Adverse Events Reported in Patients Applying Zyclara®

| Zyclara® 3.75% (n=400) | Zyclara® 2.5% (n=379)
Application site pain | 6 (1.5%) | 5 (1.3%)
Application site irritation | 2 (0.5%) | 3 (0.8%)
Application site reaction | 1 (0.3%) | 3 (0.8%)
Application site pruritus | 1 (0.3%) | 2 (0.5%)
Application site rash | 2 (0.5%) | 0
Application site dermatitis | 0 | 1 (0.3%)
Application site erythema | 0 | 1 (0.3%)
Application site ulcer | 0 | 1 (0.3%)
Application site vesicles | 1 (0.3%) | 0
Chest pain | 1 (0.3%) | 0
Influenza like illness | 1 (0.3%) | 0
Pelvic mass | 1 (0.3%) | 0
Infections and infestation | 3 (0.8%) | 3 (1.1%)
Nasopharyngitis | 1 (0.3%) | 1 (0.3%)
Application site infection | 0 | 1 (0.3%)
Bronchitis | 0 | 1 (0.3%)
Influenza | 1 (0.3%) | 0
Pharyngitis streptococcal | 0 | 1 (0.3%)
Vaginal infection | 1 (0.3%) | 0
Gastrointestinal disorders | 3 (0.8%) | 2 (0.5%)
Acute abdomen | 1 (0.3%) | 0
Diarrhea | 0 | 1 (0.3%)
Haemorrhoidal haemorrhage | 1 (0.3%) | 0
Haemorrhoids | 0 | 1 (0.3%)
Proctalgia | 1 (0.3%) | 0
Reproductive system and breast disorders | 4 (1.0%) | 2 (0.5%)
Scrotal erythema | 2 (0.5%) | 1 (0.3%)
Dysmenorrhea | 2 (0.5%) | 0
Vulval ulceration | 0 | 1 (0.3%)
Injury, poisoning and procedural complications | 1 (0.3%) | 1 (0.3%)
Gunshot wound | 1 (0.3%) | 0
Upper limb fracture | 0 | 1 (0.3%)
Musculoskeletal and connective tissue disorders | 0 | 1 (0.3%)
Groin pain | 0 | 1 (0.3%)
Nervous system disorders | 1 (0.3%) | 1 (0.3%)
Headache | 1 (0.3%) | 0
Migraine | 0 | 1 (0.3%)
Respiratory, thoracic and mediastinal disorders | 1 (0.3%) | 0
Dyspnea | 1 (0.3%) | 0
Iron deficiency anemia | 0 | 1 (0.3%)
Tooth extraction | 1 (0.3) | 0

#### Discontinuations

Patients utilizing Aldara® for actinic keratosis withdrew from studies or initialed rest periods most often due to application site reactions and local skin reactions.13 Specifically, 2% (5/215) of patients discontinued from clinical trials due to local skin/application site reactions. Rest periods occurred in 16% (35/215), 11% (17/160), and 7% (11/160) of patients using Aldara®, Zyclara® 3.75% and Zyclara® 2.5% cream respectively.12,13 Four out of 327 (1.2%) patients applying Aldara® and 3 out of 400 (1%) patients applying Zyclara® for genital warts reported discontinuing due to local skin/application reactions.12,13 Thirty-two percent (126/400) of patients taking Zyclara® temporarily discontinued treatment due to local skin reactions.12

Aldara® was studied in male and female patients (n=784) aged 15–77 (mean age 31.5) with genital warts. Patients applied Aldara® three times a week for 16 weeks.25 Some patients were treated for up to 32 weeks if their warts were not cleared after the initial 16 weeks. Patients discontinued due to the following adverse events: intolerable local skin reactions: burning, tenderness, itching, pain (31); flu-like symptoms (2); fatigue (1); bacterial infection at the wart site (1); urethral irritation (1); and intraepithelial vulvar neoplasia (1). In a similar study of male and female patients (n=943) age 16–78 (mean 31.2) with genital warts, 105 patients discontinued due to an adverse event including: local site reaction: burning, tenderness, itching, and pain (89); flu-like symptoms (8); headache, chills and fever (3); worsening of psoriasis (1); generalized itching (1); diarrhea (1); vaginal candidiasis (1); and fatigue (1).

Out of the 227 patients applying Zyclara® and completed the GW01-0702 trial, two withdrew from the treatment due to safety reasons: tachycardia, chest pain, hypertension, and increased tremors.24

#### Postmarking Adverse Events

Additional adverse events identified after Aldara® and Zyclara® were brought to the market include: tingling at the application site, angioedema, capillary leak syndrome, cardiac failure, cardiomyopathy, pulmonary edema, arrhythmias (tachycardia, atrial fibrillation, palpitations), chest pain, ischemia, myocardial infarction, syncope, thyroiditis, abdominal pain, decreases in red cell, white cell and platelet counts (including idiopathic thrombocytopenic purpura), lymphoma, abnormal liver function, herpes simplex, arthralgia, agitation, cerebrovascular accident, convulsions (including febrile convulsions), depression, insomnia, multiple sclerosis aggravation, paresis, suicide, dyspnea, proteinuria, dysuria, urinary retention, exfoliative dermatitis, erythema multiforme, hyper/hypo pigmentation, hypertrophic scar, and Henoch-Schönlein purpura syndrome.12,13 Post-marketing data was gathered by the sponsor in 2004 and was included in the Zyclara® original FDA approval document.24 Adverse reported include: chest pain (2), angina (1), myocardial infarction (1), tachycardia (2), syncope (2), palpitation (1), sudden death (1) (potentially due to arrhythmia), atrial fibrillation (1).

### Tenormin® (atenolol)

Tenormin® is not FDA approved for use in pediatric patients and therefore safety data in this population is not available.14 The adverse event data provided below was gathered from the Tenormin® package insert and is specific for adult hypertensive patients. Adverse events specific for patients using this medication for acute myocardial infarction was not included in this analysis.

Controlled studies in conducted in the United States and in unspecified foreign countries revealed the following adverse events associated with atenolol (n=399): bradycardia (3%), cold extremities (12%), postural hypotension (4%), leg pain (3%), dizziness (13%), vertigo (2%), light-headedness (3%), tiredness (26%); fatigue (6%), lethargy (3%), drowsiness (2%), depression (12%); dreaming (3%), diarrhea (3%), nausea (3%), wheeziness (3%), and dyspnea (6%).14

Adverse events reported for beta-adrengeric blocking agents in general include: agranulocytosis; fever, combined with aching and sore throat, laryngospasm, and respiratory distress; reversible mental depression progressing to catatonia; acute reversible syndrome characterized by disorientation of time and place; short-term memory loss; emotional lability with slightly clouded sensorium; decreased performance on neuropsychometrics; mesenteric arterial thrombosis, ischemic colitis, erythematous rash; skin rashes and/or dry eyes.14

#### Post-marketing Adverse Events

Additional adverse events revealed during post-marketing surveillance include: dry mouth, headache, elevated liver enzymes and/or bilirubin, hallucinations, impotence, purpura, reversible alopecia, Peyronie’s disease, postural hypotension which may be associated with syncope, psoriasiform rash or exacerbation of psoriasis, psychoses, thrombocytopenia, visual disturbance, sick sinus syndrome, development of antinuclear antibodies (ANA), lupus syndrome, and Raynaud’s phenomenon.14

### Timoptic® (timolol maleate), Timoptic-XE® (timolol maleate), Betimol® (timolol)

Timoptic®, Timoptic-XE®, and Betimol® are not FDA approved for use in pediatric patients and therefore safety data in this population is not available.15–17 The adverse event data provided below is gathered from the package inserts for these medications and is specific for adult patients. These medications are ophthalmic preparations and therefore many of the common adverse events are associated with the ophthalmic route of administration. One in eight patients reported stinging and burning after administration of all three of these medications.15–17

In patients taking Timoptic-XE®, one in three patients, in clinical trials, experienced blurred vision upon drop administration lasting 30 seconds to 5 minutes.16 One in eight patients reported stinging and burning after use. Additional adverse events reported in 1–5% of patients included: pain, conjunctivitis, discharge (e.g., crusting), foreign body sensation, itching and tearing, headache, dizziness, and upper respiratory infections.

In patients taking Betimol® 0.25% or 0.5%, adverse events that occurred more than 5% in two controlled clinical studies (n=184 patients) included: dry eyes, itching, foreign body sensation, discomfort in the eye, eyelid erythema, conjunctival injection, and headache.17 Adverse events occurring at a frequency of 1–5% included: eye pain, epiphora, photophobia, blurred or abnormal vision, corneal fluorescein staining, keratitis, blepharitis and cataract, allergic reaction, asthenia, common cold and pain in extremities, hypertension, nausea, peripheral edema, dizziness, dry mouth, respiratory infection and sinusitis. Additional adverse events reported in ophthalmic use of beta-blockers include: blepharoptosis, retinal vascular disorder, bronchospasm.

The following adverse events were reported in the package inserts of both Timpotic® and Timoptic-XE®: headache; asthenia/fatigue; arrhythmia; hypertension; worsening of angina pectoris; pulmonary edema; edema; claudication; Raynaud’s phenomenon; cold hands and feet; nausea; dyspepsia; anorexia; dry mouth; systemic lupus erythematosus; dizziness; somnolence; insomnia; nightmares; behavioral changes and psychic disturbances including confusion, hallucinations, anxiety, disorientation, nervousness, and memory loss; alopecia and psoriasiform rash or exacerbation of psoriasis; signs and symptoms of systemic allergic reactions, including anaphylaxis, and angioedema; cough and upper respiratory infections; signs and symptoms of ocular irritation including blepharitis, keratitis, ocular pain, discharge (e.g., crusting), foreign body sensation, itching and tearing, and dry eyes; ptosis; cystoid macular edema; visual disturbances including refractive changes and diplopia; pseudopemphigoid; choroidal detachment following filtration surgery; tinnitus; retroperitoneal fibrosis; decreased libido; and Peyronie’s disease.15,16

Adverse events reported for Betimol®, Timpotic®, Timoptic-XE® included: conjunctivitis, decreased corneal sensitivity, visual disturbances including refractive changes and diplopia, chest pain, arrhythmia, palpitation, bradycardia, hypotension, syncope, heart block, cerebral vascular accident, cerebral ischemia, cardiac failure, cardiac arrest, masked symptoms of hypoglycemia in diabetic patients, diarrhea, depression, impotence, increase in signs and symptoms of myasthenia gravis and paresthesia, dyspnea, bronchospasm (predominantly in patients with preexisting bronchospastic disease), respiratory failure, nasal congestion; alopecia, urticaria, and localized/generalized rash.15–17

Adverse events reported for oral timolol and oral beta-blocking agents that could be considered potential adverse events for ophthalmic timolol include: erythematous rash; fever combined with aching and sore throat; laryngospasm with respiratory distress; extremity pain; decreased exercise tolerance; weight loss; worsening of arterial insufficiency; vasodilatation; gastrointestinal pain; hepatomegaly; vomiting; mesenteric arterial thrombosis; ischemic colitis; nonthrombocytopenic purpura; thrombocytopenic purpura; agranulocytosis; hyperglycemia; hypoglycemia; pruritus; skin irritation; increased pigmentation; sweating; arthralgia; vertigo; local weakness; diminished concentration; reversible mental depression progressing to catatonia; an acute reversible syndrome characterized by disorientation for time and place; emotional lability; slightly clouded sensorium; and decreased performance on neuropsychometrics; rales; bronchial obstruction; urination difficulties.15,16

## References

1 Hemangeol [package insert]. Parsippany, NJ. Pierre Fabre Pharmaceuticals, Inc. March. 2014.
2 Flo-Pred [package insert]. Hawthorne, NY. Taro Pharmaceuticals U.S.A., Inc. June. 2011.
3 Orapred ODT [package insert]. Bridgetown, Barbados. Concordia Pharmaceuticals Inc. July. 2013.
4 Rayos [package insert]. Deerfield, IL. Horizon Pharma Inc. February. 2014.
5 Medrol [package insert]. New York, NY. Pharmacia and Upjohn Company. June. 2013.
6 Depo-Medrol [package insert]. New York, NY. Pharmacia and Upjohn Co. July. 2014.
7 Solu-Medrol [package insert]. New York, NY. Pharmacia & Upjohn Co. July. 2014.
8 Aristospan [package insert]. Princeton, NJ. Sandoz Inc. April. 2014.
9 Kenalog-10 [package insert]. Princeton, NJ. Bristol-Myers Squibb Company. July. 2014.
10 Celestone Soluspan [package insert]. Whitehouse Station, NJ. Merck Sharp Dohme. February. 2015.
11 Elocon [package insert]. Whitehouse Station, NJ. Merck Sharp & Dohme Corp. 2012.
12 Zyclara [package insert]. Bridgewater, NJ. Valeant Pharmaceuticals North America LLC. August. 2014.
13 Aldara [package insert]. Bridgewater, NJ. Valeant Pharmaceuticals North America LLC. August. 2014.
14 Tenormin [package insert]. Wilmington, DE. AstraZeneca Pharmaceuticals LP. October. 2012.
15 Timoptic [package insert]. Lawrenceville, NJ. Aton Pharma. May. 2009.
16 Timoptic-XE [package insert]. Lawrenceville, NJ. Aton Pharma. May. 2009.
17 Betimol [package insert]. Lake Forest, IL. Oak Pharmaceutical. February. 2014.
18 Propranolol Hydrochloride Solution [package insert]. Columbus, OH. Roxane Laboratories, Inc. January. 2012.
19 Inderal LA [package insert]. Cranford, NJ. Akrimax Pharmaceuticals, LLC. June. 2012.
20 Propranolol Hydrochloride Tablet [package insert]. Eatontown, NJ. Heritage Pharmaceuticals Inc. September. 2013.
21 Flo-Pred Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2008.
22 Orapred ODT Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2006.
23 Rayos Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2012.
24 Zyclara Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2010.
25 Zyclara Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2011.