# Quality/Risk of Bias Ratings

Table F-1 Quality assessment of randomized controlled trials

Author, Year | Allocation Sequence Generated Adequately | Allocation Treatment Adequately Concealed | Participants Analyzed In Groups Originally Assigned | Design Account for Confounding | Rule Out Impact from Concurrent Intervention or Unintended Exposure | Fidelity Maintained to Intervention Protocol | If Attrition, Were Missing Data Handled Appropriately | Difference in Length of Follow-up Between Groups | Outcome Assessors Blinded | Interventions/Exposures Assessed Clearly | Outcomes Assessed Clearly | Potential Outcomes Prespecified | All Prespecified Outcomes Reported | Risk of Bias Rating for Outcome
Leaute-Labreze 2015^1^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Good
Tawfik 2015^2^ | Unclear | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Fair
Abarzua-Araya 2014^3^ | Unclear | Unclear | Yes | No | No | Unclear | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Bauman 2014^4^ | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | Yes | Yes | Yes | Yes | Good
Chan 2013^5^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Good
Kessels 2013^6^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes | Good
Leaute-Labreze 2013^7^ | Yes | Unclear | Yes | No | Unclear | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Malik 2013^8^ | Yes | Unclear | Yes | No | Yes | Yes | Unclear | No | Yes | Yes | Yes | Yes | Yes | Fair
Zaher 2013^9^ | Unclear | Unclear | yes | No | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Fair
Hogeling 2011^10^ | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes | Unclear | Yes | Yes | Good
Pandey 2010^11^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | No | Unclear | Yes | Yes | Yes | Yes | Fair
Pope 2007^12^ | Yes | Yes | Yes | Yes | Unclear | No | Yes | No | Yes | Yes | Yes | Yes | Yes | Good
Jalil 2006^13^ | Unclear | No | Yes | Unclear | Unclear | Unclear | Yes | No | Unclear | Yes | Yes | Yes | Yes | Poor
Kono 2006^14^ | Unclear | Unclear | Yes | Yes | Yes | Unclear | Yes | No | Yes | Yes | No | Yes | Yes | Fair
Batta 2002^15^ | Yes | Yes | Yes | Yes | Unclear | No | Yes | No | No | Yes | Yes | Yes | Yes | Fair

Table F-2 Quality assessment of cohort studies

Author, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts | Assessment of outcome | Follow-up long enough | Adequacy of follow-up of cohorts | Quality Rating
Goelz 2014^16^ | Selected group | Drawn from same community | No description | Yes | Cohorts not comparable | No description | Yes | Complete follow-up | Poor
Hoornweg 2014^17^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for age | Record linkage | Yes | Follow up rate less than 80% and no description of those lost | Fair
Park 2014^18^ | Somewhat representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | Record linkage | Yes | Complete follow-up | Poor
Perkins 2014^19^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for age | Record linkage | Yes | Complete follow-up | Fair
Ryzhevskiy 2014^20^ | Truly representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | No description | Yes | Complete follow-up | Poor
de Graaf 2013^21–23^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for age | Independent blind assessment | Yes | Complete follow-up | Good
Pope 2013^24^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for other factors | Independent blind assessment | No | No statement | Poor
Qiu 2013^25^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for other factors | Record linkage | Yes | Complete follow-up | Fair
Reddy 2013^26^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for other factors | Independent blind assessment | Yes | Complete follow-up | Fair
Sondhi 2013^27^ | Truly representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias | Fair
Yu 2013^28^ | Truly representative | Drawn from same community | No description | Yes | Controls for age | No description | Yes | Complete follow-up | Poor
Chambers 2012^29^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for age | Independent blind assessment | Yes | Complete follow-up | Fair
Pope 2012^24^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for other factors | Independent blind assessment | No | No statement | Poor
Rossler 2012^30, 31^ | No description of the derivation of cohort | No description of derivation of non-exposed cohort | Secure record | Yes | Cohorts not comparable | Record linkage | No | Complete follow-up | Poor
Tay 2012^32^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for age | Record linkage | Yes | Complete follow-up | Fair
Thayal 2012^33^ | Somewhat representative | No description of derivation of non-exposed cohort | Secure record | Yes | Cohorts not comparable | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias | Poor
Awadein 2011^34^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for age | Independent blind assessment | No | Complete follow-up | Fair
Bertrand 2011^35^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for age | Independent blind assessment | Yes | Complete follow-up | Fair
Hermans 2011^36^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for other factors | Record linkage | Yes | Complete follow-up | Fair
Price 2011^37^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for other factors | Record linkage | Yes | Complete follow-up | Fair
Nicolai 2005^38^ | Truly representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | Self report | Yes | Subjects lost to follow up unlikely to introduce bias | Poor
Vlachakis 2004^39^ | Truly representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | Record linkage | Yes | Complete follow-up | Fair
Akyuz 2001^40^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for age | Record linkage | Yes | Complete follow-up | Fair
Chang 2001^41^ | No description of the derivation of cohort | Drawn from same community | Secure record | Yes | Cohorts not comparable | Independent blind assessment | Yes | Complete follow-up | Poor
Raulin 2001^42^ | No description of the derivation of cohort | Drawn from same community | Secure record | Yes | Cohorts not comparable | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias | Poor
Achauer 1997^43^ | Truly representative | Drawn from same community | Secure record | Yes | Cohorts not comparable | Record linkage | No | Complete follow-up | Poor
Achauer 1989^44^ | Selected group | Drawn from same community | Secure record | Yes | Cohorts not comparable | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias | Poor

Table F-3 Quality assessment of studies reporting harms

Author, Year | Were the harms predefined using standardized or precise definitions? | Were all pre-specified harms reported? | Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? | Were the statistical methods used to assess the main harm or adverse event outcomes adequate? | Rating
Chen 2015^45^ | Partial | Unclear | Partial | Yes | Poor
Chen 2015^46^ | No | Unclear | Unclear | Yes | Poor
Leaute-Labreze 2015^1^ | Yes | Yes | Yes | Yes | Good
Raphael 2015^47^ | Partial | Unclear | Partial | Yes | Poor
Tawfik 2015^2^ | Partial | Unclear | Partial | Yes | Poor
Xu 2015^48^ | Partial | Unclear | Partial | No | Poor
Abarzua-Araya 2014^3^ | Partial | Unclear | Partial | Yes | Poor
Andersen 2014^49^ | Unclear | Unclear | Unclear | Yes | Poor
Bauman 2014^4^ | Yes | Yes | Yes | Yes | Good
Chai 2014^50^ | Partial | Unclear | Partial | Yes | Poor
Chen 2014^51^ | Yes | Yes | Unclear | Yes | Fair
Chu 2014^52^ | Partial | Unclear | Partial | Yes | Poor
Couto 2014^53^ | No | Unclear | No | No | Poor
El Ezzi 2014^54^ | Partial | Unclear | Partial | Yes | Poor
Giachetti 2014^55^ | Partial | Unclear | Partial | Yes | Poor
Goelz 2014^16^ | No | Unclear | No | Yes | Poor
Hassan 2014^56^ | Partial | Unclear | Partial | Yes | Poor
Hoornweg 2014^17^ | Partial | Unclear | Unclear | Yes | Poor
Jian 2014^57^ | Partial | Unclear | No | Yes | Poor
Kaune 2014^58^ | Yes | Unclear | Unclear | Yes | Poor
Ke 2014^59^ | No | Unclear | Unclear | No | Poor
Kwon 2014^60^ | Yes | Yes | Yes | Yes | Good
Lynch 2014^61^ | Partial | Unclear | Unclear | No | Poor
Martinez Roca 2014^62^ | Partial | Unclear | Partial | Yes | Poor
May 2014^63^ | No | Unclear | No | Yes | Poor
Muzaffar 2014^64^ | Partial | Unclear | Partial | Yes | Poor
Park 2014^18^ | No | Unclear | Unclear | No | Poor
Park 2014^65^ | Partial | Unclear | Partial | Yes | Poor
Sagi 2014^66^ | Partial | Unclear | Partial | No | Poor
Schneider 2014^67^ | Partial | Unclear | Partial | Yes | Poor
Schneider 2014^68^ | Partial | Unclear | Partial | No | Poor
Solman 2014^69^ | Partial | Unclear | Partial | Yes | Poor
Su 2014^70^ | No | Unclear | Unclear | Yes | Poor
Szychta 2014^71^ | No | Unclear | Unclear | Yes | Poor
Bonifazi 2013^72^ | No | Unclear | Unclear | Yes | Poor
Chan 2013^5^ | Yes | Yes | Yes | Yes | Good
de Graaf 2013^21–23^ | Unclear | Unclear | Unclear | Yes | Poor
Gan 2013^73^ | Partial | Unclear | Partial | No | Poor
Hermans 2013^74^ | Partial | Unclear | Partial | Yes | Poor
Hong 2013^75^ | Partial | Unclear | Partial | Yes | Poor
Kessels 2013^6^ | No | Unclear | Unclear | Yes | Poor
Leaute-Labreze 2013^7^ | Partial | Unclear | Partial | No | Poor
Liu 2013^76^ | Partial | Unclear | Partial | Yes | Poor
Ma 2013^77^ | Yes | Yes | Yes | Yes | Good
Malik 2013^8^ | No | Unclear | Unclear | Yes | Poor
Puttgen 2013^78^ | Yes | Yes | Yes | Yes | Good
Qiu 2013^25^ | Yes | Yes | Yes | Yes | Good
Reddy 2013^26^ | No | Unclear | Unclear | Yes | Poor
Sadykov 2013^79, 80^ | Partial | Unclear | Partial | Yes | Poor
Semkova 2013^81^ | No | Unclear | No | Yes | Poor
Sondhi 2013^27^ | Partial | Unclear | Partial | Yes | Poor
Vercellino 2013^82^ | Unclear | Unclear | Unclear | Yes | Poor
Xiao 2013^83^ | Partial | Unclear | Partial | Yes | Poor
Yu 2013^28^ | Unclear | Unclear | Unclear | Yes | Poor
Yuan 2013^84^ | Unclear | Unclear | Unclear | Yes | Poor
Zaher 2013^9^ | Partial | Unclear | Partial | Yes | Poor
Balma-Mena 2012^85^ | No | Unclear | Unclear | Yes | Poor
Bertrand 2012^86^ | No | Unclear | Unclear | Yes | Poor
Celik 2012^87^ | Partial | Unclear | Partial | Yes | Poor
Chakkittakandiyil 2012^88^ | No | Unclear | Unclear | Yes | Poor
Chambers 2012^29^ | No | Unclear | Unclear | Yes | Poor
Georgountzou 2012^89^ | Partial | Unclear | Partial | Yes | Poor
Janmohamed 2012^90^ | No | Unclear | Unclear | Yes | Poor
Kunzi-Rapp 2012^91^ | Partial | Unclear | Partial | Yes | Poor
Lv 2012^92^ | Partial | Unclear | Partial | Yes | Poor
Phillips 2012^93^ | No | Unclear | No | Yes | Poor
Pope 2012^24^ | Unclear | Unclear | Unclear | Yes | Poor
Samimi 2012^94^ | Unclear | Unclear | Unclear | Yes | Poor
Talaat 2012^95^ | Partial | Unclear | Partial | Yes | Poor
Tay 2012^32^ | No | Unclear | Unclear | Yes | Poor
Thayal 2012^33^ | Partial | Unclear | Partial | Unclear | Poor
Wang 2012^96^ | Partial | Unclear | Partial | Yes | Poor
Xu 2012^97^ | Yes | Yes | Yes | Yes | Good
Zegpi-Trueba 2012^98^ | Unclear | Unclear | Unclear | Yes | Poor
Awadein 2011^34^ | No | Unclear | Unclear | Yes | Poor
Bertrand 2011^35^ | No | Unclear | Unclear | Yes | Poor
Blatt 2011^99^ | No | Unclear | Unclear | Yes | Poor
Chang 2011^100^ | Unclear | Unclear | Unclear | Yes | Poor
Cushing 2011^101^ | Yes | Yes | Yes | Unclear | Fair
Daramola 2011^102^ | No | Unclear | Unclear | Yes | Poor
Di Maio 2011^103^ | Yes | Yes | Yes | No | Fair
Fuchsmann 2011^104^ | Yes | Yes | Yes | Yes | Good
Greene 2011^105^ | No | Unclear | Unclear | Yes | Poor
Hermans 2011^36^ | No | Unclear | Unclear | Yes | Poor
Hogeling 2011^10^ | Partial | Unclear | Partial | Yes | Poor
Holmes 2011^106^ | Partial | Unclear | Partial | Yes | Poor
Kulbersh 2011^107^ | No | Unclear | Unclear | Yes | Poor
Li 2011^108^ | No | Unclear | Unclear | Yes | Poor
Price 2011^37^ | No | Unclear | Unclear | Yes | Poor
Rossler 2011^30, 31^ | Partial | Unclear | Partial | Yes | Poor
Saint-Jean 2011^109^ | Partial | Unclear | Partial | Yes | Poor
Schiestl 2011^110^ | Partial | Unclear | Partial | Yes | Poor
Schupp 2011^111^ | Partial | Unclear | Partial | Yes | Poor
Snir 2011^112^ | Partial | Unclear | Partial | Yes | Poor
Zaher 2011^113^ | Partial | Unclear | Partial | Unclear | Poor
Zvulunov 2011^114^ | No | Unclear | No | Yes | Poor
Arneja 2010^115^ | No | Unclear | No | Yes | Poor
Hamou 2010^116^ | No | Unclear | No | Yes | Poor
Li 2010^117^ | No | Unclear | Unclear | No | Poor
Manunza 2010^118^ | Partial | Unclear | Partial | Unclear | Poor
Pandey 2010^11^ | No | Unclear | Unclear | Yes | Poor
Chen 2009^119^ | No | Unclear | Unclear | Yes | Poor
Pandey 2009^120^ | No | Unclear | Unclear | Yes | Poor
Rizzo 2009^121^ | No | Unclear | No | Yes | Poor
Saleh 2009^122^ | No | Unclear | No | No | Poor
Sans 2009^123^ | Partial | Unclear | Partial | Yes | Poor
Wu 2009^124^ | No | Unclear | No | Yes | Poor
Chantharatanapiboon 2008^125^ | No | Unclear | Unclear | Yes | Poor
Chen 2008^126^ | No | Unclear | Unclear | Yes | Poor
Claude 2008^127^ | No | Unclear | Unclear | Yes | Poor
Baraldini 2007^128^ | No | Unclear | Unclear | Yes | Poor
Pope 2007^12^ | Yes | Yes | Yes | Yes | Good
Jalil 2006^13^ | Yes | Yes | Yes | Yes | Good
Kono 2006^14^ | Unclear | Unclear | Unclear | Yes | Poor
Garzon 2005^129^ | No | Unclear | No | No | Poor
McHeik 2005^130^ | No | Unclear | No | Yes | Poor
Nicolai 2005^38^ | No | Unclear | Unclear | Yes | Poor
Waldschmidt 2005^131^ | No | Unclear | Unclear | Yes | Poor
Vlachakis 2004^39^ | No | Unclear | Unclear | Unclear | Poor
David 2003^132^ | No | Unclear | Unclear | Unclear | Poor
Vlachakis 2003^133^ | No | Unclear | No | Yes | Poor
Batta 2002^15^ | Yes | Yes | Yes | Yes | Good
Akyuz 2001^40^ | No | Unclear | Unclear | Unclear | Poor
Chang 2001^41^ | No | Unclear | Unclear | Unclear | Poor
Demiri 2001^134^ | No | Unclear | Unclear | Yes | Poor
Hohenleutner 2001^135^ | Unclear | Unclear | Unclear | No | Poor
Raulin 2001^42^ | Yes | Yes | Yes | Yes | Good
Chen 2000^136^ | No | Unclear | No | Yes | Poor
Poetke 2000^137^ | No | Unclear | Unclear | Yes | Poor
Blei 1999^138^ | Partial | Unclear | Partial | Yes | Poor
Boon 1999^139^ | No | Unclear | Unclear | Yes | Poor
Zide 1997^140^ | No | Unclear | Unclear | Yes | Poor
Gangopadhyay 1996^141^ | No | Unclear | Unclear | Yes | Poor
Sadan 1996^142^ | No | Unclear | Unclear | Yes | Poor
Chowdri 1994^143^ | No | Unclear | No | Yes | Poor
Morelli 1994^144^ | No | Unclear | Unclear | Yes | Poor
Preeyanont 1994^145^ | No | Unclear | No | No | Poor
Morrell 1991^146^ | No | Unclear | No | Yes | Poor
Kushner 1990^147^ | No | Unclear | No | Yes | Poor
Achauer 1989^44^ | Yes | Yes | Yes | Yes | Good
Sloan 1989^148^ | No | Unclear | No | Yes | Poor
Kushner 1985^149^ | No | Unclear | No | No | Poor
Healy 1984^150^ | No | Unclear | No | Yes | Poor
Sharma 1983^151^ | No | Unclear | Unclear | Yes | Poor

## References

1 Léauté-Labrèze C, Hoeger P, Mazereeuw-Hautier J, et al. A Randomized, Controlled Trial of Oral Propranolol in Infantile Hemangioma. New England Journal of Medicine. 2015;372(8):735-46. [pmid: 25693013].
2 Tawfik AA, Alsharnoubi J. Topical Timolol Solution Versus Laser in Treatment of Infantile Hemangioma: A Comparative Study. Pediatr Dermatol. 2015. Mar. 5. [pmid: 25740672].
3 Abarzua-Araya A, Navarrete-Dechent CP, Heusser F, et al. Atenolol versus propranolol for the treatment of infantile hemangiomas: a randomized controlled study. J Am Acad Dermatol. Jun. 2014;70(6):1045-9. [pmid: 24656727].
4 Bauman NM, McCarter RJ, Guzzetta PC, et al. Propranolol vs prednisolone for symptomatic proliferating infantile hemangiomas: a randomized clinical trial. JAMA Otolaryngol Head Neck Surg. Apr. 2014;140(4):323-30. [pmid: 24526257].
5 Chan H, McKay C, Adams S, et al. RCT of timolol maleate gel for superficial infantile hemangiomas in 5- to 24-week-olds. Pediatrics. Jun. 2013;131(6):e1739-47. [pmid: 23650294].
6 Kessels JP, Hamers ET, Ostertag JU. Superficial hemangioma: pulsed dye laser versus wait-and-see. Dermatol Surg. Mar. 2013;39(3 Pt 1):414-21. [pmid: 23279058].
7 Leaute-Labreze C, Dumas de la Roque E, Nacka F, et al. Double-blind randomized pilot trial evaluating the efficacy of oral propranolol on infantile haemangiomas in infants < 4 months of age. Br J Dermatol. Jul. 2013;169(1):181-3. [pmid: 23301692].
8 Malik MA, Menon P, Rao KL, et al. Effect of propranolol vs prednisolone vs propranolol with prednisolone in the management of infantile hemangioma: a randomized controlled study. J Pediatr Surg. Dec. 2013;48(12):2453-9. [pmid: 24314186].
9 Zaher H, Rasheed H, Esmat S, et al. Propranolol and infantile hemangiomas: different routes of administration, a randomized clinical trial. Eur J Dermatol. Sep–Oct. 2013;23(5):646-52. [pmid: 24135427].
10 Hogeling M, Adams S, Wargon O. A randomized controlled trial of propranolol for infantile hemangiomas. Pediatrics. Aug. 2011;128(2):e259-66. [pmid: 21788220].
11 Pandey A, Gangopadhyay AN, Sharma SP, et al. Evaluation of topical steroids in the treatment of superficial hemangioma. Skinmed. Jan–Feb. 2010;8(1):9-11. [pmid: 20839418].
12 Pope E, Krafchik BR, Macarthur C, et al. Oral versus high-dose pulse corticosteroids for problematic infantile hemangiomas: a randomized, controlled trial. Pediatrics. Jun. 2007;119(6):e1239-47. [pmid: 17485449].
13 Jalil S, Akhtar J, Ahmed S. Corticosteroids therapy in the management of infantile cutaneous hemangiomas. J Coll Physicians Surg Pak. Oct. 2006;16(10):662-5. [pmid: 17007757].
14 Kono T, Sakurai H, Groff WF, et al. Comparison study of a traditional pulsed dye laser versus a long-pulsed dye laser in the treatment of early childhood hemangiomas. Lasers Surg Med. Feb. 2006;38(2):112-5. [pmid: 16374781].
15 Batta K, Goodyear HM, Moss C, et al. Randomised controlled study of early pulsed dye laser treatment of uncomplicated childhood haemangiomas: results of a 1-year analysis. Lancet. Aug. 17. 2002;360(9332):521-7. [pmid: 12241656].
16 Goelz R, Moll M, Meisner C, et al. Prospective controlled study to evaluate cryocontact therapy for infantile haemangioma in preterm infants. Arch Dis Child Fetal Neonatal Ed. Jul. 2014;99(4):F345-6. [pmid: 24668831].
17 Hoornweg MJ, Saeed P, Tanck MW, et al. Comparison of intralesional corticosteroid and propranolol treatment of periorbital infantile hemangiomas: an outcome study of 61 cases. Eur J Ophthalmol. Nov–Dec. 2014;24(6):940-7. [pmid: 24729139].
18 Park KH, Jang YH, Chung HY, et al. Topical timolol maleate 0.5% for infantile hemangioma; it’s effectiveness and/or adjunctive pulsed dye laser - single center experience of 102 cases in Korea. J Dermatolog Treat. Dec. 2014;29:1-3. [pmid: 25424048].
19 Perkins JA, Chen BS, Saltzman B, et al. Propranolol therapy for reducing the number of nasal infantile hemangioma invasive procedures. JAMA Otolaryngol Head Neck Surg. Mar. 2014;140(3):220-7. [pmid: 24557492].
20 Ryzhevskiy DV, Trubin VV, Durnovo EA. The use of selective photothermolysis with sclerosing to treat congenital and neonatal vascular maxillofacial hyperplasia in children. Sovremennye Tehnologii v Medicine. 2014;6(4):145-9.
21 de Graaf M, Raphael MF, Breugem CC, et al. Treatment of infantile haemangiomas with atenolol: comparison with a historical propranolol group. J Plast Reconstr Aesthet Surg. Dec. 2013;66(12):1732-40. [pmid: 24011909].
22 De Graaf M, Araphael M, Breugem C, et al. Treatment of infantile hemangiomas with atenolol or propranolol: Cohort study with historical control group. European Journal of Pediatric Dermatology. March. 2012;22(1):12.
23 de Graaf M, Breur JM, Raphael MF, et al. Adverse effects of propranolol when used in the treatment of hemangiomas: a case series of 28 infants. J Am Acad Dermatol. Aug. 2011;65(2):320-7. [pmid: 21601311].
24 Pope E, Chakkittakandiyil A, Lara-Corrales I, et al. Expanding the therapeutic repertoire of infantile haemangiomas: cohort-blinded study of oral nadolol compared with propranolol. Br J Dermatol. Jan. 2013;168(1):222-4. [pmid: 22762503].
25 Qiu Y, Ma G, Yang J, et al. Imiquimod 5% cream versus timolol 0.5% ophthalmic solution for treating superficial proliferating infantile haemangiomas: a retrospective study. Clin Exp Dermatol. Dec. 2013;38(8):845-50. [pmid: 23627540].
26 Reddy KK, Blei F, Brauer JA, et al. Retrospective study of the treatment of infantile hemangiomas using a combination of propranolol and pulsed dye laser. Dermatol Surg. Jun. 2013;39(6):923-33. [pmid: 23458381].
27 Sondhi V, Patnaik SK. Propranolol for infantile hemangioma (PINCH): an open-label trial to assess the efficacy of propranolol for treating infantile hemangiomas and for determining the decline in heart rate to predict response to propranolol. J Pediatr Hematol Oncol. Oct. 2013;35(7):493-9. [pmid: 23929318].
28 Yu L, Li S, Su B, et al. Treatment of superficial infantile hemangiomas with timolol: Evaluation of short-term efficacy and safety in infants. Exp Ther Med. August. 2013;6(2):388-90. [pmid: 24137194].
29 Chambers CB, Katowitz WR, Katowitz JA, et al. A controlled study of topical 0.25% timolol maleate gel for the treatment of cutaneous infantile capillary hemangiomas. Ophthal Plast Reconstr Surg. Mar–Apr. 2012;28(2):103-6. [pmid: 22410658].
30 Rossler J, Schill T, Bahr A, et al. Propranolol for proliferating infantile haemangioma is superior to corticosteroid therapy--a retrospective, single centre study. J Eur Acad Dermatol Venereol. Sep. 2012;26(9):1173-5. [pmid: 22035186].
31 Rossler J, Wehl G, Niemeyer CM. Evaluating systemic prednisone therapy for proliferating haemangioma in infancy. Eur J Pediatr. Jul. 2008;167(7):813-5. [pmid: 17676341].
32 Tay YK, Tan SK. Treatment of infantile hemangiomas with the 595-nm pulsed dye laser using different pulse widths in an Asian population. Lasers Surg Med. Feb. 2012;44(2):93-6. [pmid: 22241650].
33 Thayal PK, Bhandari PS, Sarin YK. Comparison of efficacy of intralesional bleomycin and oral propanolol in management of hemangiomas. Plast Reconstr Surg. Apr. 2012;129(4):733e-5e. [pmid: 22456397].
34 Awadein A, Fakhry MA. Evaluation of intralesional propranolol for periocular capillary hemangioma. Clin Ophthalmol. 2011;5(1):1135-40. [pmid: 21887095].
35 Bertrand J, McCuaig C, Dubois J, et al. Propranolol versus prednisone in the treatment of infantile hemangiomas: a retrospective comparative study. Pediatr Dermatol. Nov–Dec. 2011;28(6):649-54. [pmid: 21995756].
36 Hermans DJ, van Beynum IM, Schultze Kool LJ, et al. Propranolol, a very promising treatment for ulceration in infantile hemangiomas: a study of 20 cases with matched historical controls. J Am Acad Dermatol. May. 2011;64(5):833-8. [pmid: 21353329].
37 Price CJ, Lattouf C, Baum B, et al. Propranolol vs corticosteroids for infantile hemangiomas: a multicenter retrospective analysis. Arch Dermatol. Dec. 2011;147(12):1371-6. [pmid: 21844428].
38 Nicolai T, Fischer-Truestedt C, Reiter K, et al. Subglottic hemangioma: a comparison of CO2 laser, Neodym-Yag laser, and tracheostomy. Pediatr Pulmonol. Mar. 2005;39(3):233-7. [pmid: 15635618].
39 Vlachakis I, Arbiros I, Velaoras K, et al. Different modes cooling the epidermis with ice during Nd:YAG laser treatment of hemangiomas in children. Med Laser Appl. May. 2004;19(1):19-23.
40 Akyuz C, Yaris N, Kutluk MT, et al. Management of cutaneous hemangiomas: a retrospective analysis of 1109 cases and comparison of conventional dose prednisolone with high-dose methylprednisolone therapy. Pediatr Hematol Oncol. Jan–Feb. 2001;18(1):47-55. [pmid: 11205840].
41 Chang CJ, Kelly KM, Nelson JS. Cryogen spray cooling and pulsed dye laser treatment of cutaneous hemangiomas. Ann Plast Surg. Jun. 2001;46(6):577-83. [pmid: 11405354].
42 Raulin C, Greve B. Retrospective clinical comparison of hemangioma treatment by flashlamp-pumped (585 nm) and frequency-doubled Nd:YAG (532 nm) lasers. Lasers Surg Med. 2001;28(1):40-3. [pmid: 11430441].
43 Achauer BM, Chang CJ, Vander Kam VM. Management of hemangioma of infancy: review of 245 patients. Plast Reconstr Surg. Apr. 1997;99(5):1301-8. [pmid: 9105356].
44 Achauer BM, Vander Kam VM. Capillary hemangioma (strawberry mark) of infancy: comparison of argon and Nd:YAG laser treatment. Plast Reconstr Surg. Jul. 1989;84(1):60-9. discussion 70. [pmid: 2734405].
45 Chen ZG, Zheng JW, Yuan ML, et al. A novel topical nano-propranolol for treatment of infantile hemangiomas. Nanomedicine. 2015. Mar. 16. [pmid: 25791814].
46 Chen W, Liu S, Yang C, et al. Clinical efficacy of the 595 nm pulsed dye laser in the treatment of childhood superficial hemangioma - analysis of 10-year application in Chinese patients. J Dermatolog Treat. Feb. 2015;26(1):54-8. [pmid: 23697537].
47 Raphael MF, Breugem CC, Vlasveld FA, et al. Is cardiovascular evaluation necessary prior to and during beta-blocker therapy for infantile hemangiomas?: A cohort study. J Am Acad Dermatol. Mar. 2015;72(3):465-72. [pmid: 25592625].
48 Xu DP, Cao RY, Xue L, et al. Treatment of severe infantile hemangiomas with propranolol: an evaluation of the efficacy and effects of cardiovascular parameters in 25 consecutive patients. J Oral Maxillofac Surg. Mar. 2015;73(3):430-6. [pmid: 25544304].
49 Andersen IG, Rechnitzer C, Charabi B. Effectiveness of propanolol for treatment of infantile haemangioma. Dan Med J. Feb. 2014;61(2):A4776. [pmid: 24495884].
50 Chai Q, Chen WL, Huang ZQ, et al. Preliminary experiences in treating infantile hemangioma with propranolol. Ann Plast Surg. Feb. 2014;72(2):169-72. [pmid: 21629056].
51 Chen W, Yang C, Liu S, et al. Curative effect study of pulsed dye laser in the treatment of 43 patients with hand infantile hemangioma. Eur J Dermatol. Jan–Feb. 2014;24(1):76-9. [pmid: 24413474].
52 Chu DH, Castelo-Soccio L, Wan J, et al. Retrospective analysis of beta-blocker instituted for treatment of hemangiomas (RABBIT study). Clin Pediatr (Phila). Oct. 2014;53(11):1084-90. [pmid: 24849505].
53 Couto JA, Greene AK. Management of problematic infantile hemangioma using intralesional triamcinolone: efficacy and safety in 100 infants. J Plast Reconstr Aesthet Surg. Nov. 2014;67(11):1469-74. [pmid: 25104131].
54 El Ezzi O, Hohlfeld J, de Buys Roessingh A. Propranolol in infantile haemangioma: simplifying pretreatment monitoring. Swiss Med Wkly. 2014;144:w13943. [pmid: 24610228].
55 Giachetti A, Garcia-Monaco R, Sojo M, et al. Long-term treatment with oral propranolol reduces relapses of infantile hemangiomas. Pediatr Dermatol. Jan–Feb. 2014;31(1):14-20. [pmid: 24283619].
56 Hassan BA, Shreef KS. Propranolol in treatment of huge and complicated infantile hemangiomas in egyptian children. Dermatol Res Pract. 2014;2014(541810).
57 Jian D, Chen X, Babajee K, et al. Adverse effects of propranolol treatment for infantile hemangiomas in China. J Dermatolog Treat. Oct. 2014;25(5):388-90. [pmid: 23216314].
58 Kaune KM, Lauerer P, Kietz S, et al. Combination therapy of infantile hemangiomas with pulsed dye laser and Nd:YAG laser is effective and safe. J Dtsch Dermatol Ges. Jun. 2014;12(6):473-8. [pmid: 24825388].
59 Ke Y, Hao R, He Y, et al. The value of color Doppler imaging and intralesional steroid injection in pediatric orbital capillary hemangioma. J Chin Med Assoc. May. 2014;77(5):258-64. [pmid: 24694673].
60 Kwon SH, Choi JW, Byun SY, et al. Effect of early long-pulse pulsed dye laser treatment in infantile hemangiomas. Dermatol Surg. Apr. 2014;40(4):405-11. [pmid: 24460784].
61 Lynch M, Lenane P, O’Donnell BF. Propranolol for the treatment of infantile haemangiomas: our experience with 44 patients. Clin Exp Dermatol. Mar. 2014;39(2):142-5. [pmid: 24289272].
62 Martinez Roca C, Rodriguez Ruiz M, Vilaboa Pedrosa C, et al. Oral propranolol in the treatment of infantile hemangioma: A case series of 50 infants. European Journal of Pediatric Dermatology. April–June. 2014;24(2):86-90.
63 May JE, Liew SH. A new treatment pathway for propranolol use in infantile haemangiomas. J Plast Reconstr Aesthet Surg. Mar. 2014;67(3):e91-2. [pmid: 24268691].
64 Muzaffar F, Shah GN. Propranolol for the treatment of infantile hemangioma: Our experience at The Children’s Hospital, Lahore. Journal of Pakistan Association of Dermatologists. 2014;24(4):312-8.
65 Park YW, Yeom KB, Choi JW, et al. Effect of propranolol on the treatment of infantile hemangiomas: a single tertiary center 3-year experience. J Dermatolog Treat. Oct. 2014;25(5):391-5. [pmid: 23273264].
66 Sagi L, Zvulunov A, Lapidoth M, et al. Efficacy and safety of propranolol for the treatment of infantile hemangioma: a presentation of ninety-nine cases. Dermatology. 2014;228(2):136-44. [pmid: 24556822].
67 Schneider M, Cremer HJ, Ruef P. A retrospective analysis of systemic propranolol for the treatment of complicated infantile haemangiomas. Acta Paediatr. Sep. 2014;103(9):977-83. [pmid: 24837972].
68 Schneider M, Reimer A, Cremer H, et al. Topical treatment with propranolol gel as a supplement to the existing treatment of hemangiomas. World J Pediatr. Nov. 2014;10(4):313-7. [pmid: 25515804].
69 Solman L, Murabit A, Gnarra M, et al. Propranolol for infantile haemangiomas: single centre experience of 250 cases and proposed therapeutic protocol. Arch Dis Child. Dec. 2014;99(12):1132-6. [pmid: 25123404].
70 Su W, Ke Y, Xue J. Beneficial effects of early treatment of infantile hemangiomas with a long-pulse Alexandrite laser. Lasers Surg Med. Mar. 2014;46(3):173-9. [pmid: 24391080].
71 Szychta P, Stewart K, Anderson W. Treatment of infantile hemangiomas with propranolol: clinical guidelines. Plast Reconstr Surg. Apr. 2014;133(4):852-62. [pmid: 24352207].
72 Bonifazi E, Milano A, Colonna V. Evaluation of safety and efficacy of a galenic preparation of 1% propranolol in 89 cases of cutaneous infantile hemangioma. European Journal of Pediatric Dermatology. April–June. 2013;23(2):93-104.
73 Gan LQ, Ni SL, Tan Q, et al. A retrospective study of propranolol therapy in 109 infants with infantile hemangioma. Pediatr Dermatol. Mar–Apr. 2013;30(2):270-2. [pmid: 23252446].
74 Hermans DJ, Bauland CG, Zweegers J, et al. Propranolol in a case series of 174 patients with complicated infantile haemangioma: indications, safety and future directions. Br J Dermatol. Apr. 2013;168(4):837-43. [pmid: 23278381].
75 Hong P, Tammareddi N, Walvekar R, et al. Successful discontinuation of propranolol for infantile hemangiomas of the head and neck at 12 months of age. Int J Pediatr Otorhinolaryngol. Jul. 2013;77(7):1194-7. [pmid: 23706952].
76 Liu LS, Sokoloff D, Antaya RJ. Twenty-four-hour hospitalization for patients initiating systemic propranolol therapy for infantile hemangiomas--is it indicated?. Pediatr Dermatol. Sep–Oct. 2013;30(5):554-60. [pmid: 23829941].
77 Ma X, Zhao T, Xiao Y, et al. Preliminary experience on treatment of infantile hemangioma with low-dose propranolol in China. Eur J Pediatr. May. 2013;172(5):653-9. [pmid: 23340697].
78 Puttgen KB, Summerer B, Schneider J, et al. Cardiovascular and blood glucose parameters in infants during propranolol initiation for treatment of symptomatic infantile hemangiomas. Ann Otol Rhinol Laryngol. Sep. 2013;122(9):550-4. [pmid: 24224397].
79 Sadykov RR, Podmelle F, Sadykov RA, et al. Use of propranolol for the treatment infantile hemangiomas in the maxillofacial region. Int J Oral Maxillofac Surg. Jul. 2013;42(7):863-7. [pmid: 23618833].
80 Bagazgoitia L, Torrelo A, Gutierrez JC, et al. Propranolol for infantile hemangiomas. Pediatr Dermatol. Mar–Apr. 2011;28(2):108-14. [pmid: 21385205].
81 Semkova K, Kazandjieva J. Topical timolol maleate for treatment of infantile haemangiomas: preliminary results of a prospective study. Clin Exp Dermatol. Mar. 2013;38(2):143-6. [pmid: 22731954].
82 Vercellino N, Romanini MV, Pelegrini M, et al. The use of propranolol for complicated infantile hemangiomas. Int J Dermatol. Sep. 2013;52(9):1140-6. [pmid: 23829783].
83 Xiao Q, Li Q, Zhang B, et al. Propranolol therapy of infantile hemangiomas: efficacy, adverse effects, and recurrence. Pediatr Surg Int. Jun. 2013;29(6):575-81. [pmid: 23519547].
84 Yuan WL, Jin ZL, Wei JJ, et al. Propranolol given orally for proliferating infantile haemangiomas: analysis of efficacy and serological changes in vascular endothelial growth factor and endothelial nitric oxide synthase in 35 patients. Br J Oral Maxillofac Surg. Oct. 2013;51(7):656-61. [pmid: 23291092].
85 Balma-Mena A, Chakkittakandiyil A, Weinstein M, et al. Propranolol in the management of infantile hemangiomas: clinical response and predictors. J Cutan Med Surg. May–Jun. 2012;16(3):169-73. [pmid: 22713439].
86 Bertrand J, Sammour R, McCuaig C, et al. Propranolol in the treatment of problematic infantile hemangioma: review of 35 consecutive patients from a vascular anomalies clinic. J Cutan Med Surg. Sep–Oct. 2012;16(5):317-23. [pmid: 22971306].
87 Celik A, Tiryaki S, Musayev A, et al. Propranolol as the first-line therapy for infantile hemangiomas: preliminary results of two centers. J Drugs Dermatol. Jul. 2012;11(7):808-11. [pmid: 22777220].
88 Chakkittakandiyil A, Phillips R, Frieden IJ, et al. Timolol maleate 0.5% or 0.1% gel-forming solution for infantile hemangiomas: a retrospective, multicenter, cohort study. Pediatr Dermatol. Jan–Feb. 2012;29(1):28-31. [pmid: 22150436].
89 Georgountzou A, Karavitakis E, Klimentopoulou A, et al. Propranolol treatment for severe infantile hemangiomas: a single-centre 3-year experience. Acta Paediatr. Oct. 2012;101(10):e469-74. [pmid: 22804809].
90 Janmohamed SR, Madern GC, Nieuwenhuis K, et al. Evaluation of intra-lesional corticosteroids in the treatment of peri-ocular haemangioma of infancy: still an alternative besides propranolol. Pediatr Surg Int. Apr. 2012;28(4):393-8. [pmid: 22200732].
91 Kunzi-Rapp K. Topical propranolol therapy for infantile hemangiomas. Pediatr Dermatol. Mar–Apr. 2012;29(2):154-9. [pmid: 22141326].
92 Lv MM, Fan XD, Su LX. Propranolol for problematic head and neck hemangiomas: an analysis of 37 consecutive patients. Int J Pediatr Otorhinolaryngol. Apr. 2012;76(4):574-8. [pmid: 22326207].
93 Phillips RJ, Penington AJ, Bekhor PS, et al. Use of propranolol for treatment of infantile haemangiomas in an outpatient setting. J Paediatr Child Health. Oct. 2012;48(10):902-6. [pmid: 22897120].
94 Samimi DB, Alabiad CR, Tse DT. An anatomically based approach to intralesional corticosteroid injection for eyelid capillary hemangiomas. Ophthalmic Surg Lasers Imaging. May–Jun. 2012;43(3):190-5. [pmid: 22432604].
95 Talaat AA, Elbasiouny MS, Elgendy DS, et al. Propranolol treatment of infantile hemangioma: clinical and radiologic evaluations. J Pediatr Surg. Apr. 2012;47(4):707-14. [pmid: 22498385].
96 Wang L, Xia Y, Zhai Y, et al. Topical propranolol hydrochloride gel for superficial infantile hemangiomas. J Huazhong Univ Sci Technolog Med Sci. Dec. 2012;32(6):923-6. [pmid: 23271298].
97 Xu G, Lv R, Zhao Z, et al. Topical propranolol for treatment of superficial infantile hemangiomas. J Am Acad Dermatol. Dec. 2012;67(6):1210-3. [pmid: 22516113].
98 Zegpi-Trueba MS, Abarzua-Araya A, Silva-Valenzuela S, et al. Oral propranolol for treating infantile hemangiomas: a case series of 57 patients. Actas Dermosifiliogr. Oct. 2012;103(8):708-17. [pmid: 22853960].
99 Blatt J, Morrell DS, Buck S, et al. beta-blockers for infantile hemangiomas: a single-institution experience. Clin Pediatr (Phila). Aug. 2011;50(8):757-63. [pmid: 21525081].
100 Chang CJ. Long term follow-up of intralesional laser photocoagulation (ILP) for hemangioma patients. Laser Therapy. 2011;20(4):255-63. [pmid: 24155535].
101 Cushing SL, Boucek RJ, Manning SC, et al. Initial experience with a multidisciplinary strategy for initiation of propranolol therapy for infantile hemangiomas. Otolaryngol Head Neck Surg. Jan. 2011;144(1):78-84. [pmid: 21493392].
102 Daramola OO, Chun RH, Nash JJ, et al. Surgical treatment of infantile hemangioma in a multidisciplinary vascular anomalies clinic. Int J Pediatr Otorhinolaryngol. Oct. 2011;75(10):1271-4. [pmid: 21803434].
103 Di Maio L, Baldi A, Dimaio V, et al. Use of flashlamp-pumped pulsed dye laser in the treatment of superficial vascular malformations and ulcerated hemangiomas. In Vivo. Jan–Feb. 2011;25(1):117-23. [pmid: 21282744].
104 Fuchsmann C, Quintal MC, Giguere C, et al. Propranolol as first-line treatment of head and neck hemangiomas. Arch Otolaryngol Head Neck Surg. May. 2011;137(5):471-8. [pmid: 21576558].
105 Greene AK, Couto RA. Oral prednisolone for infantile hemangioma: efficacy and safety using a standardized treatment protocol. Plast Reconstr Surg. Sep. 2011;128(3):743-52. [pmid: 21572374].
106 Holmes WJ, Mishra A, Gorst C, et al. Propranolol as first-line treatment for rapidly proliferating infantile haemangiomas. J Plast Reconstr Aesthet Surg. Apr. 2011;64(4):445-51. [pmid: 20797926].
107 Kulbersh J, Hochman M. Serial excision of facial hemangiomas. Arch Facial Plast Surg. May–Jun. 2011;13(3):199-202. [pmid: 21576667].
108 Li WY, Chaudhry O, Reinisch JF. Guide to early surgical management of lip hemangiomas based on our experience of 214 cases. Plast Reconstr Surg. Nov. 2011;128(5):1117-24. [pmid: 21738083].
109 Saint-Jean M, Leaute-Labreze C, Mazereeuw-Hautier J, et al. Propranolol for treatment of ulcerated infantile hemangiomas. J Am Acad Dermatol. May. 2011;64(5):827-32. [pmid: 21353332].
110 Schiestl C, Neuhaus K, Zoller S, et al. Efficacy and safety of propranolol as first-line treatment for infantile hemangiomas. Eur J Pediatr. Apr. 2011;170(4):493-501. [pmid: 20936416].
111 Schupp CJ, Kleber JB, Gunther P, et al. Propranolol therapy in 55 infants with infantile hemangioma: dosage, duration, adverse effects, and outcome. Pediatr Dermatol. Nov–Dec. 2011;28(6):640-4. [pmid: 21995836].
112 Snir M, Reich U, Siegel R, et al. Refractive and structural changes in infantile periocular capillary haemangioma treated with propranolol. Eye (Lond). Dec. 2011;25(12):1627-34. [pmid: 21921959].
113 Zaher H, Rasheed H, Hegazy RA, et al. Oral propranolol: an effective, safe treatment for infantile hemangiomas. Eur J Dermatol. Jul–Aug. 2011;21(4):558-63. [pmid: 21697036].
114 Zvulunov A, McCuaig C, Frieden IJ, et al. Oral propranolol therapy for infantile hemangiomas beyond the proliferation phase: a multicenter retrospective study. Pediatr Dermatol. Mar–Apr. 2011;28(2):94-8. [pmid: 21362031].
115 Arneja JS, Mulliken JB. Resection of amblyogenic periocular hemangiomas: indications and outcomes. Plast Reconstr Surg. Jan. 2010;125(1):274-81. [pmid: 20048618].
116 Hamou C, Diner PA, Dalmonte P, et al. Nasal tip haemangiomas: guidelines for an early surgical approach. J Plast Reconstr Aesthet Surg. Jun. 2010;63(6):934-9. [pmid: 19540825].
117 Li DN, Gold MH, Sun ZS, et al. Treatment of infantile hemangioma with optimal pulse technology. J Cosmet Laser Ther. Jun. 2010;12(3):145-50. [pmid: 20482239].
118 Manunza F, Syed S, Laguda B, et al. Propranolol for complicated infantile haemangiomas: a case series of 30 infants. Br J Dermatol. Feb. 1. 2010;162(2):466-8. [pmid: 20055816].
119 Chen WL, Zhang B, Li JS, et al. Liquid nitrogen cryotherapy of lip mucosa hemangiomas under inhalation general anesthesia with sevoflurane in early infancy. Ann Plast Surg. Feb. 2009;62(2):154-7. [pmid: 19158525].
120 Pandey A, Gangopadhyay AN, Gopal SC, et al. Twenty years’ experience of steroids in infantile hemangioma--a developing country’s perspective. J Pediatr Surg. Apr. 2009;44(4):688-94. [pmid: 19361627].
121 Rizzo C, Brightman L, Chapas AM, et al. Outcomes of childhood hemangiomas treated with the pulsed-dye laser with dynamic cooling: a retrospective chart analysis. Dermatol Surg. Dec. 2009;35(12):1947-54. [pmid: 19889007].
122 Saleh KH. Steroids in complicated hemangioma. Iranian Red Crescent Medical Journal. 2009;11(2):217.
123 Sans V, de la Roque ED, Berge J, et al. Propranolol for severe infantile hemangiomas: follow-up report. Pediatrics. Sep. 2009;124(3):e423-31. [pmid: 19706583].
124 Wu JK, Rohde CH. Purse-string closure of hemangiomas: early results of a follow-up study. Ann Plast Surg. May. 2009;62(5):581-5. [pmid: 19387166].
125 Chantharatanapiboon W. Intralesional corticosteroid therapy in hemangiomas: clinical outcome in 160 cases. J Med Assoc Thai. Oct. Suppl 3. 2008;91:S90-6. [pmid: 19253502].
126 Chen W, Li J, Yang Z, et al. SMAS fold flap and ADM repair of the parotid bed following removal of parotid haemangiomas via pre- and retroauricular incisions to improve cosmetic outcome and prevent Frey’s syndrome. J Plast Reconstr Aesthet Surg. Aug. 2008;61(8):894-9. discussion 9–900. [pmid: 18504166].
127 Claude O, Picard A, O’Sullivan N, et al. Use of ultrasonic dissection in the early surgical management of periorbital haemangiomas. J Plast Reconstr Aesthet Surg. Dec. 2008;61(12):1479-85. [pmid: 18037085].
128 Baraldini V, Coletti M, Cigognetti F, et al. Haemostatic squeezing and purse-string sutures: optimising surgical techniques for early excision of critical infantile haemangiomas. J Pediatr Surg. Feb. 2007;42(2):381-5. [pmid: 17270553].
129 Garzon MC, Lucky AW, Hawrot A, et al. Ultrapotent topical corticosteroid treatment of hemangiomas of infancy. J Am Acad Dermatol. Feb. 2005;52(2):281-6. [pmid: 15692474].
130 McHeik JN, Renauld V, Duport G, et al. Surgical treatment of haemangioma in infants. Br J Plast Surg. Dec. 2005;58(8):1067-72. [pmid: 16039624].
131 Waldschmidt J, Giest H, Meyer L. Endoscopic laser application in 56 children with hemangiomas of the larynx and trachea. Med Laser Appl. 08. Dec. 2005;20(4):297-302.
132 David LR, Malek MM, Argenta LC. Efficacy of pulse dye laser therapy for the treatment of ulcerated haemangiomas: a review of 78 patients. Br J Plast Surg. Jun. 2003;56(4):317-27. [pmid: 12873458].
133 Vlachakis I, Gardikis S, Michailoudi E, et al. Treatment of hemangiomas in children using a Nd:YAG laser in conjunction with ice cooling of the epidermis: techniques and results. BMC Pediatr. Apr. 12. 2003;3:2. [pmid: 12697072].
134 Demiri EC, Pelissier P, Genin-Etcheberry T, et al. Treatment of facial haemangiomas: the present status of surgery. Br J Plast Surg. Dec. 2001;54(8):665-74. [pmid: 11728108].
135 Hohenleutner S, Badur-Ganter E, Landthaler M, et al. Long-term results in the treatment of childhood hemangioma with the flashlamp-pumped pulsed dye laser: an evaluation of 617 cases. Lasers Surg Med. 2001;28(3):273-7. [pmid: 11295764].
136 Chen MT, Yeong EK, Horng SY. Intralesional corticosteroid therapy in proliferating head and neck hemangiomas: a review of 155 cases. J Pediatr Surg. Mar. 2000;35(3):420-3. [pmid: 10726680].
137 Poetke M, Philipp C, Berlien HP. Flashlamp-pumped pulsed dye laser for hemangiomas in infancy: treatment of superficial vs mixed hemangiomas. Arch Dermatol. May. 2000;136(5):628-32. [pmid: 10815856].
138 Blei F, Chianese J. Corticosteroid toxicity in infants treated for endangering hemangiomas: experience and guidelines for monitoring. International Pediatrics. 1999;14(1):53.
139 Boon LM, MacDonald DM, Mulliken JB. Complications of systemic corticosteroid therapy for problematic hemangioma. Plast Reconstr Surg. Nov. 1999;104(6):1616-23. [pmid: 10541160].
140 Zide BM, Glat PM, Stile FL, et al. Vascular lip enlargement: Part I. Hemangiomas--tenets of therapy. Plast Reconstr Surg. Dec. 1997;100(7):1664-73. [pmid: 9393462].
141 Gangopadhyay AN, Sharma SP, Gopal SC, et al. Local steroid therapy in cutaneous hemangiomas. Indian Pediatr. Jan. 1996;33(1):31-3. [pmid: 8772948].
142 Sadan N, Wolach B. Treatment of hemangiomas of infants with high doses of prednisone. J Pediatr. Jan. 1996;128(1):141-6. [pmid: 8551406].
143 Chowdri NA, Darzi MA, Fazili Z, et al. Intralesional corticosteroid therapy for childhood cutaneous hemangiomas. Ann Plast Surg. Jul. 1994;33(1):46-51. [pmid: 7944196].
144 Morelli JG, Tan OT, Yohn JJ, et al. Treatment of ulcerated hemangiomas infancy. Arch Pediatr Adolesc Med. Oct. 1994;148(10):1104-5. [pmid: 7921107].
145 Preeyanont P, Nimsakul N. The Nd:YAG laser treatment of hemangioma. J Clin Laser Med Surg. Aug. 1994;12(4):225-9. [pmid: 10147482].
146 Morrell AJ, Willshaw HE. Normalisation of refractive error after steroid injection for adnexal haemangiomas. Br J Ophthalmol. May. 1991;75(5):301-5. [pmid: 2036349].
147 Kushner BJ. Infantile orbital hemangiomas. International Pediatrics. 1990;5(3):249-57.
148 Sloan GM, Reinisch JF, Nichter LS, et al. Intralesional corticosteroid therapy for infantile hemangiomas. Plast Reconstr Surg. Mar. 1989;83(3):459-67. [pmid: 2919200].
149 Kushner BJ. The treatment of periorbital infantile hemangioma with intralesional corticosteroid. Plast Reconstr Surg. Oct. 1985;76(4):517-26. [pmid: 4034770].
150 Healy G, McGill T, Friedman EM. Carbon dioxide laser in subglottic hemangioma. An update. Ann Otol Rhinol Laryngol. Jul–Aug. 1984;93(4 Pt 1):370-3. [pmid: 6431866].
151 Sharma LK, Dalal SS. Corticosteroid therapy in the treatment of cutaneous hemangioma of infancy and childhood. Indian J Pediatr. Mar–Apr. 1983;50(403):153-6. [pmid: 6618575].