# Methods for Network Meta-Analysis

Using data extracted by the systematic review, we conducted a multi-intervention (network) meta-analysis to estimate the effectiveness of several corticosteroids and beta-blockers for the treatment of infantile hemangioma. Of particular interest was the estimation of the efficacy of propranolol, a beta-blocker that was used in a large number of studies in the review. To this end, we estimated the expected clearance of IH following intervention based on outcomes from 17 unique studies obtained from the systematic review. This set included outcomes for 4 different non-control pharmacologic interventions: propranolol, timolol, triamcinolone, and oral steroids.

A challenge for meta-analyzing these outcomes is the diversity in outcome reporting among the constituent studies. Though most used some measure of the reduction in the original IH at end of treatment, typically results were reported as counts of subjects achieving some arbitrary minimum clearance threshold, such as 50% or 75%. An approach to analyzing outcomes reported in this way is via a binomial model. For this model, the response variable is the number of individuals in study j under intervention k that achieve the clearance threshold:

y_j k_ = ∑_i = 1_^n_j k_^ I_i_ ( a b o v e c l e a r a n c e t h r e s h o l d )

where I is the indicator function, returning 1 if the argument is true, or 0 otherwise. This outcome can then modeled as a binomial response:

y_jk_ ~ Bin(n_jk_, π_jk_)

where π_jk_ is the probability of a positive response for study j under intervention k. To allow for heterogeneity in this probability across studies, we can specify it as a random effect:

logit(π_jk_) = θ_jk_ θ_jk_~Normal(μ_k_, σ_k_)

where μ_k_, σ_k_ are the parameters of a normal distribution (which, inverse logit-transformed, models quantities on the [0,1] interval).

However, the use of an arbitrary cutoff value as a threshold of success is an unsatisfactory modeling choice because there is an inherent loss of information in the dichotomization or discretization of continuous variables, and this loss is magnified here by having to discard data from studies that use a different response threshold than the adopted value (e.g. 75%). Since the clearance rate is a continuous measure, one can hypothesize a latent, continuous probability distribution that each study reports relative to specific quantiles: 50%, 75%, etc. If there is sufficient information, one may use a Bayesian approach to attempt to reconstruct this latent distribution, which would allow for more of the available information to be used in the meta-analytic procedure.

Under treatment k, one can consider a notional distribution of hemangioma clearance rates, from no effect (0) to complete clearance (1)—for our purposes, we will not consider IH enlargement, other than assigning it a “no effect” outcome. As a matter of convenience in a particular study j, researchers chose a clearance threshold c_j_, only reporting whether a particular subject occupied one side or the other of this threshold. We can characterize the true, latent response distribution by estimating the parameters via the following identity:

π_jk_ = 1 − Φ(c_j_|μ_k_, σ_k_)

where Φ(x) is the cumulative distribution function of the normal distribution (our latent ditribution) under parameters evaluated at x. The resulting probability is the same as specified above, and can be used in the same binomial likelihood:

y_jk_ ~ Bin(n_jk_, π_jk_)

This can be readily generalized to studies that report multiple thresholds, simply by dividing the distribution of π_jk_ into regions corresponding to each threshold. This corresponds to a multinomial, rather than binomial, likelihood.

In principle, one may incorporate covariates to improve the prediction of intervention effectiveness. For example, the mode of delivery (oral, intralesional, topical), dose, or the hemangioma location may be predictive of intervention effectiveness. In this work, only propanolol had a sufficient number of studies to estimate covariate effects; we included an indicator variable for intralesional mode of delivery, relative to the oral mode that was used as a baseline. The logit-expected value of treatment k from study j was modeled as:

θ_jk_ = μ + β_k_ + ψz_j_ + ε_j_

where μ is the baseline (control) clearance rate, β_k_ is the relative effect of treatment k, z_j_ is an indicator for the use of intralesional propranolol, and ψ the associated relative intralesional effect. Finally, ε_j_ is a study random effect that is assigned to all treatment arms of study j, which accounts for the lack of independence within-study. This random effect was assumed to be normally distributed with zero mean and variance σ^2^ that was estimated from the data.

A handful of studies, rather than reporting threshold counts, reported summary statistics of VAS scores for each study arm. Using the latent variable framework described above under a Bayesian estimation approach, this information can also be brought to bear on the estimation of the model parameters. This required the transformation of the reported outcomes from the VAS scale (0–100) to values on the real line (i.e. a logit transformation), including the reported standard deviation, which was transformed using the delta method. The resulting transformed values can then be used to inform the expected outcome for the corresponding intervention via a normal likelihood:

l o g i t ( V A S_j k_ ) ~ N ( θ_k_ , s_j k_^δ^ )

where s_j_^δ^ is the transformed standard deviation for the outcome.

Finally, one study (Qiu 2013) reported individual patient data in the form of VAS scores. This data was integrated into the study via the same method as for the summarized VAS score output outlined above, except that the delta transformation was not necessary, since the data were used directly.

This model was implemented in the PyMC package for Bayesian analysis in Python (Patil et al. 2010). Parameter estimates were obtained using Markov chain Monte Carlo (MCMC, Brooks et al. 2011) methods. Sampling was carried out for 100,000 iterations, with the first 90,000 conservatively discarded as burn-in to ensure convergence of the sampler. In order to evaluate convergence using the Gelman-Rubin diagnostic (Gelman and Rubin 1992), a second chain was sampled of identical size. The complete analysis is available is an open-access GitHub repository (https://github.com/fonnesbeck/IH_meta-analysis), including an IPython Notebook containing the model described above (https://github.com/fonnesbeck/IH_meta-analysis/blob/master/Infantile%20Hemangioma%20Meta-analysis.ipynb).

## Model Results

The expected efficacy of control arms was estimated to be 0.06 (95% Bayesian credible interval = [0.01, 0.11]). All non-control treatments were estimated to have a larger expected clearance than control (Figure D-1). The largest mean estimate was oral propranolol (0.95, 95% BCI = [0.88, 0.99]), followed by timolol (0.62, 95% BCI = [0.39, 0.83]) and triamcinolone (0.58, 95% BCI = [0.22, 0.93]). Oral steroids had a mean clearance estimate of 0.43(95% BCI = [0.21, 0.66]).

Figure D-1 Estimates of expected IH clearance

Note: Estimates of expected IH clearance (expressed as percent clearance relative to initial condition) for each treatment, along with associated posterior interquartile range (thick lines) and 95% credible interval (thin lines).

This figure illustrates the mean expected clearance rates and confidence bounds around the estimates. Estimates of expected IH clearance are expressed as percent clearance relative to initial condition for each treatment, along with associated posterior interquartile range (thick lines) and 95% credible interval (thin lines). The expected efficacy of control arms was estimated to be 6 percent (95% BCI: 1% to 11%), i.e., we would expect to see, on average, 6 percent clearance of IH in children who receive placebo or no treatment during the study period. All non-control treatments were estimated to have a larger expected clearance than control. The largest mean estimate of clearance was for oral propranolol (95%, 95% BCI: 88% to 99%).

We calculated the probability that each of the non-control interventions is the best treatment, based on expected clearance rate. This was estimated from the MCMC simulation that tallied the number of iterations that each intervention had the highest expected value, and calculating the proportion for each intervention as an estimate of the probability of being best. Oral propranolol had the highest probability (99%), followed by triamcinolone (1%); all others had probabilities less than 1% combined. To better account for the uncertainty in the estimated treatment effects, we also calculated the surface under the cumulative ranking curve (SUCRA) for each treatment, which provides a probabilistic summary of the rankings of the treatments (Figure D-3). Oral propranolol had the highest SUCRA score (0.902), intralesional propanolol the lowest (0.119), with the other treatments intermediate.

Figure D-3 Posterior SUCRA estimates for each treatment

This figure provide posterior surface under the cumulative ranking curve (SUCRA ) estimates, which illustrate the distribution of expected clearance summary statistic for the cumulative ranking. SUCRA ranges from 0 to 1, with 1 reflecting the best treatment without any uncertainty and 0 the worst treatment without any uncertainty. SUCRA estimates ranged from 0.119 to 0.902.

Propanolol was estimated to have the largest variability in clearance rate (Figure D-2, σ=2.5, 95% BCI = [2.1, 2.9]) with timolol (σ=1.5, 95% BCI: 1.4 to 1.6), intralesional triamcinolone (σ=1.8, 95% BCI: 1.3 to 2.3), and oral steroids (σ=1.3, 95% BCI: 1.1 to 1.6) yielding similar, lower estimates. With the exception of Timolol, interventions with larger effect sizes tended to have larger effect size variance.

Figure D-2 Estimates of the variation of each treatment

Note: Estimates of the variation of each treatment, expressed as standard deviation, along with associated posterior interquartile range (thick lines) and 95% credible interval (thin lines).

This figure represents the variability in effects seen across the patient populations in terms of percent clearance. Estimates of the variation of each treatment are expressed as standard deviation, along with associated posterior interquartile range (thick lines) and 95% credible interval (thin lines). Propranolol was estimated to have the largest variability in clearance rate with some patients experiencing much greater clearance than others (σ=2.5, 95% BCI: 2.1 to 2.9).

Table D-1 Posterior estimates of effect size

| Mean | SE | 95% Credible interval
Oral propranolol | 6.0 | 0.7 | [4.6 7.5]
Timolol | 3.5 | 0.5 | [2.4 4.6]
Triamcinolone | 3.3 | 0.8 | [1.7 4.9]
Oral steroid | 2.6 | 0.5 | [1.8 3.6]

Note: Posterior estimates of effect size, on logit scale, relative to control, along with standard error and 95% credible interval. Positive values indicate increased clearance relative to control, negative indicate decreased clearance.

To give an overview of the expected distribution of clearance rates across treatments, Figure D-4 plots estimated probability distribution functions based on the posterior clearance rates and standard deviations of four treatments. For each of 100 iterations, a sample was drawn from the posterior distributions of both the mean and standard deviation for oral propranolol, timolol, triamcinolone, and oral steroid. Inverse-logit transforming the normal probability distribution function resulted in plots that integrate the residual uncertainty of the parameters with the sampling variability of the model.

Figure D-4 100 posterior samples of distribution of clearance rates under oral propranolol, timolol, triamcinolone, and oral steroid

This figure plots estimated probability distribution functions based on the posterior clearance rates and standard deviations of four treatments. For each of 100 iterations, a sample was drawn from the posterior distributions of both the mean and standard deviation for oral propranolol, timolol, triamcinolone, and oral steroid. Inverse-logit transforming the normal probability distribution function resulted in plots that integrate the residual uncertainty of the parameters with the sampling variability of the model.

The network diagram in Figure D-5 illustrates the relative numbers of direct comparisons between intervention types. The largest number (thickest line) is four comparisons.

Figure D-5 Network diagram of comparisons

The network diagram in Figure D-5 illustrates the relative numbers of direct comparisons between intervention types. The largest number (thickest line) is four comparisons of propranolol and oral steroids.

## References

1 Patil A, Huard D, Fonnesbeck CJ. PyMC: Bayesian Stochastic Modelling in Python. J Stat Softw. 2010;35(4):1-81. [pmid: 21603108].
2 Brooks S, Gelman A, Jones G, Meng X-L. Handbook of Markov Chain Monte Carlo. CRC Press. 2011.
3 Gelman A, Rubin DB. Inference from iterative simulation using multiple sequences. Statist Sci. 1992:457-472.
4 Salanti G, Ades AE, Ioannidis JPA. Graphical methods and numerical summaries for presenting results from multiple-treatment meta-analysis: an overview and tutorial. J Clin Epidemiol. 2011;64(2):163-171. [doi: 10.1016/j.jclinepi.2010.03.016]. [pmid: 20688472].