# Excluded Studies

Reasons for Exclusion

X-1 | Does not include children with infantile hemangioma
X-2 | Not original research
X-3 | Does not address interventions/outcomes of interest
X-4 | Ineligible study design
X-5 | Not obtainable
X-6 | Not in English

1 Argenta LC, Bishop E, Cho KJ, et al. Complete resolution of life-threatening hemangioma by embolization and corticosteroids. Plast Reconstr Surg. Dec. 1982;70(6):739-44. X-1, X-2. [pmid: 6890694].
2 Bardelli AM, Lasorella G. Primary and secondary ocular tumors in children. J Neurosurg Sci. Jan–Mar. 1982;26(1):11-6. X-1. [pmid: 6815311].
3 Biller HF, Krespi YP, Som PM. Combined therapy for vascular lesions of the head and neck with intra-arterial embolization and surgical excision. Otolaryngol Head Neck Surg. Jan–Feb. 1982;90(1):37-47. X-1, X-2. [pmid: 6806755].
4 Bloom DA, Scardino PT, Ehrlich RM, et al. The significance of lymph nodal involvement in renal angiomyolipoma. J Urol. Dec. 1982;128(6):1292-5. X-1. [pmid: 7154190].
5 Bookstein JJ, Cho KJ, Davis GB, et al. Arterioportal communications: observations and hypotheses concerning transsinusoidal and transvasal types. Radiology. Mar. 1982;142(3):581-90. X-1. [pmid: 7063671].
6 Bradley PJ, Singh SD. Congenital nasal masses: diagnosis and management. Clin Otolaryngol Allied Sci. Apr. 1982;7(2):87-97. X-1. [pmid: 7094387].
7 Brooks BS, El Gammal T, Beveridge WD. Erosion of vertebral pedicles by unusual vascular causes. Report of three cases. Neuroradiology. 1982;23(2):107-12. X-1. [pmid: 7078720].
8 Brown BZ, Huffaker G. Local injection of steroids for juvenile hemangiomas which disturb the visual axis. Ophthalmic Surg. Aug. 1982;13(8):630-3. X-2. [pmid: 7133606].
9 Carruth JA. The argon laser in he treatment of vascular naevi. Br J Dermatol. Sep. 1982;107(3):365-8. X-1. [pmid: 7115616].
10 Carruth JA, McKenzie AL. The argon laser in dermatology: safety aspects. Clin Exp Dermatol. May. 1982;7(3):247-53. X-1. [pmid: 7105476].
11 de Tribolet N, Kaech D, Perentes E. Cerebellar haematoma due to a cavernous angioma in a child. Acta Neurochir (Wien). 1982;60(1–2):37-43. X-1. [pmid: 7058698].
12 Demakas JJ, Sonntag VK, Kaplan AM, et al. Surgical management of pineal area tumors in early childhood. Surg Neurol. Jun. 1982;17(6):435-40. X-1. [pmid: 7112375].
13 Di Trapani G, Di Rocco C, Abbamondi AL, et al. Light microscopy and ultrastructural studies of Sturge-Weber disease. Childs Brain. 1982;9(1):23-36. X-1. [pmid: 6460599].
14 Edgerton MT. Vascular hamartomas and hemangiomas: classification and treatment. South Med J. Dec. 1982;75(12):1541-7. X-1, X-2. [pmid: 7146992].
15 Fabian JT, Rose AG. Tumours of the heart. A study of 89 cases. S Afr Med J. Jan. 16. 1982;61(3):71-7. X-1. [pmid: 6277017].
16 Felder KS, Brockhurst RJ. Neovascular fundus abnormalities in peripheral uveitis. Arch Ophthalmol. May. 1982;100(5):750-4. X-1. [pmid: 6177305].
17 Fischer EG, Sotrel A, Welch K. Cerebral hemangioma with glial neoplasia (angioglioma?). Report of two cases. J Neurosurg. Mar. 1982;56(3):430-4. X-1. [pmid: 7057243].
18 Gilchrest BA, Rosen S, Noe JM. Chilling port wine stains improves the response to argon laser therapy. Plast Reconstr Surg. Feb. 1982;69(2):278-83. X-1. [pmid: 7054797].
19 Gresty MA, Ell JJ, Findley LJ. Acquired pendular nystagmus: its characteristics, localising value and pathophysiology. J Neurol Neurosurg Psychiatry. May. 1982;45(5):431-9. X-1. [pmid: 7086456].
20 Grundfest-Broniatowski S, Carey WD, Sivak MV Jr, et al. Klippel-Trenaunay-Weber syndrome with visceral involvement and portal hypertension. Cleve Clin Q. Winter. 1982;49(4):239-47. X-1. [pmid: 6301708].
21 Hayman LA, Evans RA, Ferrell RE, et al. Familial cavernous angiomas: natural history and genetic study over a 5-year period. Am J Med Genet. Feb. 1982;11(2):147-60. X-1. [pmid: 6950664].
22 Hurvitz CH, Greenberg SH, Song CH, et al. Hemangiomatosis of the pleura with hemorrhage and disseminated intravascular coagulation. J Pediatr Surg. Feb. 1982;17(1):73-5. X-1, X-2. [pmid: 7077482].
23 Ilbawi M, DeLeon S, Riggs T, et al. Primary vascular tumors of the heart in infancy. Report of a case with successful surgical management. Chest. Apr. 1982;81(4):511-2. X-1. [pmid: 7067518].
24 Kaibara N, Mitsuyasu M, Katsuki I, et al. Generalized enchondromatosis with unusual complications of soft tissue calcifications and hemangiomas. Follow-up for over a twelve-year period. Skeletal Radiol. 1982;8(1):43-6. X-1. [pmid: 7079783].
25 Kalicinski ZH, Joszt W, Perdzynski W, et al. Hemangioma of the superior caval vein. J Pediatr Surg. Apr. 1982;17(2):178-9. X-2. [pmid: 7077501].
26 Kobus K, Licznerski A, Stepniewski J, et al. The surgical treatment of vascular tumours of the face. J Maxillofac Surg. May. 1982;10(2):99-112. X-3, X-4. [pmid: 7047664].
27 Kushner BJ. Intralesional corticosteroid injection for infantile adnexal hemangioma. Am J Ophthalmol. Apr. 1982;93(4):496-506. X-4. [pmid: 7072814].
28 Kveton JF, Pillsbury HC. Conservative treatment of infantile subglottic hemangioma with corticosteroids. Arch Otolaryngol. Feb. 1982;108(2):117-9. X-2. [pmid: 7059313].
29 Ladurner G, Fritsch G, Sager WD, et al. Computer tomography in children with stroke. Eur Neurol. 1982;21(4):235-41. X-1. [pmid: 7117310].
30 Liberski PP, Alwasiak J, Wegrzyn Z, et al. Sturge-Weber syndrome with a unilateral developmental anomaly of the cerebral hemisphere. Neuropatol Pol. 1982;20(3–4):505-10. X-1. [pmid: 7183945].
31 McCarthy JC, Goldberg MJ, Zimbler S. Orthopaedic dysfunction in the blue rubber-bleb nevus syndrome. J Bone Joint Surg Am. Feb. 1982;64(2):280-3. X-1. [pmid: 7056783].
32 Mencke HJ, Zilkens J, Bigalke KH, et al. The problem of intramuscular haemangioma. Arch Orthop Trauma Surg. 1982;100(4):243-7. X-1. [pmid: 7159196].
33 Moazam F, Talbert JL, Rodgers BM. Primary tumors of the liver in infancy and childhood. J Fla Med Assoc. Dec. 1982;69(12):991-6. X-2. [pmid: 6296270].
34 Moss LA, Stueber K, Hafiz MA. Congenital hemangioendothelioma of the hand--case report. J Hand Surg Am. Jan. 1982;7(1):53-6. X-1. [pmid: 7061809].
35 Nguyen L, Shandling B, Ein S, et al. Hepatic hemangioma in childhood: medical management or surgical management?. J Pediatr Surg. Oct. 1982;17(5):576-9. X-1. [pmid: 7175647].
36 Niechajev IA, Karlsson S. Angiomatosis osteohypotrophica. Scand J Plast Reconstr Surg. 1982;16(1):77-85. X-1. [pmid: 7112039].
37 Niechajev IA, Karlsson S. Vascular tumours of the hand. Scand J Plast Reconstr Surg. 1982;16(1):67-75. X-1. [pmid: 7112038].
38 Norins AL, Treadwell PA. The management of persistent pediatric skin problems. Pediatr Clin North Am. Feb. 1982;29(1):37-53. X-1, X-2. [pmid: 6460218].
39 Ogawa Y, Inoue K. Electrothrombosis as a treatment of cirsoid angioma in the face and scalp and varicosis of the leg. Plast Reconstr Surg. Sep. 1982;70(3):310-8. X-1. [pmid: 7111485].
40 Pereyra R, Andrassy RJ, Mahour GH. Management of massive hepatic hemangiomas in infants and children: a review of 13 cases. Pediatrics. Aug. 1982;70(2):254-8. X-3, X-4. [pmid: 7099792].
41 Polus K. Skin haemangioma: treatment by cryosurgery. Acta Paediatr Acad Sci Hung. 1982;23(2):167-70. X-3, X-4. [pmid: 7136598].
42 Pretorius HT, Katikineni M, Kinsella TJ, et al. Thyroid nodules after high-dose external radiotherapy. Fine-needle aspiration cytology in diagnosis and management. Jama. Jun. 18. 1982;247(23):3217-20. X-1, X-2. [pmid: 7087060].
43 Price JB Jr, Schullinger JN, Santulli TV. Major hepatic resections for neoplasia in children. Arch Surg. Sep. 1982;117(9):1139-41. X-1. [pmid: 6287966].
44 Ramming KP, Holmes EC, Zarem HA, et al. Surgical management and reconstruction of extensive chest wall malignancies. Am J Surg. Jul. 1982;144(1):146-52. X-1. [pmid: 6953769].
45 Randall PA. Vascular mass. Preoperative occlusion of feeding vessel. N Y State J Med. Feb. 1982;82(2):189-91. X-1, X-2. [pmid: 6952084].
46 Ricketts RR, Stryker S, Raffensperger JG. Ventral fasciotomy in the management of hepatic hemangioendothelioma. J Pediatr Surg. Apr. 1982;17(2):187-8. X-1. [pmid: 6210769].
47 Sadan N, Sade J, Grunebaum M. The treatment of subglottic hemangiomas of infants with prednisone. Int J Pediatr Otorhinolaryngol. Mar. 1982;4(1):7-14. X-4. [pmid: 7095995].
48 Sanborn GE, Augsburger JJ, Shields JA. Treatment of circumscribed choroidal hemangiomas. Ophthalmology. Dec. 1982;89(12):1374-80. X-1. [pmid: 6891765].
49 Schneeweiss A, Blieden LC, Shem-Tov A, et al. Coarctation of the aorta with congenital hemangioma of the face and neck and aneurysm or dilatation of a subclavian or innominate artery. A new syndrome? Chest. Aug. 1982;82(2):186-7. X-1. [pmid: 7047095].
50 Shannon K, Buchanan GR, Votteler TP. Multiple hepatic hemangiomas: failure of corticosteroid therapy and successful hepatic artery ligation. Am J Dis Child. Mar. 1982;136(3):275-6. X-2. [pmid: 7064957].
51 Starzl TE, Iwatsuki S, Shaw BW Jr, et al. Left hepatic trisegmentectomy. Surg Gynecol Obstet. Jul. 1982;155(1):21-7. X-1. [pmid: 6283687].
52 Verity CM, Strauss EH, Moyes PD, et al. Long-term follow-up after cerebral hemispherectomy: neurophysiologic, radiologic, and psychological findings. Neurology. Jun. 1982;32(6):629-39. X-1. [pmid: 7201093].
53 Abad JM, Alvarez F, Manrique M, et al. Cerebral arteriovenous malformations. Comparative results of surgical vs conservative treatment in 112 cases. J Neurosurg Sci. Jul–Sep. 1983;27(3):203-10. X-1. [pmid: 6663354].
54 Bart RS, Kopf AW. Tumor conference #50. Untreated massive hemangioma with satisfactory outcome. J Dermatol Surg Oncol. Nov. 1983;9(11):875-7. X-2. [pmid: 6630701].
55 Becht EW, Rumpelt HJ, Frohneberg D, et al. Angioma-like pseudometamorphosis in Wilms’ tumors subjected to preoperative radio- and chemotherapy. Pathol Res Pract. Jun. 1983;177(1):22-31. X-1. [pmid: 6312438].
56 Bendl BJ, Bashir R, Dowling AD. Sturge-Weber syndrome. Cutis. Mar. 1983;31(3):286-94. X-1. [pmid: 6839805].
57 Benjamin B, Carter P. Congenital laryngeal hemangioma. Ann Otol Rhinol Laryngol. Sep–Oct. 1983;92(5 Pt 1):448-55. X-2. [pmid: 6625442].
58 Bernhard LM, Brant RG, Bakst MJ, et al. Hypertrophic hemangioma vs. hemangiopericytoma. J Foot Surg. Winter. 1983;22(4):308-13. X-1. [pmid: 6643939].
59 Bouwman DL, Walt AJ. Current status of resection for hepatic neoplasms. Semin Liver Dis. Aug. 1983;3(3):193-202. X-1. [pmid: 6623102].
60 Browne AF, Katz S, Miser J, et al. Blue Rubber Bleb Nevi as a cause of intussusception. J Pediatr Surg. Feb. 1983;18(1):7-9. X-1. [pmid: 6834229].
61 Charboneau JW, Hattery RR, Ernst EC 3rd, et al. Spectrum of sonographic findings in 125 renal masses other than benign simple cyst. AJR Am J Roentgenol. Jan. 1983;140(1):87-94. X-1. [pmid: 6295123].
62 Chew E, Morin JD. Glaucoma in children. Pediatr Clin North Am. Dec. 1983;30(6):1043-60. X-1. [pmid: 6646864].
63 Corbella F, Arico M, Podesta AF, et al. Infantile hepatic hemangioendothelioma treated by radiotherapy. Pediatr Radiol. 1983;13(5):297-300. X-1. [pmid: 6622093].
64 Crow J, Gibbs DA, Cozens W, et al. Biochemical and histopathological studies on patients with mucopolysaccharidoses, two of whom had been treated by fibroblast transplantation. J Clin Pathol. Apr. 1983;36(4):415-30. X-1. [pmid: 6403596].
65 Dachman AH, Lichtenstein JE, Friedman AC, et al. Infantile hemangioendothelioma of the liver: a radiologic-pathologic-clinical correlation. AJR Am J Roentgenol. Jun. 1983;140(6):1091-6. X-1. [pmid: 6602472].
66 David TJ, Evans DI, Stevens RF. Haemangioma with thrombocytopenia (Kasabach-Merritt syndrome). Arch Dis Child. Dec. 1983;58(12):1022-3. X-1. [pmid: 6660888].
67 Edmondson HA, Peters RL. Tumors of the liver: pathologic features. Semin Roentgenol. Apr. 1983;18(2):75-83. X-1, X-2. [pmid: 6306841].
68 Ehren H, Mahour GH, Isaacs H Jr, et al. Benign liver tumors in infancy and childhood. Report of 48 cases. Am J Surg. Mar. 1983;145(3):325-9. X-3, X-4. [pmid: 6837854].
69 Esterly NB. Kasabach-Merritt syndrome in infants. J Am Acad Dermatol. Apr. 1983;8(4):504-13. X-1. [pmid: 6853783].
70 Ford CN. Serial excision and advancement flaps in the management of facial lesions. Otolaryngol Head Neck Surg. Apr. 1983;91(2):156-64. X-1. [pmid: 6408572].
71 Gibbs DA, Spellacy E, Tompkins R, et al. A clinical trial of fibroblast transplantation for the treatment of mucopolysaccharidoses. J Inherit Metab Dis. 1983;6(2):62-81. X-1. [pmid: 6410119].
72 Gonzalez DG, Breur K. Clinical data from irradiated growing long bones in children. Int J Radiat Oncol Biol Phys. Jun. 1983;9(6):841-6. X-1. [pmid: 6863057].
73 Gu BK. 10 cases of cavernous hemangioma treated with injection of “Xiao Zhi Ling” solution. J Tradit Chin Med. Dec. 1983;3(4):289-90. X-1. [pmid: 6325829].
74 Haik BG, Clancy P, Ellsworth RM, et al. Ocular manifestations in diffuse neonatal hemangiomatosis. J Pediatr Ophthalmol Strabismus. May–Jun. 1983;20(3):101-5. X-1. [pmid: 6864423].
75 Hall JG, Reed SD, Driscoll EP. Part I. Amyoplasia: a common, sporadic condition with congenital contractures. Am J Med Genet. Aug. 1983;15(4):571-90. X-1. [pmid: 6614047].
76 Hanchard B, Persaud V, Kerr G, et al. Primary infantile haemangioendothelioma of the liver. West Indian Med J. Mar. 1983;32(1):44-7. X-1. [pmid: 6868571].
77 Healy M, Herz DA, Pearl L. Spinal hemangiomas. Neurosurgery. Dec. 1983;13(6):689-91. X-1. [pmid: 6657023].
78 Hobby LW. Further evaluation of the potential of the argon laser in the treatment of strawberry hemangiomas. Plast Reconstr Surg. Apr. 1983;71(4):481-9. X-2. [pmid: 6681910].
79 Hurwitz A, Milwidsky A, Yarkoni S, et al. Severe fetal distress with hydramnios due to chorioangioma. Acta Obstet Gynecol Scand. 1983;62(6):633-5. X-1. [pmid: 6367341].
80 Jacobs AH. Vascular nevi. Pediatr Clin North Am. Jun. 1983;30(3):465-82. X-2. [pmid: 6877893].
81 Kadir S, Ernst CB, Hamper U, et al. Management of vascular soft tissue neoplasms using transcatheter embolization and surgical excision. Am J Surg. Sep. 1983;146(3):409-12. X-1. [pmid: 6614340].
82 Keeling JW, Gough DJ, Iliff P. The pathology of non-Rhesus hydrops. Diagn Histopathol. Apr–Jun. 1983;6(2):89-111. X-1. [pmid: 6661995].
83 Ketonen L, Koskiniemi ML. Gyriform calcification after herpes simplex virus encephalitis. J Comput Assist Tomogr. Dec. 1983;7(6):1070-2. X-1. [pmid: 6630636].
84 Koerper MA, Addiego JE Jr, de Lorimier AA, et al. Use of aspirin and dipyridamole in children with platelet trapping syndromes. J Pediatr. Feb. 1983;102(2):311-4. X-1. [pmid: 6822944].
85 Kopf AW, Bart RS. Tumor Conference #48. Massive congenital hemangioma resulting in death. J Dermatol Surg Oncol. Jul. 1983;9(7):509-12. X-1. [pmid: 6853818].
86 Kumakiri M, Muramoto F, Tsukinaga I, et al. Crystalline lamellae in the endothelial cells of a type of hemangioma characterized by the proliferation of immature endothelial cells and pericytes--angioblastoma (Nakagawa). J Am Acad Dermatol. Jan. 1983;8(1):68-75. X-1. [pmid: 6826810].
87 Landwehr AJ, Starink TM. Inflammatory linear verrucous epidermal naevus. Report of a case with bilateral distribution and nail involvement. Dermatologica. 1983;166(2):107-9. X-1. [pmid: 6852314].
88 Lavyne MH, Patterson RH Jr, et al. Subchoroidal trans-velum interpositum approach to mid-third ventricular tumors. Neurosurgery. Jan. 1983;12(1):86-94. X-1. [pmid: 6828226].
89 Majchrzak H, Wencel T, Bierzynska-Macyszyn G, et al. Possible significance of juvenile oral venous angioma as marker of intracerebral vascular lesion. J Neurosurg. Aug. 1983;59(2):348-50. X-1. [pmid: 6864304].
90 Maurer AH, Holder LE, Espinola DA, et al. Three-phase radionuclide scintigraphy of the hand. Radiology. Mar. 1983;146(3):761-75. X-1. [pmid: 6219422].
91 Moazam F, Rodgers BM, Talbert JL. Hepatic artery ligation for hepatic hemangiomatosis of infancy. J Pediatr Surg. Apr. 1983;18(2):120-3. X-1. [pmid: 6854487].
92 Muhlbauer JE, Margolis RJ, Mihm MC Jr, et al. Minimal deviation melanoma: a histologic variant of cutaneous malignant melanoma in its vertical growth phase. J Invest Dermatol. Jun. 1983;80(Suppl):63s-5s. X-1. [pmid: 6854057].
93 Nair K, Khera SS, Chitre AP, et al. Cryosurgery in the management of haemangiomas. J Indian Dent Assoc. Nov. 1983;55(11):463-6. X-1. [pmid: 6590630].
94 Ohshiro T, Maruyama Y. The ruby and argon lasers in the treatment of naevi. Ann Acad Med Singapore. Apr. 1983;12(2 Suppl):388-95. X-1, X-2. [pmid: 6684895].
95 Paller AS, Esterly NB, Charrow J, et al. Pedal hemangiomas in Turner syndrome. J Pediatr. Jul. 1983;103(1):87-8. X-1, X-2. [pmid: 6864400].
96 Palmieri TJ. Subcutaneous hemangiomas of the hand. J Hand Surg Am. Mar. 1983;8(2):201-4. X-1. [pmid: 6300216].
97 Plesner-Rasmussen HJ, Marushak D, Andersen M. Sequelae of capillary hemangiomas of the eyelids and orbita. Scand J Plast Reconstr Surg. 1983;17(3):241-5. X-2. [pmid: 6673091].
98 Plesner-Rasmussen HJ, Marushak D, Goldschmidt E. Capillary haemangiomas of the eyelids and orbit. A review of 5 children. Acta Ophthalmol (Copenh). Aug. 1983;61(4):645-54. X-2. [pmid: 6637426].
99 Roberts JW, Devine CJ Jr, et al. Urethral hemangioma: treatment by total excision and grafting. J Urol. May. 1983;129(5):1053-4. X-1. [pmid: 6343630].
100 Rydholm A, Berg NO. Size, site and clinical incidence of lipoma. Factors in the differential diagnosis of lipoma and sarcoma. Acta Orthop Scand. Dec. 1983;54(6):929-34. X-1. [pmid: 6670522].
101 Savoiardo M, Strada L, Passerini A. Cavernous hemangiomas of the orbit: value of CT, angiography, and phlebography. AJNR Am J Neuroradiol. May–Jun. 1983;4(3):741-4. X-1. [pmid: 6410846].
102 Schwechheimer K, Kuhl G. Arteriovenous angioma of the vein of Galen causing cardiac failure in the neonate. Report on clinical and pathological findings in two cases. Neuropediatrics. Aug. 1983;14(3):184-7. X-1. [pmid: 6621811].
103 Shah K. Computed tomography and radiotherapy in giant hemangioma with thrombocytopenia. Comput Radiol. Sep–Oct. 1983;7(5):319-22. X-1, X-2. [pmid: 6641198].
104 Solbiati L, Bossi MC, Bellotti E, et al. Focal lesions in the spleen: sonographic patterns and guided biopsy. AJR Am J Roentgenol. Jan. 1983;140(1):59-65. X-1. [pmid: 6600326].
105 Stanley P, Grinnell VS, Stanton RE, et al. Therapeutic embolization of infantile hepatic hemangioma with polyvinyl alcohol. AJR Am J Roentgenol. Nov. 1983;141(5):1047-51. X-2. [pmid: 6605046].
106 Stillman AE, Hansen RC, Hallinan V, et al. Diffuse neonatal hemangiomatosis with severe gastrointestinal involvement. Favorable response to steroid therapy. Clin Pediatr (Phila). Aug. 1983;22(8):589-91. X-1. [pmid: 6602682].
107 Swerlick RA, Cooper PH. Pyogenic granuloma (lobular capillary hemangioma) within port-wine stains. J Am Acad Dermatol. May. 1983;8(5):627-30. X-1. [pmid: 6863618].
108 Trastek VF, van Heerden JA, Sheedy PF 2nd, et al. Cavernous hemangiomas of the liver: resect or observe?. Am J Surg. Jan. 1983;145(1):49-53. X-1. [pmid: 6849494].
109 Vorse HB, Smith EI, Luckstead EF, et al. Hepatic hemangiomatosis of infancy. Am J Dis Child. Jul. 1983;137(7):672-3. X-1. [pmid: 6858982].
110 Wu MC, Zhang XH, Chen H, et al. Experiences in 467 cases of hepatic resection. Acta Acad Med Wuhan. 1983;3(1):1-7. X-1. [pmid: 6866375].
111 Yoshida T, Kuratomi K, Mitsumasu T. Benign neoplasms of the larynx. A 10-year review of 38 patients. Auris Nasus Larynx. 1983;10(Suppl):S61-71. X-2. [pmid: 6316888].
112 Young PH. Lumbar hemangioendothelioma. Surg Neurol. Jul. 1983;20(1):55-6. X-1. [pmid: 6867929].
113 Zocchi D, Innao V, Calderoni P. Maffucci’s syndrome. Report of 3 cases and review of the literature. Ital J Orthop Traumatol. Jun. 1983;9(2):263-6. X-1. [pmid: 6654663].
114 Special symposia. The management of disseminated eruptive hemangiomata in infants. Pediatr Dermatol. Apr. 1984;1(4):312-7. X-1. [pmid: 6494071].
115 Abramson DH. Intraocular tumors. Hosp Pract (Off Ed). Oct. 1984;19(10):97-106. X-1. [pmid: 6434568].
116 Adzick NS, Strome M, Gang D, et al. Cryotherapy of subglottic hemangioma. J Pediatr Surg. Aug. 1984;19(4):353-7. X-2. [pmid: 6481576].
117 Bakker-Niezen SH, Walder HA, Merx JL. The tethered spinal cord syndrome. Z Kinderchir. Dec. 1984;39(Suppl 2):100-3. X-1. [pmid: 6395542].
118 Bart RS, Kopf AW. Tumor conference #53. Necrotizing hemangioma. J Dermatol Surg Oncol. Oct. 1984;10(10):769-73. X-2. [pmid: 6491015].
119 Bluemm RG, Baleriaux D, Lausberg G, et al. Initial experience with MR-imaging of intracranial midline-lesions and lesions of the cervical spine at half Tesla. Neurosurg Rev. 1984;7(4):287-302. X-1. [pmid: 6099524].
120 Carruth JA. Argon laser in the treatment of port wine stains. J R Soc Med. Sep. 1984;77(9):722-4. X-3, X-4. [pmid: 6481751].
121 Carvell JE, Chopin D. Infantile idiopathic scoliosis in hemihypertrophy with haemangiomatosis. J R Coll Surg Edinb. Sep. 1984;29(5):321-5. X-1. [pmid: 6094802].
122 Chen TJ, Kuo T. Giant intracranial Masson’s hemangioma. Report of a fatal case. Arch Pathol Lab Med. Jul. 1984;108(7):555-6. X-2. [pmid: 6547319].
123 Chuong R, Donoff RB. Intraparotid hemangioma in an adult. Case report and review of the literature. Int J Oral Surg. Aug. 1984;13(4):346-51. X-1. [pmid: 6434455].
124 Cibis GW, Tripathi RC, Tripathi BJ. Glaucoma in Sturge-Weber syndrome. Ophthalmology. Sep. 1984;91(9):1061-71. X-1. [pmid: 6493715].
125 Crandall AS. Developmental ocular abnormalities and glaucoma. Int Ophthalmol Clin. Spring. 1984;24(1):73-86. X-1. [pmid: 6443569].
126 Demuth RJ, Miller SH, Keller F. Complications of embolization treatment for problem cavernous hemangiomas. Ann Plast Surg. Aug. 1984;13(2):135-44. X-1. [pmid: 6476734].
127 Desgrippes Y, Bensahel H, Sonsino E, et al. Atypical bone angiomas in children. Ital J Orthop Traumatol. Jun. 1984;10(2):251-5. X-1. [pmid: 6381397].
128 Dixon JA, Rotering RH, Huether SE. Patient’s evaluation of argon laser therapy of port wine stain, decorative tattoo, and essential telangiectasia. Lasers Surg Med. 1984;4(2):181-90. X-1. [pmid: 6472031].
129 Fitzsimons R. Intralesional corticosteroid injection of infantile adnexal haemangioma. Trans Ophthalmol Soc N Z. 1984;36:74-5. X-2. [pmid: 6591621].
130 Folkman J. Toward a new understanding of vascular proliferative disease in children. Pediatrics. Nov. 1984;74(5):850-6. X-1. [pmid: 6208529].
131 Garcia RL, Dixon SL. Occlusion amblyopia secondary to a mixed capillary-cavernous hemangioma. J Am Acad Dermatol. Feb. 1984;10(2 Pt 1):263-7. X-1. [pmid: 6715593].
132 Gooding CA, Brasch RC, Lallemand DP, et al. Nuclear magnetic resonance imaging of the brain in children. J Pediatr. Apr. 1984;104(4):509-15. X-1. [pmid: 6707810].
133 Greene EE, Iams JD. Chorioangioma: a case presentation. Am J Obstet Gynecol. Apr. 15. 1984;148(8):1146-8. X-1. [pmid: 6711654].
134 Hachisuga T, Hashimoto H, Enjoji M. Angioleiomyoma. A clinicopathologic reappraisal of 562 cases. Cancer. Jul. 1. 1984;54(1):126-30. X-1. [pmid: 6722737].
135 Hanada T, Nakahara S, Takita H, et al. 111In-labelled platelet scintigraphy in Kasabach-Merritt syndrome. Nihon Ketsueki Gakkai Zasshi. Sep. 1984;47(6):1359-65. X-1. [pmid: 6542736].
136 Hawkins DB, Crockett DM, Kahlstrom EJ, et al. Corticosteroid management of airway hemangiomas: long-term follow-up. Laryngoscope. May. 1984;94(5 Pt 1):633-7. X-2. [pmid: 6717220].
137 Heffner DK. Problems in pediatric otorhinolaryngic pathology. V. Diseases of the larynx and trachea. Int J Pediatr Otorhinolaryngol. Jul. 1984;7(3):203-19. X-1. [pmid: 6480230].
138 Heikkinen ES, Salminen PM. Surgical treatment of congenital thoraco-brachial arterio-venous macrofistula, complicated by haemorrhage, infection and congestive heart failure. Z Kinderchir. Oct. 1984;39(5):337-8. X-1. [pmid: 6516595].
139 Hermann G, Yeh HC, Schwartz I. Computed tomography of soft-tissue lesions of the extremities, pelvic and shoulder girdles: sonographic and pathological correlations. Clin Radiol. May. 1984;35(3):193-202. X-1, X-2. [pmid: 6713795].
140 Howell DM, Gumbiner CH, Martin GE. Congestive heart failure due to giant cutaneous cavernous hemangioma. Clin Pediatr (Phila). Sep. 1984;23(9):504-6. X-1. [pmid: 6467784].
141 Ikegami N, Nishijima K. Hemangioma of the buccal pad with phlebolithiasis: report of a case. Acta Med Okayama. Feb. 1984;38(1):79-87. X-1. [pmid: 6702488].
142 Johnson DH, Vinson AM, Wirth FH, et al. Management of hepatic hemangioendotheliomas of infancy by transarterial embolization: a report of two cases. Pediatrics. Apr. 1984;73(4):546-9. X-1. [pmid: 6709438].
143 Jooma R, Kendall BE, Hayward RD. Intracranial tumors in neonates: a report of seventeen cases. Surg Neurol. Feb. 1984;21(2):165-70. X-1. [pmid: 6322370].
144 Kaplan I, Sarig A, Taube E, et al. The CO2 laser in pediatric surgery. J Pediatr Surg. Jun. 1984;19(3):248-57. X-1. [pmid: 6431072].
145 Katoh H, Nakajima T, Yoshimura Y. The double-Z rhomboid plasty: an improvement in design. Plast Reconstr Surg. Dec. 1984;74(6):817-24. X-1. [pmid: 6505101].
146 Khosla VK, Banerjee AK, Mathuriya SN, et al. Giant cystic cavernoma in a child. Case report. J Neurosurg. Jun. 1984;60(6):1297-9. X-1. [pmid: 6726375].
147 Kulkarni MV, Shaff MI, Sandler MP, et al. Evaluation of renal masses by MR imaging. J Comput Assist Tomogr. Oct. 1984;8(5):861-5. X-1. [pmid: 6088602].
148 Lazerson J. An invasive hemangioma and failure to thrive. Hosp Pract (Off Ed). Dec. 1984;19(12):32. 4. X-2. [pmid: 6438131].
149 Leavitt A. Cavernous hemangioma of the face, larynx, and subglottic region. Med Pediatr Oncol. 1984;12(6):377-9. X-1. [pmid: 6503857].
150 Luna RF, Resende C, Tishler JM, et al. Computerized tomography in evaluation of hepatic neoplasms. South Med J. Aug. 1984;77(8):1015-9. X-1. [pmid: 6087466].
151 Lyon AJ, Johnson J. Non immune hydrops fetalis. J R Army Med Corps. Feb. 1984;130(1):66-8. X-1. [pmid: 6716361].
152 Ma GF, Leung PC. The management of the soft-tissue haemangiomatous manifestations of Maffucci’s syndrome. Br J Plast Surg. Oct. 1984;37(4):615-8. X-1. [pmid: 6498405].
153 Maddox JL Jr, Riordan TP, Odom RB. Pyomyositis in a neonate. J Am Acad Dermatol. Feb. 1984;10(2 Pt 2):391-4. X-1. [pmid: 6707262].
154 Maeda K. A successful case of urethral reconstruction in a child with persistent urethral bleeding due to an extensive cavernous haemangioma. Br J Plast Surg. Oct. 1984;37(4):536-8. X-1. [pmid: 6498393].
155 McBride JT. Stridor in childhood. J Fam Pract. Dec. 1984;19(6):782-90. X-1. [pmid: 6502082].
156 McIntosh C, Dehkharghani F. The neurocutaneous syndromes: diagnosis and management for the primary care pediatrician. J Ark Med Soc. Dec. 1984;81(7):354-60. X-1. [pmid: 6240482].
157 Messmer E, Font RL, Laqua H, et al. Cavernous hemangioma of the retina. Immunohistochemical and ultrastructural observations. Arch Ophthalmol. Mar. 1984;102(3):413-8. X-1. [pmid: 6538410].
158 Mizono G, Dedo HH. Subglottic hemangiomas in infants: treatment with CO2 laser. Laryngoscope. May. 1984;94(5 Pt 1):638-41. X-4. [pmid: 6717221].
159 Nelson LB, Melick JE, Harley RD. Intralesional corticosteroid injections for infantile hemangiomas of the eyelid. Pediatrics. Aug. 1984;74(2):241-5. X-2. [pmid: 6462821].
160 Newman SL, Goodwin CD. Colonic hemangioma in childhood. Diagnostic and therapeutic contribution of colonoscopy. Clin Pediatr (Phila). Oct. 1984;23(10):584-5. X-1. [pmid: 6331940].
161 Nielsen G. Arteriovenous malformations as a cause of congestive heart failure in the newborn and infant. Three cases with different haemodynamic mechanisms. Eur J Pediatr. Sep. 1984;142(4):298-300. X-1. [pmid: 6541577].
162 Nistal M, Paniagua R, Fuentes E, et al. Histogenesis of adenomatoid tumour associated to pseudofibromatous periorchitis in an infant with hydrocele. J Pathol. Dec. 1984;144(4):275-80. X-1. [pmid: 6520651].
163 Noronha R, Gonzalez-Crussi F. Hepatic angiosarcoma in childhood. A case report and review of the literature. Am J Surg Pathol. Nov. 1984;8(11):863-71. X-1. [pmid: 6542321].
164 Novitzky D, Rose AG, Morgan JA, et al. Primary cardiac haemangiomas. A report of 2 cases. S Afr Med J. Aug. 18. 1984;66(7):267-70. X-1. [pmid: 6463804].
165 Pasyk KA, Dingman RO, Argenta LC, et al. The management of hemangiomas of the eyelid and orbit. Head Neck Surg. Mar–Apr. 1984;6(4):851-7. X-2. [pmid: 6706624].
166 Persky MS, Berenstein A, Cohen NL. Combined treatment of head and neck vascular masses with preoperative embolization. Laryngoscope. Jan. 1984;94(1):20-7. X-2. [pmid: 6690874].
167 Person VA, Lembach LJ, Tax HR, et al. Case comparisons of arch-area arteriovenous fistula and cavernous hemangioma. J Am Podiatry Assoc. Nov. 1984;74(11):569-71. X-1. [pmid: 6501778].
168 Petersen KE. ACTH in normal children and children with pituitary and adrenal diseases. II. Plasma ACTH (cortisol and growth hormone) values during insulin hypoglycaemia--patients with idiopathic hypopituitarism and intracranial tumour. Acta Paediatr Scand. May. 1984;73(3):372-8. X-1. [pmid: 6331059].
169 Pitanguy I, Caldeira AM, Calixto CA, et al. Clinical evaluation and surgical treatment of hemangiomata. Head Neck Surg. Oct. 1984;7(1):47-59. X-1, X-2. [pmid: 6490384].
170 Rao PL, Nair KV, Nooruddin SM, et al. Cryosurgery in the management of hemangiomas in children. Indian Pediatr. Feb. 1984;21(2):139-43. X-4. [pmid: 6469296].
171 Richardson MA, Cotton RT. Anatomic abnormalities of the pediatric airway. Pediatr Clin North Am. Aug. 1984;31(4):821-34. X-1. [pmid: 6462801].
172 Riggs T, Sholl JS, Ilbawi M, et al. In utero diagnosis of pericardial tumor with successful surgical repair. Pediatr Cardiol. Jan–Mar. 1984;5(1):23-5. X-1. [pmid: 6462925].
173 Rosen I, Salford L, Starck L. Sturge-Weber disease--neurophysiological evaluation of a case with secondary epileptogenesis, successfully treated with lobe-ectomy. Neuropediatrics. May. 1984;15(2):95-8. X-1. [pmid: 6738822].
174 Rothfus WE, Albright AL, Casey KF, et al. Cerebellar venous angioma: “benign” entity?. AJNR Am J Neuroradiol. Jan–Feb. 1984;5(1):61-6. X-1. [pmid: 6421127].
175 Ryan EA, Reiss E. Oncogenous osteomalacia. Review of the world literature of 42 cases and report of two new cases. Am J Med. Sep. 1984;77(3):501-12. X-1. [pmid: 6548080].
176 Salyer KE. Use of a new hemostatic scalpel in plastic surgery. Ann Plast Surg. Dec. 1984;13(6):532-8. X-1. [pmid: 6441505].
177 Sant GR, Heaney JA, Ucci AA Jr, et al. Computed tomographic findings in renal angiomyolipoma: an histologic correlation. Urology. Sep. 1984;24(3):293-6. X-1. [pmid: 6474646].
178 Sasaki GH, Pang CY, Wittliff JL. Pathogenesis and treatment of infant skin strawberry hemangiomas: clinical and in vitro studies of hormonal effects. Plast Reconstr Surg. Mar. 1984;73(3):359-70. X-1. [pmid: 6701212].
179 Schmidt RP, Lentle BC. Hemangioma with consumptive coagulopathy (Kasabach-Merritt syndrome) detection by indium-111 oxine-labeled platelets. Clin Nucl Med. Jul. 1984;9(7):389-91. X-1, X-2. [pmid: 6432394].
180 Smith JD, Cook TA. Argon laser treatment of hemangiomas in children. Int J Pediatr Otorhinolaryngol. May. 1984;7(2):153-8. X-1. [pmid: 6540251].
181 Sondel PM, Ritter MW, Wilson DG, et al. Use of 111In platelet scans in the detection and treatment of Kasabach-Merritt syndrome. J Pediatr. Jan. 1984;104(1):87-9. X-1. [pmid: 6690678].
182 Stringel G, Mercer S. Giant hemangioma in the newborn and infant. Complications and management. Clin Pediatr (Phila). Sep. 1984;23(9):498-502. X-1, X-2. [pmid: 6467783].
183 Suzuki J, Katakura R, Mori T. Interhemispheric approach through the lamina terminalis to tumors of the anterior part of the third ventricle. Surg Neurol. Aug. 1984;22(2):157-63. X-1. [pmid: 6740479].
184 Tax HR. The handicapped child. Clin Podiatry. Dec. 1984;1(3):459-76. X-1. [pmid: 6242142].
185 Tschappeler H. CT-evaluation of the pediatric mediastinum. Ann Radiol (Paris). Feb–Mar. 1984;27(2–3):160-5. X-1. [pmid: 6721423].
186 Tsementzis SA, Kennett RP, Hitchcock ER. Rupture of intracranial vascular lesions during arteriography. J Neurol Neurosurg Psychiatry. Aug. 1984;47(8):795-8. X-1. [pmid: 6470721].
187 Wakai S, Chiu CW. Rare combination of spinal lesions and spina bifida occulta: case report. Dev Med Child Neurol. Feb. 1984;26(1):117-21. X-1. [pmid: 6365665].
188 Weber TR, West KW, Cohen M, et al. Massive hemangioma in infants: therapeutic considerations. J Vasc Surg. May. 1984;1(3):423-8. X-4. [pmid: 6481892].
189 Weinblatt ME, Kahn E, Kochen JA. Hemangioendothelioma with intravascular coagulation and ischemic colitis. Cancer. Nov. 15. 1984;54(10):2300-4. X-1. [pmid: 6488150].
190 Achauer BM, Vander Kam VM. Argon laser treatment of strawberry hemangioma in infancy. West J Med. Nov. 1985;143(5):628-32. X-4. [pmid: 4082569].
191 Adelt D, Zeumer H, Wolters J. Surgical treatment of cerebral arteriovenous malformations. Follow-up study of 43 cases. Acta Neurochir (Wien). 1985;76(1–2):45-9. X-1. [pmid: 4003127].
192 Alkalay AL, Puri AR, Pomerance JJ, et al. Mesenchymal hamartoma of the liver responsive to cyclophosphamide therapy: therapeutic approach. J Pediatr Surg. Apr. 1985;20(2):125-8. X-1. [pmid: 4009357].
193 Alpers CE, Edwards MS. Hemangiomatous anomaly of bone in Crouzon’s syndrome: case report. Neurosurgery. Mar. 1985;16(3):391-4. X-1. [pmid: 3982620].
194 Alt B, Hafez GR, Trigg M, et al. Angiosarcoma of the liver and spleen in an infant. Pediatr Pathol. 1985;4(3–4):331-9. X-1. [pmid: 3835556].
195 Alves JC, Fernal WH, Christo MC, et al. Giant haemangioma of the thigh (Kasabach-Merritt syndrome): resection with temporary clamping of the common iliac artery. Br J Plast Surg. Jul. 1985;38(3):426-8. X-1, X-2. [pmid: 4040413].
196 Apfelberg DB, Maser MR, Lash H, et al. Benefits of the CO2 laser in oral hemangioma excision. Plast Reconstr Surg. Jan. 1985;75(1):46-50. X-4. [pmid: 3917570].
197 Arodi J, Auslender R, Atad J, et al. Giant chorioangioma of the placenta. Acta Obstet Gynecol Scand. 1985;64(1):91-2. X-1. [pmid: 3883693].
198 Bonafe JL, Laffitte F, Chavoin JP, et al. Hyperpigmentation induced by argon laser therapy of hemangiomas. Optical and electron microscope studies. Dermatologica. 1985;170(5):225-9. X-1. [pmid: 4007217].
199 Burrows PE, Rosenberg HC, Chuang HS. Diffuse hepatic hemangiomas: percutaneous transcatheter embolization with detachable silicone balloons. Radiology. Jul. 1985;156(1):85-8. X-1, X-2. [pmid: 4001425].
200 Chadduck WM, Binet EF, Farrell FW Jr, et al. Intraventricular cavernous hemangioma: report of three cases and review of the literature. Neurosurgery. Feb. 1985;16(2):189-97. X-1. [pmid: 3974830].
201 Clodius L. Surgery for the extensive facial port-wine stain?. Aesthetic Plast Surg. 1985;9(2):61-8. X-1. [pmid: 3895849].
202 Cotton RT, Tewfik TL. Laryngeal stenosis following carbon dioxide laser in subglottic hemangioma. Report of three cases. Ann Otol Rhinol Laryngol. Sep–Oct. 1985;94(5 Pt 1):494-7. X-2. [pmid: 3931531].
203 Craig RD, Purser JM, Lessells AM, et al. Argon laser therapy for cutaneous lesions. Br J Plast Surg. Apr. 1985;38(2):148-55. X-1. [pmid: 3986414].
204 Crockett DM, Healy GB, McGill TJ, et al. Benign lesions of the nose, oral cavity, and oropharynx in children: excision by carbon dioxide laser. Ann Otol Rhinol Laryngol. Sep–Oct. 1985;94(5 Pt 1):489-93. X-2. [pmid: 3931530].
205 Davis C, Symon L. The management of cerebral arteriovenous malformations. Acta Neurochir (Wien). 1985;74(1–2):4-11. X-1. [pmid: 3976444].
206 Dreno B, Patrice T, Litoux P, et al. The benefit of chilling in argon-laser treatment of port-wine stains. Plast Reconstr Surg. Jan. 1985;75(1):42-5. X-1. [pmid: 3966106].
207 Enjolras O, Riche MC, Merland JJ. Facial port-wine stains and Sturge-Weber syndrome. Pediatrics. Jul. 1985;76(1):48-51. X-1. [pmid: 4011357].
208 Feingold M. Picture of the month. Hemangioma and lymphangioma of the nose. Am J Dis Child. Mar. 1985;139(3):319-20. X-1, X-2. [pmid: 3976616].
209 Fischer AQ, Leibrock LG, Anderson JC. Evaluation of congenital extracranial masses by waterpath sonography. Pediatr Neurol. Mar–Apr. 1985;1(2):117-9. X-1. [pmid: 3880395].
210 Foley WD, Milde MW. Intra-arterial digital subtraction angiography. Radiol Clin North Am. Jun. 1985;23(2):293-319. X-1. [pmid: 2986195].
211 Frerebeau P, Benezech J, Segnarbieux F, et al. Intraventricular tumors in tuberous sclerosis. Childs Nerv Syst. 1985;1(1):45-8. X-1. [pmid: 3986841].
212 Fujino T, Yamamoto K, Kuboto J, et al. Microsurgical technique in resection of hemangioma in infants. Ann Plast Surg. Mar. 1985;14(3):190-204. X-2. [pmid: 3994264].
213 Haik BG, Saint Louis L, Smith ME, et al. Computed tomography of the nonrhegmatogenous retinal detachment in the pediatric patient. Ophthalmology. Aug. 1985;92(8):1133-42. X-1. [pmid: 3840243].
214 Han JS, Benson JE, Kaufman B, et al. MR imaging of pediatric cerebral abnormalities. J Comput Assist Tomogr. Jan–Feb. 1985;9(1):103-14. X-1. [pmid: 3968257].
215 Hayashi T, Fukui M, Shyojima K, et al. Giant cerebellar hemangioma in an infant. Childs Nerv Syst. 1985;1(4):230-3. X-1, X-2. [pmid: 4064023].
216 Helin I, Persson PH. Intra-abdominal cysts detected at prenatal ultrasound screening. Helv Paediatr Acta. Apr. 1985;40(1):55-9. X-1. [pmid: 3916364].
217 Hertzanu Y, Mendelsohn DB, Davidge-Pitts K, et al. Preoperative embolization in paediatric maxillofacial haemangiomas. J Laryngol Otol. Nov. 1985;99(11):1089-95. X-1, X-2. [pmid: 4056594].
218 Hill JH, Mafee MF, Chow JM, et al. Dynamic computerized tomography in the assessment of hemangioma. Am J Otolaryngol. Jan–Feb. 1985;6(1):23-8. X-2. [pmid: 3977008].
219 Horie H, Iwasaki I, Iida H, et al. Benign hemangioendothelioma of the pancreas with obstructive jaundice. Acta Pathol Jpn. Jul. 1985;35(4):975-9. X-1. [pmid: 4072679].
220 Iliev E, Chilova-Atanassova B. Hemangioma on the eyelids and ocular conjunctiva. Folia Med (Plovdiv). 1985;27(1):27-34. X-3, X-4. [pmid: 3937800].
221 Jacobson HG. Dense bone--too much bone: radiological considerations and differential diagnosis. Part II. Skeletal Radiol. 1985;13(2):97-113. X-1. [pmid: 3883506].
222 Laskin JL, Lawrence MA. An oral hemangioma in a three-month-old child: clinical report. Pediatr Dent. Sep. 1985;7(3):231-4. X-1, X-2. [pmid: 3865163].
223 Lofgren EP, Lofgren KA. Surgical treatment of cavernous hemangioma. Surgery. Apr. 1985;97(4):474-80. X-1. [pmid: 3983824].
224 Maillard GF, Geinoz J. Argon laser photocoagulation of various angiomas. Br J Plast Surg. Apr. 1985;38(2):156-62. X-1, X-2. [pmid: 3986415].
225 Mazoit JX, Brunelle F, Danel P, et al. Therapeutic embolization of hemangiomas and hemangioendotheliomas of the liver in infants. A hemodynamics study. Ann Radiol (Paris). 1985;28(3–4):283-8. X-2. [pmid: 4014979].
226 McIntosh WA, Lownie JF, Berezowski BM. Haemangioma of the mandible. Diagnosis and management. J Laryngol Otol. Sep. 1985;99(9):913-7. X-1. [pmid: 4045312].
227 Miller JH, Greenspan BS. Integrated imaging of hepatic tumors in childhood. Part II: Benign lesions (congenital, reparative, and inflammatory). Radiology. Jan. 1985;154(1):91-100. X-1. [pmid: 3880615].
228 Milligan NS, Edwards JC, Monro JL, et al. Excision of giant haemangioma in the newborn using hypothermia and cardiopulmonary bypass. Anaesthesia. Sep. 1985;40(9):875-8. X-1. [pmid: 4051152].
229 Mohr G, Hardy J, Gauvin P. Chiasmal apoplexy due to ruptured cavernous hemangioma of the optic chiasm. Surg Neurol. Dec. 1985;24(6):636-40. X-1. [pmid: 4060042].
230 Narcy P, Contencin P, Bobin S, et al. Treatment of infantile subglottic hemangioma. A report of 49 cases. Int J Pediatr Otorhinolaryngol. Jul. 1985;9(2):157-64. X-3, X-4. [pmid: 4030237].
231 Nem-Yun B, Zulkiflee Laidin A. Giant cavernous hemangioma of the anterior chest wall in a neonate: a case report. Med J Malaysia. Sep. 1985;40(3):252-6. X-1, X-2. [pmid: 3842722].
232 Ogata S, Mizoguchi H, Arita M, et al. A case of hemangiomyoma of the ureter in a child. Eur Urol. 1985;11(5):355-6. X-1. [pmid: 4076279].
233 O’Sullivan TJ, Healy GB. Complications of Venturi jet ventilation during microlaryngeal surgery. Arch Otolaryngol. Feb. 1985;111(2):127-31. X-1. [pmid: 3977727].
234 Paletta FX. Vascular tumors: 30-year inventory. Aesthetic Plast Surg. 1985;9(4):281-6. X-2. [pmid: 4091084].
235 Pancurak J, Goldberg MF, Frenkel M, et al. Cavernous hemangioma of the retina. Genetic and central nervous system involvement. Retina. Fall–Winter. 1985;5(4):215-20. X-1. [pmid: 3835615].
236 Parkin JL, Dixon JA. Argon laser treatment of head and neck vascular lesions. Otolaryngol Head Neck Surg. Apr. 1985;93(2):211-6. X-3, X-4. [pmid: 3921911].
237 Pode D, Meretik S, Shapiro A, et al. Diagnosis and management of renal angiomyolipoma. Urology. May. 1985;25(5):461-7. X-1. [pmid: 3887727].
238 Popescu V. Intratumoral ligation in the management of orofacial cavernous haemangiomas. J Maxillofac Surg. Jun. 1985;13(3):99-107. X-1. [pmid: 3860592].
239 Ruff RJ, Osborn AG, Harnsberger HR, et al. Extracalvarial soft tissues in cranial computed tomography. Normal anatomy and pathology. Invest Radiol. Jul. 1985;20(4):374-80. X-1, X-2. [pmid: 4044178].
240 Saive C, Trotteur G, Magotteaux P, et al. Portal cavernoma in a 9-year-old child. J Belge Radiol. 1985;68(6):462-3. X-1. [pmid: 3912384].
241 Schneider PE. Hemangioma of the tongue and adjacent structures (a case report). J Oral Med. Jul–Sep. 1985;40(3):115-9. X-2. [pmid: 3162011].
242 Servelle M. Klippel and Trenaunay’s syndrome. 768 operated cases. Ann Surg. Mar. 1985;201(3):365-73. X-1. [pmid: 2983626].
243 Smith SW, Carruthers JD. Intractable periocular hemangioma of infancy. Can J Ophthalmol. Oct. 1985;20(6):220-4. X-1, X-2. [pmid: 4063879].
244 Sun TC, Swee RG, Shives TC, et al. Chondrosarcoma in Maffucci’s syndrome. J Bone Joint Surg Am. Oct. 1985;67(8):1214-9. X-1. [pmid: 4055846].
245 Tateno A, Matsui A, Sakuragawa N, et al. Two siblings with multiple intracranial haemangiomatosis with calcification. J Neurol. 1985;232(2):112-4. X-1. [pmid: 4020390].
246 Trout HH 3rd, McAllister HA Jr, Giordano JM, et al. Vascular malformations. Surgery. Jan. 1985;97(1):36-41. X-1. [pmid: 3966228].
247 Upton J, Mulliken JB, Murray JE. Classification and rationale for management of vascular anomalies in the upper extremity. J Hand Surg Am. Nov. 1985;10(6 Pt 2):970-5. X-1, X-2. [pmid: 4078289].
248 van Wering JH, van der Slikke JW. Prenatal diagnosis of chorioangioma associated with polyhydramnios using ultrasound. Eur J Obstet Gynecol Reprod Biol. Apr. 1985;19(4):255-9. X-1. [pmid: 3891446].
249 Vilalta J, Mascaro JM. Hemangiolymphangioma of the tongue treated by transfixion technique. J Dermatol Surg Oncol. Feb. 1985;11(2):168-70. X-1. [pmid: 2981911].
250 Wakai S, Ueda Y, Inoh S, et al. Angiographically occult angiomas: a report of thirteen cases with analysis of the cases documented in the literature. Neurosurgery. Oct. 1985;17(4):549-56. X-1. [pmid: 4058688].
251 Walter C. The treatment of hemangioma with fibrin glue. Facial Plast Surg. Summer. 1985;2(4):357-62. X-2. [pmid: 3877661].
252 Wannakrairot P, Benjavongkulchai S. Giant hemangioma of liver with bleeding tendency: report of 2 cases. J Med Assoc Thai. Aug. 1985;68(8):432-8. X-2. [pmid: 4067463].
253 Wright GL, Smith RJ, Katz CD, et al. Benign parotid diseases of childhood. Laryngoscope. Aug. 1985;95(8):915-20. X-3, X-4. [pmid: 4021684].
254 Yanai A, Fukuda O, Soyano S, et al. Argon laser therapy of port-wine stains: effects and limitations. Plast Reconstr Surg. Apr. 1985;75(4):520-7. X-1. [pmid: 3983252].
255 Yenrudi S, Shuangshoti S. Bleeding of intracranial angioma as a cause of intrauterine death of fetus. J Med Assoc Thai. Nov. 1985;68(11):605-8. X-1. [pmid: 4086953].
256 Yu DT, Sheth KJ. Cystic renal involvement in tuberous sclerosis. Clin Pediatr (Phila). Jan. 1985;24(1):36-9. X-1. [pmid: 3880684].
257 Abe S. Local steroid therapy of adnexal strawberry hemangioma in infants - long-term follow-up. Eur J Plast Surg. 1986;9(1):29-35. X-2.
258 Apfelberg DB. Summary of carbon dioxide laser usage in plastic surgery. Scand J Plast Reconstr Surg. 1986;20(1):19-24. X-1. [pmid: 3775288].
259 Apfelberg DB, Bailin P, Rosenberg H. Preliminary investigation of KTP/532 laser light in the treatment of hemangiomas and tattoos. Lasers Surg Med. 1986;6(1):38-42. 56. 7. X-1. [pmid: 3959714].
260 Bell AJ, Chisholm M, Hickton M. Reversal of coagulopathy in Kasabach-Merritt syndrome with tranexamic acid. Scand J Haematol. Sep. 1986;37(3):248-52. X-1, X-2. [pmid: 3787175].
261 Beran M, Petruson B. Changes in the nasal mucosa of habitual nose-bleeders. Acta Otolaryngol. Sep–Oct. 1986;102(3–4):308-14. X-1. [pmid: 3776525].
262 Biondi A, Scotti G, Scialfa G, et al. Magnetic resonance imaging of cerebral cavernous angiomas. Acta Radiol Suppl. 1986;369:82-5. X-1. [pmid: 2980619].
263 Brahams D. Explanation and disclosure of risks in the treatment of children. Lancet. Apr. 19. 1986;1(8486):925-6. X-1. [pmid: 2870397].
264 Burke DR, Verstandig A, Edwards O, et al. Infantile hemangioendothelioma: angiographic features and factors determining efficacy of hepatic artery embolization. Cardiovasc Intervent Radiol. 1986;9(3):154-7. X-1. [pmid: 3089623].
265 Carruth JA, Shakespeare P. Toward the ideal treatment for the port wine stain with the argon laser: better prediction and an “optimal” technique. Lasers Surg Med. 1986;6(1):2-4. X-1. [pmid: 3959711].
266 Choa DI, Smith MC, Evans JN, et al. Subglottic haemangioma in children. J Laryngol Otol. Apr. 1986;100(4):447-54. X-3, X-4. [pmid: 3958591].
267 Cleland WJ, Riding K. Subglottic hemangiomas in infants. J Otolaryngol. Apr. 1986;15(2):119-23. X-2. [pmid: 3712542].
268 Clodius L. Surgery for the facial port-wine stain: technique and results. Ann Plast Surg. Jun. 1986;16(6):457-71. X-1. [pmid: 3273061].
269 Cohen RC, Myers NA. Diagnosis and management of massive hepatic hemangiomas in childhood. J Pediatr Surg. Jan. 1986;21(1):6-9. X-3, X-4. [pmid: 3511216].
270 de Slegte RG, Valk J, Broere G, et al. Further experience with ultrasound examinations in the postoperative brain. Acta Neurochir (Wien). 1986;81(3–4):106-12. X-1. [pmid: 3751693].
271 Deady JP, Willshaw HE. Vascular hamartomas in childhood. Trans Ophthalmol Soc U K. 1986;105(Pt 6):712-6. X-1. [pmid: 3477898].
272 Di Lorenzo N, Nardi P, Ciappetta P, et al. Benign tumors and tumorlike conditions of the spine. Radiological features, treatment, and results. Surg Neurol. May. 1986;25(5):449-56. X-1. [pmid: 3961662].
273 Dixon JA, Davis RK, Gilbertson JJ. Laser photocoagulation of vascular malformations of the tongue. Laryngoscope. May. 1986;96(5):537-41. X-1. [pmid: 3754609].
274 Dyer C. Death from interventionist radiology: a cautionary tale. Br Med J (Clin Res Ed). Sep. 13. 1986;293(6548):686-7. X-2. [pmid: 3092980].
275 Ehrlich MG, Zaleske DJ. Pediatric orthopedic pain of unknown origin. J Pediatr Orthop. Jul–Aug. 1986;6(4):460-8. X-1. [pmid: 3734072].
276 Famiglietti PJ. Intralesional corticosteroid injection for capillary hemangioma of the eyelid. Trans Pa Acad Ophthalmol Otolaryngol. 1986;38(1):371-3. X-2. [pmid: 3765021].
277 Fawcett WAt, Ferry GD, Gorin LJ, et al. Immunodeficiency secondary to structural intestinal defects. Malrotation of the small bowel and cavernous hemangioma of the jejunum. Am J Dis Child. Feb. 1986;140(2):169-72. X-1. [pmid: 3484895].
278 Fernell E, Hagberg B, Hagberg G, et al. Epidemiology of infantile hydrocephalus in Sweden. I. Birth prevalence and general data. Acta Paediatr Scand. Nov. 1986;75(6):975-81. X-1. [pmid: 3564981].
279 Fishman MA, Baram TZ. Megalencephaly due to impaired cerebral venous return in a Sturge-Weber variant syndrome. J Child Neurol. Apr. 1986;1(2):115-8. X-1. [pmid: 3598114].
280 Forbes G, Earnest Ft, Jackson IT, et al. Therapeutic embolization angiography for extra-axial lesions in the head. Mayo Clin Proc. Jun. 1986;61(6):427-41. X-1. [pmid: 3012215].
281 Goldberg NS, Hebert AA, Esterly NB. Sacral hemangiomas and multiple congenital abnormalities. Arch Dermatol. Jun. 1986;122(6):684-7. X-3. [pmid: 3717979].
282 Golitz LE, Rudikoff J, O’Meara OP. Diffuse neonatal hemangiomatosis. Pediatr Dermatol. Feb. 1986;3(2):145-52. X-1. [pmid: 3952031].
283 Gough JD, Keeling JW, Castle B, et al. The obstetric management of non-immunological hydrops. Br J Obstet Gynaecol. Mar. 1986;93(3):226-34. X-1. [pmid: 3964598].
284 Haik BG, Ellsworth RM. Pediatric orbital tumors. Trans New Orleans Acad Ophthalmol. 1986;34:89-109. X-2. [pmid: 3726971].
285 Hobby LW. Argon laser treatment of superficial vascular lesions in children. Lasers Surg Med. 1986;6(1):16-9. 46. 9. X-2. [pmid: 3959710].
286 Hurvitz CH, Alkalay AL, Sloninsky L, et al. Cyclophosphamide therapy in life-threatening vascular tumors. J Pediatr. Aug. 1986;109(2):360-3. X-2. [pmid: 3734975].
287 Kaban LB, Mulliken JB. Vascular anomalies of the maxillofacial region. J Oral Maxillofac Surg. Mar. 1986;44(3):203-13. X-2. [pmid: 3456442].
288 Kibbi AG, Mihm MC Jr, Sober AJ, et al. Diagnosis and management of malignant melanoma. Compr Ther. May. 1986;12(5):23-31. X-1. [pmid: 2940047].
289 Leithiser RE Jr, Fyfe D, Weatherby E 3rd, et al. Prenatal sonographic diagnosis of atrial hemangioma. AJR Am J Roentgenol. Dec. 1986;147(6):1207-8. X-1. [pmid: 3535456].
290 Liu P, Daneman A, Stringer DA, et al. Computed tomography of hemangiomas and related soft-tissue lesions in children. Can Assoc Radiol J. Dec. 1986;37(4):248-55. X-3, X-4. [pmid: 2950108].
291 Machen BC, Williams JP, Lum GB, et al. Intracranial gyriform calcification associated with subarachnoid fat. J Comput Tomogr. Oct. 1986;10(4):385-8. X-1. [pmid: 3780268].
292 Maeda M, Yamashiro Y. Diagnostic red blood cell scintigraphy in GI tract bleeding from an intestinal hemangioma. J Pediatr Gastroenterol Nutr. Nov–Dec. 1986;5(6):987-9. X-1, X-2. [pmid: 3025396].
293 McCaffrey TV, Cortese DA. Neodymium:YAG laser treatment of subglottic hemangioma. Otolaryngol Head Neck Surg. Mar. 1986;94(3):382-4. X-2. [pmid: 3083371].
294 McGahan JP, Schneider JM. Fetal neck hemangioendothelioma with secondary hydrops fetalis: sonographic diagnosis. J Clin Ultrasound. Jun. 1986;14(5):384-8. X-1. [pmid: 3088056].
295 Miall-Allen VM, Morgan B, Cooper P, et al. Peripheral arteriovenous fistula as a cause of neonatal cardiac failure. Int J Cardiol. Feb. 1986;10(2):177-9. X-1. [pmid: 3943936].
296 Minami A, Usui M, Ogino T, et al. Simultaneous reconstruction of bone and skin defects by free fibular graft with a skin flap. Microsurgery. 1986;7(1):38-45. X-1. [pmid: 3702664].
297 Morgan RF, Horowitz JH, Wanebo HJ, et al. Surgical management of vascular malformations of the head and neck. Am J Surg. Oct. 1986;152(4):424-9. X-1. [pmid: 3766876].
298 Nishizaki T, Tamaki N, Matsumoto S, et al. Consideration of the operative indications for posterior fossa venous angiomas. Surg Neurol. May. 1986;25(5):441-5. X-1. [pmid: 3961660].
299 Oranje AP. Blue rubber bleb nevus syndrome. Pediatr Dermatol. Sep. 1986;3(4):304-10. X-1. [pmid: 3022262].
300 Paley D, Evans DC. Angiomatous involvement of an extremity. A spectrum of syndromes. Clin Orthop Relat Res. May. 1986;(206):215-8. X-1. [pmid: 3708978].
301 Paley D, Jackson RW. Synovial haemangioma of the knee joint: diagnosis by arthroscopy. Arthroscopy. 1986;2(3):174-7. X-1. [pmid: 3768113].
302 Patel CB, Tsai TM, Kleinert HE. Hemangioma of the median nerve: a report of two cases. J Hand Surg Am. Jan. 1986;11(1):76-9. X-2. [pmid: 3944449].
303 Persky MS. Congenital vascular lesions of the head and neck. Laryngoscope. Sep. 1986;96(9 Pt 1):1002-15. X-1. [pmid: 3747686].
304 Pribyl C, Burke SW, Roberts JM, et al. Infiltrating angiolipoma or intramuscular hemangioma? A report of five cases. J Pediatr Orthop. Mar–Apr. 1986;6(2):172-6. X-1, X-2. [pmid: 3958171].
305 Rosenfeld H, Sherman R. Treatment of cutaneous and deep vascular lesions with the Nd:YAG laser. Lasers Surg Med. 1986;6(1):20-3. 50. 1. X-1, X-2. [pmid: 3959712].
306 Schofield D, Zaatari GS, Gay BB. Klippel-Trenaunay and Sturge-Weber syndromes with renal hemangioma and double inferior vena cava. J Urol. Aug. 1986;136(2):442-5. X-1, X-2. [pmid: 3016342].
307 Seimon LP, Hekmat F. Synovial hemangioma of the knee. J Pediatr Orthop. May–Jun. 1986;6(3):356-9. X-1, X-2. [pmid: 3711330].
308 Shikhani AH, Shehadi SI. Surgical treatment of giant hemangiomas of the head and neck. Otolaryngol Head Neck Surg. Jan. 1986;94(1):113-22. X-1. [pmid: 3081847].
309 Shorr N, Seiff SR. Central retinal artery occlusion associated with periocular corticosteroid injection for juvenile hemangioma. Ophthalmic Surg. Apr. 1986;17(4):229-31. X-2. [pmid: 3714192].
310 Shu QS, Hu SS, Xie AF. Advances in the design of special cryosurgical apparatus in China. Cryobiology. Apr. 1986;23(2):184-93. X-1. [pmid: 3698646].
311 Shulman RJ, Holmes R, Ferry GD, et al. Splanchnic bed vascular malformations and the development of portal hypertension. J Pediatr Surg. Apr. 1986;21(4):355-7. X-1. [pmid: 3701554].
312 Silberman S, Fresco R, Suarez C. Pseudo-Chediak-Higashi anomaly in a child with a hepatic vascular malformation. Am J Pediatr Hematol Oncol. Spring. 1986;8(1):38-42. X-1. [pmid: 3013038].
313 Silver L. Argon laser photocoagulation of port wine stain hemangiomas. Lasers Surg Med. 1986;6(1):24-8. 52. 5. X-1. [pmid: 3959713].
314 Simard JM, Garcia-Bengochea F, Ballinger WE Jr, et al. Cavernous angioma: a review of 126 collected and 12 new clinical cases. Neurosurgery. Feb. 1986;18(2):162-72. X-1. [pmid: 3960293].
315 Spraker MK. The vascular lesions of childhood. Dermatol Clin. Jan. 1986;4(1):79-87. X-2. [pmid: 3720028].
316 Stanley P, Gomperts E, Woolley MM. Kasabach-Merritt syndrome treated by therapeutic embolization with polyvinyl alcohol. Am J Pediatr Hematol Oncol. Winter. 1986;8(4):308-11. X-1, X-2. [pmid: 3799931].
317 Stiller AG, Skafish PR. Placental chorioangioma: a rare cause of fetomaternal transfusion with maternal hemolysis and fetal distress. Obstet Gynecol. Feb. 1986;67(2):296-8. X-1. [pmid: 3945441].
318 Suzuki A, Ito S, Takechi H. Follow-up study of cartilaginous bone tumors. Acta Med Okayama. Jun. 1986;40(3):147-61. X-1. [pmid: 3526817].
319 Tagle P, Huete I, Mendez J, et al. Intracranial cavernous angioma: presentation and management. J Neurosurg. May. 1986;64(5):720-3. X-1. [pmid: 3701420].
320 Takeshita M, Kagawa M, Izawa M, et al. Hemorrhagic stroke in infancy, childhood, and adolescence. Surg Neurol. Nov. 1986;26(5):496-500. X-1. [pmid: 3764653].
321 Tanaka K, Shimao S, Okada T, et al. Kasabach-Merritt syndrome with disseminated intravascular coagulopathy treated by exchange transfusion and surgical excision. Dermatologica. 1986;173(2):90-4. X-1, X-2. [pmid: 3792604].
322 Trout HH 3rd. Management of patients with hemangiomas and arteriovenous malformations. Surg Clin North Am. Apr. 1986;66(2):333-8. X-1, X-2. [pmid: 3952606].
323 Trout HH 3rd, McAllister HA Jr, Giordano JM. Vascular anomalies. J Vasc Surg. May. 1986;3(5):833-6. X-1, X-2. [pmid: 3009904].
324 Vomberg PP, Buller HA, Marsman JW, et al. Hepatic artery embolisation; successful treatment of multinodular haemangiomatosis of the liver. Eur J Pediatr. Feb. 1986;144(5):472-4. X-1. [pmid: 3956535].
325 Weiss SW, Enzinger FM. Spindle cell hemangioendothelioma. A low-grade angiosarcoma resembling a cavernous hemangioma and Kaposi’s sarcoma. Am J Surg Pathol. Aug. 1986;10(8):521-30. X-1. [pmid: 3740350].
326 White AK, Smith RJ. Thyroid nodules in children. Otolaryngol Head Neck Surg. Jul. 1986;95(1):70-5. X-1. [pmid: 3106898].
327 Wilson S, Venzel JM, Miller R. Angiography, gingival hyperplasia and Sturge-Weber syndrome: report of case. ASDC J Dent Child. Jul–Aug. 1986;53(4):283-6. X-1. [pmid: 2942585].
328 Wong PC, Arulkumaran S, Ratnam SS, et al. Acute polyhydramnios and cord presentation--complication of chorioangioma of the placenta--a case report. Int J Gynaecol Obstet. Feb. 1986;24(1):61-4. X-1. [pmid: 2874072].
329 Yamasaki T, Handa H, Yamashita J, et al. Intracranial and orbital cavernous angiomas. A review of 30 cases. J Neurosurg. Feb. 1986;64(2):197-208. X-1. [pmid: 3944629].
330 Yoshimoto T, Suzuki J. Radical surgery on cavernous angioma of the brainstem. Surg Neurol. Jul. 1986;26(1):72-8. X-1. [pmid: 3715704].
331 Adams SJ, Swain CP, Mills TN, et al. The effect of wavelength, power and treatment pattern on the outcome of laser treatment of port-wine stains. Br J Dermatol. Oct. 1987;117(4):487-94. X-1. [pmid: 3314972].
332 Apfelberg DB, Smith T, Lash H, et al. Preliminary report on use of the neodymium-YAG laser in plastic surgery. Lasers Surg Med. 1987;7(2):189-98. X-1. [pmid: 3613811].
333 Bank ER, Hernandez RJ, Byrne WJ. Gastrointestinal hemangiomatosis in children: demonstration with CT. Radiology. Dec. 1987;165(3):657-8. X-1, X-2. [pmid: 3500485].
334 Battistella PA, Mattesi P, Casara GL, et al. Bilateral cerebral occipital calcifications and migraine-like headache. Cephalalgia. Jun. 1987;7(2):125-9. X-1. [pmid: 3111714].
335 Bogan S, Simon JW, Krohel GB, et al. Astigmatism associated with adnexal masses in infancy. Arch Ophthalmol. Oct. 1987;105(10):1368-70. X-3. [pmid: 3662910].
336 Brauner GJ, Schliftman A. Laser surgery for children. J Dermatol Surg Oncol. Feb. 1987;13(2):178-86. X-1. [pmid: 2948981].
337 Burrows PE, Lasjaunias PL, Ter Brugge KG, et al. Urgent and emergent embolization of lesions of the head and neck in children: indications and results. Pediatrics. Sep. 1987;80(3):386-94. X-3, X-4. [pmid: 3627890].
338 Byrne JM, Gates RD. Single-case study of left cerebral hemispherectomy: development in the first five years of life. J Clin Exp Neuropsychol. Aug. 1987;9(4):423-34. X-1. [pmid: 3597733].
339 Cervera A, Corral MJ, Gomez Campdera FJ, et al. Idiopathic hypercalciuria in children. Classification, clinical manifestations and outcome. Acta Paediatr Scand. Mar. 1987;76(2):271-8. X-1. [pmid: 3591293].
340 Chandna S, Bhatnagar V, Mitra DK, et al. Hemangiolymphangioma of the urinary bladder in a child. J Pediatr Surg. Nov. 1987;22(11):1051-2. X-1, X-2. [pmid: 3430315].
341 Cohen AJ, Sbaschnig RJ, Hochholzer L, et al. Mediastinal hemangiomas. Ann Thorac Surg. Jun. 1987;43(6):656-9. X-1. [pmid: 3592837].
342 Cohen BA. Hemangiomas in infancy and childhood. Pediatr Ann. Jan. 1987;16(1):17-26. X-2. [pmid: 3562091].
343 Colver GB, Savin JA. Port wine stains. J R Soc Med. Oct. 1987;80(10):603. X-1. [pmid: 3694594].
344 Dado DV, Stalnecker MC, Kernahan DA. Experience with electrothrombosis in the treatment of angiomas. Ann Plast Surg. Jan. 1987;18(1):12-6. X-1. [pmid: 3548553].
345 Daum R, Denecke HJ, Roth H. Tumour-induced intraluminal stenoses of the cervical trachea--tumour excision and tracheoplasty. Prog Pediatr Surg. 1987;21:50-7. X-2. [pmid: 3107073].
346 Dombrowski MP, Budev H, Wolfe HM, et al. Fetal hemorrhage from umbilical cord hemangioma. Obstet Gynecol. Sep. 1987;70(3 Pt 2):439-42. X-1. [pmid: 3627598].
347 Fernell E, Hagberg B, Hagberg G, et al. Epidemiology of infantile hydrocephalus in Sweden. III. Origin in preterm infants. Acta Paediatr Scand. May. 1987;76(3):418-23. X-1. [pmid: 2440228].
348 Fernell E, Hagberg B, Hagberg G, et al. Epidemiology of infantile hydrocephalus in Sweden. II. Origin in infants born at term. Acta Paediatr Scand. May. 1987;76(3):411-7. X-1. [pmid: 2440227].
349 Fleury P, Smits N, van Baal S. The incidence of hepatic hamartomas in tuberous sclerosis. Evaluation by ultrasonography. Rofo. Jun. 1987;146(6):694-6. X-1. [pmid: 3037642].
350 Goldsmith MM 3rd, Strope GL, Postma DS. Presentation and management of postcricoid hemangiomata in infancy. Laryngoscope. Jul. 1987;97(7 Pt 1):851-3. X-2. [pmid: 3600138].
351 Govender S, Charles RW, Kelman IE. Vertebral haemangiomas. A report of 2 cases. S Afr Med J. Nov. 7. 1987;72(9):640-2. X-1. [pmid: 3686305].
352 Govrin-Yehudain J, Moscona AR, Calderon N, et al. Treatment of hemangiomas by sclerosing agents: an experimental and clinical study. Ann Plast Surg. Jun. 1987;18(6):465-9. X-3, X-4. [pmid: 3605981].
353 Griffin C, DeLaPaz R, Enzmann D. Magnetic resonance appearance of slow flow vascular malformations of the brainstem. Neuroradiology. 1987;29(6):506-11. X-1. [pmid: 3431693].
354 Haynes R, Sobel DF, Holeman G. Cranial arteriovenous hemangioma in a neonate. AJNR Am J Neuroradiol. Sep–Oct. 1987;8(5):916-8. X-1, X-2. [pmid: 3118685].
355 Hendren WG, Monfort GJ. Symptomatic bilateral renal angiomyolipomas in a child. J Urol. Feb. 1987;137(2):256-7. X-1. [pmid: 3806815].
356 Hilborne LH, Glasgow BJ, Layfield LJ. Fine-needle aspiration cytology of juvenile hemangioma of the parotid gland: a case report. Diagn Cytopathol. Jun. 1987;3(2):152-5. X-2. [pmid: 3595412].
357 Jackson CG, Levine SC, McKennan KX. Hemangioma of the middle ear. Am J Otol. Mar. 1987;8(2):131-2. X-2. [pmid: 3591920].
358 Jones WP, Keller FS, Odrezin GT, et al. Venous hemangioma of the gallbladder. Gastrointest Radiol. 1987;12(4):319-21. X-1, X-2. [pmid: 3305129].
359 Kawahara M, Takeshita T, Akita S. Anesthetic management of a patient with Kasabach-Merritt syndrome. Anesth Prog. Jan–Feb. 1987;34(1):17-9. X-1. [pmid: 3472474].
360 Kremer I, Nissenkorn I, Feuerman P, et al. Congenital orbital vascular malformation complicated by massive retrobulbar hemorrhage. J Pediatr Ophthalmol Strabismus. Jul–Aug. 1987;24(4):190-3. X-1. [pmid: 3668767].
361 Larsen EC, Zinkham WH, Eggleston JC, et al. Kasabach-Merritt syndrome: therapeutic considerations. Pediatrics. Jun. 1987;79(6):971-80. X-1. [pmid: 3108848].
362 Leung AK. Port-wine stain associated with maternal use of lithium carbonate. J Natl Med Assoc. Aug. 1987;79(8):877-8. X-1. [pmid: 3149678].
363 Lofland GK, Filston HC. Giant cutaneous hemangioma associated with axillary arteriovenous fistula causing congestive heart failure in the newborn infant. J Pediatr Surg. May. 1987;22(5):458-60. X-1, X-2. [pmid: 3585670].
364 Magnin PH, Schroh RG, Barquin MA. Endovascular papillary angioendothelioma in children. Pediatr Dermatol. Dec. 1987;4(4):332-5. X-1. [pmid: 3444784].
365 Mahboubi S, Sunaryo FP, Glassman MS, et al. Computed tomography, management, and follow-up in infantile hemangioendothelioma of the liver in infants and children. J Comput Tomogr. Oct. 1987;11(4):370-5. X-1. [pmid: 3443011].
366 Marks MW, Argenta LC, Thornton JW. Rapid expansion: experimental and clinical experience. Clin Plast Surg. Jul. 1987;14(3):455-63. X-1. [pmid: 3608355].
367 Mawk JR, Leibrock LG, McComb RD, et al. Metameric capillary hemangioma producing complete myelographic block in an infant. Case report. J Neurosurg. Sep. 1987;67(3):456-9. X-1, X-2. [pmid: 3612279].
368 Miller JH. Technetium-99m-labeled red blood cells in the evaluation of hemangiomas of the liver in infants and children. J Nucl Med. Sep. 1987;28(9):1412-8. X-3, X-4. [pmid: 3625294].
369 Milner RH, Sykes PJ. Diffuse cavernous haemangiomas of the upper limb. J Hand Surg Br. Jun. 1987;12(2):199-202. X-1. [pmid: 3624977].
370 Narasimharao KL, Patel RV, Mitra S, et al. Mixed angioma of parotid gland simulating malignancy. Indian J Cancer. Jun. 1987;24(2):91-4. X-1. [pmid: 3692533].
371 Nguyen JP, Djindjian M, Gaston A, et al. Vertebral hemangiomas presenting with neurologic symptoms. Surg Neurol. Apr. 1987;27(4):391-7. X-1. [pmid: 3824146].
372 Nohara Y, Horiguchi H, Tsuji H, et al. Dental deformities caused by radium therapy for hemangioma of upper lip. Gifu Shika Gakkai Zasshi. Dec. 1987;14(2):426-35. X-2. [pmid: 3504860].
373 Osguthorpe JD, Halstead L. Invasive congenital hemangiomas of the nose. Otolaryngol Head Neck Surg. Jul. 1987;97(1):76-8. X-1, X-2. [pmid: 3112690].
374 Patterson RM, Maher F, Sitrin C. The prenatal sonographic visualization of a fetal calvarial capillary hemangioma. Journal of Diagnostic Medical Sonography. 1987;3(6):286-8. X-1, X-2.
375 Plavsic B, Jereb-Provic B. Radiologic and endoscopic diagnosis of duodenal angioma. Acta Radiol. Nov–Dec. 1987;28(6):735-8. X-1. [pmid: 2962610].
376 Poe R, Blair PA. Hemangioma of the head and neck. J La State Med Soc. Apr. 1987;139(4):17-20. X-1, X-2. [pmid: 3484323].
377 Powell TG, West CR, Pharoah PO, et al. Epidemiology of strawberry haemangioma in low birthweight infants. Br J Dermatol. May. 1987;116(5):635-41. X-3. [pmid: 3593631].
378 Ravussin P, Bayer-Berger M, Monnier P, et al. Percutaneous transtracheal ventilation for laser endoscopic procedures in infants and small children with laryngeal obstruction: report of two cases. Can J Anaesth. Jan. 1987;34(1):83-6. X-2. [pmid: 3829291].
379 Ruiz-Maldonado R, Tamayo L, Laterza AM, et al. Phacomatosis pigmentovascularis: a new syndrome? Report of four cases. Pediatr Dermatol. Nov. 1987;4(3):189-96. X-1. [pmid: 3422849].
380 Sato Y, Frey EE, Wicklund B, et al. Embolization therapy in the management of infantile hemangioma with Kasabach Merritt syndrome. Pediatr Radiol. 1987;17(6):503-4. X-2. [pmid: 3317252].
381 Sauer L, Harrison MR, Bond SJ, et al. Long-term percutaneous biliary drainage in an infant with hemangioendothelioma. J Pediatr Surg. Jul. 1987;22(7):606-8. X-1. [pmid: 3612453].
382 Schieken LS, Brenner JI, Baker KR, et al. Aneurysm of the ascending aorta associated with sternal cleft, cutaneous hemangioma, and occlusion of the right innominate artery in a neonate. Am Heart J. Jan. 1987;113(1):202-4. X-2. [pmid: 3541557].
383 Schubert A, Todd MM, Luerssen TG, et al. Loss of intraoperative evoked responses during dorsal column surgery associated with isolated postoperative sensory deficit. J Clin Monit. Oct. 1987;3(4):277-81. X-1. [pmid: 3681361].
384 Sencer S, Coulter-Knoff A, Day D, et al. Splenic hemangioma with thrombocytopenia in a newborn. Pediatrics. Jun. 1987;79(6):960-6. X-1. [pmid: 3588149].
385 Shah KD, Beck AR, Jhaveri MK, et al. Infantile hemangioendothelioma of heterotopic intrathoracic liver associated with diaphragmatic hernia. Hum Pathol. Jul. 1987;18(7):754-6. X-1. [pmid: 3596593].
386 Shapshay SM, David LM, Zeitels S. Neodymium-YAG laser photocoagulation of hemangiomas of the head and neck. Laryngoscope. Mar. 1987;97(3 Pt 1):323-30. X-2. [pmid: 3821352].
387 Silver RK, Huff RW. Intrapartum management of the fetus with idiopathic hydrocephalus. Am J Perinatol. Jan. 1987;4(1):16-9. X-1. [pmid: 3539132].
388 Snyderman NL, Johnson JT. Salivary gland tumors. Diagnostic characteristics of the common types. Postgrad Med. Oct. 1987;82(5):105-8. 10. 2. X-1, X-2. [pmid: 2823241].
389 Stillwell TJ, Gomez MR, Kelalis PP. Renal lesions in tuberous sclerosis. J Urol. Sep. 1987;138(3):477-81. X-1. [pmid: 3625844].
390 Stringel G. Giant hemangioma: treatment with intermittent pneumatic compression. J Pediatr Surg. Jan. 1987;22(1):7-10. X-1, X-2. [pmid: 2950220].
391 Stringel G, Dastous J. Klippel-Trenaunay syndrome and other cases of lower limb hypertrophy: pediatric surgical implications. J Pediatr Surg. Jul. 1987;22(7):645-50. X-1. [pmid: 3039103].
392 Suh YL, Cho KJ, Chi JG, et al. Infantile hemangioendothelioma of the liver--a case report. J Korean Med Sci. Sep. 1987;2(3):195-200. X-1. [pmid: 3268177].
393 Sutula FC, Glover AT. Eyelid necrosis following intralesional corticosteroid injection for capillary hemangioma. Ophthalmic Surg. Feb. 1987;18(2):103-5. X-2. [pmid: 3574861].
394 Tan OT, Stafford TJ. Treatment of port-wine stains at 577 nm: clinical results. Med Instrum. Aug. 1987;21(4):218-21. X-1. [pmid: 3452742].
395 Vaksmann G, Rey C, Marache P, et al. Severe congestive heart failure in newborns due to giant cutaneous hemangiomas. Am J Cardiol. Aug. 1. 1987;60(4):392-4. X-2. [pmid: 3618503].
396 Vankova B, Barinka L. Haemangiomas of the tongue. Acta Chir Plast. 1987;29(4):242-8. X-1, X-2. [pmid: 2449790].
397 Viljoen D, Saxe N, Pearn J, et al. The cutaneous manifestations of the Klippel-Trenaunay-Weber syndrome. Clin Exp Dermatol. Jan. 1987;12(1):12-7. X-1. [pmid: 2820629].
398 Willshaw HE, Deady JP. Vascular hamartomas in childhood. J Pediatr Surg. Mar. 1987;22(3):281-3. X-1. [pmid: 3559873].
399 Woods JE. Extended use of sodium tetradecyl sulfate in treatment of hemangiomas and other related conditions. Plast Reconstr Surg. Apr. 1987;79(4):542-9. X-1. [pmid: 3823245].
400 Yagupsky P, Giladi Y. Group A beta-hemolytic streptococcal septicemia complicating infected hemangioma in children. Pediatr Dermatol. May. 1987;4(1):24-6. X-2. [pmid: 3295826].
401 Yeoman CM. Management of haemangioma involving facial, mandibular and pharyngeal structures. Br J Oral Maxillofac Surg. Jun. 1987;25(3):195-203. X-1. [pmid: 3474017].
402 Yoshikawa M, Hayashi T, Sato T, et al. A case of pericardial hemangioma with consumption coagulopathy cured by radiotherapy. Pediatr Radiol. 1987;17(2):149-50. X-1, X-2. [pmid: 3104872].
403 Alexander LJ, Moates KN. Cavernous hemangioma of the retina. J Am Optom Assoc. Jul. 1988;59(7):539-48. X-1. [pmid: 3403902].
404 Awaya S, Miyake S. Form vision deprivation amblyopia: further observations. Graefes Arch Clin Exp Ophthalmol. 1988;226(2):132-6. X-1. [pmid: 3360338].
405 Beninson J, Hurley JP. Hemolymphangioma in a neonate--a therapeutic problem--case history. Angiology. Dec. 1988;39(12):1043-7. X-1. [pmid: 3189949].
406 Black CT, Luck SR, Raffensperger JG. Bronchoplastic techniques for pediatric lung salvage. J Pediatr Surg. Jul. 1988;23(7):653-6. X-1. [pmid: 3204465].
407 Blute ML, Malek RS, Segura JW. Angiomyolipoma: clinical metamorphosis and concepts for management. J Urol. Jan. 1988;139(1):20-4. X-1. [pmid: 3336097].
408 Boechat MI, Kangarloo H, Ortega J, et al. Primary liver tumors in children: comparison of CT and MR imaging. Radiology. Dec. 1988;169(3):727-32. X-1. [pmid: 2847233].
409 Brunelle FO, Chaumont P, Teillac D, et al. Facial vascular malformations in children. Conventional and digital, diagnostic and therapeutic angiography. Pediatr Radiol. 1988;18(5):377-82. X-1. [pmid: 3174277].
410 Cohen EK, Kressel HY, Perosio T, et al. MR imaging of soft-tissue hemangiomas: correlation with pathologic findings. AJR Am J Roentgenol. May. 1988;150(5):1079-81. X-1. [pmid: 3258709].
411 Corbally MT, McMullin JP. Diffuse cavernous hemangioma of the rectosigmoid and low anterior resection using the autostapler. J Pediatr Surg. Nov. 1988;23(11):1032-3. X-1. [pmid: 3244080].
412 De SK, Dey DD. Tumours of the mastoid temporal bone: with interesting cases in the paediatric age group. J Laryngol Otol. Jul. 1988;102(7):582-7. X-1. [pmid: 3411206].
413 Droste PJ, Ellis FD, Sondhi N, et al. Linear subcutaneous fat atrophy after corticosteroid injection of periocular hemangiomas. Am J Ophthalmol. Jan. 15. 1988;105(1):65-9. X-2. [pmid: 3337195].
414 Farmer JP, Cosgrove GR, Villemure JG, et al. Intracerebral cavernous angiomas. Neurology. Nov. 1988;38(11):1699-704. X-1. [pmid: 3185904].
415 Feinfield RE, Hesse RJ, Scharfenberg JC. Orbital angiolipoma. Arch Ophthalmol. Aug. 1988;106(8):1093-5. X-1. [pmid: 3401137].
416 Fernell E, Hagberg B, Hagberg G, et al. Epidemiology of infantile hydrocephalus in Sweden. Current aspects of the outcome in preterm infants. Neuropediatrics. Aug. 1988;19(3):143-5. X-1. [pmid: 3221986].
417 Fernell E, Hagberg B, Hagberg G, et al. Epidemiology of infantile hydrocephalus in Sweden: a clinical follow-up study in children born at term. Neuropediatrics. Aug. 1988;19(3):135-42. X-1. [pmid: 2464773].
418 Fong PH, Chan HL, Tan W. Initial experience with the argon laser in cutaneous vascular lesions. Ann Acad Med Singapore. Oct. 1988;17(4):498-501. X-1, X-2. [pmid: 3223738].
419 Furusaka T, Ishiyama E, Kida A, et al. Indication of cryosurgery on tonsillar diseases. Acta Otolaryngol Suppl. 1988;454:292-8. X-1. [pmid: 3066107].
420 Gillespie JB, Mallory SB, Kearns GL, et al. Altered gentamicin disposition in a child with a cavernous hemangioma. J Am Acad Dermatol. Nov. 1988;19(5 Pt 2):965-8. X-1. [pmid: 3192781].
421 Gozal D, Soudry M, Arad P, et al. Arteriovenous haemangioma of the joint capsule of the knee in a child. Eur J Pediatr. Dec. 1988;148(3):198-9. X-1. [pmid: 3215195].
422 Hagberg G, Fernell E, von Wendt L. Epidemiology of infantile hydrocephalus in Sweden. Reduced optimality in prepartum, partum and postpartum conditions. A case-control study. Neuropediatrics. Feb. 1988;19(1):16-23. X-1. [pmid: 3362308].
423 Hatzis J, Kostakis P, Tosca A, et al. Nuchal nevus flammeus as a skin marker of prognosis in alopecia areata. Dermatologica. 1988;177(3):149-51. X-1. [pmid: 3169340].
424 Hauben DJ. Reduction cheiloplasty for upper lip hemangioma. Plast Reconstr Surg. Oct. 1988;82(4):694-7. X-1. [pmid: 3420193].
425 Herter T, Brandt M, Szuwart U. Cavernous hemangiomas in children. Childs Nerv Syst. Jun. 1988;4(3):123-7. X-1. [pmid: 3396017].
426 Holcomb GW 3rd, O’Neill JA Jr, Mahboubi S, et al. Experience with hepatic hemangioendothelioma in infancy and childhood. J Pediatr Surg. Jul. 1988;23(7):661-6. X-1. [pmid: 3204467].
427 Holloway H, Johnson J, Sandler M. Detection of an ileal cavernous hemangioma by technetium-99m red blood cell imaging. Clin Nucl Med. Jan. 1988;13(1):32-4. X-1. [pmid: 3349695].
428 Imakita M, Yutani C, Ishibashi-Ueda H, et al. A case of hydrops fetalis due to placental chorioangioma. Acta Pathol Jpn. Jul. 1988;38(7):941-5. X-1. [pmid: 3055811].
429 Iwatsuki S, Starzl TE. Personal experience with 411 hepatic resections. Ann Surg. Oct. 1988;208(4):421-34. X-1. [pmid: 3178330].
430 Konior RJ, Holinger LD, Russell EJ. Superselective embolization of laryngeal hemangioma. Laryngoscope. Aug. 1988;98(8 Pt 1):830-4. X-2. [pmid: 3398657].
431 Lack EE, Upton MP. Histopathologic review of salivary gland tumors in childhood. Arch Otolaryngol Head Neck Surg. Aug. 1988;114(8):898-906. X-1, X-3. [pmid: 2839210].
432 Leonard MP, Nickel JC, Morales A. Cavernous hemangiomas of the bladder in the pediatric age group. J Urol. Dec. 1988;140(6):1503-4. X-1. [pmid: 3057231].
433 Leung AK, Lowry RB, Mitchell I, et al. Klippel-Trenaunay and Sturge-Weber syndrome with extensive Mongolian spots, hypoplastic larynx and subglottic stenosis. Clin Exp Dermatol. Mar. 1988;13(2):128-32. X-1. [pmid: 2850877].
434 Levin AV, Selbst SM. Vulvar hemangioma simulating child abuse. Clin Pediatr (Phila). Apr. 1988;27(4):213-5. X-1, X-2. [pmid: 3349732].
435 Levy I, Danziger Y, Mechlis-Frish S, et al. Technetium-labeled red blood cell imaging to evaluate soft tissue hemangioma of the hand. Pediatr Dermatol. Feb. 1988;5(1):47-9. X-1. [pmid: 2837746].
436 Liu HC, Chang MH, Lue HC, et al. Hepatic hemangioma in infancy and early childhood. Taiwan Yi Xue Hui Za Zhi. Mar. 1988;87(3):288-96. X-1. [pmid: 3397726].
437 Loh W Jr, Miller JH, Gomperts ED. Imaging with technetium 99m-labeled erythrocytes in evaluation of the Kasabach-Merritt syndrome. J Pediatr. Nov. 1988;113(5):856-9. X-1. [pmid: 3183843].
438 Malm M, Jurell G, Glas JE. Argon laser treatment of port wine stain. Scand J Plast Reconstr Surg Hand Surg. 1988;22(3):245-8. X-1. [pmid: 3252454].
439 Maruiwa M, Nakamura Y, Motomura K, et al. Cornelia de Lange syndrome associated with Wilms’ tumour and infantile haemangioendothelioma of the liver: report of two autopsy cases. Virchows Arch A Pathol Anat Histopathol. 1988;413(5):463-8. X-1. [pmid: 2845644].
440 Mastroiacovo P, Spagnolo A, Marni E, et al. Birth defects in the Seveso area after TCDD contamination. Jama. Mar. 18. 1988;259(11):1668-72. X-1. [pmid: 3343773].
441 Michaud LJ, Jaffe KM, Benjamin DR, et al. Hemangioblastoma of the conus medullaris associated with cutaneous hemangioma. Pediatr Neurol. Sep–Oct. 1988;4(5):309-12. X-1. [pmid: 3242536].
442 Monnier PH, Ravussin P, Savary M, et al. Percutaneous transtracheal ventilation for laser endoscopic treatment of laryngeal and subglottic lesions. Clin Otolaryngol Allied Sci. Jun. 1988;13(3):209-17. X-1, X-2. [pmid: 3402098].
443 Myer CM 3rd, Miller R, Gray S. Nasal presentation of an intracranial vascular anomaly. Int J Pediatr Otorhinolaryngol. May. 1988;15(2):221-5. X-1. [pmid: 3397243].
444 Narasimharao KL, Kaushik S, Malik AK, et al. Tongue hemangiomas. Indian Pediatr. Jan. 1988;25(1):92-4. X-2. [pmid: 3220530].
445 Nuutinen EM, Puistola U, Herva R, et al. Two cases of large placental chorioangioma with fetal and neonatal complications. Eur J Obstet Gynecol Reprod Biol. Dec. 1988;29(4):315-20. X-1. [pmid: 2976380].
446 Occhiogrosso M, Spada A, Vailati G. Forth ventricle hematoma in a eight-year-old child. J Neurosurg Sci. Apr–Jun. 1988;32(2):87-9. X-1. [pmid: 3199216].
447 Ogita S, Tsuto T, Deguchi E, et al. Giant cavernous haemangioma: treatment with intralesional injection of OK-432. Z Kinderchir. Dec. 1988;43(6):408-9. X-1. [pmid: 3239253].
448 Plowman PN, Harnett AN. Radiotherapy in benign orbital disease. I: Complicated ocular angiomas. Br J Ophthalmol. Apr. 1988;72(4):286-8. X-1, X-2. [pmid: 3378026].
449 Qureshi SA, Gregg JE, Galloway RW. Computed tomographic appearances of massive neonatal hemangioma of the liver: a case report. J Comput Tomogr. Apr. 1988;12(2):135-7. X-1, X-2. [pmid: 3168523].
450 Ranne RD, Ashcraft KW, Holder TM, et al. Hepatic hemangioma: resection using hypothermic circulatory arrest in the newborn. J Pediatr Surg. Oct. 1988;23(10):924-6. X-1. [pmid: 3236162].
451 Rappaport ZH. Corpus callosum section in the treatment of intractable seizures in the Sturge-Weber syndrome. Childs Nerv Syst. Aug. 1988;4(4):231-2. X-1. [pmid: 3167877].
452 Rizzo R, Micali G, Incorpora G, et al. A very aggressive form of facial hemangioma. Pediatr Dermatol. Nov. 1988;5(4):263-5. X-1, X-2. [pmid: 3231585].
453 Sato SE, Herschler J, Lynch PJ, et al. Congenital glaucoma associated with cutis marmorata telangiectatica congenita: two case reports. J Pediatr Ophthalmol Strabismus. Jan–Feb. 1988;25(1):13-7. X-1. [pmid: 3343635].
454 Scott GA, Rosai J. Spindle cell hemangioendothelioma. Report of seven additional cases of a recently described vascular neoplasm. Am J Dermatopathol. Aug. 1988;10(4):281-8. X-1. [pmid: 2458050].
455 Shorr N, Goldberg RA, David LM. Laser treatment of juvenile hemangioma. Ophthal Plast Reconstr Surg. 1988;4(3):131-4. X-2. [pmid: 3154730].
456 Soberman MS, Plauth WH, Winn KJ, et al. Hemangioma of the right ventricle causing outflow tract obstruction. J Thorac Cardiovasc Surg. Aug. 1988;96(2):307-9. X-1, X-2. [pmid: 3398552].
457 Srinivas CR, Rao PL. Sudoriparous angioma--regression following intravascular aethoxysclerol, a sclerosing agent. Br J Dermatol. Jul. 1988;119(1):111-3. X-1. [pmid: 3408654].
458 Taratuto AL, Zurbriggen G, Sevlever G, et al. Epithelioid hemangioendothelioma of the central nervous system. Immunohistochemical and ultrastructural observations of a pediatric case. Pediatr Neurosci. 1988;14(1):11-4. X-1. [pmid: 3217280].
459 Tolmie JL, Browne BH, McGettrick PM, et al. A familial syndrome with coats’ reaction retinal angiomas, hair and nail defects and intracranial calcification. Eye (Lond). 1988;2(Pt 3):297-303. X-1. [pmid: 3402627].
460 Totsuka Y, Fukuda H, Tomita K. Compression therapy for parotid haemangioma in infants. A report of three cases. J Craniomaxillofac Surg. Nov. 1988;16(8):366-70. X-2. [pmid: 3204160].
461 Vaillant L, Lorette G, Chantepie A, et al. Multiple cutaneous hemangiomas and coarctation of the aorta with right aortic arch. Pediatrics. May. 1988;81(5):707-10. X-2. [pmid: 3357730].
462 Vellodi A, Bini RM. Malignant ventricular arrhythmias caused by hyperkalaemia complicating the Kasabach-Merritt syndrome. J R Soc Med. Mar. 1988;81(3):167-8. X-1. [pmid: 3357160].
463 Wagner RS, Caputo AR, Del Negro RG, et al. Trabeculectomy with cyclocryotherapy for infantile glaucoma in the Sturge-Weber syndrome. Ann Ophthalmol. Aug. 1988;20(8):289-91. 95. X-1. [pmid: 3190106].
464 Weir MR. Atypical idiopathic hypercalciuria in an adolescent. J Adolesc Health Care. Nov. 1988;9(6):498-500. X-1. [pmid: 3182367].
465 Weiss SW. Pedal hemangioma (venous malformation) occurring in Turner’s syndrome: an additional manifestation of the syndrome. Hum Pathol. Sep. 1988;19(9):1015-8. X-1. [pmid: 3417285].
466 Wenig BL, Abramson AL. Congenital subglottic hemangiomas: a treatment update. Laryngoscope. Feb. 1988;98(2):190-2. X-4. [pmid: 3123827].
467 Wick MR, Rocamora A. Reactive and malignant “angioendotheliomatosis”: a discriminant clinicopathological study. J Cutan Pathol. Oct. 1988;15(5):260-71. X-1. [pmid: 3209761].
468 Wright JE. Doyne Lecture: Current concepts in orbital disease. Eye (Lond). 1988;2(Pt 1):1-11. X-1, X-2. [pmid: 3044844].
469 Yamaguchi K, Yamaguchi K, Tamai M. Cavernous hemangioma of the retina in a pediatric patient. Ophthalmologica. 1988;197(3):127-9. X-1. [pmid: 3231418].
470 Dye-laser treatment of children with port-wine stains. N Engl J Med. Sep. 28. 1989;321(13):901-3. X-3, X-4. [pmid: 2770828].
471 Albright AL, Gartner JC, Wiener ES. Lumbar cutaneous hemangiomas as indicators of tethered spinal cords. Pediatrics. Jun. 1989;83(6):977-80. X-3, X-4. [pmid: 2657627].
472 Anand R, Augsburger JJ, Shields JA. Circumscribed choroidal hemangiomas. Arch Ophthalmol. Sep. 1989;107(9):1338-42. X-1. [pmid: 2783066].
473 Apfelberg DB, Maser MR, Lash H, et al. Sapphire tip technology for YAG laser excisions in plastic surgery. Plast Reconstr Surg. Aug. 1989;84(2):273-9. X-1. [pmid: 2748740].
474 Apfelberg DB, Maser MR, White DN, et al. A preliminary study of the combined effect of neodymium: YAG laser photocoagulation and direct steroid instillation in the treatment of capillary/cavernous hemangiomas of infancy. Ann Plast Surg. Feb. 1989;22(2):94-104. X-4. [pmid: 2735715].
475 Augsburger JJ. Birthmarks of the eye and eyelids as indicators of ocular or systemic tumors. J Ophthalmic Nurs Technol. Sep–Oct. 1989;8(5):197-202. X-1. [pmid: 2795670].
476 Azmy AF, Stephenson J, Ziervogel M. Angiomyolipoma causing life-threatening hematuria in a child with tuberous sclerosis. J Pediatr Surg. Dec. 1989;24(12):1308-9. X-1. [pmid: 2593064].
477 Bennett JE. Re: Apfelberg et al: a preliminary study of the combined effect of neodymium: YAG laser photocoagulation and direct steroid instillation in the treatment of capillary/cavernous hemangiomas of infancy. Ann Plast Surg. Oct. 1989;23(4):375. X-3, X-4. [pmid: 2817722].
478 Brooks M. Small bowel volvulus, mesenteric band, cavernous haemangioma, and failure to thrive. Scott Med J. Oct. 1989;34(5):535-6. X-1. [pmid: 2587983].
479 Buckingham MJ, Crone KR, Ball WS, et al. Management of cerebral cavernous angiomas in children presenting with seizures. Childs Nerv Syst. Dec. 1989;5(6):347-9. X-1. [pmid: 2611768].
480 Casale AJ, Menashe DS. Massive strawberry hemangioma of the male genitalia. J Urol. Mar. 1989;141(3):593-4. X-2. [pmid: 2918599].
481 Castle VP, Shulkin BL, Coates G, et al. The use of indium-111 oxine platelet scintigraphy and survival studies in pediatric patients with thrombocytopenia. J Nucl Med. Nov. 1989;30(11):1819-24. X-1, X-3. [pmid: 2509647].
482 Chiron C, Raynaud C, Tzourio N, et al. Regional cerebral blood flow by SPECT imaging in Sturge-Weber disease: an aid for diagnosis. J Neurol Neurosurg Psychiatry. Dec. 1989;52(12):1402-9. X-1. [pmid: 2614436].
483 Cogen MS, Elsas FJ. Eyelid depigmentation following corticosteroid injection for infantile ocular adnexal hemangioma. J Pediatr Ophthalmol Strabismus. Jan–Feb. 1989;26(1):35-8. X-2. [pmid: 2915311].
484 Colombo F, Benedetti A, Pozza F, et al. Linear accelerator radiosurgery of cerebral arteriovenous malformations. Neurosurgery. Jun. 1989;24(6):833-40. X-1. [pmid: 2664545].
485 Corboy JR, Galetta SL. Familial cavernous angiomas manifesting with an acute chiasmal syndrome. Am J Ophthalmol. Sep. 15. 1989;108(3):245-50. X-1. [pmid: 2774032].
486 Cornelius AS, Womer RB, Jakacki R. Multiple hemangioendotheliomas of the liver. Med Pediatr Oncol. 1989;17(6):501-4. X-1. [pmid: 2586364].
487 de Keizer RJ, Scheffer E. Masquerade of eyelid tumours. Doc Ophthalmol. Aug. 1989;72(3–4):309-21. X-1. [pmid: 2625092].
488 Ferrante L, Acqui M, d’Addetta R, et al. Neuroradiological findings in cavernous hemangioma. An analysis of 15 cases. Zentralbl Neurochir. 1989;50(3–4):184-7. X-1. [pmid: 2642237].
489 Folkman J. Successful treatment of an angiogenic disease. N Engl J Med. May. 4. 1989;320(18):1211-2. X-3, X-4. [pmid: 2469017].
490 Fradis M, Podoshin L, Simon J, et al. Combined treatment of large head and neck capillaro-venous malformation by a fibrosing agent. J Laryngol Otol. Apr. 1989;103(4):390-8. X-1. [pmid: 2715693].
491 Frima-Verhoeven PA, Op de Coul AA, Tijssen CC, et al. Intracranial cavernous angiomas: diagnosis and therapy. Eur Neurol. 1989;29(1):56-60. X-1. [pmid: 2707292].
492 Furst CJ, Lundell M, Ahlback SO, et al. Breast hypoplasia following irradiation of the female breast in infancy and early childhood. Acta Oncol. 1989;28(4):519-23. X-3. [pmid: 2789829].
493 Furst CJ, Silfversward C, Holm LE. Mortality in a cohort of radiation treated childhood skin hemangiomas. Acta Oncol. 1989;28(6):789-94. X-3. [pmid: 2611031].
494 Gangemi M, Longatti P, Maiuri F, et al. Cerebral cavernous angiomas in the first year of life. Neurosurgery. Sep. 1989;25(3):465-8. discussion 8–9. X-1. [pmid: 2771019].
495 Glassberg E, Lask G, Rabinowitz LG, et al. Capillary hemangiomas: case study of a novel laser treatment and a review of therapeutic options. J Dermatol Surg Oncol. Nov. 1989;15(11):1214-23. X-1, X-2. [pmid: 2808890].
496 Goldberg DJ. Laser surgery of the skin. Am Fam Physician. Nov. 1989;40(5):109-16. X-1. [pmid: 2510483].
497 Gonen R, Fong K, Chiasson DA. Prenatal sonographic diagnosis of hepatic hemangioendothelioma with secondary nonimmune hydrops fetalis. Obstet Gynecol. Mar. 1989;73(3 Pt 2):485-7. X-1. [pmid: 2644601].
498 Hanna BD, Bernstein M. Tranexamic acid in the treatment of Kasabach-Merritt syndrome in infants. Am J Pediatr Hematol Oncol. Summer. 1989;11(2):191-5. X-1, X-2. [pmid: 2751074].
499 Ito H, Yamasaki T, Okamoto O, et al. Infantile hemangioendothelioma of the liver in patient with interstitial deletion of chromosome 6q: report of an autopsy case. Am J Med Genet. Nov. 1989;34(3):325-9. X-1. [pmid: 2596522].
500 Ito M, Sato K, Maruki C, et al. Surgical treatment of Sturge-Weber syndrome--case report. Neurol Med Chir (Tokyo). Jan. 1989;29(1):60-4. X-1. [pmid: 2472571].
501 Korn EL, Goodrich S. Use of the carbon dioxide laser to remove an eyelid hemangioma. Ophthalmic Surg. Dec. 1989;20(12):887-8. X-2. [pmid: 2517140].
502 Kristal H, Sperber F. Hepatic angiomyolipoma in a tuberous sclerosis patient. Isr J Med Sci. Jul. 1989;25(7):412-4. X-1. [pmid: 2668223].
503 Kushner BJ, Meyers FL. Good visual outcome after endophthalmitis in an eye previously treated successfully for amblyopia. J Pediatr Ophthalmol Strabismus. Mar–Apr. 1989;26(2):69-71. X-1, X-2. [pmid: 2785175].
504 Lanigan SW, Cartwright P, Cotterill JA. Continuous wave dye laser therapy of port wine stains. Br J Dermatol. Sep. 1989;121(3):345-52. X-1. [pmid: 2803960].
505 Leary DL, Weiskittel DA, Blane CE, et al. Follow-up imaging of benign pediatric liver tumors. Pediatr Radiol. 1989;19(4):234-6. X-1. [pmid: 2546119].
506 Luukkonen P, Jarvinen HJ, Rintala R. Colo-anal sleeve resection for rectal hemangioma. Case report. Acta Chir Scand. Nov–Dec. 1989;155(11–12):613-6. X-1. [pmid: 2618519].
507 Machin GA, Kent S. Pulmonary thromboembolism from a large hemangioma in a 4-week-old infant. Pediatr Pathol. 1989;9(1):73-8. X-1, X-2. [pmid: 2717500].
508 Mallory SB, Morris P. Bleeding hemangioma detected by enuresis blanket. Pediatr Dermatol. Jun. 1989;6(2):139-40. X-2. [pmid: 2748474].
509 Mulder JJ, van den Broek P. Surgical treatment of infantile subglottic hemangioma. Int J Pediatr Otorhinolaryngol. Feb. 1989;17(1):57-63. X-2. [pmid: 2707979].
510 Narbone MC, D’Amico D, Bramanti P, et al. Bilateral cortical calcifications with benign clinical course: an unusual case of Sturge-Weber syndrome?. Acta Neurol (Napoli). Dec. 1989;11(6):423-7. X-1. [pmid: 2618827].
511 Niedt GW, Greco MA, Wieczorek R, et al. Hemangioma with Kaposi’s sarcoma-like features: report of two cases. Pediatr Pathol. 1989;9(5):567-75. X-1. [pmid: 2813203].
512 Nishio A, Sakaguchi M, Murata K, et al. Lateral situated sinus pericranii. Case report. Surg Neurol. Nov. 1989;32(5):382-6. X-1. [pmid: 2814792].
513 Ogunmekan AO, Hwang PA, Hoffman HJ. Sturge-Weber-Dimitri disease: role of hemispherectomy in prognosis. Can J Neurol Sci. Feb. 1989;16(1):78-80. X-1. [pmid: 2924212].
514 Ozsoylu S, Irken G, Gurgey A. High dose intravenous methylprednisolone for Kassabach-Merritt syndrome. Eur J Pediatr. Feb. 1989;148(5):403-5. X-1, X-2. [pmid: 2920745].
515 Picci P, Sudanese A, Greggi T, et al. Intramuscular hemangioma in infancy: diagnostic and therapeutic considerations. J Pediatr Orthop. Jan–Feb. 1989;9(1):72-5. X-2. [pmid: 2915042].
516 Remacle M, Declaye X, Mayne A. Subglottic haemangioma in the infant: contribution by CO2 laser. J Laryngol Otol. Oct. 1989;103(10):930-4. X-3, X-4. [pmid: 2511264].
517 Reyes BA, Vazquez-Botet M, Capo H. Intralesional steroids in cutaneous hemangioma. J Dermatol Surg Oncol. Aug. 1989;15(8):828-32. X-2. [pmid: 2754087].
518 Sadan N, Horowitz I, Choc L, et al. Giant hemangioma with thrombocytopenia and osteolysis successfully treated with prednisone. J Pediatr Orthop. Jul–Aug. 1989;9(4):472-5. X-1, X-2. [pmid: 2732330].
519 Seifert V, Trost HA, Dietz H. Cavernous angiomas of the supratentorial compartment. Zentralbl Neurochir. 1989;50(2):89-92. X-1. [pmid: 2516390].
520 Skopec LL, Lakatua DJ. Non-immune fetal hydrops with hepatic hemangioendothelioma and Kasabach-Merritt syndrome: a case report. Pediatr Pathol. 1989;9(1):87-93. X-1. [pmid: 2717502].
521 Smith MB, Hardin WD Jr, Moynihan PC. Differentiation and treatment of hemangiomas and arteriovenous malformations. J La State Med Soc. Jun. 1989;141(6):41-3. X-1, X-2. [pmid: 2732611].
522 Staindl O. Treatment of hemangiomas of the face with magnesium seeds. Arch Otorhinolaryngol. 1989;246(4):213-7. X-3, X-4. [pmid: 2597082].
523 Stanley P, Geer GD, Miller JH, et al. Infantile hepatic hemangiomas. Clinical features, radiologic investigations, and treatment of 20 patients. Cancer. Aug. 15. 1989;64(4):936-49. X-4. [pmid: 2663135].
524 Suen JY, Waner M. Treatment of oral cavity vascular malformations using the neodymium:YAG laser. Arch Otolaryngol Head Neck Surg. Nov. 1989;115(11):1329-33. X-1, X-2. [pmid: 2553074].
525 Tan OT, Sherwood K, Gilchrest BA. Treatment of children with port-wine stains using the flashlamp-pulsed tunable dye laser. N Engl J Med. Feb. 16. 1989;320(7):416-21. X-1. [pmid: 2913507].
526 Taylor RS, Joseph DB, Kohaut EC, et al. Renal angiomyolipoma associated with lymph node involvement and renal cell carcinoma in patients with tuberous sclerosis. J Urol. Apr. 1989;141(4):930-2. X-1. [pmid: 2926893].
527 Trussart V, Berry I, Manelfe C, et al. Epileptogenic cerebral vascular malformations and MRI. J Neuroradiol. Dec. 1989;16(4):273-84. X-1. [pmid: 2638394].
528 van Baal JG, Fleury P, Brummelkamp WH. Tuberous sclerosis and the relation with renal angiomyolipoma. A genetic study on the clinical aspects. Clin Genet. Mar. 1989;35(3):167-73. X-1. [pmid: 2706800].
529 Vazquez-Botet R, Reyes BA, Vazquez-Botet M. Sclerodermiform linear atrophy after the use of intralesional steroids for periorbital hemangiomas: a review of complications. J Pediatr Ophthalmol Strabismus. May–Jun. 1989;26(3):124-7. X-2. [pmid: 2723973].
530 Walker EP, Butler PH, Pickering JW, et al. Histology of port wine stains after copper vapour laser treatment. Br J Dermatol. Aug. 1989;121(2):217-23. X-1. [pmid: 2775646].
531 Weiss AH. Adrenal suppression after corticosteroid injection of periocular hemangiomas. Am J Ophthalmol. May. 15. 1989;107(5):518-22. X-4. [pmid: 2540659].
532 White CW, Sondheimer HM, Crouch EC, et al. Treatment of pulmonary hemangiomatosis with recombinant interferon alfa-2a. N Engl J Med. May. 4. 1989;320(18):1197-200. X-1. [pmid: 2710192].
533 Yeoman LJ, Shaw D. Computerized tomography appearances of pelvic haemangioma involving the large bowel in childhood. Pediatr Radiol. 1989;19(6–7):414-6. X-1, X-2. [pmid: 2771480].
534 Achauer BM, Vander Kam VM, Miller SR. Clinical experience with the pulsed-dye laser in the treatment of capillary malformations (port-wine stains): a preliminary report. Ann Plast Surg. Nov. 1990;25(5):344-52. X-1. [pmid: 2256647].
535 Adam YG, Alberts W. Retroperitoneal hemangioma. Am Surg. Jun. 1990;56(6):374-6. X-2. [pmid: 1972007].
536 Aguirre Vila-Coro A, Dominguez R, Calk JB, et al. Congenital generalized fibromatosis. Ann Ophthalmol (Skokie). Jun. 1990;22(6):217-21. PMID: X-1.
537 Akashi S, Motizuki H. Screening for hypercalciuria. Acta Paediatr Jpn. Dec. 1990;32(6):701-9. X-1. [pmid: 2082673].
538 Ali MA, Fahmy IA, Spaeth GL. Trabeculectomy for glaucoma associated with Sturge-Weber syndrome. Ophthalmic Surg. May. 1990;21(5):352-5. X-1. [pmid: 2381658].
539 Apfelberg DB, Maser MR, Lash H, et al. YAG laser resection of complicated hemangiomas of the hand and upper extremity. J Hand Surg Am. Sep. 1990;15(5):765-73. X-1. [pmid: 2229976].
540 Apfelberg DB, Maser MR, White DN, et al. Benefits of contact and noncontact YAG laser for periorbital hemangiomas. Ann Plast Surg. May. 1990;24(5):397-408. X-1. [pmid: 2350150].
541 Apfelberg DB, Maser MR, White DN, et al. Combination treatment for massive cavernous hemangioma of the face: YAG laser photocoagulation plus direct steroid injection followed by YAG laser resection with sapphire scalpel tips, aided by superselective embolization. Lasers Surg Med. 1990;10(3):217-23. X-1. [pmid: 2345471].
542 Ashinoff R, Geronemus RG. Effect of the topical anesthetic EMLA on the efficacy of pulsed dye laser treatment of port-wine stains. J Dermatol Surg Oncol. Nov. 1990;16(11):1008-11. X-1. [pmid: 2246405].
543 Asthana AK, Tandon SC, Pant GC, et al. Radiation therapy for symptomatic vertebral haemangioma. Clin Oncol (R Coll Radiol). May. 1990;2(3):159-62. X-1. [pmid: 2261405].
544 Aylett SE, Williams AF, Bevan DH, et al. The Kasabach-Merritt syndrome: treatment with intermittent pneumatic compression. Arch Dis Child. Jul. 1990;65(7):790-1. X-1. [pmid: 2386388].
545 Bandoh Y, Yanai A, Tsuzuki K. Dye laser treatment of port-wine stains. Aesthetic Plast Surg. Fall. 1990;14(4):287-91. X-1. [pmid: 2239519].
546 Basaklar AC. Haemangiomas of the gastrointestinal tract in children. Z Kinderchir. Apr. 1990;45(2):114-6. X-1. [pmid: 2360368].
547 Blodi CF, Russell SR, Pulido JS, et al. Direct and feeder vessel photocoagulation of retinal angiomas with dye yellow laser. Ophthalmology. Jun. 1990;97(6):791-5. discussion 6–7. X-1. [pmid: 2374684].
548 Bottoni F, Canevini MP, Canger R, et al. Twin vessels in familial retinal cavernous hemangioma. Am J Ophthalmol. Mar. 15. 1990;109(3):285-9. X-1. [pmid: 2309859].
549 Bowyer JJ, Sheppard M. Capillary haemangioma presenting as a lung pseudocyst. Arch Dis Child. Oct. 1990;65(10):1162-4. X-1, X-2. [pmid: 2248511].
550 Brocheler J, Thron A. Intracranial arterial aneurysms in children. Clinical, neuroradiological and histological findings. Neurosurg Rev. 1990;13(4):309-13. X-1. [pmid: 2280842].
551 Casey WF, Rice LJ, Hannallah RS, et al. A comparison between bupivacaine instillation versus ilioinguinal/iliohypogastric nerve block for postoperative analgesia following inguinal herniorrhaphy in children. Anesthesiology. Apr. 1990;72(4):637-9. X-1. [pmid: 2321781].
552 Chazotte C, Girz B, Koenigsberg M, et al. Spontaneous infarction of placental chorioangioma and associated regression of hydrops fetalis. Am J Obstet Gynecol. Oct. 1990;163(4 Pt 1):1180-1. X-1. [pmid: 2220924].
553 Costello SA, Seywright M. Postirradiation malignant transformation in benign haemangioma. Eur J Surg Oncol. Dec. 1990;16(6):517-9. X-1. [pmid: 2253799].
554 Dabashi Y, Eisen RN. Infantile hemangioendothelioma of the pelvis associated with Kasabach-Merritt syndrome. Pediatr Pathol. 1990;10(3):407-15. X-1. [pmid: 2349157].
555 Davenport M, Salisbury J, Karani J, et al. Retroperitoneal haemangiolymphangioma presenting with projectile vomiting and thrombocytopaenia at 2 weeks of age. J R Soc Med. Sep. 1990;83(9):591-2. X-1. [pmid: 2213812].
556 Dawson MH. Tuberous sclerosis. J La State Med Soc. Mar. 1990;142(3):35-8. X-1. [pmid: 2319202].
557 Diwan R. Laser therapy in the treatment of congenital vascular abnormalities. Md Med J. Apr. 1990;39(4):343-6. X-1. [pmid: 2333019].
558 Edwards WH Jr, Sawyers JL, Adkins RB Jr, et al. Major hepatic resection: an update. South Med J. Jan. 1990;83(1):18-22. X-1. [pmid: 2154037].
559 Enjolras O, Riche MC, Merland JJ, et al. Management of alarming hemangiomas in infancy: a review of 25 cases. Pediatrics. Apr. 1990;85(4):491-8. X-3, X-4. [pmid: 2097998].
560 Epstein MA, Berman PH, Schut L. Cavernous angioma presenting as atypical facial and head pain. J Child Neurol. Jan. 1990;5(1):27-30. X-1. [pmid: 2299136].
561 Epstein RH, Brummett RR Jr, Lask GP. Incendiary potential of the flash-lamp pumped 585-nm tunable dye laser. Anesth Analg. Aug. 1990;71(2):171-5. X-1. [pmid: 2375518].
562 Fernell E, Hagberg G, Hagberg B. Infantile hydrocephalus--the impact of enhanced preterm survival. Acta Paediatr Scand. Nov. 1990;79(11):1080-6. X-1. [pmid: 2267927].
563 Fivush B. Irritability and dysuria in infants with idiopathic hypercalciuria. Pediatr Nephrol. May. 1990;4(3):262-3. X-1. [pmid: 2133372].
564 Ford MD, Codere F. Perilymphatic subcutaneous atrophy in adnexal hemangioma: a complication of intralesional corticosteroid injection. Ophthalmic Surg. Mar. 1990;21(3):215-7. X-2. [pmid: 2348971].
565 Franca-Martins AM, Graubard Z, Holloway GA, et al. Placental haemangioma associated with acute fetal anemia in labour. Acta Med Port. May–Jun. 1990;3(3):187-9. X-1. [pmid: 2220431].
566 Franks R, Rothera M. Cardiopulmonary bypass for resection of low tracheal haemangioma. Arch Dis Child. Jun. 1990;65(6):630-2. X-2. [pmid: 2378524].
567 Friedman EM, Vastola AP, McGill TJ, et al. Chronic pediatric stridor: etiology and outcome. Laryngoscope. Mar. 1990;100(3):277-80. X-3, X-4. [pmid: 2308452].
568 Furst CJ, Lundell M, Holm LE. Tumors after radiotherapy for skin hemangioma in childhood. A case-control study. Acta Oncol. 1990;29(5):557-62. X-3. [pmid: 2206565].
569 Gangemi M, Maiuri F, Donati P, et al. Familial cerebral cavernous angiomas. Neurol Res. Sep. 1990;12(3):131-6. X-1. [pmid: 1979841].
570 Gaspar L, Szabo G. Manifestation of the advantages and disadvantages of using the CO2 laser in oral surgery. J Clin Laser Med Surg. Feb. 1990;8(1):39-43. X-3, X-4. [pmid: 10148946].
571 Goldstein MH. The elastic flap: an expanding vermilion myocutaneous flap for lip repairs. Facial Plast Surg. 1990;7(2):119-25. X-1, X-2. [pmid: 2132232].
572 Gozal D, Saad N, Bader D, et al. Diffuse neonatal haemangiomatosis: successful management with high dose corticosteroids. Eur J Pediatr. Feb. 1990;149(5):321-4. X-1. [pmid: 2311628].
573 Greene LA, Freedman PD, Friedman JM, et al. Capillary hemangioma of the maxilla. A report of two cases in which angiography and embolization were used. Oral Surg Oral Med Oral Pathol. Sep. 1990;70(3):268-73. X-1. [pmid: 2216353].
574 Gunes HA, Egilmez R, Dulger M. Ovarian haemangioma. Br J Clin Pract. Dec. 1990;44(12):734-5. X-1, X-2. [pmid: 2102218].
575 Hamvas A, Perlman JM, Volpe JJ. Brain death secondary to arteriovenous hemangioma of the forearm. Pediatr Neurol. Jan–Feb. 1990;6(1):63-4. X-1, X-2. [pmid: 2310440].
576 Hardy PA, Kucharczyk W, Henkelman RM. Cause of signal loss in MR images of old hemorrhagic lesions. Radiology. Feb. 1990;174(2):549-55. X-1. [pmid: 2296664].
577 Heffez DS, Zinreich SJ, Long DM. Surgical resection of intrinsic brain stem lesions: an overview. Neurosurgery. Nov. 1990;27(5):789-97. discussion 97–8. X-1. [pmid: 2259410].
578 Held JL, Haber RS, Silvers DN, et al. Benign neonatal hemangiomatosis: review and description of a patient with unusually persistent lesions. Pediatr Dermatol. Mar. 1990;7(1):63-6. X-1. [pmid: 2343009].
579 Hofhuis WJ, Oranje AP, Bouquet J, et al. Blue rubber-bleb naevus syndrome: report of a case with consumption coagulopathy complicated by manifest thrombosis. Eur J Pediatr. May. 1990;149(8):526-8. X-1. [pmid: 2347349].
580 Ikeda DM, Caron KH, Faison JD. Term infant with progressive tachypnea. Invest Radiol. Jan. 1990;25(1):79-81. X-1, X-2. [pmid: 2298554].
581 Ito M, Sato K, Ohnuki A, et al. Sturge-Weber disease: operative indications and surgical results. Brain Dev. 1990;12(5):473-7. X-1. [pmid: 2288377].
582 Iwach AG, Hoskins HD Jr, Hetherington J Jr, et al. Analysis of surgical and medical management of glaucoma in Sturge-Weber syndrome. Ophthalmology. Jul. 1990;97(7):904-9. X-1. [pmid: 2381705].
583 Iwatsuki S, Todo S, Starzl TE. Excisional therapy for benign hepatic lesions. Surg Gynecol Obstet. Sep. 1990;171(3):240-6. X-1. [pmid: 1696751].
584 Jeter TS, Hackney FL, Aufdemorte TB. Cavernous hemangioma of the zygoma: report of cases. J Oral Maxillofac Surg. May. 1990;48(5):508-12. X-1, X-2. [pmid: 2329401].
585 Kaplan P, Normandin J Jr, Wilson GN, et al. Malformations and minor anomalies in children whose mothers had prenatal diagnosis: comparison between CVS and amniocentesis. Am J Med Genet. Nov. 1990;37(3):366-70. X-1. [pmid: 2260567].
586 Kodachi K, Kojima T, Shimbashi T, et al. Hemangioma of the fingers. Handchir Mikrochir Plast Chir. Jan. 1990;22(1):49-52. X-1, X-2. [pmid: 2311997].
587 Koivu MK, Nuutinen EM. Large placental chorioangioma as a cause of congestive heart failure in newborn infants. Pediatr Cardiol. Oct. 1990;11(4):221-4. X-1. [pmid: 2274453].
588 Lanigan SW, Cotterill JA. The treatment of port wine stains with the carbon dioxide laser. Br J Dermatol. Aug. 1990;123(2):229-35. X-1. [pmid: 2119215].
589 Leighton DM, Benghanem T, Montagne JP, et al. A case of rectal bleeding in infancy. Australas Radiol. Feb. 1990;34(1):89-90. X-1, X-2. [pmid: 2357199].
590 Lieb WE, Shields JA, Cohen SM, et al. Color Doppler imaging in the management of intraocular tumors. Ophthalmology. Dec. 1990;97(12):1660-4. X-1. [pmid: 2087296].
591 Lundell M, Furst CJ, Hedlund B, et al. Radium treatment for hemangioma in early childhood. Reconstruction and dosimetry of treatments, 1920–1959. Acta Oncol. 1990;29(5):551-6. X-3. [pmid: 2206564].
592 Luthringer DJ, Virmani R, Weiss SW, et al. A distinctive cardiovascular lesion resembling histiocytoid (epithelioid) hemangioma. Evidence suggesting mesothelial participation. Am J Surg Pathol. Nov. 1990;14(11):993-1000. X-1. [pmid: 2240358].
593 Malone PS, Kiely EM, Spitz L. Diffuse cavernous haemangioma of the rectum in childhood. Br J Surg. Mar. 1990;77(3):338-9. X-1. [pmid: 2322806].
594 McShane MA, Finn JP, Hall-Craggs MA, et al. Neonatal hemangiomatosis presenting as infantile spasms. Neuropediatrics. Nov. 1990;21(4):211-2. X-1. [pmid: 2290483].
595 Meeuwis J, Bos CE, Hoeve LJ, et al. Subglottic hemangiomas in infants: treatment with intralesional corticosteroid injection and intubation. Int J Pediatr Otorhinolaryngol. Jun. 1990;19(2):145-50. X-4. [pmid: 2373598].
596 Molina JE, Edwards JE, Ward HB. Primary cardiac tumors: Experience at the University of Minnesota. Thoracic and Cardiovascular Surgeon, Supplement. 1990;38(2):183-91. PMID: X-1.
597 Montgomery SP, Guillot AP, Barth RA. MRI of disseminated neonatal hemangiomatosis: case report. Pediatr Radiol. 1990;20(3):204-5. X-1. [pmid: 2352803].
598 Morgan DW, Evans JN. Developmental nasal anomalies. J Laryngol Otol. May. 1990;104(5):394-403. X-3, X-4. [pmid: 2370465].
599 Mucitelli DR, Charles EZ, Kraus FT. Chorioangiomas of intermediate size and intrauterine growth retardation. Pathol Res Pract. Aug. 1990;186(4):455-8. X-1. [pmid: 2247373].
600 Ochi JW, Kearns DB, Seid AB, et al. Do angiomas of the nasal septum exist?. Int J Pediatr Otorhinolaryngol. Jun. 1990;19(2):169-73. X-1, X-2. [pmid: 2165038].
601 Oi S, Matsumoto S, Choi JU, et al. Brain tumors diagnosed in the first year of life in five Far-Eastern countries. Statistical analysis of 307 cases. Childs Nerv Syst. Mar. 1990;6(2):79-85. X-1. [pmid: 2340533].
602 Paes EH, Vollmar JF. Aneurysma transformation in congenital venous angiodysplasias in lower extremities. Int Angiol. Apr–Jun. 1990;9(2):90-6. X-1. [pmid: 2174953].
603 Pantzer JG Jr, et al. Port-wine stain: a new therapeutic approach to an old birth defect. Indiana Med. Nov. 1990;83(11):848-51. X-6. [pmid: 2262680].
604 Pickering JW, Walker EP, Butler PH, et al. Copper vapour laser treatment of port-wine stains and other vascular malformations. Br J Plast Surg. May. 1990;43(3):273-82. X-1. [pmid: 2350632].
605 Poirier VC, Ablin DS, Frank EH. Diffuse neonatal hemangiomatosis: a case report. AJNR Am J Neuroradiol. Nov–Dec. 1990;11(6):1097-9. X-1. [pmid: 2124035].
606 Powars D, Adams RJ, Nichols FT, et al. Delayed intracranial hemorrhage following cerebral infarction in sickle cell anemia. J Assoc Acad Minor Phys. 1990;1(3):79-82. X-1. [pmid: 2136621].
607 Qureshi S, Abbasi Z, Qadeer N, et al. Kasabach-Merritt syndrome. J Pak Med Assoc. Jul. 1990;40(7):159-61. X-1. [pmid: 2125659].
608 Raroque HG Jr, Mandler RN, Griffey MS, et al. Neoplastic angioendotheliomatosis. Arch Neurol. Aug. 1990;47(8):929-30. X-1. [pmid: 2375700].
609 Restrepo M, Munoz N, Day N, et al. Birth defects among children born to a population occupationally exposed to pesticides in Colombia. Scand J Work Environ Health. Aug. 1990;16(4):239-46. X-1, X-3. [pmid: 2389130].
610 Reyes BA, Geronemus R. Treatment of port-wine stains during childhood with the flashlamp-pumped pulsed dye laser. J Am Acad Dermatol. Dec. 1990;23(6 Pt 1):1142-8. X-1. [pmid: 2273116].
611 Rigamonti D, Spetzler RF, Medina M, et al. Cerebral venous malformations. J Neurosurg. Oct. 1990;73(4):560-4. X-1. [pmid: 2398388].
612 Rothman KF, Nutile A, Appel C. The use of dolls as a teaching aid for children undergoing treatment with the flashlamp-pulsed tunable dye laser. J Am Acad Dermatol. May. 1990;22(5 Pt 1):854-5. X-1. [pmid: 2347974].
613 Ryoppy S, Poussa M, Heiskanen O, et al. Resection of a thoracic vertebra for hemangioma--operation under deep hypothermia and circulatory arrest. A case report. J Bone Joint Surg Am. Sep. 1990;72(8):1245-9. X-1. [pmid: 2398095].
614 Salloum E, Flamant F, Caillaud JM, et al. Diagnostic and therapeutic problems of soft tissue tumors other than rhabdomyosarcoma in infants under 1 year of age: a clinicopathological study of 34 cases treated at the Institut Gustave-Roussy. Med Pediatr Oncol. 1990;18(1):37-43. X-2. [pmid: 2294390].
615 Schafer J, Pirsig W. Digital signal analysis of snoring sounds in children. Int J Pediatr Otorhinolaryngol. Dec. 1990;20(3):193-202. X-1, X-3. [pmid: 2089017].
616 Scott RM. Brain stem cavernous angiomas in children. Pediatr Neurosurg. 1990;16(6):281-6. X-1. [pmid: 2134736].
617 Sherwood KA, Tan OT. Treatment of a capillary hemangioma with the flashlamp pumped-dye laser. J Am Acad Dermatol. Jan. 1990;22(1):136-7. X-2. [pmid: 2298954].
618 Shulkin BL, Argenta LC, Cho KJ, et al. Kasabach-Merritt syndrome: treatment with epsilon-aminocaproic acid and assessment by indium 111 platelet scintigraphy. J Pediatr. Nov. 1990;117(5):746-9. X-1, X-2. [pmid: 2231207].
619 Smith JA Jr, et al. Laser treatment of bladder hemangioma. J Urol. Feb. 1990;143(2):282-4. X-3, X-4. [pmid: 2299718].
620 Staindl O. Hemangiomas of the lips: treatment with magnesium seeds. Facial Plast Surg. 1990;7(2):114-8. X-2. [pmid: 2132231].
621 Stewart G, Farmer G. Sturge-Weber and Klippel-Trenaunay syndromes with absence of inferior vena cava. Arch Dis Child. May. 1990;65(5):546-7. X-1. [pmid: 2162657].
622 Suska P, Jakubovsky J, Polak S. Premature delivery and placenta. A morphological study. Czech Med. 1990;13(4):193-212. X-1. [pmid: 2081444].
623 Taylor JL, Hockley AD, Downing R. Vascular anomalies of the scalp. Childs Nerv Syst. Sep. 1990;6(6):356-9. X-1, X-2. [pmid: 2257551].
624 Tjaden BL, Buscema J, Haller JA Jr, et al. Vulvar congenital dysplastic angiopathy. Obstet Gynecol. Mar. 1990;75(3 Pt 2):552-4. X-1. [pmid: 2154731].
625 Tokuda Y, Uozumi T, Sakoda K, et al. Giant congenital capillary hemangioma of pericranium--case report. Neurol Med Chir (Tokyo). Dec. 1990;30(13):1029-33. X-2. [pmid: 1714050].
626 Tong YC, Chieng PU, Tsai TC, et al. Renal angiomyolipoma: report of 24 cases. Br J Urol. Dec. 1990;66(6):585-9. X-1. [pmid: 2265329].
627 Townshend LM, Buckley EG. Linear subcutaneous fat atrophy after a single corticosteroid injection for ocular adnexal hemangioma. Am J Ophthalmol. Jan. 15. 1990;109(1):102-3. X-2. [pmid: 2297019].
628 van der Stricht J. The sclerosing therapy in congenital vascular defects. Int Angiol. Jul–Sep. 1990;9(3):224-7. X-1. [pmid: 2090706].
629 Weber TR, Connors RH, Tracy TF Jr, et al. Complex hemangiomas of infants and children. Individualized management in 22 cases. Arch Surg. Aug. 1990;125(8):1017-20. discussion 20–1. X-3, X-4. [pmid: 2198856].
630 Wetzel LH, Levine E. Soft-tissue tumors of the foot: value of MR imaging for specific diagnosis. AJR Am J Roentgenol. Nov. 1990;155(5):1025-30. X-1. [pmid: 2120930].
631 Winters Z, Mannell A. Parotid haemangioma. A case report. S Afr J Surg. Sep. 1990;28(3):105-6. X-1. [pmid: 2218752].
632 Yohannan MD, Abdulla AM, Patel PJ. Neonatal hepatic haemangioendothelioma: presentation with jaundice and microangiopathic haemolytic anaemia. Eur J Pediatr. Aug. 1990;149(11):804-5. X-1. [pmid: 2226558].
633 Laser treatment of cutaneous vascular lesions. Med Lett Drugs Ther. Nov. 1. 1991;33(856):104-6. X-1, X-2. [pmid: 1943977].
634 Achauer BM, Vander Kam VM. Strawberry hemangioma of infancy: early definitive treatment with an argon laser. Plast Reconstr Surg. Sep. 1991;88(3):486-9. discussion 90–1. X-2. [pmid: 1871229].
635 Achauer BM, Vander Kam VM. Ulcerated anogenital hemangioma of infancy. Plast Reconstr Surg. May. 1991;87(5):861-6. discussion 7–8. X-4. [pmid: 2017494].
636 Apfelberg DB, Lane B, Marx MP. Combined (team) approach to hemangioma management: arteriography with superselective embolization plus YAG laser/sapphire-tip resection. Plast Reconstr Surg. Jul. 1991;88(1):71-82. X-1. [pmid: 2052663].
637 Ashinoff R, Geronemus RG. Flashlamp-pumped pulsed dye laser for port-wine stains in infancy: earlier versus later treatment. J Am Acad Dermatol. Mar. 1991;24(3):467-72. X-1. [pmid: 2061448].
638 Ashinoff R, Geronemus RG. Capillary hemangiomas and treatment with the flash lamp-pumped pulsed dye laser. Arch Dermatol. Feb. 1991;127(2):202-5. X-4. [pmid: 1990985].
639 Azizkhan RG. Life-threatening hematochezia from a rectosigmoid vascular malformation in Klippel-Trenaunay syndrome: long-term palliation using an argon laser. J Pediatr Surg. Sep. 1991;26(9):1125-7. discussion 8. X-1. [pmid: 1719183].
640 Barak S, Katz J, Kaplan I. The CO2 laser in surgery of vascular tumors of the oral cavity in children. ASDC J Dent Child. Jul–Aug. 1991;58(4):293-6. X-2. [pmid: 1939793].
641 Baurmash H, DeChiara S. A conservative approach to the management of orofacial vascular lesions in infants and children: report of cases. J Oral Maxillofac Surg. Nov. 1991;49(11):1222-5. X-2. [pmid: 1941339].
642 Bertalanffy H, Gilsbach JM, Eggert HR, et al. Microsurgery of deep-seated cavernous angiomas: report of 26 cases. Acta Neurochir (Wien). 1991;108(3–4):91-9. X-1. [pmid: 2031478].
643 Bise RN, Jackson IT, Fukuta K, et al. Nasal bone haemangiomas: rare entities treatable by craniofacial approach. Br J Plast Surg. Apr. 1991;44(3):206-9. X-1. [pmid: 2025757].
644 Boyd MJ, Collin JR. Capillary haemangiomas: an approach to their management. Br J Ophthalmol. May. 1991;75(5):298-300. X-4. [pmid: 2036348].
645 Bradley M, Stewart I, Metreweli C. Diagnosis of the peripheral cavernous haemangioma: comparison of ultrasound, CT and RBC scintigraphy. Clin Radiol. Jul. 1991;44(1):34-7. X-1. [pmid: 1873950].
646 Brauner G, Schliftman A, Cosman B. Evaluation of argon laser surgery in children under 13 years of age. Plast Reconstr Surg. Jan. 1991;87(1):37-43. X-1. [pmid: 1984281].
647 Brauner GJ. The pulsed-dye laser for port-wine stains. Plast Reconstr Surg. Sep. 1991;88(3):549-50. X-3, X-4. [pmid: 1871247].
648 Byard RW, Burrows PE, Izakawa T, et al. Diffuse infantile haemangiomatosis: clinicopathological features and management problems in five fatal cases. Eur J Pediatr. Feb. 1991;150(4):224-7. X-1. [pmid: 1843615].
649 Caroli A, Zanasi S, Marcuzzi M, et al. Hemangioma of the hand. Chir Organi Mov. Oct–Dec. 1991;76(4):317-25. X-1. [pmid: 1800043].
650 Chen FS, Wong TK, Shyr MH, et al. Comparison of inguinal nerve block and intravenous fentanyl in relieving postinguinal herniorrhaphy pain for pediatric outpatients. Ma Zui Xue Za Zhi. Jun. 1991;29(2):580-5. X-1. [pmid: 1758250].
651 Copley IB, Derwael EF. Investigation and treatment of a multiple limb birth. Br J Neurosurg. 1991;5(3):281-7. X-1, X-2. [pmid: 1892571].
652 Currie BG, Schell D, Bowring AC. Giant hemangioma of the arm associated with cardiac failure and the Kasabach-Merritt syndrome in a neonate. J Pediatr Surg. Jun. 1991;26(6):734-7. X-2. [pmid: 1941468].
653 de Prost Y, Teillac D, Bodemer C, et al. Successful treatment of Kasabach-Merritt syndrome with pentoxifylline. J Am Acad Dermatol. Nov. 1991;25(5 Pt 1):854-5. X-1, X-2. [pmid: 1802912].
654 Demick DA. Cerebrovascular malformation causing sudden death. Analysis of three cases and review of the literature. Am J Forensic Med Pathol. Mar. 1991;12(1):45-9. X-1. [pmid: 2063819].
655 Destro M, D’Amico DJ, Gragoudas ES, et al. Retinal manifestations of neurofibromatosis. Diagnosis and management. Arch Ophthalmol. May. 1991;109(5):662-6. X-1. [pmid: 1902661].
656 Dresse MF, David M, Hume H, et al. Successful treatment of Kasabach-Merritt syndrome with prednisone and epsilon-aminocaproic acid. Pediatr Hematol Oncol. Oct–Dec. 1991;8(4):329-34. X-1. [pmid: 1669958].
657 Dutton SC, Plowman PN. Paediatric haemangiomas: the role of radiotherapy. Br J Radiol. Mar. 1991;64(759):261-9. X-2. [pmid: 2021799].
658 Ezekowitz A, Mulliken J, Folkman J. Interferon alpha therapy of haemangiomas in newborns and infants. Br J Haematol. Oct. 1991;79(Suppl 1):67-8. X-4. [pmid: 1931713].
659 Fellows KE, Hoffer FA, Markowitz RI, et al. Multiple collaterals to hepatic infantile hemangioendotheliomas and arteriovenous malformations: effect on embolization. Radiology. Dec. 1991;181(3):813-8. X-1. [pmid: 1947103].
660 Fernell E, Gillberg C, von Wendt L. Autistic symptoms in children with infantile hydrocephalus. Acta Paediatr Scand. Apr. 1991;80(4):451-7. X-1. [pmid: 2058395].
661 Fletcher CD, Beham A, Schmid C. Spindle cell haemangioendothelioma: a clinicopathological and immunohistochemical study indicative of a non-neoplastic lesion. Histopathology. Apr. 1991;18(4):291-301. X-1. [pmid: 2071088].
662 Fragu P, Lemarchand-Venencie F, Benhamou S, et al. Long-term effects in skin and thyroid after radiotherapy for skin angiomas: a French retrospective cohort study. Eur J Cancer. 1991;27(10):1215-22. X-1. [pmid: 1835589].
663 Garner TB, Del Curling O Jr, Kelly DL Jr, et al. The natural history of intracranial venous angiomas. J Neurosurg. Nov. 1991;75(5):715-22. X-1. [pmid: 1919693].
664 Glatt HJ, Putterman AM, Van Aalst JJ, et al. Adrenal suppression and growth retardation after injection of periocular capillary hemangioma with corticosteroids. Ophthalmic Surg. Feb. 1991;22(2):95-7. X-2. [pmid: 2038483].
665 Gloviczki P, Stanson AW, Stickler GB, et al. Klippel-Trenaunay syndrome: the risks and benefits of vascular interventions. Surgery. Sep. 1991;110(3):469-79. X-1. [pmid: 1653464].
666 Goerg C, Schwerk WB, Goerg K. Splenic lesions: sonographic patterns, follow-up, differential diagnosis. Eur J Radiol. Jul–Aug. 1991;13(1):59-66. X-3, X-4. [pmid: 1889432].
667 Goldberg DJ, Sciales CW. Pyogenic granuloma in children. Treatment with the flashlamp-pumped pulsed dye laser. J Dermatol Surg Oncol. Dec. 1991;17(12):960-2. X-1, X-2. [pmid: 1960269].
668 Hurvitz C, Alkalay A. Managing hemangiomas. Pediatrics. Apr. 1991;87(4):582-3. X-3, X-4. [pmid: 2011442].
669 Imai T, Matsuo N, Yamashita T, et al. Two cases of hemangioma of the upper lip in infants--treatment using the Nd: YAG laser. Aichi Gakuin Dent Sci. 1991;4:35-44. X-2. [pmid: 1819335].
670 Kerr R, Frey C. MR imaging in tarsal tunnel syndrome. J Comput Assist Tomogr. Mar–Apr. 1991;15(2):280-6. X-1. [pmid: 1672132].
671 Kondziolka D, Dempsey PK, Lunsford LD. The case for conservative management of venous angiomas. Can J Neurol Sci. Aug. 1991;18(3):295-9. X-1. [pmid: 1913363].
672 Kristidis P, de Silva M, Howman-Giles R, et al. Infantile hepatic haemangioma: investigation and treatment. J Paediatr Child Health. Feb. 1991;27(1):57-61. X-2. [pmid: 2043394].
673 Lai FM, Allen PW, Yuen PM, et al. Locally metastasizing vascular tumor. Spindle cell, epithelioid, or unclassified hemangioendothelioma? Am J Clin Pathol. Nov. 1991;96(5):660-3. X-1. [pmid: 1951188].
674 Ledley RS, Lusted LB. Reasoning foundations of medical diagnosis. MD Comput. Sep–Oct. 1991;8(5):300-15. X-1. [pmid: 1749340].
675 Luks FI, Yazbeck S, Brandt ML, et al. Benign liver tumors in children: a 25-year experience. J Pediatr Surg. Nov. 1991;26(11):1326-30. X-3, X-4. [pmid: 1812268].
676 Madrid M. Management of facial arteriovenous malformations. J Vasc Nurs. Jun. 1991;9(2):16-20. X-1. [pmid: 1859797].
677 Maillard GF, Clavel PR. Aesthetic units in skin grafting of the face. Ann Plast Surg. Apr. 1991;26(4):347-52. X-1. [pmid: 1872540].
678 Masih AS, Woods GL, Thiele GM, et al. Detection of cytomegalovirus in bronchoalveolar lavage: a comparison of techniques. Mod Pathol. Jan. 1991;4(1):108-12. X-1. [pmid: 1850516].
679 Masterson J, Woods D, Lau G, et al. Isolated colonic hemangioma in a child. Can Assoc Radiol J. Dec. 1991;42(6):431-4. X-1. [pmid: 1751906].
680 Melchior B, Bensahel H, Desgrippes Y. Lower limb bone hemangiomas in children: report of two cases. J Pediatr Orthop. Jul–Aug. 1991;11(4):482-4. X-1. [pmid: 1860947].
681 Morelli JG, Tan OT, Weston WL. Treatment of ulcerated hemangiomas with the pulsed tunable dye laser. Am J Dis Child. Sep. 1991;145(9):1062-4. X-4. [pmid: 1877568].
682 Mulliken JB. A plea for a biologic approach to hemangiomas of infancy. Arch Dermatol. Feb. 1991;127(2):243-4. X-3, X-4. [pmid: 1990991].
683 Nelson JS. Selective photothermolysis and removal of cutaneous vasculopathies and tattoos by pulsed laser. Plast Reconstr Surg. Oct. 1991;88(4):723-31. X-1. [pmid: 1896548].
684 Neumann RA, Knobler RM, Lindmaier AP. Photoelectric quantitative evaluation of argon laser treatment of port wine stains. Br J Dermatol. Feb. 1991;124(2):181-6. X-1. [pmid: 2004003].
685 Ozsoylu S. High doses of methylprednisolone for Kasabach-Merritt syndrome. J Pediatr. Oct. 1991;119(4):676. X-1. [pmid: 1919908].
686 Palmieri J, Garden JM, Seleny FL, et al. Unrecognized cyanosis during laser treatment of cutaneous vascular lesions. Anesthesiology. Jun. 1991;74(6):1164. X-3, X-4. [pmid: 2042778].
687 Patrice SJ, Wiss K, Mulliken JB. Pyogenic granuloma (lobular capillary hemangioma): a clinicopathologic study of 178 cases. Pediatr Dermatol. Dec. 1991;8(4):267-76. X-1. [pmid: 1792196].
688 Paul KP, Borner C, Muller KM, et al. Capillary hemangioma of the right main bronchus treated by sleeve resection in infancy. Am Rev Respir Dis. Apr. 1991;143(4 Pt 1):876-9. X-2. [pmid: 2008998].
689 Perrone HC, Ajzen H, Toporovski J, et al. Metabolic disturbance as a cause of recurrent hematuria in children. Kidney Int. Apr. 1991;39(4):707-10. X-1. [pmid: 2051727].
690 Pfeiffer N. Infants with port wine stains respond to pulsed dye laser. J Clin Laser Med Surg. Oct. 1991;9(5):335-6. X-1. [pmid: 10149474].
691 Pontisso P, Basso G, Perilongo G, et al. Does hepatitis B virus play a role in primary liver cancer in children of Western countries?. Cancer Detect Prev. 1991;15(5):363-8. X-1. [pmid: 1661202].
692 Premachandra DJ, Milton CM. Childhood haemangiomas of the head and neck. Clin Otolaryngol Allied Sci. Apr. 1991;16(2):117-23. X-2. [pmid: 2070524].
693 Rebeiz E, April MM, Bohigian RK, et al. Nd-YAG laser treatment of venous malformations of the head and neck: an update. Otolaryngol Head Neck Surg. Nov. 1991;105(5):655-61. X-1. [pmid: 1754247].
694 Robertson JS, Wiegand DA, Schaitkin BM. Life-threatening hemangioma arising from the parotid gland. Otolaryngol Head Neck Surg. Jun. 1991;104(6):858-62. X-2. [pmid: 1908981].
695 Robinson JR, Awad IA, Little JR. Natural history of the cavernous angioma. J Neurosurg. Nov. 1991;75(5):709-14. X-1. [pmid: 1919692].
696 Scheibner A, Wheeland RG. Use of the argon-pumped tunable dye laser for port-wine stains in children. J Dermatol Surg Oncol. Sep. 1991;17(9):735-9. X-1. [pmid: 1890246].
697 Schild SE, Buskirk SJ, Frick LM, et al. Radiotherapy for large symptomatic hemangiomas. Int J Radiat Oncol Biol Phys. Aug. 1991;21(3):729-35. X-1, X-2. [pmid: 1869466].
698 Scott TA, Augsburger JJ, Brady LW, et al. Low dose ocular irradiation for diffuse choroidal hemangiomas associated with bullous nonrhegmatogenous retinal detachment. Retina. 1991;11(4):389-93. X-1. [pmid: 1813954].
699 Seccia A, Salgarello M. Treatment of angiomas with sclerosing injection of hydroxypolyethoxydodecan. Angiology. Jan. 1991;42(1):23-9. X-1. [pmid: 1992855].
700 Seid AB, Pransky SM, Kearns DB. The open surgical approach to subglottic hemangioma. Int J Pediatr Otorhinolaryngol. Jul. 1991;22(1):85-90. X-2. [pmid: 1917342].
701 Seo JK, Lee BK, Kim KH, et al. Surgical treatment of giant cavernous hemangiomas of the liver--analysis of 7 patients. J Korean Med Sci. Jun. 1991;6(2):127-33. X-1. [pmid: 1751017].
702 Shieh CC, Wang PJ. Giant nevocellular nevi with rickets and brainstem tumor. Pediatr Neurol. Nov–Dec. 1991;7(6):452-4. X-1. [pmid: 1665693].
703 Sihota R, Kumar H, Sood NN. The additive influence of nevus flammeus and the nevus of Ota on congenital glaucoma. Indian J Ophthalmol. Jul–Sep. 1991;39(3):122-4. X-1. [pmid: 1841885].
704 Steiman HR, Cullen CL, Geist JR. Bilateral mandibular regional odontodysplasia with vascular nevus. Pediatr Dent. Sep–Oct. 1991;13(5):303-6. X-1. [pmid: 1667684].
705 Toye R, Armstrong P, Dacie JE. Lymphangiohaemangioma of the mediastinum. Br J Radiol. Jan. 1991;64(757):62-4. X-1. [pmid: 1998842].
706 Weatherford DA, Abrams RS, Wallace JG. Vascular malformation: case report and literature review. J S C Med Assoc. Nov. 1991;87(11):539-42. X-1. [pmid: 1766244].
707 White CW, Wolf SJ, Korones DN, et al. Treatment of childhood angiomatous diseases with recombinant interferon alfa-2a. J Pediatr. Jan. 1991;118(1):59-66. X-2. [pmid: 1986099].
708 Wowra B, Layer G, Schad LR, et al. Three-dimensional time-of-flight MR-angiography and the surgical indication of brainstem cavernomas. Acta Neurochir (Wien). 1991;112(3–4):77-82. X-1. [pmid: 1776522].
709 Abernethy LJ, Phelan E, Rosenfeld JV. Choroid plexus angioma: a rare cause of cerebral hemorrhage in childhood. Pediatr Radiol. 1992;22(2):138-9. X-1. [pmid: 1501945].
710 Alani HM, Warren RM. Percutaneous photocoagulation of deep vascular lesions using a fiberoptic laser wand. Ann Plast Surg. Aug. 1992;29(2):143-8. X-2. [pmid: 1530264].
711 Alexander E 3rd, Loeffler JS. Radiosurgery for intracranial vascular malformations: techniques, results, and complications. Clin Neurosurg. 1992;39:273-91. X-1. [pmid: 1458744].
712 Assaf A, Nasr A, Johnson T. Corticosteroids in the management of adnexal hemangiomas in infancy and childhood. Ann Ophthalmol. Jan. 1992;24(1):12-8. X-4. [pmid: 1543320].
713 Barton DJ, Miller JH, Allwright SJ, et al. Distinguishing soft-tissue hemangiomas from vascular malformations using technetium-labeled red blood cell scintigraphy. Plast Reconstr Surg. Jan. 1992;89(1):46-52. discussion 3–5. X-3, X-4. [pmid: 1727262].
714 Beals RK, Lovrien EW. Diffuse capillary hemangiomas associated with skeletal hypotrophy. J Pediatr Orthop. May–Jun. 1992;12(3):401-2. X-1, X-2. [pmid: 1573010].
715 Bergeson PS, Rekate HL, Tack ED. Cerebral cavernous angiomas in the newborn. Clin Pediatr (Phila). Jul. 1992;31(7):435-7. X-1. [pmid: 1617869].
716 Bertalanffy H, Kuhn G, Scheremet R, et al. Indications for surgery and prognosis in patients with cerebral cavernous angiomas. Neurol Med Chir (Tokyo). Aug. 1992;32(9):659-66. X-1. [pmid: 1383853].
717 Bilyk JR, Adamis AP, Mulliken JB. Treatment options for periorbital hemangioma of infancy. Int Ophthalmol Clin. Summer. 1992;32(3):95-109. X-1, X-2. [pmid: 1639604].
718 Brahams D. Cosmetic surgery for portwine stain. Lancet. Apr. 25. 1992;339(8800):1045-6. X-1, X-2. [pmid: 1349063].
719 Buchanan DS, Fagan PA, Turner J. Cavernous haemangioma of the temporal bone. J Laryngol Otol. Dec. 1992;106(12):1086-8. X-1. [pmid: 1487668].
720 Castro R, Meek R, Bean C, et al. Successful treatment of a giant cavernous hemangioma with oral cyclophosphamide (cytoxan) in an infant. Del Med J. Dec. 1992;64(12):745-9. X-1. [pmid: 1478327].
721 Chow LT, Chow WH, Fong DT. Epithelioid hemangioendothelioma of the brain. Am J Surg Pathol. Jun. 1992;16(6):619-25. X-1. [pmid: 1376023].
722 Churchyard A, Khangure M, Grainger K. Cerebral cavernous angioma: a potentially benign condition? Successful treatment in 16 cases. J Neurol Neurosurg Psychiatry. Nov. 1992;55(11):1040-5. X-1. [pmid: 1469400].
723 Cooper M, Slovis TL, Madgy DN, et al. Congenital subglottic hemangioma: frequency of symmetric subglottic narrowing on frontal radiographs of the neck. AJR Am J Roentgenol. Dec. 1992;159(6):1269-71. X-3, X-4. [pmid: 1442399].
724 Davidoff AM, Filston HC. Treatment of infantile subglottic hemangioma with electrocautery. J Pediatr Surg. Apr. 1992;27(4):436-9. X-2. [pmid: 1522452].
725 De Laey JJ, Heintz B, Pollet L. Retinal angioma and juvenile sex-linked retinoschisis. Ophthalmic Paediatr Genet. Jun. 1992;13(2):73-6. X-1. [pmid: 1495769].
726 Deans RM, Harris GJ, Kivlin JD. Surgical dissection of capillary hemangiomas. An alternative to intralesional corticosteroids. Arch Ophthalmol. Dec. 1992;110(12):1743-7. X-3, X-4. [pmid: 1463416].
727 Dieterich-Miller CA, Safford PL. Psychosocial development of children with hemangiomas: home, school, health care collaboration. Children’s health care : journal of the Association for the Care of Children’s Health. 1992. 1992;21(2):84-9. PMID: X-1.
728 Doi O, Takada Y. Kasabach-Merritt syndrome in two neonates. J Pediatr Surg. Dec. 1992;27(12):1507-8. X-1. [pmid: 1469553].
729 Donati P, Maiuri F, Gangemi M, et al. Cavernous angioma of the pineal region. J Neurosurg Sci. Jul–Sep. 1992;36(3):155-60. X-1. [pmid: 1484302].
730 Drut R, Drut RM, Toulouse JC. Hepatic hemangioendotheliomas, placental chorioangiomas, and dysmorphic kidneys in Beckwith-Wiedemann syndrome. Pediatr Pathol. Mar–Apr. 1992;12(2):197-203. X-1. [pmid: 1570237].
731 Ebeling U, Huber P. Localization of central lesions by correlation of CT findings and neurological deficits. Acta Neurochir (Wien). 1992;119(1–4):17-22. X-1. [pmid: 1481744].
732 Eto H, Toriyama K, Tsuda N, et al. Flow cytometric DNA analysis of vascular soft tissue tumors, including African endemic-type Kaposi’s sarcoma. Hum Pathol. Sep. 1992;23(9):1055-60. X-1. [pmid: 1516928].
733 Ezekowitz RA, Mulliken JB, Folkman J. Interferon alfa-2a therapy for life-threatening hemangiomas of infancy. N Engl J Med. May. 28. 1992;326(22):1456-63. X-4. [pmid: 1489383].
734 Farley TJ, Klionsky N. Mixed hemangioma and cystic lymphangioma of the esophagus in a child. J Pediatr Gastroenterol Nutr. Aug. 1992;15(2):178-80. X-1. [pmid: 1403466].
735 Farrell MA, DeRosa MJ, Curran JG, et al. Neuropathologic findings in cortical resections (including hemispherectomies) performed for the treatment of intractable childhood epilepsy. Acta Neuropathol. 1992;83(3):246-59. X-1. [pmid: 1557956].
736 Ferrante L, Palma L, d’Addetta R, et al. Intracranial cavernous angioma. Neurosurg Rev. 1992;15(2):125-33. X-1. [pmid: 1635626].
737 Filling-Katz MR, Levin SW, Patronas NJ, et al. Terminal transverse limb defects associated with familial cavernous angiomatosis. Am J Med Genet. Feb. 1. 1992;42(3):346-51. X-1. [pmid: 1536177].
738 Frieden IJ, Esterly NB. Pyogenic granulomas of infancy masquerading as strawberry hemangiomas. Pediatrics. Dec. 1992;90(6):989-91. X-1. [pmid: 1437442].
739 Fujii K, Matsushima T, Inamura T, et al. Natural history and choice of treatment in forty patients with medullary venous malformation (MVM). Neurosurg Rev. 1992;15(1):13-20. X-1. [pmid: 1584432].
740 Garden JM, Bakus AD, Paller AS. Treatment of cutaneous hemangiomas by the flashlamp-pumped pulsed dye laser: prospective analysis. J Pediatr. Apr. 1992;120(4 Pt 1):555-60. X-4. [pmid: 1552392].
741 Goodman P, Dominguez R, Castillo M. Diffuse neonatal hemangiomatosis: imaging findings in two patients. Comput Med Imaging Graph. Mar–Apr. 1992;16(2):117-20. X-1. [pmid: 1568198].
742 Greenspan A, McGahan JP, Vogelsang P, et al. Imaging strategies in the evaluation of soft-tissue hemangiomas of the extremities: correlation of the findings of plain radiography, angiography, CT, MRI, and ultrasonography in 12 histologically proven cases. Skeletal Radiol. 1992;21(1):11-8. X-1. [pmid: 1546331].
743 Hellmann JR, Myer CM 3rd, Prenger EC. Therapeutic alternatives in the treatment of life-threatening vasoformative tumors. Am J Otolaryngol. Jan–Feb. 1992;13(1):48-53. X-1. [pmid: 1585985].
744 Holy A, Geronemus RG. Treatment of periorbital port-wine stains with the flashlamp-pumped pulsed dye laser. Arch Ophthalmol. Jun. 1992;110(6):793-7. X-1. [pmid: 1596226].
745 Horak D, Svec F, Isakov Y, et al. Use of poly(2-hydroxyethyl methacrylate) for endovascular occlusion in pediatric surgery. Clin Mater. 1992;9(1):43-8. X-1. [pmid: 10149958].
746 Huston J 3rd, Forbes GS, Ruefenacht DA, et al. Magnetic resonance imaging of facial vascular anomalies. Mayo Clin Proc. Aug. 1992;67(8):739-47. X-3, X-4. [pmid: 1434912].
747 Illum N, Winther Nielsen H, Guldhammer Skov B. Recurrent nodular haemangiomas in Klippel-Trenaunay syndrome. Acta Paediatr. May. 1992;81(5):456-8. X-1, X-2. [pmid: 1323362].
748 Karabocuoglu M, Basarer N, Aydogan U, et al. Development of Kasabach-Merritt syndrome following needle aspiration of a hemangioma. Pediatr Emerg Care. Aug. 1992;8(4):218-20. X-1. [pmid: 1513734].
749 Keleti D, Flickinger JC, Hobson SR, et al. Radiotherapy of lymphoproliferative diseases of the orbit. Surveillance of 65 cases. Am J Clin Oncol. Oct. 1992;15(5):422-7. X-1. [pmid: 1524043].
750 Kennard CD, Whitaker DC. Iontophoresis of lidocaine for anesthesia during pulsed dye laser treatment of port-wine stains. J Dermatol Surg Oncol. Apr. 1992;18(4):287-94. X-1. [pmid: 1560152].
751 Khandelwal N, Malik N, Rao DS, et al. Vertebral hemangioma with spinal cord compression: the role of pre-operative embolisation. Indian Pediatr. Jun. 1992;29(6):771-3. X-1, X-2. [pmid: 1500142].
752 Knych SA, Goldberg MJ, Wolfe HJ. Intraosseous arteriovenous malformation in a pediatric patient. Clin Orthop Relat Res. Mar. 1992;(276):307-12. X-1. [pmid: 1537171].
753 Komiyama M, Khosla VK, Yamamoto Y, et al. Embolization in high-flow arteriovenous malformations of the face. Ann Plast Surg. Jun. 1992;28(6):575-83. X-1. [pmid: 1622040].
754 Korolev BA, Pavlunin AV, Karpova NA. Congenital pulmonary arteriovenous aneurysms. Cor et Vasa. 1992;34(2):149-57. X-1. [pmid: 1304455].
755 Kroh H, Taraszewska A, Ruzikowski E, et al. Neuropathological changes in resected temporal lobe of patients with cryptogenic epilepsy. Neuropatol Pol. 1992;30(2):133-45. X-1. [pmid: 1297928].
756 Louis DS, Fortin PT. Perineural hemangiomas of the upper extremity: report of four cases. J Hand Surg Am. Mar. 1992;17(2):308-11. X-1. [pmid: 1564281].
757 Luomanen M. Experience with a carbon dioxide laser for removal of benign oral soft-tissue lesions. Proc Finn Dent Soc. 1992;88(1–2):49-55. X-1. [pmid: 1470632].
758 Lyon DB, Tang TT, Kidder TM. Epithelioid hemangioendothelioma of the orbital bones. Ophthalmology. Dec. 1992;99(12):1773-8. X-1. [pmid: 1480392].
759 Malik S, Cohen BH, Robinson J, et al. Progressive vision loss. A rare manifestation of familial cavernous angiomas. Arch Neurol. Feb. 1992;49(2):170-3. X-1. [pmid: 1736851].
760 Mast HL, Haller JO, Solomon M. Benign lesions of the mandibular and maxillary region in children: characterization by CT and MRI. Comput Med Imaging Graph. Jan–Feb. 1992;16(1):1-9. X-1. [pmid: 1313327].
761 Matsushima T, Fukui M, Inoue T, et al. Microsurgical and magnetic resonance imaging anatomy of the cerebello-medullary fissure and its application during fourth ventricle surgery. Neurosurgery. Mar. 1992;30(3):325-30. X-1. [pmid: 1620293].
762 McHugh K, Burrows PE. Infantile hepatic hemangioendotheliomas: significance of portal venous and systemic collateral arterial supply. J Vasc Interv Radiol. May. 1992;3(2):337-44. X-1. [pmid: 1627883].
763 Messineo A, Wesson DE, Filler RM, et al. Juvenile hemangiomas involving the thoracic trachea in children: report of two cases. J Pediatr Surg. Oct. 1992;27(10):1291-3. X-1, X-2. [pmid: 1403505].
764 Miaux Y, Lemarchand-Venencie F, Cyna-Gorse F, et al. MR imaging of breast hemangioma in female infants. Pediatr Radiol. 1992;22(6):463-4. X-3, X-4. [pmid: 1437377].
765 Miller JG, Orton CI. Long term follow-up of a case of Kasabach-Merritt syndrome successfully treated with radiotherapy and corticosteroids. Br J Plast Surg. Oct. 1992;45(7):559-61. X-1. [pmid: 1446205].
766 Mizoi K, Yoshimoto T, Suzuki J. Clinical analysis of ten cases with surgically treated brain stem cavernous angiomas. Tohoku J Exp Med. Feb. 1992;166(2):259-67. X-1. [pmid: 1566274].
767 Mizutani T, Tanaka H, Aruga T. Multiple arteriovenous malformations located in the cerebellum, posterior fossa, spinal cord, dura, and scalp with associated port-wine stain and supratentorial venous anomaly. Neurosurgery. Jul. 1992;31(1):137-40. discussion 40–1. X-1. [pmid: 1641094].
768 Mordick TG 3rd, Larossa D, Whitaker L. Soft-tissue reconstruction of the face: a comparison of dermal-fat grafting and vascularized tissue transfer. Ann Plast Surg. Nov. 1992;29(5):390-6. X-1. [pmid: 1444125].
769 Oakes WJ. The natural history of patients with the Sturge-Weber syndrome. Pediatr Neurosurg. 1992;18(5–6):287-90. X-1. [pmid: 1476938].
770 Ohshiro T, Chen I. Low reactive-level 830 nm diode laser therapy (LLLT) successfully accelerates regression of strawberry haemangioma in the infant: Case reports. Laser Therapy. 1992;4(3):127-32. X-2.
771 Ozsoylu S. Megadose methylprednisolone for diffuse infantile haemangiomatosis. Eur J Pediatr. May. 1992;151(5):389. X-1. [pmid: 1396900].
772 Padalkar JA, Bapat VS, Phadke MA, et al. Successful treatment of hepatic hemangiomas with corticosteroids. Indian Pediatr. Jun. 1992;29(6):769-70. X-2. [pmid: 1500141].
773 Paltiel HJ, Patriquin HB, Keller MS, et al. Infantile hepatic hemangioma: Doppler US. Radiology. Mar. 1992;182(3):735-42. X-4. [pmid: 1535887].
774 Park DD, Ricketts RR. Infantile gastrointestinal hemangioma as a cause of chronic anemia. South Med J. Feb. 1992;85(2):201-3. X-2. [pmid: 1738891].
775 Perez-Guillermo M, Sola Perez J, Garcia Rojo B, et al. Fine needle aspiration cytology of cutaneous vascular tumours. Cytopathology. 1992;3(4):231-44. X-1, X-2. [pmid: 1330048].
776 Pierce RN, Dunn L, Knisely AS. Consumptive coagulopathy in utero associated with multiple vascular malformations. Pediatr Pathol. Jan–Feb. 1992;12(1):67-71. X-1. [pmid: 1561152].
777 Pongprasit P. Corticosteroid treatment of extensive hemangiomas: analysis of 22 cases in children. J Med Assoc Thai. Dec. 1992;75(12):671-9. X-4. [pmid: 1308535].
778 Rajput A, Gauderer MW, Hack M. Inguinal hernias in very low birth weight infants: incidence and timing of repair. J Pediatr Surg. Oct. 1992;27(10):1322-4. X-1. [pmid: 1403513].
779 Reid WH, Miller ID, Murphy MJ, et al. Treatment of portwine stains using the pulsed dye laser. Br J Plast Surg. Nov–Dec. 1992;45(8):565-70. X-1. [pmid: 1493527].
780 Robinson D, Segal M, Halperin N, et al. Neuropeptidergic innervation of intramuscular hemangiomas. Exp Mol Pathol. Jun. 1992;56(3):186-96. X-1. [pmid: 1379196].
781 Rootman J, Kao SC, Graeb DA. Multidisciplinary approaches to complicated vascular lesions of the orbit. Ophthalmology. Sep. 1992;99(9):1440-6. X-1. [pmid: 1407977].
782 Santos-Dias A. CO 2 laser surgery in hemophilia treatment. J Clin Laser Med Surg. Aug. 1992;10(4):297-301. X-1. [pmid: 10183941].
783 Scott RM, Barnes P, Kupsky W, et al. Cavernous angiomas of the central nervous system in children. J Neurosurg. Jan. 1992;76(1):38-46. X-1. [pmid: 1727167].
784 Shriner DL, Wagner RF Jr, Weedn VW, et al. Informed consent and risk management in dermatology: to what extent do dermatologists disclose alternate diagnostic and treatment options to their patients?. J Contemp Health Law Policy. Spring. 1992;8:137-62. X-1. [pmid: 10118984].
785 Spiller JC, Sharma V, Woods GM, et al. Diffuse neonatal hemangiomatosis treated successfully with interferon alfa-2a. J Am Acad Dermatol. Jul. 1992;27(1):102-4. X-1. [pmid: 1619055].
786 Steichen-Gersdorf E, Felber S, Fuchs W, et al. Familial cavernous angiomas of the brain: observations in a four generation family. Eur J Pediatr. Nov. 1992;151(11):861-3. X-1. [pmid: 1468464].
787 Sullivan TJ, Clarke MP, Morin JD. The ocular manifestations of the Sturge-Weber syndrome. J Pediatr Ophthalmol Strabismus. Nov–Dec. 1992;29(6):349-56. X-1. [pmid: 1287171].
788 Takamatsu H, Akiyama H, Noguchi H, et al. Endorectal pull-through operation for diffuse cavernous hemangiomatosis of the sigmoid colon, rectum and anus. Eur J Pediatr Surg. Aug. 1992;2(4):245-7. X-1. [pmid: 1390557].
789 Tan OT, Stafford TJ. EMLA for laser treatment of portwine stains in children. Lasers Surg Med. 1992;12(5):543-8. X-1. [pmid: 1406008].
790 Tan SA, Yeo SH. Placental chorioangioma: a case report and review. Singapore Med J. Feb. 1992;33(1):83-5. X-1. [pmid: 1598615].
791 Troughton AH, Paxton RM. Direct puncture venography in subcutaneous cavernous haemangiomas. Clin Radiol. Apr. 1992;45(4):250-3. X-1. [pmid: 1395381].
792 Turjman F, Arteaga C, Tavernier T, et al. Haemorrhagic complications of intracerebral cavernomas: value of MRI. J Neuroradiol. 1992;19(2):107-17. X-1. [pmid: 1629774].
793 Van Campenhout I, Patriquin H. Malignant microvasculature in abdominal tumors in children: detection with Doppler US. Radiology. May. 1992;183(2):445-8. X-1. [pmid: 1373242].
794 Vedung S, Atterhem H. Argon laser treatment of port-wine stains: the patients’ evaluations of the result. Plast Reconstr Surg. Sep. 1992;90(3):430-5. X-1. [pmid: 1513888].
795 Waner M, Suen JY, Dinehart S. Treatment of hemangiomas of the head and neck. Laryngoscope. Oct. 1992;102(10):1123-32. X-1, X-2. [pmid: 1405964].
796 White WL, Mumma JV, Tomasovic JJ. Congenital oculomotor nerve palsy, cerebellar hypoplasia, and facial capillary hemangioma. Am J Ophthalmol. May. 15. 1992;113(5):497-500. X-2. [pmid: 1575222].
797 Wirth T, Rauch G, Ruschoff J, et al. Synovial haemangioma of the knee joint. Int Orthop. 1992;16(2):130-2. X-2. [pmid: 1428309].
798 Zide BM, Karp NS. Maximizing gain from rectangular tissue expanders. Plast Reconstr Surg. Sep. 1992;90(3):500-4. discussion 5–6. X-1. [pmid: 1513899].
799 Abdul-Wahab BR, Olusegun OA. Haemangioma of the vallecula causing acute upper airway obstruction in a 6 1/2 week old Nigerian infant with strawberry naevus. Trop Geogr Med. Mar. 1993;45(1):33-5. X-1. [pmid: 8470305].
800 Acciarri N, Padovani R, Giulioni M, et al. Intracranial and orbital cavernous angiomas: a review of 74 surgical cases. Br J Neurosurg. 1993;7(5):529-39. X-1. [pmid: 8267890].
801 Agarwal HC, Sandramouli S, Sihota R, et al. Sturge-Weber syndrome: management of glaucoma with combined trabeculotomy-trabeculectomy. Ophthalmic Surg. Jun. 1993;24(6):399-402. X-1. [pmid: 8336891].
802 Alter GJ, Trengove-Jones G, Horton CE Jr, et al. Hemangioma of penis and scrotum. Urology. Aug. 1993;42(2):205-8. X-2. [pmid: 8367930].
803 Apfelberg DB, Smoller B. Preliminary analysis of histological results of Hexascan device with continuous tunable dye laser at 514 (argon) and 577 NM (yellow). Lasers Surg Med. 1993;13(1):106-12. X-1. [pmid: 8426517].
804 Armstrong AL, Finch RG, Bailie FB. Serious group A streptococcal infections complicating cryotherapy to lip haemangiomas. Clin Exp Dermatol. Nov. 1993;18(6):537-9. X-2. [pmid: 8252791].
805 Ashinoff R, Geronemus RG. Failure of the flashlamp-pumped pulsed dye laser to prevent progression to deep hemangioma. Pediatr Dermatol. Mar. 1993;10(1):77-80. X-2. [pmid: 8493176].
806 Atebara NH, Shields JA. Capillary hemangioma of the optic disc associated with a total retinal detachment. Ophthalmic Surg. Oct. 1993;24(10):686-8. X-2. [pmid: 8259247].
807 Awad IA, Robinson JR Jr, Mohanty S, et al. Mixed vascular malformations of the brain: clinical and pathogenetic considerations. Neurosurgery. Aug. 1993;33(2):179-88. discussion 88. X-1. [pmid: 8367039].
808 Baker LL, Dillon WP, Hieshima GB, et al. Hemangiomas and vascular malformations of the head and neck: MR characterization. AJNR Am J Neuroradiol. Mar–Apr. 1993;14(2):307-14. X-4. [pmid: 8456703].
809 Baronia AK, Pandey CK, Kaushik S. Diffuse oral facial cavernous hemangioma causing severe airway obstruction after intramuscular ketamine. Anesthesiology. Dec. 1993;79(6):1421-4. X-1. [pmid: 8267215].
810 Benedikt RA, Brown DC, Walker R, et al. Sturge-Weber syndrome: cranial MR imaging with Gd-DTPA. AJNR Am J Neuroradiol. Mar–Apr. 1993;14(2):409-15. X-1. [pmid: 8456721].
811 Blei F, Orlow SJ, Geronemus RG. Interferon alfa-2a therapy for extensive perianal and lower extremity hemangioma. J Am Acad Dermatol. Jul. 1993;29(1):98-9. X-2. [pmid: 8315084].
812 Blei F, Orlow SJ, Geronemus RG. Supraumbilical midabdominal raphe, sternal atresia, and hemangioma in an infant: response of hemangioma to laser and interferon alfa-2a. Pediatr Dermatol. Mar. 1993;10(1):71-6. X-2. [pmid: 8493175].
813 Bloom PA, Laidlaw A, Easty DL. Spontaneous development of retinal ischaemia and rubeosis in eyes with retinal racemose angioma. Br J Ophthalmol. Feb. 1993;77(2):124-5. X-1. [pmid: 8435415].
814 Boehm DK, Kobrinsky NL. Treatment of cavernous hemangioma with vincristine. Ann Pharmacother. Jul–Aug. 1993;27(7–8):981. X-1. [pmid: 8364292].
815 Breviere GM, Bonnevalle M, Pruvo JP, et al. Use of Ethibloc in the treatment of cystic and venous angiomas in children. 19 cases. Eur J Pediatr Surg. Jun. 1993;3(3):166-70. X-1. [pmid: 8353118].
816 Burton BK, Schulz CJ, Burd LI. Spectrum of limb disruption defects associated with chorionic villus sampling. Pediatrics. May. 1993;91(5):989-93. X-1. [pmid: 8474823].
817 Carrington PR, Rowley MJ, Fowler M, et al. Kasabach-Merritt syndrome with bone involvement: the pseudomalignant sign of Gorham. J Am Acad Dermatol. Jul. 1993;29(1):117-9. X-1. [pmid: 8315070].
818 de Vathaire F, Fragu P, Francois P, et al. Long-term effects on the thyroid of irradiation for skin angiomas in childhood. Radiat Res. Mar. 1993;133(3):381-6. X-3. [pmid: 8451391].
819 Devaney K, Vinh TN, Sweet DE. Synovial hemangioma: a report of 20 cases with differential diagnostic considerations. Hum Pathol. Jul. 1993;24(7):737-45. X-1. [pmid: 8319952].
820 Diaz-Landaeta L, Kerdel FA. Hyperhidrotic, painful lesion. Eccrine angiomatous hamartoma. Arch Dermatol. Jan. 1993;129(1):107. 10. X-1. [pmid: 8420481].
821 Donauer E, Reif J, al-Khalaf B, et al. Intraventricular haemorrhage caused by aneurysms and angiomas. Acta Neurochir (Wien). 1993;122(1–2):23-31. X-1. [pmid: 8333305].
822 Ecklund J, Schut L, Rorke L. Associated vascular malformations and neoplasms in children. Pediatr Neurosurg. Jul–Aug. 1993;19(4):196-201. X-1. [pmid: 8329304].
823 Enjolras O, Mulliken JB. The current management of vascular birthmarks. Pediatr Dermatol. Dec. 1993;10(4):311-3. X-1. [pmid: 8302734].
824 Faro SH, Mahboubi S, Ortega W. CT diagnosis of rib anomalies, tumors, and infection in children. Clin Imaging. Jan–Mar. 1993;17(1):1-7. X-1. [pmid: 8439835].
825 Fiore F, Califano L, Cortese A, et al. Hemangiomas of the maxillofacial area. Usefulness of 99Tcm-labelled red cell scintigraphy. Nucl Med Commun. May. 1993;14(5):378-83. X-1. [pmid: 8510878].
826 Fornage BD, McGavran MH, Duvic M, et al. Imaging of the skin with 20-MHz US. Radiology. Oct. 1993;189(1):69-76. X-1. [pmid: 8372222].
827 Fox MW, Onofrio BM. The natural history and management of symptomatic and asymptomatic vertebral hemangiomas. J Neurosurg. Jan. 1993;78(1):36-45. X-1. [pmid: 8416240].
828 Frodel JL Jr, Whitaker DC. Primary reconstruction of congenital facial lesion defects with tissue expansion. J Dermatol Surg Oncol. Dec. 1993;19(12):1110-6. X-1. [pmid: 8282910].
829 Fuchs B, Philipp C, Engel-Murke F, et al. Techniques for endoscopic and non-endoscopic intracorporeal laser applications. Endosc Surg Allied Technol. Aug. 1993;1(4):217-23. X-1, X-2. [pmid: 8050024].
830 Fukunaga M, Shimoda T, Nikaido T, et al. Soft tissue vascular tumors. A flow cytometric DNA analysis. Cancer. Apr. 1. 1993;71(7):2233-41. X-1. [pmid: 8453543].
831 Gangemi M, Maiuri F, Donati PA, et al. Rapid growth of a brain-stem cavernous angioma. Acta Neurol (Napoli). Apr. 1993;15(2):132-7. X-1. [pmid: 8328323].
832 Garden JM, Bakus AD. Clinical efficacy of the pulsed dye laser in the treatment of vascular lesions. J Dermatol Surg Oncol. Apr. 1993;19(4):321-6. X-1. [pmid: 8478471].
833 Gelb AB, Van Meter SH, Billingham ME, et al. Infantile histiocytoid cardiomyopathy--myocardial or conduction system hamartoma: what is the cell type involved?. Hum Pathol. Nov. 1993;24(11):1226-31. X-1. [pmid: 8244322].
834 Geronemus RG. Pulsed dye laser treatment of vascular lesions in children. J Dermatol Surg Oncol. Apr. 1993;19(4):303-10. X-1, X-2. [pmid: 8478469].
835 Goh WH, Lo R. A new 3C syndrome: cerebellar hypoplasia, cavernous haemangioma and coarctation of the aorta. Dev Med Child Neurol. Jul. 1993;35(7):637-41. X-1. [pmid: 9435781].
836 Goldman MP, Fitzpatrick RE, Ruiz-Esparza J. Treatment of port-wine stains (capillary malformation) with the flashlamp-pumped pulsed dye laser. J Pediatr. Jan. 1993;122(1):71-7. X-1. [pmid: 8419617].
837 Hatley RM, Sabio H, Howell CG, et al. Successful management of an infant with a giant hemangioma of the retroperitoneum and Kasabach-Merritt syndrome with alpha-interferon. J Pediatr Surg. Oct. 1993;28(10):1356-7. discussion 8–9. X-1, X-2. [pmid: 8263701].
838 Henley JD, Danielson CF, Rothenberger SS, et al. Kasabach-Merritt syndrome with profound platelet support. Am J Clin Pathol. May. 1993;99(5):628-30. X-1, X-2. [pmid: 8493954].
839 Huang JF, Li GS, Chen BX. An improved technique for bloodless hepatic resection on in situ cold perfused liver. Chin Med J (Engl). May. 1993;106(5):385-9. X-1. [pmid: 8404283].
840 Jabra AA, Taylor GA. MRI evaluation of superficial soft tissue lesions in children. Pediatr Radiol. 1993;23(6):425-8. X-1. [pmid: 8255642].
841 Jackson IT, Carreno R, Potparic Z, et al. Hemangiomas, vascular malformations, and lymphovenous malformations: classification and methods of treatment. Plast Reconstr Surg. Jun. 1993;91(7):1216-30. X-3, X-4. [pmid: 8497521].
842 Jarrett F. Cavernous hemangioma of the cephalic vein. Cardiovasc Surg. Aug. 1993;1(4):386-8. X-1. [pmid: 8076066].
843 Jimenez-Cruz JF, Osca JM. Laser treatment of glans penis hemangioma. Eur Urol. 1993;24(1):81-3. X-1, X-2. [pmid: 8365446].
844 Kawagishi J, Suzuki M, Kayama T, et al. Huge multilobular cavernous angioma in an infant: case report. Neurosurgery. Jun. 1993;32(6):1028-30. discussion 30–1. X-1. [pmid: 8327078].
845 Kennedy WA 3rd, Hensle TW, Giella J, et al. Potassium thiophosphate laser treatment of genitourinary hemangioma in the pediatric population. J Urol. Sep. 1993;150(3):950-2. X-1, X-2. [pmid: 8345617].
846 Kojima Y, Kuwana N. Progressive diffuse arteriovenous malformation--case report. Neurol Med Chir (Tokyo). Apr. 1993;33(4):242-5. X-1. [pmid: 7685857].
847 Kulkarni ML, Kumar CS, George VG, et al. Oral steroids in the treatment of periorbital hemangioma. Indian Pediatr. Mar. 1993;30(3):379-82. X-2. [pmid: 8365795].
848 Kumar A, Aggarwal S, Willinsky R, et al. Posterior fossa surgery: an unusual cause of superficial siderosis. Neurosurgery. Mar. 1993;32(3):455-7. discussion 7. X-1. [pmid: 8455772].
849 Kurtz SN, Melamed S, Blumenthal M. Cataract and intraocular lens implantation after remote trabeculectomy for Sturge-Weber syndrome. J Cataract Refract Surg. Jul. 1993;19(4):539-41. X-1. [pmid: 8355162].
850 Lee C, Dineen TE, Brack M, et al. The mucopolysaccharidoses: characterization by cranial MR imaging. AJNR Am J Neuroradiol. Nov–Dec. 1993;14(6):1285-92. X-1. [pmid: 8279321].
851 Levine MR, Kellis A, Lash R. Nasal glioma masquerading as a capillary hemangioma. Ophthal Plast Reconstr Surg. Jun. 1993;9(2):132-4. X-1. [pmid: 8323905].
852 Lim RY. Nd:YAG laser surgery of venous malformations. W V Med J. Mar. 1993;89(3):109-10. X-1. [pmid: 8475623].
853 Lindquist C, Guo WY, Karlsson B, et al. Radiosurgery for venous angiomas. J Neurosurg. Apr. 1993;78(4):531-6. X-1. [pmid: 8110208].
854 Lupret V, Negovetic L, Smiljanic D, et al. Cerebral venous angiomas: surgery as a mode of treatment for selected cases. Acta Neurochir (Wien). 1993;120(1–2):33-9. X-1. [pmid: 8434514].
855 MacArthur CJ, Gliklich R, McGill TJ, et al. Sinus complications in mucopolysaccharidosis IH/S (Hurler-Scheie syndrome). Int J Pediatr Otorhinolaryngol. Feb. 1993;26(1):79-87. X-1. [pmid: 8444549].
856 Mantravadi J, Roth LM, Kafrawy AH. Vascular neoplasms of the parotid gland. Parotid vascular tumors. Oral Surg Oral Med Oral Pathol. Jan. 1993;75(1):70-5. X-1, X-2. [pmid: 8419878].
857 Matsumoto T, Okano R, Sakura N, et al. Hypergalactosaemia in a patient with portal-hepatic venous and hepatic arterio-venous shunts detected by neonatal screening. Eur J Pediatr. Dec. 1993;152(12):990-2. X-1. [pmid: 8131818].
858 Mazzocchi A, Foschini MP, Marconi F, et al. Kasabach-Merritt syndrome associated to angiosarcoma of the breast. A case report and review of the literature. Tumori. Apr. 30. 1993;79(2):137-40. X-1. [pmid: 8346567].
859 McCarthy RE, Lytle JO, Van Devanter S. The use of total circulatory arrest in the surgery of giant hemangioma and Klippel-Trenaunay syndrome in neonates. Clin Orthop Relat Res. Apr. 1993;(289):237-42. X-1, X-2. [pmid: 8386070].
860 McDaniel DH. Clinical usefulness of the Hexascan. Treatment of cutaneous vascular and melanocytic disorders. J Dermatol Surg Oncol. Apr. 1993;19(4):312-9. X-1. [pmid: 8478470].
861 Miyagi Y, Mannoji H, Akaboshi K, et al. Intraventricular cavernous malformation associated with medullary venous malformation. Neurosurgery. Mar. 1993;32(3):461-4. discussion 4. X-1. [pmid: 8455774].
862 Mizuguchi M, Kano H, Narita M, et al. Weber syndrome caused by intracerebral hemorrhage in a hemophiliac boy. Brain Dev. Nov–Dec. 1993;15(6):446-7. X-1. [pmid: 8147504].
863 Mordon S, Rotteleur G, Brunetaud JM, et al. Rationale for automatic scanners in laser treatment of port wine stains. Lasers Surg Med. 1993;13(1):113-23. X-1. [pmid: 8426518].
864 Morelli JG, Huff JC, Weston WL. Treatment of congenital telangiectatic vascular malformations with the pulsed-dye laser (585 nm). Pediatrics. Oct. 1993;92(4):603-6. X-1. [pmid: 8414835].
865 Nakada K, Kawada T, Fujioka T, et al. Hemangioma of the upper arm associated with massive hemorrhage in a neonate. Surg Today. 1993;23(3):273-6. X-1, X-2. [pmid: 8467182].
866 Neumann RA, Leonhartsberger H, Bohler-Sommeregger K, et al. Results and tissue healing after copper-vapour laser (at 578 nm) treatment of port wine stains and facial telangiectasias. Br J Dermatol. Mar. 1993;128(3):306-12. X-1. [pmid: 8471515].
867 Niechajev IA, Clodius L. Diagnostic criteria of vascular lesions in the face. Ann Plast Surg. Jul. 1993;31(1):32-41. X-1, X-2. [pmid: 8357218].
868 Pascual-Castroviejo I, Diaz-Gonzalez C, Garcia-Melian RM, et al. Sturge-Weber syndrome: study of 40 patients. Pediatr Neurol. Jul–Aug. 1993;9(4):283-8. X-1. [pmid: 8216540].
869 Phillips WG, Marsden JR. Kasabach-Merritt syndrome exacerbated by platelet transfusion. J R Soc Med. Apr. 1993;86(4):231-2. X-1. [pmid: 8505736].
870 Radke M, Waldschmidt J, Stolpe HJ, et al. Blue rubber-bleb-nevus syndrome with predominant urinary bladder hemangiomatosis. Eur J Pediatr Surg. Oct. 1993;3(5):313-6. X-1. [pmid: 8292588].
871 Ramadwar RH, Deshmukh SS, Oak SN, et al. Infantile hemangioendothelioma of the liver in a neonate. Indian Pediatr. Dec. 1993;30(12):1441-4. X-1, X-2. [pmid: 8077034].
872 Ramon F, Degryse H, De Schepper A. Intramuscular haemangioma. J Belge Radiol. Dec. 1993;76(6):406. X-1. [pmid: 8163449].
873 Reese V, Frieden IJ, Paller AS, et al. Association of facial hemangiomas with Dandy-Walker and other posterior fossa malformations. J Pediatr. Mar. 1993;122(3):379-84. X-2. [pmid: 8441091].
874 Renfro L, Geronemus RG. Anatomical differences of port-wine stains in response to treatment with the pulsed dye laser. Arch Dermatol. Feb. 1993;129(2):182-8. X-1. [pmid: 8434975].
875 Robinson JR Jr, Awad IA, Masaryk TJ, et al. Pathological heterogeneity of angiographically occult vascular malformations of the brain. Neurosurgery. Oct. 1993;33(4):547-54. discussion 54–5. X-1. [pmid: 8232794].
876 Rogalski R, Hensinger R, Loder R. Vascular abnormalities of the extremities: clinical findings and management. J Pediatr Orthop. Jan–Feb. 1993;13(1):9-14. X-1. [pmid: 8416363].
877 Rossiter JL, Hendrix RA, Tom LW, et al. Intramuscular hemangioma of the head and neck. Otolaryngol Head Neck Surg. Jan. 1993;108(1):18-26. X-2. [pmid: 8437870].
878 Ruttum MS, Abrams GW, Harris GJ, et al. Bilateral retinal embolization associated with intralesional corticosteroid injection for capillary hemangioma of infancy. J Pediatr Ophthalmol Strabismus. Jan–Feb. 1993;30(1):4-7. X-2. [pmid: 8455125].
879 Schulman A. Intrahepatic biliary stones: imaging features and a possible relationship with ascaris lumbricoides. Clin Radiol. May. 1993;47(5):325-32. X-1. [pmid: 8508594].
880 Schulman SR, Jones BR, Slotnick N, et al. Fetal tracheal intubation with intact uteroplacental circulation. Anesth Analg. Jan. 1993;76(1):197-9. X-1. [pmid: 8418725].
881 Schwartz MZ, Silver H, Schulman S. Maintenance of the placental circulation to evaluate and treat an infant with massive head and neck hemangioma. J Pediatr Surg. Apr. 1993;28(4):520-2. X-1, X-2. [pmid: 8483063].
882 Seo W, Kishimoto M, Minato T, et al. Submandibular hemangioma as the initial manifestation of Kasabach-Merritt syndrome. Int J Pediatr Otorhinolaryngol. Jan. 1993;25(1–3):269-76. X-2. [pmid: 8436476].
883 Serna MJ, Vazquez-Doval J, Vanaclocha V, et al. Occult spinal dysraphism: a neurosurgical problem with a dermatologic hallmark. Pediatr Dermatol. Jun. 1993;10(2):149-52. X-1. [pmid: 8346109].
884 Sexton J, O’Hare D. Simplified treatment of vascular lesions using the argon laser. J Oral Maxillofac Surg. Jan. 1993;51(1):12-6. X-1. [pmid: 8419567].
885 Sheehan-Dare RA. Laser treatment of port wine stains. BMJ. Feb. 6. 1993;306(6874):394-5. X-3, X-4. [pmid: 8461702].
886 Smith TP, Koci T, Mehringer CM, et al. Transarterial embolization of vertebral hemangioma. J Vasc Interv Radiol. Sep–Oct. 1993;4(5):681-5. X-1. [pmid: 8219564].
887 Stenninger E, Schollin J. Diffuse neonatal haemangiomatosis in a newborn child. Acta Paediatr. Jan. 1993;82(1):102-4. X-1. [pmid: 8453203].
888 Stoltenberg L, Rootwelt T, Oyasaeter S, et al. Hypoxanthine, xanthine, and uric acid concentrations in plasma, cerebrospinal fluid, vitreous humor, and urine in piglets subjected to intermittent versus continuous hypoxemia. Pediatr Res. Dec. 1993;34(6):767-71. X-1. [pmid: 8108190].
889 Taccone A, Tortori Donati P, Marzoli A, et al. Mucopolysaccharidosis: thickening of dura mater at the craniocervical junction and other CT/MRI findings. Pediatr Radiol. 1993;23(5):349-52. X-1. [pmid: 8233683].
890 Takato T, Komuro Y, Yonehara Y. Giant hemangioma of the parotid gland associated with Kasabach-Merritt syndrome: a case report. J Oral Maxillofac Surg. Apr. 1993;51(4):425-8. X-1. [pmid: 8450364].
891 Tawfik OW, Moral LA, Richardson WP, et al. Multicentric bilateral renal cell carcinomas and a vascular leiomyoma in a child. Pediatr Pathol. May–Jun. 1993;13(3):289-98. X-1. [pmid: 8516223].
892 Taylor MB. Can early therapy make a difference in treatment of strawberry hemangiomas?. Clin Laser Mon. Jun. 1993;11(6):87-90. X-4. [pmid: 10148820].
893 Teillac-Hamel D, De Prost Y, Bodemer C, et al. Serious childhood angiomas: unsuccessful alpha-2b interferon treatment. A report of four cases. Br J Dermatol. Oct. 1993;129(4):473-6. X-1. [pmid: 8217766].
894 Telander RL, Ahlquist D, Blaufuss MC. Rectal mucosectomy: a definitive approach to extensive hemangiomas of the rectum. J Pediatr Surg. Mar. 1993;28(3):379-81. X-1. [pmid: 8468650].
895 Terada S, Suzuki N, Uchide K, et al. Vulvar angioleiomyoma. Arch Gynecol Obstet. 1993;253(1):51-8. X-1. [pmid: 8392314].
896 Tiacci C, D’Alessandro P, Cantisani TA, et al. Epilepsy with bilateral occipital calcifications: Sturge-Weber variant or a different encephalopathy?. Epilepsia. May–Jun. 1993;34(3):528-39. X-1. [pmid: 8504785].
897 Tsao CY, Sommer A, Hamoudi AB. Aicardi syndrome, metastatic angiosarcoma of the leg, and scalp lipoma. Am J Med Genet. Mar. 1. 1993;45(5):594-6. X-1. [pmid: 8456830].
898 Velez A, Herrera M, Del Rio E, et al. Gorham’s syndrome. Int J Dermatol. Dec. 1993;32(12):884-7. X-1. [pmid: 8125692].
899 Vitale MK, Willwerth-Fortin J, Robbins K. Management of children on interferon therapy. Pediatr Nurs. May–Jun. 1993;19(3):230-4. X-1, X-2. [pmid: 8511002].
900 Walton JM, Rubin SZ, Soucy P, et al. Fetal tumors associated with hydrops: the role of the pediatric surgeon. J Pediatr Surg. Sep. 1993;28(9):1151-3. X-1. [pmid: 8308682].
901 Wheeland RG. Treatment of port-wine stains for the 1990s. J Dermatol Surg Oncol. Apr. 1993;19(4):348-56. X-1. [pmid: 8478474].
902 Wolf M, Engelberg S. Recurrent oral bleeding in Maffucci’s syndrome: report of a case. J Oral Maxillofac Surg. May. 1993;51(5):596-7. X-1. [pmid: 8478771].
903 Yamamoto K, Tanaka T, Fujita T, et al. Intractable temporal lobe epilepsy with calcified mass in the temporal lobe. Jpn J Psychiatry Neurol. Jun. 1993;47(2):262-3. X-1. [pmid: 8271558].
904 Yang MT, Chen CH, Mak SC, et al. Arthrogryposis multiplex congenita: report of a case of amyoplasia. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Mar–Apr. 1993;34(2):132-6. X-1. [pmid: 8372669].
905 Zukerberg LR, Nickoloff BJ, Weiss SW. Kaposiform hemangioendothelioma of infancy and childhood. An aggressive neoplasm associated with Kasabach-Merritt syndrome and lymphangiomatosis. Am J Surg Pathol. Apr. 1993;17(4):321-8. X-1. [pmid: 8494101].
906 Alster TS, Wilson F. Treatment of port-wine stains with the flashlamp-pumped pulsed dye laser: extended clinical experience in children and adults. Ann Plast Surg. May. 1994;32(5):478-84. X-1. [pmid: 8060071].
907 Apfelberg DB. Argon-pumped tunable dye laser. Ann Plast Surg. Apr. 1994;32(4):394-400. X-1. [pmid: 8210159].
908 Arisoy AE, Tunnessen WW Jr, et al. Pictures of the month. Case 2. Sturge-Weber syndrome. Arch Pediatr Adolesc Med. Sep. 1994;148(9):955-6. X-1. [pmid: 8075741].
909 Batra RK, Gulaya V, Madan R, et al. Anaesthesia and the Sturge-Weber syndrome. Can J Anaesth. Feb. 1994;41(2):133-6. X-1. [pmid: 7907531].
910 Berger TM, Berger MF, Hoffman AD, et al. Imaging diagnosis and follow-up of infantile hepatic haemangioendothelioma: a case report. Eur J Pediatr. Feb. 1994;153(2):100-2. X-1. [pmid: 8157013].
911 Besnard M, Pariente D, Hadchouel M, et al. Portal cavernoma in congenital hepatic fibrosis. Angiographic reports of 10 pediatric cases. Pediatr Radiol. 1994;24(1):61-5. X-1. [pmid: 8008502].
912 Bromley B, Benacerraf BR. Solid masses on the fetal surface of the placenta: differential diagnosis and clinical outcome. J Ultrasound Med. Nov. 1994;13(11):883-6. X-1. [pmid: 7837336].
913 Bruns J, Eggers-Stroeder G, von Torklus D. Synovial hemangioma--a rare benign synovial tumor. Report of four cases. Knee Surg Sports Traumatol Arthrosc. 1994;2(3):186-9. X-1. [pmid: 7584204].
914 Castiglia PT. Hemangiomas. J Pediatr Health Care. May–Jun. 1994;8(3):130-1. X-1, X-2. [pmid: 7799178].
915 Cerda J, Luque Mialdea R, Soleto J, et al. Segmentary splenectomy of the lower tip because of spontaneous rupture of a splenic hemangioendothelioma in a new-born child--a case report. Eur J Pediatr Surg. Apr. 1994;4(2):113-5. X-1. [pmid: 8025093].
916 Crosland JG, Roberts LJ. Pulsed dye laser therapy for port-wine stains in children. J Pediatr. Jan. 1994;124(1):161-2. X-6. [pmid: 8110293].
917 Damiano TR, Truwit CL, Dowd CF, et al. Posterior fossa venous angiomas with drainage through the brain stem. AJNR Am J Neuroradiol. Apr. 1994;15(4):643-52. X-1. [pmid: 8010264].
918 Day W. Topical anesthesia for birthmark removal. J Tenn Med Assoc. Mar. 1994;87(3):95-6. X-1, X-2. [pmid: 8035599].
919 Depierraz B, Ravussin P, Brossard E, et al. Percutaneous transtracheal jet ventilation for paediatric endoscopic laser treatment of laryngeal and subglottic lesions. Can J Anaesth. Dec. 1994;41(12):1200-7. X-4. [pmid: 7867117].
920 Devaney K, Vinh TN, Sweet DE. Skeletal-extraskeletal angiomatosis. A clinicopathological study of fourteen patients and nosologic considerations. J Bone Joint Surg Am. Jun. 1994;76(6):878-91. X-1, X-3. [pmid: 8200895].
921 Devaney K, Vinh TN, Sweet DE. Surface-based hemangiomas of bone. A review of 11 cases. Clin Orthop Relat Res. Mar. 1994;(300):233-40. X-1. [pmid: 8131341].
922 Drigo P, Mammi I, Battistella PA, et al. Familial cerebral, hepatic, and retinal cavernous angiomas: a new syndrome. Childs Nerv Syst. May. 1994;10(4):205-9. X-1. [pmid: 7923228].
923 Dyall-Smith D, Ramsden A, Laurie S. Adams-Oliver syndrome: aplasia cutis congenita, terminal transverse limb defects and cutis marmorata telangiectatica congenita. Australas J Dermatol. 1994;35(1):19-22. X-1. [pmid: 7998895].
924 Egawa H, Berquist W, Garcia-Kennedy R, et al. Respiratory distress from benign liver tumors: a report of two unusual cases treated with hepatic transplantation. J Pediatr Gastroenterol Nutr. Jul. 1994;19(1):114-7. X-1. [pmid: 7965461].
925 Elsas FJ, Lewis AR. Topical treatment of periocular capillary hemangioma. J Pediatr Ophthalmol Strabismus. May–Jun. 1994;31(3):153-6. X-2. [pmid: 7931948].
926 Enjolras O. Practical approach to angiomas. Nouvelles Dermatologiques. 1994;13(2):70-85. PMID: X-1, X-2.
927 Eppley BL, Sadove AM. Preoperative marking of cutaneous capillary malformations. Plast Reconstr Surg. Apr. 1994;93(5):1102-3. X-3, X-4. [pmid: 8134473].
928 Epstein RH, Halmi BH. Oxygen leakage around the laryngeal mask airway during laser treatment of port-wine stains in children. Anesth Analg. Mar. 1994;78(3):486-9. X-1. [pmid: 8109765].
929 Giulioni M, Acciarri N, Padovani R, et al. Surgical management of cavernous angiomas in children. Surg Neurol. Sep. 1994;42(3):194-9. X-1. [pmid: 7940104].
930 Harries RW. A rational approach to radiological screening in von Hippel-Lindau disease. J Med Screen. Apr. 1994;1(2):88-95. X-1. [pmid: 8790493].
931 Hochberg J, Ardenghy M, Pait TG. Scalp tourniquet. Br J Plast Surg. Apr. 1994;47(3):194-8. X-1. [pmid: 8193859].
932 Ito M, Kumamoto T, Yamamoto H, et al. A case report of placental hemangioma resulting in severe fetal distress. Acta Paediatr Jpn. Apr. 1994;36(2):207-11. X-1. [pmid: 8203269].
933 Iwanaka T, Tsuchida Y, Hashizume K, et al. Intralesional corticosteroid injection with short-term oral prednisolone for infantile hemangiomas of the eyelid and orbit. J Pediatr Surg. Apr. 1994;29(4):482-6. X-2. [pmid: 8014798].
934 Jamjoom ZA, Abdul-Aziz S, Jamjoom AH, et al. Subtentorial diverticulum of the third ventricle associated with a mural cavernous angioma in a child. Surg Neurol. Sep. 1994;42(3):211-7. X-1. [pmid: 7940106].
935 Jarzab G, Rozylo TK. The efficiency of cryosurgery in the treatment of maxillo-facial haemangiomata. Ann Univ Mariae Curie Sklodowska Med. 1994;49:151-3. X-2. [pmid: 8771847].
936 Julow J, Balint K, Gortvai P, et al. Posterior fossa haemangioblastomas. Acta Neurochir (Wien). 1994;128(1–4):109-14. X-1. [pmid: 7847125].
937 Klapper J. Headache in Sturge-Weber syndrome. Headache. Oct. 1994;34(9):521-2. X-1. [pmid: 8002325].
938 Klemme WR, James P, Skinner SR. Latent onset unilateral toe-walking secondary to hemangioma of the gastrocnemius. J Pediatr Orthop. Nov–Dec. 1994;14(6):773-5. X-1. [pmid: 7814593].
939 Kunkel EJ, Zager RP, Hausman CL, et al. An interdisciplinary group for parents of children with hemangiomas. Psychosomatics. Nov–Dec. 1994;35(6):524-32. X-3. [pmid: 7809355].
940 Kushner MS, Jampol LM, Haller JA. Cavernous hemangioma of the optic nerve. Retina. 1994;14(4):359-61. X-1. [pmid: 7817031].
941 Langmann A, Lindner S. Normalisation of asymmetric astigmatism after intralesional steroid injection for upper eye lid hemangioma in childhood. Doc Ophthalmol. 1994;87(3):283-90. X-3, X-4. [pmid: 7835197].
942 Latifi HR, Siegel MJ. Color Doppler flow imaging of pediatric soft tissue masses. J Ultrasound Med. Mar. 1994;13(3):165-9. X-1. [pmid: 7932971].
943 Laufer L, Cohen A. Sturge-Weber syndrome associated with a large left hemispheric arteriovenous malformation. Pediatr Radiol. 1994;24(4):272-3. X-1. [pmid: 7800450].
944 Leung AKC, Robson WLM, Wong AL. Diagnosis at a glance... cavernous hemangioma, mucocele. Emergency Medicine (00136654). 1994;26(10):23-4. Language: English. Entry Date: 19961201. Revision Date: 20140829. Publication Type: journal article. X-1.
945 Lo LJ, Noordhoff MS, Chen YR. Cleft lip and hemangioma: a patient with Wolf-Hirschhorn syndrome. Ann Plast Surg. May. 1994;32(5):539-41. X-2. [pmid: 8060081].
946 Lundell M. Estimates of absorbed dose in different organs in children treated with radium for skin hemangiomas. Radiat Res. Dec. 1994;140(3):327-33. X-3. [pmid: 7972684].
947 Lundell M, Hakulinen T, Holm LE. Thyroid cancer after radiotherapy for skin hemangioma in infancy. Radiat Res. Dec. 1994;140(3):334-9. X-3. [pmid: 7972685].
948 Mancini J, de Schonen S, Deruelle C, et al. Face recognition in children with early right or left brain damage. Dev Med Child Neurol. Feb. 1994;36(2):156-66. X-1. [pmid: 8132126].
949 Manglani M, Chari G, Sharma U, et al. Successful treatment with cyclophosphamide in a large hepatic hemangioendothelioma. Indian Pediatr. Jul. 1994;31(7):875-7. X-1. [pmid: 7890363].
950 Misra D, Hewitt G, Potts SR, et al. Inguinal herniotomy in young infants, with emphasis on premature neonates. J Pediatr Surg. Nov. 1994;29(11):1496-8. X-1. [pmid: 7844731].
951 Norbash AM, Marks MP, Lane B. Correlation of pressure measurements with angiographic characteristics predisposing to hemorrhage and steal in cerebral arteriovenous malformations. AJNR Am J Neuroradiol. May. 1994;15(5):809-13. X-1. [pmid: 8059646].
952 Ohlms LA, Jones DT, McGill TJ, et al. Interferon alfa-2a therapy for airway hemangiomas. Ann Otol Rhinol Laryngol. Jan. 1994;103(1):1-8. X-4. [pmid: 8291854].
953 Pfeiffer N. Guidelines for treating different stages of hemangioma. J Clin Laser Med Surg. Aug. 1994;12(4):239-40. X-1, X-2. [pmid: 10147487].
954 Reyes AT, Kantrowitz AB, Issenberg HJ, et al. Use of neurosurgical techniques for removal of a cardiac tumor. Ann Thorac Surg. Mar. 1994;57(3):741-3. X-2. [pmid: 8147651].
955 Ricketts RR, Hatley RM, Corden BJ, et al. Interferon-alpha-2a for the treatment of complex hemangiomas of infancy and childhood. Ann Surg. Jun. 1994;219(6):605-12. discussion 12–4. X-2. [pmid: 8203969].
956 Roach ES, Riela AR, Chugani HT, et al. Sturge-Weber syndrome: recommendations for surgery. J Child Neurol. Apr. 1994;9(2):190-2. X-1. [pmid: 8006373].
957 Samii M, Klekamp J. Surgical results of 100 intramedullary tumors in relation to accompanying syringomyelia. Neurosurgery. Nov. 1994;35(5):865-73. discussion 73. X-1. [pmid: 7838335].
958 Seikaly H, Cuyler JP. Infantile subglottic hemangioma. J Otolaryngol. Apr. 1994;23(2):135-7. X-3, X-4. [pmid: 8028072].
959 Sheehan-Dare RA, Cotterill JA. Copper vapour laser (578 nm) and flashlamp-pumped pulsed tunable dye laser (585 nm) treatment of port wine stains: results of a comparative study using test sites. Br J Dermatol. Apr. 1994;130(4):478-82. X-1. [pmid: 8186113].
960 Sheu BC, Shyu MK, Lin YF, et al. Prenatal diagnosis and corticosteroid treatment of diffuse neonatal hemangiomatosis: case report. J Ultrasound Med. Jun. 1994;13(6):495-9. X-1. [pmid: 8083954].
961 Sie KC, McGill T, Healy GB. Subglottic hemangioma: ten years’ experience with the carbon dioxide laser. Ann Otol Rhinol Laryngol. Mar. 1994;103(3):167-72. X-3, X-4. [pmid: 8122831].
962 Simonati A, Colamaria V, Bricolo A, et al. Microgyria associated with Sturge-Weber angiomatosis. Childs Nerv Syst. Aug. 1994;10(6):392-5. X-1. [pmid: 7842427].
963 Stefanova P, Chatalbashev N, Anastasov V. On combination treatment of hemangiomas in childhood. Folia Med (Plovdiv). 1994;36(3):41-7. X-3, X-4. [pmid: 8566902].
964 Stein BM, Sisti MB, Mohr JP, et al. Radiosurgery and venous malformations. J Neurosurg. Jan. 1994;80(1):175. author reply -7. X-6. [pmid: 8271010].
965 Suchet IB. Colour-flow Doppler artifacts in anechoic soft-tissue masses of infants. Can Assoc Radiol J. Jun. 1994;45(3):201-3. X-1, X-2. [pmid: 8193966].
966 Takahashi K, Mulliken JB, Kozakewich HP, et al. Cellular markers that distinguish the phases of hemangioma during infancy and childhood. J Clin Invest. Jun. 1994;93(6):2357-64. X-1. [pmid: 7911127].
967 Teske S, Ohlrich SJ, Gole G, et al. Treatment of orbital capillary haemangioma with interferon. Aust N Z J Ophthalmol. Feb. 1994;22(1):13-7. X-2. [pmid: 7986264].
968 Thompson DN, Taylor WF, Hayward RD. Silastic dural substitute: experience of its use in spinal and foramen magnum surgery. Br J Neurosurg. 1994;8(2):157-67. X-1. [pmid: 7917087].
969 Tomlinson FH, Houser OW, Scheithauer BW, et al. Angiographically occult vascular malformations: a correlative study of features on magnetic resonance imaging and histological examination. Neurosurgery. May. 1994;34(5):792-9. discussion 9–800. X-1. [pmid: 8052376].
970 Vachuanichsanong P, Malagon M, Moore ES. Childhood idiopathic hypercalciuria. International Pediatrics. 1994;9(1):40-8. X-1.
971 van der Meulen JC, Gilbert M, Roddi R. Early excision of nasal hemangiomas: the L-approach. Plast Reconstr Surg. Sep. 1994;94(3):465-73. discussion 74–5. X-2. [pmid: 8047598].
972 Vaughn RY, Lesher JL Jr, Chandler FW, et al. Histogenesis of vascular tumors in the Proteus syndrome. South Med J. Feb. 1994;87(2):228-32. X-1. [pmid: 8115889].
973 Verheggen R, Finkenstaedt M, Rittmeyer K, et al. Intra- and paraventricular arteriovenous malformations: symptomatology, neuroradiological diagnosis, surgical approach and postoperative results. Acta Neurochir (Wien). 1994;131(3–4):176-83. X-1. [pmid: 7754817].
974 Walker RS, Custer PL, Nerad JA. Surgical excision of periorbital capillary hemangiomas. Ophthalmology. Aug. 1994;101(8):1333-40. X-3, X-4. [pmid: 8058277].
975 Waner M, Suen JY, Dinehart S, et al. Laser photocoagulation of superficial proliferating hemangiomas. J Dermatol Surg Oncol. Jan. 1994;20(1):43-6. X-4. [pmid: 8288807].
976 Wong YC, Li YW, Chang MH. Gastrointestinal bleeding and paraparesis in blue rubber bleb nevus syndrome. Pediatr Radiol. 1994;24(8):600-1. X-1. [pmid: 7724289].
977 Wortsman J, Kumar V. Case report: idiopathic hypoparathyroidism co-existing with celiac disease: immunologic studies. Am J Med Sci. Jun. 1994;307(6):420-7. X-1. [pmid: 8198149].
978 Wu TJ, Teng RJ. Diffuse neonatal haemangiomatosis with intra-uterine haemorrhage and hydrops fetalis: a case report. Eur J Pediatr. Oct. 1994;153(10):759-61. X-1. [pmid: 7813536].
979 Zabramski JM, Wascher TM, Spetzler RF, et al. The natural history of familial cavernous malformations: results of an ongoing study. J Neurosurg. Mar. 1994;80(3):422-32. X-1. [pmid: 8113854].
980 Acciarri N, Giulioni M, Padovani R, et al. Surgical management of cerebral cavernous angiomas causing epilepsy. J Neurosurg Sci. Mar. 1995;39(1):13-20. X-1. [pmid: 8568551].
981 Aiba T, Koike T, Takeda N, et al. Intracranial cavernous malformations and skin angiomas associated with middle fossa arachnoid cyst: a report of three cases. Surg Neurol. Jan. 1995;43(1):31-3. discussion 4. X-1. [pmid: 7701419].
982 Aiba T, Tanaka R, Koike T, et al. Natural history of intracranial cavernous malformations. J Neurosurg. Jul. 1995;83(1):56-9. X-1. [pmid: 7782850].
983 Akagi S, Saito T, Ogawa R. Maffucci’s syndrome involving hemangioma in the cervical spine. Spine. Jul. 1. 1995;20(13):1510-4. X-1. [pmid: 8623072].
984 Apfelberg DB. Argon and YAG laser photocoagulation and excision of hemangiomas and vascular malformations of the nose. West J Med. Aug. 1995;163(2):122-7. X-3, X-4. [pmid: 7571558].
985 Apfelberg DB. Intralesional laser photocoagulation-steroids as an adjunct to surgery for massive hemangiomas and vascular malformations. Ann Plast Surg. Aug. 1995;35(2):144-8. discussion 9. X-1. [pmid: 7486735].
986 Azzena A, Vasoin F, Braghetto M, et al. High risk pregnancy in a patient with angioma of the corpus callosum. Clin Exp Obstet Gynecol. 1995;22(2):165-8. X-1. [pmid: 7781185].
987 Boothroyd AE, Carty H. The painless soft tissue mass in childhood--tumour or not?. Postgrad Med J. Jan. 1995;71(831):10-6. X-2. [pmid: 7708584].
988 Bruce S, Downe L, Devonald K, et al. Noninvasive investigation of infantile hepatic hemangioma: a case study. Pediatrics. Apr. 1995;95(4):595-7. X-1, X-2. [pmid: 7700764].
989 Burton BK, Schulz CJ, Angle B, et al. An increased incidence of haemangiomas in infants born following chorionic villus sampling (CVS). Prenat Diagn. Mar. 1995;15(3):209-14. X-1, X-2. [pmid: 7784377].
990 Casey AT, Thomas DG, Harkness WF. Stereotactically-guided craniotomy for cavernous angiomas presenting wit epilepsy. Acta Neurochir (Wien). 1995;137(1–2):34-7. X-1. [pmid: 8748865].
991 Cervoni L, Artico M, Delfini R. Intraosseous cavernous hemangioma of the skull. Neurosurg Rev. 1995;18(1):61-4. X-1. [pmid: 7566532].
992 Chiu HH, Chen RL, Lin KH, et al. Recombinant alpha-interferon treatment of intracranial hemangioma and Kasabach-Merritt syndrome in an infant with cytomegalovirus. J Formos Med Assoc. May. 1995;94(5):261-6. X-1, X-2. [pmid: 7613260].
993 Cleary MA, Wraith JE. The presenting features of mucopolysaccharidosis type IH (Hurler syndrome). Acta Paediatr. Mar. 1995;84(3):337-9. X-1. [pmid: 7780260].
994 Cohen DS, Zubay GP, Goodman RR. Seizure outcome after lesionectomy for cavernous malformations. J Neurosurg. Aug. 1995;83(2):237-42. X-1. [pmid: 7616268].
995 Colon F, Upton J. Pediatric hand tumors. A review of 349 cases. Hand Clin. May. 1995;11(2):223-43. X-1. [pmid: 7635884].
996 Crecco M, Floris R, Vidiri A, et al. Venous angiomas: plain and contrast-enhanced MRI and MR angiography. Neuroradiology. Jan. 1995;37(1):20-4. X-1. [pmid: 7708182].
997 Cruz OA, Zarnegar SR, Myers SE. Treatment of periocular capillary hemangioma with topical clobetasol propionate. Ophthalmology. Dec. 1995;102(12):2012-5. X-2. [pmid: 9098309].
998 Dalton R. Inquiry at Harvard prompts research paper corrections. Nature. Oct. 19. 1995;377(6550):569. X-1. [pmid: 7566162].
999 De Lorenzo RA, Fisher R. Infant with crying and fever. Ann Emerg Med. May. 1995;25(5):699-705. X-1. [pmid: 7741353].
1000 de Lorimier AA. Sclerotherapy for venous malformations. J Pediatr Surg. Feb. 1995;30(2):188-93. discussion 94. X-1. [pmid: 7738736].
1001 Drigo P, Battistella PA, Mammi I. Familial cerebral, hepatic, and retinal cavernous angiomas. Childs Nerv Syst. Feb. 1995;11(2):65. X-1. [pmid: 7758014].
1002 Ezekowitz A, Mulliken J, Folkman J. Additional corrections: interferon for hemangiomas of infancy. N Engl J Med. Aug. 31. 1995;333(9):595-6. X-3, X-4. [pmid: 7623913].
1003 Fernandez GR, Munoz FJ, Padron C, et al. Microphthalmos, facial capillary hemangioma and Dandy-Walker malformation. Acta Ophthalmol Scand. Apr. 1995;73(2):173-5. X-1, X-2. [pmid: 7656150].
1004 Ferrer FA, McKenna PH. Cavernous hemangioma of the scrotum: a rare benign genital tumor of childhood. J Urol. Apr. 1995;153(4):1262-4. X-1. [pmid: 7869525].
1005 Frim DM, Ogilvy CS. Mutism and cerebellar dysarthria after brain stem surgery: case report. Neurosurgery. Apr. 1995;36(4):854-7. X-1. [pmid: 7596521].
1006 Froehlich P, Stamm D, Floret D, et al. Management of subglottic haemangioma. Clin Otolaryngol Allied Sci. Aug. 1995;20(4):336-9. X-4. [pmid: 8548966].
1007 Furman GI, Sills J, Zeltzer P, et al. Visual diagnosis casebook. Kasabach-Merritt syndrome. J Perinatol. May–Jun. 1995;15(3):242-5. X-1. [pmid: 7666277].
1008 Geeze MA. Advanced practice case study: congenital hemangiomas. Semin Perioper Nurs. Apr. 1995;4(2):132-9. X-1, X-2. [pmid: 7780418].
1009 Gil-Nagel A, Wilcox KJ, Stewart JM, et al. Familial cerebral cavernous angioma: clinical analysis of a family and phenotypic classification. Epilepsy Res. May. 1995;21(1):27-36. X-1. [pmid: 7641673].
1010 Ginsbach G. Periorbital aesthetic surgery with the KTP laser. Aesthetic Plast Surg. Nov–Dec. 1995;19(6):505-9. X-1. [pmid: 8638485].
1011 Giulioni M, Acciarri N, Padovani R, et al. Results of surgery in children with cerebral cavernous angiomas causing epilepsy. Br J Neurosurg. Apr. 1995;9(2):135-41. X-1. [pmid: 7632358].
1012 Glassberg E, Lask G. Laser treatment of proliferating cutaneous hemangiomas. Dermatol Surg. Feb. 1995;21(2):185. X-3, X-4. [pmid: 7894944].
1013 Gregg CM, Wiatrak BJ, Koopmann CF Jr, et al. Management options for infantile subglottic hemangioma. Am J Otolaryngol. Nov–Dec. 1995;16(6):409-14. X-2. [pmid: 8572258].
1014 Gunalp I, Gunduz K. Vascular tumors of the orbit. Doc Ophthalmol. 1995;89(4):337-45. X-3, X-4. [pmid: 7493535].
1015 Hase T, Kodama M, Kishida A, et al. Successful management of infantile hepatic hilar hemangioendothelioma with obstructive jaundice and consumption coagulopathy. J Pediatr Surg. Oct. 1995;30(10):1485-7. X-1. [pmid: 8786496].
1016 Hoeger PH, Helmke K, Winkler K. Chronic consumption coagulopathy due to an occult splenic haemangioma: Kasabach-Merritt syndrome. Eur J Pediatr. May. 1995;154(5):365-8. X-1, X-2. [pmid: 7641767].
1017 Ichimura K, Nibu K, Tanaka T. Essentials of surgical treatment for intramasseteric hemangioma. Eur Arch Otorhinolaryngol. 1995;252(3):125-9. X-1. [pmid: 7662343].
1018 Illum N, Karlsmark T, Svejgaard E, et al. Ulcerated haemangioma successfully treated with interferon alfa-2b and topical granulocyte-macrophage colony-stimulating factor. Dermatology. 1995;191(4):315-7. X-1, X-2. [pmid: 8573929].
1019 Kane WJ, Morris S, Jackson IT, et al. Significant hemangiomas and vascular malformations of the head and neck: clinical management and treatment outcomes. Ann Plast Surg. Aug. 1995;35(2):133-43. X-3, X-4. [pmid: 7486734].
1020 Kaplan M, Paller AS. Clinical pearl: use of self-adhesive, compressive wraps in the treatment of limb hemangiomas. J Am Acad Dermatol. Jan. 1995;32(1):117-8. X-1, X-2. [pmid: 7822500].
1021 Kasantikul V, Trivijitsilp P. Intrathoracic lymphangiohemangioma associated with hemothorax: a cause of intrauterine fetal death. J Med Assoc Thai. Feb. 1995;78(2):99-102. X-1. [pmid: 7629452].
1022 Kattapong VJ, Hart BL, Davis LE. Familial cerebral cavernous angiomas: clinical and radiologic studies. Neurology. Mar. 1995;45(3 Pt 1):492-7. X-1. [pmid: 7898703].
1023 Kida Y, Kobayashi T, Tanaka T. Treatment of symptomatic AOVMs with radiosurgery. Acta Neurochir Suppl. 1995;63:68-72. X-1. [pmid: 7502732].
1024 Kondziolka D, Lunsford LD, Kestle JR. The natural history of cerebral cavernous malformations. J Neurosurg. Nov. 1995;83(5):820-4. X-1. [pmid: 7472549].
1025 Lam CH, Farmer JP, Meagher-Villemure K, et al. Masson’s vegetant haemangioendothelioma. Pediatr Neurosurg. 1995;23(2):93-6. X-1. [pmid: 8555102].
1026 Landthaler M, Hohenleutner U, el-Raheem TA. Laser therapy of childhood haemangiomas. Br J Dermatol. Aug. 1995;133(2):275-81. X-3. [pmid: 7547398].
1027 Levine VJ, Geronemus RG. Adverse effects associated with the 577- and 585-nanometer pulsed dye laser in the treatment of cutaneous vascular lesions: a study of 500 patients. J Am Acad Dermatol. Apr. 1995;32(4):613-7. X-1. [pmid: 7896952].
1028 Lindberg S, Karlsson P, Arvidsson B, et al. Cancer incidence after radiotherapy for skin haemangioma during infancy. Acta Oncol. 1995;34(6):735-40. X-3. [pmid: 7576739].
1029 Lundell M, Holm LE. Risk of solid tumors after irradiation in infancy. Acta Oncol. 1995;34(6):727-34. X-3. [pmid: 7576738].
1030 MacArthur CJ, Senders CW, Katz J. The use of interferon alfa-2a for life-threatening hemangiomas. Arch Otolaryngol Head Neck Surg. Jun. 1995;121(6):690-3. X-4. [pmid: 7772325].
1031 Malozowski S, Tanner LA, Wysowski DK, et al. Benign intracranial hypertension in children with growth hormone deficiency treated with growth hormone. J Pediatr. Jun. 1995;126(6):996-9. X-1. [pmid: 7776116].
1032 Marks DS, Thomas AM, Thompson AG, et al. Surgical management of haemangioendothelioma of the spine. Eur Spine J. 1995;4(3):186-90. X-1. [pmid: 7552654].
1033 Martinez-Perez D, Fein NA, Boon LM, et al. Not all hemangiomas look like strawberries: uncommon presentations of the most common tumor of infancy. Pediatr Dermatol. Mar. 1995;12(1):1-6. X-2. [pmid: 7792211].
1034 Matschke RG. Experiences with laser surgery in benign and malignant findings of the oro- and hypopharynx. Adv Otorhinolaryngol. 1995;49:153-7. X-1, X-2. [pmid: 7653353].
1035 Matz P, McDermott M, Gutin P, et al. Cavernous malformations: results of image-guided resection. J Image Guid Surg. 1995;1(5):273-9. X-1. [pmid: 9080347].
1036 McNamara T, Trotman CA, Hewson A, et al. Facial developmental vascular anomalies. Spec Care Dentist. May–Jun. 1995;15(3):107-12. X-1. [pmid: 8619171].
1037 Mejides AA, Adra AM, O’Sullivan MJ, et al. Prenatal diagnosis and therapy for a fetal hepatic vascular malformation. Obstet Gynecol. May. 1995;85(5 Pt 2):850-3. X-1. [pmid: 7724135].
1038 Mikola E, Yang Z, Merkel K, et al. A 7-year-old girl with a growth disturbance in the extremities. Am J Orthop (Belle Mead NJ). Apr. 1995;24(4):360-3. X-1. [pmid: 7788317].
1039 Misra D, Hewitt G, Potts SR, et al. Transperitoneal closure of the internal ring in incarcerated infantile inguinal hernias. J Pediatr Surg. Jan. 1995;30(1):95-6. X-1. [pmid: 7722840].
1040 Montes JL, Rosenblatt B, Farmer JP, et al. Lesionectomy of MRI detected lesions in children with epilepsy. Pediatr Neurosurg. 1995;22(4):167-73. X-1. [pmid: 7619716].
1041 Moran CA, Suster S. Mediastinal hemangiomas: a study of 18 cases with emphasis on the spectrum of morphological features. Hum Pathol. Apr. 1995;26(4):416-21. X-3. [pmid: 7705821].
1042 Motwani MV, Simon JW, Pickering JD, et al. Steroid injection versus conservative treatment of anisometropia amblyopia in juvenile adnexal hemangioma. J Pediatr Ophthalmol Strabismus. Jan–Feb. 1995;32(1):26-8. X-4. [pmid: 7752030].
1043 Mysore J, Roth LM, Kafrawy AH. Turner’s syndrome in association with hemangioma of the parotid gland: report of case. ASDC J Dent Child. Jan–Feb. 1995;62(1):67-9. X-1. [pmid: 7775687].
1044 Neubert AG, Golden MA, Rose NC. Kasabach-Merritt coagulopathy complicating Klippel-Trenaunay-Weber syndrome in pregnancy. Obstet Gynecol. May. 1995;85(5 Pt 2):831-3. X-1. [pmid: 7724128].
1045 Ogasawara KK, Ogasawara EM, Hirata G. Pregnancy complicated by von Hippel-Lindau disease. Obstet Gynecol. May. 1995;85(5 Pt 2):829-31. X-1. [pmid: 7724127].
1046 Onizuka K, Tsuneda K, Shibata Y, et al. Efficacy of flashlamp-pumped pulsed dye laser therapy for port wine stains: clinical assessment and histopathological characteristics. Br J Plast Surg. Jul. 1995;48(5):271-9. X-1. [pmid: 7633763].
1047 Park KC, Ahn PS, Lee YS, et al. Treatment of angioblastoma with recombinant interferon-alpha 2. Pediatr Dermatol. Jun. 1995;12(2):184-6. X-1. [pmid: 7659649].
1048 Rampini P, Occella C, Bleidl D, et al. Interferon alfa-2b therapy for extensive vision-threatening facial hemangioma. Nouvelles Dermatologiques. 1995;14(8):502-4. X-2.
1049 Rehan VK, Greenberg H, Fajardo C. Radiological case of the month. Hepatic hemangioendothelioma. Arch Pediatr Adolesc Med. Dec. 1995;149(12):1389-90. X-1. [pmid: 7489079].
1050 Reich DS, Wiatrak BJ. Upper airway obstruction in Sturge-Weber and Klippel-Trenaunay-Weber syndromes. Ann Otol Rhinol Laryngol. May. 1995;104(5):364-8. X-1. [pmid: 7747906].
1051 Reutens DC, Dubeau F, Melanson D, et al. Intractable partial epilepsy following low-dose scalp irradiation in infancy. Ann Neurol. Dec. 1995;38(6):951-4. X-1, X-2. [pmid: 8526469].
1052 Riss JM, Girard NJ, Proust H, et al. Diffuse choroidal hemangioma: report of a clinicopathological study in a 4-year-old boy. Ophthalmologica. 1995;209(5):284-8. X-1. [pmid: 8570155].
1053 Robbins RC, Chin C, Yun KL, et al. Arterial switch and resection of hepatic hemangioendothelioma. Ann Thorac Surg. Jun. 1995;59(6):1575-7. X-1. [pmid: 7771849].
1054 Roebuck DJ. Hemangioendothelioma of the liver in infants. J Pediatr Surg. Nov. 1995;30(11):1632. X-1. [pmid: 8583341].
1055 Rosenthal G, Snir M, Biedner B. Corticosteroid resistant orbital hemangioma with proptosis treated with interferon alfa-2-a and partial tarsorrhaphy. J Pediatr Ophthalmol Strabismus. Jan–Feb. 1995;32(1):50-1. X-1, X-2. [pmid: 7752034].
1056 Rozylo TK, Krupski W, Galkowska E. Ultrasonographic diagnostics of maxillo-facial haemangiomas. Ann Univ Mariae Curie Sklodowska Med. 1995;50:179-81. X-1. [pmid: 9263504].
1057 Rudy C. Newborn with port wine stain. J Pediatr Health Care. Sep–Oct. 37. 1995;9(5):229-8. X-1. [pmid: 7562314].
1058 Samuel M, Spitz L. Infantile hepatic hemangioendothelioma: the role of surgery. J Pediatr Surg. Oct. 1995;30(10):1425-9. X-1. [pmid: 8786479].
1059 Scheepers JH, Quaba AA. Does the pulsed tunable dye laser have a role in the management of infantile hemangiomas? Observations based on 3 years’ experience. Plast Reconstr Surg. Feb. 1995;95(2):305-12. X-3. [pmid: 7824610].
1060 Schwager K, Waner M, Hohmann D. Hemangioma: differential diagnosis and necessary early laser treatment. Adv Otorhinolaryngol. 1995;49:70-4. X-1, X-2. [pmid: 7653390].
1061 Shields CL, Shields JA, Barrett J, et al. Vasoproliferative tumors of the ocular fundus. Classification and clinical manifestations in 103 patients. Arch Ophthalmol. May. 1995;113(5):615-23. X-1. [pmid: 7748132].
1062 Soma H, Watanabe Y, Hata T. Chorangiosis and chorangioma in three cohorts of placentas from Nepal, Tibet, and Japan. Reprod Fertil Dev. 1995;7(6):1533-8. X-1. [pmid: 8743160].
1063 Squires LA, Constantini S, Miller DC, et al. Hypothalamic hamartoma and the Pallister-Hall syndrome. Pediatr Neurosurg. 1995;22(6):303-8. X-1. [pmid: 7577664].
1064 Stover B, Laubenberger J, Niemeyer C, et al. Haemangiomatosis in children: value of MRI during therapy. Pediatr Radiol. 1995;25(2):123-6. X-1. [pmid: 7541125].
1065 Suarez SM, Pensler JM, Paller AS. Response of deep tufted angioma to interferon alfa. J Am Acad Dermatol. Jul. 1995;33(1):124-6. X-1. [pmid: 7601929].
1066 Sujansky E, Conradi S. Sturge-Weber syndrome: age of onset of seizures and glaucoma and the prognosis for affected children. J Child Neurol. Jan. 1995;10(1):49-58. X-1. [pmid: 7769179].
1067 Sung MW, Chang SO, Choi JH, et al. Bleomycin sclerotherapy in patients with congenital lymphatic malformation in the head and neck. Am J Otolaryngol. Jul–Aug. 1995;16(4):236-41. X-1. [pmid: 7573743].
1068 Tai PT, Jewell LD. Case report: mesenteric mixed haemangioma and lymphangioma; report of a case with 10 year follow-up after radiation treatment. Br J Radiol. Jun. 1995;68(810):657-61. X-1. [pmid: 7627491].
1069 Tepetes K, Selby R, Webb M, et al. Orthotopic liver transplantation for benign hepatic neoplasms. Arch Surg. Feb. 1995;130(2):153-6. X-1. [pmid: 7848084].
1070 Tew JM Jr, Lewis AI, Reichert KW. Management strategies and surgical techniques for deep-seated supratentorial arteriovenous malformations. Neurosurgery. Jun. 1995;36(6):1065-72. X-1. [pmid: 7643983].
1071 Troilius A, Ljunggren B. Reflectance spectrophotometry in the objective assessment of dye laser-treated port-wine stains. Br J Dermatol. Feb. 1995;132(2):245-50. X-1. [pmid: 7888361].
1072 van Kasteren ME, van der Wurff AA, Palmen FM, et al. Epithelioid haemangioendothelioma of the lung: clinical and pathological pitfalls. Eur Respir J. Sep. 1995;8(9):1616-9. X-1. [pmid: 8575593].
1073 von Schweinitz D, Gluer S, Mildenberger H. Liver tumors in neonates and very young infants: diagnostic pitfalls and therapeutic problems. Eur J Pediatr Surg. Apr. 1995;5(2):72-6. X-1. [pmid: 7542025].
1074 Werner JA, Lippert BM, Hoffmann P, et al. Nd: YAG laser therapy of voluminous hemangiomas and vascular malformations. Adv Otorhinolaryngol. 1995;49:75-80. X-3, X-4. [pmid: 7653391].
1075 West KW, Rescorla FJ, Scherer LR 3rd, et al. Diagnosis and treatment of symptomatic breast masses in the pediatric population. J Pediatr Surg. Feb. 1995;30(2):182-6. discussion 6–7. X-1. [pmid: 7738735].
1076 Wong DC, Masel JP. Infantile hepatic haemangioendothelioma. Australas Radiol. May. 1995;39(2):140-4. X-1. [pmid: 7605318].
1077 Yeh KW, Jiang TH, Hung IJ. Interferon therapy in an infant with Kasabach-Merritt syndrome. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Sep–Oct. 1995;36(5):368-72. X-1. [pmid: 8607364].
1078 Achilleos OA, Buist LJ, Kelly DA, et al. Unresectable hepatic tumors in childhood and the role of liver transplantation. J Pediatr Surg. Nov. 1996;31(11):1563-7. X-1. [pmid: 8943124].
1079 Adamsbaum C, Pinton F, Rolland Y, et al. Accelerated myelination in early Sturge-Weber syndrome: MRI-SPECT correlations. Pediatr Radiol. Nov. 1996;26(11):759-62. X-1. [pmid: 8929371].
1080 Albregts AE, Hebert AA, Aboul-Nasr RA, et al. Malignant rhabdoid tumor presenting as a hemangioma. Pediatr Dermatol. Nov–Dec. 1996;13(6):468-71. X-1. [pmid: 8987055].
1081 Awan S, Davenport M, Portmann B, et al. Angiosarcoma of the liver in children. J Pediatr Surg. Dec. 1996;31(12):1729-32. X-1. [pmid: 8987004].
1082 Barlow RJ, Walker NP, Markey AC. Treatment of proliferative haemangiomas with the 585 nm pulsed dye laser. Br J Dermatol. Apr. 1996;134(4):700-4. X-4. [pmid: 8733375].
1083 Boon LM, Enjolras O, Mulliken JB. Congenital hemangioma: evidence of accelerated involution. J Pediatr. Mar. 1996;128(3):329-35. X-1. [pmid: 8774499].
1084 Botash RJ, Oliphant M, Capaldo G. Imaging of congenital kaposiform retroperitoneal hemangioendothelioma associated with Kasabach-Merritt syndrome. Clin Imaging. Jan–Mar. 1996;20(1):17-20. X-1. [pmid: 8846303].
1085 Boulot P, Deschamps F, Montoya F, et al. Prenatal aspects of giant fetal cranial haemangioendothelioma. Prenat Diagn. Apr. 1996;16(4):357-9. X-1. [pmid: 8734813].
1086 Calder CI, Raafat F, Buckels JA, et al. Orthotopic liver transplantation for type 2 hepatic infantile haemangioendothelioma. Histopathology. Mar. 1996;28(3):271-3. X-1. [pmid: 8729050].
1087 Canavese F, Cortese MG, Proietti L, et al. Bulky-pedunculated hemolymphangioma of the esophagus: rare case in a two-years old girl. Eur J Pediatr Surg. Jun. 1996;6(3):170-2. X-1. [pmid: 8817212].
1088 Ceballos-Quintal JM, Pinto-Escalante D, Castillo-Zapata I. A new case of Klippel-Trenaunay-Weber (KTW) syndrome: evidence of autosomal dominant inheritance. Am J Med Genet. Jun. 14. 1996;63(3):426-7. X-1, X-2. [pmid: 8737646].
1089 Chang CJ, Achauer BM, Vander Kam VM. Laser treatment of complicated head and neck hemangiomas in infancy. Changgeng Yi Xue Za Zhi. Jun. 1996;19(2):135-41. X-3. [pmid: 8828255].
1090 Chung T, Hoffer FA, Burrows PE, et al. MR imaging of hepatic hemangiomas of infancy and changes seen with interferon alpha-2a treatment. Pediatr Radiol. 1996;26(5):341-8. X-3, X-4. [pmid: 8657464].
1091 Davis MM, Bugaieski EM, Heifetz SA. Pathological case of the month. Capillary hemangioma of the lung. Arch Pediatr Adolesc Med. Dec. 1996;150(12):1309-10. X-1, X-2. [pmid: 8954007].
1092 DeFilippo JL, Yu JS, Weis L, et al. Soft tissue hemangioma with adjacent periosteal reaction simulating a primary bone tumor. Skeletal Radiol. Feb. 1996;25(2):174-7. X-1. [pmid: 8848750].
1093 D’Ercole C, Cravello L, Boubli L, et al. Large chorioangioma associated with hydrops fetalis: prenatal diagnosis and management. Fetal Diagn Ther. Sep–Oct. 1996;11(5):357-60. X-1. [pmid: 8894632].
1094 Egbert JE, Schwartz GS, Walsh AW. Diagnosis and treatment of an ophthalmic artery occlusion during an intralesional injection of corticosteroid into an eyelid capillary hemangioma. Am J Ophthalmol. Jun. 1996;121(6):638-42. X-1, X-2. [pmid: 8644806].
1095 Ettlinger JJ, Fleming PJ, Joffe HS, et al. Cavernous haemangioma with Kasabach-Merritt syndrome: treatment with alpha-interferon. J R Soc Med. Jan. 1996;89(1):55p-6p. X-1. [pmid: 8709089].
1096 Fernandes ET, Manivel JC, Reinberg Y. Hematuria in a newborn infant caused by bladder hemangioma. Urology. Mar. 1996;47(3):412-5. X-1, X-2. [pmid: 8633412].
1097 Fok TF, Chan MS, Metreweli C, et al. Hepatic haemangioendothelioma presenting with early heart failure in a newborn: treatment with hepatic artery embolization and interferon. Acta Paediatr. Nov. 1996;85(11):1373-5. X-1. [pmid: 8955471].
1098 Foster TD, Gold MH. The successful use of the Photoderm VL in the treatment of a cavernous hemangioma in a dark-skinned infant. Minim Invasive Surg Nurs. Fall. 1996;10(3):102-4. X-1. [pmid: 9025485].
1099 Fremont S, Kanny G, Bieber S, et al. Identification of a masked allergen, alpha-lactalbumin, in baby-food cereal flour guaranteed free of cow’s milk protein. Allergy. Oct. 1996;51(10):749-54. X-1. [pmid: 8905005].
1100 Frieden IJ, Reese V, Cohen D. PHACE syndrome. The association of posterior fossa brain malformations, hemangiomas, arterial anomalies, coarctation of the aorta and cardiac defects, and eye abnormalities. Arch Dermatol. Mar. 1996;132(3):307-11. X-2. [pmid: 8607636].
1101 Frim DM, Zec N, Golden J, et al. Immunohistochemically identifiable tissue plasminogen activator in cavernous angioma: mechanism for re-hemorrhage and lesion growth. Pediatr Neurosurg. Sep. 1996;25(3):137-41. discussion 41–2. X-1. [pmid: 9144712].
1102 Fujii M, Arisawa M, Morimoto M, et al. Supra- and infratentorial multiple cavernous angiomas in an infant: report with MR evaluation of an unusual case. Childs Nerv Syst. Sep. 1996;12(9):564-7. X-1. [pmid: 8906376].
1103 Geronemus RG, Kauvar AN. The pulsed-dye laser for infantile hemangiomas. Plast Reconstr Surg. May. 1996;97(6):1302-3. X-3, X-4. [pmid: 8628815].
1104 Griffiths PD, Boodram MB, Blaser S, et al. Abnormal ocular enhancement in Sturge-Weber syndrome: correlation of ocular MR and CT findings with clinical and intracranial imaging findings. AJNR Am J Neuroradiol. Apr. 1996;17(4):749-54. X-1. [pmid: 8730196].
1105 Hande AM, Nagpal RD. Cerebellar haemangioblastoma with extensive dissemination. Br J Neurosurg. Oct. 1996;10(5):507-11. X-1. [pmid: 8922714].
1106 Hijii T, Fukushige J, Tasaki K, et al. Interferon-alpha therapy for multiple hemangiomas associated with coarctation of the aorta. Heart Vessels. 1996;11(4):211-4. X-1, X-2. [pmid: 9119811].
1107 Hovius SE, Borg DH, Paans PR, et al. The diagnostic value of magnetic resonance imaging in combination with angiography in patients with vascular malformations: a prospective study. Ann Plast Surg. Sep. 1996;37(3):278-85. X-1. [pmid: 8883726].
1108 Hsiang JN, Ng HK, Tsang RK, et al. Dural cavernous angiomas in a child. Pediatr Neurosurg. Aug. 1996;25(2):105-8. X-1. [pmid: 9075255].
1109 Huber G, Henkes H, Hermes M, et al. Regional association of developmental venous anomalies with angiographically occult vascular malformations. Eur Radiol. 1996;6(1):30-7. X-1. [pmid: 8797947].
1110 Ishii H, Iwabuchi K, Kameya T, et al. Pulmonary capillary haemangiomatosis. Histopathology. Sep. 1996;29(3):275-8. X-1, X-2. [pmid: 8884358].
1111 Iyer CP, Stanley P, Mahour GH. Hepatic hemangiomas in infants and children: a review of 30 cases. Am Surg. May. 1996;62(5):356-60. X-3, X-4. [pmid: 8615561].
1112 Jenner G, Soderlund V, Bauer HF, et al. MR imaging of skeletal muscle hemangiomas. A report of 16 cases. Acta Radiol. Mar. 1996;37(2):140-4. X-3, X-4. [pmid: 8600950].
1113 Kasantikul V, Shuangshoti S, Panichabhongse V, et al. Combined angioma and glioma (angioglioma). J Surg Oncol. May. 1996;62(1):15-21. X-1. [pmid: 8618395].
1114 Kiff KM, Mok Q, Dunne J, et al. Steroids for intubated croup masking airway haemangioma. Arch Dis Child. Jan. 1996;74(1):66-7. X-2. [pmid: 8660054].
1115 Kleer CG, Unni KK, McLeod RA. Epithelioid hemangioendothelioma of bone. Am J Surg Pathol. Nov. 1996;20(11):1301-11. X-1. [pmid: 8898834].
1116 Koukkari MW, Vanefsky MA, Steinberg GK, et al. Phenytoin-related chorea in children with deep hemispheric vascular malformations. J Child Neurol. Nov. 1996;11(6):490-1. X-1. [pmid: 9120230].
1117 Lacour M, Syed S, Linward J, et al. Role of the pulsed dye laser in the management of ulcerated capillary haemangiomas. Arch Dis Child. Feb. 1996;74(2):161-3. X-4. [pmid: 8660082].
1118 Lauvetz RW, Malek RS, Husmann DA. Treatment of extensive urethral hemangioma with KTP/532 laser. Lasers Surg Med. 1996;18(1):92-5. X-1. [pmid: 8850471].
1119 Lawton MT, Golfinos JG, Spetzler RF. The contralateral transcallosal approach: experience with 32 patients. Neurosurgery. Oct. 1996;39(4):729-34. discussion 34–5. X-1. [pmid: 8880765].
1120 Leblanc R, Melanson D, Wilkinson RD. Hereditary neurocutaneous angiomatosis. Report of four cases. J Neurosurg. Dec. 1996;85(6):1135-42. X-1. [pmid: 8929507].
1121 Lundell M, Holm LE. Mortality from leukemia after irradiation in infancy for skin hemangioma. Radiat Res. May. 1996;145(5):595-601. X-1, X-3. [pmid: 8619025].
1122 Lundell M, Mattsson A, Hakulinen T, et al. Breast cancer after radiotherapy for skin hemangioma in infancy. Radiat Res. Feb. 1996;145(2):225-30. X-3. [pmid: 8606933].
1123 Maier H, Neumann R. Treatment of strawberry marks with flashlamp-pumped pulsed dye laser in infancy. Lancet. Jan. 13. 1996;347(8994):131-2. X-6. [pmid: 8538336].
1124 Mathiesen T, Lindquist C, Kihlstrom L. Microsurgery with the Steiner-Lindquist stereotaxic guide. Br J Neurosurg. Apr. 1996;10(2):155-60. X-2. [pmid: 8861306].
1125 McCannel CA, Hoenig J, Umlas J, et al. Orbital lesions in the blue rubber bleb nevus syndrome. Ophthalmology. Jun. 1996;103(6):933-6. X-1. [pmid: 8643250].
1126 Merino MJ, Chuaqui R, Fernandez P. Parathyroid Hemangioma: A Report of Two Cases. Endocr Pathol. Winter. 1996;7(4):319-22. X-1. [pmid: 12114803].
1127 Montan S, Anandakumar C, Joseph R, et al. Fetal and neonatal haemodilution associated with multiple placental chorioangioma: case report. J Obstet Gynaecol Res. Feb. 1996;22(1):43-6. X-1. [pmid: 8624891].
1128 Ohlms LA, Forsen J, Burrows PE. Venous malformation of the pediatric airway. Int J Pediatr Otorhinolaryngol. Oct. 1996;37(2):99-114. X-1. [pmid: 8894808].
1129 Ozsoylu S. Megadose methylprednisolone therapy for Kasabach-Merritt syndrome. J Pediatr. Dec. 1996;129(6):947-8. X-1. [pmid: 8969749].
1130 Pascual-Castroviejo I, Viano J, Moreno F, et al. Hemangiomas of the head, neck, and chest with associated vascular and brain anomalies: a complex neurocutaneous syndrome. AJNR Am J Neuroradiol. Mar. 1996;17(3):461-71. X-1. [pmid: 8881240].
1131 Perrone HC, Toporovski J, Schor N. Urinary inhibitors of crystallization in hypercalciuric children with hematuria and nephrolithiasis. Pediatr Nephrol. Aug. 1996;10(4):435-7. X-1. [pmid: 8865237].
1132 Pitanguy I, Machado BH, Radwanski HN, et al. Surgical treatment of hemangiomas of the nose. Ann Plast Surg. Jun. 1996;36(6):586-92. discussion 92–3. X-1. [pmid: 8792967].
1133 Pozzati E, Acciarri N, Tognetti F, et al. Growth, subsequent bleeding, and de novo appearance of cerebral cavernous angiomas. Neurosurgery. Apr. 1996;38(4):662-9. discussion 9–70. X-1. [pmid: 8692382].
1134 Pozzati E, Giangaspero F, Marliani F, et al. Occult cerebrovascular malformations after irradiation. Neurosurgery. Oct. 1996;39(4):677-82. discussion 82–4. X-1. [pmid: 8880758].
1135 Prayson RA, Grewal ID, McMahon JT, et al. Leukocyte adhesion molecules and x-ray energy dispersive spectroscopy in Sturge-Weber disease. Pediatr Neurol. Nov. 1996;15(4):332-6. X-1. [pmid: 8972534].
1136 Sabhikhi AK, Chaudhury MC, Singh D, et al. Chorangioma of the placenta with hydrops fetalis. Indian Pediatr. Jun. 1996;33(6):520-1. X-1. [pmid: 8979617].
1137 Sawin PD, Follett KA, Wen BC, et al. Symptomatic intrasellar hemangioblastoma in a child treated with subtotal resection and adjuvant radiosurgery. Case report. J Neurosurg. Jun. 1996;84(6):1046-50. X-1. [pmid: 8847570].
1138 Seawright AA, Sullivan TJ, Pelekanos JT, et al. Coexistent orbital and cerebellar venous anomalies in linear sebaceous naevus syndrome. Aust N Z J Ophthalmol. Nov. 1996;24(4):373-6. X-1. [pmid: 8985552].
1139 Serrano M, Iglesias A, San Millan J. Long-term response to radiotherapy of vertebral hemangioma resulting in paraplegia. Acta Oncol. 1996;35(4):498-9. X-1, X-2. [pmid: 8695171].
1140 Shevell MI, Rosenblatt B, Watters GV, et al. “Pseudo-BECRS”: intracranial focal lesions suggestive of a primary partial epilepsy syndrome. Pediatr Neurol. Jan. 1996;14(1):31-5. X-1. [pmid: 8652012].
1141 Soumekh B, Adams GL, Shapiro RS. Treatment of head and neck hemangiomas with recombinant interferon alpha 2B. Ann Otol Rhinol Laryngol. Mar. 1996;105(3):201-6. X-4. [pmid: 8615583].
1142 Sreeram N, Miller P, John P. Detachable balloon occlusion of vascular malformations in young patients. Int J Cardiol. Oct. 11. 1996;56(2):119-24. X-1, X-2. [pmid: 8894781].
1143 Stokes RB, Saunders CJ, Thaller SR. Bregmatic masses in children. J Craniofac Surg. May. 1996;7(3):204-6. X-1. [pmid: 9086886].
1144 Uchino A, Hasuo K, Matsumoto S, et al. Cerebral venous angiomas associated with hemorrhagic lesions. Their MRI manifestations. Clin Imaging. Jul–Sep. 1996;20(3):157-63. X-1. [pmid: 8877166].
1145 Urgelles E, Pascual-Castroviejo I, Roche C, et al. Arteriovenous malformation in hypomelanosis of Ito. Brain Dev. Jan–Feb. 1996;18(1):78-80. X-1. [pmid: 8907350].
1146 Ward DG, Wang W, Fesmire W, et al. A deep-tissue hemangioma presenting as a rapidly progressive expanding mass and thrombocytopenia in an infant. Pediatr Emerg Care. Dec. 1996;12(6):422-4. X-2. [pmid: 8989790].
1147 Wiatrak BJ, Reilly JS, Seid AB, et al. Open surgical excision of subglottic hemangioma in children. Int J Pediatr Otorhinolaryngol. Jan. 1996;34(1–2):191-206. X-2. [pmid: 8770689].
1148 Wiener ES, Touloukian RJ, Rodgers BM, et al. Hernia survey of the Section on Surgery of the American Academy of Pediatrics. J Pediatr Surg. Aug. 1996;31(8):1166-9. X-1. [pmid: 8863257].
1149 Wu JM, Lin CS, Wang JN, et al. Pulmonary cavernous hemangiomatosis treated with interferon alfa-2a. Pediatr Cardiol. Sep–Oct. 1996;17(5):332-4. X-1. [pmid: 8660452].
1150 Wu TJ, Teng RJ, Tsou Yau KI. Hepatic hemangioendothelioma: successful treatment with steroid in a very-low-birth-weight infant. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Jan–Feb. 1996;37(1):56-8. X-1. [pmid: 8936013].
1151 Wyllie E, Comair YG, Kotagal P, et al. Epilepsy surgery in infants. Epilepsia. Jul. 1996;37(7):625-37. X-1. [pmid: 8681894].
1152 Zevgaridis D, van Velthoven V, Ebeling U, et al. Seizure control following surgery in supratentorial cavernous malformations: a retrospective study in 77 patients. Acta Neurochir (Wien). 1996;138(6):672-7. X-1. [pmid: 8836281].
1153 Zimmermann A, Baer HU. Fibrous tumor-liver interface in large hepatic neoplasms: its significance for tumor resection and enucleation. Liver Transpl Surg. May. 1996;2(3):192-9. X-1. [pmid: 9346648].
1154 Management of hemangiomas. Pediatr Dermatol. Jan–Feb. 1997;14(1):57-83. X-1, X-2. [pmid: 9050768].
1155 Double take. A collage of nevi. Consultant. 1997;37(7):1924-5. 8. 33. 4. passim. PMID: X-1.
1156 Achauer BM, Chang CJ, Vander Kam VM. Management of hemangioma of infancy: review of 245 patients. Plast Reconstr Surg. Apr. 1997;99(5):1301-8. X-3. [pmid: 9105356].
1157 Bajpai M, Kataria R, Gupta DK, et al. Occult spinal dysraphism. Indian J Pediatr. Nov–Dec. 1997;64(6 Suppl):62-7. X-1. [pmid: 11129883].
1158 Bauman NM, Burke DK, Smith RJ. Treatment of massive or life-threatening hemangiomas with recombinant alpha(2a)-interferon. Otolaryngol Head Neck Surg. Jul. 1997;117(1):99-110. X-4. [pmid: 9230332].
1159 Behnke J, Christen HJ, Mursch K, et al. Intra-axial endophytic tumors in the pons and/or medulla oblongata. II. Intraoperative findings, postoperative results, and 2-year follow up in 25 children. Childs Nerv Syst. Mar. 1997;13(3):135-46. X-1. [pmid: 9137855].
1160 Berard M, Sordello S, Ortega N, et al. Vascular endothelial growth factor confers a growth advantage in vitro and in vivo to stromal cells cultured from neonatal hemangiomas. Am J Pathol. Apr. 1997;150(4):1315-26. X-1. [pmid: 9094988].
1161 Bhatoe HS. Mutism, oropharyngeal apraxia and dysarthria after posterior fossa tumour excision. Br J Neurosurg. Aug. 1997;11(4):341-3. X-1. [pmid: 9337934].
1162 Blei F, Isakoff M, Deb G. The response of parotid hemangiomas to the use of systemic interferon alfa-2a or corticosteroids. Arch Otolaryngol Head Neck Surg. Aug. 1997;123(8):841-4. X-3, X-4. [pmid: 9260550].
1163 Blei F, Orlow SJ, Geronemus R. Multimodal management of diffuse neonatal hemangiomatosis. J Am Acad Dermatol. Dec. 1997;37(6):1019-21. X-1. [pmid: 9418785].
1164 Brennan TD, Miller AS, Chen SY. Lymphangiomas of the oral cavity: a clinicopathologic, immunohistochemical, and electron-microscopic study. J Oral Maxillofac Surg. Sep. 1997;55(9):932-5. X-1. [pmid: 9294501].
1165 Brouwers MA, Peeters PM, de Jong KP, et al. Surgical treatment of giant haemangioma of the liver. Br J Surg. Mar. 1997;84(3):314-6. X-1. [pmid: 9117293].
1166 Capin DM, Gottlieb SM, Rosman NP. Central nervous system hemangiomatosis in early childhood. Pediatr Neurol. Nov. 1997;17(4):365-70. X-1, X-2. [pmid: 9436805].
1167 Cappabianca P, Alfieri A, Maiuri F, et al. Supratentorial cavernous malformations and epilepsy: seizure outcome after lesionectomy on a series of 35 patients. Clin Neurol Neurosurg. Aug. 1997;99(3):179-83. X-1. [pmid: 9350398].
1168 Castello MA, Ragni G, Antimi A, et al. Successful management with interferon alpha-2a after prednisone therapy failure in an infant with a giant cavernous hemangioma. Med Pediatr Oncol. Mar. 1997;28(3):213-5. X-1. [pmid: 9024520].
1169 Cattini Perrone H, Bruder Stapleton F, Toporovski J, et al. Hematuria due to hyperuricosuria in children: 36-month follow-up. Clin Nephrol. Nov. 1997;48(5):288-91. X-1. [pmid: 9403212].
1170 Chang B, Gu H, Qian H, et al. Treatment of cutaneous hemangiomas with low-dose soft x-ray. Chin Med J (Engl). Nov. 1997;110(11):893-4. X-1. [pmid: 9772427].
1171 Chang CJ, Achauer BM, VanderKam VM. Reconstruction of head and neck hemangiomas with tissue expansion in the pediatric population. Ann Plast Surg. Jan. 1997;38(1):15-8. X-3, X-4. [pmid: 9015533].
1172 Chang E, Boyd A, Nelson CC, et al. Successful treatment of infantile hemangiomas with interferon-alpha-2b. J Pediatr Hematol Oncol. May–Jun. 1997;19(3):237-44. X-2. [pmid: 9201147].
1173 Cheung DS, Warman ML, Mulliken JB. Hemangioma in twins. Ann Plast Surg. Mar. 1997;38(3):269-74. X-2, X-3. [pmid: 9088466].
1174 Chia J, Teh M, Pho RW. Haemangioendothelioma in an infant’s wrist. J Hand Surg Br. Feb. 1997;22(1):119-21. X-1. [pmid: 9061545].
1175 Chiron C, Jambaque I, Nabbout R, et al. The right brain hemisphere is dominant in human infants. Brain. Jun. 1997;120(Pt 6):1057-65. X-1. [pmid: 9217688].
1176 Cunha e Sa M, Barroso CP, Caldas MC, et al. Innervation pattern of malformative cortical vessels in Sturge-Weber disease: an histochemical, immunohistochemical, and ultrastructural study. Neurosurgery. Oct. 1997;41(4):872-6. discussion 6–7. X-1. [pmid: 9316049].
1177 Deb G, Jenkner A, De Sio L, et al. Spindle cell (Kaposiform) hemangioendothelioma with Kasabach-Merritt syndrome in an infant: successful treatment with alpha-2A interferon. Med Pediatr Oncol. May. 1997;28(5):358-61. X-1. [pmid: 9121401].
1178 Demiriz M, Tunca Y, Ozcan A, et al. Placental chorioangioma associated with fetal cardiac complication. Acta Obstet Gynecol Scand. Aug. 1997;76(7):708-9. X-1. [pmid: 9292650].
1179 Di Rocco C, Iannelli A, Tamburrini G. Surgical management of paediatric cerebral cavernomas. J Neurosurg Sci. Dec. 1997;41(4):343-7. X-1. [pmid: 9555641].
1180 Dixon JJ, James D, Fleming PJ, et al. A novel method for estimating the volume of capillary haemangioma to determine response to treatment. Clin Exp Dermatol. Jan. 1997;22(1):20-2. X-2. [pmid: 9330047].
1181 Eliashar R, Saah D, Osin P, et al. Hemangioendothelioma of the temporal bone in a child. Int J Pediatr Otorhinolaryngol. May. 4. 1997;40(1):67-71. X-1. [pmid: 9184980].
1182 Elsner P, Dummer R. Signs of methaemoglobinaemia after topical application of EMLA cream in an infant with haemangioma. Dermatology. 1997;195(2):153-4. X-1, X-2. [pmid: 9310724].
1183 Emoto M, Tamura R, Izumi H, et al. Sonodynamic changes after transcatheter arterial embolization in a vaginal hemangioma: case report. Ultrasound Obstet Gynecol. Jul. 1997;10(1):66-7. X-1. [pmid: 9263427].
1184 Enjolras O, Gelbert F. Superficial hemangiomas: associations and management. Pediatr Dermatol. May–Jun. 1997;14(3):173-9. X-3, X-4. [pmid: 9192407].
1185 Enjolras O, Wassef M, Mazoyer E, et al. Infants with Kasabach-Merritt syndrome do not have “true” hemangiomas. J Pediatr. Apr. 1997;130(4):631-40. X-1. [pmid: 9108863].
1186 Esassolak M, Yalman D, Aras AB, et al. Radiotherapy in Kasabach-Merritt syndrome. Radiography. 1997;3(2):149-53. PMID: X-1.
1187 Evole-Buselli M, Hernandez-Marti MJ, Gasco-Lacalle B, et al. Neonatal dermal hematopoiesis associated with diffuse neonatal hemangiomatosis. Pediatr Dermatol. Sep–Oct. 1997;14(5):383-6. X-1. [pmid: 9336812].
1188 Ezekowitz RA. The relationship between facial and airway hemangiomas: does seeing red bode ill?. J Pediatr. Oct. 1997;131(4):514-5. X-3, X-4. [pmid: 9386650].
1189 Fan J, Yang P. Versatility of expanded forehead flaps for facial reconstruction. Case report. Scand J Plast Reconstr Surg Hand Surg. Dec. 1997;31(4):357-63. X-1. [pmid: 9444714].
1190 Gangopadhyay AN, Sinha CK, Gopal SC, et al. Role of steroid in childhood haemangioma: a 10 years review. Int Surg. Jan–Mar. 1997;82(1):49-51. X-3, X-4. [pmid: 9189802].
1191 Gdal-On M, Gelfand YA. Cryoextraction of orbital capillary hemangioma diagnosed by technetium-99m-labeled red blood cell scintigraphy. Ophthalmic Surg Lasers. Nov. 1997;28(11):954-6. X-2. [pmid: 9387184].
1192 Griffiths PD, Boodram MB, Blaser S, et al. 99mTechnetium HMPAO imaging in children with the Sturge-Weber syndrome: a study of nine cases with CT and MRI correlation. Neuroradiology. Mar. 1997;39(3):219-24. X-1. [pmid: 9106299].
1193 Hastings MM, Milot J, Barsoum-Homsy M, et al. Recombinant interferon alfa-2b in the treatment of vision-threatening capillary hemangiomas in childhood. J aapos. Dec. 1997;1(4):226-30. X-4. [pmid: 10532768].
1194 Herman TE, McAlister PW, Dehner LP, et al. Beckwith-Wiedemann syndrome and splenic hemangioma: report of a case. Pediatr Radiol. Apr. 1997;27(4):350-2. X-1. [pmid: 9094248].
1195 Higano S, Takahashi S, Kurihara N, et al. Supratentorial primary intra-axial tumors in children. MR and CT evaluation. Acta Radiol. Nov. 1997;38(6):945-52. X-1. [pmid: 9394647].
1196 Hoeve LJ, Kuppers GL, Verwoerd CD. Management of infantile subglottic hemangioma: laser vaporization, submucous resection, intubation, or intralesional steroids?. Int J Pediatr Otorhinolaryngol. Dec. 10. 1997;42(2):179-86. X-3, X-4. [pmid: 9692627].
1197 Horigome H, Hamada H, Sohda S, et al. Large placental chorioangiomas as a cause of cardiac failure in two fetuses. Fetal Diagn Ther. Jul–Aug. 1997;12(4):241-3. X-1. [pmid: 9354885].
1198 Huang JS, Chen CC, Wu YM, et al. Periodontal manifestations and treatment of Sturge-Weber syndrome--report of two cases. Kaohsiung J Med Sci. Feb. 1997;13(2):127-35. X-1. [pmid: 9099052].
1199 Huang MH, Cohen SR, Burstein FD, et al. Endoscopic pediatric plastic surgery. Ann Plast Surg. Jan. 1997;38(1):1-8. X-1. [pmid: 9015531].
1200 Humpl T, Bruhl K, Bohl J, et al. Cerebral haemorrhage in long-term survivors of childhood acute lymphoblastic leukaemia. Eur J Pediatr. May. 1997;156(5):367-70. X-1. [pmid: 9177978].
1201 Hundt C, Auberger K, Munch G, et al. Brain hemangiomas of infancy. Sonographic detection and follow-up. J Neuroimaging. Apr. 1997;7(2):81-5. X-2. [pmid: 9128444].
1202 Inoue Y, Ohtake T, Wakita S, et al. Flow characteristics of soft-tissue vascular anomalies evaluated by direct puncture scintigraphy. Eur J Nucl Med. May. 1997;24(5):505-10. X-1. [pmid: 9142730].
1203 Iplikcioglu AC, Yaradanakul V, Trakya U. Supratentorial haemangioblastoma: appearances on MR imaging. Br J Neurosurg. Dec. 1997;11(6):576-8. X-1. [pmid: 11013633].
1204 Itosaka H, Tada M, Sawamura Y, et al. Vanishing tumor of the temporalis muscle: repeated hemorrhage in an intramuscular venous hemangioma. AJNR Am J Neuroradiol. May. 1997;18(5):983-5. X-1. [pmid: 9159382].
1205 Jayakumar PN, Vasudev MK, Srikanth SG. Symptomatic vertebral haemangioma: endovascular treatment of 12 patients. Spinal Cord. Sep. 1997;35(9):624-8. X-1. [pmid: 9300972].
1206 Kai Y, Kuratsu J, Suginohara K, et al. Cerebellar mutism after posterior fossa surgery--two case reports. Neurol Med Chir (Tokyo). Dec. 1997;37(12):929-33. X-1. [pmid: 9465594].
1207 Kakkar N, Vasishta RK, Banerjee AK, et al. Pulmonary capillary haemangiomatosis as a cause of pulmonary hypertension in Takayasu’s aortoarteritis. Respiration. 1997;64(5):381-3. X-1. [pmid: 9311057].
1208 Kane JW, Page-Salyards W, Perry CR. Congenital hepatic hemangioma in the neonate. MCN Am J Matern Child Nurs. Jul–Aug. 1997;22(4):187-93. X-2. [pmid: 9234606].
1209 Kaplan DL. Dermclinic. Cutaneous conundrums, dermatologic disguises. Consultant. 1997;37(5):1206-8. 18. 20. passim. PMID: X-1.
1210 Karasawa H, Furuya H, Naito H, et al. Acute hydrocephalus in posterior fossa injury. J Neurosurg. Apr. 1997;86(4):629-32. X-1. [pmid: 9120626].
1211 Karlsson P, Holmberg E, Lundberg LM, et al. Intracranial tumors after radium treatment for skin hemangioma during infancy--a cohort and case-control study. Radiat Res. Aug. 1997;148(2):161-7. X-1. [pmid: 9254735].
1212 Kempinaire A, De Raeve L, Roseeuw D, et al. Capillary-venous malformation in the labia majora in a 12-year-old girl. Dermatology. 1997;194(4):405-7. X-1. [pmid: 9252777].
1213 Kullendorff CM. Efficacy of bleomycin treatment for symptomatic hemangiomas in children. Pediatr Surg Int. Sep. 1997;12(7):526-8. X-1, X-2. [pmid: 9238123].
1214 Liang MG, Frieden IJ. Perineal and lip ulcerations as the presenting manifestation of hemangioma of infancy. Pediatrics. Feb. 1997;99(2):256-9. X-2. [pmid: 9024458].
1215 Maggi G, Aliberti F, Ruggiero C, et al. Cerebral cavernous angiomas in critical areas. Reports of three cases in children. J Neurosurg Sci. Dec. 1997;41(4):353-7. X-1. [pmid: 9555643].
1216 Matsui T, Ono T, Kito M, et al. Extensive facial strawberry mark associated with cerebellar hypoplasia and vascular abnormalities. J Dermatol. Feb. 1997;24(2):113-6. X-1, X-2. [pmid: 9065707].
1217 Mendel T, Louis DS. Major vascular malformations of the upper extremity: long-term observation. J Hand Surg Am. Mar. 1997;22(2):302-6. X-1. [pmid: 9195430].
1218 Mendivil A, Cuartero V. Radiological case of the month. Choroidal hemangioma. Arch Pediatr Adolesc Med. Dec. 1997;151(12):1261-2. X-1. [pmid: 9412605].
1219 Mitsuhashi N, Furuta M, Sakurai H, et al. Outcome of radiation therapy for patients with Kasabach-Merritt syndrome. Int J Radiat Oncol Biol Phys. Sep. 1. 1997;39(2):467-73. X-1. [pmid: 9308952].
1220 Mor Y, Hitchcock RJ, Zaidi SZ, et al. Bladder hemangioma as a cause of massive hematuria in a child. A case report and literature review. Scand J Urol Nephrol. Jun. 1997;31(3):305-7. X-1. [pmid: 9249900].
1221 Nako Y, Fukushima N, Igarashi T, et al. Successful interferon therapy in a neonate with life-threatening Kasabach-Merritt syndrome. J Perinatol. May–Jun. 1997;17(3):244-7. X-1. [pmid: 9210084].
1222 Neumann D, Isenberg SJ, Rosenbaum AL, et al. Ultrasonographically guided injection of corticosteroids for the treatment of retroseptal capillary hemangiomas in infants. J aapos. Mar. 1997;1(1):34-40. X-2. [pmid: 10530983].
1223 Novelli PM, Reigel DH, Langham Gleason P, et al. Multiple cavernous angiomas after high-dose whole-brain radiation therapy. Pediatr Neurosurg. Jun. 1997;26(6):322-5. X-1. [pmid: 9485161].
1224 O’Donovan JC, Donaldson JS, Morello FP, et al. Symptomatic hemangiomas and venous malformations in infants, children, and young adults: treatment with percutaneous injection of sodium tetradecyl sulfate. AJR Am J Roentgenol. Sep. 1997;169(3):723-9. X-1. [pmid: 9275886].
1225 Ogata N, Yonekawa Y. Paramedian supracerebellar approach to the upper brain stem and peduncular lesions. Neurosurgery. Jan. 1997;40(1):101-4. discussion 4–5. X-1. [pmid: 8971831].
1226 Okudaira Y, Arai H, Sato K. Hemodynamic compromise as a factor in clinical progression of Sturge-Weber syndrome. Childs Nerv Syst. Apr. 1997;13(4):214-9. X-1. [pmid: 9202857].
1227 Orlow SJ, Isakoff MS, Blei F. Increased risk of symptomatic hemangiomas of the airway in association with cutaneous hemangiomas in a “beard” distribution. J Pediatr. Oct. 1997;131(4):643-6. X-3, X-4. [pmid: 9386676].
1228 Paley MR, Farrant P, Kane P, et al. Developmental intrahepatic shunts of childhood: radiological features and management. Eur Radiol. 1997;7(9):1377-82. X-1. [pmid: 9369502].
1229 Pant B, Sumida M, Kurisu K, et al. Usefulness of two-dimensional time-of-flight MR angiography combined with surface anatomy scanning for convexity lesions. Neurosurg Rev. 1997;20(2):108-13. X-1, X-2. [pmid: 9226669].
1230 Patel SD, Cohen BA, Kan JS. Extensive facial hemangioma associated with cardiac and abdominal anomalies. J Am Acad Dermatol. Apr. 1997;36(4):636-8. X-2. [pmid: 9092757].
1231 Plager DA, Snyder SK. Resolution of astigmatism after surgical resection of capillary hemangiomas in infants. Ophthalmology. Jul. 1997;104(7):1102-6. X-2. [pmid: 9224460].
1232 Polymeropoulos MH, Hurko O, Hsu F, et al. Linkage of the locus for cerebral cavernous hemangiomas to human chromosome 7q in four families of Mexican-American descent. Neurology. Mar. 1997;48(3):752-7. X-1. [pmid: 9065560].
1233 Sarihan H, Mocan H, Yildiz K, et al. A new treatment with bleomycin for complicated cutaneous hemangioma in children. Eur J Pediatr Surg. Jun. 1997;7(3):158-62. X-4. [pmid: 9241503].
1234 Sarkar M, Mulliken JB, Kozakewich HP, et al. Thrombocytopenic coagulopathy (Kasabach-Merritt phenomenon) is associated with Kaposiform hemangioendothelioma and not with common infantile hemangioma. Plast Reconstr Surg. Nov. 1997;100(6):1377-86. X-1. [pmid: 9385948].
1235 Sato M, Tanaka N, Sato T, et al. Oral and maxillofacial tumours in children: a review. Br J Oral Maxillofac Surg. Apr. 1997;35(2):92-5. X-3, X-4. [pmid: 9146865].
1236 Schiebe ME, Hoffmann W, Rebmann H, et al. Radiotherapy in the management of large childhood hemangiomas. European Journal of Pediatric Dermatology. 1997;7(3):159-62. X-2.
1237 Sherrington CA, Sim DK, Freezer NJ, et al. Subglottic haemangioma. Arch Dis Child. May. 1997;76(5):458-9. X-3, X-4. [pmid: 9196368].
1238 Slaughenhoupt BL, Van Savage J. The evaluation and treatment of prolonged hematuria in adolescents. J Ky Med Assoc. Aug. 1997;95(8):315-7. X-1. [pmid: 9291736].
1239 Smit LM, Halbertsma FJ. Cerebral cavernous hemangiomas in childhood. Clinical presentation and therapeutic considerations. Childs Nerv Syst. Oct. 1997;13(10):522-5. X-1. [pmid: 9403199].
1240 Sweet C, Silbergleit R, Mehta B. Primary intraosseous hemangioma of the orbit: CT and MR appearance. AJNR Am J Neuroradiol. Feb. 1997;18(2):379-81. X-1. [pmid: 9111679].
1241 Tam WH, Fung HY, Fung TY, et al. Intra-uterine growth retardation and transverse lie due to massive subchorionic thrombohematoma and overlying large subchorionic cyst. Acta Obstet Gynecol Scand. Apr. 1997;76(4):381-3. X-1. [pmid: 9174438].
1242 Tamayo L, Ortiz DM, Orozco-Covarrubias L, et al. Therapeutic efficacy of interferon alfa-2b in infants with life-threatening giant hemangiomas. Arch Dermatol. Dec. 1997;133(12):1567-71. X-4. [pmid: 9420543].
1243 Tammam AG, Lewis PD, Crockard HA. Cerebello-pontine angle epithelioid haemangioendothelioma in a 4-year-old boy. Childs Nerv Syst. Nov–Dec. 1997;13(11–12):648-50. X-1. [pmid: 9454988].
1244 Tanaka H, Patel U, Coniglio JU, et al. Solitary subglottic neurofibroma: MR findings. AJNR Am J Neuroradiol. Oct. 1997;18(9):1726-8. X-1. [pmid: 9367323].
1245 Uchida K, Takahashi A, Miyao N, et al. Juvenile hemangioma of the testis: analysis of expression of angiogenic factors. Urology. Feb. 1997;49(2):285-6. X-2. [pmid: 9037300].
1246 Uzzo RG, Bilsky M, Mininberg DT, et al. Laparoscopic surgery in children with ventriculoperitoneal shunts: effect of pneumoperitoneum on intracranial pressure--preliminary experience. Urology. May. 1997;49(5):753-7. X-1. [pmid: 9145983].
1247 Vanhooteghem O, Andre J, Bruderer P, et al. Tufted angioma, a particular form of angioma. Dermatology. 1997;194(4):402-4. X-1. [pmid: 9252776].
1248 Vargha-Khadem F, Carr LJ, Isaacs E, et al. Onset of speech after left hemispherectomy in a nine-year-old boy. Brain. Jan. 1997;120(Pt 1):159-82. X-1. [pmid: 9055805].
1249 Vining EP, Freeman JM, Pillas DJ, et al. Why would you remove half a brain? The outcome of 58 children after hemispherectomy-the Johns Hopkins experience: 1968 to 1996. Pediatrics. Aug. 1997;100(2 Pt 1):163-71. X-1. [pmid: 9240794].
1250 Wang LH, Tang JR, Teng RJ, et al. Hydrops fetalis due to placental chorioangioma: report of one case. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Mar–Apr. 1997;38(2):155-8. X-1. [pmid: 9151471].
1251 Wheeler HMD. Clinical issues in midwifery. Birthmarks, body image and their implications... this article is the first in a series of three. Br J Midwifery. 1997;5(5):272-6. PMID: X-1.
1252 Wilde G, Sjostrand J. A clinical study of radiation cataract formation in adult life following gamma irradiation of the lens in early childhood. Br J Ophthalmol. Apr. 1997;81(4):261-6. X-3, X-4. [pmid: 9215051].
1253 Williams JK, Hitner JB, Wood RJ. Unilateral cleft lip repair in the presence of a vermilion hemangioma. Plast Reconstr Surg. Jan. 1997;99(1):230-3. X-2. [pmid: 8982210].
1254 Woltering MC, Robben S, Egeler RM. Hepatic hemangioendothelioma of infancy: treatment with interferon alpha. J Pediatr Gastroenterol Nutr. Mar. 1997;24(3):348-51. X-1. [pmid: 9138183].
1255 Yanai S, Tsutsumi H, Hotsubo T, et al. Development of a testicular haemangioma after interferon therapy for hepatic haemangiomas: a case report. Eur J Pediatr. Oct. 1997;156(10):784-6. X-2. [pmid: 9365068].
1256 Zamorano L, Matter A, Saenz A, et al. Interactive image-guided resection of cerebral cavernous malformations. Comput Aided Surg. 1997;2(6):327-32. X-1. [pmid: 9587694].
1257 Photoclinic. Consultant. 1998;38(10):2544-7. 51. 2. 54. 5. passim. PMID: X-1.
1258 Achauer BM, Celikoz B, VanderKam VM. Intralesional bare fiber laser treatment of hemangioma of infancy. Plast Reconstr Surg. Apr. 1998;101(5):1212-7. X-4. [pmid: 9529203].
1259 Albano G, Pugliese A, Stabile M, et al. Hydrops foetalis caused by hepatic haemangioma. Acta Paediatr. Dec. 1998;87(12):1307-9. X-1. [pmid: 9894836].
1260 Anger J, Carneiro RG, Pinus J, et al. The rebound effect in the treatment of complex hemangioma with interferon alpha 2A. Sao Paulo Med J. Sep–Oct. 1998;116(5):1826-8. X-1, X-2. [pmid: 10030110].
1261 Ankrett V. Picture quiz: skin lesion. Practice Nurse. 1998;15(2):106. PMID: X-1.
1262 Arnaout MK, Pappo AS. Kaposiform hemangioendothelioma with associated Kasabach-Merritt phenomenon. J Pediatr. Dec. 1998;133(6):788. X-1. [pmid: 9842045].
1263 Atuk NO, Stolle C, Owen JA Jr, et al. Pheochromocytoma in von Hippel-Lindau disease: clinical presentation and mutation analysis in a large, multigenerational kindred. J Clin Endocrinol Metab. Jan. 1998;83(1):117-20. X-1. [pmid: 9435426].
1264 Bailey CM, Froehlich P, Hoeve HL. Management of subglottic haemangioma. J Laryngol Otol. Aug. 1998;112(8):765-8. X-2. [pmid: 9850319].
1265 Barlow CF, Priebe CJ, Mulliken JB, et al. Spastic diplegia as a complication of interferon Alfa-2a treatment of hemangiomas of infancy. J Pediatr. Mar. 1998;132(3 Pt 1):527-30. X-2. [pmid: 9544915].
1266 Beaubien ER, Ball NJ, Storwick GS. Kaposiform hemangioendothelioma: a locally aggressive vascular tumor. J Am Acad Dermatol. May. 1998;38(5 Pt 2):799-802. X-1. [pmid: 9591789].
1267 Bidzinski J, Marchel A. Lesionectomy in surgical treatment of epilepsy. Neurol Neurochir Pol. 1998;32(Suppl 2):69-79. X-1. [pmid: 9757433].
1268 Bonduel M, Sciuccati G, Torres AF, et al. Familial idiopathic myelofibrosis and multiple hemangiomas. Am J Hematol. Oct. 1998;59(2):175-7. X-1. [pmid: 9766805].
1269 Boriani S, Biagini R, De Iure F, et al. Resection surgery in the treatment of vertebral tumors. Chir Organi Mov. Jan–Jun. 1998;83(1–2):53-64. X-1. [pmid: 9718815].
1270 Brodwater BK, Queiroz R. Young male patient with atypical chest pain and cardiac mass on chest radiograph: case from A3CR2 film panel. Acad Radiol. Jan. 1998;5(1):69-71. X-1. [pmid: 9442211].
1271 Burrows PE, Robertson RL, Mulliken JB, et al. Cerebral vasculopathy and neurologic sequelae in infants with cervicofacial hemangioma: report of eight patients. Radiology. Jun. 1998;207(3):601-7. X-1, X-2. [pmid: 9609880].
1272 Carruthers J, Jevon G, Prendiville J. Localized dystrophic periocular calcification: a complication of intralesional corticosteroid therapy for infantile periocular hemangiomas. Pediatr Dermatol. Jan–Feb. 1998;15(1):23-6. X-2. [pmid: 9496798].
1273 Chang CJ, Anvari B, Nelson JS. Cryogen spray cooling for spatially selective photocoagulation of hemangiomas: a new methodology with preliminary clinical reports. Plast Reconstr Surg. Aug. 1998;102(2):459-63. X-2. [pmid: 9703086].
1274 Chaskis C, Brotchi J. The surgical management of cerebral cavernous angiomas. Neurol Res. Oct. 1998;20(7):597-606. X-1. [pmid: 9785587].
1275 Chatrath P, Pfleiderer AG, Blundell JW. A rare case of intramuscular haemangioma in a six-year-old boy--a diagnostic dilemma. J Laryngol Otol. Dec. 1998;112(12):1181-2. X-1, X-2. [pmid: 10209617].
1276 Cholewa D, Waldschmidt J. Laser treatment of hemangiomas of the larynx and trachea. Lasers Surg Med. 1998;23(4):221-32. X-1. [pmid: 9829433].
1277 Clymer MA, Fortune DS, Reinisch L, et al. Interstitial Nd:YAG photocoagulation for vascular malformations and hemangiomas in childhood. Arch Otolaryngol Head Neck Surg. Apr. 1998;124(4):431-6. X-1. [pmid: 9559692].
1278 Coley SC, Britton J, Clarke A. Status epilepticus and venous infarction in Sturge-Weber syndrome. Childs Nerv Syst. Dec. 1998;14(12):693-6. X-1. [pmid: 9881620].
1279 Cremer H. Cryosurgery for hemangiomas. Pediatr Dermatol. Sep–Oct. 1998;15(5):410-1. X-3, X-4. [pmid: 9796600].
1280 de-Medeiros BC, Strapasson E, Pasquini R, et al. Effect of all-trans retinoic acid on newly diagnosed acute promyelocytic leukemia patients: results of a Brazilian center. Braz J Med Biol Res. Dec. 1998;31(12):1537-43. X-1. [pmid: 9951549].
1281 Dubois J, Garel L, Grignon A, et al. Imaging of hemangiomas and vascular malformations in children. Acad Radiol. May. 1998;5(5):390-400. X-1, X-2. [pmid: 9597107].
1282 Dummer R, Graf P, Greif C, et al. Treatment of vascular lesions using the VersaPulse variable pulse width frequency doubled neodymium:YAG laser. Dermatology. 1998;197(2):158-61. X-1. [pmid: 9732166].
1283 Eggert P, Muller D, Schroter T. Nephrocalcinosis in three siblings with idiopathic hypercalciuria. Pediatr Nephrol. Feb. 1998;12(2):144-6. X-1. [pmid: 9543376].
1284 Fard AK, Traboulsi EI. Coloboma of the lens, optic nerve hypoplasia, and orbital hemangioma--a possible developmental field defect. Ophthalmic Genet. Dec. 1998;19(4):209-12. X-1. [pmid: 9895246].
1285 Fishman SJ, Burrows PE, Leichtner AM, et al. Gastrointestinal manifestations of vascular anomalies in childhood: varied etiologies require multiple therapeutic modalities. J Pediatr Surg. Jul. 1998;33(7):1163-7. X-2. [pmid: 9694115].
1286 Fitzgerald JF, Troncone R, Caprai S, et al. Clinical quiz. Infantile haemangioendothelioma. J Pediatr Gastroenterol Nutr. Jul. 1998;27(1):85. 113. X-1. [pmid: 9669731].
1287 Forte V, Triglia JM, Zalzal G. Hemangioma. Head Neck. Jan. 1998;20(1):69-72. X-2. [pmid: 9464955].
1288 Fukui M, Matsushima T, Ikezaki K, et al. Surgery of angiomas in the brainstem with a stress on the presence of telangiectasia. Neurol Med Chir (Tokyo). 1998;38(Suppl):250-4. X-1. [pmid: 10235014].
1289 Gaab MR, Schroeder HW. Neuroendoscopic approach to intraventricular lesions. J Neurosurg. Mar. 1998;88(3):496-505. X-1. [pmid: 9488304].
1290 Giannini C, Scheithauer BW, Hellbusch LC, et al. Peripheral nerve hemangioblastoma. Mod Pathol. Oct. 1998;11(10):999-1004. X-1. [pmid: 9796730].
1291 Grieve JP, Wilkins PR, Marsh HT. Neurenteric sinus dorsal to the thoracic spine with an associated cutaneous haemangioma: case report. Br J Neurosurg. Jun. 1998;12(3):259-63. X-1, X-2. [pmid: 11013691].
1292 Haga N, Nakamura K, Taniguchi K, et al. Enchondromatosis with features of dysspondyloenchondromatosis and Maffucci syndrome. Clin Dysmorphol. Jan. 1998;7(1):65-8. X-1. [pmid: 9546836].
1293 Han SJ, Tsai CC, Tsai HM, et al. Infantile hemangioendothelioma with a highly elevated serum alpha-fetoprotein level. Hepatogastroenterology. Mar–Apr. 1998;45(20):459-61. X-1. [pmid: 9638427].
1294 Haramoto U, Yamada A, Kobayashi S, et al. Quarter vermillion flap: a method for symmetrical lower vermillion reconstruction. Plast Reconstr Surg. Apr. 1998;101(5):1334-7. X-1. [pmid: 9529221].
1295 Hart YM, Andermann F, Robitaille Y, et al. Double pathology in Rasmussen’s syndrome: a window on the etiology?. Neurology. Mar. 1998;50(3):731-5. X-1. [pmid: 9521265].
1296 Hassan E, Giannakopoulou C, Stefanaki K, et al. Congenital capillary hemangioma and its therapeutic approach in infants: a case report. J Dermatol. Oct. 1998;25(10):673-6. X-1. [pmid: 9830268].
1297 Hata D, Isu T, Nakanishi M, et al. Intraoperative electrocorticography and successful focus resection in a case of Sturge-Weber syndrome. Seizure. Dec. 1998;7(6):505-8. X-1. [pmid: 9888497].
1298 Hiraiwa H, Hamazaki M, Tsuruta S, et al. Infantile hemangioendothelioma of the thymus with massive pleural effusion and Kasabach--Merritt syndrome: histopathological, flow cytometrical analysis of the tumor. Acta Paediatr Jpn. Dec. 1998;40(6):604-7. X-1. [pmid: 9893299].
1299 Holmstrom G, Taylor D. Capillary haemangiomas in association with morning glory disc anomaly. Acta Ophthalmol Scand. Oct. 1998;76(5):613-6. X-1, X-3. [pmid: 9826051].
1300 Hu B, Lachman R, Phillips J, et al. Kasabach-Merritt syndrome-associated kaposiform hemangioendothelioma successfully treated with cyclophosphamide, vincristine, and actinomycin D. J Pediatr Hematol Oncol. Nov–Dec. 1998;20(6):567-9. X-1. [pmid: 9856681].
1301 Inskip PD, Mellemkjaer L, Gridley G, et al. Incidence of intracranial tumors following hospitalization for head injuries (Denmark). Cancer Causes Control. Jan. 1998;9(1):109-16. X-1. [pmid: 9486470].
1302 Jackson IT. Management of vascular and lymphovenous malformations. Gefasschirurgie. 1998;3(4):205-11. PMID: X-1, X-2.
1303 Jackson IT, Sosa J. Excision of nasal tip hemangioma via open rhinoplasty - A skin sparing technique. Eur J Plast Surg. June. 1998;21(5):265-8. X-2.
1304 Kallen B, Karlsson P, Lundell M, et al. Outcome of reproduction in women irradiated for skin hemangioma in infancy. Radiat Res. Feb. 1998;149(2):202-8. X-1, X-3. [pmid: 9457901].
1305 Kanai N, Saito K, Homma Y, et al. Infantile hemangioendothelioma of the liver associated with anomalous dilated and tortuous vessels on the placental surface. Pediatr Surg Int. Mar. 1998;13(2–3):175-6. X-1. [pmid: 9563039].
1306 Kaplan I, Mass E, Littner M. A study of small superficial capillary hemangiomas on the lips in children. Pediatr Dent. May–Jun. 1998;20(3):188-91. X-1. [pmid: 9635315].
1307 Karlsson P, Holmberg E, Lundell M, et al. Intracranial tumors after exposure to ionizing radiation during infancy: a pooled analysis of two Swedish cohorts of 28,008 infants with skin hemangioma. Radiat Res. Sep. 1998;150(3):357-64. X-1, X-3. [pmid: 9728664].
1308 Katz SE, Rootman J, Vangveeravong S, et al. Combined venous lymphatic malformations of the orbit (so-called lymphangiomas). Association with noncontiguous intracranial vascular anomalies. Ophthalmology. Jan. 1998;105(1):176-84. X-1. [pmid: 9442796].
1309 Koscick RL, Petersilge CA, Makley JT, et al. CT-guided fine needle aspiration and needle core biopsy of skeletal lesions. Complementary diagnostic techniques. Acta Cytol. May–Jun. 1998;42(3):697-702. X-1. [pmid: 9622690].
1310 Lawton MT, Raudzens PA, Zabramski JM, et al. Hypothermic circulatory arrest in neurovascular surgery: evolving indications and predictors of patient outcome. Neurosurgery. Jul. 1998;43(1):10-20. discussion -1. X-1. [pmid: 9657183].
1311 Leaute-Labreze C, Taieb A. Caution with regard to the efficacy of interferon alfa-2b in the treatment of giant hemangiomas. Arch Dermatol. Oct. 1998;134(10):1297-8. X-3, X-4. [pmid: 9801696].
1312 Lezama-del Valle P, Gerald WL, Tsai J, et al. Malignant vascular tumors in young patients. Cancer. Oct. 15. 1998;83(8):1634-9. X-1. [pmid: 9781959].
1313 Ligot L, Diallo I, Shamsaldin A, et al. Individualized phantom based on CT slices and auxological data (ICTA) for dose estimations following radiotherapy for skin haemangioma in childhood. Radiother Oncol. Dec. 1998;49(3):279-85. X-1. [pmid: 10075261].
1314 Maria BL, Neufeld JA, Rosainz LC, et al. High prevalence of bihemispheric structural and functional defects in Sturge-Weber syndrome. J Child Neurol. Dec. 1998;13(12):595-605. X-1. [pmid: 9881530].
1315 Maria BL, Neufeld JA, Rosainz LC, et al. Central nervous system structure and function in Sturge-Weber syndrome: evidence of neurologic and radiologic progression. J Child Neurol. Dec. 1998;13(12):606-18. X-1. [pmid: 9881531].
1316 Mariotti P, Iuvone L, Torrioli MG, et al. Linguistic and non-linguistic abilities in a patient with early left hemispherectomy. Neuropsychologia. Dec. 1998;36(12):1303-12. X-1. [pmid: 9863684].
1317 McLaughlin MR, Kondziolka D, Flickinger JC, et al. The prospective natural history of cerebral venous malformations. Neurosurgery. Aug. 1998;43(2):195-200. discussion -1. X-1. [pmid: 9696070].
1318 Mehdorn HM, Barth H, Buhl R, et al. Intracranial cavernomas: indications for and results of surgery. Neurol Med Chir (Tokyo). 1998;38(Suppl):245-9. X-1. [pmid: 10235013].
1319 Meis-Kindblom JM, Kindblom LG. Angiosarcoma of soft tissue: a study of 80 cases. Am J Surg Pathol. Jun. 1998;22(6):683-97. X-1. [pmid: 9630175].
1320 Miyazoe Y, Sawairi T, Ito K, et al. Development of the small caliber centrifugal blood pump. Artif Organs. Jun. 1998;22(6):461-5. X-1. [pmid: 9650666].
1321 Naidoo K, Bhigjee AI. Multiple cerebellar haemangioblastomas symptomatic during pregnancy. Br J Neurosurg. Jun. 1998;12(3):281-4. X-1. [pmid: 11013697].
1322 Norouzi BB, Shanberg AM. Laser treatment of large cavernous hemangiomas of the penis. J Urol. Jul. 1998;160(1):60-2. X-1. [pmid: 9628605].
1323 Olsen KE, Huang AS, Wright MM. The efficacy of goniotomy/trabeculotomy in early-onset glaucoma associated with the Sturge-Weber syndrome. J aapos. Dec. 1998;2(6):365-8. X-1. [pmid: 10532726].
1324 Ono H, Mawatari H, Mizoguchi N, et al. Clinical features and outcome of eight infants with intrahepatic porto-venous shunts detected in neonatal screening for galactosaemia. Acta Paediatr. Jun. 1998;87(6):631-4. X-1. [pmid: 9686654].
1325 Orr RJ, Elwood T. Special challenging problems in the difficult pediatric airway: lymphangioma, laryngeal papillomatosis, and subglottic hemangioma. Anesthesiol Clin North America. 1998;16(4):869-83. PMID: X-1, X-2.
1326 Patrizi A, Neri I, Marzaduri S, et al. Tumor of the right shoulder in a newborn. Bossed hemangioma with telangiectasia and peripheral pallor. Arch Dermatol. Sep. 8. 1998;134(9):1146-9. X-1. [pmid: 9762030].
1327 Pittet B, Montandon D. Nasal reconstruction in children: a review of 29 patients. J Craniofac Surg. Nov. 1998;9(6):522-8. X-1. [pmid: 10029764].
1328 Platokouki H, Aronis S, Mitsika A, et al. Diffuse splenic and visceral hemangiomas complicated by chronic consumption coagulopathy. Acta Paediatr Jpn. Aug. 1998;40(4):381-4. X-1. [pmid: 9745787].
1329 Ricci RM, Finley EM, Grimwood RE. Treatment of cutaneous hemangiomas in preterm neonatal twins with the flashlamp-pumped pulsed dye laser. Lasers Surg Med. 1998;22(1):10-3. X-2. [pmid: 9443144].
1330 Rodriguez CD. What is your assessment? Capillary hemangioma. Pediatr Nurs. Mar–Apr. 1998;24(2):174-5. X-1, X-2. [pmid: 9697572].
1331 Rokitansky AM, Jakl RJ, Gopfrich H, et al. Special compression sutures: a new surgical technique to achieve a quick decrease in shunt volume caused by diffuse hemangiomatosis of the liver. Pediatr Surg Int. Nov. 1998;14(1–2):119-21. X-1, X-2. [pmid: 9880718].
1332 Sakaguchi M, Sue K, Etoh G, et al. A case of solitary cavernous hemangioma of the small intestine with recurrent clinical anemic attacks in childhood. J Pediatr Gastroenterol Nutr. Sep. 1998;27(3):342-3. X-1. [pmid: 9740209].
1333 Salman MS. Is the prophylactic use of antiepileptic drugs in Sturge-Weber syndrome justified?. Med Hypotheses. Oct. 1998;51(4):293-6. X-1. [pmid: 9824833].
1334 Sarihan H, Mocan H, Abeys M, et al. Kasabach-Merrit syndrome in infants. Panminerva Med. Jun. 1998;40(2):128-31. X-1. [pmid: 9689834].
1335 Scafidi DE, McLeary MS, Young LW. Diffuse neonatal gastrointestinal hemangiomatosis: CT findings. Pediatr Radiol. Jul. 1998;28(7):512-4. X-1, X-2. [pmid: 9662569].
1336 Sgonc R, Fuerhapter C, Boeck G, et al. Induction of apoptosis in human dermal microvascular endothelial cells and infantile hemangiomas by interferon-alpha. Int Arch Allergy Immunol. Nov. 1998;117(3):209-14. X-1, X-2. [pmid: 9831809].
1337 Sung MS, Kang HS, Lee HG. Regional bone changes in deep soft tissue hemangiomas: radiographic and MR features. Skeletal Radiol. Apr. 1998;27(4):205-10. X-1. [pmid: 9592903].
1338 Svatek M, Stevens S, Ment LR. Caudal appendage in a full-term infant. Curr Opin Pediatr. Dec. 1998;10(6):635-9. X-1. [pmid: 9848025].
1339 Tryfonas GI, Tsikopoulos G, Liasidou E, et al. Conservative treatment of hemangiomas in infancy and childhood with interferon-alpha 2a. Pediatr Surg Int. Oct. 1998;13(8):590-3. X-3, X-4. [pmid: 9799383].
1340 Vanderhooft SL, Doidge WW, Maughan T. Flashlamp-pumped pulsed dye laser treatment of vascular birthmarks. Aorn j. Jun. 1998;67(6):1214-23. quiz 24, 26, 29–30. X-1, X-2. [pmid: 9629455].
1341 Wacker FK, Cholewa D, Roggan A, et al. Vascular lesions in children: percutaneous MR imaging-guided interstitial Nd:YAG laser therapy--preliminary experience. Radiology. Sep. 1998;208(3):789-94. X-1. [pmid: 9722861].
1342 Webster AR, Richards FM, MacRonald FE, et al. An analysis of phenotypic variation in the familial cancer syndrome von Hippel-Lindau disease: evidence for modifier effects. Am J Hum Genet. Oct. 1998;63(4):1025-35. X-1. [pmid: 9758595].
1343 Werner JA, Lippert BM, Gottschlich S, et al. Ultrasound-guided interstitial Nd: YAG laser treatment of voluminous hemangiomas and vascular malformations in 92 patients. Laryngoscope. Apr. 1998;108(4 Pt 1):463-70. X-3. [pmid: 9546253].
1344 Yang CB, Freedman SF, Myers JS, et al. Use of latanoprost in the treatment of glaucoma associated with Sturge-Weber syndrome. Am J Ophthalmol. Oct. 1998;126(4):600-2. X-1. [pmid: 9780111].
1345 Yang YH, Lee PI, Lin KH, et al. Absolute ethanol embolotherapy for hemangioma with Kasabach-Merritt syndrome. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Jan–Feb. 1998;39(1):51-4. X-1, X-2. [pmid: 9553294].
1346 Yoon PH, Kim DI, Jeon P, et al. Cerebral cavernous malformations: serial magnetic resonance imaging findings in patients with and without gamma knife surgery. Neurol Med Chir (Tokyo). 1998;38(Suppl):255-61. X-1. [pmid: 10235015].
1347 Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 35-1999. A five-month-old girl with coffee-grounds vomitus. N Engl J Med. Nov. 18. 1999;341(21):1597-603. X-1. [pmid: 10564691].
1348 Abdulrauf SI, Kaynar MY, Awad IA. A comparison of the clinical profile of cavernous malformations with and without associated venous malformations. Neurosurgery. Jan. 1999;44(1):41-6. discussion 6–7. X-1. [pmid: 9894962].
1349 Achauer BM, Chang CJ, VanderKam VM, et al. Intralesional photocoagulation of periorbital hemangiomas. Plast Reconstr Surg. Jan. 1999;103(1):11-6. discussion 7–9. X-4. [pmid: 9915158].
1350 Aldave AJ, Shields CL, Shields JA. Surgical excision of selected amblyogenic periorbital capillary hemangiomas. Ophthalmic Surg Lasers. Nov–Dec. 1999;30(9):754-7. X-2. [pmid: 10574498].
1351 Altuna JC, Greenfield DS, Wand M, et al. Latanoprost in glaucoma associated with Sturge-Weber syndrome: benefits and side-effects. J Glaucoma. Jun. 1999;8(3):199-203. X-1. [pmid: 10376261].
1352 Altunay IK, Gokdemir G, Koken R, et al. An infant with multiple hemangiomas showing favorable prognosis. Int J Dermatol. Mar. 1999;38(3):211-3. X-1, X-2. [pmid: 10208620].
1353 Angermeier MC. Treatment of facial vascular lesions with intense pulsed light. J Cutan Laser Ther. Apr. 1999;1(2):95-100. X-1. [pmid: 11357295].
1354 Auriemma A, Bellan C, Poggiani C, et al. Imaging of neonatal hemangiomas, two cases. Eur J Ultrasound. May. 1999;9(2):161-5. X-1, X-2. [pmid: 10413752].
1355 Awad AH, Mullaney PB, Al-Mesfer S, et al. Glaucoma in Sturge-Weber syndrome. J aapos. Feb. 1999;3(1):40-5. X-1. [pmid: 10071900].
1356 Aylett SE, Neville BG, Cross JH, et al. Sturge-Weber syndrome: cerebral haemodynamics during seizure activity. Dev Med Child Neurol. Jul. 1999;41(7):480-5. X-1. [pmid: 10454232].
1357 Basu S, Singhal U, Mohan H. Fine needle aspiration of angiomatoid malignant fibrous histiocytoma. A case report. Acta Cytol. Sep–Oct. 1999;43(5):859-61. X-1. [pmid: 10518144].
1358 Bemporad JA, Sze G, Chaloupka JC, et al. Pseudohemangioma of the vertebra: an unusual radiographic manifestation of primary Ewing’s sarcoma. AJNR Am J Neuroradiol. Nov–Dec. 1999;20(10):1809-13. X-1. [pmid: 10588101].
1359 Bhandarkar PV, Sreenivasa D, Mistry FP, et al. Profile of extrahepatic portal venous obstruction in Mumbai. J Assoc Physicians India. Aug. 1999;47(8):791-4. X-1. [pmid: 10778624].
1360 Bouchard S, Yazbeck S, Lallier M. Perineal hemangioma, anorectal malformation, and genital anomaly: a new association?. J Pediatr Surg. Jul. 1999;34(7):1133-5. X-2. [pmid: 10442608].
1361 Brant AJ, James HE, Tung H. Cutaneomeningospinal angiomatosis (Cobb syndrome) with tethered cord. Pediatr Neurosurg. Feb. 1999;30(2):93-5. X-1, X-2. [pmid: 10325565].
1362 Castellote A, Vazquez E, Vera J, et al. Cervicothoracic lesions in infants and children. Radiographics. May–Jun. 1999;19(3):583-600. X-1. [pmid: 10336190].
1363 Catsman-Berrevoets CE, Van Dongen HR, Mulder PG, et al. Tumour type and size are high risk factors for the syndrome of “cerebellar” mutism and subsequent dysarthria. J Neurol Neurosurg Psychiatry. Dec. 1999;67(6):755-7. X-1. [pmid: 10567492].
1364 Ceyhan A, Cakan T, Basar H, et al. Anaesthesia for Sturge-Weber syndrome. Eur J Anaesthesiol. May. 1999;16(5):339-41. X-1. [pmid: 10390670].
1365 Chang CJ, Fisher DM, Chen YR. Intralesional photocoagulation of vascular anomalies of the tongue. Br J Plast Surg. Apr. 1999;52(3):178-81. X-2. [pmid: 10474467].
1366 Chang J, Most D, Bresnick S, et al. Proliferative hemangiomas: analysis of cytokine gene expression and angiogenesis. Plast Reconstr Surg. Jan. 1999;103(1):1-9. discussion 10. X-1, X-3. [pmid: 9915157].
1367 Chien HY, Sung TC. Aneurysm of the ascending aorta in a neonate. Acta Paediatr Taiwan. Mar–Apr. 1999;40(2):121-3. X-1. [pmid: 10910601].
1368 Daller JA, Bueno J, Gutierrez J, et al. Hepatic hemangioendothelioma: clinical experience and management strategy. J Pediatr Surg. Jan. 1999;34(1):98-105. discussion -6. X-1. [pmid: 10022152].
1369 Deb G, Jenkner A, Donfrancesco A. Spastic diplegia and interferon. J Pediatr. Mar. 1999;134(3):382. X-1. [pmid: 10064684].
1370 Devulapalli CS. Index of suspicion. Case 1. Chronic autoimmune hepatitis. Pediatr Rev. Aug. 1999;20(8):273. discussion 4. X-1. [pmid: 10429147].
1371 Di Landro A, Tadini GL, Marchesi L, et al. Phakomatosis pigmentovascularis: A new case with renal angiomas and some considerations about the classification. Pediatr Dermatol. Jan–Feb. 1999;16(1):25-30. X-1. [pmid: 10027995].
1372 Drolet BA, Esterly NB, Frieden IJ. Hemangiomas in children. N Engl J Med. Jul. 15. 1999;341(3):173-81. X-1, X-2. [pmid: 10403856].
1373 Dubois J, Hershon L, Carmant L, et al. Toxicity profile of interferon alfa-2b in children: A prospective evaluation. J Pediatr. Dec. 1999;135(6):782-5. X-3. [pmid: 10586188].
1374 Eckstein FS, Heinemann MK, Mielke GJ, et al. Resection of a large right atrial hemangioma in a neonate after prenatal diagnosis. Ann Thorac Surg. Sep. 1999;68(3):1074-5. X-1. [pmid: 10510016].
1375 Eisenberg MB, Al-Mefty O, DeMonte F, et al. Benign nonmeningeal tumors of the cavernous sinus. Neurosurgery. May. 1999;44(5):949-54. discussion 54–5. X-1. [pmid: 10232527].
1376 El-Hakim IE, El-Khashab MM. Cavernous haemangioma of the submandibular salivary gland. Int J Oral Maxillofac Surg. Feb. 1999;28(1):58-9. X-1. [pmid: 10065653].
1377 Fisher MD, Bridges M, Lin KY. The use of ultrasound-assisted liposuction in the treatment of an involuted hemangioma. J Craniofac Surg. Nov. 1999;10(6):500-2. X-1, X-2. [pmid: 10726503].
1378 Fong M, Clarke K, Cron C. Clinical applications of the holmium:YAG laser in disorders of the paediatric airway. J Otolaryngol. Dec. 1999;28(6):337-43. X-1, X-2. [pmid: 10604163].
1379 Freeman AI, Lossos A, Gomori JM, et al. Interferon in the treatment of base of the skull hemangioendothelioma. Otolaryngol Head Neck Surg. Dec. 1999;121(6):842-3. X-1. [pmid: 10580254].
1380 Frim DM, Scott RM. Management of cavernous malformations in the pediatric population. Neurosurg Clin N Am. Jul. 1999;10(3):513-8. X-1. [pmid: 10419575].
1381 Glasker S, Bender BU, Apel TW, et al. The impact of molecular genetic analysis of the VHL gene in patients with haemangioblastomas of the central nervous system. J Neurol Neurosurg Psychiatry. Dec. 1999;67(6):758-62. X-1. [pmid: 10567493].
1382 Greinwald JH Jr, Burke DK, Bonthius DJ, et al. An update on the treatment of hemangiomas in children with interferon alfa-2a. Arch Otolaryngol Head Neck Surg. Jan. 1999;125(1):21-7. X-4. [pmid: 9932582].
1383 Guillou L, Calonje E, Speight P, et al. Hobnail hemangioma: a pseudomalignant vascular lesion with a reappraisal of targetoid hemosiderotic hemangioma. Am J Surg Pathol. Jan. 1999;23(1):97-105. X-1, X-2. [pmid: 9888709].
1384 Haak MC, Oosterhof H, Mouw RJ, et al. Pathophysiology and treatment of fetal anemia due to placental chorioangioma. Ultrasound Obstet Gynecol. Jul. 1999;14(1):68-70. X-1. [pmid: 10461342].
1385 Haasbeek JF, Alvillar RE. Childhood lipoma arborescens presenting as bilateral suprapatellar masses. J Rheumatol. Mar. 1999;26(3):683-6. X-1. [pmid: 10090182].
1386 Hamush NG, Coleman AL, Wilson MR. Ahmed glaucoma valve implant for management of glaucoma in Sturge-Weber syndrome. Am J Ophthalmol. Dec. 1999;128(6):758-60. X-1. [pmid: 10612515].
1387 Herman TE, McAlister WH, Dehner LP. Posterior mediastinal capillary hemangioma with extradural extension resembling neuroblastoma. Pediatr Radiol. Jul. 1999;29(7):517-9. X-2. [pmid: 10398787].
1388 Horie Y, Kato M. Juvenile hemangioma (infantile hemangioendothelioma) of the parotid gland associated with cytomegalovirus infection. Pathol Int. Jul. 1999;49(7):668-71. X-1, X-2. [pmid: 10504531].
1389 Hosono S, Ohno T, Kimoto H, et al. Successful transcutaneous arterial embolization of a giant hemangioma associated with high-output cardiac failure and Kasabach-Merritt syndrome in a neonate: a case report. J Perinat Med. 1999;27(5):399-403. X-1. [pmid: 10642962].
1390 Hughes CA, Rezaee A, Ludemann JP, et al. Management of congenital subglottic hemangioma. J Otolaryngol. Aug. 1999;28(4):223-8. X-4. [pmid: 10461260].
1391 Irkec M, Kiratli H, Bilgic S. Results of trabeculotomy and guarded filtration procedure for glaucoma associated with Sturge-Weber syndrome. Eur J Ophthalmol. Apr–Jun. 1999;9(2):99-102. X-1. [pmid: 10435421].
1392 Kaban LB, Mulliken JB, Ezekowitz RA, et al. Antiangiogenic therapy of a recurrent giant cell tumor of the mandible with interferon alfa-2a. Pediatrics. Jun. 1999;103(6 Pt 1):1145-9. X-1. [pmid: 10353921].
1393 Kim MS, Lee SI, Sim SH. Brain tumors with cysts treated with Gamma Knife radiosurgery: is microsurgery indicated?. Stereotact Funct Neurosurg. 1999;72(Suppl 1):38-44. X-1. [pmid: 10681689].
1394 Kiristioglu I, Kilic N, Gurpinar AN, et al. Aicardi syndrome associated with palatal hemangioma. Eur J Pediatr Surg. Oct. 1999;9(5):325-6. X-1. [pmid: 10584193].
1395 Kuo KT, Tsai TF, Hsiao CH. Diffuse neonatal hemangiomatosis complicated with cardiac tamponade: A case report. Tzu Chi Medical Journal. 1999;11(1):103-8. X-1.
1396 Lafaut BA, Meire FM, Leys AM, et al. Vasoproliferative retinal tumors associated with peripheral chorioretinal scars in presumed congenital toxoplasmosis. Graefes Arch Clin Exp Ophthalmol. Dec. 1999;237(12):1033-8. X-1. [pmid: 10654174].
1397 Leung AC, Kao CP. Photo essay: focus on signs and symptoms. Pediatric vascular lesions. Consultant. 1999;39(11):3110. PMID: X-1.
1398 Leung AKC, Kao CP. Pediatric vascular lesions. Consultant. 1999;39(11):3110. X-2.
1399 Liekens S, Verbeken E, Vandeputte M, et al. A novel animal model for hemangiomas: inhibition of hemangioma development by the angiogenesis inhibitor TNP-470. Cancer Res. May. 15. 1999;59(10):2376-83. X-1. [pmid: 10344747].
1400 Lopriore E, Markhorst DG. Diffuse neonatal haemangiomatosis: new views on diagnostic criteria and prognosis. Acta Paediatr. Jan. 1999;88(1):93-7. X-1. [pmid: 10090556].
1401 Lundell M, Mattsson A, Karlsson P, et al. Breast cancer risk after radiotherapy in infancy: a pooled analysis of two Swedish cohorts of 17,202 infants. Radiat Res. May. 1999;151(5):626-32. X-1, X-3. [pmid: 10319736].
1402 Makhlouf HR, Ishak KG, Goodman ZD. Epithelioid hemangioendothelioma of the liver: a clinicopathologic study of 137 cases. Cancer. Feb. 1. 1999;85(3):562-82. X-1. [pmid: 10091730].
1403 Makino Y, Horiuchi S, Sonoda M, et al. A case of large placental chorioangioma with non-immunological hydrops fetalis. J Perinat Med. 1999;27(2):128-31. X-1. [pmid: 10379503].
1404 Mandal AK. Primary combined trabeculotomy-trabeculectomy for early-onset glaucoma in Sturge-Weber syndrome. Ophthalmology. Aug. 1999;106(8):1621-7. X-1. [pmid: 10442913].
1405 Mandal AK. Sturge-Weber syndrome with bilateral congenital syndactyly: a previously undescribed association. Ophthalmic Surg Lasers. Mar. 1999;30(3):221-2. X-1. [pmid: 10100258].
1406 Matsumoto K, Hukuda S, Ishizawa M, et al. Partial rupture of the quadriceps tendon (jumper’s knee) in a ten-year-old boy. A case report. Am J Sports Med. Jul–Aug. 1999;27(4):521-5. X-1. [pmid: 10424225].
1407 Matturri L, Ottaviani G, Rossi L. Sudden and unexpected infant death due to an hemangioendothelioma located in the medulla oblongata. Adv Clin Path. Jan–Apr. 1999;3(1–2):29-33. X-1. [pmid: 10655571].
1408 McCarthy EF, Lietman S, Argani P, et al. Endovascular papillary angioendothelioma (Dabska tumor) of bone. Skeletal Radiol. Feb. 1999;28(2):100-3. X-1. [pmid: 10197456].
1409 Mohanty R, Gondal, Dash, et al. Diffuse cavernous haemangioma of the rectosigmoid with bladder involvement--a case report. Indian J Pathol Microbiol. Oct. 1999;42(4):487-9. X-1. [pmid: 11127383].
1410 Morris J, Abbott J, Burrows P, et al. Antenatal diagnosis of fetal hepatic hemangioma treated with maternal corticosteroids. Obstet Gynecol. Nov. 1999;94(5 Pt 2):813-5. X-1. [pmid: 10546738].
1411 Oda D. Case challenge. Pathological condition of a newborn child. J Contemp Dent Pract. Nov. 15. 1999;1(1):50-4. X-1. [pmid: 12167901].
1412 Paterson A, Frush DP, Donnelly LF, et al. A pattern-oriented approach to splenic imaging in infants and children. Radiographics. Nov–Dec. 1999;19(6):1465-85. X-1. [pmid: 10555669].
1413 Pohlen U, Kroesen AJ, Berger G, et al. Diagnostics and surgical treatment strategy for rectal cavernous hemangiomas based on three case examples. Int J Colorectal Dis. Dec. 1999;14(6):300-3. X-1. [pmid: 10663899].
1414 Pumberger W, Gindl K, Amann G, et al. Polypoid fibro-haemangioma of the kidney in a child with gross haematuria. Scand J Urol Nephrol. Oct. 1999;33(5):344-6. X-1. [pmid: 10573003].
1415 Ratan S, Bhatnagar V, Gupta SD, et al. Epithelioid hemangioendothelioma of the greater omentum: report of a case. Surg Today. 1999;29(9):919-21. X-1. [pmid: 10489137].
1416 Robinson HA, Keeton BR, Moore IE. Critical obstruction of the right ventricular outflow tract by a primary hemangioendothelioma in a seven month old. Cardiol Young. Mar. 1999;9(2):185-8. X-1. [pmid: 10323517].
1417 Sallee D, Spector ML, van Heeckeren DW, et al. Primary pediatric cardiac tumors: a 17 year experience. Cardiol Young. Mar. 1999;9(2):155-62. X-1. [pmid: 10323513].
1418 Schemmer DC, Goh RH, Maguire JA. Cavernous angioma: a cryptic CT and MRI presentation. Pediatr Radiol. Feb. 1999;29(2):146. X-1. [pmid: 9933338].
1419 Schlecht I, Hierholzer J, Maurer J, et al. Gastric haemangioma: a rare cause of gastrointestinal bleeding. Pediatr Radiol. Jan. 1999;29(1):63. X-1, X-2. [pmid: 9880621].
1420 Schulz AS, Urban J, Gessler P, et al. Anaemia, thrombocytopenia and coagulopathy due to occult diffuse infantile haemangiomatosis of spleen and pancreas. Eur J Pediatr. May. 1999;158(5):379-83. X-1. [pmid: 10333119].
1421 Schwobel MG, Schramm H, Gitzelmann CA. The infantile inguinal hernia - a bilateral disease?. Pediatr Surg Int. 1999;15(2):115-8. X-1. [pmid: 10079343].
1422 Scott IU, Alexandrakis G, Cordahi GJ, et al. Diffuse and circumscribed choroidal hemangiomas in a patient with Sturge-Weber syndrome. Arch Ophthalmol. Mar. 1999;117(3):406-7. X-1. [pmid: 10088826].
1423 Seo SK, Suh JC, Na GY, et al. Kasabach-Merritt syndrome: identification of platelet trapping in a tufted angioma by immunohistochemistry technique using monoclonal antibody to CD61. Pediatr Dermatol. Sep–Oct. 1999;16(5):392-4. X-1. [pmid: 10571842].
1424 Sharma S, Bandhu S, Gulati MS, et al. Gastric hemangioma associated with phleboliths: CT appearance. AJR Am J Roentgenol. Sep. 1999;173(3):859-60. X-1. [pmid: 10470966].
1425 Sibbald B. Calgary home to country’s first comprehensive vascular birthmark clinic. Cmaj. Mar. 23. 1999;160(6):898. X-1. [pmid: 10189445].
1426 Stegersjo G, Kahnberg KE. Prosthetic restoration following maxillary resection without an oroantral defect: a case report. Int J Prosthodont. Sep–Oct. 1999;12(5):391-4. X-1. [pmid: 10709518].
1427 Thirlwall AS, Bailey CM, Ramsay AD, et al. Laryngeal paraganglioma in a five-year-old child--the youngest case ever recorded. J Laryngol Otol. Jan. 1999;113(1):62-4. X-1. [pmid: 10341923].
1428 Tortori-Donati P, Fondelli MP, Rossi A, et al. Intracranial contrast-enhancing masses in infants with capillary haemangioma of the head and neck: intracranial capillary haemangioma?. Neuroradiology. May. 1999;41(5):369-75. X-1, X-3. [pmid: 10379597].
1429 Uemura S, Woodward AA, Amerena R, et al. Early repair of inguinal hernia in premature babies. Pediatr Surg Int. 1999;15(1):36-9. X-1. [pmid: 9914352].
1430 Van Den Abbeele T, Triglia JM, Lescanne E, et al. Surgical removal of subglottic hemangiomas in children. Laryngoscope. Aug. 1999;109(8):1281-6. X-4. [pmid: 10443834].
1431 Verheul HM, Panigrahy D, Flynn E, et al. Treatment of the Kasabach-Merritt syndrome with pegylated recombinant human megakaryocyte growth and development factor in mice: elevated platelet counts, prolonged survival, and tumor growth inhibition. Pediatr Res. Nov. 1999;46(5):562-5. X-1. [pmid: 10541319].
1432 Walker MB, Hilbert GA, Rinehart J. Face to face with Sturge-Weber syndrome. J Soc Pediatr Nurs. Apr–Jun. 1999;4(2):74-82. X-1. [pmid: 10410356].
1433 Walker P, Cooper D, MacDonald D. Subglottic haemangioma: controversies in management. J Paediatr Child Health. Aug. 1999;35(4):392-5. X-2. [pmid: 10457300].
1434 Webster AR, Maher ER, Bird AC, et al. A clinical and molecular genetic analysis of solitary ocular angioma. Ophthalmology. Mar. 1999;106(3):623-9. X-1. [pmid: 10080225].
1435 Webster AR, Maher ER, Moore AT. Clinical characteristics of ocular angiomatosis in von Hippel-Lindau disease and correlation with germline mutation. Arch Ophthalmol. Mar. 1999;117(3):371-8. X-1. [pmid: 10088816].
1436 Woydt M, Horowski A, Krone A, et al. Localization and characterization of intracerebral cavernous angiomas by intra-operative high-resolution colour-duplex-sonography. Acta Neurochir (Wien). 1999;141(2):143-51. discussion 52. X-1. [pmid: 10189495].
1437 Yoshida D, Sugisaki Y, Shimura T, et al. Cavernous hemangioma of the skull in a neonate. Childs Nerv Syst. Jul. 1999;15(6–7):351-3. X-1. [pmid: 10461786].
1438 Zeevi B, Berant M. Unusual malformation of the aortic arch in a patient with a large facial hemangioma. Cardiol Young. Sep. 1999;9(5):539-40. X-1, X-2. [pmid: 10535840].
1439 Achauer BM, VanderKam VM. Treating vascular birthmarks with laser surgery. Contemp Pediatr. 2000;17(3):91-2. 5. 6. 8. passim. PMID: X-1, X-2.
1440 Akiyoshi K, Mizote H, Tanaka Y, et al. Capillary hemangioma of the liver with Kasabach-Merritt syndrome in a neonate: report of a case. Surg Today. 2000;30(1):86-8. X-1. [pmid: 10648092].
1441 Al-Sebeih K, Manoukian J. Systemic steroids for the management of obstructive subglottic hemangioma. J Otolaryngol. Dec. 2000;29(6):361-6. X-4. [pmid: 11770144].
1442 Amirikia A, Scott IU, Murray TG. Bilateral diffuse choroidal hemangiomas with unilateral facial nevus flammeus in Sturge-Weber syndrome. Am J Ophthalmol. Sep. 2000;130(3):362-4. X-1. [pmid: 11020422].
1443 Andiran F, Tanyel FC. Hemangioma of the cecum: an overlooked cause of rectal bleeding. J Pediatr Gastroenterol Nutr. Mar. 2000;30(3):330-1. X-1, X-2. [pmid: 10749422].
1444 Arzimanoglou AA, Andermann F, Aicardi J, et al. Sturge-Weber syndrome: indications and results of surgery in 20 patients. Neurology. Nov. 28. 2000;55(10):1472-9. X-1. [pmid: 11094100].
1445 Avery JK. Loss prevention case of the month. Physician + nurse = expensive clash. Tenn Med. Mar. 2000;93(3):86-7. X-2. [pmid: 10714183].
1446 Bakaeen G, Winkler S, Bakaeen L, et al. Congenital macroglossal angiodysplasia (“Lymphangioendotheliomatosis”). Arch Pathol Lab Med. Sep. 2000;124(9):1349-51. X-1. [pmid: 10975936].
1447 Bentz BG, Hughes CA, Ludemann JP, et al. Masses of the salivary gland region in children. Arch Otolaryngol Head Neck Surg. Dec. 2000;126(12):1435-9. X-1, X-3. [pmid: 11115277].
1448 Bigot JL, Iacona C, Lepreux A, et al. Sinus pericranii: advantages of MR imaging. Pediatr Radiol. Oct. 2000;30(10):710-2. X-1. [pmid: 11075608].
1449 Bornet G, Claudet I, Fries F, et al. Cervicofacial angioma and the Kasabach-Merritt syndrome. Neuroradiology. Sep. 2000;42(9):703-6. X-1, X-2. [pmid: 11071448].
1450 Budenz DL, Sakamoto D, Eliezer R, et al. Two-staged Baerveldt glaucoma implant for childhood glaucoma associated with Sturge-Weber syndrome. Ophthalmology. Nov. 2000;107(11):2105-10. X-1. [pmid: 11054342].
1451 Burstein FD, Simms C, Cohen SR, et al. Intralesional laser therapy of extensive hemangiomas in 100 consecutive pediatric patients. Ann Plast Surg. Feb. 2000;44(2):188-94. X-1. [pmid: 10696047].
1452 Ceyhan A, Gulhan Y, Cakan T, et al. Anaesthesia for Proteus syndrome. Eur J Anaesthesiol. Oct. 2000;17(10):645-7. X-1. [pmid: 11050524].
1453 Chang MW, Orlow SJ. Pyogenic granuloma: what to do when a child presents with this problem. Consultant. 2000;40(1):137. PMID: X-1.
1454 Chen LE, Minkes RK, Langer JC. Pediatric surgery on the Internet: is the truth out there?. J Pediatr Surg. Aug. 2000;35(8):1179-82. X-1. [pmid: 10945690].
1455 Cota N, Chandna A, Abernethy LJ. Orbital abscess masquerading as a rhabdomyosarcoma. J aapos. Oct. 2000;4(5):318-20. X-1. [pmid: 11040485].
1456 DeCou JM, Gauderer MW. Inguinal hernia in infants with very low birth weight. Semin Pediatr Surg. May. 2000;9(2):84-7. X-1. [pmid: 10807229].
1457 Deutsch H, Jallo GI, Faktorovich A, et al. Spinal intramedullary cavernoma: clinical presentation and surgical outcome. J Neurosurg. Jul. 2000;93(1 Suppl):65-70. X-1. [pmid: 10879760].
1458 Donnelly LF, Adams DM, Bisset GS 3rd. Vascular malformations and hemangiomas: a practical approach in a multidisciplinary clinic. AJR Am J Roentgenol. Mar. 2000;174(3):597-608. X-1, X-2. [pmid: 10701595].
1459 Eloubeidi MA, Branch MS, Treem WR. Image of the month. Gastroenterology. Mar. 2000;118(3):462. 643. X-1. [pmid: 10755867].
1460 Enjolras O, Mulliken JB, Wassef M, et al. Residual lesions after Kasabach-Merritt phenomenon in 41 patients. J Am Acad Dermatol. Feb. 2000;42(2 Pt 1):225-35. X-1. [pmid: 10642677].
1461 Fan HC, Hung CH, Juan CJ, et al. Subglottic hemangioma associated with cutaneous and cerebellar hemangiomas detected by MRI: report of one case. Acta Paediatr Taiwan. Jul–Aug. 2000;41(4):214-7. X-2. [pmid: 11021008].
1462 Fender LJ, Lenthall RK, Jaspan T. De novo development of presumed cavernomas following resolution of E. Coli subdural empyemas. Neuroradiology. Oct. 2000;42(10):778-80. X-1. [pmid: 11110086].
1463 Gupta G, Bilsland D. A prospective study of the impact of laser treatment on vascular lesions. Br J Dermatol. Aug. 2000;143(2):356-9. X-1. [pmid: 10951145].
1464 Halperin EC. Neonatal neoplasms. Int J Radiat Oncol Biol Phys. Apr. 1. 2000;47(1):171-8. X-1. [pmid: 10758320].
1465 Hasan Q, Ruger BM, Tan ST, et al. Clusterin/apoJ expression during the development of hemangioma. Hum Pathol. Jun. 2000;31(6):691-7. X-2. [pmid: 10872662].
1466 Hasan Q, Tan ST, Gush J, et al. Steroid therapy of a proliferating hemangioma: histochemical and molecular changes. Pediatrics. Jan. 2000;105(1 Pt 1):117-20. X-1, X-2. [pmid: 10617714].
1467 Haywood RM, Monk BE, Mahaffey PJ. The treatment of early cutaneous capillary haemangiomata (strawberry naevi) with the tunable dye laser. Br J Plast Surg. Jun. 2000;53(4):302-7. X-1. [pmid: 10876254].
1468 Ho V, Krol A, Bhargava R, et al. Diffuse neonatal haemangiomatosis. J Paediatr Child Health. Jun. 2000;36(3):286-9. X-1. [pmid: 10849236].
1469 Huang SA, Tu HM, Harney JW, et al. Severe hypothyroidism caused by type 3 iodothyronine deiodinase in infantile hemangiomas. N Engl J Med. Jul. 20. 2000;343(3):185-9. X-2. [pmid: 10900278].
1470 Ingram JD, Yerushalmi B, Connell J, et al. Hepatoblastoma in a neonate: a hypervascular presentation mimicking hemangioendothelioma. Pediatr Radiol. Nov. 2000;30(11):794-7. X-1. [pmid: 11100498].
1471 Kaniklides C, Dimopoulos PA, Bajic D. Infantile hemangioendothelioma. A case report. Acta Radiol. Mar. 2000;41(2):161-4. X-1. [pmid: 10741790].
1472 Kato M, Chiba Y, Sakai K, et al. Endoscopic neodymium:yttrium aluminium garnet (Nd:YAG) laser irradiation of a bladder hemangioma associated with Klippel-Weber syndrome. Int J Urol. Apr. 2000;7(4):145-8. X-1. [pmid: 10810971].
1473 Kestle J, Connolly M, Cochrane D. Pediatric peri-insular hemispherotomy. Pediatr Neurosurg. Jan. 2000;32(1):44-7. X-1. [pmid: 10765138].
1474 Kiely PD, Tierney S, Barry M, et al. Infantile hypertrophic pyloric stenosis in a regional centre. Ir J Med Sci. Apr–Jun. 2000;169(2):100-2. X-1. [pmid: 11006662].
1475 Kogler A, Talan-Hranilovic J, Bozic B, et al. Concomitant bihemispheric cerebral ganglioglioma and hemangioma in an 18-month-old child: case report. J Child Neurol. Apr. 2000;15(4):244-8. X-1, X-2. [pmid: 10805191].
1476 Komiyama M, Nakajima H, Kitano S, et al. Endovascular treatment of huge cervicofacial hemangioma complicated by Kasabach-Merritt syndrome. Pediatr Neurosurg. Jul. 2000;33(1):26-30. X-2. [pmid: 11025419].
1477 Kothari SS, Karthikeyan G, Sharma S, et al. Infantile hepatic hemangio-endothelioma: treatment by coil embolization of the hepatic artery. Indian Pediatr. Jul. 2000;37(7):780-4. X-1. [pmid: 10906813].
1478 Kouri JG, Chen MY, Watson JC, et al. Resection of suprasellar tumors by using a modified transsphenoidal approach. Report of four cases. J Neurosurg. Jun. 2000;92(6):1028-35. X-1. [pmid: 10839266].
1479 Kramer U, Kahana E, Shorer Z, et al. Outcome of infants with unilateral Sturge-Weber syndrome and early onset seizures. Dev Med Child Neurol. Nov. 2000;42(11):756-9. X-1. [pmid: 11104348].
1480 Kreusel KM, Bechrakis NE, Heinichen T, et al. Retinal angiomatosis and von Hippel-Lindau disease. Graefes Arch Clin Exp Ophthalmol. Nov. 2000;238(11):916-21. X-1. [pmid: 11148816].
1481 Labauge P, Brunereau L, Levy C, et al. The natural history of familial cerebral cavernomas: a retrospective MRI study of 40 patients. Neuroradiology. May. 2000;42(5):327-32. X-1. [pmid: 10872151].
1482 Lathbuty K. No need to be marked for life: a case study using endoscopy to remove birthmarks. Inside Case Management. 2000;6(10):6-8. PMID: X-2.
1483 Licun W, Gongjia S. Treatment of hemangioma with an angiogenesis inhibitor pingyangmycin. Indian Pediatr. Jun. 2000;37(6):636-9. X-3, X-4. [pmid: 10869144].
1484 Linward J. Care and treatment of haemangioma. Nurs Times. Aug. 3–9. 2000;96(31):37. X-1, X-2. [pmid: 11962854].
1485 Lynch HT, McComb RD, Osborn NK, et al. Predominance of brain tumors in an extended Li-Fraumeni (SBLA) kindred, including a case of Sturge-Weber syndrome. Cancer. Jan. 15. 2000;88(2):433-9. X-1. [pmid: 10640978].
1486 Mankani MH, Dufresne CR. Verrucous malformations: their presentation and management. Ann Plast Surg. Jul. 2000;45(1):31-6. X-1. [pmid: 10917095].
1487 Maxwell-Jones A. Haemangioma: Hannah’s story. Nurs Times. Aug. 3–9. 2000;96(31):38-9. X-2. [pmid: 11962855].
1488 McCabe CM, Flynn HW Jr, Shields CL, et al. Juxtapapillary capillary hemangiomas. Clinical features and visual acuity outcomes. Ophthalmology. Dec. 2000;107(12):2240-8. X-1. [pmid: 11097604].
1489 Metry DW, Hebert AA. Benign cutaneous vascular tumors of infancy: when to worry, what to do. Arch Dermatol. Jul. 2000;136(7):905-14. X-1, X-2. [pmid: 10890993].
1490 Miyagami M, Katayama Y, Nakamura S. Clinicopathological study of vascular endothelial growth factor (VEGF), p53, and proliferative potential in familial von Hippel-Lindau disease and sporadic hemangioblastomas. Brain Tumor Pathol. 2000;17(3):111-20. X-1. [pmid: 11310918].
1491 Nafday SM, Heiden RA, Rai DB. Unusual Case of Klippel-Trenaunay Syndrome A Case Report and Review of the Literature. Int J Angiol. Oct. 2000;9(4):250-3. X-1. [pmid: 11062318].
1492 Naito S, Shimizu K, Nakashima M, et al. Overexpression of Ets-1 transcription factor in angiosarcoma of the skin. Pathol Res Pract. 2000;196(2):103-9. X-1. [pmid: 10707367].
1493 Nakayama Y, Tanaka A, Ueno Y, et al. Scalp cavernous angioma presenting as sinus pericranii: diagnostic value of cerebral angiography and magnetic resonance imaging. Childs Nerv Syst. Sep. 2000;16(9):598-602. X-1. [pmid: 11048636].
1494 Navarro O, Dugougeat F, Kornecki A, et al. The impact of imaging in the management of intussusception owing to pathologic lead points in children. A review of 43 cases. Pediatr Radiol. Sep. 2000;30(9):594-603. X-1. [pmid: 11009295].
1495 Neri I, Patrizi A, Guerrini V, et al. Eruptive pseudoangiomatosis. Br J Dermatol. Aug. 2000;143(2):435-8. X-1. [pmid: 10951161].
1496 Niemela M, Lemeta S, Sainio M, et al. Hemangioblastomas of the retina: impact of von Hippel-Lindau disease. Invest Ophthalmol Vis Sci. Jun. 2000;41(7):1909-15. X-1. [pmid: 10845616].
1497 North PE, Waner M, Mizeracki A, et al. GLUT1: a newly discovered immunohistochemical marker for juvenile hemangiomas. Hum Pathol. Jan. 2000;31(1):11-22. X-1, X-3. [pmid: 10665907].
1498 Obana A, Cho A, Takamine Y, et al. A case of glaucoma with choroidal hemangioma managed by nonpenetrating trabeculectomy. Jpn J Ophthalmol. Mar–Apr. 2000;44(2):174-7. X-1. [pmid: 10715387].
1499 Ohyama M, Ijiri R, Tanaka Y, et al. Congenital primitive epithelial tumor of the liver showing focal rhabdoid features, placental involvement, and clinical features mimicking multifocal hemangioma or stage 4S neuroblastoma. Hum Pathol. Feb. 2000;31(2):259-63. X-1. [pmid: 10685646].
1500 Olivero WC, Deshmukh P, Gujrati M. Radiation-induced cavernous angioma mimicking metastatic disease. Br J Neurosurg. Dec. 2000;14(6):575-8. X-1. [pmid: 11272041].
1501 Oranje AP, de Waard-van der Spek FB, Devillers AC, et al. Treatment and pain relief of ulcerative hemangiomas with a polyurethane film. Dermatology. 2000;200(1):31-4. X-4. [pmid: 10681610].
1502 Ozsoylu S. About the treatment of Kasabach-Merritt syndrome. Pediatr Hematol Oncol. Dec. 2000;17(8):727-8. X-1. [pmid: 11127410].
1503 Packwood EA, Havertape SA, Cruz OA, et al. Visual rehabilitation in a child with diffuse choroidal hemangioma by using aggressive amblyopia therapy with low-dose external beam irradiation. J aapos. Oct. 2000;4(5):321-2. X-1. [pmid: 11040486].
1504 Pampin C, Devillers A, Treguier C, et al. Intratumoral consumption of indium-111-labeled platelets in a child with splenic hemangioma and thrombocytopenia. J Pediatr Hematol Oncol. May–Jun. 2000;22(3):256-8. X-1. [pmid: 10864058].
1505 Panow C, Berger C, Willi U, et al. MRI and CT of a haemangioma of the mandible in Kasabach-Merritt syndrome. Neuroradiology. Mar. 2000;42(3):215-7. X-1. [pmid: 10772147].
1506 Patel RJ, Appukuttan B, Ott S, et al. DNA-based diagnosis of the von Hippel-Lindau syndrome. Am J Ophthalmol. Feb. 2000;129(2):258-60. X-1. [pmid: 10682986].
1507 Poetke M, Bultmann O, Berlien HP. Association of large facial hemangiomas with Dandy-Walker syndrome. Case study concerning three infants. Eur J Pediatr Surg. Apr. 2000;10(2):125-9. X-1. [pmid: 10877082].
1508 Prapas N, Liang RI, Hunter D, et al. Color Doppler imaging of placental masses: differential diagnosis and fetal outcome. Ultrasound Obstet Gynecol. Nov. 2000;16(6):559-63. X-1. [pmid: 11169351].
1509 Prayson RA. Clinicopathological findings in patients who have undergone epilepsy surgery in the first year of life. Pathol Int. Aug. 2000;50(8):620-5. X-1. [pmid: 10972860].
1510 Prochazkova L, Machalka M, Prochazka J, et al. Arteriovenous malformations of the orofacial area. Acta Chir Plast. 2000;42(2):55-9. X-1. [pmid: 10949855].
1511 Rampini E, Rampini P, Occella C, et al. Interferon alpha 2b for treatment of complex cutaneous haemangiomas of infancy: a reduced dosage schedule. Br J Dermatol. Jan. 2000;142(1):189-91. X-3, X-4. [pmid: 10819554].
1512 Reischle S, Schuller-Petrovic S. Treatment of capillary hemangiomas of early childhood with a new method of cryosurgery. J Am Acad Dermatol. May. 2000;42(5 Pt 1):809-13. X-4. [pmid: 10775859].
1513 Schmidt D, Natt E, Neumann HP. Long-term results of laser treatment for retinal angiomatosis in von Hippel-Lindau disease. Eur J Med Res. Feb. 28. 2000;5(2):47-58. X-1. [pmid: 10720563].
1514 Shamsaldin A, Lundell M, Diallo I, et al. Estimation of the radiation dose from radiotherapy for skin haemangiomas in childhood: the ICTA software for epidemiology. Phys Med Biol. Dec. 2000;45(12):3589-99. X-1. [pmid: 11131186].
1515 Shields CL, Shields JA, Minzter R, et al. Cutaneous capillary hemangiomas of the eyelid, scalp, and digits in premature triplets. Am J Ophthalmol. Apr. 2000;129(4):528-31. X-2. [pmid: 10764865].
1516 Shin HY, Ryu KH, Ahn HS. Stepwise multimodal approach in the treatment of Kasabach-Merritt syndrome. Pediatr Int. Dec. 2000;42(6):620-4. X-1. [pmid: 11192517].
1517 Srivastava DN, Mahajan A, Berry M, et al. Colour Doppler flow imaging of focal hepatic lesions. Australas Radiol. Aug. 2000;44(3):285-9. X-1. [pmid: 10974721].
1518 Tan ST, Hasan Q, Velickovic M, et al. A novel in vitro human model of hemangioma. Mod Pathol. Jan. 2000;13(1):92-9. X-1, X-3. [pmid: 10658915].
1519 Uysal G, Guven A, Ozhan B, et al. Phakomatosis pigmentovascularis with Sturge-Weber syndrome: a case report. J Dermatol. Jul. 2000;27(7):467-70. X-1. [pmid: 10935346].
1520 van Emelen C, Goethals M, Dralands L, et al. Treatment of glaucoma in children with Sturge-Weber syndrome. J Pediatr Ophthalmol Strabismus. Jan–Feb. 2000;37(1):29-34. X-1. [pmid: 10714693].
1521 Wakabayashi Y, Isono M, Shimomura T, et al. Neurocutaneous vascular hamartomas mimicking Cobb syndrome. Case report. J Neurosurg. Jul. 2000;93(1 Suppl):133-6. X-1. [pmid: 10879770].
1522 Wild AT, Raab P, Krauspe R. Hemangioma of skeletal muscle. Arch Orthop Trauma Surg. 2000;120(3–4):139-43. X-1. [pmid: 10738870].
1523 Wilken JJ, Meier FA, Kornstein MJ. Kaposiform hemangioendothelioma of the thymus. Arch Pathol Lab Med. Oct. 2000;124(10):1542-4. X-1. [pmid: 11035594].
1524 Williams EF 3rd, Stanislaw P, Dupree M, et al. Hemangiomas in infants and children. An algorithm for intervention. Arch Facial Plast Surg. Apr–Jun. 2000;2(2):103-11. X-3, X-4. [pmid: 10925435].
1525 Williams JV, Bickel KD, Cunningham BB. Raney clips: excision of vascular lesions on the scalp made (ridiculously) simple. Pediatr Dermatol. May–Jun. 2000;17(3):238-9. X-2. [pmid: 10886762].
1526 Winter H, Drager E, Sterry W. Sclerotherapy for treatment of hemangiomas. Dermatol Surg. Feb. 2000;26(2):105-8. X-1. [pmid: 10691936].
1527 Wong JH, Awad IA, Kim JH. Ultrastructural pathological features of cerebrovascular malformations: a preliminary report. Neurosurgery. Jun. 2000;46(6):1454-9. X-1. [pmid: 10834648].
1528 Woo KI, Kim YD. Vascular hamartoma of the orbit. Korean J Ophthalmol. Dec. 2000;14(2):103-6. X-1. [pmid: 11213733].
1529 Yamakawa N, Noda M, Ohyama T, et al. A cellular variant of supratentorial hemangioblastoma. Brain Tumor Pathol. 2000;17(1):15-9. X-1. [pmid: 10982005].
1530 Yoshikawa T, Aoki S, Hori M, et al. Time-resolved two-dimensional thick-slice magnetic resonance digital subtraction angiography in assessing brain tumors. Eur Radiol. 2000;10(5):736-44. X-1. [pmid: 10823625].
1531 Yung BC, Loke TK, Chan YL. Angiomatosis of the hand demonstrated by contrast-enhanced magnetic resonance angiogram. Australas Radiol. May. 2000;44(2):198-200. X-1. [pmid: 10849984].
1532 Zhang N, Pan L, Wang BJ, et al. Gamma knife radiosurgery for cavernous hemangiomas. J Neurosurg. Dec. 2000;93(Suppl 3):74-7. X-1. [pmid: 11143267].
1533 Index of suspicion. Pediatr Rev. Oct. 2001;22(10):343-8. X-1. [pmid: 11581487].
1534 Updates. Severe hypothyroidism and infantile hemangiomas. Contemp Ob Gyn. 2001;46:77. PMID: X-2.
1535 Akyol MU, Yalciner EG, Dogan AI. Pyogenic granuloma (lobular capillary hemangioma) of the tongue. Int J Pediatr Otorhinolaryngol. May. 11. 2001;58(3):239-41. X-1, X-2. [pmid: 11335013].
1536 Amirikia A, Scott IU, Capo H, et al. Increasing hyperopia and esotropia as the presenting signs of bilateral diffuse choroidal hemangiomas in a patient with Sturge-Weber syndrome. J Pediatr Ophthalmol Strabismus. Nov–Dec. 2001;38(6):367-8. X-1. [pmid: 11759777].
1537 Arbiser JL, Weiss SW, Arbiser ZK, et al. Differential expression of active mitogen-activated protein kinase in cutaneous endothelial neoplasms: implications for biologic behavior and response to therapy. J Am Acad Dermatol. Feb. 2001;44(2):193-7. X-1, X-3. [pmid: 11174372].
1538 Atahan IL, Cengiz M, Ozyar E, et al. Radiotherapy in the management of Kasabach-Merritt syndrome: a case report. Pediatr Hematol Oncol. Oct–Nov. 2001;18(7):471-6. X-1, X-2. [pmid: 11594711].
1539 Attar A, Ugur HC, Savas A, et al. Surgical treatment of intracranial cavernous angiomas. J Clin Neurosci. May. 2001;8(3):235-9. X-1. [pmid: 11386797].
1540 Bannister CF, Brosius KK, Sigl JC, et al. The effect of bispectral index monitoring on anesthetic use and recovery in children anesthetized with sevoflurane in nitrous oxide. Anesth Analg. Apr. 2001;92(4):877-81. X-1. [pmid: 11273918].
1541 Bennett ML, Fleischer AB Jr, Chamlin SL, et al. Oral corticosteroid use is effective for cutaneous hemangiomas: an evidence-based evaluation. Arch Dermatol. Sep. 2001;137(9):1208-13. X-1, X-2. [pmid: 11559219].
1542 Billio A, Pescosta N, Rosanelli C, et al. Treatment of Kasabach-Merritt syndrome by embolisation of a giant liver hemangioma. Am J Hematol. Feb. 2001;66(2):140-1. X-1, X-2. [pmid: 11421294].
1543 Bree AF, Siegfried E, Sotelo-Avila C, et al. Infantile hemangiomas: speculation on placental trophoblastic origin. Arch Dermatol. May. 2001;137(5):573-7. X-1, X-3. [pmid: 11346335].
1544 Broome ME. Professional issues... commentary on Krasna IH (2000). Abdominal pain and appendicitis: is there a difference in referrals between HMO prediatricians [sic] and private pediatricians? JOURNAL OF PEDIATRIC SURGERY, 35(7), 1084–1086. J Child Fam Nurs. 2001. Jan–Feb. 2001;4(1):59-60. PMID: X-1.
1545 Brumblay HG, Khoshyomn S, Tranmer BI, et al. Giant cavernous angioma. Pediatr Neurosurg. Dec. 2001;35(6):336. X-1. [pmid: 11786705].
1546 Cacciaguerra S, Vasta G, Benedetto AG, et al. Neonatal diaphragmatic hemangioma. J Pediatr Surg. Sep. 2001;36(9):E21. X-1, X-2. [pmid: 11528638].
1547 Cho S, Lee SY, Choi JH, et al. Treatment of “Cyrano” angioma with pulsed dye laser. Dermatol Surg. Jul. 2001;27(7):670-2. X-1, X-2. [pmid: 11442621].
1548 Clatterbuck RE, Moriarity JL, Rigamonti D. Intramedullary cavernoma. J Neurosurg. Jul. 2001;95(1 Suppl):156-7. X-1. [pmid: 11453423].
1549 Cooke R. Lack of thyroid hormone is linked to retardation in infants. Los Angeles Times -- Southern California Edition (Front Page). 2001:S6-S. PMID: X-1.
1550 Curros F, Brunelle F. Prenatal thoracoabdominal tumor mimicking pulmonary sequestration: a diagnosis dilemma. Eur Radiol. 2001;11(1):167-70. X-1. [pmid: 11194909].
1551 Damiani S, Eusebi V. Gynecomastia in type-1 neurofibromatosis with features of pseudoangiomatous stromal hyperplasia with giant cells. Report of two cases. Virchows Arch. May. 2001;438(5):513-6. X-1. [pmid: 11407482].
1552 Deda H, Ugur HC, Yorulmaz I, et al. Anteromedial approach to the orbit. Skull Base. 2001;11(4):233-9. X-1. [pmid: 17167625].
1553 Deutsch H, Shrivistava R, Epstein F, et al. Pediatric intramedullary spinal cavernous malformations. Spine. Sep. 15. 2001;26(18):E427-31. X-1. [pmid: 11547214].
1554 Diment J, Yurim O, Pappo O. Infantile hemangioendothelioma of the liver in an adult. Arch Pathol Lab Med. Jul. 2001;125(7):931-2. X-1. [pmid: 11419979].
1555 Drolet BA, Scott LA, Esterly NB, et al. Early surgical intervention in a patient with Kasabach-Merritt phenomenon. J Pediatr. May. 2001;138(5):756-8. X-1. [pmid: 11343057].
1556 Dunn KJ. Flying home. J Soc Pediatr Nurs. Apr–Jun. 2001;6(2):83-6. X-1. [pmid: 11326465].
1557 Dunn KJ. Case study. Flying home. J Soc Pediatr Nurs. 2001;6(2):83-6. PMID: X-1. [pmid: 11326465].
1558 Egbert JE, Paul S, Engel WK, et al. High injection pressure during intralesional injection of corticosteroids into capillary hemangiomas. Arch Ophthalmol. May. 2001;119(5):677-83. X-2. [pmid: 11346395].
1559 Endo H, Kawada A, Aragane Y, et al. The successful treatment of diffuse neonatal hemangiomatosis with flashlamp pulsed dye laser. Pediatr Dermatol. Mar–Apr. 2001;18(2):146-8. X-1. [pmid: 11358559].
1560 Enjolras O, Mulliken JB, Boon LM, et al. Noninvoluting congenital hemangioma: a rare cutaneous vascular anomaly. Plast Reconstr Surg. Jun. 2001;107(7):1647-54. X-1. [pmid: 11391180].
1561 Ertem D, Acar Y, Kotiloglu E, et al. Blue rubber bleb nevus syndrome. Pediatrics. Feb. 2001;107(2):418-20. X-1. [pmid: 11158481].
1562 Esposito C, Zupi A, Califano L. Surgical therapy of parotid hemangiomas. Pediatr Surg Int. Jul. 2001;17(5–6):335-7. X-4. [pmid: 11527159].
1563 Fledelius HC, Illum N, Jensen H, et al. Interferon-alfa treatment of facial infantile haemangiomas: with emphasis on the sight-threatening varieties. A clinical series. Acta Ophthalmol Scand. Aug. 2001;79(4):370-3. X-4. [pmid: 11453856].
1564 Folkersma H, Mooij JJ. Follow-up of 13 patients with surgical treatment of cerebral cavernous malformations: effect on epilepsy and patient disability. Clin Neurol Neurosurg. Jul. 2001;103(2):67-71. X-1. [pmid: 11516547].
1565 Forest-Lalande L. Helpful hints in neonatology wound care. Primary Intention: The Australian Journal of Wound Management. 2001;9(1):7. PMID: X-1.
1566 Fukino K, Umeoka K, Kitamura T, et al. Cortical dysplasia with subcutaneous angioma and dilated dural venous sinuses. J Neuroradiol. Jun. 2001;28(2):127-9. X-1. [pmid: 11466498].
1567 Gaggero R, Devescovi R, Zaccone A, et al. Epilepsy associated with infantile hemiparesis: predictors of long-term evolution. Brain Dev. Mar. 2001;23(1):12-7. X-1. [pmid: 11226723].
1568 Garmendia G, Miranda N, Borroso S, et al. Regression of infancy hemangiomas with recombinant IFN-alpha 2b. J Interferon Cytokine Res. Jan. 2001;21(1):31-8. X-3. [pmid: 11177578].
1569 Geeze MA. Advanced practice case study: congenital hemangiomas. Semin Perioper Nurs. 2001;10(4):188-95. PMID: X-1, X-2.
1570 Ghourab S. Ultrasound in the management of Chorioangioma. Saudi Med J. Jul. 2001;22(7):585-9. X-1. [pmid: 11479638].
1571 Gorst CM, Munnoch DA, Hancock K. Combined treatment of a proliferative peri-orbital haemangioma with a tuneable dye laser and intra-lesional steroids to prevent deprivation amblyopia. J R Coll Surg Edinb. Aug. 2001;46(4):234-6. X-4. [pmid: 11523716].
1572 Goto T, Kojima T, Iijima T, et al. Soft-tissue haemangioma and periosteal new bone formation on the neighbouring bone. Arch Orthop Trauma Surg. Nov. 2001;121(10):549-53. X-1. [pmid: 11768633].
1573 Grosz AH, Jacobs IN, Cho C, et al. Use of helium-oxygen mixtures to relieve upper airway obstruction in a pediatric population. Laryngoscope. Sep. 2001;111(9):1512-4. X-2. [pmid: 11568598].
1574 Hasan Q, Tan ST, Gush J, et al. Altered mitochondrial cytochrome b gene expression during the regression of hemangioma. Plast Reconstr Surg. Nov. 2001;108(6):1471-6. discussion 7–8. X-1, X-3. [pmid: 11711910].
1575 Hecht DA, Jackson CG, Grundfast KM. Management of middle ear hemangiomas. Am J Otolaryngol. Sep–Oct. 2001;22(5):362-6. X-1. [pmid: 11562890].
1576 Hodaie M, Becker L, Teshima I, et al. Total resection of an intracerebral hemangioendothelioma in an infant. Case report and review of the literature. Pediatr Neurosurg. Feb. 2001;34(2):104-12. X-1. [pmid: 11287811].
1577 Hoeger PH, Schaefer H, Ussmueller J, et al. Nasal glioma presenting as capillary haemangioma. Eur J Pediatr. Feb. 2001;160(2):84-7. X-1. [pmid: 11271395].
1578 Holmberg E, Holm LE, Lundell M, et al. Excess breast cancer risk and the role of parity, age at first childbirth and exposure to radiation in infancy. Br J Cancer. Aug. 3. 2001;85(3):362-6. X-1. [pmid: 11487266].
1579 Ibarra RA, Kesava P, Hallet KK, et al. Hemangioendothelioma of the temporal bone with radiologic findings resembling hemangioma. AJNR Am J Neuroradiol. Apr. 2001;22(4):755-8. X-1. [pmid: 11290494].
1580 Kacker A, April M, Ward RF. Use of potassium titanyl phosphate (KTP) laser in management of subglottic hemangiomas. Int J Pediatr Otorhinolaryngol. May. 31. 2001;59(1):15-21. X-4. [pmid: 11376814].
1581 Kaminsky RA. Pathologic quiz case: An exceedingly rare cause of sudden cardiac death. Arch Pathol Lab Med. Apr. 2001;125(4):573-4. X-1. [pmid: 11260643].
1582 Kammula US, Buell JF, Labow DM, et al. Surgical management of benign tumors of the liver. Int J Gastrointest Cancer. 2001;30(3):141-6. X-1. [pmid: 12540026].
1583 Kaneko R, Tohnai I, Ueda M, et al. Curative treatment of central hemangioma in the mandible by direct puncture and embolisation with n-butyl-cyanoacrylate (NBCA). Oral Oncol. Oct. 2001;37(7):605-8. X-1, X-2. [pmid: 11564583].
1584 Kapella M, Panosetti E, Rombaux P, et al. Lobular capillary haemangioma of the nasal cavity: observation of three specific cases. Acta Otorhinolaryngol Belg. 2001;55(3):241-6. X-1. [pmid: 11685962].
1585 Karmazyn B, Michovitz S, Sirota L, et al. Intracranial cavernous hemangioma in a neonate. Pediatr Radiol. Sep. 2001;31(9):610-2. X-1. [pmid: 11511998].
1586 Kayser K, Zink S, Link B, et al. Endobronchial juvenile hemangioma--a case report of a neonate including immunohistochemical monitoring and nuclear, cellular, and vascular morphometry. Virchows Arch. Feb. 2001;438(2):192-7. X-2. [pmid: 11253122].
1587 Khurana KK, Mortelliti AJ. The role of fine-needle aspiration biopsy in the diagnosis and management of juvenile hemangioma of the parotid gland and cheek. Arch Pathol Lab Med. Oct. 2001;125(10):1340-3. X-2. [pmid: 11570911].
1588 Kim HJ, Colombo M, Frieden IJ. Ulcerated hemangiomas: clinical characteristics and response to therapy. J Am Acad Dermatol. Jun. 2001;44(6):962-72. X-3, X-4. [pmid: 11369908].
1589 Kiratli H, Bozkurt B, Mocan C. Peripapillary staphyloma associated with orofacial capillary hemangioma. Ophthalmic Genet. Dec. 2001;22(4):249-53. X-2. [pmid: 11803491].
1590 Kollar CD, Johnston IH, Sholler GF. Communicating hydrocephalus secondary to a cardiac tumour compressing the superior vena cava. Childs Nerv Syst. Feb. 2001;17(3):117-20. X-1. [pmid: 11305763].
1591 Kriplani A, Abbi M, Banerjee N, et al. Indomethacin therapy in the treatment of polyhydramnios due to placental chorioangioma. J Obstet Gynaecol Res. Oct. 2001;27(5):245-8. X-1. [pmid: 11776505].
1592 Labauge P, Brunereau L, Coubes P, et al. Appearance of new lesions in two nonfamilial cerebral cavernoma patients. Eur Neurol. 2001;45(2):83-8. X-1. [pmid: 11244270].
1593 Lamberg L. Advances in pediatric dermatology: specialist training to Internet atlas. JAMA. Apr. 25. 2001;285(16):2065-7. X-1. [pmid: 11311075].
1594 Landells I. Treatment of hemangiomas in children. Skin Therapy Lett. Oct. 2001;6(11):3-5. X-1, X-2. [pmid: 11719826].
1595 Lee H, Choi SS, Kim SS, et al. A case of glaucoma associated with Sturge-Weber syndrome and Nevus of Ota. Korean J Ophthalmol. Jun. 2001;15(1):48-53. X-1. [pmid: 11530821].
1596 Lee JK, Kim JH, Kim JS, et al. Cervical dermal sinus associated with dermoid cyst. Childs Nerv Syst. Aug. 2001;17(8):491-3. X-1. [pmid: 11508540].
1597 Leighton SE, Papsin B, Vellodi A, et al. Disordered breathing during sleep in patients with mucopolysaccharidoses. Int J Pediatr Otorhinolaryngol. Apr. 27. 2001;58(2):127-38. X-1. [pmid: 11278021].
1598 Levy AD, Abbott RM, Rohrmann CA Jr, et al. Gastrointestinal hemangiomas: imaging findings with pathologic correlation in pediatric and adult patients. AJR Am J Roentgenol. Nov. 2001;177(5):1073-81. X-1, X-2. [pmid: 11641173].
1599 Lindberg S. Radiotherapy of childhood haemangiomas: from active treatment to radiation risk estimates. Radiat Environ Biophys. Sep. 2001;40(3):179-89. X-2. [pmid: 11783846].
1600 Lukish JR, Gill GG, McCoy TR. Surgical care in the isolated military hospital. Mil Med. Jan. 2001;166(1):90-3. X-1. [pmid: 11197107].
1601 Madgy D, Ahsan SF, Kest D, et al. The application of the potassium-titanyl-phosphate (KTP) laser in the management of subglottic hemangioma. Arch Otolaryngol Head Neck Surg. Jan. 2001;127(1):47-50. X-4. [pmid: 11177013].
1602 Mason KP, Koka BV, Eldredge EA, et al. Perioperative considerations in a hypothyroid infant with hepatic haemangioma. Paediatr Anaesth. Mar. 2001;11(2):228-32. X-1, X-2. [pmid: 11240884].
1603 Matsushima T, Inoue T, Inamura T, et al. Transcerebellomedullary fissure approach with special reference to methods of dissecting the fissure. J Neurosurg. Feb. 2001;94(2):257-64. X-1. [pmid: 11213963].
1604 McDonald HR. Diagnostic and therapeutic challenges. Retina. 2001;21(1):62-4. discussion 4–5. X-1. [pmid: 11217932].
1605 Niemela M, Maenpaa H, Salven P, et al. Interferon alpha-2a therapy in 18 hemangioblastomas. Clin Cancer Res. Mar. 2001;7(3):510-6. X-1. [pmid: 11297241].
1606 North PE, Waner M, James CA, et al. Congenital nonprogressive hemangioma: a distinct clinicopathologic entity unlike infantile hemangioma. Arch Dermatol. Dec. 2001;137(12):1607-20. X-1, X-3. [pmid: 11735711].
1607 North PE, Waner M, Mizeracki A, et al. A unique microvascular phenotype shared by juvenile hemangiomas and human placenta. Arch Dermatol. May. 2001;137(5):559-70. X-1, X-3. [pmid: 11346333].
1608 Ogino I, Torikai K, Kobayasi S, et al. Radiation therapy for life- or function-threatening infant hemangioma. Radiology. Mar. 2001;218(3):834-9. X-3, X-4. [pmid: 11230664].
1609 Orsini M, Rocha RS, Disch J, et al. The role of nutritional status and insulin-like growth factor in reduced physical growth in hepatosplenic Schistosoma mansoni infection. Trans R Soc Trop Med Hyg. Jul–Aug. 2001;95(4):453-6. X-1. [pmid: 11579895].
1610 Park EA, Seo JW, Lee SW, et al. Infantile hemangioendothelioma treated with high dose methylprednisolone pulse therapy. J Korean Med Sci. Feb. 2001;16(1):127-9. X-1. [pmid: 11289392].
1611 Parmar RC, Bavdekar SB, Borwankar SS, et al. Infantile hemangioendothelioma. Indian J Pediatr. May. 2001;68(5):459-61. X-1. [pmid: 11407165].
1612 Pasek T. Abby’s gift. J Soc Pediatr Nurs. Oct–Dec. 2001;6(4):196-200. X-1. [pmid: 11777333].
1613 Pasek T. Role play. Abby’s gift. J Soc Pediatr Nurs. 2001;6(4):196-200. PMID: X-1. [pmid: 11777333].
1614 Poetke M, Philipp CM, Urban P, et al. Interstitial laser treatment of venous malformations. Medical Laser Application. 2001;16(2):111-9. PMID: X-3, X-4.
1615 Ramsey PS, Danilenko DR, Derleth DP. Special feature: radiological case of the month. Arch Pediatr Adolesc Med. Jun. 2001;155(6):733-4. X-2. [pmid: 11386968].
1616 Rossi A, Bava GL, Biancheri R, et al. Posterior fossa and arterial abnormalities in patients with facial capillary haemangioma: presumed incomplete phenotypic expression of PHACES syndrome. Neuroradiology. Nov. 2001;43(11):934-40. X-3. [pmid: 11760796].
1617 Sakura N, Mizoguchi N, Ono H, et al. Congenital porto-systemic shunt as a major cause of galactosemia. International Pediatrics. 2001;16(4):206-10. PMID: X-1.
1618 Samii M, Eghbal R, Carvalho GA, et al. Surgical management of brainstem cavernomas. J Neurosurg. Nov. 2001;95(5):825-32. X-1. [pmid: 11702873].
1619 Senoh D, Hanaoka U, Tanaka Y, et al. Antenatal ultrasonographic features of fetal giant hemangiolymphangioma. Ultrasound Obstet Gynecol. Mar. 2001;17(3):252-4. X-1. [pmid: 11309178].
1620 Seto T, Kono K, Morimoto K, et al. Brain magnetic resonance imaging in 23 patients with mucopolysaccharidoses and the effect of bone marrow transplantation. Ann Neurol. Jul. 2001;50(1):79-92. X-1. [pmid: 11456314].
1621 Sherman JA, Davies HT. Intramuscular hemangioma of the temporalis muscle. J Oral Maxillofac Surg. Feb. 2001;59(2):207-9. X-2. [pmid: 11213991].
1622 Shields CL, Honavar SG, Shields JA, et al. Circumscribed choroidal hemangioma: clinical manifestations and factors predictive of visual outcome in 200 consecutive cases. Ophthalmology. Dec. 2001;108(12):2237-48. X-1. [pmid: 11733265].
1623 Simonovsky V, Lisy J, Pipkova R, et al. Benign liver tumours - Tomographic imaging methods. Haemangioma, infantile haemangioendothelioma and angiomyolipoma. Cesk Radiol. 2001;55(1):12-8. X-11.
1624 Singh A, Shields J, Shields C. Solitary retinal capillary hemangioma: hereditary (von Hippel-Lindau disease) or nonhereditary?. Arch Ophthalmol. Feb. 2001;119(2):232-4. X-1. [pmid: 11176984].
1625 Singh AD, Nouri M, Shields CL, et al. Retinal capillary hemangioma: a comparison of sporadic cases and cases associated with von Hippel-Lindau disease. Ophthalmology. Oct. 2001;108(10):1907-11. X-1. [pmid: 11581072].
1626 Sora S, Ueki K, Saito N, et al. Incidence of von Hippel-Lindau disease in hemangioblastoma patients: the University of Tokyo Hospital experience from 1954–1998. Acta Neurochir (Wien). Sep. 2001;143(9):893-6. X-1. [pmid: 11685621].
1627 Spendel S, Prandl EC, Uggowitzer M, et al. Ultrasound-navigated interstitial Nd:YAG laser coagulation of congenital vascular disorders. Medical Laser Application. 2001;16(2):121-7. PMID: X-1, X-4.
1628 Stiller B, Hetzer R, Meyer R, et al. Primary cardiac tumours: when is surgery necessary?. Eur J Cardiothorac Surg. Nov. 2001;20(5):1002-6. X-1. [pmid: 11675188].
1629 Strouhal P, Bradshaw K. Case 2: assessment. Postural-dependent stridor. Paediatr Respir Rev. Mar. 2001;2(1):85-6. X-2. [pmid: 16256728].
1630 Sure U, Butz N, Schlegel J, et al. Endothelial proliferation, neoangiogenesis, and potential de novo generation of cerebrovascular malformations. J Neurosurg. Jun. 2001;94(6):972-7. X-1. [pmid: 11409527].
1631 Tarantal AF, O’Rourke JP, Case SS, et al. Rhesus monkey model for fetal gene transfer: studies with retroviral- based vector systems. Mol Ther. Feb. 2001;3(2):128-38. X-1. [pmid: 11237669].
1632 Uysal KM, Olgun N, Erbay A, et al. High-dose oral methylprednisolone therapy in childhood hemangiomas. Pediatr Hematol Oncol. Jul–Aug. 2001;18(5):335-41. X-4. [pmid: 11452405].
1633 Vachvanichsanong P, Malagon M, Moore ES. Recurrent abdominal and flank pain in children with idiopathic hypercalciuria. Acta Paediatr. Jun. 2001;90(6):643-8. X-1. [pmid: 11440097].
1634 Vachvanichsanong P, Malagon M, Moore ES. Urinary tract infection in children associated with idiopathic hypercalciuria. Scand J Urol Nephrol. Apr. 2001;35(2):112-6. X-1. [pmid: 11411652].
1635 Vargel I, Mavili ME, Canter HI, et al. Surgical excision of cutaneous vascular lesions after percutaneous injection of n-butyl 2-cyanoacrylate. Ann Plast Surg. Jun. 2001;46(6):658-9. X-4. [pmid: 11405375].
1636 Vassilyadi M, Jones BV, Ball WS Jr, et al. Identification of an arteriovenous fistula in a child. Case report and review of the literature. Childs Nerv Syst. Nov. 2001;17(11):685-8. X-1. [pmid: 11734989].
1637 Verma K, Verma KK. Infantile periocular haemangioma treated with two days in a week betamethasone oral mini pulse therapy. Indian J Pediatr. Apr. 2001;68(4):355-6. X-2. [pmid: 11370446].
1638 Wang C, Zhang J, Liu A, et al. Surgical management of medullary hemangioblastoma. Report of 47 cases. Surg Neurol. Oct. 2001;56(4):218-26. discussion 26–7. X-1. [pmid: 11738662].
1639 Wong CH, Wright JG, Silove ED, et al. A new syndrome of multiple hemangiomas, right dominant double aortic arch, and coarctation. J Thorac Cardiovasc Surg. Jun. 2001;121(6):1207-9. X-2. [pmid: 11385394].
1640 Wong LC, Rogers M, Lammi A. Severe cyclical thrombocytopenia in a patient with a large lymphatic-venous malformation: a potential association?. Australas J Dermatol. Feb. 2001;42(1):38-42. X-1. [pmid: 11233720].
1641 Woydt M, Krone A, Soerensen N, et al. Ultrasound-guided neuronavigation of deep-seated cavernous haemangiomas: clinical results and navigation techniques. Br J Neurosurg. Dec. 2001;15(6):485-95. X-1. [pmid: 11814000].
1642 Yakinci C, Durmaz Y, Korkut M, et al. Cavernous hemangioma in a child presenting with hemichorea: response to pimozide. J Child Neurol. Sep. 2001;16(9):685-8. X-1. [pmid: 11575611].
1643 Abe T, Tomatsu T, Tazaki K. Synovial hemangioma of the knee in young children. J Pediatr Orthop B. Oct. 2002;11(4):293-7. X-1. [pmid: 12370579].
1644 Abrahams NA, Colby TV, Pearl RH, et al. Pulmonary hemangiomas of infancy and childhood: report of two cases and review of the literature. Pediatr Dev Pathol. May–Jun. 2002;5(3):283-92. X-1, X-2. [pmid: 12007021].
1645 Amirikia A, Scott IU, Capo H, et al. Increasing hyperopia and esotropia as the presenting signs of bilateral diffuse choroidal hemangiomas in a patient with Sturge-Weber syndrome. J Pediatr Ophthalmol Strabismus. Mar–Apr. 2002;39(2):121-2. X-1. [pmid: 11911543].
1646 Ashoor A, Baker YA. Intraosseus Haemangioma of the nasal bone. Bahrain Med Bull. 2002;24(1):32-3. X-1, X-2.
1647 Bannur U, Korah I, Chandy MJ. Midbrain venous angioma with obstructive hydrocephalus. Neurol India. Jun. 2002;50(2):207-9. X-1. [pmid: 12134191].
1648 Baron JA, Raines J, Bangert J, et al. Persistent nodule on the nose. Arch Dermatol. Feb. 2002;138(2):259-64. X-1. [pmid: 11843651].
1649 Bava GL, Dalmonte P, Oddone M, et al. Life-threatening hemorrhage from a vulvar hemangioma. J Pediatr Surg. Apr. 2002;37(4):E6. X-1, X-2. [pmid: 11912541].
1650 Baxter MA, Wynn RF, Deakin JA, et al. Retrovirally mediated correction of bone marrow-derived mesenchymal stem cells from patients with mucopolysaccharidosis type I. Blood. Mar. 1. 2002;99(5):1857-9. X-1. [pmid: 11861306].
1651 Burge DM, Sugarman IS. Exclusion of androgen insensitivity syndrome in girls with inguinal hernias: current surgical practice. Pediatr Surg Int. Dec. 2002;18(8):701-3. X-1. [pmid: 12598968].
1652 Chatrath P, Black M, Jani P, et al. A review of the current management of infantile subglottic haemangioma, including a comparison of CO(2) laser therapy versus tracheostomy. Int J Pediatr Otorhinolaryngol. Jun. 17. 2002;64(2):143-57. X-4. [pmid: 12049827].
1653 Chattopadhyay A, Kumar V, Maruliah M, et al. Duodenojejunal obstruction by a hemangioma. Pediatr Surg Int. Sep. 2002;18(5–6):501-2. X-2. [pmid: 12415392].
1654 Chen DH, Lipe HP, Qin Z, et al. Cerebral cavernous malformation: novel mutation in a Chinese family and evidence for heterogeneity. J Neurol Sci. Apr. 15. 2002;196(1–2):91-6. X-1. [pmid: 11959162].
1655 Cherninkova S, Tzekov C, Bussarski V, et al. Neuro-ophthalmologic symptomatology in 246 patients with orbital space-occupying processes. Neuro-Ophthalmology. February/May. 2002;27(1–3):45-54. PMID: X-3, X-4.
1656 Childers EL, Furlong MA, Fanburg-Smith JC. Hemangioma of the salivary gland: a study of ten cases of a rarely biopsied/excised lesion. Ann Diagn Pathol. Dec. 2002;6(6):339-44. X-2, X-3. [pmid: 12478482].
1657 Chiller KG, Passaro D, Frieden IJ. Hemangiomas of infancy: clinical characteristics, morphologic subtypes, and their relationship to race, ethnicity, and sex. Arch Dermatol. Dec. 2002;138(12):1567-76. X-3. [pmid: 12472344].
1658 Chmielik M, Zajac B. Laryngeal haemangioma in children. New Medicine. 2002;5(2):55-7. PMID: X-1, X-2.
1659 Choi SJ, Choi BK, Kim HJ, et al. Lateral decubitus HRCT: a simple technique to replace expiratory CT in children with air trapping. Pediatr Radiol. Mar. 2002;32(3):179-82. X-1, X-2. [pmid: 12164350].
1660 Coghlan D, Lynch B, Allcutt D. Hereditary cerebral cavernous angiomas: presentation as idiopathic familial epilepsy. Ir Med J. Feb. 2002;95(2):56-8. X-1. [pmid: 11989951].
1661 Conrad M, Schonauer C, Morel C, et al. Computer-assisted resection of supra-tentorial cavernous malformation. Minim Invasive Neurosurg. Jun. 2002;45(2):87-90. X-1. [pmid: 12087505].
1662 D’Antonio A, Boscaino A, De Dominicis G, et al. Splenic hemangiomatosis. A report of two cases and review of literature. Adv Clin Path. Jul–Oct. 2002;6(3–4):119-24. X-1. [pmid: 19757634].
1663 de Kanter K. Ulcerated hemangiomas. Dermatol Nurs. Oct. 2002;14(5):337. X-2. [pmid: 12430523].
1664 Deb G, Donfrancesco A, Ilari I, et al. Hemangioendothelioma: successful therapy with interferon-alpha: a study in Association with the Italian Pediatric Haematology/Oncology Society (AIEOP). Med Pediatr Oncol. Feb. 2002;38(2):118-9. X-1. [pmid: 11813178].
1665 Denk MJ, Ajkay N, Yuan X, et al. Surgical treatment of nasal hemangiomas. Ann Plast Surg. May. 2002;48(5):489-94. discussion 94–5. X-3, X-4. [pmid: 11981188].
1666 Dietrich CF, Ignee A, Gebel M, et al. [Imaging of the abdomen. Z Gastroenterol. Dec. 2002;40(12):965-70. X-1. [pmid: 12564420].
1667 Dollfus H, Massin P, Taupin P, et al. Retinal hemangioblastoma in von Hippel-Lindau disease: a clinical and molecular study. Invest Ophthalmol Vis Sci. Sep. 2002;43(9):3067-74. X-1. [pmid: 12202531].
1668 Domini M, Aquino A, Fakhro A, et al. Blue rubber bleb nevus syndrome and gastrointestinal haemorrhage: which treatment?. Eur J Pediatr Surg. Apr. 2002;12(2):129-33. X-1. [pmid: 12015660].
1669 Eliashiv DS, Elsas SM, Squires K, et al. Ictal magnetic source imaging as a localizing tool in partial epilepsy. Neurology. Nov. 26. 2002;59(10):1600-10. X-1. [pmid: 12451204].
1670 El-Kayali AY, Al-Salman MM, Iqbal KI, et al. Vascular anomalies - diagnosis and therapy. Saudi Med J. Mar. 2002;23(3):272-6. X-3, X-4. [pmid: 11938414].
1671 Erez I, Rathause V, Vacian I, et al. Preoperative ultrasound and intraoperative findings of inguinal hernias in children: A prospective study of 642 children. J Pediatr Surg. Jun. 2002;37(6):865-8. X-1. [pmid: 12037751].
1672 Faguer K, Dompmartin A, Labbe D, et al. Early surgical treatment of Cyrano-nose haemangiomas with Rethi incision. Br J Plast Surg. Sep. 2002;55(6):498-503. X-4. [pmid: 12479424].
1673 Ferrari A, Casanova M, Bisogno G, et al. Malignant vascular tumors in children and adolescents: a report from the Italian and German Soft Tissue Sarcoma Cooperative Group. Med Pediatr Oncol. Aug. 2002;39(2):109-14. X-1. [pmid: 12116058].
1674 Frevel T, Rabe H, Uckert F, et al. Giant cavernous haemangioma with Kasabach-Merritt syndrome: a case report and review. Eur J Pediatr. May. 2002;161(5):243-6. X-2. [pmid: 12012216].
1675 Gangemi M, Maiuri F, Cappabianca P, et al. Endoscopic fenestration of symptomatic septum pellucidum cysts: three case reports with discussion on the approaches and technique. Minim Invasive Neurosurg. Jun. 2002;45(2):105-8. X-1. [pmid: 12087509].
1676 Garcia Muret MP, Puig L, Allard C, et al. Hypomelanosis of Ito with Sturge-Weber syndrome-like leptomeningeal angiomatosis. Pediatr Dermatol. Nov–Dec. 2002;19(6):536-40. X-1. [pmid: 12437559].
1677 Gargiulo G, Pace Napoleone C, Giardini A, et al. Repair of a complex aortic arch anomaly associated with cutaneous hemangioma. Ann Thorac Surg. Jul. 2002;74(1):245-6. X-2. [pmid: 12118772].
1678 Gasparovic H, Anic D, Saric D, et al. Surgical excision of a hemangioendothelioma of the left ventricle. Ann Thorac Surg. Sep. 2002;74(3):914-6. X-1. [pmid: 12238864].
1679 Gembruch U, Baschat AA, Gloeckner-Hoffmann K, et al. Prenatal diagnosis and management of fetuses with liver hemangiomata. Ultrasound Obstet Gynecol. May. 2002;19(5):454-60. X-1. [pmid: 11982977].
1680 Goyal A, Babu SN, Kim V, et al. Hemangioendothelioma of liver and spleen: trauma-induced consumptive coagulopathy. J Pediatr Surg. Oct. 2002;37(10):E29. X-1. [pmid: 12378475].
1681 Haisley-Royster C, Enjolras O, Frieden IJ, et al. Kasabach-merritt phenomenon: a retrospective study of treatment with vincristine. J Pediatr Hematol Oncol. Aug–Sep. 2002;24(6):459-62. X-1. [pmid: 12218593].
1682 Hanaoka J, Inoue S, Fujino S, et al. Mediastinal cavernous hemangioma in a child: report of a case. Surg Today. 2002;32(11):985-8. X-1, X-2. [pmid: 12444436].
1683 Hardisson D, Prim MP, De Diego JI, et al. Kaposiform hemangioendothelioma of the external auditory canal in an adult. Head Neck. Jun. 2002;24(6):614-7. X-1. [pmid: 12112561].
1684 Harigaya A, Nako Y, Morikawa A, et al. Premature infant with severe periventricular leukomalacia associated with a large placental chorioangioma: a case report. J Perinatol. Apr–May. 2002;22(3):252-4. X-1. [pmid: 11948392].
1685 Hasson O, Shacham R, Nahlieli O, et al. A firm, bluish mass of the cheek in a 17-month-old child. J Oral Maxillofac Surg. Mar. 2002;60(3):301-4. X-1. [pmid: 11887144].
1686 Hatton MP, Remulla HD, Tolentino MJ, et al. Clinical applications of color Doppler imaging in the management of orbital lesions. Ophthal Plast Reconstr Surg. Nov. 2002;18(6):462-5. X-1. [pmid: 12439062].
1687 Heckl S, Aschoff A, Kunze S. Radiation-induced cavernous hemangiomas of the brain: a late effect predominantly in children. Cancer. Jun. 15. 2002;94(12):3285-91. X-1. [pmid: 12115362].
1688 Hein KD, Mulliken JB, Kozakewich HP, et al. Venous malformations of skeletal muscle. Plast Reconstr Surg. Dec. 2002;110(7):1625-35. X-1. [pmid: 12447041].
1689 Herman AR, Carucci JA. Management of obstructive airway hemangiomas in the neonate. J Drugs Dermatol. Dec. 2002;1(3):331-2. X-2. [pmid: 12851995].
1690 Herron MD, Coffin CM, Vanderhooft SL. Tufted angiomas: variability of the clinical morphology. Pediatr Dermatol. Sep–Oct. 2002;19(5):394-401. X-1. [pmid: 12383094].
1691 Hesselmann S, Micke O, Marquardt T, et al. Case report: Kasabach-Merritt syndrome: a review of the therapeutic options and a case report of successful treatment with radiotherapy and interferon alpha. Br J Radiol. Feb. 2002;75(890):180-4. X-1. [pmid: 11893644].
1692 Hohenleutner U, Landthaler M. Laser treatment of childhood haemangioma: progress or not?. Lancet. Aug. 17. 2002;360(9332):502-3. X-3, X-4. [pmid: 12241650].
1693 Holmberg E, Wallgren A, Holm LE, et al. Dose-response relationship for parathyroid adenoma after exposure to ionizing radiation in infancy. Radiat Res. Oct. 2002;158(4):418-23. X-3, X-4. [pmid: 12236809].
1694 Hopf M, Hopf JUG, Rohde E, et al. Endoscopically controlled laser therapy of recurrent epistaxis with the 940 nm diode laser. Med Laser Appl. October. 2002;17(3):231-41. X-1.
1695 Iwata N, Hattori K, Nakagawa T, et al. Hemangioma of the nasal cavity: a clinicopathologic study. Auris Nasus Larynx. Oct. 2002;29(4):335-9. X-1. [pmid: 12393037].
1696 Jain S, Goulstine D, Gottlob I. Acute adduction deficit in a 7-week-old infant. Strabismus. Dec. 2002;10(4):241-4. X-1, X-2. [pmid: 12660849].
1697 Jansen FE, van Huffelen AC, Witkamp T, et al. Diazepam-enhanced beta activity in Sturge Weber syndrome: its diagnostic significance in comparison with MRI. Clin Neurophysiol. Jul. 2002;113(7):1025-9. X-1. [pmid: 12088695].
1698 Jayakumar PN, Desai SV, Kovoor JM, et al. Percutaneous embolization of mandibular hemangioma: a case report. J Oral Maxillofac Surg. Aug. 2002;60(8):945-8. X-1, X-2. [pmid: 12149745].
1699 Kaira N, Mahapatra GK, Srivastava D, et al. Hemangioma of the oral cavity in a seven year old: a case report. J Indian Soc Pedod Prev Dent. Jun. 2002;20(2):49-50. X-2. [pmid: 12435016].
1700 Kaplan DL. Dermclinic. A photo quiz to hone dermatologic skills. Consultant. 9. 2002;42(7):836-42. 45. 6. passim. PMID: X-1.
1701 Karagama YG, Howarth K, Steel PR, et al. Lobular capillary haemangioma of the nasal vestibule: a rare entity. Int J Pediatr Otorhinolaryngol. Oct. 21. 2002;66(1):71-5. X-1, X-2. [pmid: 12363425].
1702 Kim DG, Choe WJ, Paek SH, et al. Radiosurgery of intracranial cavernous malformations. Acta Neurochir (Wien). Sep. 2002;144(9):869-78. discussion 78. X-1. [pmid: 12376768].
1703 Koc ON, Day J, Nieder M, et al. Allogeneic mesenchymal stem cell infusion for treatment of metachromatic leukodystrophy (MLD) and Hurler syndrome (MPS-IH). Bone Marrow Transplant. Aug. 2002;30(4):215-22. X-1. [pmid: 12203137].
1704 Kontzoglou G, Triaridis S, Noussios G, et al. Subglottic hemangioma treated with interferon alpha 2A. Acta Otorhinolaryngol Belg. 2002;56(1):83-5. X-1, X-2. [pmid: 11894636].
1705 Kossoff EH, Buck C, Freeman JM. Outcomes of 32 hemispherectomies for Sturge-Weber syndrome worldwide. Neurology. Dec. 10. 2002;59(11):1735-8. X-1. [pmid: 12473761].
1706 Kullendorff CM, Cwikiel W, Sandstrom S. Embolization of hepatic hemangiomas in infants. Eur J Pediatr Surg. Oct. 2002;12(5):348-52. X-1. [pmid: 12469266].
1707 Kumar VH, Clive J, Rosenkrantz TS, et al. Inguinal hernia in preterm infants (< or = 32-week gestation). Pediatr Surg Int. Mar. 2002;18(2–3):147-52. X-1. [pmid: 11956782].
1708 Kuo MF, Wang HS, Chen MT. Sincipital encephalocele mismanaged as a facial hemangioma. Pediatr Neurol. May. 2002;26(5):408-10. X-1. [pmid: 12057807].
1709 Leaute-Labreze C, Boralevi F, Pedespan JM, et al. Pulsed dye laser for Sturge-Weber syndrome. Arch Dis Child. Nov. 2002;87(5):434-5. X-1. [pmid: 12390926].
1710 Lee CH. Intestinal obstruction caused by infarcted splenic hemangioma with renal vein thrombosis in a newborn: a case report. Int Surg. Jul–Sep. 2002;87(3):157-9. X-1, X-2. [pmid: 12403090].
1711 Lim SL, Ng Sb A, Tan GM. Ilioinguinal and iliohypogastric nerve block revisited: single shot versus double shot technique for hernia repair in children. Paediatr Anaesth. Mar. 2002;12(3):255-60. X-1. [pmid: 11903940].
1712 Lu CC, Ko SF, Liang CD, et al. Infantile hepatic hemangioendothelioma presenting as early heart failure: report of two cases. Chang Gung Med J. Jun. 2002;25(6):405-10. X-1. [pmid: 12173671].
1713 Mahendran R, White SI, Clark AH, et al. Response of childhood tufted angioma to the pulsed-dye laser. J Am Acad Dermatol. Oct. 2002;47(4):620-2. X-1. [pmid: 12271313].
1714 Mara M, Calda P, Zizka Z, et al. Fetal anemia, thrombocytopenia, dilated umbilical vein, and cardiomegaly due to a voluminous placental chorioangioma. A case report. Fetal Diagn Ther. Sep–Oct. 2002;17(5):286-92. X-1. [pmid: 12169813].
1715 Marler JJ, Rubin JB, Trede NS, et al. Successful antiangiogenic therapy of giant cell angioblastoma with interferon alfa 2b: report of 2 cases. Pediatrics. Feb. 2002;109(2):E37. X-1. [pmid: 11826247].
1716 Martinez MI, Sanchez-Carpintero I, North PE, et al. Infantile hemangioma: clinical resolution with 5% imiquimod cream. Arch Dermatol. Jul. 2002;138(7):881-4. discussion 4. X-2. [pmid: 12071813].
1717 Matitiau A, Birk E, Schonfeld T, et al. Stent implantation for long-segment coarctation of aorta in infant with facial and mediastinal hemangioma. Catheter Cardiovasc Interv. Apr. 2002;55(4):510-2. X-2. [pmid: 11948901].
1718 Mazoyer E, Enjolras O, Laurian C, et al. Coagulation abnormalities associated with extensive venous malformations of the limbs: differentiation from Kasabach-Merritt syndrome. Clin Lab Haematol. Aug. 2002;24(4):243-51. X-1. [pmid: 12181029].
1719 McCarthy JG, Borud LJ, Schreiber JS. Hemangiomas of the nasal tip. Plast Reconstr Surg. Jan. 2002;109(1):31-40. X-4. [pmid: 11786788].
1720 Miura K, Han G, Sano M, et al. Regression of congenital fibrosarcoma to hemangiomatous remnant with histological and genetic findings. Pathol Int. Sep. 2002;52(9):612-8. X-1. [pmid: 12406191].
1721 Mohan UR, Hay AA, Cleary MA, et al. Cardiovascular changes in children with mucopolysaccharide disorders. Acta Paediatr. 2002;91(7):799-804. X-1. [pmid: 12200906].
1722 Mulliken JB, Rogers GF, Marler JJ. Circular excision of hemangioma and purse-string closure: the smallest possible scar. Plast Reconstr Surg. Apr. 15. 2002;109(5):1544-54. discussion 55. X-3, X-4. [pmid: 11932595].
1723 Naftchi S, la Cour M. A case of central visual loss in a child due to macular cavernous haemangioma of the retina. Acta Ophthalmol Scand. Oct. 2002;80(5):550-2. X-1. [pmid: 12390171].
1724 Nassiri SJ. Contralateral exploration is not mandatory in unilateral inguinal hernia in children: a prospective 6-year study. Pediatr Surg Int. Sep. 2002;18(5–6):470-1. X-1. [pmid: 12415383].
1725 Pascual-Castroviejo I, Frutos R, Viano J, et al. Cobb syndrome: case report. J Child Neurol. Nov. 2002;17(11):847-9. X-1, X-2. [pmid: 12585726].
1726 Perez J, Pardo J, Gomez C. Vincristine--an effective treatment of corticoid-resistant life-threatening infantile hemangiomas. Acta Oncol. 2002;41(2):197-9. X-1, X-2. [pmid: 12102167].
1727 Picker L. Saving face. Parents. 2002;77(5):85. PMID: X-2.
1728 Poetke M, Jamil B, Muller U, et al. Diffuse neonatal hemangiomatosis associated with Simpson-Golabi-Behmel syndrome: a case report. Eur J Pediatr Surg. Feb. 2002;12(1):59-62. X-1. [pmid: 11967762].
1729 Pokorny JJ, Roth F, Balfour I, et al. An unusual complication of the treatment of a hemangioma. Ann Plast Surg. Jan. 2002;48(1):83-7. X-2. [pmid: 11773735].
1730 Pomeranz A, Libman L, Pomeranz M, et al. Ambulatory blood pressure monitoring in children with isolated haematuria. Pediatr Nephrol. Nov. 2002;17(11):938-42. X-1. [pmid: 12432438].
1731 Price T, Fayad G. Abducens nerve palsy as the sole presenting symptom of petrous apicitis. J Laryngol Otol. Sep. 2002;116(9):726-9. X-1. [pmid: 12437811].
1732 Prokurat A, Kluge P, Chrupek M, et al. Hemangioma of the liver in children: proliferating vascular tumor or congenital vascular malformation?. Med Pediatr Oncol. Nov. 2002;39(5):524-9. X-1. [pmid: 12228911].
1733 Raja KA, Schurman S, D’Mello R G, et al. Responsiveness of hypercalciuria to thiazide in Dent’s disease. J Am Soc Nephrol. Dec. 2002;13(12):2938-44. X-1. [pmid: 12444212].
1734 Ratageri VH, Rajshankar S. Palatal hemangioma with cleft zero. Indian Pediatr. Jul. 2002;39(7):693-4. X-1, X-2. [pmid: 12147901].
1735 Ritter MR, Dorrell MI, Edmonds J, et al. Insulin-like growth factor 2 and potential regulators of hemangioma growth and involution identified by large-scale expression analysis. Proc Natl Acad Sci U S A. May. 28. 2002;99(11):7455-60. X-1. [pmid: 12032304].
1736 Rohana J, Boo NY, Hayati AR, et al. Diffuse neonatal haemangiomatosis: a rare cause of haemorrhagic shock and refractory coagulopathy in the newborn. Med J Malaysia. Sep. 2002;57(3):364-7. X-1. [pmid: 12440278].
1737 Rozylo-Kalinowska I, Brodzisz A, Galkowska E, et al. Application of Doppler ultrasonography in congenital vascular lesions of the head and neck. Dentomaxillofac Radiol. Jan. 2002;31(1):2-6. X-1. [pmid: 11803381].
1738 Sarkar M, Odegard K, Laussen P. Cardiac surgery in a child with sacral and intrasacral haemangioma. Paediatr Anaesth. Jul. 2002;12(6):552-5. X-2. [pmid: 12139599].
1739 Schrottner O, Unger F, Eder HG, et al. Gamma-Knife radiosurgery of mesiotemporal tumour epilepsy observations and long-term results. Acta Neurochir Suppl. 2002;84:49-55. X-1. [pmid: 12379004].
1740 Shalaby R, Desoky A. Needlescopic inguinal hernia repair in children. Pediatr Surg Int. Mar. 2002;18(2–3):153-6. X-1. [pmid: 11956783].
1741 Singh AD, Ahmad NN, Shields CL, et al. Solitary retinal capillary hemangioma: lack of genetic evidence for von Hippel-Lindau disease. Ophthalmic Genet. Mar. 2002;23(1):21-7. X-1. [pmid: 11910555].
1742 Singh AD, Nouri M, Shields CL, et al. Treatment of retinal capillary hemangioma. Ophthalmology. Oct. 2002;109(10):1799-806. X-1. [pmid: 12359597].
1743 Sleep TJ, Fairhurst JJ, Manners RM, et al. Doppler ultrasonography to aid diagnosis of orbital capillary haemangioma in neonates. Eye (Lond). May. 2002;16(3):316-9. X-2. [pmid: 12032724].
1744 Sugarman JL, Mauro TM, Frieden IJ. Treatment of an ulcerated hemangioma with recombinant platelet-derived growth factor. Arch Dermatol. Mar. 2002;138(3):314-6. X-2. [pmid: 11902979].
1745 Tamburrini G, Iannelli A, Caldarelli M, et al. Large cerebral cavernoma mimicking a brain tumor. Pediatr Neurosurg. Aug. 2002;37(2):105-6. X-1. [pmid: 12145521].
1746 Tang P, Hornicek FJ, Gebhardt MC, et al. Surgical treatment of hemangiomas of soft tissue. Clin Orthop Relat Res. Jun. 2002;(399):205-10. X-1. [pmid: 12011711].
1747 Triglia JM, Nazarian B, Sudre-Levillain I, et al. Virtual laryngotracheal endoscopy based on geometric surface modeling using spiral computed tomography data. Ann Otol Rhinol Laryngol. Jan. 2002;111(1):36-43. X-1. [pmid: 11800368].
1748 Tubbs RS, Wellons JC 3rd, Oakes WJ. Hemangioma of the transverse sinus. Pediatr Neurosurg. Nov. 2002;37(5):278-9. X-1, X-2. [pmid: 12411724].
1749 Tuxhorn IE, Pannek HW. Epilepsy surgery in bilateral Sturge-Weber syndrome. Pediatr Neurol. May. 2002;26(5):394-7. X-1. [pmid: 12057803].
1750 Vachharajani A, Paes B. Orbital lymphangioma with non-contiguous cerebral arteriovenous malformation, manifesting with thrombocytopenia (Kasabach-Merritt syndrome) and intracerebral hemorrhage. Acta Paediatr. 2002;91(1):98-9. X-1. [pmid: 11883828].
1751 Van Doorne L, De Maeseneer M, Stricker C, et al. Diagnosis and treatment of vascular lesions of the lip. Br J Oral Maxillofac Surg. Dec. 2002;40(6):497-503. X-2. [pmid: 12464208].
1752 Ville D, Enjolras O, Chiron C, et al. Prophylactic antiepileptic treatment in Sturge-Weber disease. Seizure. Apr. 2002;11(3):145-50. X-1. [pmid: 12018956].
1753 Walker GM, Abu-Rajab R, MacLennan A, et al. Kasabach-Merritt syndrome in a neonate caused by a kaposiform haemangioendothelioma. Med Pediatr Oncol. Jun. 2002;38(6):424-7. X-1. [pmid: 11984805].
1754 Walter JW, North PE, Waner M, et al. Somatic mutation of vascular endothelial growth factor receptors in juvenile hemangioma. Genes Chromosomes Cancer. Mar. 2002;33(3):295-303. X-1, X-3. [pmid: 11807987].
1755 Wananukul S. Clinical manifestation and management of hemangiomas of infancy. J Med Assoc Thai. Jun. 2002;85(Suppl 1):S280-5. X-3, X-4. [pmid: 12188424].
1756 Wananukul S, Chatproedprai S. Ulcerated hemangiomas: clinical features and management. J Med Assoc Thai. Nov. 2002;85(11):1220-5. X-3, X-4. [pmid: 12546320].
1757 Warren SM, Longaker MT, Zide BM. The subunit approach to nasal tip hemangiomas. Plast Reconstr Surg. Jan. 2002;109(1):25-30. X-2. [pmid: 11786787].
1758 Williams HJ, Wake MJ, John PR. Intraosseous haemangioma of the mandible: a case report. Pediatr Radiol. Aug. 2002;32(8):605-8. X-2. [pmid: 12136355].
1759 Wong SN, Tay YK. Tufted angioma: a report of five cases. Pediatr Dermatol. Sep–Oct. 2002;19(5):388-93. X-1. [pmid: 12383093].
1760 Yang CH, Ohara K. Successful surgical treatment of verrucous hemangioma: a combined approach. Dermatol Surg. Oct. 2002;28(10):913-19. discussion 20. X-1. [pmid: 12410675].
1761 Yang KH, Kim DS, Choi JU. The reversible focal MRI abnormalities in complex partial seizure: technical instruction. Childs Nerv Syst. Dec. 2002;18(12):722-4. X-1. [pmid: 12483359].
1762 Yavuzer R, Latifoglu O, Ozmen S, et al. Unilateral cleft lip complicated by a hemangioma. Plast Reconstr Surg. Sep. 15. 2002;110(4):1084-7. X-1. [pmid: 12198422].
1763 Zalel Y, Gamzu R, Weiss Y, et al. Role of color Doppler imaging in diagnosing and managing pregnancies complicated by placental chorioangioma. J Clin Ultrasound. Jun. 2002;30(5):264-9. X-1. [pmid: 12116105].
1764 Zenge JP, Fenton L, Lovell MA, et al. Case report: infantile hemangioendothelioma. Curr Opin Pediatr. Feb. 2002;14(1):99-102. X-1. [pmid: 11880743].
1765 Agesta N, Boralevi F, Sarlangue J, et al. Life-threatening haemorrhage as a complication of a congenital haemangioma. Acta Paediatr. Oct. 2003;92(10):1216-8. X-1, X-2. [pmid: 14632343].
1766 Akabane N, Hamanaka T. Histopathological study of a case with glaucoma due to Sturge-Weber syndrome. Jpn J Ophthalmol. Mar–Apr. 2003;47(2):151-7. X-1. [pmid: 12738548].
1767 Allen RM, Sandquist MA, Piatt JH Jr, et al. Ultrasonographic screening in infants with isolated spinal strawberry nevi. J Neurosurg. Apr. 2003;98(3 Suppl):247-50. X-1. [pmid: 12691379].
1768 Andronikou S, Mandelstam S, Fasulakis S. MRI and preoperative embolization of a nasal cavity haemangioma in a child. Australas Radiol. Dec. 2003;47(4):386-8. X-2. [pmid: 14641190].
1769 Andronikou S, McHugh K, Jadwat S, et al. MRI features of bilateral parotid haemangiomas of infancy. Eur Radiol. Apr. 2003;13(4):711-6. X-3, X-4. [pmid: 12664107].
1770 Aoyagi N, Kojima K, Kasai H. Review of spinal epidural cavernous hemangioma. Neurol Med Chir (Tokyo). Oct. 2003;43(10):471-5. discussion 6. X-1. [pmid: 14620197].
1771 Bejarano PA, Serrano MF, Casillas J, et al. Concurrent infantile hemangioendothelioma and mesenchymal hamartoma in a developmentally arrested liver of an infant requiring hepatic transplantation. Pediatr Dev Pathol. Nov–Dec. 2003;6(6):552-7. X-1, X-2. [pmid: 15018455].
1772 Bonaga S, Bardi C, Gigante C, et al. Synovial involvement in hemangiomatosis. Arch Orthop Trauma Surg. Apr. 2003;123(2–3):102-6. X-1. [pmid: 12721689].
1773 Brasanac D, Janic D, Boricic I, et al. Retroperitoneal kaposiform hemangioendothelioma with tufted angioma-like features in an infant with Kasabach-Merritt syndrome. Pathol Int. Sep. 2003;53(9):627-31. X-1. [pmid: 14507321].
1774 Caldarella A, Buccoliero AM, Taddei A, et al. Hemangioma of the umbilical cord: report of a case. Pathol Res Pract. 2003;199(1):51-5. X-1. [pmid: 12650519].
1775 Cansiz H, Yener M, Dervisoglu S, et al. Hemangioendothelioma of the frontal bone in a child. J Craniofac Surg. Sep. 2003;14(5):724-8. X-1. [pmid: 14501337].
1776 Cansiz H, Yener M, Kalekoglu N, et al. Arteriovenous malformation of the maxillary sinus and mandible: a case report. Ear Nose Throat J. Aug. 2003;82(8):608-10. 12. 14. X-1. [pmid: 14503098].
1777 Chang SE, Roh KH, Lee MW, et al. Microvenular hemangioma in a boy with acute myelogenous leukemia. Pediatr Dermatol. May–Jun. 2003;20(3):266-7. X-1. [pmid: 12787280].
1778 Chen CC, Kong MS, Yang CP, et al. Hepatic hemangioendothelioma in children: analysis of thirteen cases. Acta Paediatr Taiwan. Jan–Feb. 2003;44(1):8-13. X-1. [pmid: 12800377].
1779 Chung MT, Chen CH, Chiu CH, et al. Successful nonoperative therapy for Kaposiform hemangioendothelioma involving the neck: report of 1 case. Otolaryngol Head Neck Surg. Nov. 2003;129(5):605-7. X-1. [pmid: 14595290].
1780 Coats DK, O’Neil JW, D’Elia VJ, et al. SubTenon’s infusion of steroids for treatment of orbital hemangiomas. Ophthalmology. Jun. 2003;110(6):1255-9. X-4. [pmid: 12799256].
1781 Comi AM, Hunt P, Vawter MP, et al. Increased fibronectin expression in sturge-weber syndrome fibroblasts and brain tissue. Pediatr Res. May. 2003;53(5):762-9. X-1. [pmid: 12621118].
1782 Coras B, Hohenleutner U, Landthaler M, et al. Spindle cell hemangioma. Dermatol Surg. Aug. 2003;29(8):875-8. X-1, X-2. [pmid: 12859394].
1783 Correa-Rivas MS, Colon-Gonzalez G, Lugo-Vicente H. Cavernous hemangioma presenting as a right adnexal mass in a child. P R Health Sci J. Sep. 2003;22(3):311-3. X-1. [pmid: 14619460].
1784 Dasgupta NR, Bentz ML. Nasal gliomas: identification and differentiation from hemangiomas. J Craniofac Surg. Sep. 2003;14(5):736-8. X-1. [pmid: 14501339].
1785 Davies BW, Fraser N, Najmaldin AS, et al. A prospective study of neonatal inguinal herniotomy: the problem of the postoperative hydrocele. Pediatr Surg Int. Apr. 2003;19(1–2):68-70. X-1. [pmid: 12721728].
1786 Deb G. Kaposiform hemangioendothelioma and therapy with interferon-alpha. Med Pediatr Oncol. Dec. 2003;41(6):593. X-1. [pmid: 14595731].
1787 Douri T. Segmental facial hemangioma accompanied by brain anomalies: report of a case. Dermatol Online J. Dec. 2003;9(5):22. X-2. [pmid: 14996395].
1788 Dumortier J, Vaillant E, Boillot O, et al. Diagnosis and treatment of biliary obstruction caused by portal cavernoma. Endoscopy. May. 2003;35(5):446-50. X-1. [pmid: 12701019].
1789 Fawehinmi O, Abdulaziz A, Al Ghamdi S. Review of Congenital Neck Masses in Assir Central Hospital of Saudi Arabia. Journal of the Bahrain Medical Society. July. 2003;15(3):127-31. PMID: X-1.
1790 Feller L, Lemmer J. Encephalotrigeminal angiomatosis. Sadj. Oct. 2003;58(9):370-3. X-1. [pmid: 14964051].
1791 Firth PG, Ahmed MI. Systemic embolism in an infant following haemangioma embolization: a two-step process. Paediatr Anaesth. Oct. 2003;13(8):728-32. X-1. [pmid: 14535915].
1792 Forschner A, Harms D, Metzler G, et al. Ulcerated epithelioid hemangioendothelioma of the foot in childhood. J Am Acad Dermatol. Jul. 2003;49(1):113-6. X-1. [pmid: 12833020].
1793 Franc-Guimond J, Houle AM, Barrieras D. The Proteus syndrome associated with life threatening hematuria. J Urol. Dec. 2003;170(6 Pt 1):2418-9. X-1. [pmid: 14634442].
1794 Giaoui L, Princ G, Chiras J, et al. Treatment of vascular malformations of the mandible: a description of 12 cases. Int J Oral Maxillofac Surg. Apr. 2003;32(2):132-6. X-1. [pmid: 12729771].
1795 Gold L, Nazarian LN, Johar AS, et al. Characterization of maxillofacial soft tissue vascular anomalies by ultrasound and color Doppler imaging: an adjuvant to computed tomography and magnetic resonance imaging. J Oral Maxillofac Surg. Jan. 2003;61(1):19-31. X-1. [pmid: 12524603].
1796 Gordon S. Birthmark basics. Parents. 2003;78(8):83. PMID: X-2.
1797 Gralla J, Ganslandt O, Kober H, et al. Image-guided removal of supratentorial cavernomas in critical brain areas: application of neuronavigation and intraoperative magnetic resonance imaging. Minim Invasive Neurosurg. Apr. 2003;46(2):72-7. X-1. [pmid: 12761675].
1798 Groot D, Rao J, Johnston P, et al. Algorithm for using a long-pulsed Nd:YAG laser in the treatment of deep cutaneous vascular lesions. Dermatol Surg. Jan. 2003;29(1):35-42. X-1. [pmid: 12534510].
1799 Guschmann M, Henrich W, Entezami M, et al. Chorioangioma--new insights into a well-known problem. I. Results of a clinical and morphological study of 136 cases. J Perinat Med. 2003;31(2):163-9. X-1. [pmid: 12747233].
1800 Hadfield PJ, Lloyd-Faulconbridge RV, Almeyda J, et al. The changing indications for paediatric tracheostomy. Int J Pediatr Otorhinolaryngol. Jan. 2003;67(1):7-10. X-3, X-4. [pmid: 12560142].
1801 Hayashi N, Masumoto T, Okubo T, et al. Hemangiomas in the face and extremities: MR-guided sclerotherapy--optimization with monitoring of signal intensity changes in vivo. Radiology. Feb. 2003;226(2):567-72. X-1. [pmid: 12563156].
1802 Hohenleutner U, Landthaler M. Abstracts from the literature. Journal of Pediatrics. 2003;142(3):354-5. PMID: X-1.
1803 Honda M, Toda K, Baba H, et al. Congenital cavernous angioma of the temporal bone: case report. Surg Neurol. Feb. 2003;59(2):120-3. discussion 3. X-1. [pmid: 12648911].
1804 Inuzuka M, Tomita K, Tokura Y, et al. Congenital self-healing reticulohistiocytosis presenting with hemorrhagic bullae. J Am Acad Dermatol. May. 2003;48(5 Suppl):S75-7. X-1. [pmid: 12734483].
1805 Ishikawa K, Saitoh M, Chida S. Detection of bladder hemangioma in a child by blood-pool scintigraphy. Pediatr Radiol. Jun. 2003;33(6):433-5. X-1, X-2. [pmid: 12768257].
1806 Jeon SY, Jeong JH, Kim HS, et al. Hemifacial degloving approach for medial maxillectomy: a modification of midfacial degloving approach. Laryngoscope. Apr. 2003;113(4):754-6. X-1. [pmid: 12671442].
1807 Kanamori Y, Hashizume K, Kitano Y, et al. Congenital extrahepatic portocaval shunt (Abernethy type 2), huge liver mass, and patent ductus arteriosus--a case report of its rare clinical presentation in a young girl. J Pediatr Surg. Apr. 2003;38(4):E15. X-1. [pmid: 12677602].
1808 Kaplan DL. Dermclinic. A photo quiz to hone dermatologic skills. Consultant. 2003;43(8):969. PMID: X-1.
1809 Kasahara M, Kiuchi T, Haga H, et al. Monosegmental living-donor liver transplantation for infantile hepatic hemangioendothelioma. J Pediatr Surg. Jul. 2003;38(7):1108-11. X-1. [pmid: 12861553].
1810 Khong PL, Burrows PE, Kozakewich HP, et al. Fast-flow lingual vascular anomalies in the young patient: is imaging diagnostic?. Pediatr Radiol. Feb. 2003;33(2):118-22. X-2. [pmid: 12557068].
1811 Kilde JD, Rhee JS, Balla AA, et al. Hemangioma of the sphenoid and ethmoid sinuses: two case reports. Ear Nose Throat J. Mar. 2003;82(3):217-21. X-1, X-2. [pmid: 12696244].
1812 Kiratli H, Bilgic S, Caglar M, et al. Intramuscular hemangiomas of extraocular muscles. Ophthalmology. Mar. 2003;110(3):564-8. X-1, X-2. [pmid: 12623822].
1813 Kleinman ME, Tepper OM, Capla JM, et al. Increased circulating AC133+ CD34+ endothelial progenitor cells in children with hemangioma. Lymphat Res Biol. 2003;1(4):301-7. X-3. [pmid: 15624558].
1814 Kolde G. Early pulsed-dye laser treatment of childhood haemangiomas. Lancet. Jan. 25. 2003;361(9354):348-9. author reply 9. X-3, X-4. [pmid: 12559891].
1815 Konez O, Burrows PE, Mulliken JB, et al. Angiographic features of rapidly involuting congenital hemangioma (RICH). Pediatr Radiol. Jan. 2003;33(1):15-9. X-1. [pmid: 12497230].
1816 Konrad D, Ellis G, Perlman K. Spontaneous regression of severe acquired infantile hypothyroidism associated with multiple liver hemangiomas. Pediatrics. Dec. 2003;112(6 Pt 1):1424-6. X-2. [pmid: 14654623].
1817 Lau TK, Leung TY, Yu SC, et al. Prenatal treatment of chorioangioma by microcoil embolisation. Bjog. Jan. 2003;110(1):70-3. X-1. [pmid: 12504940].
1818 Lin DD, Barker PB, Kraut MA, et al. Early characteristics of Sturge-Weber syndrome shown by perfusion MR imaging and proton MR spectroscopic imaging. AJNR Am J Neuroradiol. Oct. 2003;24(9):1912-5. X-1. [pmid: 14561628].
1819 Lin MC, Chen CH, Chi CS. PHACE syndrome: report of one case. Acta Paediatr Taiwan. Nov–Dec. 2003;44(6):379-82. X-2. [pmid: 14983664].
1820 Lucas M, Costa AF, Garcia-Moreno JM, et al. Variable expression of cerebral cavernous malformations in carriers of a premature termination codon in exon 17 of the Krit1 gene. BMC Neurol. Jul. 23. 2003;3:5. X-1. [pmid: 12877753].
1821 Ly JQ, Sanders TG, Mulloy JP, et al. Osseous change adjacent to soft-tissue hemangiomas of the extremities: correlation with lesion size and proximity to bone. AJR Am J Roentgenol. Jun. 2003;180(6):1695-700. X-1. [pmid: 12760946].
1822 Magee WP, Ajkay N, Rosenblum RS. Surgical treatment of lip hemangiomas. International Pediatrics. 2003;18(1):49-54. PMID: X-1, X-3, X-4.
1823 Mathiesen T, Edner G, Kihlstrom L. Deep and brainstem cavernomas: a consecutive 8-year series. J Neurosurg. Jul. 2003;99(1):31-7. X-1. [pmid: 12854740].
1824 Matsumoto K, Nakanishi H, Koizumi Y, et al. Sclerotherapy of hemangioma with late involution. Dermatol Surg. Jun. 2003;29(6):668-71. discussion 71. X-2. [pmid: 12786717].
1825 Maymon R, Hermann G, Reish O, et al. Chorioangioma and its severe infantile sequelae: case report. Prenat Diagn. Dec. 15. 2003;23(12):976-80. X-1. [pmid: 14663833].
1826 McQueen CT, Cullen RD. Endoscopic ablation of distal tracheal lesions using Nd:YAG contact laser. Int J Pediatr Otorhinolaryngol. Feb. 2003;67(2):181-3. X-2. [pmid: 12623156].
1827 Mendez R, Capdevila A, Tellado MG, et al. Kaposiform hemangioendothelioma associated with Milroy’s disease (primary hereditary lymphedema). J Pediatr Surg. Jul. 2003;38(7):E9-12. X-1. [pmid: 12861592].
1828 Michel JL. Treatment of hemangiomas with 595 nm pulsed dye laser dermobeam. Eur J Dermatol. Mar–Apr. 2003;13(2):136-41. X-3, X-4. [pmid: 12695128].
1829 Miles MS, Brunssen SH. Psychometric properties of the parental stressor scale: infant hospitalization. Adv Neonatal Care. Aug. 2003;3(4):189-96. X-1. [pmid: 14502526].
1830 Miller KK, Giuffre RM, Kellner B, et al. Congenital right ventricular diverticulum in association with disseminated neonatal hemangiomatosis. Can J Cardiol. Mar. 15. 2003;19(3):303-5. X-1. [pmid: 12677288].
1831 Morton DL, Hoon DS, Cochran AJ, et al. Lymphatic mapping and sentinel lymphadenectomy for early-stage melanoma: therapeutic utility and implications of nodal microanatomy and molecular staging for improving the accuracy of detection of nodal micrometastases. Ann Surg. Oct. 2003;238(4):538-49. discussion 49–50. X-1. [pmid: 14530725].
1832 Naiman AN, Ayari S, Froehlich P. Controlled risk of stenosis after surgical excision of laryngeal hemangioma. Arch Otolaryngol Head Neck Surg. Dec. 2003;129(12):1291-5. X-4. [pmid: 14676154].
1833 Ng SK, Soo G, Abdullah V, et al. Congenital glabellar hemangioma. Otolaryngol Head Neck Surg. Jul. 2003;129(1):161-2. X-1. [pmid: 12869938].
1834 Ng WT, Kong CK. Argon plasma coagulation for blue rubber bleb nevus syndrome in a female infant. Eur J Pediatr Surg. Apr. 2003;13(2):137-9. X-1. [pmid: 12776249].
1835 Nieto J, Hinojosa J, Munoz MJ, et al. Intraventricular cavernoma in pediatric age. Childs Nerv Syst. Jan. 2003;19(1):60-2. X-1. [pmid: 12541090].
1836 Odemis E, Cakir M, Aynaci FM. Rhombencephalosynapsis associated with cutaneous pretibial hemangioma in an infant. J Child Neurol. Mar. 2003;18(3):225-8. X-1, X-2. [pmid: 12731648].
1837 O’Keefe M, Lanigan B, Byrne SA. Capillary haemangioma of the eyelids and orbit: a clinical review of the safety and efficacy of intralesional steroid. Acta Ophthalmol Scand. Jun. 2003;81(3):294-8. X-4. [pmid: 12780411].
1838 Onesti GM, Mazzocchi M, Mezzana P, et al. Different types of embolization before surgical excision of haemangiomas of the face. Acta Chir Plast. 2003;45(2):55-60. X-2. [pmid: 12921261].
1839 Oviedo A, Abramson LP, Worthington R, et al. Congenital pulmonary capillary hemangiomatosis: Report of two cases and review of the literature. Pediatr Pulmonol. Sep. 2003;36(3):253-6. X-1. [pmid: 12910588].
1840 Ozsoylu S. Megadose methylprednisolone for Kasabach-Merritt syndrome. Eur J Pediatr. Jul. 2003;162(7–8):562. author reply 3–4. X-1. [pmid: 12748852].
1841 Pascual-Castroviejo I, Viano J, Pascual-Pascual SI, et al. Do cutaneous hemangiomas and internal vascular anomalies follow the same evolution?. Neurology. Jul. 8. 2003;61(1):140-1. X-1. [pmid: 12847180].
1842 Puig S, Aref H, Brunelle F. Double-needle sclerotherapy of lymphangiomas and venous angiomas in children: a simple technique to prevent complications. AJR Am J Roentgenol. May. 2003;180(5):1399-401. X-1. [pmid: 12704058].
1843 Rades D, Bajrovic A, Alberti W, et al. Is there a dose-effect relationship for the treatment of symptomatic vertebral hemangioma?. Int J Radiat Oncol Biol Phys. Jan. 1. 2003;55(1):178-81. X-1. [pmid: 12504051].
1844 Radhakrishna S. Picture quiz. Perinatology. May/June. 2003;5(3):125-6. PMID: X-1.
1845 Ramli N, Sachet M, Bao C, et al. Cerebrofacial venous metameric syndrome (CVMS) 3: Sturge-Weber syndrome with bilateral lymphatic/venous malformations of the mandible. Neuroradiology. Oct. 2003;45(10):687-90. X-1. [pmid: 13680025].
1846 Re M, Forte V, Berardi C, et al. Role of endoscopic CO2 laser surgery in the treatment of congenital infantile subglottic hemangioma. Experience in the Department of Otolaryngology, “Sick Children Hospital”, Toronto, Canada. Acta Otorhinolaryngol Ital. Jun. 2003;23(3):175-9. X-3, X-4. [pmid: 14677310].
1847 Rehman SU, Hazir T, Nisar YB, et al. Blue rubber bleb nevus syndrome: associated with severe GI bleeding requiring one hundred blood transfusions. J Pak Med Assoc. Nov. 2003;53(11):570-3. X-1. [pmid: 14738268].
1848 Reich P, Winkler J, Straube A, et al. Molecular genetic investigations in the CCM1 gene in sporadic cerebral cavernomas. Neurology. Apr. 8. 2003;60(7):1135-8. X-1. [pmid: 12682320].
1849 Ritter MR, Moreno SK, Dorrell MI, et al. Identifying potential regulators of infantile hemangioma progression through large-scale expression analysis: a possible role for the immune system and indoleamine 2,3 dioxygenase (IDO) during involution. Lymphat Res Biol. 2003;1(4):291-9. X-1, X-3. [pmid: 15624557].
1850 Roos JE, Pfiffner R, Stallmach T, et al. Infantile hemangioendothelioma. Radiographics. Nov–Dec. 2003;23(6):1649-55. X-1. [pmid: 14615570].
1851 Schiavetti A, De Pasquale MD, Di Salvo S, et al. Recombinant interferon alfa 2a in hepatic hemangiomatosis with congestive heart failure: a case report. Pediatr Hematol Oncol. Mar. 2003;20(2):161-5. X-2. [pmid: 12554528].
1852 Sefau SO, Dorey MW, Brownstein S, et al. Radiation-induced chorioretinal degeneration: a clinicopathological report of three cases. Can J Ophthalmol. Feb. 2003;38(1):57-62. X-1. [pmid: 12608519].
1853 Shenkar R, Elliott JP, Diener K, et al. Differential gene expression in human cerebrovascular malformations. Neurosurgery. Feb. 2003;52(2):465-77. discussion 77–8. X-1. [pmid: 12535382].
1854 Simon NP, Simon MW. Large cavernous hemangiomas: The need for closer monitoring. International Pediatrics. 2003;18(1):30-2. X-1.
1855 Skorin L Jr. Can You Identify These Facial Findings?. Consultant. 01. Sep. 2003;43(10):1245-60. X-1.
1856 Skorin L Jr, et al. Photo quiz: can you identify these facial findings?. Consultant. 2003;43(10):1245-6. 50. 53. passim. PMID: X-1.
1857 Skrinjaric I, Jukic J, Skrinjaric K, et al. Dental and minor physical anomalies in children with developmental disorders--a discriminant analysis. Coll Antropol. Dec. 2003;27(2):769-78. X-1. [pmid: 14746170].
1858 Slaughter K, Sullivan T, Boulton J, et al. Early surgical intervention as definitive treatment for ocular adnexal capillary haemangioma. Clin Experiment Ophthalmol. Oct. 2003;31(5):418-23. X-4. [pmid: 14516430].
1859 Soeda A, Sakai N, Iihara K, et al. Cobb syndrome in an infant: treatment with endovascular embolization and corticosteroid therapy: case report. Neurosurgery. Mar. 2003;52(3):711-5. discussion 4–5. X-1, X-2. [pmid: 12590699].
1860 Suziedelis AK. Cosmetic surgery for children with Down syndrome: the cruelest cut of all?. Health Care Ethics USA. 2003;11(1):E1. X-1. [pmid: 16184692].
1861 Szabo I, Szabo B. Expanding masses of the posterior orbit. Oftalmologia. 2003;58(3):39-44. X-6. [pmid: 14702731].
1862 Szymik-Kantorowicz S, Partyka L, Dembinska-Kiec A, et al. Vascular endothelial growth factor in monitoring therapy of hepatic haemangioendothelioma. Med Pediatr Oncol. Mar. 2003;40(3):196-7. X-1. [pmid: 12518353].
1863 Tan C, Alphonso N, Anderson D, et al. Mediastinal haemangiomas in children. Eur J Cardiothorac Surg. Jun. 2003;23(6):1065-7. X-2. [pmid: 12829094].
1864 Tastekin A, Kantarci M, Onbas O, et al. Superior sternal cleft and minor hemangiomas in a newborn. Genet Couns. 2003;14(3):349-52. X-1. [pmid: 14577681].
1865 Toida M, Hasegawa T, Watanabe F, et al. Lobular capillary hemangioma of the oral mucosa: clinicopathological study of 43 cases with a special reference to immunohistochemical characterization of the vascular elements. Pathol Int. Jan. 2003;53(1):1-7. X-1. [pmid: 12558863].
1866 Tsao MN, Schwartz ML, Bernstein M, et al. Capillary hemangioma of the cavernous sinus. Report of two cases. J Neurosurg. Jan. 2003;98(1):169-74. X-1, X-2. [pmid: 12546367].
1867 Tubbs RS, Wellons IJ, Oakes WJ. Capillary hemangioma of the calvaria. Pediatr Neurosurg. Jul. 2003;39(2):112. X-2. [pmid: 12845203].
1868 Van Aalst JA, Bhuller A, Sadove AM. Pediatric vascular lesions. J Craniofac Surg. Jul. 2003;14(4):566-83. X-1, X-2. [pmid: 12867875].
1869 Van Calenbergh F, Demaerel P, Sciot R, et al. Acquired cerebellar cavernous angioma following childhood radiotherapy in a patient with neurofibromatosis type 1. Acta Neurol Belg. Jun. 2003;103(2):103-6. X-1. [pmid: 12892005].
1870 Wananukul S, Nuchprayoon I, Seksarn P. Treatment of Kasabach-Merritt syndrome: a stepwise regimen of prednisolone, dipyridamole, and interferon. Int J Dermatol. Sep. 2003;42(9):741-8. X-1. [pmid: 12956695].
1871 Waner M, North PE, Scherer KA, et al. The nonrandom distribution of facial hemangiomas. Arch Dermatol. Jul. 2003;139(7):869-75. X-3. [pmid: 12873881].
1872 Wang LY, Hung HY, Lee KS. Infantile subglottic hemangioma treated by intralesional steroid injection: report of one case. Acta Paediatr Taiwan. Jan–Feb. 2003;44(1):35-7. X-2. [pmid: 12800382].
1873 Warmann S, Bertram H, Kardorff R, et al. Interventional treatment of infantile hepatic hemangioendothelioma. J Pediatr Surg. Aug. 2003;38(8):1177-81. X-1. [pmid: 12891488].
1874 Watters K, O’Marcaigh A, Canny G, et al. Management of a large bronchial haemangioma in an infant. Int J Pediatr Otorhinolaryngol. Apr. 2003;67(4):429-33. X-2. [pmid: 12663120].
1875 Werle AH, Kirse DJ, Nopper AJ, et al. Osseous hemangioma of the maxilla in an infant. Otolaryngol Head Neck Surg. Jun. 2003;128(6):906-9. X-1, X-2. [pmid: 12825048].
1876 Williams EF 3rd, Hochman M, Rodgers BJ, et al. A psychological profile of children with hemangiomas and their families. Arch Facial Plast Surg. May–Jun. 2003;5(3):229-34. X-3. [pmid: 12756116].
1877 Williamson A, Patrylo PR, Lee S, et al. Physiology of human cortical neurons adjacent to cavernous malformations and tumors. Epilepsia. Nov. 2003;44(11):1413-9. X-1. [pmid: 14636349].
1878 Winstanley D, Graham B, Blair M, et al. Sacral hemangioma with sinus tract in an infant. Pediatr Dermatol. May–Jun. 2003;20(3):221-4. X-1, X-2. [pmid: 12787270].
1879 Witters I, Van Damme MT, Ramaekers P, et al. Benign multiple diffuse neonatal hemangiomatosis after a pregnancy complicated by polyhydramnios and a placental chorioangioma. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2003;106(1):83-5. X-2. [pmid: 12475589].
1880 Youssef JS, Quraishi HA. Cervicofacial hemangioma and its association with PHACE syndrome. Otolaryngol Head Neck Surg. May. 2003;128(5):758-60. X-2. [pmid: 12748574].
1881 Zacharia TT, Ittoop A, Perumpillichira JJ, et al. Sonographic appearance of a congenital parotid gland hemangiolymphangioma simulating malignancy in an infant. J Clin Ultrasound. Nov–Dec. 2003;31(9):493-6. X-1. [pmid: 14595742].
1882 Abe M, Tabuchi K, Tanaka S, et al. Capillary hemangioma of the central nervous system. J Neurosurg. Jul. 2004;101(1):73-81. X-1. [pmid: 15255254].
1883 Abid N, Rashid A. Haemangioma presenting as perianal ulcer in neonates. J Perinatol. May. 2004;24(5):327-8. X-3, X-4. [pmid: 15116132].
1884 Agostinelli C, Roncaroli F, Galassi E, et al. Leptomeningeal hemangioblastoma. Case illustration. J Neurosurg. Aug. 2004;101(1 Suppl):122. X-1. [pmid: 16206984].
1885 Al-Attar M, Verma R, Shannon RS, et al. Focal nodular hyperplasia in a child with hemihypertrophy and multiple cutaneous vascular malformations. Australas Radiol. Mar. 2004;48(1):77-9. X-1. [pmid: 15027928].
1886 Amer OT, Abd El-Rahma HA, Sherief LM, et al. Role of some viral infections in neonatal cholestasis. Egypt J Immunol. 2004;11(2):149-55. X-1. [pmid: 16734127].
1887 Andrade ZR, Garippo AL, Saldiva PH, et al. Immunohistochemical and in situ detection of cytomegalovirus in lung autopsies of children immunocompromised by secondary interstitial pneumonia. Pathol Res Pract. 2004;200(1):25-32. X-1. [pmid: 15157047].
1888 Aviles R, Boyce TG, Thompson DM. Pneumocystis carinii pneumonia in a 3-month-old infant receiving high-dose corticosteroid therapy for airway hemangiomas. Mayo Clin Proc. Feb. 2004;79(2):243-5. X-2. [pmid: 14959920].
1889 Bains HS, Cirino AC, Ticho BH, et al. Photodynamic therapy using verteporfin for a diffuse choroidal hemangioma in Sturge-Weber syndrome. Retina. Feb. 2004;24(1):152-5. X-1. [pmid: 15076958].
1890 Bakaris S, Karabiber H, Yuksel M, et al. Case of large placental chorioangioma associated with diffuse neonatal hemangiomatosis. Pediatr Dev Pathol. May–Jun. 2004;7(3):258-61. X-1, X-2. [pmid: 15022059].
1891 Banerjee R, Bharucha BA, Bhangale T, et al. Use of Blood Viscosity Parameters for Evaluation of Acute Idiopathic Hemiplegia of Childhood in Children of Indian Origin. International Pediatrics. 2004;19(1):48-51. X-1.
1892 Barankin B. Dermatology case challenge. Patient Care. 2004;38(12):67-8. PMID: X-2.
1893 Barankin B. Dermatology case challenge: a “red mark and bruising” on an infant’s face. Patient Care for the Nurse Practitioner. 2004:1p. PMID: X-1.
1894 Bent JP. Airway hemangiomas: contemporary management. Lymphat Res Biol. 2004;2(1):56-60. X-1, X-2. [pmid: 15609928].
1895 Bernal B, Altman N. Visual functional magnetic resonance imaging in patients with Sturge-Weber syndrome. Pediatr Neurol. Jul. 2004;31(1):9-15. X-1. [pmid: 15246485].
1896 Bhattacharya JJ, Luo CB, Alvarez H, et al. PHACES syndrome: a review of eight previously unreported cases with late arterial occlusions. Neuroradiology. Mar. 2004;46(3):227-33. X-3. [pmid: 14758450].
1897 Bilkay U, Tokat C, Ozek C, et al. Reconstruction of congenital absent columella. J Craniofac Surg. Jan. 2004;15(1):60-3. X-1. [pmid: 14704565].
1898 Blereau RP. Do you recognize these disorders?. Consultant. 01. Apr. 2004;44(4):605-10. X-1.
1899 Blereau RP. Photo quiz. Do you recognize these disorders? Consultant. 2004;44(4):605. PMID: X-1.
1900 Bowman RJ, Nischal KK, Patel K, et al. An ultrasound based classification of periocular haemangiomas. Br J Ophthalmol. Nov. 2004;88(11):1419-21. X-3, X-4. [pmid: 15489485].
1901 Brook I. Microbiology of infected hemangiomas in children. Pediatr Dermatol. Mar–Apr. 2004;21(2):113-6. X-1, X-3. [pmid: 15078348].
1902 Bukhari IA. Impetigo herpetiformis in a primigravida: successful treatment with etretinate. J Drugs Dermatol. Jul–Aug. 2004;3(4):449-51. X-1. [pmid: 15303793].
1903 Chen C, Yu Y, Zhen H. Sturge-Weber syndrome associated with early diffuse choroidal hemangiaoma: a case report. Yan Ke Xue Bao. Sep. 2004;20(3):168-70. X-1. [pmid: 15499725].
1904 Clark C, Cameron H, Moseley H, et al. Treatment of superficial cutaneous vascular lesions: experience with the KTP 532 nm laser. Lasers Med Sci. 2004;19(1):1-5. X-1. [pmid: 15316851].
1905 Cohen BA. Neonatal lesions: another baby and another cutaneous lesion -- and more on efficient recognition and management. Contemp Pediatr. 2004;21(10):39-40. 1. 5. passim. PMID: X-1.
1906 Cummings TJ, George TM, Fuchs HE, et al. The pathology of extracranial scalp and skull masses in young children. Clin Neuropathol. Jan–Feb. 2004;23(1):34-43. X-2. [pmid: 14986932].
1907 De Santis M, Cavaliere AF, Caruso A, et al. Hemangiomas and other congenital malformations in infants exposed to antiretroviral therapy in utero. JAMA. Jan. 21. 2004;291(3):305. X-1. [pmid: 14734592].
1908 Demir Z, Oktem F, Celebioglu S. Rare case of intramasseteric cavernous hemangioma in a three-year-old boy: a diagnostic dilemma. Ann Otol Rhinol Laryngol. Jun. 2004;113(6):455-8. X-1. [pmid: 15224828].
1909 Denier C, Labauge P, Brunereau L, et al. Clinical features of cerebral cavernous malformations patients with KRIT1 mutations. Ann Neurol. Feb. 2004;55(2):213-20. X-1. [pmid: 14755725].
1910 Desuter GR, El Makhloufi K, Francois GJ, et al. Postcricoid hemangioma: an overlooked cause of dysphagia in infants?-a case report. Dysphagia. Winter. 2004;19(1):48-51. X-2. [pmid: 14745646].
1911 Donati D, Albisinni U, Zavatta M, et al. Long-term roentgenographic evaluation of proximal femur prosthesis after tumor resection. Chir Organi Mov. Jul–Aug. 2004;89(3):191-203. X-1. [pmid: 15751586].
1912 Dondon MG, de Vathaire F, Shamsaldin A, et al. Cancer mortality after radiotherapy for a skin hemangioma during childhood. Radiother Oncol. Jul. 2004;72(1):87-93. X-1, X-3. [pmid: 15236880].
1913 Eber E. Short case presentation. Right-sided subglottic haemangioma. Paediatr Respir Rev. Mar. 2004;5(1):90-1. X-1, X-2. [pmid: 15230262].
1914 Erasmus CE, Beems T, Rotteveel JJ. Frontal ataxia in childhood. Neuropediatrics. Dec. 2004;35(6):368-70. X-1. [pmid: 15627946].
1915 Fawcett SL, Grant I, Hall PN, et al. Vincristine as a treatment for a large haemangioma threatening vital functions. Br J Plast Surg. Mar. 2004;57(2):168-71. X-2. [pmid: 15037175].
1916 Fitz EW, Newman SA. Neuro-ophthalmology of von Hippel-Lindau. Curr Neurol Neurosci Rep. Sep. 2004;4(5):384-90. X-1. [pmid: 15324605].
1917 Fogelholm R. Ionising radiation in infancy and adult cognitive function: radiation may not solely explain later cognitive function. BMJ. Mar. 6. 2004;328(7439):581-2. author reply 2. X-1. [pmid: 15001513].
1918 Fraunfelder FW, Fraunfelder FT, Corbett JJ. Isotretinoin-associated intracranial hypertension. Ophthalmology. Jun. 2004;111(6):1248-50. X-1. [pmid: 15177980].
1919 Freese PM, Svalander CT, Molne J, et al. Renal allograft glomerulopathy and the value of immunohistochemistry. Clin Nephrol. Oct. 2004;62(4):279-86. X-1. [pmid: 15524058].
1920 Frieden IJ, Haggstrom AN, McCulloch C, et al. Combined antiretroviral therapy during pregnancy and risk of congenital malformations. JAMA. Apr. 28. 2004;291(16):1961-2. author reply 2. X-1. [pmid: 15113813].
1921 George ME, Sharma V, Jacobson J, et al. Adverse effects of systemic glucocorticosteroid therapy in infants with hemangiomas. Arch Dermatol. Aug. 2004;140(8):963-9. X-4. [pmid: 15313812].
1922 Goyal R, Watts P, Lane CM, et al. Adrenal suppression and failure to thrive after steroid injections for periocular hemangioma. Ophthalmology. Feb. 2004;111(2):389-95. X-3, X-4. [pmid: 15019396].
1923 Greene AK, Rogers GF, Mulliken JB. Management of parotid hemangioma in 100 children. Plast Reconstr Surg. Jan. 2004;113(1):53-60. X-3, X-4. [pmid: 14707622].
1924 Gulati G, Sharma S, Kothari SS, et al. Comparison of echo and MRI in the imaging evaluation of intracardiac masses. Cardiovasc Intervent Radiol. Sep–Oct. 2004;27(5):459-69. X-1. [pmid: 15383848].
1925 Gurelik M, Ozum U, Erdogan H, et al. Orbital lymphangioma and its association with intracranial venous angioma. Br J Neurosurg. Apr. 2004;18(2):168-70. X-1. [pmid: 15176559].
1926 Hall P, Adami HO, Trichopoulos D, et al. Effect of low doses of ionising radiation in infancy on cognitive function in adulthood: Swedish population based cohort study. Bmj. Jan. 3. 2004;328(7430):19. X-3. [pmid: 14703539].
1927 Hayashi S, Kondoh T, Morishita A, et al. Congenital cavernous angioma exhibits a progressive decrease in size after birth. Childs Nerv Syst. Mar. 2004;20(3):199-203. X-1. [pmid: 14704811].
1928 Hockstein NG, Samadi DS, Gendron K, et al. Pediatric submandibular triangle masses: a fifteen-year experience. Head Neck. Aug. 2004;26(8):675-80. X-1. [pmid: 15287034].
1929 Ikeda T, Shimamoto K, Tanji N, et al. Cavernous hemangioma of the urinary bladder in an 8-year-old child. Int J Urol. Jun. 2004;11(6):429-31. X-1. [pmid: 15157217].
1930 Jansen FE, van der Worp HB, van Huffelen A, et al. Sturge-Weber syndrome and paroxysmal hemiparesis: epilepsy or ischaemia?. Dev Med Child Neurol. Nov. 2004;46(11):783-6. X-1. [pmid: 15540641].
1931 Karian VE, Buchanan T, Lord D, et al. Focus on skin disorders: vascular anomalies. “But they told us she had a hemangioma....”. Contemp Pediatr. 2004;21(7):51-4. 6. 7. 61. 4. passim. PMID: X-1.
1932 Kim HL, Im SA, Lim GY, et al. High grade hemangioendothelioma of the temporal bone in a child: a case report. Korean J Radiol. Jul–Sep. 2004;5(3):214-7. X-1. [pmid: 15467419].
1933 Kitagawa H, Kawase H, Wakisaka M, et al. Six cases of children with a benign cervical tumor who required tracheostomy. Pediatr Surg Int. Jan. 2004;20(1):51-4. X-2. [pmid: 14689216].
1934 Kitagawa N, Ohhama Y, Fukuzato Y, et al. Pericardial hemangioma presenting fetal cardiac tamponade and postnatal bronchostenosis. Pediatr Surg Int. May. 2004;20(5):376-7. X-1, X-2. [pmid: 15221363].
1935 Kocer U, Ozdemir R, Tiftikcioglu YO, et al. Soft tissue hemangioma formation within a previously excised intraosseous hemangioma site. J Craniofac Surg. Jan. 2004;15(1):82-3. X-1, X-2. [pmid: 14704569].
1936 Kumar S, Muranjan MN, Tullu MS, et al. Incomplete monosymptomatic leptomeningeal angiomatosis. Indian J Pediatr. Oct. 2004;71(10):947. X-1. [pmid: 15531846].
1937 Kuo JS, Chen JC, Yu C, et al. Gamma knife radiosurgery for benign cavernous sinus tumors: quantitative analysis of treatment outcomes. Neurosurgery. Jun. 2004;54(6):1385-93. discussion 93–4. X-1. [pmid: 15157295].
1938 Labeodan OA. Choroid plexus angioma in a newborn presenting with hydrocephalus. Pediatr Neurosurg. May–Jun. 2004;40(3):153-4. X-1. [pmid: 15367812].
1939 Lam SM, Williams EF 3rd. Practical considerations in the treatment of capillary vascular malformations, or port wine stains. Facial Plast Surg. Feb. 2004;20(1):71-6. X-1. [pmid: 15034817].
1940 Lolekha R, Chokephaibulkit K, Yoksan S, et al. Diagnosis of dengue infection using various diagnostic tests in the early stage of illness. Southeast Asian J Trop Med Public Health. Jun. 2004;35(2):391-5. X-1. [pmid: 15691143].
1941 Martinez AE, Robinson MJ, Alexis JB. Kaposiform hemangioendothelioma associated with nonimmune fetal hydrops. Arch Pathol Lab Med. Jun. 2004;128(6):678-81. X-1. [pmid: 15163230].
1942 Mathes EF, Haggstrom AN, Dowd C, et al. Clinical characteristics and management of vascular anomalies: findings of a multidisciplinary vascular anomalies clinic. Arch Dermatol. Aug. 2004;140(8):979-83. X-3, X-4. [pmid: 15313815].
1943 Meara J, Kendall G, Muirhead C, et al. Ionising radiation in infancy and adult cognitive function: protocols for computed tomography must be optimised. BMJ. Mar. 6. 2004;328(7439):581. author reply 2. X-1. [pmid: 15001512].
1944 Metz BJ, Rubenstein MC, Levy ML, et al. Response of ulcerated perineal hemangiomas of infancy to becaplermin gel, a recombinant human platelet-derived growth factor. Arch Dermatol. Jul. 2004;140(7):867-70. X-4. [pmid: 15262700].
1945 Metzelder ML, Springer A, August C, et al. Neonatal hemoperitoneum caused by a congenital liver angioma. J Pediatr Surg. Feb. 2004;39(2):234-6. X-1. [pmid: 14966751].
1946 Mikuni N, Satow T, Taki J, et al. Endotracheal tube electrodes to map and monitor activities of the vagus nerve intraoperatively. Technical note. J Neurosurg. Sep. 2004;101(3):536-40. X-1. [pmid: 15352615].
1947 Miyagami M, Katayama Y. Long-term prognosis of hemangioblastomas of the central nervous system: clinical and immunohistochemical study in relation to recurrence. Brain Tumor Pathol. 2004;21(2):75-82. X-1. [pmid: 15700837].
1948 Miyama S, Goto T. Leptomeningeal angiomatosis with infantile spasms. Pediatr Neurol. Nov. 2004;31(5):353-6. X-1. [pmid: 15519118].
1949 Mo JQ, Dimashkieh HH, Bove KE. GLUT1 endothelial reactivity distinguishes hepatic infantile hemangioma from congenital hepatic vascular malformation with associated capillary proliferation. Hum Pathol. Feb. 2004;35(2):200-9. X-3, X-4. [pmid: 14991538].
1950 Mounayer C, Benndorf G, Bisdorff A, et al. Facial infantile hemangiopericytoma resembling an arteriovenous malformation. J Neuroradiol. Jun. 2004;31(3):227-30. X-1. [pmid: 15356450].
1951 Mulliken JB, Anupindi S, Ezekowitz RA, et al. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 13–2004. A newborn girl with a large cutaneous lesion, thrombocytopenia, and anemia. N Engl J Med. Apr. 22. 2004;350(17):1764-75. X-1. [pmid: 15103004].
1952 Muniz AE. Sturge-Weber syndrome presenting as an acute life-threatening event. Pediatr Emerg Care. Sep. 2004;20(9):610-2. X-1. [pmid: 15599265].
1953 Murakami K, Umezawa K, Kaimori M, et al. Cavernous angioma presenting as epilepsy 13 years after initial diagnosis. J Clin Neurosci. May. 2004;11(4):430-2. X-1. [pmid: 15080966].
1954 Neudorfer M, Leibovitch I, Stolovitch C, et al. Intraorbital and periorbital tumors in children--value of ultrasound and color Doppler imaging in the differential diagnosis. Am J Ophthalmol. Jun. 2004;137(6):1065-72. X-3, X-4. [pmid: 15183791].
1955 Nishimura Y, Tajima G, Dwi Bahagia A, et al. Differential diagnosis of neonatal mild hypergalactosaemia detected by mass screening: clinical significance of portal vein imaging. J Inherit Metab Dis. 2004;27(1):11-8. X-1. [pmid: 14970742].
1956 O’Hagan AH, Irvine AD, Sands A, et al. Miliary neonatal hemangiomatosis with fulminant heart failure and cardiac septal hypertrophy in two infants. Pediatr Dermatol. Jul–Aug. 2004;21(4):469-72. X-1. [pmid: 15283793].
1957 Okahashi K, Sugimoto K, Iwai M, et al. Intra-articular synovial hemangioma; a rare cause of knee pain and swelling. Arch Orthop Trauma Surg. Oct. 2004;124(8):571-3. X-1. [pmid: 15340750].
1958 Ozcan C, Apa DD, Gorur K. Pediatric lobular capillary hemangioma of the nasal cavity. Eur Arch Otorhinolaryngol. Sep. 2004;261(8):449-51. X-1, X-2. [pmid: 14652770].
1959 Pagliai KA, Cohen BA. Pyogenic granuloma in children. Pediatr Dermatol. Jan–Feb. 2004;21(1):10-3. X-1. [pmid: 14871318].
1960 Patel A, Davies SJ, Sandler PJ. The potentially fatal vascular anomaly and orthodontic treatment--a case report. Dent Update. May. 2004;31(4):230-2. 5. 6. X-1. [pmid: 15188530].
1961 Piatt JH Jr, et al. Skin hemangiomas and occult dysraphism. J Neurosurg. Feb. 2004;100(2 Suppl Pediatrics):81-2. discussion 2. X-3, X-4. [pmid: 14758932].
1962 Prabhu SP. Ionising radiation in infancy and adult cognitive function: wrong impression was created by study’s publicity. BMJ. Mar. 6. 2004;328(7439):582. author reply. X-1. [pmid: 15001515].
1963 Pransky SM, Canto C. Management of subglottic hemangioma. Curr Opin Otolaryngol Head Neck Surg. Dec. 2004;12(6):509-12. X-1, X-2. [pmid: 15548909].
1964 Pulidori M, Capuano C, Mouchaty H, et al. Intramuscular thrombosed arteriovenous hemangioma of the upper right arm mimicking a neuroma of the ulnar nerve: case report. Neurosurgery. Mar. 2004;54(3):770-1. discusion 1–2. X-1. [pmid: 15028157].
1965 Rahbar R, Nicollas R, Roger G, et al. The biology and management of subglottic hemangioma: past, present, future. Laryngoscope. Nov. 2004;114(11):1880-91. X-3, X-4. [pmid: 15510009].
1966 Ramseier LE, Exner GU. Arthropathy of the knee joint caused by synovial hemangioma. J Pediatr Orthop. Jan–Feb. 2004;24(1):83-6. X-1. [pmid: 14676540].
1967 Ray R, Rishi A, Venugopal P, et al. Hemangioma of the tricuspid valve: a report of two cases with review of literature. Cardiovasc Pathol. Mar–Apr. 2004;13(2):120-2. X-1, X-2. [pmid: 15033163].
1968 Reinisch JF, Kim RY, Harshbarger RJ, et al. Surgical management of parotid hemangioma. Plast Reconstr Surg. Jun. 2004;113(7):1940-8. X-4. [pmid: 15253181].
1969 Rezvani M, Yager JY, Hartfield DS. Group A streptococcal meningitis as a complication of an infected capillary haemangioma. Eur J Pediatr. Jan. 2004;163(1):19-21. X-2. [pmid: 14610671].
1970 Rizzo R, Pavone L, Pero G, et al. A neurocutaneous disorder with a severe course: Wyburn-Mason’s syndrome. J Child Neurol. Nov. 2004;19(11):908-11. X-1. [pmid: 15658797].
1971 Santoro A, Piccirilli M, Frati A, et al. Intramedullary spinal cord cavernous malformations: report of ten new cases. Neurosurg Rev. Apr. 2004;27(2):93-8. X-1. [pmid: 14714194].
1972 Sar C, Eralp L. Double thoracic vertebral hemangioma causing complete paraplegia. Am J Orthop (Belle Mead NJ). Feb. 2004;33(2):81-4. 57. X-1. [pmid: 15005597].
1973 Scott IU, Gorscak J, Gass JD, et al. Anatomic and visual acuity outcomes following thermal laser photocoagulation or photodynamic therapy for symptomatic circumscribed choroidal hemangioma with associated serous retinal detachment. Ophthalmic Surg Lasers Imaging. Jul–Aug. 2004;35(4):281-91. X-1. [pmid: 15305551].
1974 Sharif K, English M, Ramani P, et al. Management of hepatic epithelioid haemangioendothelioma in children: what option?. Br J Cancer. Apr. 19. 2004;90(8):1498-501. X-1. [pmid: 15083175].
1975 Shields CL, Mashayekhi A, Luo CK, et al. Optical coherence tomography in children: analysis of 44 eyes with intraocular tumors and simulating conditions. J Pediatr Ophthalmol Strabismus. Nov–Dec. 2004;41(6):338-44. X-1, X-2. [pmid: 15609518].
1976 Shields JA, Shields CL, Scartozzi R. Survey of 1264 patients with orbital tumors and simulating lesions: The 2002 Montgomery Lecture, part 1. Ophthalmology. May. 2004;111(5):997-1008. X-1, X-2. [pmid: 15121380].
1977 Sidwell RU, Daubeney PE, Porter W, et al. Neonatal hemangiomatosis and atrial septal defect: a rare cause of right heart failure in infancy. Pediatr Dermatol. Jan–Feb. 2004;21(1):66-9. X-1, X-2. [pmid: 14871331].
1978 Stephen-Haynes J. Vascular birthmarks: a care study of an infant with haemangioma. Br J Nurs. Jan 22–Feb 11. 2004;13(2):87-93. X-2. [pmid: 14997065].
1979 Sterker I, Grafe G. Periocular hemangiomas in childhood--functional and esthetic results. Strabismus. Jun. 2004;12(2):103-10. X-3, X-4. [pmid: 15672933].
1980 Sunil TM. Intramuscular hemangioma complicated by a Volkmann’s like contracture of the forearm muscles. Indian Pediatr. Mar. 2004;41(3):270-3. X-1. [pmid: 15064516].
1981 Swietlinski J, Maruniak-Chudek I, Niemir ZI, et al. A case of atypical congenital nephrotic syndrome. Pediatr Nephrol. Mar. 2004;19(3):349-52. X-1, X-2. [pmid: 14714170].
1982 Tasca RA, Williams RG. Capillary haemangioma of the nasal cavity in a 7-week-old baby--successful treatment using intralesional steroid injection. Int J Pediatr Otorhinolaryngol. Mar. 2004;68(3):365-7. X-1, X-2. [pmid: 15129949].
1983 Tubbs RS, Wellons JC 3rd, Iskandar BJ, et al. Isolated flat capillary midline lumbosacral hemangiomas as indicators of occult spinal dysraphism. J Neurosurg. Feb. 2004;100(2 Suppl Pediatrics):86-9. X-3, X-4. [pmid: 14758934].
1984 Ulgen T, Turhan T, Yurtseven T, et al. Simple anterior orbitotomy. Minim Invasive Neurosurg. Apr. 2004;47(2):115-8. X-1. [pmid: 15257486].
1985 Waldschmidt J, Giest H, Meyer-Junghanel L, et al. Video assisted laser surgery (VATS) in pediatric thoracoscopy. Medical Laser Application. May. 2004;19(1):24-31. X-1, X-4.
1986 Walsh R, Harrington J, Beneck D, et al. Congenital infantile hepatic hemangioendothelioma type II treated with orthotopic liver transplantation. J Pediatr Hematol Oncol. Feb. 2004;26(2):121-3. X-1. [pmid: 14767204].
1987 Walsh SRA, Leung AKC, Fong JHS, et al. Photo diagnosis. Canadian Journal of Diagnosis. 2004;21(6):44. PMID: X-1.
1988 Wasserman BN, Medow NB, Homa-Palladino M, et al. Treatment of periocular capillary hemangiomas. J aapos. Apr. 2004;8(2):175-81. X-1. [pmid: 15088053].
1989 Welsh O, Olazaran Z, Gomez M, et al. Treatment of infantile hemangiomas with short-term application of imiquimod 5% cream. J Am Acad Dermatol. Oct. 2004;51(4):639-42. X-4. [pmid: 15389206].
1990 Winkler D, Lindner D, Trantakis C, et al. Cavernous malformations--navigational supported surgery. Minim Invasive Neurosurg. Feb. 2004;47(1):24-8. X-1. [pmid: 15100928].
1991 Wong KK, Sandor GG, Sett SS. Isolated haemangioma of the tricuspid valve. Cardiol Young. Jun. 2004;14(3):324. X-1, X-2. [pmid: 15680028].
1992 Woo SJ, Kim CJ, Yu YS. Cavernous hemangioma of the iris in an infant. J aapos. Oct. 2004;8(5):499-501. X-1, X-2. [pmid: 15492746].
1993 Wortsman XC, Holm EA, Wulf HC, et al. Real-time spatial compound ultrasound imaging of skin. Skin Res Technol. Feb. 2004;10(1):23-31. X-1. [pmid: 14731245].
1994 Wowra B, Muacevic A, Muller-Schunk S, et al. Special indications in gamma knife surgery. Acta Neurochir Suppl. 2004;91:89-102. X-1. [pmid: 15707030].
1995 Wurm G, Fellner FA. Implementation of T2*-weighted MR for multimodal image guidance in cerebral cavernomas. Neuroimage. Jun. 2004;22(2):841-6. X-1. [pmid: 15193613].
1996 Yan J, Wu Z. Cavernous hemangioma of the orbit: analysis of 214 cases. Orbit. Mar. 2004;23(1):33-40. X-1. [pmid: 15513018].
1997 Zawadzka-Glos L, Zajac B, Kaczmarczyk A. Causes of laryngeal stridor in children. New Medicine. 2004;7(3):80-2. X-1.
1998 Photoclinic: foresee your next patient. Klippel-Trenaunay-Weber syndrome. Consultant. 2005;45(6):700. PMID: X-1.
1999 Photoclinic: foresee your next patient. Deep (cavernous) hemangioma. Consultant. 2005;45(6):706. PMID: X-1.
2000 Aaberg TM Jr, Aaberg TM Sr, Martin DF, et al. Three cases of large retinal capillary hemangiomas treated with verteporfin and photodynamic therapy. Arch Ophthalmol. Mar. 2005;123(3):328-32. X-1. [pmid: 15767474].
2001 Abe M, Misago N, Tanaka S, et al. Capillary hemangioma of the central nervous system: a comparative study with lobular capillary hemangioma of the skin. Acta Neuropathol. Feb. 2005;109(2):151-8. X-1. [pmid: 15365728].
2002 Agrawal S, Misra R, Aggarwal A. Angiomatous malformation: a rare cause of recurrent swelling of the knee joint. Indian Pediatr. Sep. 2005;42(9):937-9. X-1. [pmid: 16208055].
2003 Ali TZ, Beyer G, Taylor M, et al. Splenic hamartoma: immunohistochemical and ultrastructural profile of two cases. Int J Surg Pathol. Jan. 2005;13(1):103-11. X-1. [pmid: 15735864].
2004 Al-Mazrou KA, Richardson MA. Kasabach-Merritt phenomenon. Saudi Med J. Aug. 2005;26(8):1286-8. X-1, X-2. [pmid: 16127531].
2005 Antonoff MB, Kreykes NS, Saltzman DA, et al. American Academy of Pediatrics Section on Surgery hernia survey revisited. J Pediatr Surg. Jun. 2005;40(6):1009-14. X-1. [pmid: 15991187].
2006 Aziz A, Kane TD, Meza MP, et al. An unusual cause of rectal bleeding and intestinal obstruction in a child with peripheral vascular malformations. Pediatr Surg Int. Jun. 2005;21(6):491-3. X-1. [pmid: 15806421].
2007 Bakri SJ, Sears JE, Singh AD. Transient closure of a retinal capillary hemangioma with verteporfin photodynamic therapy. Retina. Dec. 2005;25(8):1103-4. X-1. [pmid: 16340546].
2008 Barrio VR, Drolet BA. Treatment of hemangiomas of infancy. Dermatol Ther. Mar–Apr. 2005;18(2):151-9. X-1, X-2. [pmid: 15953144].
2009 Bay A, Oner AF, Etlik O, et al. Unusual presentation of infantile hemangioendothelioma. Pediatr Blood Cancer. Mar. 2005;44(3):267-9. X-1. [pmid: 15503295].
2010 Bingul F, Tuncali D, Terzioglu A, et al. Hemangioma of the lower lip associated with schistosomiasis: a case report. Br J Plast Surg. Jul. 2005;58(5):736-7. X-1, X-2. [pmid: 15992532].
2011 Bitar MA, Moukarbel RV, Zalzal GH. Management of congenital subglottic hemangioma: trends and success over the past 17 years. Otolaryngol Head Neck Surg. Feb. 2005;132(2):226-31. X-2. [pmid: 15692531].
2012 Bolde SA, Shete SS, Dantkale SS, et al. Kasabach-Merritt syndrome: a case report. Indian J Pathol Microbiol. Jan. 2005;48(1):27-9. X-1. [pmid: 16758782].
2013 Borsaru AD, Naidoo P. Pyogenic abscess complicating a resolving cerebral haematoma secondary to a cavernous haemangioma: computed tomography and magnetic resonance imaging findings. Australas Radiol. Apr. 2005;49(2):144-50. X-1. [pmid: 15845053].
2014 Brotchi J, Baleriaux D, Kalangu KK, et al. Capillary hemangioma in the superior sagittal sinus as a rare cause of intracranial hypertension in a child: case report. Neurosurgery. Oct. 2005;57(4):E815. X-1, X-2. [pmid: 17152670].
2015 Bryan Y, Chwals W, Ovassapian A. Sedation and fiberoptic intubation of a neonate with a cystic hygroma. Acta Anaesthesiol Scand. Jan. 2005;49(1):122-3. X-1. [pmid: 15675998].
2016 Cai J, Hoff GL, Dew PC, et al. Perinatal periods of risk: analysis of fetal-infant mortality rates in Kansas City, Missouri. Matern Child Health J. Jun. 2005;9(2):199-205. X-1. [pmid: 15965626].
2017 Caroli E, Salvati M, Roperto R, et al. High-dose radiation-induced meningioma in children - case report and critical review of the literature. Zentralbl Neurochir. Feb. 2005;66(1):39-42. X-1. [pmid: 15744628].
2018 Ceballos C, Ramundo JM. Management of infants with ulcerated hemangiomas. J Wound Ostomy Continence Nurs. Jan–Feb. 2005;32(1):58-61. discussion -3. X-2. [pmid: 15718959].
2019 Chan KL, Hui WC, Tam PK. Prospective randomized single-center, single-blind comparison of laparoscopic vs open repair of pediatric inguinal hernia. Surg Endosc. Jul. 2005;19(7):927-32. X-1. [pmid: 15920685].
2020 Chapas AM, Geronemus RG. Our approach to pediatric dermatologic laser surgery. Lasers Surg Med. Oct. 2005;37(4):255-63. X-1, X-2. [pmid: 16245293].
2021 Chew EY. Ocular manifestations of von Hippel-Lindau disease: clinical and genetic investigations. Trans Am Ophthalmol Soc. 2005;103:495-511. X-1. [pmid: 17057815].
2022 Chou SY, Chiang HK, Chow PK, et al. Fetal hepatic hemangioma diagnosed prenatally with ultrasonography. Acta Obstet Gynecol Scand. Mar. 2005;84(3):301-2. X-1, X-2. [pmid: 15715543].
2023 Chrzanowski DS, Powers CN, Reiter ER. Parapharyngeal space hemangioma in a pediatric patient. Otolaryngol Head Neck Surg. Sep. 2005;133(3):455-7. X-1, X-2. [pmid: 16143201].
2024 Chuang CC, Lin HC, Huang CW. Submandibular cavernous hemangiomas with multiple phleboliths masquerading as sialolithiasis. J Chin Med Assoc. Sep. 2005;68(9):441-3. X-1. [pmid: 16187603].
2025 Coffin CM. USCAP Specialty Conference: case 3. Pediatr Dev Pathol. Jan–Feb. 2005;8(1):74-6. X-1. [pmid: 15702365].
2026 Colella G, Vuolo G, Siniscalchi G, et al. Radiotherapy for maxillo-facial hemangiomas in children. Dental and periodontal long term effects. Minerva Stomatol. Sep. 2005;54(9):509-16. X-1, X-2. [pmid: 16215535].
2027 Comi AM, Mehta P, Hatfield LA, et al. Sturge-Weber syndrome associated with other abnormalities: a medical record and literature review. Arch Neurol. Dec. 2005;62(12):1924-7. X-1. [pmid: 16344352].
2028 de Lange DH, Aufenacker TJ, Roest M, et al. Inguinal hernia surgery in The Netherlands: a baseline study before the introduction of the Dutch Guidelines. Hernia. May. 2005;9(2):172-7. X-1. [pmid: 15723152].
2029 Dourmishev LA, Dourmishev AL. Craniofacial cavernous hemangioma: succesful treatment with methylprednisolone. Acta Dermatovenerol Alp Pannonica Adriat. Jun. 2005;14(2):49-52. X-1. [pmid: 16001100].
2030 Duhem R, Vinchon M, Leblond P, et al. Cavernous malformations after cerebral irradiation during childhood: report of nine cases. Childs Nerv Syst. Oct. 2005;21(10):922-5. X-1. [pmid: 15662523].
2031 Dusing SC, Rosenberg A, Hiemenz JR, et al. Gross and fine motor skills of children with Hurler syndrome (MPS-IH) post umbilical cord blood transplantation: a case series report. Pediatr Phys Ther. Winter. 2005;17(4):264-7. X-1. [pmid: 16357681].
2032 Egeli E, Oghan F, Alper M, et al. Unusual case of laryngeal tumor (capillary hemangioma) obturating the larynx. Ann Otolaryngol Chir Cervicofac. Jun. 2005;122(3):154-6. X-2. [pmid: 16142096].
2033 Eggers G, Flechtenmacher C, Kurzen H, et al. Infiltrating basal cell carcinoma of the neck 34 years after irradiation of an haemangioma in early childhood. A case-report. J Craniomaxillofac Surg. Jun. 2005;33(3):197-200. X-1, X-2. [pmid: 15878521].
2034 El-Watidy S. Bifrontal decompressive craniotomy in a 6-month-old infant with posttraumatic refractory intracranial hypertension. Pediatr Neurosurg. May–Jun. 2005;41(3):151-4. X-1. [pmid: 15995334].
2035 Erkek E, Hizel S, Sanly C, et al. Clinical and histopathological findings in Bannayan-Riley-Ruvalcaba syndrome. J Am Acad Dermatol. Oct. 2005;53(4):639-43. X-1. [pmid: 16198785].
2036 Ersoy S, Mancini AJ. Hemifacial infantile hemangioma with intracranial extension: a rare entity. Pediatr Dermatol. Jul–Aug. 2005;22(4):309-13. X-2. [pmid: 16060865].
2037 Ferroli P, Sinisi M, Franzini A, et al. Brainstem cavernomas: long-term results of microsurgical resection in 52 patients. Neurosurgery. Jun. 2005;56(6):1203-12. discussion 12–4. X-1. [pmid: 15918936].
2038 Fishman SJ, Smithers CJ, Folkman J, et al. Blue rubber bleb nevus syndrome: surgical eradication of gastrointestinal bleeding. Ann Surg. Mar. 2005;241(3):523-8. X-1. [pmid: 15729077].
2039 Frider B, Bruno A, Selser J, et al. Kasabach-Merrit syndrome and adult hepatic epithelioid hemangioendothelioma an unusual association. J Hepatol. Feb. 2005;42(2):282-3. X-1. [pmid: 15664259].
2040 Frieden IJ, Haggstrom AN, Drolet BA, et al. Infantile hemangiomas: current knowledge, future directions. Proceedings of a research workshop on infantile hemangiomas, April 7–9, 2005, Bethesda, Maryland, USA. Pediatr Dermatol. Sep–Oct. 2005;22(5):383-406. X-1, X-2. [pmid: 16190987].
2041 Friedlander SF, Ritter MR, Friedlander M. Recent progress in our understanding of the pathogenesis of infantile hemangiomas. Lymphat Res Biol. 2005;3(4):219-25. X-1. [pmid: 16379591].
2042 Furuse M, Miyatake SI, Kuroiwa T. Cavernous malformation after radiation therapy for astrocytoma in adult patients: report of 2 cases. Acta Neurochir (Wien). Oct. 2005;147(10):1097-101. discussion 101. X-1. [pmid: 16021386].
2043 Gelmetti C, Moglia I, Restano L. Magnetic resonance imaging application in infantile hemangiomas and vascular malformations. Giornale Italiano di Dermatologia e Venereologia. 2005;140(5):491-6. PMID: X-1, X-2, X-4.
2044 Good WV. Periorbital haemangiomas. Br J Ophthalmol. Sep. 2005;89(9):1074-5. X-2. [pmid: 16113350].
2045 Greene AK, Rogers GF, Mulliken JB. Management of parotid hemangioma. Plast Reconstr Surg. Aug. 2005;116(2):676-7. X-3, X-4. [pmid: 16079718].
2046 Gruman A, Liang MG, Mulliken JB, et al. Kaposiform hemangioendothelioma without Kasabach-Merritt phenomenon. J Am Acad Dermatol. Apr. 2005;52(4):616-22. X-1. [pmid: 15793511].
2047 Guthrie SO, Rhodes M, Janco R, et al. An infant with Kasabach-Merritt syndrome with associated renal hematoma and intussusception. J Perinatol. Feb. 2005;25(2):143-5. X-1, X-2. [pmid: 15660105].
2048 Guven A, Aygun C, Ince H, et al. Severe hypothyroidism caused by hepatic hemangioendothelioma in an infant of a diabetic mother. Horm Res. 2005;63(2):86-9. X-1. [pmid: 15711094].
2049 Hamlat A, Adn M, Pasqualini E, et al. Pathophysiology of capillary haemangioma growth after birth. Med Hypotheses. 2005;64(6):1093-6. X-1. [pmid: 15823691].
2050 Hazen PG, Carney JF, Engstrom CW, et al. Proliferating hemangioma of infancy: successful treatment with topical 5% imiquimod cream. Pediatr Dermatol. May–Jun. 2005;22(3):254-6. X-2. [pmid: 15916578].
2051 Hernandez F, Navarro M, Encinas JL, et al. The role of GLUT1 immunostaining in the diagnosis and classification of liver vascular tumors in children. J Pediatr Surg. May. 2005;40(5):801-4. X-1. [pmid: 15937818].
2052 Hibi M, Tokiwa K, Fukata R, et al. Obstructive jaundice in a child with pancreatic hemangioma. Pediatr Surg Int. Sep. 2005;21(9):752-4. X-1, X-2. [pmid: 16047179].
2053 Ho J, Kendrick V, Dewey D, et al. New insight into the pathophysiology of severe hypothyroidism in an infant with multiple hepatic hemangiomas. J Pediatr Endocrinol Metab. May. 2005;18(5):511-4. X-1, X-2. [pmid: 15921182].
2054 Hochman M, Mascareno A. Management of nasal hemangiomas. Arch Facial Plast Surg. Sep–Oct. 2005;7(5):295-300. X-1, X-2. [pmid: 16172336].
2055 Holmberg E, Anderson H, Lundell M, et al. The impact of reproductive factors on breast cancer risk--the feasibility of using Swedish population-based registers to account for the effect of confounding in cohort studies. Cancer Causes Control. Apr. 2005;16(3):235-43. X-1. [pmid: 15947875].
2056 Hsiao CC, Chen CC, Ko SF, et al. A case of axillary kaposiform hemangioendothelioma resembles a soft tissue sarcoma. J Pediatr Hematol Oncol. Nov. 2005;27(11):596-8. X-1. [pmid: 16282890].
2057 Huiskamp EA, Muskens RP, Ballast A, et al. Diffuse choroidal haemangioma in Sturge-Weber syndrome treated with photodynamic therapy under general anaesthesia. Graefes Arch Clin Exp Ophthalmol. Jul. 2005;243(7):727-30. X-1. [pmid: 15702328].
2058 Hurvitz KA, Rosen H, Meara JG. Pediatric cervicofacial tissue expansion. Int J Pediatr Otorhinolaryngol. Nov. 2005;69(11):1509-13. X-1. [pmid: 15908016].
2059 Iannelli A, Lupi G, Castagna M, et al. Intramedullary capillary hemangioma associated with hydrocephalus in an infant. J Neurosurg. Sep. 2005;103(3 Suppl):272-6. X-1, X-2. [pmid: 16238083].
2060 Ioannidis AS, Liasis A, Syed S, et al. The value of visual evoked potentials in the evaluation of periorbital hemangiomas. Am J Ophthalmol. Aug. 2005;140(2):314-6. X-2. [pmid: 16086956].
2061 Islam S, Newman EA, Strouse PJ, et al. Antiangiogenic therapy for a large splenic hemangioma. Pediatr Surg Int. Dec. 2005;21(12):1007-10. X-2. [pmid: 16215767].
2062 Jian XC. Surgical management of lymphangiomatous or lymphangiohemangiomatous macroglossia. J Oral Maxillofac Surg. Jan. 2005;63(1):15-9. X-1. [pmid: 15635551].
2063 Jiang XW, Wang GH, Li JH, et al. Expression of glucocorticoid receptor isoforms in cutaneous hemangiomas and vascular malformations. Chin Med J (Engl). Jun. 20. 2005;118(12):977-81. X-1, X-3. [pmid: 15978204].
2064 Jianhong L, Xianliang H, Xuewu J. Transcatheter arterial embolization in the treatment of extensive maxillofacial hemangioma in children. World J Surg. Dec. 2005;29(12):1550-6. X-1. [pmid: 16317485].
2065 Johann AC, Aguiar MC, do Carmo MA, et al. Sclerotherapy of benign oral vascular lesion with ethanolamine oleate: an open clinical trial with 30 lesions. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Nov. 2005;100(5):579-84. X-1. [pmid: 16243243].
2066 Kapoor S, Pal S, Chattopadhyay TK. Giant hemangioma of the liver presenting with abdominal compartment syndrome: A case report. Eur Surg. February. 2005;37(1):52-4. X-1.
2067 Katori H, Tsukuda M. Lobular capillary hemangioma of the nasal cavity in child. Auris Nasus Larynx. Jun. 2005;32(2):185-8. X-2. [pmid: 15917177].
2068 Kelley TM, Hatfield LA, Lin DD, et al. Quantitative analysis of cerebral cortical atrophy and correlation with clinical severity in unilateral Sturge-Weber syndrome. J Child Neurol. Nov. 2005;20(11):867-70. X-1. [pmid: 16417855].
2069 Kilickesmez O, Sanal HT, Haholu A, et al. Coexistence of pleomorphic xanthoastrocytoma with Sturge-Weber syndrome: MRI features. Pediatr Radiol. Sep. 2005;35(9):910-3. X-1. [pmid: 15883827].
2070 Kim MS, Pyo SY, Jeong YG, et al. Gamma knife surgery for intracranial cavernous hemangioma. J Neurosurg. Jan. 2005;102(Suppl):102-6. X-1. [pmid: 15662789].
2071 Kitagawa Y, Ito H, Iketani M, et al. Epithelioid hemangioendothelioma of the phalanx: a case report. J Hand Surg Am. May. 2005;30(3):615-9. X-1. [pmid: 15925176].
2072 Koch BL. The child with a neck mass. Appl Radiol. 10. 2005;34(8):8-4. 6. 8. passim. PMID: X-1.
2073 Kondo M, Suzuki K, Inoue R, et al. Characterization of T-cell clones specific to ovomucoid from patients with egg-white allergy. J Investig Allergol Clin Immunol. 2005;15(2):107-11. X-1. [pmid: 16047710].
2074 Kordic R, Sabol Z, Cerovski B, et al. Eye disorders in neurofibromatosis (NF1). Coll Antropol. 2005;29(Suppl 1):29-31. X-1. [pmid: 16193672].
2075 Kossoff EH, Hatfield LA, Ball KL, et al. Comorbidity of epilepsy and headache in patients with Sturge-Weber syndrome. J Child Neurol. Aug. 2005;20(8):678-82. X-1. [pmid: 16225815].
2076 Koulouris G, Rao P. Multiple congenital cranial hemangiomas. Skeletal Radiol. Aug. 2005;34(8):485-9. X-1. [pmid: 15723210].
2077 Kronenberg A, Blei F, Ceisler E, et al. Ocular and systemic manifestations of PHACES (Posterior fossa malformations, Hemangiomas, Arterial anomalies, Cardiac defects and coarctation of the Aorta, Eye abnormalities, and Sternal abnormalities or ventral developmental defects) syndrome. J aapos. Apr. 2005;9(2):169-73. X-3, X-4. [pmid: 15838446].
2078 Lawley LP, Cerimele F, Weiss SW, et al. Expression of Wilms tumor 1 gene distinguishes vascular malformations from proliferative endothelial lesions. Arch Dermatol. Oct. 2005;141(10):1297-300. X-1. [pmid: 16230568].
2079 Lee CW, Choi DY, Oh YG, et al. An infantile case of Sturge-Weber syndrome in association with Klippel-Trenaunay-Weber syndrome and phakomatosis pigmentovascularis. J Korean Med Sci. Dec. 2005;20(6):1082-4. X-1. [pmid: 16361829].
2080 Lehnhardt FG, von Smekal U, Ruckriem B, et al. Value of gradient-echo magnetic resonance imaging in the diagnosis of familial cerebral cavernous malformation. Arch Neurol. Apr. 2005;62(4):653-8. X-1. [pmid: 15824268].
2081 Liu AL, Wang C, Sun S, et al. Gamma knife radiosurgery for tumors involving the cavernous sinus. Stereotact Funct Neurosurg. 2005;83(1):45-51. X-1. [pmid: 15860936].
2082 Lok C, Viseux V, Avril MF, et al. Brain magnetic resonance imaging in patients with Cowden syndrome. Medicine (Baltimore). Mar. 2005;84(2):129-36. X-1. [pmid: 15758842].
2083 Lopez-Gutierrez JC, Diaz M, Ros Z. Giant rapidly involuting congenital hemangioma of the face: 15-year follow-up. Arch Facial Plast Surg. Sep–Oct. 2005;7(5):316-8. X-1. [pmid: 16172340].
2084 Mackie AS, Kozakewich HP, Geva T, et al. Vascular tumors of the heart in infants and children: case series and review of the literature. Pediatr Cardiol. Jul–Aug. 2005;26(4):344-9. X-1, X-2. [pmid: 15549621].
2085 Marler JJ, Fishman SJ, Kilroy SM, et al. Increased expression of urinary matrix metalloproteinases parallels the extent and activity of vascular anomalies. Pediatrics. Jul. 2005;116(1):38-45. X-1, X-3. [pmid: 15995028].
2086 Matulich J, Wood G, Sugo E. Case of non-involuting congenital haemangioma. Australas J Dermatol. Aug. 2005;46(3):165-8. X-1. [pmid: 16008648].
2087 Mentzel HJ, Dieckmann A, Fitzek C, et al. Early diagnosis of cerebral involvement in Sturge-Weber syndrome using high-resolution BOLD MR venography. Pediatr Radiol. Jan. 2005;35(1):85-90. X-1. [pmid: 15480615].
2088 Messieha ZS, Ananda RC, Hoffman WE, et al. Bispectral index system (BIS) monitoring reduces time to extubation and discharge in children requiring oral presedation and general anesthesia for outpatient dental rehabilitation. Pediatr Dent. Nov–Dec. 2005;27(6):500-4. X-1. [pmid: 16532892].
2089 Miller MA, Sandler AD. Elevated plasma vascular endothelial growth factor levels in 2 patients with hemangioendothelioma. J Pediatr Surg. May. 2005;40(5):e17-9. X-1. [pmid: 15937808].
2090 Morel KD, Hogeling M, Eichenfield LF. More than skin deep: cutaneous signs of systemic disease. Contemp Pediatr. 2005;22(2):48-56. PMID: X-2.
2091 Moskowitz C, Edelstein C, Oh M, et al. Retinal capillary hemangioma in von Hippel–Lindau disease. Can J Ophthalmol. Apr. 2005;40(2):192-4. X-3, X-4. [pmid: 16116503].
2092 Muraoka M, Motomura H, Hayashi I, et al. Two cases of tumor-forming strawberry mark hemangioma of the upper lip which caught surgical treatment. Medical Journal of Minami Osaka Hospital. September. 2005;53(1):47-53. X-1, X-2.
2093 Murthy R, Hanovaz SG, Naik M, et al. Ruthenium-106 plaque brachytherapy for the treatment of diffuse choroidal haemangioma in Sturge-Weber syndrome. Indian J Ophthalmol. Dec. 2005;53(4):274-5. X-1, X-2. [pmid: 16333180].
2094 Muzaffar F. Clinical profile and morphologic types of infantile hemangioma. A study of 252 children. Journal of Pakistan Association of Dermatologists. 2005;15(2):119-24. X-3, X-4.
2095 Omidvari S, Nezakatgoo N, Ahmadloo N, et al. Role of intralesional bleomycin in the treatment of complicated hemangiomas: prospective clinical study. Dermatol Surg. May. 2005;31(5):499-501. X-3. [pmid: 15962730].
2096 Pai I, Hegde V, Wilson PO, et al. Ectopic thymus presenting as a subglottic mass: diagnostic and management dilemmas. Int J Pediatr Otorhinolaryngol. Apr. 2005;69(4):573-6. X-1. [pmid: 15763300].
2097 Pallua N, von Heimburg D. Pre-expanded ultra-thin supraclavicular flaps for (full-) face reconstruction with reduced donor-site morbidity and without the need for microsurgery. Plast Reconstr Surg. Jun. 2005;115(7):1837-44. discussion 45–7. X-1. [pmid: 15923825].
2098 Park YH, Choi JY, Chung HS, et al. Hematuria and proteinuria in a mass school urine screening test. Pediatr Nephrol. Aug. 2005;20(8):1126-30. X-1. [pmid: 15947990].
2099 Pascual-Castroviejo I, Pascual-Pascual SI, Garcia-Guereta L, et al. Cutaneous thoracic hemangioma and internal vascular anomalies. J Pediatr Neurol. 2005;3(2):103-6. X-2.
2100 Patrizi A, Varotti E, Parlangeli A, et al. Acquired tufted angioma of the thigh in an adult. [Italian, English]. Angioma tufted acquisito dell’adulto. G Ital Dermatol Venereol. 2005;140(2):149-54. X-1.
2101 Patrizi A, Varotti E, Parlangeli A, et al. Acquired tufted angioma of the thigh in an adult. Giornale Italiano di Dermatologia e Venereologia. 2005;140(2):149-54. PMID: X-1.
2102 Peng Q, Liu W, Tang Y, et al. The establishment of the hemangioma model in nude mouse. J Pediatr Surg. Jul. 2005;40(7):1167-72. X-1. [pmid: 16034764].
2103 Perez DE, Pereira Neto JS, Graner E, et al. Sturge-Weber syndrome in a 6-year-old girl. Int J Paediatr Dent. Mar. 2005;15(2):131-5. X-1. [pmid: 15790372].
2104 Piraccini BM, Antonucci A, Rech G, et al. Congenital pseudoclubbing of a fingernail caused by subungual hemangioma. J Am Acad Dermatol. Aug. 2005;53(2 Suppl 1):S123-6. X-1, X-2. [pmid: 16021160].
2105 Poetke M, Berlien HP. Laser treatment in hemangiomas and vascular malformations. Medical Laser Application. 2005;20(2):95-102. PMID: X-3, X-4.
2106 Polito E, Burroni L, Pichierri P, et al. Technetium tc 99m-labeled red blood cells in the preoperative diagnosis of cavernous hemangioma and other vascular orbital tumors. Arch Ophthalmol. Dec. 2005;123(12):1678-83. X-1. [pmid: 16344439].
2107 Posner JC, Spandorfer PR. Early detection of imperforate hymen prevents morbidity from delays in diagnosis. Pediatrics. Apr. 2005;115(4):1008-12. X-1. [pmid: 15805378].
2108 Prasad KC, Karthik S, Prasad SC. A comprehensive study on lesions of the pinna. Am J Otolaryngol. Jan–Feb. 2005;26(1):1-6. X-3, X-4. [pmid: 15635573].
2109 Premalata CS, Kumar RV, Appaji L, et al. Childhood hepatic angiosarcoma--a case report. Indian J Pathol Microbiol. Oct. 2005;48(4):487-9. X-1. [pmid: 16366104].
2110 Puvabanditsin S, Garrow E, Mehta D, et al. Large chorioangioma associated with hydrops fetalis: a case report. Neonatal Intensive Care. 2005. Jan–Feb. 2005;18(1):15-7. PMID: X-1.
2111 Raghu AR, Tandon S, Rao NN, et al. Intraoral papillary endothelial hyperplasia: case discussion with supportive histochemistry and immunohistochemistry. J Clin Pediatr Dent. Spring. 2005;29(3):253-7. X-1. [pmid: 15926444].
2112 Reck SD, Zacks DN, Eibschitz-Tsimhoni M. Retinal and intracranial arteriovenous malformations: Wyburn-Mason syndrome. J Neuroophthalmol. Sep. 2005;25(3):205-8. X-1. [pmid: 16148629].
2113 Reis RM, Reis-Filho JS, Longatto Filho A, et al. Differential Prox-1 and CD 31 expression in mucousae, cutaneous and soft tissue vascular lesions and tumors. Pathol Res Pract. 2005;201(12):771-6. X-1. [pmid: 16308102].
2114 Rohde V, Spangenberg P, Mayfrank L, et al. Advanced neuronavigation in skull base tumors and vascular lesions. Minim Invasive Neurosurg. Feb. 2005;48(1):13-8. X-1. [pmid: 15747211].
2115 Roman KS, Somers GR, Jaeggi ET. Prenatal presentation of an intracardiac infantile type of haemangioendothelioma. Cardiol Young. Apr. 2005;15(2):182-3. X-1. [pmid: 15845162].
2116 Ross G, Bekhor P, Su J, et al. A case of PHACE syndrome. Australas J Dermatol. Nov. 2005;46(4):253-6. X-2. [pmid: 16197426].
2117 Sabharwal GK, Strouse PJ. Posterior mediastinal hemangioma. Pediatr Radiol. Dec. 2005;35(12):1263-6. X-1, X-2. [pmid: 16163502].
2118 Sandalcioglu IE, Gasser T, Asgari S, et al. Functional outcome after surgical treatment of intramedullary spinal cord tumors: experience with 78 patients. Spinal Cord. Jan. 2005;43(1):34-41. X-1. [pmid: 15326473].
2119 Sasaoka N, Kawaguchi M, Yoshitani K, et al. Evaluation of genitofemoral nerve block, in addition to ilioinguinal and iliohypogastric nerve block, during inguinal hernia repair in children. Br J Anaesth. Feb. 2005;94(2):243-6. X-1. [pmid: 15567812].
2120 Schmidt D, Neumann HP. Spontaneous regression of retinal angiomatous lesions in v. Hippel-Lindau disease (VHL). Eur J Med Res. Dec. 7. 2005;10(12):532-4. X-1. [pmid: 16356869].
2121 Shaul DB, Monforte HL, Levitt MA, et al. Surgical management of perineal masses in patients with anorectal malformations. J Pediatr Surg. Jan. 2005;40(1):188-91. X-3, X-4. [pmid: 15868583].
2122 Shih YH, Pan DH. Management of supratentorial cavernous malformations: craniotomy versus gammaknife radiosurgery. Clin Neurol Neurosurg. Feb. 2005;107(2):108-12. X-1. [pmid: 15708224].
2123 Simon SL, Moonis G, Judkins AR, et al. Intracranial capillary hemangioma: case report and review of the literature. Surg Neurol. Aug. 2005;64(2):154-9. X-1. [pmid: 16051010].
2124 Sullivan JG, Gohel M, Kinder RB. Ectopic adrenocortical tissue found at groin exploration in children: incidence in relation to diagnosis, age and sex. BJU Int. Feb. 2005;95(3):407-10. X-1. [pmid: 15679804].
2125 Szymik-Kantorowicz S, Kobylarz K, Krysta M, et al. Interferon-alpha in the treatment of high-risk haemangiomas in infants. Eur J Pediatr Surg. Feb. 2005;15(1):11-6. X-4. [pmid: 15795821].
2126 Taddeucci G, Bonuccelli A, Polacco P. Migraine-like attacks in child with Sturge-Weber syndrome without facial nevus. Pediatr Neurol. Feb. 2005;32(2):131-3. X-1. [pmid: 15664776].
2127 Takahashi A, Ogawa C, Kanazawa T, et al. Remission induced by interferon alfa in a patient with massive osteolysis and extension of lymph-hemangiomatosis: a severe case of Gorham-Stout syndrome. J Pediatr Surg. Mar. 2005;40(3):E47-50. X-1, X-2. [pmid: 15793714].
2128 Tansel T, Aydogan U, Yilmazbayhan D, et al. Epitheloid hemangioendothelioma of the heart in infancy. Ann Thorac Surg. Apr. 2005;79(4):1402-5. X-1. [pmid: 15797093].
2129 Tatli M, Guzel A, Keklikci U, et al. Pediatric orbital multifocal cavernous hemangiomas associated with bilateral arachnoid cysts of the middle cranial fossa. Case report and review of the literature. J Neurosurg. Nov. 2005;103(5 Suppl):454-7. X-1. [pmid: 16302620].
2130 Thomas RF, Hornung RL, Manning SC, et al. Hemangiomas of infancy: treatment of ulceration in the head and neck. Arch Facial Plast Surg. Sep–Oct. 2005;7(5):312-5. X-2. [pmid: 16172339].
2131 Trager JD. What’s your diagnosis? A 3-month-old girl with an ulcerated perineal plaque. J Pediatr Adolesc Gynecol. Dec. 2005;18(6):409-13. X-1. [pmid: 16338607].
2132 Tu J, Stoodley MA, Morgan MK, et al. Ultrastructural characteristics of hemorrhagic, nonhemorrhagic, and recurrent cavernous malformations. J Neurosurg. Nov. 2005;103(5):903-9. X-1. [pmid: 16304995].
2133 Ulrich H, Baumler W, Hohenleutner U, et al. Neodymium-YAG Laser for hemangiomas and vascular malformations -- long term results. J Dtsch Dermatol Ges. Jun. 2005;3(6):436-40. X-3, X-4. [pmid: 15892846].
2134 Umehara F, Matsuura E, Kitajima S, et al. Unilateral toe-walking secondary to intramuscular hemangioma in the gastrocnemius. Neurology. Oct. 11. 2005;65(7):E15. X-1, X-2. [pmid: 16217043].
2135 Upton A. Diffuse neonatal hemangiomatosis. Journal of Diagnostic Medical Sonography. July/August. 2005;21(4):350-3. X-1.
2136 Verhelst H, Van Coster R. Neuroradiologic findings in a young patient with characteristics of Sturge-Weber syndrome and Klippel-Trenaunay syndrome. J Child Neurol. Nov. 2005;20(11):911-3. X-1. [pmid: 16417862].
2137 Woo CLF, Ho BHT, Young BWY. A newborn with ptosis secondary to a cavernous haemangioma. Hong Kong Journal of Paediatrics. July. 2005;10(3):211-3+8. X-1.
2138 Yagmurlu B, Fitoz S, Atasoy C, et al. An unusual cause of hydrocephalus: aqueductal developmental venous anomaly. Eur Radiol. Jun. 2005;15(6):1159-62. X-1. [pmid: 15150667].
2139 Yan AC. Recent developments in neonatal dermatology. Curr Opin Pediatr. Aug. 2005;17(4):480. X-3, X-4. [pmid: 16012259].
2140 Zhang L, Lin X, Wang W, et al. Circulating level of vascular endothelial growth factor in differentiating hemangioma from vascular malformation patients. Plast Reconstr Surg. Jul. 2005;116(1):200-4. X-2. [pmid: 15988268].
2141 Zur KB, Wood RE, Elluru RG. Pediatric postcricoid vascular malformation: a diagnostic and treatment challenge. Int J Pediatr Otorhinolaryngol. Dec. 2005;69(12):1697-701. X-2. [pmid: 15961166].
2142 Ada M, Guvenc MG, Yilmaz S. Infantile supraglottic hemangioma: a case report. Ear Nose Throat J. Jun. 2006;85(6):388-9. 91. X-2. [pmid: 16866116].
2143 Akil H, Statham PF, Gotz M, et al. Adult cerebellar mutism and cognitive-affective syndrome caused by cystic hemangioblastoma. Acta Neurochir (Wien). May. 2006;148(5):597-8. X-1. [pmid: 16200477].
2144 Al-Shahwan S, Khan AO. Buphthalmos following systemic steroid treatment. J Pediatr Ophthalmol Strabismus. Sep–Oct. 2006;43(5):311-2. X-2. [pmid: 17022166].
2145 Anderson RR. Infant hemangiomas: a controversy worth solving. Lasers Surg Med. Feb. 2006;38(2):92-3. X-3, X-4. [pmid: 16493676].
2146 Aoi Y, Kamiya Y, Shioda M, et al. Pre-anesthetic evaluation can play a crucial role in the determination of airway management in a child with oropharyngeal tumor. J Anesth. 2006;20(3):215-9. X-1. [pmid: 16897242].
2147 Ashworth JL, Biswas S, Wraith E, et al. The ocular features of the mucopolysaccharidoses. Eye (Lond). May. 2006;20(5):553-63. X-1. [pmid: 15905869].
2148 Audren F, Abitbol O, Dureau P, et al. Non-penetrating deep sclerectomy for glaucoma associated with Sturge-Weber syndrome. Acta Ophthalmol Scand. Oct. 2006;84(5):656-60. X-1. [pmid: 16965497].
2149 Awwad RJ, Mortelliti AJ. Postcricoid hemangioma of childhood: report of four cases. Ann Otol Rhinol Laryngol. Mar. 2006;115(3):191-4. X-3, X-4. [pmid: 16572608].
2150 Bajaj Y, Hartley BE, Wyatt ME, et al. Subglottic haemangioma in children: experience with open surgical excision. J Laryngol Otol. Dec. 2006;120(12):1033-7. X-4. [pmid: 17052378].
2151 Baradaranfar MH, Dabirmoghaddam P. Endoscopic endonasal surgery for resection of benign sinonasal tumors: experience with 105 patients. Arch Iran Med. Jul. 2006;9(3):244-9. X-1. [pmid: 16859060].
2152 Barankin B. A “red mark and bruising” on an infant’s face. Contemp Pediatr. 2006;23(7):16-7. PMID: X-1.
2153 Birchler MT, Schmid S, Holzmann D, et al. Kaposiform hemangioendothelioma arising in the ethmoid sinus of an 8-year-old girl with severe epistaxis. Head Neck. Aug. 2006;28(8):761-4. X-1. [pmid: 16721737].
2154 Broniscer A, Laningham FH, Kocak M, et al. Intratumoral hemorrhage among children with newly diagnosed, diffuse brainstem glioma. Cancer. Mar. 15. 2006;106(6):1364-71. X-1. [pmid: 16463390].
2155 Brooker RW, Keenan WJ. Inguinal hernia: relationship to respiratory disease in prematurity. J Pediatr Surg. Nov. 2006;41(11):1818-21. X-1. [pmid: 17101350].
2156 Bruneau M, Bijlenga P, Reverdin A, et al. Early surgery for brainstem cavernomas. Acta Neurochir (Wien). Apr. 2006;148(4):405-14. X-1. [pmid: 16311840].
2157 Bucher S, Guerra M, Corrias F, et al. Basal cell carcinoma of the nose requiring amputation arising after irradiation for childhood hemangioma. Anticancer Res. Nov–Dec. 2006;26(6c):4767-70. X-1, X-2. [pmid: 17214338].
2158 Burstein FD, Williams JK, Schwentker AR, et al. Intralesional laser therapy treatment for hemangiomas: technical evolution. J Craniofac Surg. Jul. 2006;17(4):756-60. X-1. [pmid: 16877930].
2159 Cannady SB, Kahn TA, Traboulsi EI, et al. PHACE syndrome: report of a case with a glioma of the anterior skull base and ocular malformations. Int J Pediatr Otorhinolaryngol. Mar. 2006;70(3):561-4. X-2. [pmid: 16144720].
2160 Chi JH, Lawton MT. Posterior interhemispheric approach: surgical technique, application to vascular lesions, and benefits of gravity retraction. Neurosurgery. Jul. 2006;59(1 Suppl 1):ONS41-9. discussion ONS-9. X-1. [pmid: 16888550].
2161 Chiummariello S, Mezzana P, Fioramonti P, et al. The use of laser and Varioscope in the management of hemangiomas and vascular malformations. Acta Chir Plast. 2006;48(1):20-5. X-1. [pmid: 16722347].
2162 Cho SH, Na KS. Haemangioendothelioma on the conjunctiva of the upper eyelid. Clin Experiment Ophthalmol. Nov. 2006;34(8):794-6. X-1. [pmid: 17073904].
2163 Chopra A, Iyer VK, Thapar R, et al. Diffuse multifocal chorangiomatosis of the placenta with multiple intestinal stenosis of the fetus: combination of rare causes for nonimmune hydrops fetalis. Indian J Pathol Microbiol. Oct. 2006;49(4):600-2. X-1. [pmid: 17183871].
2164 Cong X. Kangaroo care for analgesia in preterm infants undergoing heel stick pain. Case Western Reserve University. 2006.
2165 Corapcioglu F, Akansel G, Gonullu E, et al. Fatal giant pediatric intracranial cavernous angioma. Turk J Pediatr. Jan–Mar. 2006;48(1):89-92. X-1. [pmid: 16562795].
2166 Dalen K, Bruaroy S, Wentzel-Larsen T, et al. Non-verbal learning disabilities in children with infantile hydrocephalus, aged 4–7 years: a population-based, controlled study. Neuropediatrics. Feb. 2006;37(1):1-5. X-1. [pmid: 16541361].
2167 D’Angelo VA, De Bonis C, Amoroso R, et al. Supratentorial cerebral cavernous malformations: clinical, surgical, and genetic involvement. Neurosurg Focus. 2006;21(1):e9. X-1. [pmid: 16859262].
2168 Davids T, Reid D. Capillary hemangioma of the middle ear. J Otolaryngol. Jun. 2006;35(3):196-9. X-2. [pmid: 16929999].
2169 de la Hunt MN. Kasabach-Merritt syndrome: dangers of interferon and successful treatment with pentoxifylline. J Pediatr Surg. Jan. 2006;41(1):e29-31. X-1. [pmid: 16410085].
2170 Delesalle F, Staumont D, Houmany MA, et al. Pulse methylprednisolone therapy for threatening periocular haemangiomas of infancy. Acta Derm Venereol. 2006;86(5):429-32. X-4. [pmid: 16955189].
2171 Delvi MB, Takrouri MS. Anesthesia for encephalo-trigeminal angiomatosis (Sturge-Weber syndrome). Middle East J Anesthesiol. Feb. 2006;18(4):785-90. X-1. [pmid: 16749573].
2172 Denier C, Labauge P, Bergametti F, et al. Genotype-phenotype correlations in cerebral cavernous malformations patients. Ann Neurol. Nov. 2006;60(5):550-6. X-1. [pmid: 17041941].
2173 Deraedt K, Vander Poorten V, Van Geet C, et al. Multifocal kaposiform haemangioendothelioma. Virchows Arch. Jun. 2006;448(6):843-6. X-1. [pmid: 16596383].
2174 Devalia KL, Mehta R, Yagnik MG. Benign juvenile hemangioma--a case report. Acta Orthop. Feb. 2006;77(1):171-3. X-2. [pmid: 16534720].
2175 Devesa PM, Sood S, Chaudhari M, et al. Masson’s tumour: Differential diagnosis of neck lump in children. Int J Pediatr Otorhinolaryngol Extra. September. 2006;1(3):196-9. X-1.
2176 Downey-Carmona FJ, Gonzalez-Herranz P, De La Fuente-Gonzalez C, et al. Acute compartment syndrome of the foot caused by a hemangioma. J Foot Ankle Surg. Jan–Feb. 2006;45(1):52-5. X-1. [pmid: 16399561].
2177 Drolet BA, Dohil M, Golomb MR, et al. Early stroke and cerebral vasculopathy in children with facial hemangiomas and PHACE association. Pediatrics. Mar. 2006;117(3):959-64. X-3, X-4. [pmid: 16510684].
2178 Drosou A, Benjamin L, Linfante I, et al. Infantile midline facial hemangioma with agenesis of the corpus callosum and sinus pericranii: another face of the PHACE syndrome. J Am Acad Dermatol. Feb. 2006;54(2):348-52. X-2. [pmid: 16443074].
2179 Dubois J, Milot J, Jaeger BI, et al. Orbit and eyelid hemangiomas: is there a relationship between location and ocular problems?. J Am Acad Dermatol. Oct. 2006;55(4):614-9. X-3, X-4. [pmid: 17010740].
2180 Durusoy C, Mihci E, Tacoy S, et al. PHACES syndrome presenting as hemangiomas, sternal clefting and congenital ulcerations on the helices. J Dermatol. Mar. 2006;33(3):219-22. X-2. [pmid: 16620231].
2181 Eckardt A, Swennen G, Barth EL, et al. Long-term results after mandibular continuity resection in infancy: the role of autogenous rib grafts for mandibular restoration. J Craniofac Surg. Mar. 2006;17(2):255-60. X-1. [pmid: 16633171].
2182 Farrokhi MR, Aghamajidi J. Surgical treatment of occult spinal dysraphism with tethered spinal cord. Pan Arab Journal of Neurosurgery. October. 2006;10(2):13-6. X-1.
2183 Friedlich P, Shin CE, Seri I. Cardiovascular compromise in the surgical neonate. Seminars in Anesthesia, Perioperative Medicine & Pain. 2006;25(3):124-35. PMID: X-1.
2184 Ghidini A, Locatelli A. Diffuse placental chorioangiomatosis causing multiple fetal cerebral embolism: a case report. J Reprod Med. Apr. 2006;51(4):321-4. X-1. [pmid: 16737029].
2185 Girn HR, Towns G, Chumas P, et al. Gorham’s disease of skull base and cervical spine--confusing picture in a two year old. Acta Neurochir (Wien). Aug. 2006;148(8):909-13. discussion 13. X-1. [pmid: 16791440].
2186 Goddard DS, Liang MG, Chamlin SL, et al. Hypopituitarism in PHACES Association. Pediatr Dermatol. Sep–Oct. 2006;23(5):476-80. X-2. [pmid: 17014646].
2187 Gold R, O’Keefe M, Langer P. Management of capillary hemangiomas. J Pediatr Ophthalmol Strabismus. Nov–Dec. 2006;43(6):326-30. X-2. [pmid: 17162966].
2188 Gottschling S, Schneider G, Meyer S, et al. Two infants with life-threatening diffuse neonatal hemangiomatosis treated with cyclophosphamide. Pediatr Blood Cancer. Feb. 2006;46(2):239-42. X-1. [pmid: 16369922].
2189 Haggstrom AN, Drolet BA, Baselga E, et al. Prospective study of infantile hemangiomas: clinical characteristics predicting complications and treatment. Pediatrics. Sep. 2006;118(3):882-7. X-3, X-4. [pmid: 16950977].
2190 Haggstrom AN, Lammer EJ, Schneider RA, et al. Patterns of infantile hemangiomas: new clues to hemangioma pathogenesis and embryonic facial development. Pediatrics. Mar. 2006;117(3):698-703. X-1, X-3. [pmid: 16510649].
2191 Hansen SL, Dosanjh A, Young DM, et al. Hemangiomas and homeobox gene expression. J Craniofac Surg. Jul. 2006;17(4):767-71. X-1. [pmid: 16877932].
2192 Haroon N, Aggarwal A, Landis MS, et al. What’s your call?. Cmaj. 2006;175(9):1059-61. PMID: X-1. [pmid: 17060654].
2193 Harper L, Michel JL, Enjolras O, et al. Successful management of a retroperitoneal kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon using alpha-interferon. Eur J Pediatr Surg. Oct. 2006;16(5):369-72. X-1, X-2. [pmid: 17160787].
2194 Ishihara H, Bjeljac M, Straumann D, et al. The role of intraoperative monitoring of oculomotor and trochlear nuclei -safe entry zone to tegmental lesions. Minim Invasive Neurosurg. Jun. 2006;49(3):168-72. X-1. [pmid: 16921458].
2195 Iwami D, Shimaoka S, Mochizuki I, et al. Kaposiform hemangioendothelioma of the mediastinum in a 7-month-old boy: a case report. J Pediatr Surg. Aug. 2006;41(8):1486-8. X-1. [pmid: 16863862].
2196 Iyoob SD, Tsai A, Ruchelli ED, et al. Large umbilical cord hemangioma: sonographic features with surgical pathologic correlation. J Ultrasound Med. Nov. 2006;25(11):1495-8. X-1. [pmid: 17060442].
2197 Jallo GI, Freed D, Zareck M, et al. Clinical presentation and optimal management for intramedullary cavernous malformations. Neurosurg Focus. 2006;21(1):e10. X-1. [pmid: 16859248].
2198 Jeon YS, Cho SG, Kim WH, et al. Cavernous haemangioma of the spermatic cord in a child. Pediatr Radiol. Dec. 2006;36(12):1323-5. X-1. [pmid: 17031632].
2199 Jothilakshmi K, Matthai J, Paul S, et al. Symptomatic hepatic hemangioendothelioma in a newborn. Indian Pediatr. Oct. 2006;43(10):908-10. X-1. [pmid: 17079836].
2200 Karikari IO, Selznick LA, Cummings TJ, et al. Capillary hemangioma of the fourth ventricle in an infant. Case report and review of the literature. J Neurosurg. Mar. 2006;104(3 Suppl):188-91. X-2. [pmid: 16572636].
2201 Kavanagh EC, Heran MK, Peleg A, et al. Imaging of the natural history of an orbital capillary hemangioma. Orbit. Mar. 2006;25(1):69-72. X-2. [pmid: 16527782].
2202 Kavin H, Berman J, Martin TL, et al. Successful wireless capsule endoscopy for a 2.5-year-old child: obscure gastrointestinal bleeding from mixed, juvenile, capillary hemangioma-angiomatosis of the jejunum. Pediatrics. Feb. 2006;117(2):539-43. X-1, X-2. [pmid: 16452379].
2203 Keskin M, Kelly CP, Yavuzer R, et al. External filling ports in tissue expansion: confirming their safety and convenience. Plast Reconstr Surg. Apr. 15. 2006;117(5):1543-51. X-1. [pmid: 16641723].
2204 Khan ZA, Melero-Martin JM, Wu X, et al. Endothelial progenitor cells from infantile hemangioma and umbilical cord blood display unique cellular responses to endostatin. Blood. Aug. 1. 2006;108(3):915-21. X-1. [pmid: 16861344].
2205 Kim JM, Cheong JH, Bak KH, et al. Congenital supratentorial hemangioblastoma as an unusual cause of simultaneous supra- and infratentorial intracranial hemorrhage: case report. J Neurooncol. Mar. 2006;77(1):59-63. X-1. [pmid: 16132529].
2206 Kreusel KM, Bechrakis NE, Neumann HP, et al. Pars plana vitrectomy for juxtapapillary capillary retinal angioma. Am J Ophthalmol. Mar. 2006;141(3):587-9. X-1, X-2. [pmid: 16490522].
2207 Kumar GS, Poonnoose SI, Chacko AG, et al. Trigonal cavernous angiomas: report of three cases and review of literature. Surg Neurol. Apr. 2006;65(4):367-71. discussion 71. X-1. [pmid: 16531197].
2208 Kutay V, Yakut C, Ekim H. Mitral annular tumors: report of two cases in childhood. J Card Surg. Mar–Apr. 2006;21(2):191-4. X-1, X-2. [pmid: 16492286].
2209 Laga S, Gewillig MH, Van Schoubroeck D, et al. Imminent fetal cardiac tamponade by right atrial hemangioma. Pediatr Cardiol. Sep–Oct. 2006;27(5):633-5. X-1. [pmid: 16944336].
2210 Lantuejoul S, Sheppard MN, Corrin B, et al. Pulmonary veno-occlusive disease and pulmonary capillary hemangiomatosis: a clinicopathologic study of 35 cases. Am J Surg Pathol. Jul. 2006;30(7):850-7. X-1. [pmid: 16819327].
2211 Lee E, Billings SD, Roumpf S, et al. Abdominal plaque in a 10-day-old boy. Arch Dermatol. May. 2006;142(5):641-6. X-1. [pmid: 16702506].
2212 Lee TC, Barshes NR, Agee EE, et al. Resolution of medically resistant hypothyroidism after liver transplantation for hepatic hemangioendothelioma. J Pediatr Surg. Oct. 2006;41(10):1783-5. X-1. [pmid: 17011291].
2213 Lerner A, Gilboa Y, Gerad L, et al. Sonographic detection of fetal cerebellar cavernous hemangioma with in-utero hemorrhage leading to cerebellar hemihypoplasia. Ultrasound Obstet Gynecol. Dec. 2006;28(7):968-71. X-1. [pmid: 17121422].
2214 Lew SM, Morgan JN, Psaty E, et al. Cumulative incidence of radiation-induced cavernomas in long-term survivors of medulloblastoma. J Neurosurg. Feb. 2006;104(2 Suppl):103-7. X-1. [pmid: 16506497].
2215 Li JH, Xin YL, Zhang W, et al. Effect of electro-acupuncture in treating patients with lingual hemangioma. Chin J Integr Med. Jun. 2006;12(2):146-9. X-1. [pmid: 16800996].
2216 Lim HG, Lee JR, Min SK, et al. Aortobrachial bypass for acute vascular insufficiency due to tumor embolization. Eur J Cardiothorac Surg. Apr. 2006;29(4):609. X-1, X-2. [pmid: 16473515].
2217 Lin DD, Gailloud P, McCarthy EF, et al. Oromaxillofacial osseous abnormality in Sturge-Weber syndrome: case report and review of the literature. AJNR Am J Neuroradiol. Feb. 2006;27(2):274-7. X-1. [pmid: 16484391].
2218 Linnankivi T, Valanne L, Paetau A, et al. Cerebroretinal microangiopathy with calcifications and cysts. Neurology. Oct. 24. 2006;67(8):1437-43. X-1. [pmid: 16943371].
2219 Loeb JA, Sohrab SA, Huq M, et al. Brain calcifications induce neurological dysfunction that can be reversed by a bone drug. J Neurol Sci. Apr. 15. 2006;243(1–2):77-81. X-1. [pmid: 16430923].
2220 Lomenick JP, Backeljauw PF, Lucky AW. Growth, bone mineral accretion, and adrenal function in glucocorticoid-treated infants with hemangiomas-- a retrospective study. Pediatr Dermatol. Mar–Apr. 2006;23(2):169-74. X-4. [pmid: 16650230].
2221 Manabe N, Tanaka S, Fukumoto A, et al. Double-balloon enteroscopy in patients with GI bleeding of obscure origin. Gastrointest Endosc. Jul. 2006;64(1):135-40. X-1. [pmid: 16813826].
2222 McLane K, Bookout KR, McCord S. Case study: using a negative pressure wound therapy device (NPWT) in pediatric patients. Journal of Wound, Ostomy & Continence Nursing. 2006;33(3S):S20-S. PMID: X-2.
2223 Mehta JS, Gajdatsy A, Webster AR, et al. Severe, unstable migraine: a risk factor for postoperative ophthalmic artery spasm?. Orbit. Mar. 2006;25(1):65-7. X-1. [pmid: 16527781].
2224 Metry DW, Haggstrom AN, Drolet BA, et al. A prospective study of PHACE syndrome in infantile hemangiomas: demographic features, clinical findings, and complications. Am J Med Genet A. May. 1. 2006;140(9):975-86. X-3, X-4. [pmid: 16575892].
2225 Miller P, Mack CD, Sammer M, et al. The incidence and risk factors for hypotension during emergent decompressive craniotomy in children with traumatic brain injury. Anesth Analg. Oct. 2006;103(4):869-75. X-1. [pmid: 17000796].
2226 Mishra A, Tripathy K, Bhuyan P, et al. Endovascular papillary angioendothelioma in an elderly female. Indian J Pathol Microbiol. Jul. 2006;49(3):392-3. X-1. [pmid: 17001894].
2227 Morioka T, Hashiguchi K, Nagata S, et al. Epileptogenicity of supratentorial medullary venous malformation. Epilepsia. Feb. 2006;47(2):365-70. X-1. [pmid: 16499761].
2228 Morota N, Deletis V. The importance of brainstem mapping in brainstem surgical anatomy before the fourth ventricle and implication for intraoperative neurophysiological mapping. Acta Neurochir (Wien). May. 2006;148(5):499-509. discussion. X-1. [pmid: 16374568].
2229 Murphy AM, Brenner C, Ann Lynch S. Agenesis of the corpus callosum with interhemispheric cyst, hepatic haemangioma and trisomy 21. Clin Dysmorphol. Jul. 2006;15(3):149-51. X-2. [pmid: 16760733].
2230 Nakamura A, Iguchi H, Kusuki M, et al. Intramasseteric schwannoma in a child. Auris Nasus Larynx. Sep. 2006;33(3):347-50. X-1. [pmid: 16431063].
2231 Nazir Z, Pervez S. Malignant vascular tumors of liver in neonates. J Pediatr Surg. Jan. 2006;41(1):e49-51. X-1. [pmid: 16410090].
2232 Neuhauser C, Dietrich K, Bettina R, et al. Successful laser-treatment of an endobronchial hemangioma in an infant. Int J Pediatr Otorhinolaryngol Extra. September. 2006;1(3):213-6. X-2.
2233 Nicolaidou P, Papadopoulou A. Idiopathic hypercalciuria in children. Current Pediatric Reviews. February. 2006;2(1):93-8. PMID: X-1.
2234 Nomura S, Kato S, Ishihara H, et al. Association of intra- and extradural developmental venous anomalies, so-called venous angioma and sinus pericranii. Childs Nerv Syst. Apr. 2006;22(4):428-31. X-1. [pmid: 16052365].
2235 Oak SN, Viswanath N. Management of hemangiomas in children. Indian J Dermatol Venereol Leprol. Jan–Feb. 2006;72(1):1-4. X-3, X-4. [pmid: 16481701].
2236 Oji C, Chukwuneke F, Mgbor N. Tobacco-pouch suture technique for the treatment of vascular lesions of the lip in Enugu, Nigeria. Br J Oral Maxillofac Surg. Jun. 2006;44(3):245-7. X-1. [pmid: 16009473].
2237 Opie JM, Chow CW, Ditchfield M, et al. Segmental haemangioma of infancy of the lower limb with skeletal overgrowth. Australas J Dermatol. Aug. 2006;47(3):198-203. X-2. [pmid: 16867004].
2238 Padalino MA, Zanon GF, Migneco F, et al. Surgical repair of incomplete cleft sternum and cardiac anomalies in early infancy. Ann Thorac Surg. Jun. 2006;81(6):2291-4. X-1. [pmid: 16731175].
2239 Penido MG, Lima EM, Souto MF, et al. Hypocitraturia: a risk factor for reduced bone mineral density in idiopathic hypercalciuria?. Pediatr Nephrol. Jan. 2006;21(1):74-8. X-1. [pmid: 16252112].
2240 Phan TA, Adams S, Wargon O. Segmental haemangiomas of infancy: A review of 14 cases. Australas J Dermatol. Nov. 2006;47(4):242-7. X-4. [pmid: 17034465].
2241 Pienaar C, Graham R, Geldenhuys S, et al. Intralesional bleomycin for the treatment of hemangiomas. Plast Reconstr Surg. Jan. 2006;117(1):221-6. X-3. [pmid: 16404271].
2242 Pirgon O, Atabek ME, Akin F, et al. A case of Perlman syndrome presenting with hemorrhagic hemangioma. J Pediatr Hematol Oncol. Aug. 2006;28(8):531-3. X-1, X-2. [pmid: 16912594].
2243 Pirie S. Minerva. BMJ Case Rep. 2006;333(7562):310. PMID: X-1.
2244 Pittman KM, Losken HW, Kleinman ME, et al. No evidence for maternal-fetal microchimerism in infantile hemangioma: a molecular genetic investigation. J Invest Dermatol. Nov. 2006;126(11):2533-8. X-3. [pmid: 16902414].
2245 Prabhakar MM, Thakker T. Anterior decompression for cervicothoracic pathology: A study of 14 patients. J Spinal Cord Med. 2006;29(2):163-6. X-1. [pmid: 16739561].
2246 Puxeddu R, Berlucchi M, Ledda GP, et al. Lobular capillary hemangioma of the nasal cavity: A retrospective study on 40 patients. Am J Rhinol. Jul–Aug. 2006;20(4):480-4. X-1. [pmid: 16955784].
2247 Rasmussen A, Nava-Salazar S, Yescas P, et al. Von Hippel-Lindau disease germline mutations in Mexican patients with cerebellar hemangioblastoma. J Neurosurg. Mar. 2006;104(3):389-94. X-1. [pmid: 16572651].
2248 Riley MR, Garcia MG, Cox KL, et al. Hepatic infantile hemangioendothelioma with unusual manifestations. J Pediatr Gastroenterol Nutr. Jan. 2006;42(1):109-13. X-1. [pmid: 16385264].
2249 Ritter MR, Reinisch J, Friedlander SF, et al. Myeloid cells in infantile hemangioma. Am J Pathol. Feb. 2006;168(2):621-8. X-1. [pmid: 16436675].
2250 Rosca TI, Pop MI, Curca M, et al. Vascular tumors in the orbit--capillary and cavernous hemangiomas. Ann Diagn Pathol. Feb. 2006;10(1):13-9. X-1, X-2. [pmid: 16414539].
2251 Saad DF, Shehata BM, Patrick E, et al. Intramuscular hemangioma of the abdominal wall. J Pediatr Surg. Mar. 2006;41(3):601-2. X-1, X-2. [pmid: 16516647].
2252 Schropp C, Sorensen N, Krauss J. Early periinsular hemispherotomy in children with Sturge-Weber syndrome and intractable epilepsy--outcome in eight patients. Neuropediatrics. Feb. 2006;37(1):26-31. X-1. [pmid: 16541365].
2253 Schulze SM, Moser RL, Bhattacharyya N. A rare case of diffuse neonatal hemangimatosis. Am Surg. Apr. 2006;72(4):359-62. X-1, X-2. [pmid: 16676865].
2254 Schwartz SR, Blei F, Ceisler E, et al. Risk factors for amblyopia in children with capillary hemangiomas of the eyelids and orbit. J aapos. Jun. 2006;10(3):262-8. X-3. [pmid: 16814181].
2255 Sciarretta V, Pasquini E, Frank G, et al. Endoscopic treatment of benign tumors of the nose and paranasal sinuses: a report of 33 cases. Am J Rhinol. Jan–Feb. 2006;20(1):64-71. X-1. [pmid: 16539297].
2256 Senthilkumar M, Thappa DM. Vascular nevi in children. Indian J Dermatol Venereol Leprol. Jan–Feb. 2006;72(1):19-23. X-3. [pmid: 16481704].
2257 Shalaby RY, Fawy M, Soliman SM, et al. A new simplified technique for needlescopic inguinal herniorrhaphy in children. J Pediatr Surg. Apr. 2006;41(4):863-7. X-1. [pmid: 16567212].
2258 Shamaly H, Abu-Nassar Z, Groisman GM, et al. Hepatic hemangloendothelioma: the need for early diagnosis and resection. Isr Med Assoc J. Aug. 2006;8(8):585-6. X-1. [pmid: 16958255].
2259 Shimizu T, Sugawara K, Tosaka M, et al. Nestin expression in vascular malformations: a novel marker for proliferative endothelium. Neurol Med Chir (Tokyo). Mar. 2006;46(3):111-7. X-1. [pmid: 16565580].
2260 Shroff PK, Martin TW, Schmitz ML. Successful anesthetic management of a child with an extensive facial hemangioma and high output cardiac failure for placement of a central venous catheter. Paediatr Anaesth. Jan. 2006;16(1):77-81. X-2. [pmid: 16409535].
2261 Shuman C, Smith AC, Steele L, et al. Constitutional UPD for chromosome 11p15 in individuals with isolated hemihyperplasia is associated with high tumor risk and occurs following assisted reproductive technologies. Am J Med Genet A. Jul. 15. 2006;140(14):1497-503. X-1. [pmid: 16770802].
2262 Simonetti V, Legori A, Strippoli D, et al. Diffuse neonatal hemangiomatosis. A case report with limited visceral involvement. European Journal of Pediatric Dermatology. 2006;16(2):77-80. X-1.
2263 Slasky SE, Shinnar S, Bello JA. Sturge-Weber syndrome: deep venous occlusion and the radiologic spectrum. Pediatr Neurol. Nov. 2006;35(5):343-7. X-1. [pmid: 17074605].
2264 Snell M, Chau C, Hendrix D, et al. Lack of isohemagglutinin production following minor ABO incompatible unrelated HLA mismatched umbilical cord blood transplantation. Bone Marrow Transplant. Jul. 2006;38(2):135-40. X-1. [pmid: 16751785].
2265 Sterescu AE, Rousseau-Harsany E, Farrell C, et al. The potential efficacy of omega-3 fatty acids as anti-angiogenic agents in benign vascular tumors of infancy. Med Hypotheses. 2006;66(6):1121-4. X-1, X-2. [pmid: 16500033].
2266 Surucu O, Sure U, Gaetzner S, et al. Clinical impact of CCM mutation detection in familial cavernous angioma. Childs Nerv Syst. Nov. 2006;22(11):1461-4. X-1. [pmid: 16983571].
2267 Taki M, Ohi C, Yamashita A, et al. Successful treatment with vincristine of an infant with intractable Kasabach-Merritt syndrome. Pediatr Int. Feb. 2006;48(1):82-4. X-1. [pmid: 16490078].
2268 Tekkok IH, Sav A. Supratentorial cystic hemangioblastoma with infratentorial extension--a unique location and a rare infant case. Childs Nerv Syst. Sep. 2006;22(9):1177-81. X-1. [pmid: 16534645].
2269 Tennant LB, Mulliken JB, Perez-Atayde AR, et al. Verrucous hemangioma revisited. Pediatr Dermatol. May–Jun. 2006;23(3):208-15. X-1. [pmid: 16780464].
2270 Tsang MW, Garzon MC, Frieden IJ. How to measure a growing hemangioma and assess response to therapy. Pediatr Dermatol. Mar–Apr. 2006;23(2):187-90. X-1, X-2. [pmid: 16650235].
2271 Tucci E, Della Rocca C, Santilli F. Localized bacillary angiomatosis in the oral cavity: observations about a neoplasm with atypical behavior. Description of a case and review of the literature. Minerva Stomatol. Jan–Feb. 2006;55(1–2):67-75. X-1. [pmid: 16495874].
2272 Turker M, Irken G, Oren H, et al. Evaluation of plasma tissue factor and tissue factor pathway inhibitor levels in childhood hemangiomas. Pediatr Blood Cancer. Dec. 2006;47(7):914-7. X-3. [pmid: 16395682].
2273 Van Genechten M, Schelfout K, Wojciechowski M, et al. Intravascular papillary endothelial hyperplasia (Masson’s tumor) on the anterior chest wall in a 3-year-old boy. Eur J Cardiothorac Surg. Dec. 2006;30(6):938. X-1. [pmid: 17052911].
2274 Vasudevan SA, Cumbie TA, Dishop MK, et al. Retroperitoneal hemangioma of infancy. J Pediatr Surg. Jan. 2006;41(1):e41-4. X-2. [pmid: 16410088].
2275 Vesnaver A, Dovsak DA. Treatment of vascular lesions in the head and neck using Nd:YAG laser. J Craniomaxillofac Surg. Jan. 2006;34(1):17-24. X-1. [pmid: 16352435].
2276 Vijayasekaran S, White DR, Hartley BE, et al. Open excision of subglottic hemangiomas to avoid tracheostomy. Arch Otolaryngol Head Neck Surg. Feb. 2006;132(2):159-63. X-4. [pmid: 16490873].
2277 Viskova H, Calda P, Zizka Z, et al. Prenatal diagnosis of occipital dermal sinus associated with hemangioma using ultrasound and MRI. Case report. Fetal Diagn Ther. 2006;21(2):232-4. X-1. [pmid: 16491009].
2278 Vogel AM, Alesbury JM, Burrows PE, et al. Vascular anomalies of the female external genitalia. J Pediatr Surg. May. 2006;41(5):993-9. X-3, X-4. [pmid: 16677899].
2279 Vogel AM, Alesbury JM, Fox VL, et al. Complex pancreatic vascular anomalies in children. J Pediatr Surg. Mar. 2006;41(3):473-8. X-3, X-4. [pmid: 16516618].
2280 Vougioukas VI, Glasker S, Hubbe U, et al. Surgical treatment of hemangioblastomas of the central nervous system in pediatric patients. Childs Nerv Syst. Sep. 2006;22(9):1149-53. X-1. [pmid: 16369852].
2281 Vougiouklakis T, Mitselou A, Zikopoulos K, et al. Ruptured hemangioma of the umbilical cord and intrauterine fetal death, with review data. Pathol Res Pract. 2006;202(7):537-40. X-1. [pmid: 16684589].
2282 Waldman EH, Goldenberg D, Califano J, et al. Venous malformation of the sternomastoid muscle. Otolaryngol Head Neck Surg. Aug. 2006;135(2):325-7. X-1. [pmid: 16890092].
2283 Wananukul S, Voramethkul W, Nuchprayoon I, et al. Diffuse Neonatal Hemangiomatosis: report of 5 cases. J Med Assoc Thai. Aug. 2006;89(8):1297-303. X-1. [pmid: 17048444].
2284 Welch DE, Ignatz ME, Sullivan SE, et al. Orbital hemangioma requiring enucleation in a premature infant. J Pediatr Ophthalmol Strabismus. Nov–Dec. 2006;43(6):365-6. X-2. [pmid: 17162974].
2285 Winkler D, Lindner D, Strauss G, et al. Surgery of cavernous malformations with and without navigational support--a comparative study. Minim Invasive Neurosurg. Feb. 2006;49(1):15-9. X-1. [pmid: 16547876].
2286 Witman PM, Wagner AM, Scherer K, et al. Complications following pulsed dye laser treatment of superficial hemangiomas. Lasers Surg Med. Feb. 2006;38(2):116-23. X-4. [pmid: 16493677].
2287 Woo SH, Ahn HH, Kim SN, et al. Treatment of vascular skin lesions with the variable-pulse 595 nm pulsed dye laser. Dermatol Surg. Jan. 2006;32(1):41-8. X-1. [pmid: 16393597].
2288 Wu SC, Lin KK. Ahmed glaucoma valve implant for childhood glaucoma in Sturge-Weber syndrome with choroidal hemangioma. Chang Gung Med J. Sep–Oct. 2006;29(5):528-31. X-1. [pmid: 17214399].
2289 Yallapragada AV, Cure JK, Holden KR. Sturge-Weber syndrome variant with atypical intracranial findings: case report. J Child Neurol. Feb. 2006;21(2):155-7. X-1. [pmid: 16566882].
2290 Yan AC, Chamlin SL, Liang MG, et al. Congenital infantile fibrosarcoma: a masquerader of ulcerated hemangioma. Pediatr Dermatol. Jul–Aug. 2006;23(4):330-4. X-1. [pmid: 16918626].
2291 Yeung J, Somers G, Viero S, et al. Multifocal lymphangioendotheliomatosis with thrombocytopenia. J Am Acad Dermatol. May. 2006;54(5 Suppl):S214-7. X-1. [pmid: 16631943].
2292 Yoshida S, Kikuchi A, Naito S, et al. Giant hemangioma of the fetal neck, mimicking a teratoma. J Obstet Gynaecol Res. Feb. 2006;32(1):47-54. X-1. [pmid: 16445525].
2293 Zakaria MA, Abdullah JM, George JP, et al. Third ventricular cavernous angioma. Med J Malaysia. Jun. 2006;61(2):229-32. X-1. [pmid: 16898318].
2294 PeDIATRICS electronic pages. Pediatrics. 2007;119(6):1181-93. PMID: X-1.
2295 Abernethy L. Paediatric neck lumps III -- vascular and lymphatic malformations. Ultrasound. 2007;15(3):142-7. PMID: X-1.
2296 Al-Ata J, Arfi AM, Hussain A, et al. Stent angioplasty: an effective alternative in selected infants with critical native aortic coarctation. Pediatr Cardiol. May–Jun. 2007;28(3):183-92. X-1. [pmid: 17457637].
2297 Amer TA, Elwakil TF, Elbasiouny MS. Open rhinoplasty for treatment of nasal tip haemangioma. Eur J Plast Surg. September. 2007;30(2):67-73. X-4.
2298 Amini H, Razeghinejad MR, Esfandiarpour B. Primary single-plate Molteno tube implantation for management of glaucoma in children with Sturge-Weber syndrome. Int Ophthalmol. Dec. 2007;27(6):345-50. X-1. [pmid: 17557138].
2299 Ammerman RT, Bodley AL, Putnam FW, et al. In-home cognitive behavior therapy for a depressed mother in a home visitation program. Clin Case Stud. April. 2007;6(2):161-80. X-1.
2300 Baccin CE, Krings T, Alvarez H, et al. A report of two cases with dolichosegmental intracranial arteries as a new feature of PHACES syndrome. Childs Nerv Syst. May. 2007;23(5):559-67. X-1, X-2. [pmid: 17053935].
2301 Badran AM, Vahedi K, Berrebi D, et al. Pediatric ampullar and small bowel blue rubber bleb nevus syndrome diagnosed by wireless capsule endoscopy. J Pediatr Gastroenterol Nutr. Feb. 2007;44(2):283-6. X-1. [pmid: 17255847].
2302 Balazs AE, Athanassaki I, Gunn SK, et al. Rapid resolution of consumptive hypothyroidism in a child with hepatic hemangioendothelioma following liver transplantation. Ann Clin Lab Sci. Summer. 2007;37(3):280-4. X-1. [pmid: 17709695].
2303 Baraka A. A simple approach to airway management in a child with a giant tongue hemangioma--a case report. Middle East J Anesthesiol. Jun. 2007;19(2):469-70. X-2. [pmid: 17684885].
2304 Barankin B. Dermatology case challenge: what is the lesion on this infant’s face?. Patient Care. 2007;41:2. PMID: X-1.
2305 Battistini S, Rocchi R, Cerase A, et al. Clinical, magnetic resonance imaging, and genetic study of 5 Italian families with cerebral cavernous malformation. Arch Neurol. Jun. 2007;64(6):843-8. X-1. [pmid: 17562932].
2306 Baumann CR, Acciarri N, Bertalanffy H, et al. Seizure outcome after resection of supratentorial cavernous malformations: a study of 168 patients. Epilepsia. Mar. 2007;48(3):559-63. X-1. [pmid: 17346251].
2307 Bella GP, Manivel JC, Thompson RC Jr, et al. Intramuscular hemangioma: recurrence risk related to surgical margins. Clin Orthop Relat Res. Jun. 2007;459:186-91. X-1. [pmid: 17438470].
2308 Berkley EM, Gill GJ, Moore LE, et al. Consumptive coagulopathy associated with Gorham syndrome and subsequent Kasabach-Merritt syndrome during pregnancy: a case report. J Reprod Med. Dec. 2007;52(12):1103-6. X-1. [pmid: 18210901].
2309 Bhagtani H, Love E, Baci G, et al. Index of suspicion. Pediatr Rev. Jun. 2007;28(6):225-9. X-2. [pmid: 17545334].
2310 Bhattacharjee K, Bhattacharjee H, Deka A. Acute progressive multiple cavernous hemangiomas of orbit in a child--a case report. Orbit. Jun. 2007;26(2):117-9. X-1. [pmid: 17613859].
2311 Bhattacharyya NK, Chatterjee U, Sen S, et al. Infantile hemangioendothelioma of liver: report of two cases. Indian J Pathol Microbiol. Apr. 2007;50(2):340-2. X-1, X-2. [pmid: 17883065].
2312 Bourgeois M, Crimmins DW, de Oliveira RS, et al. Surgical treatment of epilepsy in Sturge-Weber syndrome in children. J Neurosurg. Jan. 2007;106(1 Suppl):20-8. X-1. [pmid: 17233308].
2313 Bradfield YS, Kulkarni A, Potter HD, et al. Eyelid fibrous hamartoma with conjunctival angioma in an infant. Arch Ophthalmol. Jun. 2007;125(6):843-5. X-1. [pmid: 17563002].
2314 Burn S, Gunny R, Phipps K, et al. Incidence of cavernoma development in children after radiotherapy for brain tumors. J Neurosurg. May. 2007;106(5 Suppl):379-83. X-1. [pmid: 17566205].
2315 Carroll MB, Higgs JB. Synovial haemangioma presenting as a recurrent monoarticular haemarthrosis. Arch Dis Child. Jul. 2007;92(7):623-4. X-1. [pmid: 17588975].
2316 Caruana CM. Skin deep: from rashes to birthmarks -- when to worry, when to wait. American Baby. 2007;69(7):29. PMID: X-1, X-2.
2317 Chadha M, Singh AP. Unusual knee swelling: a diagnostic dilemma. Arch Orthop Trauma Surg. Sep. 2007;127(7):593-6. X-1, X-2. [pmid: 17165037].
2318 Chamlin SL, Haggstrom AN, Drolet BA, et al. Multicenter prospective study of ulcerated hemangiomas. J Pediatr. Dec. 2007;151(6):684-9. 9.e1. X-3. [pmid: 18035154].
2319 Chan KL. Laparoscopic repair of recurrent childhood inguinal hernias after open herniotomy. Hernia. Feb. 2007;11(1):37-40. X-1. [pmid: 17006622].
2320 Chatha DS, Rybak LD, Wittig JC, et al. Orthopaedic-radiology-pathology conference: Elbow mass in a 9-year-old girl. Clin Orthop Relat Res. Oct. 2007;463:237-43. X-1. [pmid: 17327808].
2321 Chavers BM, Solid CA, Gilbertson DT, et al. Infection-related hospitalization rates in pediatric versus adult patients with end-stage renal disease in the United States. J Am Soc Nephrol. Mar. 2007;18(3):952-9. X-1. [pmid: 17251389].
2322 Christison-Lagay ER, Burrows PE, Alomari A, et al. Hepatic hemangiomas: subtype classification and development of a clinical practice algorithm and registry. J Pediatr Surg. Jan. 2007;42(1):62-7. discussion 7–8. X-2. [pmid: 17208542].
2323 Coats D, Paysse EA. Orbital hemangioma. Ophthalmology. Dec. 2007;114(12):2369. X-3, X-4. [pmid: 18054658].
2324 Comati A, Beck H, Halliday W, et al. Upregulation of hypoxia-inducible factor (HIF)-1alpha and HIF-2alpha in leptomeningeal vascular malformations of Sturge-Weber syndrome. J Neuropathol Exp Neurol. Jan. 2007;66(1):86-97. X-1. [pmid: 17204940].
2325 Conroy FJ, Mahaffey PJ. The use of reinforced adhesive tape in supporting pendulous upper eyelid lesions. Ann Plast Surg. May. 2007;58(5):584-5. X-1, X-2. [pmid: 17452849].
2326 Correa PH, Nunes LC, Johann AC, et al. Prevalence of oral hemangioma, vascular malformation and varix in a Brazilian population. Braz Oral Res. Jan–Mar. 2007;21(1):40-5. X-1. [pmid: 17384854].
2327 Czernik A, Bystryn JC. Does imiquimod work in infantile hemangiomas?. J Am Acad Dermatol. Sep. 2007;57(3):535. author reply 6. X-3, X-4. [pmid: 17707162].
2328 De Paoli AG, Williams M, Parsons SJ, et al. Massive hepatic congenital haemangioma: clinical dilemmas. J Paediatr Child Health. Apr. 2007;43(4):312-4. X-1, X-2. [pmid: 17444837].
2329 Deren O, Ozyuncu O, Onderoglu LS, et al. Alcohol injection for the intrauterine treatment of chorioangioma in a pregnancy with transfusion resistant fetal anemia: a case report. Fetal Diagn Ther. 2007;22(3):203-5. X-1. [pmid: 17228160].
2330 Devadason D, Murphy MS, Brown R, et al. Duodenal capillary hemangiomatous polyps: a novel manifestation of extrahepatic portal hypertension?. J Pediatr Gastroenterol Nutr. Jul. 2007;45(1):114-6. X-1. [pmid: 17592373].
2331 Draghi F, Spinazzola A, Abbati D, et al. Hepatic sonography in the evaluation of potential multi-organ donors. J Ultrasound. March. 2007;10(1):1-4. X-1.
2332 Drut R, Altamirano E. Endothelial cells of intramuscular (infantile) hemangioma express glut1. Int J Surg Pathol. Apr. 2007;15(2):166-8. X-1. [pmid: 17478771].
2333 Elgin U, Simsek T, Batman A. Use of the ex-press miniature glaucoma implant in a child with Sturge-Weber syndrome. J Pediatr Ophthalmol Strabismus. Jul–Aug. 2007;44(4):248-50. X-1. [pmid: 17694831].
2334 Ergun R, Okten AI, Gezercan Y, et al. Sturge-Weber syndrome accompanied with multiple congenital intracranial lesions. Acta Neurochir (Wien). Aug. 2007;149(8):829-30. discussion 30. X-1. [pmid: 17660941].
2335 Ergun SS, Kocabora MS, Su O, et al. Surgical treatment of giant pyogenic granuloma of the upper eyelid. Ann Ophthalmol (Skokie). Fall. 2007;39(3):264-6. X-1, X-2. [pmid: 18025641].
2336 Ewen JB, Comi AM, Kossoff EH. Myoclonic-astatic epilepsy in a child with Sturge-Weber syndrome. Pediatr Neurol. Feb. 2007;36(2):115-7. X-1. [pmid: 17275664].
2337 Farasat S. Dermatology: what’s your Dx? Blueberries on a toddler... blue rubber bleb nevus syndrome. Contemp Pediatr. 2007;24(7):25. PMID: X-1.
2338 Folia M, Naiman N, Dubois R, et al. Management of postcricoid and upper esophageal hemangioma. Int J Pediatr Otorhinolaryngol. Jan. 2007;71(1):147-51. X-3, X-4. [pmid: 16930728].
2339 Fu CH, Lee LA, Fang TJ, et al. Endoscopic Nd:YAG laser therapy of infantile subglottic hemangioma. Pediatr Pulmonol. Jan. 2007;42(1):89-92. X-3, X-4. [pmid: 17106903].
2340 Gallot D, Marceau G, Laurichesse-Delmas H, et al. The changes in angiogenic gene expression in recurrent multiple chorioangiomas. Fetal Diagn Ther. 2007;22(3):161-8. X-1. [pmid: 17228150].
2341 Gao S, Wang YJ, Li JN, et al. Clinical study of CHT-5302/Mp automatic copper needle therapeutic instrument on treatment of cavernous hemangioma and racemosum hemangioma. Eur J Plast Surg. February. 2007;29(6):271-5. X-1.
2342 Geh JL, Geh VS, Jemec B, et al. Surgical treatment of periocular hemangiomas: a single-center experience. Plast Reconstr Surg. Apr. 15. 2007;119(5):1553-62. X-4. [pmid: 17415250].
2343 Georgescu EF, Stanescu L, Dumitrescu D, et al. Portal cavernomatous transformation leading to variceal hemorrhage in Sturge-Webber syndrome. A rare, but possible association. Rom J Morphol Embryol. 2007;48(2):171-5. X-1. [pmid: 17641805].
2344 Ghosh A, Tibrewal SR, Thapa R. PHACES syndrome with congenital hypothyroidism. Indian Pediatr. Feb. 2007;44(2):144-7. X-2. [pmid: 17351309].
2345 Griffin N, Khan N, Thomas JM, et al. The radiological manifestations of intramuscular haemangiomas in adults: magnetic resonance imaging, computed tomography and ultrasound appearances. Skeletal Radiol. Nov. 2007;36(11):1051-9. X-1. [pmid: 17849114].
2346 Grootenhuis MA, Koopman HM, Verrips EG, et al. Health-related quality of life problems of children aged 8–11 years with a chronic disease. Dev Neurorehabil. Jan–Mar. 2007;10(1):27-33. X-1, X-3. [pmid: 17608324].
2347 Gumus A, Yildirim SV, Kizilkilic O, et al. Case report: seizures in a child caused by a large venous angioma. J Child Neurol. Jun. 2007;22(6):787-9. X-1. [pmid: 17641273].
2348 Haggstrom AN, Drolet BA, Baselga E, et al. Prospective study of infantile hemangiomas: demographic, prenatal, and perinatal characteristics. J Pediatr. Mar. 2007;150(3):291-4. X-3. [pmid: 17307549].
2349 Hall BD, Cadle RG, Morrill-Cornelius SM, et al. Phakomatosis pigmentovascularis: Implications for severity with special reference to Mongolian spots associated with Sturge-Weber and Klippel-Trenaunay syndromes. Am J Med Genet A. Dec. 15. 2007;143a(24):3047-53. X-1. [pmid: 17937434].
2350 Hammen T, Romstock J, Dorfler A, et al. Prediction of postoperative outcome with special respect to removal of hemosiderin fringe: a study in patients with cavernous haemangiomas associated with symptomatic epilepsy. Seizure. Apr. 2007;16(3):248-53. X-1. [pmid: 17276092].
2351 Hauer J, Graubner U, Konstantopoulos N, et al. Effective treatment of kaposiform hemangioendotheliomas associated with Kasabach-Merritt phenomenon using four-drug regimen. Pediatr Blood Cancer. Nov. 2007;49(6):852-4. X-1. [pmid: 16411198].
2352 Haught EA, Johnson MC, Witt PD. Congenital erythroleukemia presenting as a congenital infantile hemangioma. Plast Reconstr Surg. Apr. 1. 2007;119(4):70e-2e. X-1, X-2. [pmid: 17496582].
2353 Herrero Hernandez A, Escobosa Sanchez O, Acha Garcia T. Successful treatment with vincristine in PHACES syndrome. Clin Transl Oncol. Apr. 2007;9(4):262-3. X-2. [pmid: 17462981].
2354 Hirth A, Berg A, Greve G. Successful treatment of severe heart failure in an infant with Hurler syndrome. J Inherit Metab Dis. Oct. 2007;30(5):820. X-1. [pmid: 17768668].
2355 Ho NT, Lansang P, Pope E. Topical imiquimod in the treatment of infantile hemangiomas: a retrospective study. J Am Acad Dermatol. Jan. 2007;56(1):63-8. X-4. [pmid: 17190622].
2356 Hohenleutner U, Landthaler M, Hamm H, et al. Hemangiomas of infancy and childhood. J Dtsch Dermatol Ges. Apr. 2007;5(4):334-8. X-2. [pmid: 17376102].
2357 Hsiao CH, Tsao PN, Hsieh WS, et al. Huge, alarming congenital hemangioma of the scalp presenting as heart failure and Kasabach-Merritt syndrome: a case report. Eur J Pediatr. Jun. 2007;166(6):619-20. X-1. [pmid: 16937128].
2358 Hsiao KH, Lin LH, Chen DF, et al. Hepatic mesenchymal hamartoma combined with infantile hepatic hemangioendothelioma in an infant. J Formos Med Assoc. Mar. 2007;106(3 Suppl):S1-4. X-1. [pmid: 17493912].
2359 Ibrahim H, Hussein S, Bagga B, et al. Hemangioendothelioma. J La State Med Soc. Nov–Dec. 2007;159(6):307-8. X-1. [pmid: 18390267].
2360 Izci Y, Gurkanlar D, Gonul E. An unusual type of split cord malformation. J Clin Neurosci. Apr. 2007;14(4):383-6. X-2. [pmid: 17267224].
2361 Jenny B, Radovanovic I, Haenggeli CA, et al. Association of multiple vertebral hemangiomas and severe paraparesis in a patient with a PTEN hamartoma tumor syndrome. Case report. J Neurosurg. Oct. 2007;107(4 Suppl):307-13. X-2. [pmid: 17941496].
2362 Joseph RA, Mackley AB, Davis CG, et al. Stress in fathers of surgical neonatal intensive care unit babies. Adv Neonatal Care. Dec. 2007;7(6):321-5. X-1. [pmid: 18097216].
2363 Joseph RA, Mackley AB, Davis CG, et al. Ethical issues in newborn care. Stress in fathers of surgical neonatal intensive care unit babies. Adv Neonatal Care. 2007;7(6):321-5. PMID: X-1. [pmid: 18097216].
2364 Judd CD, Chapman PR, Koch B, et al. Intracranial infantile hemangiomas associated with PHACE syndrome. AJNR Am J Neuroradiol. Jan. 2007;28(1):25-9. X-3, X-4. [pmid: 17213418].
2365 Juhasz C, Batista CE, Chugani DC, et al. Evolution of cortical metabolic abnormalities and their clinical correlates in Sturge-Weber syndrome. Eur J Paediatr Neurol. Sep. 2007;11(5):277-84. X-1. [pmid: 17408998].
2366 Juhasz C, Lai C, Behen ME, et al. White matter volume as a major predictor of cognitive function in Sturge-Weber syndrome. Arch Neurol. Aug. 2007;64(8):1169-74. X-1. [pmid: 17698708].
2367 Kalpatthi R, Germak J, Mizelle K, et al. Thyroid abnormalities in infantile hepatic hemangioendothelioma. Pediatr Blood Cancer. Dec. 2007;49(7):1021-4. X-1. [pmid: 16544297].
2368 Kamida T, Takeda Y, Fujiki M, et al. Nitric oxide synthase and NMDA receptor expressions in cavernoma tissues with epileptogenesis. Acta Neurol Scand. Dec. 2007;116(6):368-73. X-1. [pmid: 17986094].
2369 Kammoun H, Jallouli M, Gouiaa N, et al. Unusual location of a capillary hemangioma: inguinal location. Aesthetic Plast Surg. Sep–Oct. 2007;31(5):593-5. X-2. [pmid: 17576501].
2370 Karabagli H, Karabagli P, Alpman A, et al. Congenital supratentorial cystic hemangioblastoma. Case report and review of the literature. J Neurosurg. Dec. 2007;107(6 Suppl):515-8. X-1. [pmid: 18154025].
2371 Karakus MF, Ozcan KM, Bilal N, et al. Pediatric lobular capillary hemangioma accompanied with a foreign body in the nasal cavity. Int J Pediatr Otorhinolaryngol Extra. December. 2007;2(4):231-4. X-1, X-2.
2372 Kaselas C, Tsikopoulos G, Papouis G, et al. Intralesional administration of interferon A for the management of severe haemangiomas. Pediatr Surg Int. Mar. 2007;23(3):215-8. X-3. [pmid: 17171547].
2373 Kerimoglu U, Uzumcugil A, Yilmaz G, et al. Intraneural hemangioma of digital nerve diagnosed with MR imaging. Skeletal Radiol. Feb. 2007;36(2):157-60. X-2. [pmid: 16552604].
2374 Khan MH, Walshe P, Russell J, et al. Congenital subglotic haemingiomas. Ir Med J. Jan. 2007;100(1):339-41. X-1, X-2. [pmid: 17380926].
2375 Khanna G, Van Heest AE, Agel J, et al. Analysis of factors affecting development of carpal tunnel syndrome in patients with Hurler syndrome after hematopoietic cell transplantation. Bone Marrow Transplant. Mar. 2007;39(6):331-4. X-1. [pmid: 17277793].
2376 Kharkar S, Shuck J, Conway J, et al. The natural history of conservatively managed symptomatic intramedullary spinal cord cavernomas. Neurosurgery. May. 2007;60(5):865-72. discussion -72. X-1. [pmid: 17460522].
2377 Kibar Y, Irkilata HC, Coban H, et al. Combined use of percutaneous and transurethral instruments in the preadolescent children with intravesical pathologies. Int Urol Nephrol. 2007;39(3):775-8. X-1. [pmid: 17333527].
2378 Kirac M, Camtosun A, Canpolat B, et al. Capillary haemangioma of the scrotum. Gazi Medical Journal. March. 2007;18(1):43-4. X-2.
2379 Kleinman ME, Greives MR, Churgin SS, et al. Hypoxia-induced mediators of stem/progenitor cell trafficking are increased in children with hemangioma. Arterioscler Thromb Vasc Biol. Dec. 2007;27(12):2664-70. X-1. [pmid: 17872454].
2380 Kon T, Mori H, Hasegawa K, et al. Neonatal cavernous angioma located in the basal ganglia with profuse intraoperative bleeding. Childs Nerv Syst. Apr. 2007;23(4):449-53. X-1. [pmid: 17103006].
2381 Kossoff EH, Balasta M, Hatfield LM, et al. Self-reported treatment patterns in patients with Sturge-Weber syndrome and migraines. J Child Neurol. Jun. 2007;22(6):720-6. X-1. [pmid: 17641257].
2382 Kurschel S, Maier R, Gellner V, et al. Chiari I malformation and intra-cranial hypertension:a case-based review. Childs Nerv Syst. Aug. 2007;23(8):901-5. X-1. [pmid: 17486353].
2383 Kwok-Williams M, Perez Z, Squire R, et al. Radiotherapy for life-threatening mediastinal hemangioma with Kasabach-Merritt syndrome. Pediatr Blood Cancer. Oct. 15. 2007;49(5):739-44. X-1, X-2. [pmid: 16453298].
2384 Lagreze WA, Zobor G. A method for noncontact measurement of corneal diameter in children. Am J Ophthalmol. Jul. 2007;144(1):141-2. X-1. [pmid: 17601441].
2385 Lapkin E. About face. Parents. 2007;82(7):4. 7. 9. passim. PMID: X-1, X-2.
2386 Lee BB, Laredo J, Lee SJ, et al. Congenital vascular malformations: general diagnostic principles. Phlebology. 2007;22(6):253-7. X-1. [pmid: 18274332].
2387 Lee JW, Cho EY, Hong SH, et al. Spinal epidural hemangiomas: various types of MR imaging features with histopathologic correlation. AJNR Am J Neuroradiol. Aug. 2007;28(7):1242-8. X-1, X-3. [pmid: 17698523].
2388 Lerut JP, Orlando G, Adam R, et al. The place of liver transplantation in the treatment of hepatic epitheloid hemangioendothelioma: report of the European liver transplant registry. Ann Surg. Dec. 2007;246(6):949-57. discussion 57. X-1. [pmid: 18043096].
2389 Lesesky EB, Cunningham BB, Makkar HS. Pediatric surgical pearls: minimizing complications. Semin Cutan Med Surg. Mar. 2007;26(1):54-64. X-1. [pmid: 17349564].
2390 Levi M, Schwartz S, Blei F, et al. Surgical treatment of capillary hemangiomas causing amblyopia. J aapos. Jun. 2007;11(3):230-4. X-4. [pmid: 17344079].
2391 Liu L, Yang S, Han D, et al. Primary tumours of the facial nerve: diagnostic and surgical treatment experience in Chinese PLA General Hospital. Acta Otolaryngol. Sep. 2007;127(9):993-9. X-1, X-2. [pmid: 17712681].
2392 Maheshwari R, Thool A. Orbital cavernous hemangioma of childhood. Indian J Ophthalmol. Jul–Aug. 2007;55(4):313-5. X-1. [pmid: 17595488].
2393 Maronn ML, Corden T, Drolet BA. Pneumocystis carinii pneumonia in infant treated with oral steroids for hemangioma. Arch Dermatol. Sep. 2007;143(9):1224-5. X-2. [pmid: 17875903].
2394 Mathieu G, Mascard E, Wicart P, et al. Forefoot reconstruction after lesser intermediate metatarsal bone resection for aggressive or malignant tumors in children: report of three cases. Foot Ankle Int. Sep. 2007;28(9):1011-6. X-1. [pmid: 17880877].
2395 Mehriar M, Attarzadeh A, Naseri M, et al. A potential therapeutic strategy for capillary hemangioma with new anti-vascular endothelial growth factor (anti-VEGF) agents. Med Hypotheses. 2007;69(4):951. X-3, X-4. [pmid: 17408872].
2396 Menon P, Rao KL, Bhasin S, et al. Giant isolated cavernous hemangioma of the stomach. J Pediatr Surg. Apr. 2007;42(4):747-9. X-1. [pmid: 17448781].
2397 Miliaras D, Conroy J, Pervana S, et al. Karyotypic changes detected by comparative genomic hybridization in a stillborn infant with chorioangioma and liver hemangioma. Birth Defects Res A Clin Mol Teratol. Mar. 2007;79(3):236-41. X-1. [pmid: 17203486].
2398 Minzer-Conzetti K, Garzon MC, Haggstrom AN, et al. Information about infantile hemangiomas on the Internet: how accurate is it?. J Am Acad Dermatol. Dec. 2007;57(6):998-1004. X-1, X-2. [pmid: 17689833].
2399 Morrison SC, Reid JR. Continuing problems with classifications of vascular malformations. Pediatr Radiol. Jun. 2007;37(6):609. X-3, X-4. [pmid: 17431607].
2400 Mulliken JB, Bischoff J, Kozakewich HP. Multifocal rapidly involuting congenital hemangioma: a link to chorangioma. Am J Med Genet A. Dec. 15. 2007;143a(24):3038-46. X-1. [pmid: 17937433].
2401 Mulliken JB, Marler JJ, Burrows PE, et al. Reticular infantile hemangioma of the limb can be associated with ventral-caudal anomalies, refractory ulceration, and cardiac overload. Pediatr Dermatol. Jul–Aug. 2007;24(4):356-62. X-3, X-4. [pmid: 17845155].
2402 Na JI, Cho KH, Kim YG, et al. Angioblastoma showing aggravation after treatment with long-pulsed Nd:YAG laser (1064 nm). Pediatr Dermatol. Jul–Aug. 2007;24(4):397-400. X-1. [pmid: 17845165].
2403 Nam YS, Hwang K. Intramuscular hemangioma of the lower lip. J Craniofac Surg. Jul. 2007;18(4):958-9. X-1, X-2. [pmid: 17667695].
2404 Oguz KK, Senturk S, Ozturk A, et al. Impact of recent seizures on cerebral blood flow in patients with sturge-weber syndrome: study of 2 cases. J Child Neurol. May. 2007;22(5):617-20. X-1. [pmid: 17690070].
2405 O’Regan GM, Watson R, Orr D, et al. Management of vascular birthmarks: review of a multidisciplinary clinic. Ir Med J. Apr. 2007;100(4):425-7. X-1. [pmid: 17566475].
2406 Ozkur A, Kervancioglu S, Kervancioglu R, et al. Prenatal sonographic diagnosis of an extensive fetal axillary hemangiolymphangioma. J Clin Ultrasound. Jun. 2007;35(5):274-6. X-1. [pmid: 17354252].
2407 Pascual-Castroviejo I, Lopez-Gutierrez JC. Cutaneous hemangioma associated with persistence of the trigeminal and both proatlantal arteries. J Child Neurol. Mar. 2007;22(3):337-40. X-2. [pmid: 17621508].
2408 Pascual-Castroviejo I, Pascual-Pascual SI, Lopez-Gutierrez JC, et al. Facial hemangioma and hemispheric migration disorder: presentation of 5 patients. AJNR Am J Neuroradiol. Sep. 2007;28(8):1609-12. X-1. [pmid: 17846222].
2409 Reddy AR, Chang BY, Bradbury JA. Is this really a capillary haemangioma?. Orbit. Dec. 2007;26(4):327-9. X-2. [pmid: 18097979].
2410 Rodgers B, Zeim S, Crawford B, et al. Splenic papillary angioendothelioma in a 6-year-old girl. J Pediatr Hematol Oncol. Dec. 2007;29(12):808-10. X-1. [pmid: 18090926].
2411 Roganovic J. An update on the treatment of high-risk hemangiomas in infants. Eur J Pediatr Surg. Apr. 2007;17(2):147. X-3, X-4. [pmid: 17503313].
2412 Rudy SJ. Pediatric dermatology: fungal/yeast infections, viral infections, acne, and hemangiomas. Dermatol Nurs. Oct. 2007;19(5):507-8. X-1. [pmid: 18286865].
2413 Russell RT, Carlin A, Ashworth M, et al. Diffuse placental chorioangiomatosis and fetal hydrops. Fetal Diagn Ther. 2007;22(3):183-5. X-1. [pmid: 17228155].
2414 San Millan Ruiz D, Delavelle J, Yilmaz H, et al. Parenchymal abnormalities associated with developmental venous anomalies. Neuroradiology. Dec. 2007;49(12):987-95. X-1. [pmid: 17703296].
2415 Sari S, Duruturk L. Radiographic evaluation of periapical healing of permanent teeth with periapical lesions after extrusion of AH Plus sealer. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Sep. 2007;104(3):e54-9. X-1. [pmid: 17709070].
2416 Schettini ST, Ribeiro RC, Brito PL, et al. Gastric hemangioma in a 5-year-old boy. J Pediatr Surg. Apr. 2007;42(4):717-8. X-1, X-2. [pmid: 17448773].
2417 Schmitz T, Opgen-Rhein B, Kroschwald P, et al. Severe transient cardiac failure caused by placental chorangiosis. Neonatology. 2007;91(4):271-4. X-1. [pmid: 17568159].
2418 Schwartz SR, Kodsi SR, Blei F, et al. Treatment of capillary hemangiomas causing refractive and occlusional amblyopia. J aapos. Dec. 2007;11(6):577-83. X-3, X-4. [pmid: 17720571].
2419 Sevinir B, Ozkan TB. Infantile hepatic hemangioendothelioma: clinical presentation and treatment. Turk J Gastroenterol. Sep. 2007;18(3):182-7. X-1. [pmid: 17891692].
2420 Shin HT, Orlow SJ, Chang MW. Ulcerated haemangioma of infancy: a retrospective review of 47 patients. Br J Dermatol. May. 2007;156(5):1050-2. X-3, X-4. [pmid: 17326746].
2421 Singhi P, Mahajan V, Hiremath GM. Joubert syndrome: Review and report of five cases from India. J Pediatr Neurol. 2007;5(4):317-21. X-1.
2422 Sonabend M. Dermatology clinic. Case #1: growing vascular red plaque on a 3-month-old’s face. Clinical Advisor. 2007;10(6):102. PMID: X-1, X-2.
2423 Song JK, Niimi Y, Kupersmith MJ, et al. Postnatal growth and development of a cerebral arteriovenous malformation on serial magnetic resonance imaging in a child with hemangiomatosis. Case report. J Neurosurg. May. 2007;106(5 Suppl):384-7. X-1. [pmid: 17566206].
2424 Spalding SJ, Hennon T, Dohar J, et al. Neonatal lupus erythematosus complicated by mucocutaneous and visceral hemangiomas. Lupus. 2007;16(11):904-7. X-1, X-2. [pmid: 17971365].
2425 Steven M, Kumaran N, Carachi R, et al. Haemangiomas and vascular malformations of the limb in children. Pediatr Surg Int. Jun. 2007;23(6):565-9. X-1. [pmid: 17390139].
2426 Stockman A, Boralevi F, Taieb A, et al. SACRAL syndrome: spinal dysraphism, anogenital, cutaneous, renal and urologic anomalies, associated with an angioma of lumbosacral localization. Dermatology. 2007;214(1):40-5. X-3, X-4. [pmid: 17191046].
2427 Stojanovic VD, Milosevic BO, Djapic MB, et al. Idiopathic hypercalciuria associated with urinary tract infection in children. Pediatr Nephrol. Sep. 2007;22(9):1291-5. X-1. [pmid: 17541648].
2428 Sun ZJ, Zhang L, Zhang WF, et al. Epithelioid hemangioendothelioma of the oral cavity. Oral Dis. Mar. 2007;13(2):244-50. X-1. [pmid: 17305630].
2429 Syed SP, Martin AM, Haupt HM, et al. Angiostatin receptor annexin II in vascular tumors including angiosarcoma. Hum Pathol. Mar. 2007;38(3):508-13. X-1. [pmid: 17239928].
2430 Tanaka N, Tsuda M, Samura O, et al. Blue rubber bleb nevus syndrome: Report of a patient with hemangiomas of the vaginal portion of the cervix appearing during pregnancy. J Obstet Gynaecol Res. Aug. 2007;33(4):546-8. X-1. [pmid: 17688627].
2431 Tang B, Reardon W, Black GC, et al. Congenital ulcerating hemangioma in a baby with KRAS mutation and cardio-facio-cutaneous syndrome. Clin Dysmorphol. Jul. 2007;16(3):203-6. X-2. [pmid: 17551339].
2432 Tang Y, Liu W, Yu S, et al. A novel in vivo model of human hemangioma: xenograft of human hemangioma tissue on nude mice. Plast Reconstr Surg. Sep. 15. 2007;120(4):869-78. X-1. [pmid: 17805113].
2433 Teh SH, Ong GB. Early presentation of right adrenal mass, hepatoblastoma and hepatic cavernous haemangioma in Beckwith-Wiedemann Syndrome. Med J Malaysia. Oct. 2007;62(4):345-6. X-1. [pmid: 18551945].
2434 Thomson K, Pinnock R, Teague L, et al. Vincristine for the treatment of Kasabach-Merritt syndrome: recent New Zealand case experience. N Z Med J. 2007;120(1249):U2418. X-1. [pmid: 17308555].
2435 TJ OL, Messner A. Open excision of subglottic hemangioma with microscopic dissection. Int J Pediatr Otorhinolaryngol. Sep. 2007;71(9):1371-6. X-3, X-4. [pmid: 17644192].
2436 Tubbs RS, Frykman PK, Harmon CM, et al. An unusual sequelae of an infected persistent dermal sinus tract. Childs Nerv Syst. May. 2007;23(5):569-71. X-1. [pmid: 16944171].
2437 van Lindert EJ, Tan TC, Grotenhuis JA, et al. Giant cavernous hemangiomas: report of three cases. Neurosurg Rev. Jan. 2007;30(1):83-92. discussion. X-1. [pmid: 16988810].
2438 Vlahovic A, Simic R, Kravljanac D. Circular excision and purse-string suture technique in the management of facial hemangiomas. Int J Pediatr Otorhinolaryngol. Aug. 2007;71(8):1311-5. X-4. [pmid: 17548115].
2439 Weibel L, Hoey S, Syed S, et al. Picture of the month. Diagnosis: periocular hemangioma: an eye-opening experience. Arch Pediatr Adolesc Med. Oct. 2007;161(10):1001. discussion 2. X-1. [pmid: 17909145].
2440 Weitz J, Klimstra DS, Cymes K, et al. Management of primary liver sarcomas. Cancer. Apr. 1. 2007;109(7):1391-6. X-1. [pmid: 17315167].
2441 Wilson MW, Hoehn ME, Haik BG, et al. Low-dose cyclophosphamide and interferon alfa 2a for the treatment of capillary hemangioma of the orbit. Ophthalmology. May. 2007;114(5):1007-11. X-4. [pmid: 17337066].
2442 Winestone JS, Lin J, Sanford RA, et al. Subepyndemal hemangioblastomas of the cervicomedullary junction: lessons learned in the management of two cases. Childs Nerv Syst. Jul. 2007;23(7):761-4. X-1. [pmid: 17396270].
2443 Wong WT, Agron E, Coleman HR, et al. Genotype-phenotype correlation in von Hippel-Lindau disease with retinal angiomatosis. Arch Ophthalmol. Feb. 2007;125(2):239-45. X-1. [pmid: 17296901].
2444 Woodward ER, Wall K, Forsyth J, et al. VHL mutation analysis in patients with isolated central nervous system haemangioblastoma. Brain. Mar. 2007;130(Pt 3):836-42. X-1. [pmid: 17264095].
2445 Wright DR, Russi DC, Mancini AJ, et al. The nasal crease sign in segmental facial hemangioma--an early sign of cartilage destruction. Pediatr Dermatol. May–Jun. 2007;24(3):241-5. X-2. [pmid: 17542872].
2446 Wu JL, Wu CC, Wang SJ, et al. Imaging strategies in intramuscular haemangiomas: an analysis of 20 cases. Int Orthop. Aug. 2007;31(4):569-75. X-1. [pmid: 17021834].
2447 Yan J, Qiu H, Li Y. Linear nevus sebaceous syndrome associated with choroidal hemangioma. Orbit. Dec. 2007;26(4):331-5. X-1. [pmid: 18097980].
2448 Yoon RK, Chussid S, Sinnarajah N. Characteristics of a pediatric patient with a capillary hemangioma of the palatal mucosa: a case report. Pediatr Dent. May–Jun. 2007;29(3):239-42. X-2. [pmid: 17688022].
2449 Yousenasna L. Neonatal hemangiomatosis. Dermatol Nurs. Feb. 2007;19(1):86. X-1. [pmid: 17330561].
2450 Yu TW, Liu HM, Lee WT. The correlation between motor impairment and cerebral blood flow in Sturge-Weber syndrome. Eur J Paediatr Neurol. Mar. 2007;11(2):96-103. X-1. [pmid: 17317246].
2451 Zhao J, Wang Y, Kang S, et al. The benefit of neuronavigation for the treatment of patients with intracerebral cavernous malformations. Neurosurg Rev. Oct. 2007;30(4):313-8. discussion 9. X-1. [pmid: 17629759].
2452 Zhao Y, Du GH, Wang YF, et al. Multiple intracranial cavernous malformations: clinical features and treatment. Surg Neurol. Nov. 2007;68(5):493-9. discussion 9. X-1. [pmid: 17707490].
2453 Zolkipli Z, Aylett S, Rankin PM, et al. Transient exacerbation of hemiplegia following minor head trauma in Sturge-Weber syndrome. Dev Med Child Neurol. Sep. 2007;49(9):697-9. X-1. [pmid: 17718827].
2454 Management discussion. AAO-HNSF Patient of the Month Program. 2008;37(7):14-25. PMID: X-1.
2455 Absi MA, Kin LL, Hanna A, et al. Index of suspicion. Pediatr Rev. Feb. 2008;29(2):61-6. X-1. [pmid: 18245302].
2456 Ahmadzadeh A, Hakimzadeh M, Safa-Abadi A. Idiopathic hypercalciuria in Iranian Children. Iran J Pediatr. June. 2008;18(2):163-6. X-1.
2457 AlJasser M, Al-Khenaizan S. Cutaneous mimickers of child abuse: a primer for pediatricians. Eur J Pediatr. Nov. 2008;167(11):1221-30. X-1. [pmid: 18661148].
2458 Al-Khaldi A, Alhabshan F, Tamimi O, et al. Repair of aortic arch atresia with diffuse hypoplasia of the descending thoracic aorta. Eur J Cardiothorac Surg. Apr. 2008;33(4):751-3. X-1, X-2. [pmid: 18262428].
2459 Atta NM. Ultrasound guided ilioinguinal/iliohypogastric nerve block versus caudal block during surgical inguinal hernia repair in children. Egyptian Journal of Anaesthesia. 2008;24(2):101-7. X-1.
2460 Balm AJ, Smeele LE, Lohuis PJ. Optimizing exposure of the posterolateral maxillary and pterygoid region: the lower cheek flap. Eur J Surg Oncol. Jun. 2008;34(6):699-703. X-1. [pmid: 18029135].
2461 Barry RB, Hughes BR, Cook LJ. Involution of infantile haemangiomas after imiquimod 5% cream. Clin Exp Dermatol. Jul. 2008;33(4):446-9. X-3, X-4. [pmid: 18485022].
2462 Baselga E, Cordisco MR, Garzon M, et al. Rapidly involuting congenital haemangioma associated with transient thrombocytopenia and coagulopathy: a case series. Br J Dermatol. Jun. 2008;158(6):1363-70. X-1. [pmid: 18410425].
2463 Bayliss SJ, Berk DR. Freckling 11 years after pulsed dye laser therapy for an infantile hemangioma: coincidence or a previously unrecognized complication?. Clin Pediatr (Phila). Mar. 2008;47(2):189-90. X-2. [pmid: 18057153].
2464 Benifla M, Rutka JT, Otsubo H, et al. Long-term seizure and social outcomes following temporal lobe surgery for intractable epilepsy during childhood. Epilepsy Res. Dec. 2008;82(2–3):133-8. X-1. [pmid: 18786810].
2465 Bilgin O, Vollmar C, Peraud A, et al. Ictal SPECT in Sturge-Weber syndrome. Epilepsy Res. Feb. 2008;78(2–3):240-3. X-1. [pmid: 18222066].
2466 Blankenburg F, Scheer I, Sarioglu N, et al. Spontaneous regression of a vascular tumor of the skull base--infantile hemangioendothelioma?. J Pediatr Hematol Oncol. Sep. 2008;30(9):712-5. X-1. [pmid: 18776768].
2467 Bliek J, Maas S, Alders M, et al. Epigenotype, phenotype, and tumors in patients with isolated hemihyperplasia. J Pediatr. Jul. 2008;153(1):95-100. X-1. [pmid: 18571544].
2468 Bonifazi E, Colonna V, Mazzotta F, et al. Propranolol in rapidly growing hemangiomas. European Journal of Pediatric Dermatology. 2008;18(3):185-92. PMID: X-4.
2469 Bramhall RJ, Quaba A. A review of 58 patients with periorbital haemangiomas to determine appropriate cases for intervention. J Plast Reconstr Aesthet Surg. 2008;61(2):138-49. X-3, X-4. [pmid: 17981104].
2470 Brandling-Bennett HA, Metry DW, Baselga E, et al. Infantile hemangiomas with unusually prolonged growth phase: a case series. Arch Dermatol. Dec. 2008;144(12):1632-7. X-3, X-4. [pmid: 19075148].
2471 Breysem L, Allewaert S, Claus F, et al. The use of duplex doppler ultrasound in a case of multifocal hepatic hemangioma. Jbr-btr. Jul–Aug. 2008;91(4):145-8. X-2. [pmid: 18817086].
2472 Buckmiller LM, Francis CL, Glade RS. Intralesional steroid injection for proliferative parotid hemangiomas. Int J Pediatr Otorhinolaryngol. Jan. 2008;72(1):81-7. X-4. [pmid: 18054392].
2473 Bukowinski AT, Ryan MA, Slymen DJ, et al. Haemangiomas and associated congenital malformations in a large population-based sample of infants. Paediatr Perinat Epidemiol. Nov. 2008;22(6):520-9. X-3. [pmid: 19000289].
2474 Campos M, Ortiz V, Correa MS, et al. Evidenced based management of neonatal hemangiolymphangioma: a case report. Bol Asoc Med P R. Apr–Jun. 2008;100(2):57-9. X-1. [pmid: 19227732].
2475 Canavese F, Soo BC, Chia SK, et al. Surgical outcome in patients treated for hemangioma during infancy, childhood, and adolescence: a retrospective review of 44 consecutive patients. J Pediatr Orthop. Apr–May. 2008;28(3):381-6. X-3. [pmid: 18362808].
2476 Caruso S, Miraglia R, Maruzzelli L, et al. An unusual presentation of malignant hepatic epithelioid haemangioendothelioma with left pleural and pulmonary localization. Pediatr Radiol. Sep. 2008;38(9):1027-30. X-1. [pmid: 18542941].
2477 Cenzato M, Stefini R, Ambrosi C, et al. Post-operative remnants of brainstem cavernomas: incidence, risk factors and management. Acta Neurochir (Wien). Sep. 2008;150(9):879-86. discussion 87. X-1. [pmid: 18754072].
2478 Ceyhan M, Elmali M, Yildiz L. Mediastinal hemangioma and accompanying aortic arch anomaly. Pediatr Cardiol. Jul. 2008;29(4):867-9. X-2. [pmid: 18183452].
2479 Chan LK, Smith GC, Quaba AA. The management of periorbital fat excess in haemangioma involution. J Plast Reconstr Aesthet Surg. 2008;61(2):133-7. X-3, X-4. [pmid: 18024248].
2480 Chang LC, Haggstrom AN, Drolet BA, et al. Growth characteristics of infantile hemangiomas: implications for management. Pediatrics. Aug. 2008;122(2):360-7. X-3. [pmid: 18676554].
2481 Chi LY, Wang SH, Liu XW, et al. Familial cerebral cavernous malformation: features of clinical manifestation, pathology and imaging in a Chinese family. Cerebrovasc Dis. 2008;26(2):206-8. X-1. [pmid: 18628620].
2482 Ch’ng S, Tan ST. Facial port-wine stains - clinical stratification and risks of neuro-ocular involvement. J Plast Reconstr Aesthet Surg. Aug. 2008;61(8):889-93. X-1. [pmid: 17604243].
2483 Cho YH, Taplin C, Mansour A, et al. Case report: consumptive hypothyroidism consequent to multiple infantile hepatic haemangiomas. Curr Opin Pediatr. Apr. 2008;20(2):213-5. X-2. [pmid: 18332720].
2484 Comi AM, Bellamkonda S, Ferenc LM, et al. Central hypothyroidism and Sturge-Weber syndrome. Pediatr Neurol. Jul. 2008;39(1):58-62. X-1. [pmid: 18555176].
2485 Connell F, Homfray T, Thilaganathan B, et al. Congenital vascular malformations: a series of five prenatally diagnosed cases. Am J Med Genet A. Oct. 15. 2008;146a(20):2673-80. X-1. [pmid: 18798321].
2486 Daenekindt T, Weyns F, Kho KH, et al. Giant intracranial capillary hemangioma associated with enlarged head circumference in a newborn. J Neurosurg Pediatr. Jun. 2008;1(6):488-92. X-2. [pmid: 18518703].
2487 Dalen K, Bruaroy S, Wentzel-Larsen T, et al. Intelligence in children with hydrocephalus, aged 4–15 years: a population-based, controlled study. Neuropediatrics. Jun. 2008;39(3):146-50. X-1. [pmid: 18991193].
2488 Das S, Ankola P, Chiechi M, et al. Perinatal cerebral arterial infarction associated with a placental chorioangioma. Am J Perinatol. Jun. 2008;25(6):381-3. X-1. [pmid: 18521777].
2489 Datir A, James SL, Ali K, et al. MRI of soft-tissue masses: the relationship between lesion size, depth, and diagnosis. Clin Radiol. Apr. 2008;63(4):373-8. discussion 9–80. X-1. [pmid: 18325355].
2490 de Ribaupierre S, Ryser C, Villemure JG, et al. Cerebellar lesions: is there a lateralisation effect on memory deficits?. Acta Neurochir (Wien). Jun. 2008;150(6):545-50. discussion 50. X-1. [pmid: 18512000].
2491 Deboer MD, Boston BA. Failure-to-thrive in an infant following injection of capillary hemangioma with triamcinolone acetonide. Clin Pediatr (Phila). Apr. 2008;47(3):296-9. X-2. [pmid: 18057161].
2492 Deng ZH, Xu CD, Chen SN. Diagnosis and treatment of blue rubber bleb nevus syndrome in children. World J Pediatr. Feb. 2008;4(1):70-3. X-1. [pmid: 18402258].
2493 Deyrup AT, Tighiouart M, Montag AG, et al. Epithelioid hemangioendothelioma of soft tissue: a proposal for risk stratification based on 49 cases. Am J Surg Pathol. Jun. 2008;32(6):924-7. X-1. [pmid: 18551749].
2494 Draper H, Diamond IR, Temple M, et al. Multimodal management of endangering hepatic hemangioma: impact on transplant avoidance: a descriptive case series. J Pediatr Surg. Jan. 2008;43(1):120-5. discussion 6. X-3, X-4. [pmid: 18206468].
2495 Egberts F, Mentzel T, Leuschner I, et al. Metastasizing epithelioid hemangioendothelioma of the nose in childhood. J Cutan Pathol. Oct. 2008;35(Suppl 1):80-2. X-1. [pmid: 18544051].
2496 Elluru RG. Infant with facial birthmark. AAO-HNSF Patient of the Month Program. 2008;37(8):1-32. PMID: X-1.
2497 Enchev YP, Popov RV, Romansky KV, et al. Neuronavigated surgery of intracranial cavernomas--enthusiasm for high technologies or a gold standard?. Folia Med (Plovdiv). Apr–Jun. 2008;50(2):11-7. X-1. [pmid: 18702220].
2498 Esposito V, Paolini S, Morace R, et al. Intraoperative localization of subcortical brain lesions. Acta Neurochir (Wien). Jun. 2008;150(6):537-42. discussion 43. X-1. [pmid: 18458808].
2499 Frei-Jones M, McKinstry RC, Perry A, et al. Use of thalidomide to diminish growth velocity in a life-threatening congenital intracranial hemangioma. J Neurosurg Pediatr. Aug. 2008;2(2):125-9. X-2. [pmid: 18671617].
2500 Freundlich M, Alon US. Bisphosphonates in children with hypercalciuria and reduced bone mineral density. Pediatr Nephrol. Dec. 2008;23(12):2215-20. X-1. [pmid: 18704505].
2501 Ganapathy S, Kleiner LI, Mirkin LD, et al. Intradural capillary hemangioma of the cauda equina. Pediatr Radiol. Nov. 2008;38(11):1235-8. X-1. [pmid: 18663441].
2502 Gao XH, Wang LL, Zhang L, et al. Familial nevus flammeus associated with early onset cherry angiomas. Int J Dermatol. Dec. 2008;47(12):1284-6. X-1. [pmid: 19126018].
2503 Gezen F, Karatas A, Is M, et al. Giant cavernous haemangioma in an infant. Br J Neurosurg. Dec. 2008;22(6):787-9. X-1. [pmid: 18686064].
2504 Greco F, Fiumara A, Sorge G, et al. Subgaleal hematoma in a child with Sturge-Weber syndrome: to prevent stroke-like episodes, is treatment with aspirin advisable?. Childs Nerv Syst. Dec. 2008;24(12):1479-81. X-1. [pmid: 18575872].
2505 Greene AK. Corticosteroid treatment for problematic infantile hemangioma: evidence does not support an increased risk for cerebral palsy. Pediatrics. Jun. 2008;121(6):1251-2. X-2. [pmid: 18519494].
2506 Gunendi Z, Karatas GK, Sepici V. Diffuse cavernous haemangioma complicated with regional osteoporosis. Rheumatol Int. Aug. 2008;28(10):1041-3. X-1, X-2. [pmid: 18309486].
2507 Hennedige AA, Quaba AA, Al-Nakib K. Sturge-Weber syndrome and dermatomal facial port-wine stains: incidence, association with glaucoma, and pulsed tunable dye laser treatment effectiveness. Plast Reconstr Surg. Apr. 2008;121(4):1173-80. X-1. [pmid: 18349634].
2508 Hernandez-Martin A, Torrelo A. Cutaneous and paravertebral infantile hemangioma: report of two cases. Pediatr Dermatol. Mar–Apr. 2008;25(2):193-5. X-2, X-3. [pmid: 18429777].
2509 Hery G, Becmeur F, Mefat L, et al. Laparoscopic partial splenectomy: indications and results of a multicenter retrospective study. Surg Endosc. Jan. 2008;22(1):45-9. X-1. [pmid: 17943384].
2510 Herzog D, Soglio DB, Fournet JC, et al. Interface hepatitis is associated with a high incidence of late graft fibrosis in a group of tightly monitored pediatric orthotopic liver transplantation patients. Liver Transpl. Jul. 2008;14(7):946-55. X-1. [pmid: 18581476].
2511 Ho R. Hail to the red, white, and blue!. Contemp Pediatr. 2008;25(9):51. PMID: X-1.
2512 Hoey SE, Eastwood D, Monsell F, et al. Histopathological features of Proteus syndrome. Clin Exp Dermatol. May. 2008;33(3):234-8. X-1. [pmid: 18205855].
2513 Horgan N, O’Keefe M, McLoone E, et al. Fundus fluorescein angiographic characterization of diffuse choroidal hemangiomas. J Pediatr Ophthalmol Strabismus. Jan–Feb. 2008;45(1):26-30. X-1. [pmid: 18286959].
2514 Hu MH, Wu CT, Lin KL, et al. Intramedullary spinal arteriovenous malformation in a boy of familial cerebral cavernous hemangioma. Childs Nerv Syst. Mar. 2008;24(3):393-6. X-1. [pmid: 18157540].
2515 Inan M, Chan G, Littleton AG, et al. Efficacy and safety of percutaneous epiphysiodesis. J Pediatr Orthop. Sep. 2008;28(6):648-51. X-1. [pmid: 18724201].
2516 Ionescu G, Mabeta P, Dippenaar N, et al. Bleomycin plasma spill-over levels in paediatric patients undergoing intralesional injection for the treatment of haemangiomas. S Afr Med J. Jul. 2008;98(7):539-40. X-3, X-4. [pmid: 18785394].
2517 Jain T, Sharma R, Gupta R. Case report: Subutaneous hemangiomatosis causing Kasabach-Merritt syndrome - MRI features. Indian J Radiol Imaging. 01. Nov. 2008;18(4):295-7. X-1, X-2. [pmid: 19774184].
2518 Jarvi K, Roebuck DJ, Sebire NJ, et al. Successful treatment of extensive infantile hemangiomatosis of the small bowel in a 3-month-old with thalidomide and somatostatin analog. J Pediatr Gastroenterol Nutr. May. 2008;46(5):593-7. X-1. [pmid: 18493217].
2519 Jha B, Choudhary AK. Unusual cause of back pain in an adolescent patient: a case report and natural history of aggressive vertebral hemangioma in children. Pain Physician. Sep–Oct. 2008;11(5):687-92. X-1. [pmid: 18850034].
2520 Jia J, Huang X, Zhang WF, et al. Human monocyte-derived hemangioma-like endothelial cells: evidence from an in vitro study. Cardiovasc Pathol. Jul–Aug. 2008;17(4):212-8. X-1. [pmid: 18402811].
2521 Jimenez-Hernandez E, Duenas-Gonzalez MT, Quintero-Curiel JL, et al. Treatment with interferon-alpha-2b in children with life-threatening hemangiomas. Dermatol Surg. May. 2008;34(5):640-7. X-4. [pmid: 18261103].
2522 Jordan LC, Wityk RJ, Dowling MM, et al. Transcranial Doppler ultrasound in children with Sturge-Weber syndrome. J Child Neurol. Feb. 2008;23(2):137-43. X-1. [pmid: 18056693].
2523 Jorge BF, Del Pozo J, Castineiras I, et al. Treatment of ulcerated haemangiomas with a non-coherent pulsed light source: brief initial clinical report. J Cosmet Laser Ther. Mar. 2008;10(1):48-51. X-3, X-4. [pmid: 18330798].
2524 Kalicinski P, Ismail H, Broniszczak D, et al. Non-resectable hepatic tumors in children - role of liver transplantation. Ann Transplant. 2008;13(2):37-41. X-1. [pmid: 18566558].
2525 Kamada N, Mitani Y, Kihira K, et al. Images in cardiovascular medicine. Fatal pulmonary lymphangiectasia manifesting after repeated surgeries for intractable chylopericardium and chylothorax in a 20-month-old girl. Circulation. Apr. 8. 2008;117(14):1894-6. X-1. [pmid: 18391124].
2526 Kamil D, Tepelmann J, Berg C, et al. Spectrum and outcome of prenatally diagnosed fetal tumors. Ultrasound Obstet Gynecol. Mar. 2008;31(3):296-302. X-1. [pmid: 18307207].
2527 Kan P, Tubay M, Osborn A, et al. Radiographic features of tumefactive giant cavernous angiomas. Acta Neurochir (Wien). Jan. 2008;150(1):49-55. discussion. X-1. [pmid: 18066488].
2528 Kanaheswari Y, Hamzaini AH, Wong SW, et al. Malignant hypertension in a child with phakomatosis pigmentovascularis type II b. Acta Paediatr. Nov. 2008;97(11):1589-91. X-1. [pmid: 18671691].
2529 Kang GC, Song C. Forty-one cervicofacial vascular anomalies and their surgical treatment--retrospection and review. Ann Acad Med Singapore. Mar. 2008;37(3):165-79. X-1. [pmid: 18392293].
2530 Kella N, Rathi PK, Rathi S, et al. Small bowel haemangioma: A rare cause of intestinal obstruction in infant. Pak J Med Sci. July/September. 2008;24(4):629-31. X-2.
2531 Keng CY, Lan HHC, Chen CCC, et al. Soft tissue hemangiomas: High-resolution grayscale and color Doppler ultrasonographic features in 43 patients. J Med Ultrasound. 2008;16(3):223-30. X-4.
2532 Khan ZA, Boscolo E, Picard A, et al. Multipotential stem cells recapitulate human infantile hemangioma in immunodeficient mice. J Clin Invest. Jul. 2008;118(7):2592-9. X-1. [pmid: 18535669].
2533 Khanna G, Gupta A, Gupta V. Synovial hemangioma: a rare benign synovial lesion. Indian J Pathol Microbiol. Apr–Jun. 2008;51(2):257-8. X-1. [pmid: 18603700].
2534 Kok-Leng Yeow V, Por YC. An audit on orthognathic surgery: a single surgeon’s experience. J Craniofac Surg. Jan. 2008;19(1):184-6. X-1. [pmid: 18216686].
2535 Kretschmar O, Knirsch W, Bernet V. Interventional treatment of a symptomatic neonatal hepatic cavernous hemangioma using the Amplatzer vascular plug. Cardiovasc Intervent Radiol. Mar–Apr. 2008;31(2):411-4. X-1, X-2. [pmid: 17031730].
2536 Kubiena H, Roka J, Frey M. Surgical management of facial vascular anomalies: Role of intraoperative seventh nerve monitoring. Eur J Plast Surg. June. 2008;31(2):65-9. X-2.
2537 Kutluhan A, Bozdemir K, Ugras S. The treatment of tongue haemangioma by plasma knife surgery. Singapore Med J. Nov. 2008;49(11):e312-4. X-1, X-2. [pmid: 19037538].
2538 Kyllerman M, Himmelmann K, Fasth A, et al. Late cerebral graft versus host reaction in a bone marrow transplanted girl with Hurler (MPS I) disease. Neuropediatrics. Oct. 2008;39(5):249-51. X-1. [pmid: 19294596].
2539 Labauge P, Bouly S, Parker F, et al. Outcome in 53 patients with spinal cord cavernomas. Surg Neurol. Aug. 2008;70(2):176-81. discussion 81. X-1. [pmid: 18207494].
2540 Lahoti SL, McNeese MC, Girardet RG, et al. Vaginal complaints in the prepubertal girl. Contemp Pediatr. 2008;25(5):65-70. PMID: X-1.
2541 Lau G. Fatal cerebral infarction complicating therapeutic embolisation of a facial cavernous haemangioma: a case report. Med Sci Law. Jul. 2008;48(3):256-60. X-1. [pmid: 18754215].
2542 Lawrence GC, Rettenmaier MA, Heinemann S, et al. A precarious pregnancy involving a patient with a large placental chorioangioma: a case report. Arch Gynecol Obstet. Oct. 2008;278(4):383-6. X-1. [pmid: 18283474].
2543 Leaute-Labreze C, Dumas de la Roque E, Hubiche T, et al. Propranolol for severe hemangiomas of infancy. N Engl J Med. Jun. 12. 2008;358(24):2649-51. X-2. [pmid: 18550886].
2544 Lee JW, Kim DS, Shim KW, et al. Management of intracranial cavernous malformation in pediatric patients. Childs Nerv Syst. Mar. 2008;24(3):321-7. X-1. [pmid: 17876588].
2545 Leng T, Wang X, Huo R, et al. The value of three-dimensional computed tomographic angiography in the diagnosis and treatment of vascular lesions. Plast Reconstr Surg. Nov. 2008;122(5):1417-24. X-3, X-4. [pmid: 18971725].
2546 Mabeta P, Davis PF. The mechanism of bleomycin in inducing haemangioma regression. S Afr Med J. Jul. 2008;98(7):538-9. X-6. [pmid: 18785393].
2547 Mahajan D, Miller C, Hirose K, et al. Incidental reduction in the size of liver hemangioma following use of VEGF inhibitor bevacizumab. J Hepatol. Nov. 2008;49(5):867-70. X-1. [pmid: 18814928].
2548 Malm G, Gustafsson B, Berglund G, et al. Outcome in six children with mucopolysaccharidosis type IH, Hurler syndrome, after haematopoietic stem cell transplantation (HSCT). Acta Paediatr. Aug. 2008;97(8):1108-12. X-1. [pmid: 18452566].
2549 Martelli L, Collini P, Meazza C, et al. Angiomatoid fibrous histiocytoma in an HIV-positive child. J Pediatr Hematol Oncol. Mar. 2008;30(3):242-4. X-1. [pmid: 18376290].
2550 Martinez-Lage JF, de la Fuente I, Ros de San Pedro J, et al. Cavernomas in children with brain tumors: a late complication of radiotherapy. Neurocirugia (Astur). Feb. 2008;19(1):50-4. X-1. [pmid: 18335155].
2551 Mathelin C, Annane K, Treisser A, et al. Pregnancy and post-partum breast cancer: a prospective study. Anticancer Res. Jul–Aug. 2008;28(4c):2447-52. X-1. [pmid: 18751433].
2552 Melegh Z, Patel Y, Ramani P. Solitary pulmonary infantile hemangioma in an infant with atrial septal defect. Pediatr Dev Pathol. Nov–Dec. 2008;11(6):465-8. X-2. [pmid: 17990917].
2553 Mendiratta V, Anand R, Chander R, et al. Multiple neonatal haemangiomatosis with liver haemangiomas and anaemia. Australas J Dermatol. Feb. 2008;49(1):42-3. X-2. [pmid: 18186848].
2554 Metry DW, Siegel DH, Cordisco MR, et al. A comparison of disease severity among affected male versus female patients with PHACE syndrome. J Am Acad Dermatol. Jan. 2008;58(1):81-7. X-2, X-3. [pmid: 18029054].
2555 Motegi H, Kuroda S, Ishii N, et al. De novo formation of cavernoma after radiosurgery for adult cerebral arteriovenous malformation--case report. Neurol Med Chir (Tokyo). Sep. 2008;48(9):397-400. X-1. [pmid: 18812682].
2556 Mouat F, Evans HM, Cutfield WS, et al. Massive hepatic hemangioendothelioma and consumptive hypothyroidism. J Pediatr Endocrinol Metab. Jul. 2008;21(7):701-3. X-1. [pmid: 18780606].
2557 Mukhopadhyay S. Sturge-Weber syndrome: a case report. J Indian Soc Pedod Prev Dent. Jan. 2008;26(Suppl 1):S29-31. X-1. [pmid: 18974543].
2558 Muramatsu K, Ihara K, Tani Y, et al. Intramuscular hemangioma of the upper extremity in infants and children. J Pediatr Orthop. Apr–May. 2008;28(3):387-90. X-1. [pmid: 18362809].
2559 Mussa A, Baldassarre G, Rosaia De Santis L, et al. Four new cases of PHACES syndrome: variable phenotypic expression and endocrine features. Acta Paediatr. Dec. 2008;97(12):1729-33. X-2. [pmid: 18801022].
2560 Nakamura M, Ishii K, Watanabe K, et al. Surgical treatment of intramedullary spinal cord tumors: prognosis and complications. Spinal Cord. Apr. 2008;46(4):282-6. X-1. [pmid: 17909556].
2561 Naqvi AH, Alfonso DT, Flores P, et al. Resolution of brachial plexus palsy due to hemangioma after intravenous corticosteroid therapy. J Child Neurol. Aug. 2008;23(8):956-8. X-1, X-2. [pmid: 18660479].
2562 Naqvi J, Ordonez NG, Luna MA, et al. Epithelioid hemangioendothelioma of the head and neck: role of podoplanin in the differential diagnosis. Head Neck Pathol. Mar. 2008;2(1):25-30. X-1. [pmid: 20614338].
2563 Noudel R, Litre F, Vinchon M, et al. Intramedullary spinal cord cavernous angioma in children: case report and literature review. Childs Nerv Syst. Feb. 2008;24(2):259-63. X-1. [pmid: 17849122].
2564 Numanoglu KV, Tatli D. A rare cause of hemorrhagic shock in children: bladder hemangioma. J Pediatr Surg. Jul. 2008;43(7):e1-3. X-1, X-2. [pmid: 18639666].
2565 Ozer EA, Duman N, Kumral A, et al. Chorioangiomatosis presenting with severe anemia and heart failure in a newborn. Fetal Diagn Ther. 2008;23(1):5-6. X-1. [pmid: 17934289].
2566 Pachl M, Elmalik K, Cohen M, et al. Ruptured splenic cavernous hemangioma in a neonate. J Pediatr Surg. Feb. 2008;43(2):407-9. X-1. [pmid: 18280302].
2567 Pascual-Castroviejo I, Pascual-Pascual SI, Velazquez-Fragua R, et al. Sturge-Weber syndrome: study of 55 patients. Can J Neurol Sci. Jul. 2008;35(3):301-7. X-1. [pmid: 18714797].
2568 Patron ME, Duker JS. Girl referred for an unusual optic disc lesion. Ocular Surgery News. 2008;26(23):42. PMID: X-1.
2569 Pereira VM, Geibprasert S, Krings T, et al. Pathomechanisms of symptomatic developmental venous anomalies. Stroke. Dec. 2008;39(12):3201-15. X-1. [pmid: 18988912].
2570 Pinho R, Rodrigues A, Proenca L, et al. Solitary hemangioma of the small bowel disclosed by wireless capsule endoscopy. Gastroenterol Clin Biol. Jan. 2008;32(1 Pt. 1):15-8. X-1. [pmid: 18405648].
2571 Polgreen LE, Tolar J, Plog M, et al. Growth and endocrine function in patients with Hurler syndrome after hematopoietic stem cell transplantation. Bone Marrow Transplant. Jun. 2008;41(12):1005-11. X-1. [pmid: 18278070].
2572 Prasad SC, Prasad KC, Bhat J. Vocal cord hemangioma. Med J Malaysia. Dec. 2008;63(5):419-20. X-1. [pmid: 19803307].
2573 Puvanachandra N, Heran MK, Lyons CJ. Morning glory disk anomaly with ipsilateral capillary hemangioma, agenesis of the internal carotid artery, and Horner syndrome: a variant of PHACES syndrome?. J aapos. Oct. 2008;12(5):528-30. X-1, X-2. [pmid: 18620881].
2574 Quagliano F, Fontana L, Parente G, et al. Choroidal effusion after diode laser cyclophotocoagulation in Sturge-Weber syndrome. J aapos. Oct. 2008;12(5):526-7. X-1. [pmid: 18571958].
2575 Rahman M, Rahman S, Rahman M, et al. Overlapping of Sturge Weber syndrome and Klippel Trenaunay Weber syndrome. Mymensingh Med J. Jan. 2008;17(1):78-81. X-1, X-2. [pmid: 18285739].
2576 Rao RP, Drolet BA, Holland KE, et al. PHACES association: a vasculocutaneous syndrome. Pediatr Cardiol. Jul. 2008;29(4):793-9. X-3, X-4. [pmid: 18427881].
2577 Ray WZ, Lee A, Blackburn SL, et al. Pseudotumor cerebri following tapered corticosteroid treatment in an 8-month-old infant. J Neurosurg Pediatr. Jan. 2008;1(1):88-90. X-2. [pmid: 18352810].
2578 Rivera LK, Nelson BL. Juvenile hemangioma of the parotid gland. Head Neck Pathol. Jun. 2008;2(2):81-2. X-2. [pmid: 20614327].
2579 Rodriguez JA, Becker NS, O’Mahony CA, et al. Long-term outcomes following liver transplantation for hepatic hemangioendothelioma: the UNOS experience from 1987 to 2005. J Gastrointest Surg. Jan. 2008;12(1):110-6. X-1. [pmid: 17710508].
2580 Saetti R, Silvestrini M, Cutrone C, et al. Treatment of congenital subglottic hemangiomas: our experience compared with reports in the literature. Arch Otolaryngol Head Neck Surg. Aug. 2008;134(8):848-51. X-3, X-4. [pmid: 18711059].
2581 Saxena AK, Willital GH. Infrared thermography: experience from a decade of pediatric imaging. Eur J Pediatr. Jul. 2008;167(7):757-64. X-3, X-4. [pmid: 17762940].
2582 Sayed W, Hellal Y, Kaabar N, et al. Sternal cleft, a rare congenital anomaly. Report of the first Tunisian case. Tunis Med. Dec. 2008;86(12):1082-5. X-1, X-2. [pmid: 19213519].
2583 Serena T. Wound closure and gradual involution of an infantile hemangioma using a noncontact, low-frequency ultrasound therapy. Ostomy Wound Manage. Feb. 2008;54(2):68-71. X-2. [pmid: 18401909].
2584 Sharp L, Makin E, Davenport M. Hepatic haemangioendothelioma: a vertical association with biliary atresia?. Eur J Pediatr Surg. Aug. 2008;18(4):277-9. X-1. [pmid: 18629768].
2585 Siegfried EC, Keenan WJ, Al-Jureidini S. More on propranolol for hemangiomas of infancy. N Engl J Med. Dec. 25. 2008;359(26):2846. author reply -7. X-1, X-2. [pmid: 19109584].
2586 Song DK, Lonser RR. Pathological satiety caused by brainstem hemangioblastoma. J Neurosurg Pediatr. Dec. 2008;2(6):397-401. X-1. [pmid: 19035684].
2587 Sorteberg A, Bakke SJ, Boysen M, et al. Angiographic balloon test occlusion and therapeutic sacrifice of major arteries to the brain. Neurosurgery. Oct. 2008;63(4):651-60. dicussion 60–1. X-1. [pmid: 18824944].
2588 Spector JA, Blei F, Zide BM. Early surgical intervention for proliferating hemangiomas of the scalp: indications and outcomes. Plast Reconstr Surg. Aug. 2008;122(2):457-62. X-3, X-4. [pmid: 18626361].
2589 Stamataki S, Francis HW, Holliday M, et al. Histological features of osteofibrous hemangioma of the maxillofacial and skull base regions. Otolaryngol Head Neck Surg. May. 2008;138(5):587-93. X-1. [pmid: 18439463].
2590 Strenger V, Sovinz P, Lackner H, et al. Intracerebral cavernous hemangioma after cranial irradiation in childhood. Incidence and risk factors. Strahlenther Onkol. May. 2008;184(5):276-80. X-1. [pmid: 18427759].
2591 Sun ZY, Yi CG, Zhao H, et al. Infantile hemangioma is originated from placental trophoblast, fact or fiction?. Med Hypotheses. Sep. 2008;71(3):444-8. X-1. [pmid: 18440158].
2592 Tang JY, Chen J, Pan C, et al. Diffuse cavernous hemangioma of the spleen with Kasabach-Merritt syndrome misdiagnosed as idiopathic thrombocytopenia in a child. World J Pediatr. Aug. 2008;4(3):227-30. X-1. [pmid: 18822934].
2593 Tolar J, Grewal SS, Bjoraker KJ, et al. Combination of enzyme replacement and hematopoietic stem cell transplantation as therapy for Hurler syndrome. Bone Marrow Transplant. Mar. 2008;41(6):531-5. X-1. [pmid: 18037941].
2594 Torre M, Rapuzzi G, Guida E, et al. Thymectomy to achieve primary closure of total sternal cleft. J Pediatr Surg. Dec. 2008;43(12):e17-20. X-1. [pmid: 19040914].
2595 Tronina SA, Bobrova NF, Khrinenko VP. Combined surgical method of orbital and periorbital hemangioma treatment in infants. Orbit. 2008;27(4):249-57. X-1. [pmid: 18716962].
2596 Uyama A, Kawamura A, Akiyama H, et al. A case of cerebellar capillary hemangioma with multiple cysts. Pediatr Neurosurg. 2008;44(4):344-9. X-1, X-2. [pmid: 18552520].
2597 van Steensel MA. Infantile hemangiomas: how to know when they grow. Arch Dermatol. Dec. 2008;144(12):1650. X-3, X-4. [pmid: 19075153].
2598 Varoglu AO, Tan H, Onbas O, et al. Intramedullary angioma with bilateral arm hypothermia. Br J Neurosurg. Oct. 2008;22(5):687-9. X-1. [pmid: 19016121].
2599 Vasilescu C, Stanciulea O, Popa M, et al. Subtotal laparoscopic splenectomy and esophagogastric devascularization for the thrombocytopenia because of portal cavernoma--case report. J Pediatr Surg. Jul. 2008;43(7):1373-5. X-1. [pmid: 18639700].
2600 Vasilevska V, Kirjas N, Zafirovski G, et al. Imaging of musculoskeletal soft-tissue vascular anomalies. Rentgenologiya i Radiologiya. 2008;47(1):42-8. X-6.
2601 Verity DH, Rose GE, Restori M. The effect of intralesional steroid injections on the volume and blood flow in periocular capillary haemangiomas. Orbit. 2008;27(1):41-7. X-3, X-4. [pmid: 18307146].
2602 Vetter-Kauczok CS, Strobel P, Brocker EB, et al. Kaposiform hemangioendothelioma with distant lymphangiomatosis without an association to Kasabach-Merritt-Syndrome in a female adult!. Vasc Health Risk Manag. 2008;4(1):263-6. X-1. [pmid: 18629354].
2603 Vineberg S, Kossoff EH. Puzzler. Don’t cry over spilled ... wine? A baby with a post-traumatic seizure. Contemp Pediatr. 5. 2008;25(10):24-7. 32. passim. PMID: X-1.
2604 Walner DL, Parker NP, Kim OS, et al. Lobular capillary hemangioma of the neonatal larynx. Arch Otolaryngol Head Neck Surg. Mar. 2008;134(3):272-7. X-1. [pmid: 18347252].
2605 Walsh MA, Carcao M, Pope E, et al. Kaposiform hemangioendothelioma presenting antenatally with a pericardial effusion. J Pediatr Hematol Oncol. Oct. 2008;30(10):761-3. X-1. [pmid: 19011475].
2606 Waner M, Kastenbaum J, Scherer K. Hemangiomas of the nose: surgical management using a modified subunit approach. Arch Facial Plast Surg. Sep–Oct. 2008;10(5):329-34. X-3, X-4. [pmid: 18794411].
2607 Wang C. Spinal hemangioblastoma: report on 68 cases. Neurol Res. Jul. 2008;30(6):603-9. X-1. [pmid: 18647501].
2608 Wasong SJ, Klepeiss SA, Zaenglein AL. Picture of the month. Ulcerated infantile hemangioma. Arch Pediatr Adolesc Med. Sep. 2008;162(9):893-4. X-2. [pmid: 18762610].
2609 Weinbreck N, Marie B, Bressenot A, et al. Immunohistochemical markers to distinguish between hemangioblastoma and metastatic clear-cell renal cell carcinoma in the brain: utility of aquaporin1 combined with cytokeratin AE1/AE3 immunostaining. Am J Surg Pathol. Jul. 2008;32(7):1051-9. X-1. [pmid: 18496143].
2610 Weiss AH, Kelly JP. Reappraisal of astigmatism induced by periocular capillary hemangioma and treatment with intralesional corticosteroid injection. Ophthalmology. Feb. 2008;115(2):390-7.e1. X-4. [pmid: 17588666].
2611 Weiss E, Sukal SA, Zimbler MS, et al. Basal cell carcinoma arising 57 years after interstitial radiotherapy of a nasal hemangioma. Dermatol Surg. Aug. 2008;34(8):1137-40. X-1, X-2. [pmid: 18513300].
2612 Wong WT, Agron E, Coleman HR, et al. Clinical characterization of retinal capillary hemangioblastomas in a large population of patients with von Hippel-Lindau disease. Ophthalmology. Jan. 2008;115(1):181-8. X-1. [pmid: 17543389].
2613 Wu PA, Mancini AJ, Marghoob AA, et al. Simultaneous occurrence of infantile hemangioma and congenital melanocytic nevus: Coincidence or real association?. J Am Acad Dermatol. Feb. 2008;58(2 Suppl):S16-22. X-3. [pmid: 18191691].
2614 Yan AC. Pain management for ulcerated hemangiomas. Pediatr Dermatol. Nov–Dec. 2008;25(6):586-9. X-1, X-2. [pmid: 19067860].
2615 Yang Y, Sun M, Hou R, et al. Preliminary study of fibrin glue combined with pingyangmycin for the treatment of venous malformations in the oral and maxillofacial region. J Oral Maxillofac Surg. Nov. 2008;66(11):2219-25. X-1. [pmid: 18940483].
2616 Yarlagadda R, Menda Y, Graham MM. Tc-99m red blood cell imaging in a patient with blue rubber bleb nevus syndrome. Clin Nucl Med. May. 2008;33(5):374-6. X-1. [pmid: 18431163].
2617 Yarmel D, Dormans JP, Pawel BR, et al. Recurrent pedal hobnail (Dabska-retiform) hemangioendothelioma with forefoot reconstructive surgery using a digital fillet flap. J Foot Ankle Surg. Sep–Oct. 2008;47(5):487-93. X-1. [pmid: 18725133].
2618 Yigiter M, Arda IS, Hicsonmez A. An unusual cause of paraphimosis: hemangioma of the glans penis. J Pediatr Surg. Feb. 2008;43(2):e31-3. X-1, X-2. [pmid: 18280267].
2619 Yu JE, Pai KS, Park MS. Congenital cavernous hemangioma exhibiting subcutaneous fat necrosis. Clin Pediatr (Phila). Jan. 2008;47(1):74-6. X-1. [pmid: 17766582].
2620 Yun TJ, Na DG, Kwon BJ, et al. A T1 hyperintense perilesional signal aids in the differentiation of a cavernous angioma from other hemorrhagic masses. AJNR Am J Neuroradiol. Mar. 2008;29(3):494-500. X-1. [pmid: 18039756].
2621 Zhang GY, Yi CG, Li X, et al. Proliferation hemangiomas formation through dual mechanism of vascular endothelial growth factor mediated endothelial progenitor cells proliferation and mobilization through matrix metalloproteinases 9. Med Hypotheses. 2008;70(4):815-8. X-1. [pmid: 17888584].
2622 CME posttest. JAAPA. 2009;22(5):50. PMID: X-1.
2623 Acciarri N, Galassi E, Giulioni M, et al. Cavernous malformations of the central nervous system in the pediatric age group. Pediatr Neurosurg. 2009;45(2):81-104. X-1. [pmid: 19307743].
2624 Acebo E, Gardeazabal J, Gonzalez-Hermosa R, et al. Congenital hemangioma: a report of evolution from rapidly involuting to noninvoluting congenital hemangioma with aberrant Mongolian spots. Pediatr Dermatol. Mar–Apr. 2009;26(2):225-6. X-1. [pmid: 19419482].
2625 Acioglu E, Cansiz H, Mercan H, et al. Head and neck hemangiopericytomas: diagnostic contradictions. J Craniofac Surg. May. 2009;20(3):930-5. X-1. [pmid: 19461334].
2626 Adams ME, Aylett SE, Squier W, et al. A spectrum of unusual neuroimaging findings in patients with suspected Sturge-Weber syndrome. AJNR Am J Neuroradiol. Feb. 2009;30(2):276-81. X-1. [pmid: 19050205].
2627 Agrawal A, Cincu R, Joharapurkar SR, et al. Hemorrhage in brain stem cavernoma presenting with torticollis. Pediatr Neurosurg. 2009;45(1):49-52. X-1. [pmid: 19258729].
2628 Alexiou GA, Mpairamidis E, Sfakianos G, et al. Surgical management of brain cavernomas in children. Pediatr Neurosurg. 2009;45(5):375-8. X-1. [pmid: 19940535].
2629 Al-Ghadeer H, Al-Rajhi A, Riley F. Episcleral hemangioma as an isolated finding. Eur J Ophthalmol. Mar–Apr. 2009;19(2):292-4. X-1. [pmid: 19253250].
2630 Al-Kaabi A, Yanofsky R, Bunge M, et al. Diffuse hemangiomatosis with predominant central nervous system involvement. Pediatr Neurol. Jan. 2009;40(1):54-7. X-1, X-2. [pmid: 19068256].
2631 Al-Mubarak L, Al-Khenaizan S. A wolf in sheep’s disguise: rhabdomyosarcoma misdiagnosed as infantile hemangioma. J Cutan Med Surg. Sep–Oct. 2009;13(5):276-9. X-1. [pmid: 19769838].
2632 Al-Tonbary Y, Fouda A. Infantile hepatic hemangioendothelioma: an 8-month old infant successfully treated with a corticosteroid. Hematol Oncol Stem Cell Ther. 2009;2(3):422-5. X-1, X-2. [pmid: 20139057].
2633 Angiero F, Benedicenti S, Benedicenti A, et al. Head and neck hemangiomas in pediatric patients treated with endolesional 980-nm diode laser. Photomed Laser Surg. Aug. 2009;27(4):553-9. X-3, X-4. [pmid: 19558311].
2634 Badi AN, Kerschner JE, North PE, et al. Histopathologic and immunophenotypic profile of subglottic hemangioma: multicenter study. Int J Pediatr Otorhinolaryngol. Sep. 2009;73(9):1187-91. X-1, X-2. [pmid: 19524305].
2635 Barbagallo M, Ruggieri M, Incorpora G, et al. Infantile spasms in the setting of Sturge-Weber syndrome. Childs Nerv Syst. Jan. 2009;25(1):111-8. X-1. [pmid: 18830609].
2636 Barco D, Baselga E, Alegre M, et al. Successful treatment of eccrine angiomatous hamartoma with botulinum toxin. Arch Dermatol. Mar. 2009;145(3):241-3. X-1. [pmid: 19289750].
2637 Beck DO, Gosain AK. The presentation and management of hemangiomas. Plast Reconstr Surg. Jun. 2009;123(6):181e-91e. X-1, X-2. [pmid: 19483535].
2638 Bedard MS, Boulanger J. Treatment of lobular capillary hemangioma with the Nd:YAG laser: retrospective case series of 25 patients. J Cutan Med Surg. May–Jun. 2009;13(3):181-2. X-4. [pmid: 19426632].
2639 Benedetti E, Proietti A, Miccoli P, et al. Contrast-enhanced ultrasonography in nodular splenomegaly associated with type B Niemann-Pick disease: an atypical hemangioma enhancement pattern. J Ultrasound. September. 2009;12(3):85-92. X-1. [pmid: 23396497].
2640 Bernotas G, Rastenyte D, Deltuva V, et al. Cavernous angiomas: an uncontrolled clinical study of 87 surgically treated patients. Medicina (Kaunas). 2009;45(1):21-8. X-1. [pmid: 19223702].
2641 Bigorre M, Van Kien AK, Valette H. Beta-blocking agent for treatment of infantile hemangioma. Plast Reconstr Surg. Jun. 2009;123(6):195e-6e. X-3, X-4. [pmid: 19483538].
2642 Bijarnia S, Shaw P, Vimpani A, et al. Combined enzyme replacement and haematopoietic stem cell transplantation in Hurler syndrome. J Paediatr Child Health. Jul–Aug. 2009;45(7–8):469-72. X-1. [pmid: 19712183].
2643 Bonifazi E, Milano A. Capillary angioma with findings of Masson’s tumor. European Journal of Pediatric Dermatology. April–June. 2009;19(2):117. X-1.
2644 Buckmiller L, Dyamenahalli U, Richter GT. Propranolol for airway hemangiomas: case report of novel treatment. Laryngoscope. Oct. 2009;119(10):2051-4. X-2. [pmid: 19650125].
2645 Buckmiller LM. Propranolol treatment for infantile hemangiomas. Curr Opin Otolaryngol Head Neck Surg. Dec. 2009;17(6):458-9. X-1, X-2. [pmid: 19858718].
2646 Bun YY, Ming CK, Ming CH, et al. Endovascular treatment of a neonate with dural arteriovenous fistula and other features suggestive of cerebrofacial arteriovenous metameric syndromes. Childs Nerv Syst. Mar. 2009;25(3):383-7. X-1. [pmid: 19082615].
2647 Burget GC. Preliminary review of pediatric nasal reconstruction with detailed report of one case. Plast Reconstr Surg. Sep. 2009;124(3):907-18. X-1. [pmid: 19730311].
2648 Cabrita SV, Goncalves S, Rodrigues H, et al. Antenatal diagnosis of congenital hepatic hemangioma: A case report. Cases Journal. 2009;2(8). X-1.
2649 Cardinal J, de Vera ME, Marsh JW, et al. Treatment of hepatic epithelioid hemangioendothelioma: a single-institution experience with 25 cases. Arch Surg. Nov. 2009;144(11):1035-9. X-1. [pmid: 19917940].
2650 Cernik C, Channaiah D, Trevino J. Angiomatoid fibrous histiocytoma in a six-year-old child. Pediatr Dermatol. Sep–Oct. 2009;26(5):636-8. X-1. [pmid: 19840338].
2651 Chao YH, Liang DC, Chen SH, et al. Interferon-alpha for alarming hemangiomas in infants: experience of a single institution. Pediatr Int. Aug. 2009;51(4):469-73. X-4. [pmid: 19400814].
2652 Chen L, Zhao Y, Chen Z, et al. Multiple dynamic cavernous malformations in a girl: long-term follow-up. Surg Neurol. Dec. 2009;72(6):728-32. X-1. [pmid: 19604555].
2653 Chen YJ, Wang CK, Tien YC, et al. MRI of multifocal kaposiform haemangioendothelioma without Kasabach-Merritt phenomenon. Br J Radiol. Mar. 2009;82(975):e51-4. X-1. [pmid: 19211904].
2654 Chiou HJ, Chou YH, Chiu SY, et al. Differentiation of benign and malignant superficial soft-tissue masses using grayscale and color doppler ultrasonography. J Chin Med Assoc. Jun. 2009;72(6):307-15. X-1. [pmid: 19541566].
2655 Cho WS, Kim SK, Park SH, et al. Intracranial kaposiform hemangioendothelioma: proposal of a new malignant variant. J Neurosurg Pediatr. Feb. 2009;3(2):147-50. X-1. [pmid: 19278316].
2656 Cole P, Kaufman Y, Metry D, et al. Non-involuting congenital haemangioma associated with high-output cardiomyopathy. J Plast Reconstr Aesthet Surg. Oct. 2009;62(10):e379-82. X-1. [pmid: 19195949].
2657 Connelly EA, Viera M, Price C, et al. Segmental hemangioma of infancy complicated by life-threatening arterial bleed. Pediatr Dermatol. Jul–Aug. 2009;26(4):469-72. X-2. [pmid: 19689527].
2658 das Chagas MS, Pinheiro Rdos S, Janini ME, et al. Pyogenic granuloma: lobular capillary hemangioma in the upper lip of a 24-month-old child: case report. J Dent Child (Chic). Sep–Dec. 2009;76(3):237-40. X-1, X-2. [pmid: 19941768].
2659 Dashti SR, Fiorella D, Spetzler RF, et al. Preoperative Onyx embolization of a giant cavernous malformation involving the dural sinuses. J Neurosurg Pediatr. Apr. 2009;3(4):302-6. X-1. [pmid: 19338408].
2660 Degerliyurt A, Kantar A, Ceylaner S, et al. Hypomelanosis of Ito and Sturge-Weber syndrome without facial nevus: an association or a new syndrome?. Pediatr Neurol. May. 2009;40(5):395-7. X-1. [pmid: 19380080].
2661 Demirci H, Shields CL, Eagle RC Jr, et al. Giant cell angiofibroma, a variant of solitary fibrous tumor, of the orbit in a 16-year-old girl. Ophthal Plast Reconstr Surg. Sep–Oct. 2009;25(5):402-4. X-1. [pmid: 19966660].
2662 Denoyelle F, Leboulanger N, Enjolras O, et al. Role of Propranolol in the therapeutic strategy of infantile laryngotracheal hemangioma. Int J Pediatr Otorhinolaryngol. Aug. 2009;73(8):1168-72. X-3, X-4. [pmid: 19481268].
2663 Dickie B, Dasgupta R, Nair R, et al. Spectrum of hepatic hemangiomas: management and outcome. J Pediatr Surg. Jan. 2009;44(1):125-33. X-3, X-4. [pmid: 19159729].
2664 Disma N, Tuo P, Pellegrino S, et al. Three concentrations of levobupivacaine for ilioinguinal/iliohypogastric nerve block in ambulatory pediatric surgery. J Clin Anesth. Sep. 2009;21(6):389-93. X-1. [pmid: 19833270].
2665 Dong KR, Zheng S, Xiao X. Conservative management of neonatal hepatic hemangioma: a report from one institute. Pediatr Surg Int. Jun. 2009;25(6):493-8. X-3, X-4. [pmid: 19415303].
2666 Drucker AM, Pope E, Mahant S, et al. Vincristine and corticosteroids as first-line treatment of Kasabach-Merritt syndrome in kaposiform hemangioendothelioma. J Cutan Med Surg. May–Jun. 2009;13(3):155-9. X-1. [pmid: 19426625].
2667 Dueas-Arias JE, Armbula-Meraz E, Frias-Castro LO, et al. Tetralogy of Fallot associated with macrocephaly-capillary malformation syndrome: A case report and review of the literature. J Med Case Rep. 2009;3(9215). X-1.
2668 Earl JB, Kramm L, Durairaj VD. Benign hamartoma masquerading as a deep orbital hemangioma. J Pediatr Ophthalmol Strabismus. Jul–Aug. 2009;46(4):228-31. X-1, X-2. [pmid: 19645403].
2669 Eidemuller M, Holmberg E, Jacob P, et al. Breast cancer risk among Swedish hemangioma patients and possible consequences of radiation-induced genomic instability. Mutat Res. Oct. 2. 2009;669(1–2):48-55. X-3, X-4. [pmid: 19416732].
2670 Evagelidou E, Tsanou E, Asproudis I, et al. Orbital cavernous hemangioma in an infant with intracranial lesions: A case report. Cases Journal. September. 2009;2(9). X-1.
2671 Fiorillo A, DeRosa G, Giugliano F, et al. Efficacy of pegylated lyposomal anthracyclines and of intra-arterial carboplatin and doxorubicin combined with local hyperthermia in a case of malignant endovascular papillary angioendothelioma. Curr Drug Deliv. Jan. 2009;6(1):58-61. X-1. [pmid: 19418956].
2672 Ford S, Dosani M, Robinson AJ, et al. Defining the reliability of sonoanatomy identification by novices in ultrasound-guided pediatric ilioinguinal and iliohypogastric nerve blockade. Anesth Analg. Dec. 2009;109(6):1793-8. X-1. [pmid: 19923504].
2673 Frieden IJ, Drolet BA. Propranolol for infantile hemangiomas: promise, peril, pathogenesis. Pediatr Dermatol. Sep–Oct. 2009;26(5):642-4. X-2. [pmid: 19840341].
2674 Friling R, Axer-Siegel R, Ben-Amitai D, et al. Intralesional and sub-Tenon’s infusion of corticosteroids for treatment of refractory periorbital and orbital capillary haemangioma. Eye (Lond). Jun. 2009;23(6):1302-7. X-3, X-4. [pmid: 18989344].
2675 Garces-Ambrossi GL, McGirt MJ, Mehta VA, et al. Factors associated with progression-free survival and long-term neurological outcome after resection of intramedullary spinal cord tumors: analysis of 101 consecutive cases. J Neurosurg Spine. Nov. 2009;11(5):591-9. X-1. [pmid: 19929363].
2676 Garg R, Gupta N, Sharma A, et al. Acquired capillary hemangioma of the eyelid in a child. J Pediatr Ophthalmol Strabismus. Mar–Apr. 2009;46(2):118-9. X-2. [pmid: 19343976].
2677 Garzon MC, Horii KA, Haggstrom AN. Advanced haemangioma management forum. Hong Kong Journal of Dermatology and Venereology. Summer. 2009;17(2):108-9. PMID: X-1.
2678 Geramizadeh B, Banani A, Foroutan H, et al. Malignant epithelioid hemangioendothelioma of the bladder: the first case report in a child. J Pediatr Surg. Jul. 2009;44(7):1443-5. X-1. [pmid: 19573676].
2679 Good WV, Hou C, Frieden IJ, et al. Evidence for visual compromise in preverbal children with orbital vascular birthmarks. Am J Ophthalmol. Apr. 2009;147(4):679-82.e1. X-3, X-4. [pmid: 19195640].
2680 Gosain AK, Zochowski CG, Cortes W. Refinements of tissue expansion for pediatric forehead reconstruction: a 13-year experience. Plast Reconstr Surg. Nov. 2009;124(5):1559-70. X-1. [pmid: 20009842].
2681 Grabhorn E, Richter A, Fischer L, et al. Neonates with severe infantile hepatic hemangioendothelioma: limitations of liver transplantation. Pediatr Transplant. Aug. 2009;13(5):560-4. X-1. [pmid: 18992050].
2682 Green H. Intonation in Hebrew-speaking children with high functioning autism. Asia Pac J Speech Lang Hear. 2009;12(2):187-98. PMID: X-1.
2683 Gucev ZS, Pop-Jordanova N, Dumalovska G, et al. Arthrogryposis multiplex congenital (AMC) in a three year old boy: Differential diagnosis with distal arthrogryposis: A case report. Cases Journal. December. 2009;2(12). X-1.
2684 Gunduz K, Kurt RA, Erden E. Well-circumscribed orbital venous-lymphatic malformations with atypical features in children. Br J Ophthalmol. May. 2009;93(5):656-9. X-1. [pmid: 19074919].
2685 Habibi S, Agrawal S, Kadel JK, et al. Post-traumatic capillary hemangiomas: a rare cause of hand nodules. Clin Rheumatol. Jun. 2009;28(Suppl 1):S51-2. X-1. [pmid: 19255719].
2686 Haddy N, Andriamboavonjy T, Paoletti C, et al. Thyroid adenomas and carcinomas following radiotherapy for a hemangioma during infancy. Radiother Oncol. Nov. 2009;93(2):377-82. X-1, X-3. [pmid: 19515442].
2687 Hale TS, Loo SK, Zaidel E, et al. Rethinking a right hemisphere deficit in ADHD. J Atten Disord. Jul. 2009;13(1):3-17. X-1. [pmid: 18753404].
2688 Hansen LF, Wewer V, Pedersen SA, et al. Severe blue rubber bleb nevus syndrome in a neonate. Eur J Pediatr Surg. Feb. 2009;19(1):47-9. X-1. [pmid: 18629772].
2689 Hara K, Yoshida T, Kajiume T, et al. Successful treatment of Kasabach-Merritt syndrome with vincristine and diagnosis of the hemangioma using three-dimensional imaging. Pediatr Hematol Oncol. Jul–Aug. 2009;26(5):375-80. X-1, X-2. [pmid: 19579084].
2690 Hartman KR, Moncur JT, Minniti CP, et al. Mediastinal Kaposiform hemangioendothelioma and Kasabach-Merritt phenomenon in an infant: treatment with interferon. J Pediatr Hematol Oncol. Sep. 2009;31(9):690-2. X-1. [pmid: 19687760].
2691 Hauck EF, Barnett SL, White JA, et al. Symptomatic brainstem cavernomas. Neurosurgery. Jan. 2009;64(1):61-70. discussion -1. X-1. [pmid: 19050659].
2692 Hermans DJ, Boezeman JB, Van de Kerkhof PC, et al. Differences between ulcerated and non-ulcerated hemangiomas, a retrospective study of 465 cases. Eur J Dermatol. Mar–Apr. 2009;19(2):152-6. X-3. [pmid: 19106042].
2693 Highton LR, Pay AD. An unusual midline nasal mass in a newborn. J Plast Reconstr Aesthet Surg. May. 2009;62(5):695-6. X-1. [pmid: 18502194].
2694 Hoeger PH, Maerker JM, Kienast AK, et al. Neonatal haemangiomatosis associated with placental chorioangiomas: report of three cases and review of the literature. Clin Exp Dermatol. Jul. 2009;34(5):e78-80. X-1. [pmid: 19438546].
2695 Holmes LB. Chorionic villus sampling and hemangiomas. J Craniofac Surg. Mar. 2009;20(Suppl 1):675-7. X-1, X-2. [pmid: 19218861].
2696 Holzapfel BM, Geitner U, Diebold J, et al. Synovial hemangioma of the knee joint with cystic invasion of the femur: a case report and review of the literature. Arch Orthop Trauma Surg. Feb. 2009;129(2):143-8. X-1. [pmid: 18758797].
2697 Hoornweg MJ, Grootenhuis MA, van der Horst CM. Health-related quality of life and impact of haemangiomas on children and their parents. J Plast Reconstr Aesthet Surg. Oct. 2009;62(10):1265-71. X-3, X-4. [pmid: 18602360].
2698 Houston SK, Bourne TD, Lopes MB, et al. Bilateral massive retinal gliosis associated with retinopathy of prematurity. Arch Pathol Lab Med. Aug. 2009;133(8):1242-5. X-1. [pmid: 19653718].
2699 Hussain W, Judge MR. The role of imiquimod in treating infantile haemangiomas: cause for concern?. Clin Exp Dermatol. Oct. 2009;34(7):e257. X-3, X-4. [pmid: 19508566].
2700 Iriz A, Durmaz E, Akmansu SH, et al. Vocal cord hemangioma; A rare localization in adults. Turkish Journal of Medical Sciences. April. 2009;39(2):305-7. X-1.
2701 Iwai Y, Yamanaka K. Gamma knife radiosurgery for other primary intra-axial tumors. Prog Neurol Surg. 2009;22:129-41. X-1. [pmid: 18948725].
2702 Jackson MG, Simms-Cendan J, Sims SM, et al. Vaginal bleeding due to an infantile hemangioma in a 3-year-old girl. J Pediatr Adolesc Gynecol. Aug. 2009;22(4):e53-5. X-2. [pmid: 19493519].
2703 Jephson CG, Manunza F, Syed S, et al. Successful treatment of isolated subglottic haemangioma with propranolol alone. Int J Pediatr Otorhinolaryngol. Dec. 2009;73(12):1821-3. X-1, X-2. [pmid: 19796830].
2704 Jerjes W, Upile T, Vincent A, et al. Management of deep-seated malformations with photodynamic therapy: a new guiding imaging modality. Lasers Med Sci. Sep. 2009;24(5):769-75. X-1. [pmid: 19377913].
2705 Joe KJ, Huitron SS, Crawford JJ, et al. Idiopathic equinocavovarus foot deformity in an 8-year-old girl. Clin Orthop Relat Res. Sep. 2009;467(9):2482-6. X-1. [pmid: 19198964].
2706 Johnson O. Splenectomy: experience from Tikur Anbessa Hospital, Addis Ababa 1988–2007. Ethiop Med J. Jan. 2009;47(2):165-9. X-1. [pmid: 19743797].
2707 Kalane U, Kulkarni S. A case of neurocutaneous syndrome associated with facial hemangioma: PHACE syndrome. J Pediatr Neurol. 2009;7(3):325-7. X-2.
2708 Kim JH, Park HY, Ahn SK. Cherry Angiomas on the Scalp. Case Rep Dermatol. 2009;1(1):82-6. X-1. [pmid: 20652121].
2709 Kleaveland B, Zheng X, Liu JJ, et al. Regulation of cardiovascular development and integrity by the heart of glass-cerebral cavernous malformation protein pathway. Nat Med. Feb. 2009;15(2):169-76. X-1. [pmid: 19151727].
2710 Koh C, Sugo E, Wargon O. Unusual presentation of GLUT-1 positive infantile haemangioma. Australas J Dermatol. May. 2009;50(2):136-40. X-2. [pmid: 19397570].
2711 Kossoff EH, Ferenc L, Comi AM. An infantile-onset, severe, yet sporadic seizure pattern is common in Sturge-Weber syndrome. Epilepsia. Sep. 2009;50(9):2154-7. X-1. [pmid: 19389148].
2712 Ksendzovsky A, Glick R, Utset M, et al. A rare case of hemangioma of infancy presenting as intraspinal hemorrhage. J Neurosurg Pediatr. May. 2009;3(5):429-34. X-2. [pmid: 19409024].
2713 Laforgia N, Milano A, De Leo E, et al. Hemangioma and propranolol. Some remarks at the end of treatment. Differences from corticosteroids. Eur J Pediat Dermatol. 2009;19:175-91. PMID: X-3.
2714 Lapidoth M, Ben-Amitai D, Bhandarkar S, et al. Efficacy of topical application of eosin for ulcerated hemangiomas. J Am Acad Dermatol. Feb. 2009;60(2):350-1. X-3, X-4. [pmid: 19150285].
2715 Laubach HJ, Anderson RR, Luger T, et al. Fractional photothermolysis for involuted infantile hemangioma. Arch Dermatol. Jul. 2009;145(7):748-50. X-2. [pmid: 19620554].
2716 Lawley LP, Siegfried E, Todd JL. Propranolol treatment for hemangioma of infancy: risks and recommendations. Pediatr Dermatol. Sep–Oct. 2009;26(5):610-4. X-2. [pmid: 19840322].
2717 Leong E, Bydder S. Use of radiotherapy to treat life-threatening Kasabach-Merritt syndrome. J Med Imaging Radiat Oncol. Feb. 2009;53(1):87-91. X-1. [pmid: 19453533].
2718 Lisle JW, Bradeen HA, Kalof AN. Kaposiform hemangioendothelioma in multiple spinal levels without skin changes. Clin Orthop Relat Res. Sep. 2009;467(9):2464-71. X-1. [pmid: 19381744].
2719 Liu FH, Hsueh C, Chao TC, et al. Neck nodule and thyroid cancer in young without radiation exposure history. Pediatr Surg Int. Sep. 2009;25(9):785-8. X-1. [pmid: 19629501].
2720 Liu XJ, Qin ZP, Tai MZ. Angiographic classification and sclerotic therapy of maxillofacial cavernous haemangiomas: a report of 204 cases. J Int Med Res. Sep–Oct. 2009;37(5):1285-92. X-1. [pmid: 19930833].
2721 Liu Y, Jiao P, Tan X, et al. Reconstruction of facial defects using prefabricated expanded flaps carried by temporoparietal fascia flaps. Plast Reconstr Surg. Feb. 2009;123(2):556-61. X-1. [pmid: 19182613].
2722 Lobo-Mueller E, Amaral JG, Babyn PS, et al. Extremity vascular anomalies in children: introduction, classification, and imaging. Semin Musculoskelet Radiol. Sep. 2009;13(3):210-35. X-1, X-2. [pmid: 19724991].
2723 Lomenick JP, Reifschneider KL, Lucky AW, et al. Prevalence of adrenal insufficiency following systemic glucocorticoid therapy in infants with hemangiomas. Arch Dermatol. Mar. 2009;145(3):262-6. X-3, X-4. [pmid: 19289754].
2724 Lonser RR, Butman JA, Kiringoda R, et al. Pituitary stalk hemangioblastomas in von Hippel-Lindau disease. J Neurosurg. Feb. 2009;110(2):350-3. X-1. [pmid: 18834262].
2725 Lopez V, Marti N, Pereda C, et al. Successful management of Kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon using vincristine and ticlopidine. Pediatr Dermatol. May–Jun. 2009;26(3):365-6. X-1. [pmid: 19706115].
2726 Madan V, Lloyd IC, Wakefield RM, et al. PHACE syndrome. Clin Exp Dermatol. Jul. 2009;34(5):651-2. X-2. [pmid: 19508485].
2727 Madhusudhan KS, Sharma R, Kandpal H, et al. A rare case of combined soft-tissue and intraosseous arteriovenous malformation of the hand with diffuse periosteal elevation: imaging appearances. Br J Radiol. Nov. 2009;82(983):e219-24. X-1. [pmid: 19890114].
2728 Maguiness SM, Frieden IJ. Infantile hemangiomas: a look back and future directions. Actas Dermosifiliogr. Nov. 2009;100(Suppl 1):73-6. X-1, X-2. [pmid: 20096199].
2729 Markiewicz-Kijewska M, Kasprzyk W, Broniszczak D, et al. Hemodynamic failure as an indication to urgent liver transplantation in infants with giant hepatic hemangiomas or vascular malformations--report of four cases. Pediatr Transplant. Nov. 2009;13(7):906-12. X-1. [pmid: 18992048].
2730 Matsuyama Y, Sakai Y, Katayama Y, et al. Surgical results of intramedullary spinal cord tumor with spinal cord monitoring to guide extent of resection. J Neurosurg Spine. May. 2009;10(5):404-13. X-1. [pmid: 19442001].
2731 McCuaig CC, Dubois J, Powell J, et al. A phase II, open-label study of the efficacy and safety of imiquimod in the treatment of superficial and mixed infantile hemangioma. Pediatr Dermatol. Mar–Apr. 2009;26(2):203-12. X-4. [pmid: 19419474].
2732 Meijer-Jorna LB, Breugem CC, de Boer OJ, et al. Presence of a distinct neural component in congenital vascular malformations relates to the histological type and location of the lesion. Hum Pathol. Oct. 2009;40(10):1467-73. X-1. [pmid: 19454356].
2733 Mendez-Gallart R, Tellado MG, Del Pozo-Losada J, et al. A rapid onset erythematous facial lesion in a neonatal patient. Pediatr Dermatol. Mar–Apr. 2009;26(2):195-6. X-1, X-2. [pmid: 19419472].
2734 Minagar A, Kelley RE. Translation of stroke research into stroke therapy. Neurol Res. Oct. 2009;31(8):773-4. X-1. [pmid: 19723444].
2735 Moghimi M, Ben Razavi S, Akhavan A, et al. Hobnail hemangioendothelioma (Dabska type) in the right thigh. Eur J Pediatr Surg. Oct. 2009;19(5):337-9. X-1. [pmid: 19431104].
2736 Mohamed AM, Elwakil TF, Taher IM, et al. Cyclin D1 gene amplification in proliferating haemangioma. Cell Tissue Res. Oct. 2009;338(1):107-15. X-1, X-3. [pmid: 19823825].
2737 Moler FW, Meert K, Donaldson AE, et al. In-hospital versus out-of-hospital pediatric cardiac arrest: a multicenter cohort study. Crit Care Med. Jul. 2009;37(7):2259-67. X-1. [pmid: 19455024].
2738 Moon SB, Kwon HJ, Park KW, et al. Clinical experience with infantile hepatic hemangioendothelioma. World J Surg. Mar. 2009;33(3):597-602. X-1. [pmid: 19132441].
2739 Murthy R, Honavar SG. Secondary vasoproliferative retinal tumor associated with Usher syndrome type 1. J aapos. Feb. 2009;13(1):97-8. X-1. [pmid: 19022692].
2740 Murthy R, Naik MN, Desai S, et al. PHACE syndrome associated with congenital oculomotor nerve palsy. Strabismus. Apr–Jun. 2009;17(2):75-7. X-2. [pmid: 19551563].
2741 Nielsen GP, Srivastava A, Kattapuram S, et al. Epithelioid hemangioma of bone revisited: a study of 50 cases. Am J Surg Pathol. Feb. 2009;33(2):270-7. X-1. [pmid: 18852673].
2742 O TM, Alexander RE, Lando T, et al. Segmental hemangiomas of the upper airway. Laryngoscope. Nov. 2009;119(11):2242-7. X-3, X-4. [pmid: 19806648].
2743 Oliveira AC, de Moraes Ramos FM, Jeunon FA, et al. Central haemangioma of the mandible in a 7-year old child. Int J Paediatr Dent. May. 2009;19(3):216-8. X-2. [pmid: 18489573].
2744 Ooi KG, Wenderoth JD, Francis IC, et al. Selective embolization and resection of a large noninvoluting congenital hemangioma of the lower eyelid. Ophthal Plast Reconstr Surg. Mar–Apr. 2009;25(2):111-4. X-1. [pmid: 19300152].
2745 O’Regan GM, Irvine AD, Yao N, et al. Mediastinal and neck kaposiform hemangioendothelioma: report of three cases. Pediatr Dermatol. May–Jun. 2009;26(3):331-7. X-1. [pmid: 19706099].
2746 Palmero ML, Pope E. Eruptive pyogenic granulomas developing after drug hypersensitivity reaction. J Am Acad Dermatol. May. 2009;60(5):855-7. X-1, X-2. [pmid: 19211171].
2747 Pandey A, Gangopadhyay AN, Sharma SP, et al. Conservative management of ulcerated haemangioma--twenty years experience. Int Wound J. Feb. 2009;6(1):59-62. X-3, X-4. [pmid: 19291117].
2748 Pang WB, Zhang TC, Chen YJ, et al. Space-occupying benign lesions in spleen: experiences in a single institute. Pediatr Surg Int. Jan. 2009;25(1):31-5. X-1. [pmid: 18956203].
2749 Pascual-Castroviejo I, Viano J, Pascual-Pascual SI, et al. Congenital and evolving vascular disorders associated with cutaneous hemangiomas: case report. Neuropediatrics. Jun. 2009;40(3):148-51. X-2. [pmid: 20020403].
2750 Peker E, Kirimi E, Tuncer O, et al. Brachial plexus paralysis due to giant cavernous hemangioma with Kasabach-Merritt syndrome: successful management with interferon alpha. Platelets. Dec. 2009;20(8):603-5. X-1. [pmid: 19929246].
2751 Perkins JA, Chen EY, Hoffer FA, et al. Proposal for staging airway hemangiomas. Otolaryngol Head Neck Surg. Oct. 2009;141(4):516-21. X-3, X-4. [pmid: 19786222].
2752 Perkins JA, Duke W, Chen E, et al. Emerging concepts in airway infantile hemangioma assessment and management. Otolaryngol Head Neck Surg. Aug. 2009;141(2):207-12. X-4. [pmid: 19643253].
2753 Perkins JA, Oliaei S, Garrison MM, et al. Airway procedures and hemangiomas: treatment patterns and outcome in U.S. pediatric hospitals. Int J Pediatr Otorhinolaryngol. Sep. 2009;73(9):1302-7. X-3, X-4. [pmid: 19592117].
2754 Petroianu A, Teixeira BC, de Alencar LF. Partial splenectomy for treatment of splenic hemangioma. Chirurgia (Bucur). Jul–Aug. 2009;104(4):483-6. X-1. [pmid: 19886058].
2755 Peyre M, Di Rocco F, Varlet P, et al. Supratentorial hemangioblastoma in the neonatal period. Pediatr Neurosurg. 2009;45(2):155-6. X-1. [pmid: 19321952].
2756 Pitt C, Lavery C, Wager N. Psychosocial outcomes of bone marrow transplant for individuals affected by Mucopolysaccharidosis I Hurler Disease: patient social competency. Child Care Health Dev. Mar. 2009;35(2):271-80. X-1. [pmid: 19228160].
2757 Pitta GBB, Gomes RR. Treatment of ulcerated hemangioma: Case report. Jornal Vascular Brasileiro. 2009;8(3). X-2.
2758 Praveen V, Vidavalur R, Rosenkrantz TS, et al. Infantile hemangiomas and retinopathy of prematurity: possible association. Pediatrics. Mar. 2009;123(3):e484-9. X-3. [pmid: 19221153].
2759 Rai P, Shah SIS, Narsani AK, et al. Analysis of primary benign orbital lesions. Int J Ophthalmol. 25. Apr. 2009;9(4):634-41. X-6.
2760 Ramantani G, Niggemann P, Hahn G, et al. Unusual radiological presentation of tuberous sclerosis complex with leptomeningeal angiomatosis associated with a hypomorphic mutation in the TSC2 gene. J Child Neurol. Mar. 2009;24(3):333-7. X-1. [pmid: 19258292].
2761 Ramesh R, De Silva B, Atherton DJ. Congenital tufted angioma with persistent low-grade coagulopathy. Clin Exp Dermatol. Dec. 2009;34(8):e766-8. X-1. [pmid: 19778314].
2762 Roganovic J, Adams D. PHACES syndrome--case report and literature review. Coll Antropol. Mar. 2009;33(1):311-4. X-2. [pmid: 19408643].
2763 Rudnick EF, Chen EY, Manning SC, et al. PHACES syndrome: otolaryngic considerations in recognition and management. Int J Pediatr Otorhinolaryngol. Feb. 2009;73(2):281-8. X-3, X-4. [pmid: 19081148].
2764 Sahiner UM, Senel S, Erkek N, et al. Rubinstein Taybi syndrome with hepatic hemangioma. Med Princ Pract. 2009;18(2):162-4. X-2. [pmid: 19204439].
2765 Saito M, Gunji Y, Kashii Y, et al. Refractory kaposiform hemangioendothelioma that expressed vascular endothelial growth factor receptor (VEGFR)-2 and VEGFR-3: a case report. J Pediatr Hematol Oncol. Mar. 2009;31(3):194-7. X-1. [pmid: 19262246].
2766 Sardi I, Sanzo M, Giordano F, et al. Monotherapy with thalidomide for treatment of spinal cord hemangioblastomas in a patient with von Hippel-Lindau disease. Pediatr Blood Cancer. Sep. 2009;53(3):464-7. X-1. [pmid: 19415739].
2767 Savino G, Aliberti S, Colucci D, et al. Atypical presentation of a case of solitary fibrous tumor of the orbit. Orbit. 2009;28(2–3):176-8. X-1. [pmid: 19839906].
2768 Schick U, Hassler W. Treatment of deep vascular orbital malformations. Clin Neurol Neurosurg. Dec. 2009;111(10):801-7. X-1. [pmid: 19726125].
2769 Schild C, Kayser G, Aschendorff A, et al. Pedunculated capillary hemangioma of the external ear. Otolaryngol Head Neck Surg. May. 2009;140(5):764-5. X-1. [pmid: 19393427].
2770 Schmitz R, Heinig J, Klockenbusch W, et al. Antenatal diagnosis of a giant fetal hepatic hemangioma and treatment with maternal corticosteroid. Ultraschall Med. Jun. 2009;30(3):223-6. X-1, X-2. [pmid: 19507116].
2771 Seitz K, Strobel D, Bernatik T, et al. Contrast-Enhanced Ultrasound (CEUS) for the characterization of focal liver lesions - prospective comparison in clinical practice: CEUS vs. CT (DEGUM multicenter trial). Parts of this manuscript were presented at the Ultrasound Dreilandertreffen 2008, Davos. Ultraschall Med. Aug. 2009;30(4):383-9. X-4. [pmid: 19688670].
2772 Shafqat G, Iqbal F, Rizvi F. Chorioangioma of the placenta with hydrops foetalis. J Pak Med Assoc. Jun. 2009;59(6):411-2. X-1. [pmid: 19534382].
2773 Sharan S, Swamy B, Taranath DA, et al. Port-wine vascular malformations and glaucoma risk in Sturge-Weber syndrome. J aapos. Aug. 2009;13(4):374-8. X-1. [pmid: 19683189].
2774 Sharma J, Hirata Y, Mosca RS. Surgical repair in neonatal life of cardiac haemangiomas diagnosed prenatally. Cardiol Young. Aug. 2009;19(4):403-6. X-1. [pmid: 19442320].
2775 Sidbury R. Hypothalamic-pituitary-adrenal axis suppression in systemic glucocorticoid-treated infantile hemangiomas: putting the risk into context. Arch Dermatol. Mar. 2009;145(3):319-20. X-3, X-4. [pmid: 19289767].
2776 Simic R, Vlahovic A, Subarevic V. Treatment of nasal hemangiomas. Int J Pediatr Otorhinolaryngol. Oct. 2009;73(10):1402-6. X-3, X-4. [pmid: 19656579].
2777 Sivasli E, Teksam O, Haliloglu M, et al. Hydrops fetalis associated with chorioangioma and thrombosis of umbilical vein. Turk J Pediatr. Sep–Oct. 2009;51(5):515-8. X-1. [pmid: 20112613].
2778 Song CE, Cho JH, Kim SY, et al. Endoscopic resection of haemangiomas in the sinonasal cavity. J Laryngol Otol. Aug. 2009;123(8):868-72. X-1. [pmid: 19275780].
2779 Stahr S, Green B, Woosely J, et al. An infant with an indurated patch on the leg. Pediatr Dermatol. May–Jun. 2009;26(3):347-8. X-1. [pmid: 19706103].
2780 Sugano H, Nakanishi H, Nakajima M, et al. Seizures continue even after prompt anti-epileptic drug medication in Sturge-Weber syndrome--study from prolonged video electrocoticography, a case report. Childs Nerv Syst. Jan. 2009;25(1):143-6. X-1. [pmid: 18769930].
2781 Summa A, Cerasti D, Crisi G, et al. Formation of intracerebral cavernous malformation after radiation treatment for medulloblastoma in a child. Neuroradiol J. April. 2009;22(2):198-203. X-1. [pmid: 24207041].
2782 Sung KS, Seo SW, Shon MS. The diagnostic value of needle biopsy for musculoskeletal lesions. Int Orthop. Dec. 2009;33(6):1701-6. X-1. [pmid: 19655141].
2783 Thapa R, Ghosh A, Dhar S. Infantile giant congenital melanocytic nevus: report of three unusual cases. Int J Dermatol. Nov. 2009;48(11):1209-12. X-1. [pmid: 20064178].
2784 Tierney E, Barker A, Ahdout J, et al. Photodynamic therapy for the treatment of cutaneous neoplasia, inflammatory disorders, and photoaging. Dermatol Surg. May. 2009;35(5):725-46. X-1. [pmid: 19309338].
2785 Turowski C, Feist H, Alzen G, et al. Conversion of a neonatal hepatic hemangioma to focal nodular hyperplasia. Pathol Int. Apr. 2009;59(4):251-4. X-2. [pmid: 19351369].
2786 Tyzio R, Khalilov I, Represa A, et al. Inhibitory actions of the gamma-aminobutyric acid in pediatric Sturge-Weber syndrome. Ann Neurol. Aug. 2009;66(2):209-18. X-1. [pmid: 19743469].
2787 Uchida Y, Takeda K, Tada K, et al. Multifocal haemangioma with extracutaneous involvement associated with hypergalactosaemia. Clin Exp Dermatol. Dec. 2009;34(8):e617-9. X-2. [pmid: 19489861].
2788 van der Meijs BB, Merks JH, de Haan TR, et al. Neonatal hepatic haemangioendothelioma: treatment options and dilemmas. Pediatr Radiol. Mar. 2009;39(3):277-81. X-1. [pmid: 19083217].
2789 Vartzelis G, Lancaster D, Fallon P. Intracranial hypertension in pediatric patients with acute lymphoblastic leukemia. Pediatr Blood Cancer. Mar. 2009;52(3):418-20. X-1. [pmid: 19058211].
2790 Vlahovic A, Simic R, Djokic D, et al. Diffuse neonatal hemangiomatosis treatment with cyclophosphamide: a case report. J Pediatr Hematol Oncol. Nov. 2009;31(11):858-60. X-2. [pmid: 19829152].
2791 Vural M, Acikalin MF, Adapinar B, et al. Congenital cavernous hemangioma of the calvaria. Case report. J Neurosurg Pediatr. Jan. 2009;3(1):41-5. X-1. [pmid: 19119903].
2792 Wakamoto H, Nakamura Y, Ebihara T, et al. Reversible coma associated with prolonged high-dose phenobarbital therapy in bilateral Sturge-Weber syndrome. J Child Neurol. Dec. 2009;24(12):1547-51. X-1. [pmid: 19671890].
2793 Wallen KE, Hadar EJ, Perry V, et al. Posterior fossa neoplasm and PHACES syndrome: a case report. J Pediatr Hematol Oncol. Mar. 2009;31(3):203-5. X-2. [pmid: 19262249].
2794 Wang J, Pei G, Yan J, et al. Coexistence of a giant splenic hemangioma and multiple hepatic hemangiomas mimicking a left adrenal neuroblastoma accompanied with multifocal hepatic metastases: pyrite answer. J Pediatr Hematol Oncol. Dec. 2009;31(12):983-4. X-1, X-2. [pmid: 19935098].
2795 Watanabe S, Takagi S, Sato Y, et al. Early surgical intervention for Japanese children with infantile hemangioma of the craniofacial region. J Craniofac Surg. Mar. 2009;20(Suppl 1):707-9. X-3, X-4. [pmid: 19218860].
2796 Wharton S, Soueid A, Nishikawa H, et al. Endangering cutaneous infantile hemangioma treated with vincristine: A case report. Eur J Plast Surg. June. 2009;32(3):157-61. PMID: X-2.
2797 Wiegand S, Eivazi B, Karger R, et al. Surgery in patients with vascular malformations of the head and neck: value of coagulation disorders. Phlebology. Feb. 2009;24(1):38-42. X-1. [pmid: 19155340].
2798 Wolfe SQ, Farhat H, Elhammady MS, et al. Transarterial embolization of a scalp hemangioma presenting with Kasabach-Merritt syndrome. J Neurosurg Pediatr. Nov. 2009;4(5):453-7. X-1. [pmid: 19877779].
2799 Wootton-Gorges SL. MR imaging of primary bone tumors and tumor-like conditions in children. Radiol Clin North Am. 2009;47(6):957-75. PMID: X-1, X-2.
2800 Wu G, Jones J, Sequeira IB, et al. Congenital pericardial hemangioma responding to high-dose corticosteroid therapy. Can J Cardiol. Apr. 2009;25(4):e139-40. X-1. [pmid: 19340361].
2801 Xia C, Zhang R, Mao Y, et al. Pediatric cavernous malformation in the central nervous system: report of 66 cases. Pediatr Neurosurg. 2009;45(2):105-13. X-1. [pmid: 19307744].
2802 Yamanaka G, Miyajima T, Kawashima H, et al. Effectiveness of intravenous immunoglobulin for epilepsy associated with Opitz trigonocephaly syndrome. Journal of Tokyo Medical University. January. 2009;67(1):71-4. X-1.
2803 Yamashita Y, Kumabe T, Higano S, et al. Minimum apparent diffusion coefficient is significantly correlated with cellularity in medulloblastomas. Neurol Res. Nov. 2009;31(9):940-6. X-1. [pmid: 19138469].
2804 Yang HY, Zheng LW, Yang HJ, et al. Long-pulsed Nd: YAG laser treatment in vascular lesions of the oral cavity. J Craniofac Surg. Jul. 2009;20(4):1214-7. X-3, X-4. [pmid: 19553836].
2805 Yang Y, Sun M, Cheng X, et al. Bleomycin A5 plus dexamethasone for control of growth in infantile parotid hemangiomas. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jul. 2009;108(1):62-9. X-3, X-4. [pmid: 19451005].
2806 Yaylali O, Kirac S, Acar M, et al. Diagnosis and follow-up of eyelid hemangioma with TC-99M RBC scintigraphy. Anatolian Journal of Clinical Investigation. 2009;3(3):185-9. X-2.
2807 Yoon HS, Lee JH, Moon HN, et al. Successful treatment of retroperitoneal infantile hemangioendothelioma with Kasabach-Merritt syndrome using steroid, alpha-interferon, and vincristine. J Pediatr Hematol Oncol. Dec. 2009;31(12):952-4. X-1. [pmid: 19875968].
2808 Yu H, Qin A. Could local delivery of bisphosphonates be a new therapeutic choice for hemangiomas?. Med Hypotheses. Oct. 2009;73(4):495-7. X-2. [pmid: 19625131].
2809 Zenzen W, Perez-Atayde AR, Elisofon SA, et al. Hepatic failure in a rapidly involuting congenital hemangioma of the liver: failure of embolotherapy. Pediatr Radiol. Oct. 2009;39(10):1118-23. X-1, X-2. [pmid: 19588131].
2810 Zhang W, He J, Wang J, et al. Ulcerated epithelioid hemangioendothelioma of the right armpit in childhood. J Pediatr Hematol Oncol. Aug. 2009;31(8):595-8. X-1. [pmid: 19636267].
2811 Zheng JW, Yang XJ, Zhou Q, et al. Short-term high-dose oral prednisone on alternate days: a more rational regime for infantile hemangiomas. Med Hypotheses. Mar. 2009;72(3):365. X-3, X-4. [pmid: 19041188].
2812 Ach T, Thiemeyer D, Hoeh AE, et al. Intravitreal bevacizumab for retinal capillary haemangioma: longterm results. Acta Ophthalmol. Jun. 2010;88(4):e137-8. X-1, X-2. [pmid: 19681788].
2813 Adeolu AA, Balogun JA, Adeleye AO, et al. Management of symptomatic vertebral haemangioma in a resource challenged environment. Childs Nerv Syst. Jul. 2010;26(7):979-82. X-1. [pmid: 20217099].
2814 Adi-Bensaid L, Ben-David A. Typical acquisition by atypical children: Initial consonant cluster acquisition by Israeli Hebrew-acquiring children with cochlear implants. Clin Linguist Phon. Oct. 2010;24(10):771-94. X-1. [pmid: 20831377].
2815 Agnese M, Cipolletta L, Bianco MA, et al. Blue rubber bleb nevus syndrome. Acta Paediatr. Apr. 2010;99(4):632-5. X-1. [pmid: 19958301].
2816 Aguilera D, Tomita T, Goldman S, et al. Incidental resolution of a radiation-induced cavernous hemangioma of the brain following the use of bevacizumab in a child with recurrent medulloblastoma. Pediatr Neurosurg. 2010;46(4):303-7. X-1. [pmid: 21196797].
2817 Ahsan U, Zaman T, Rashid T, et al. Cutaneous manifestations in 1000 Pakistani newborns. Journal of Pakistan Association of Dermatologists. October/December. 2010;20(4):199-205. X-1, X-2.
2818 Alkonyi B, Chugani HT, Behen M, et al. The role of the thalamus in neuro-cognitive dysfunction in early unilateral hemispheric injury: a multimodality imaging study of children with Sturge-Weber syndrome. Eur J Paediatr Neurol. Sep. 2010;14(5):425-33. X-1. [pmid: 20447845].
2819 Alomari AK, Alomari AI. Picture of the month: kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon. Arch Pediatr Adolesc Med. Apr. 2010;164(4):387. 8. X-1. [pmid: 20368493].
2820 Arneja JS, Chim H, Drolet BA, et al. The Cyrano nose: refinements in surgical technique and treatment approach to hemangiomas of the nasal tip. Plast Reconstr Surg. Oct. 2010;126(4):1291-9. X-3, X-4. [pmid: 20885249].
2821 Arneja JS, Pappas PN, Shwayder TA, et al. Management of complicated facial hemangiomas with beta-blocker (propranolol) therapy. Plast Reconstr Surg. Sep. 2010;126(3):889-95. X-3, X-4. [pmid: 20811222].
2822 Ashley RA, Figueroa TE. Gross hematuria in a 3-year-old girl caused by a large isolated bladder hemangioma. Urology. Oct. 2010;76(4):952-4. X-1, X-2. [pmid: 20627282].
2823 Avagyan AB, Sargsyan AL, Shahinyan AL. Neoplasms of the maxillo-facial region in children of various age groups. New Armenian Medical Journal. September. 2010;4(3):39. X-1, X-2.
2824 Avila ED, Molon RS, Conte Neto N, et al. Lip cavernous hemangioma in a young child. Braz Dent J. 2010;21(4):370-4. X-1. [pmid: 20976391].
2825 Barcot Z, Zupancic B. Pulsed dye laser treatment of vascular lesions in childhood. Acta Dermatovenerol Croat. 2010;18(3):201-8. X-1, X-2. [pmid: 20887704].
2826 Bauland CG, Smit JM, Bartelink LR, et al. Hemangioma in the newborn: increased incidence after chorionic villus sampling. Prenat Diagn. Oct. 2010;30(10):913-7. X-3. [pmid: 20824891].
2827 Bayliss SJ, Berk DR, Van Hare GF, et al. Re: Propranolol treatment for hemangioma of infancy: risks and recommendations. Pediatr Dermatol. May–Jun. 2010;27(3):319-20. author reply 20–1. X-3, X-4. [pmid: 20609165].
2828 Bechtel B, Hasson M. Depth of presentation in periocular hemangioma may be important clinical indicator. Ocular Surgery News. 2010;28(5):15. PMID: X-2.
2829 Benoit MM, Fink DS, Brigger MT, et al. Lobular capillary hemangioma of the nasal cavity in a five-year-old boy. Otolaryngol Head Neck Surg. Feb. 2010;142(2):290-1. X-2. [pmid: 20115993].
2830 Benoit MM, North PE, McKenna MJ, et al. Facial nerve hemangiomas: vascular tumors or malformations?. Otolaryngol Head Neck Surg. Jan. 2010;142(1):108-14. X-1. [pmid: 20096233].
2831 Berlucchi M, Pedruzzi B, Farina D. Radiology quiz case 2. Lobular capillary hemangioma (LCH). Arch Otolaryngol Head Neck Surg. Nov. 2010;136(11):1141. 3. X-1. [pmid: 21079173].
2832 Bessho K, Etani Y, Ichimori H, et al. Increased type 3 iodothyronine deiodinase activity in a regrown hepatic hemangioma with consumptive hypothyroidism. Eur J Pediatr. Feb. 2010;169(2):215-21. X-2. [pmid: 19548001].
2833 Bien E, Kazanowska B, Dantonello T, et al. Factors predicting survival in childhood malignant and intermediate vascular tumors : retrospective analysis of the Polish and German cooperative paediatric soft tissue sarcoma study groups and review of the literature. Ann Surg Oncol. Jul. 2010;17(7):1878-89. X-1. [pmid: 20333551].
2834 Blanchet C, Nicollas R, Bigorre M, et al. Management of infantile subglottic hemangioma: acebutolol or propranolol?. Int J Pediatr Otorhinolaryngol. Aug. 2010;74(8):959-61. X-3, X-4. [pmid: 20557953].
2835 Blatt J, Stavas J, Moats-Staats B, et al. Treatment of childhood kaposiform hemangioendothelioma with sirolimus. Pediatr Blood Cancer. Dec. 15. 2010;55(7):1396-8. X-1. [pmid: 20730884].
2836 Bonaccorsi-Riani E, Lerut JP. Liver transplantation and vascular tumours. Transpl Int. Jul. 2010;23(7):686-91. X-1. [pmid: 20492619].
2837 Bonifazi E, Acquafredda A, Milano A, et al. Severe hypoglycemia during successful treatment of diffuse hemangiomatosis with propranolol. Pediatr Dermatol. Mar–Apr. 2010;27(2):195-6. X-1. [pmid: 20537072].
2838 Bonifazi E, Mazzotta F, Colonna V, et al. Topical propranolol in the superficial infantile hemangioma of the skin. European Journal of Pediatric Dermatology. October–December. 2010;20(4):247-51. X-3, X-4.
2839 Boyce J, Dodge-Palomba S. Propranolol treatment in periocular pediatric patients with hemangiomas. Insight. Jan–Mar. 2010;35(1):22-3. X-1, X-2. [pmid: 20218265].
2840 Breugem SJM, Tytgat LGA, Schaap GR. Practical orthopaedic pathology. Epithelioid hemangioendothelioma of the upper thigh in a child. Curr Orthop Pract. 2010;21(5):518-20. PMID: X-1.
2841 Buckmiller LM, Munson PD, Dyamenahalli U, et al. Propranolol for infantile hemangiomas: early experience at a tertiary vascular anomalies center. Laryngoscope. Apr. 2010;120(4):676-81. X-4. [pmid: 20112413].
2842 Buckmiller LM, Richter GT, Suen JY. Diagnosis and management of hemangiomas and vascular malformations of the head and neck. Oral Dis. Jul. 2010;16(5):405-18. X-1, X-4. [pmid: 20233314].
2843 Canadas KT, Baum ED, Lee S, et al. Case report: Treatment failure using propanolol for treatment of focal subglottic hemangioma. Int J Pediatr Otorhinolaryngol. Aug. 2010;74(8):956-8. X-2. [pmid: 20846505].
2844 Cetinkaya S, Kendirci HN, Agladioglu SY, et al. Hypothyroidism due to hepatic hemangioendothelioma: a case report. J Clin Res Pediatr Endocrinol. 2010;2(3):126-30. X-1, X-2. [pmid: 21274327].
2845 Chan RV, Yonekawa Y, Lane AM, et al. Proton beam irradiation using a light-field technique for the treatment of choroidal hemangiomas. Ophthalmologica. 2010;224(4):209-16. X-1. [pmid: 19940527].
2846 Chang JJ, Lui TH. Intramuscular haemangioma of flexor digitorum brevis. Foot Ankle Surg. Jun. 2010;16(2):e8-11. X-1. [pmid: 20483132].
2847 Chang L, Mruthyunjaya P, Rodriguez-Rosa RE, et al. Postoperative cilioretinal artery occlusion in Sturge Weber-associated glaucoma. J aapos. Aug. 2010;14(4):358-60. X-1. [pmid: 20621528].
2848 Chee D, Phillips R, Maixner W, et al. The potential of capillary birthmarks as a significant marker for capillary malformation-arteriovenous malformation syndrome in children who had nontraumatic cerebral hemorrhage. J Pediatr Surg. Dec. 2010;45(12):2419-22. X-1. [pmid: 21129558].
2849 Cheng JF, Gole GA, Sullivan TJ. Propranolol in the management of periorbital infantile haemangioma. Clin Experiment Ophthalmol. Aug. 2010;38(6):547-53. X-4. [pmid: 20553300].
2850 Chik KK, Luk CK, Chan HB, et al. Use of propranolol in infantile haemangioma among Chinese children. Hong Kong Med J. Oct. 2010;16(5):341-6. X-4. [pmid: 20889997].
2851 Chukuezi AB, Nwosu JN. Pattern of nasal and paranasal sinus tumours in Owerri, Nigeria. Research Journal of Medical Sciences. 2010;4(1):11-4. X-1, X-2.
2852 Consales A, Piatelli G, Ravegnani M, et al. Treatment and outcome of children with cerebral cavernomas: a survey on 32 patients. Neurol Sci. Apr. 2010;31(2):117-23. X-1. [pmid: 19834644].
2853 Cornips EM, Vinken PA, Ter Laak-Poort M, et al. Intramedullary cavernoma presenting with hematomyelia: report of two girls. Childs Nerv Syst. Mar. 2010;26(3):391-8. X-1. [pmid: 19865818].
2854 Crouch M. As they grow: 0–12 months. Taking care of it! Parents. 2010;85(7):152. PMID: X-1.
2855 Cruz OA, Siegfried EC. Propranolol treatment for periocular capillary hemangiomas. J AAPOS. Jun. 2010;14(3):199-200. X-3, X-4. [pmid: 20603052].
2856 Cuccaro P, Rapacciuolo A, Vitiello R, et al. Infantile facial haemangioma and subclinical left ventricular dysfunction: the importance of z score in the diagnostic and therapeutic process. J Cardiovasc Med (Hagerstown). Sep. 2010;11(9):692-4. X-1, X-2. [pmid: 20404742].
2857 Da Ines D, Petitcolin V, Joubert-Zakeyh J, et al. Epithelioid hemangioendothelioma of the liver with metastatic coeliac lymph nodes in an 11-year-old boy. Pediatr Radiol. Jul. 2010;40(7):1293-6. X-1. [pmid: 20112013].
2858 Damm DD. Gingival mass. Congenital epulis. Gen Dent. Jul–Aug. 2010;58(4):344. 7. X-1. [pmid: 20591782].
2859 de Lange DH, Kreeft M, van Ramshorst GH, et al. Inguinal hernia surgery in The Netherlands: are patients treated according to the guidelines?. Hernia. Apr. 2010;14(2):143-8. X-1. [pmid: 19882299].
2860 de Mesquita CJ. About strawberry, crab claws, and the Sir James Black’s invention. Hypothesis: can we battle keloids with propranolol? Med Hypotheses. Feb. 2010;74(2):353-9. X-1, X-2. [pmid: 19758768].
2861 de Waele L, Freson K, Louwette S, et al. Severe gastrointestinal bleeding and thrombocytopenia in a child with an anti-GATA1 autoantibody. Pediatr Res. Mar. 2010;67(3):314-9. X-1. [pmid: 19924028].
2862 Denoyelle F, Garabedian EN. Propranolol may become first-line treatment in obstructive subglottic infantile hemangiomas. Otolaryngol Head Neck Surg. Mar. 2010;142(3):463-4. X-3, X-4. [pmid: 20172407].
2863 Duffy KJ, Runge-Samuelson C, Bayer ML, et al. Association of hearing loss with PHACE syndrome. Arch Dermatol. Dec. 2010;146(12):1391-6. X-3. [pmid: 20713775].
2864 Erbay A, Sarialioglu F, Malbora B, et al. Propranolol for infantile hemangiomas: a preliminary report on efficacy and safety in very low birth weight infants. Turk J Pediatr. Sep–Oct. 2010;52(5):450-6. X-4. [pmid: 21434528].
2865 Erol OO, Uysal OA, Agaoglu G. Percutaneous electrothrombosis: a minimally invasive technique for the treatment of deep hemangiomas. Aesthetic Plast Surg. Apr. 2010;34(2):214-7. X-1. [pmid: 19856020].
2866 Fahrtash F, McCahon E, Arbuckle S. Successful treatment of kaposiform hemangioendothelioma and tufted angioma with vincristine. J Pediatr Hematol Oncol. Aug. 2010;32(6):506-10. X-1. [pmid: 20523249].
2867 Fay A, Nguyen J, Jakobiec FA, et al. Propranolol for isolated orbital infantile hemangioma. Arch Ophthalmol. Feb. 2010;128(2):256-8. X-4. [pmid: 20142556].
2868 Feng ST, Chan T, Ching AS, et al. CT and MR imaging characteristics of infantile hepatic hemangioendothelioma. Eur J Radiol. Nov. 2010;76(2):e24-9. X-1. [pmid: 20576387].
2869 Fernandez-Pineda I, Lopez-Gutierrez JC, Ramirez G, et al. Vincristine-ticlopidine-aspirin: an effective therapy in children with Kasabach-Merritt phenomenon associated with vascular tumors. Pediatr Hematol Oncol. Nov. 2010;27(8):641-5. X-1. [pmid: 20863161].
2870 Frank RC, Cowan BJ, Harrop AR, et al. Visual development in infants: visual complications of periocular haemangiomas. J Plast Reconstr Aesthet Surg. Jan. 2010;63(1):1-8. X-3, X-4. [pmid: 19097831].
2871 Fronie A, Simionescu C, Vasca V, et al. Histopathological aspects of benign mesenchymal tumors located in “high risk areas” of the tongue. Rom J Morphol Embryol. 2010;51(1):97-104. X-1. [pmid: 20191127].
2872 Fusilli G, Merico G, Gurrado R, et al. Propranolol for infantile haemangiomas and neuroglycopenic seizures. Acta Paediatr. Dec. 2010;99(12):1756. X-2. [pmid: 20726852].
2873 Gaitanis JN, McMillan HJ, Wu A, et al. Electrophysiologic evidence for anterior horn cell disease in amyoplasia. Pediatr Neurol. Aug. 2010;43(2):142-7. X-1. [pmid: 20610128].
2874 Gajewska K, Herinckx A, Holoye A, et al. Antenatal embolization of a large chorioangioma by percutaneous Glubran 2 injection. Ultrasound Obstet Gynecol. Dec. 2010;36(6):773-5. X-1. [pmid: 20737457].
2875 Galeone M, Cervadoro E, Cervadoro G. The use of cryotherapy in the management of cutaneous hemangiomas: A review of 12 cases. Journal of Plastic Dermatology. 2010;6(1):17-9. PMID: X-4.
2876 Ganguly R, Mukherjee A. Infantile hemangioendothelioma: A case report and discussion. Pathol Res Pract. Jan. 15. 2010;206(1):53-8. X-1. [pmid: 19321270].
2877 Garcia-Carpintero ASM, Petcharunpaisan S, Ramalho JPRSNP, et al. Advances in pediatric orbital magnetic resonance imaging. Expert Review of Ophthalmology. August. 2010;5(4):483-500. PMID: X-1, X-2.
2878 Gelmetti C, Frasin A, Restano L. Innovative therapeutics in pediatric dermatology. Dermatol Clin. Jul. 2010;28(3):619-29. X-2. [pmid: 20510770].
2879 Gernon TJ, McHugh JB, Thorne MC. Pathology quiz case 2. Diagnosis: Nasal lobular capillary hemangioma (pyogenic granuloma). Arch Otolaryngol Head Neck Surg. Sep. 2. 2010;136(9):930-3. X-1. [pmid: 20855692].
2880 Giardini A, Gholam C, Khambadkone S, et al. Need for comprehensive vascular assessment before surgical repair of aortic coarctation in PHACES syndrome. Pediatr Cardiol. Feb. 2010;31(2):291-3. X-2. [pmid: 19936584].
2881 Giron-Vallejo O, Lopez-Gutierrez JC, Fernandez-Pineda I, et al. Dental caries as a side effect of infantile hemangioma treatment with propranolol solution. Pediatr Dermatol. Nov–Dec. 2010;27(6):672-3. X-2. [pmid: 21510011].
2882 Glade RS, Vinson K, Becton D, et al. Management of complicated hemangiomas with vincristine/vinblastine: Quantitative response to therapy using MRI. Int J Pediatr Otorhinolaryngol. Nov. 2010;74(11):1221-5. X-4. [pmid: 20884067].
2883 Gordillo G, Fang H, Park H, et al. Nox-4-dependent nuclear H2O2 drives DNA oxidation resulting in 8-OHdG as urinary biomarker and hemangioendothelioma formation. Antioxid Redox Signal. Apr. 15. 2010;12(8):933-43. X-1. [pmid: 19817625].
2884 Greenberger S, Adini I, Boscolo E, et al. Targeting NF-kappaB in infantile hemangioma-derived stem cells reduces VEGF-A expression. Angiogenesis. Dec. 2010;13(4):327-35. X-1. [pmid: 20872175].
2885 Greenberger S, Boscolo E, Adini I, et al. Corticosteroid suppression of VEGF-A in infantile hemangioma-derived stem cells. N Engl J Med. Mar. 18. 2010;362(11):1005-13. X-1. [pmid: 20237346].
2886 Greene AK. Systemic corticosteroid is effective and safe treatment for problematic infantile hemangioma. Pediatr Dermatol. May–Jun. 2010;27(3):322-3. X-1, X-2. [pmid: 20609168].
2887 Grover C, Arora P, Kedar A, et al. Combination of oral corticosteroids and polidocanol sclerotherapy in the management of infantile hemangiomas. Dermatol Surg. Dec. 2010;36(12):2030-6. X-4. [pmid: 21040124].
2888 Guiteau JJ, Cotton RT, Karpen SJ, et al. Pediatric liver transplantation for primary malignant liver tumors with a focus on hepatic epithelioid hemangioendothelioma: the UNOS experience. Pediatr Transplant. May. 2010;14(3):326-31. X-1. [pmid: 20051026].
2889 Guo S, Hunt MG, Superstein R. Treatment of infantile hemangiomas. J Pediatr Ophthalmol Strabismus. Jul–Aug. 2010;47(4):198-201. X-1, X-2. [pmid: 20635807].
2890 Guo S, Ni N. Topical treatment for capillary hemangioma of the eyelid using beta-blocker solution. Arch Ophthalmol. Feb. 2010;128(2):255-6. X-2, X-4. [pmid: 20142555].
2891 Haddy N, Dondon MG, Paoletti C, et al. Breast cancer following radiotherapy for a hemangioma during childhood. Cancer Causes Control. Nov. 2010;21(11):1807-16. X-1. [pmid: 20607383].
2892 Haggstrom AN, Garzon MC, Baselga E, et al. Risk for PHACE syndrome in infants with large facial hemangiomas. Pediatrics. Aug. 2010;126(2):e418-26. X-3, X-4. [pmid: 20643720].
2893 Haider KM, Plager DA, Neely DE, et al. Outpatient treatment of periocular infantile hemangiomas with oral propranolol. J aapos. Jun. 2010;14(3):251-6. X-4. [pmid: 20603059].
2894 Hassanein AH, Fishman SJ, Mulliken JB, et al. Metastatic neuroblastoma mimicking infantile hemangioma. J Pediatr Surg. Oct. 2010;45(10):2045-9. X-2. [pmid: 20920727].
2895 Hassell LA, Roanh le D. Potential response to curcumin in infantile hemangioendothelioma of the liver. Pediatr Blood Cancer. Aug. 2010;55(2):377-9. X-1. [pmid: 20582974].
2896 Ho KM. Research in infantile haemangioma: local perspectives. Hong Kong Med J. Oct. 2010;16(5):332-3. X-3, X-4. [pmid: 20889995].
2897 Holland KE, Frieden IJ, Frommelt PC, et al. Hypoglycemia in children taking propranolol for the treatment of infantile hemangioma. Arch Dermatol. Jul. 2010;146(7):775-8. X-3, X-4. [pmid: 20644039].
2898 Holmes WJ, Mishra A, Gorst C, et al. Propranolol as first-line treatment for infantile hemangiomas. Plast Reconstr Surg. Jan. 2010;125(1):420-1. X-3, X-4. [pmid: 20048640].
2899 Hong B, Hermann EJ, Klein R, et al. Surgical resection of osteolytic calvarial lesions: clinicopathological features. Clin Neurol Neurosurg. Dec. 2010;112(10):865-9. X-1. [pmid: 20685034].
2900 Hong JY, Kim WO, Koo BN, et al. The relative position of ilioinguinal and iliohypogastric nerves in different age groups of pediatric patients. Acta Anaesthesiol Scand. May. 2010;54(5):566-70. X-1. [pmid: 20236097].
2901 Huang AP, Chen JS, Yang CC, et al. Brain stem cavernous malformations. J Clin Neurosci. Jan. 2010;17(1):74-9. X-1. [pmid: 20005720].
2902 Hunzeker CM, Geronemus RG. Treatment of superficial infantile hemangiomas of the eyelid using the 595-nm pulsed dye laser. Dermatol Surg. May. 2010;36(5):590-7. X-4. [pmid: 20384759].
2903 Iacobas I, Burrows PE, Frieden IJ, et al. LUMBAR: association between cutaneous infantile hemangiomas of the lower body and regional congenital anomalies. J Pediatr. Nov. 2010;157(5):795-801.e1. 7. X-3, X-4. [pmid: 20598318].
2904 Indolfi P, Donofrio V, Fusco C, et al. Kaposiform hemangioendothelioma of the kidney: an unusual presentation of a rare vascular neoplasm. J Pediatr Hematol Oncol. Jul. 2010;32(5):e195-8. X-1. [pmid: 20588198].
2905 Irving ND, Lim JH, Cohen B, et al. Sturge-Weber syndrome: ear, nose, and throat issues and neurologic status. Pediatr Neurol. Oct. 2010;43(4):241-4. X-1. [pmid: 20837301].
2906 Jadhav VM, Tolat SN. Dramatic response of propranolol in hemangioma: report of two cases. Indian J Dermatol Venereol Leprol. Nov–Dec. 2010;76(6):691-4. X-2. [pmid: 21079315].
2907 Jinnin M, Ishihara T, Boye E, et al. Recent progress in studies of infantile hemangioma. J Dermatol. Nov. 2010;37(11):939-55. X-2. [pmid: 21039783].
2908 Kao YC, Lin MI. Intramuscular hemangioma of the temporalis muscle with incidental finding of bilateral symmetric calcification of the basal ganglia: a case report. Pediatr Neonatol. Oct. 2010;51(5):296-9. X-1. [pmid: 20951361].
2909 Kattepura S, Kini U, Das K. Retroauricular intravascular lobular capillary haemangioma in a child. Int J Pediatr Otorhinolaryngol Extra. January. 2010;5(1):13-5. X-1, X-2.
2910 Kazim SF, Bhatti, Enam SA. Intracranial cavernous angiomas. J Coll Physicians Surg Pak. Nov. 2010;20(11):738-43. X-1. [pmid: 21078247].
2911 Kelly ME, Juern AM, Grossman WJ, et al. Immunosuppressive effects in infants treated with corticosteroids for infantile hemangiomas. Arch Dermatol. Jul. 2010;146(7):767-74. X-4. [pmid: 20479291].
2912 Khandpur S, Sharma VK. Utility of intralesional sclerotherapy with 3% sodium tetradecyl sulphate in cutaneous vascular malformations. Dermatol Surg. Mar. 2010;36(3):340-6. X-1. [pmid: 20100267].
2913 Killory BD, Chang SW, Wait SD, et al. Use of flexible hollow-core CO2 laser in microsurgical resection of CNS lesions: early surgical experience. Neurosurgery. Jun. 2010;66(6):1187-92. X-1. [pmid: 20495434].
2914 Kim TJ, Lee YS, Song YS, et al. Infantile hemangioendothelioma with elevated serum alpha fetoprotein: report of 2 cases with immunohistochemical analysis. Hum Pathol. May. 2010;41(5):763-7. X-1, X-2. [pmid: 20153513].
2915 Kiymaz N, Yilmaz N, Ozen S, et al. Cavernous hemangioma presenting as a giant cervical mass: a case report. Turk Neurosurg. Jan. 2010;20(1):69-72. X-1, X-2. [pmid: 20066626].
2916 Kossoff EH, Borsage JL, Comi AM. A pilot study of the modified Atkins diet for Sturge-Weber syndrome. Epilepsy Res. Dec. 2010;92(2–3):240-3. X-1. [pmid: 20934305].
2917 Kostrzewa JP, Bowman MK, Woolley AL. Middle ear hemangioma: A novel treatment for a rare problem. Int J Pediatr Otorhinolaryngol Extra. March. 2010;5(2):50-2. X-2.
2918 Kumar PV, Salimi A, Ahmadi J. Infantile hepatic hemangioendothelioma: report of a case with fine needle aspiration findings. Acta Cytol. Sep–Oct. 2010;54(5 Suppl):807-10. X-2. [pmid: 21053545].
2919 Kumar V, Murali M. Large cavernous hemangioma. Indian Pediatr. Jun. 2010;47(6):521-2. X-1. [pmid: 20622281].
2920 Lazaridou E, Giannopoulou C, Apalla Z, et al. Calcineurin inhibitors in the treatment of cutaneous infantile haemangiomas. J Eur Acad Dermatol Venereol. May. 2010;24(5):614-5. X-3, X-4. [pmid: 19840202].
2921 Leboulanger N, Fayoux P, Teissier N, et al. Propranolol in the therapeutic strategy of infantile laryngotracheal hemangioma: A preliminary retrospective study of French experience. Int J Pediatr Otorhinolaryngol. Nov. 2010;74(11):1254-7. X-4. [pmid: 20800295].
2922 Lee IJ, Kim CS, Seo SJ, et al. A case of non-involuting congenital haemangioma with multiple epidermal cysts. J Plast Reconstr Aesthet Surg. Jan. 2010;63(1):e19-22. X-1. [pmid: 19345168].
2923 Levitin GM, Thompson SH, Berenstein A, et al. Surgical treatment of buccofacial region vascular anomalies using an intraoral buccomucosal flap procedure. Arch Otolaryngol Head Neck Surg. Feb. 2010;136(2):134-7. X-1. [pmid: 20157057].
2924 Li YC, McCahon E, Rowe NA, et al. Successful treatment of infantile haemangiomas of the orbit with propranolol. Clin Experiment Ophthalmol. Aug. 2010;38(6):554-9. X-4. [pmid: 20491798].
2925 Listernick R. A 1-day-old boy with a liver mass. Pediatr Ann. Jun. 2010;39(6):332-5. X-1. [pmid: 20669886].
2926 Londero M, Pastore S, Zanazzo GA, et al. A child with pain after mild trauma. J Pediatr. Oct. 2010;157(4):693. X-1. [pmid: 20553843].
2927 Lunsford LD, Khan AA, Niranjan A, et al. Stereotactic radiosurgery for symptomatic solitary cerebral cavernous malformations considered high risk for resection. J Neurosurg. Jul. 2010;113(1):23-9. X-1. [pmid: 20170299].
2928 Macedo A Jr, Ottoni SL, Barroso U Jr, et al. Bladder hemangiomas and Proteus syndrome: a rare clinical association. J Pediatr Urol. Aug. 2010;6(4):429-31. X-1, X-2. [pmid: 20044313].
2929 Mackley AB, Locke RG, Spear ML, et al. Forgotten parent: NICU paternal emotional response. Adv Neonatal Care. Aug. 2010;10(4):200-3. X-1. [pmid: 20697219].
2930 Madhusudhan KS, Srivastava DN, Gamanagatti S. Multifocal epithelioid hemangioendothelioma presenting with hemoptysis. Indian J Pediatr. Jun. 2010;77(6):699-700. X-1. [pmid: 20532691].
2931 Maguiness SM, Hoffman WY, McCalmont TH, et al. Early white discoloration of infantile hemangioma: a sign of impending ulceration. Arch Dermatol. Nov. 2010;146(11):1235-9. X-3, X-4. [pmid: 21079059].
2932 Mandrekas AD, Zambacos GJ, Hapsas DA. Pediatric nasal reconstruction for nasal tip hemangioma. Plast Reconstr Surg. May. 2010;125(5):1571-2. author reply 3. X-3, X-4. [pmid: 20440183].
2933 Manobianca G, Zoccolella S, Petruzzellis A, et al. The incidence of major stroke subtypes in southern Italy: a population-based study. Eur J Neurol. Sep. 2010;17(9):1148-55. X-1. [pmid: 20298424].
2934 Marsciani A, Pericoli R, Alaggio R, et al. Massive response of severe infantile hepatic hemangioma to propanolol. Pediatr Blood Cancer. Jan. 2010;54(1):176. X-3, X-4. [pmid: 19743301].
2935 Maton B, Krsek P, Jayakar P, et al. Medically intractable epilepsy in Sturge-Weber syndrome is associated with cortical malformation: implications for surgical therapy. Epilepsia. Feb. 2010;51(2):257-67. X-1. [pmid: 19780796].
2936 Maturo S, Hartnick C. Initial experience using propranolol as the sole treatment for infantile airway hemangiomas. Int J Pediatr Otorhinolaryngol. Mar. 2010;74(3):323-5. X-2. [pmid: 20071038].
2937 Mazereeuw-Hautier J, Hoeger PH, Benlahrech S, et al. Efficacy of propranolol in hepatic infantile hemangiomas with diffuse neonatal hemangiomatosis. J Pediatr. Aug. 2010;157(2):340-2. X-4. [pmid: 20488455].
2938 Mazzotta F, Bonifazi E. Eruptive angioma with satellitosis. European Journal of Pediatric Dermatology. July–September. 2010;20(3):207. X-1.
2939 McHoney M. Early human development: neonatal tumours: vascular tumours. Early Hum Dev. Oct. 2010;86(10):613-8. X-2. [pmid: 20850940].
2940 Menzler K, Chen X, Thiel P, et al. Epileptogenicity of cavernomas depends on (archi-) cortical localization. Neurosurgery. Oct. 2010;67(4):918-24. X-1. [pmid: 20881556].
2941 Meyer L, Graffstaedt H, Giest H, et al. Effectiveness of propranolol in a newborn with liver hemangiomatosis. Eur J Pediatr Surg. Nov. 2010;20(6):414-5. X-1. [pmid: 20628969].
2942 Milet A, Al Dhaybi R, Superstein R, Powell J, Hamel P, Chevrette L, Ospina LH. Propranolol for the treatment of periocular capillary hemangiomas. J APPOS. 2010;14(1):e5. PMID: X-4.
2943 Mishra A, Holmes WJ, Gorst C, et al. Role of propranolol in the management of periocular hemangiomas. Plast Reconstr Surg. Aug. 2010;126(2):671. X-3, X-4. [pmid: 20679854].
2944 Mistry N, Tzifa K. Use of propranolol to treat multicentric airway haemangioma. J Laryngol Otol. Dec. 2010;124(12):1329-32. X-2. [pmid: 20370949].
2945 Mitsionis GI, Pakos EE, Kosta P, et al. Intramuscular hemangioma of the foot: A case report and review of the literature. Foot Ankle Surg. Jun. 2010;16(2):e27-9. X-1, X-2. [pmid: 20483123].
2946 Miyoshi Y, Yasuhara T, Omori M, et al. Infantile cervical intramedullary cavernous angioma manifesting as hematomyelia. Case report. Neurol Med Chir (Tokyo). 2010;50(8):677-82. X-1. [pmid: 20805654].
2947 Moschovi M, Alexiou GA, Stefanaki K, et al. Propranolol treatment for a giant infantile brain cavernoma. J Child Neurol. May. 2010;25(5):653-5. X-1. [pmid: 20413807].
2948 Mousa W, Kues K, Haas E, et al. Successful treatment of a large hemangioma with propranolol. J Dtsch Dermatol Ges. Mar. 2010;8(3):184-6. X-1, X-2. [pmid: 19788583].
2949 Muthamilselvan S, Vinoth PN, Vilvanathan V, et al. Hepatic haemangioma of infancy: role of propranolol. Ann Trop Paediatr. 2010;30(4):335-8. X-2. [pmid: 21118629].
2950 Nagy G, Razak A, Rowe JG, et al. Stereotactic radiosurgery for deep-seated cavernous malformations: a move toward more active, early intervention. Clinical article. J Neurosurg. Oct. 2010;113(4):691-9. X-1. [pmid: 20433275].
2951 Naouri M, Schill T, Maruani A, et al. Successful treatment of ulcerated haemangioma with propranolol. J Eur Acad Dermatol Venereol. Sep. 2010;24(9):1109-12. X-3, X-4. [pmid: 20337809].
2952 Nishino K, Ito Y, Sorimachi T, et al. Sturge-Weber syndrome associated with arteriovenous malformation in a patient presenting with progressive brain edema and cyst formation. J Neurosurg Pediatr. May. 2010;5(5):529-34. X-1. [pmid: 20433269].
2953 Nonogaki S, Campos HGA, Butugan O, et al. Markers of vascular differentiation, proliferation and tissue remodeling in juvenile nasopharyngeal angiofibromas. Exp Ther Med. November. 2010;1(6):921-6. X-1. [pmid: 22993619].
2954 Ohue S, Fukushima T, Kumon Y, et al. Surgical management of brainstem cavernomas: selection of approaches and microsurgical techniques. Neurosurg Rev. Jul. 2010;33(3):315-22. discussion 23–4. X-1. [pmid: 20358241].
2955 Osio A, Fraitag S, Hadj-Rabia S, et al. Clinical spectrum of tufted angiomas in childhood: a report of 13 cases and a review of the literature. Arch Dermatol. Jul. 2010;146(7):758-63. X-1. [pmid: 20644037].
2956 Otte JB, Meyers R. PLUTO first report. Pediatr Transplant. Nov. 2010;14(7):830-5. X-1. [pmid: 20946516].
2957 Otte JB, Zimmerman A. The role of liver transplantation for pediatric epithelioid hemangioendothelioma. Pediatr Transplant. May. 2010;14(3):295-7. X-1. [pmid: 20331517].
2958 Pandya R, Tummala V. Giant infantile pulmonary hemangioma. Pediatr Radiol. Dec. 2010;40(Suppl 1):S63-7. X-1, X-2. [pmid: 20461368].
2959 Paramanathan N, Ooi KG, Reeves D, et al. Synchronous radiation-induced orbital meningioma and multiple cavernomas. Clin Experiment Ophthalmol. May. 2010;38(4):414-7. X-1. [pmid: 20491803].
2960 Pascual-Castroviejo I, Pascual-Pascual SI, Velazquez-Fragua R, et al. Association of cutaneous red-to-purple hemangiomas with leptomeningeal hemangiomas. a clinical study of two patients. Neuropediatrics. Feb. 2010;41(1):7-11. X-3, X-4. [pmid: 20571984].
2961 Patil SJ, Moray AA, Kiran VS, et al. PHACE/S syndrome: a syndromic infantile segmental hemangioma. Indian J Pediatr. Aug. 2010;77(8):911-3. X-2. [pmid: 20953914].
2962 Pavlakovic H, Kietz S, Lauerer P, et al. Hyperkalemia complicating propranolol treatment of an infantile hemangioma. Pediatrics. Dec. 2010;126(6):e1589-93. X-2. [pmid: 21115582].
2963 Perez-Valle S, Peinador M, Herraiz P, et al. Vincristine, an efficacious alternative for diffuse neonatal haemangiomatosis. Acta Paediatr. Feb. 2010;99(2):311-5. X-1, X-2. [pmid: 20353500].
2964 Peters C, Langham S, Mullis PE, et al. Use of combined liothyronine and thyroxine therapy for consumptive hypothyroidism associated with hepatic haemangiomas in infancy. Horm Res Paediatr. 2010;74(2):149-52. X-1, X-2. [pmid: 20516650].
2965 Petersen TA, Morrison LA, Schrader RM, et al. Familial versus sporadic cavernous malformations: differences in developmental venous anomaly association and lesion phenotype. AJNR Am J Neuroradiol. Feb. 2010;31(2):377-82. X-1. [pmid: 19833796].
2966 Peterson JD, Friedman PM. Letter regarding early laser treatment of periorbital infantile hemangiomas may work, but is it really the best treatment option?. Dermatol Surg. Sep. 2010;36(9):1497-8. X-3, X-4. [pmid: 21413192].
2967 Pope E, Chakkittakandiyil A. Topical timolol gel for infantile hemangiomas: a pilot study. Arch Dermatol. May. 2010;146(5):564-5. X-4. [pmid: 20479314].
2968 Poulsen ML, Budtz-Jorgensen E, Bisgaard ML. Surveillance in von Hippel-Lindau disease (vHL). Clin Genet. Jan. 2010;77(1):49-59. X-1. [pmid: 19863552].
2969 Provenzale JM. Imaging findings of structural causes of epilepsy in children: a guide for the radiologist in the emergency room. Emerg Radiol. Nov. 2010;17(6):479-86. X-1. [pmid: 20596745].
2970 Pruksachatkun C. Report of the 11th World Congress of Pediatric Dermatology in Bangkok, Thailand. Pediatr Dermatol. May–Jun. 2010;27(3):223-5. X-2. [pmid: 20609139].
2971 Ramasubramanian A, Shields CL, Harmon SA, et al. Autofluorescence of choroidal hemangioma in 34 consecutive eyes. Retina. Jan. 2010;30(1):16-22. X-1. [pmid: 19952988].
2972 Rao AB, Pence J, Mirkin DL. Diffuse infantile hemangiomatosis of the ileum presenting with multiple perforations: a case report and review of the literature. J Pediatr Surg. Sep. 2010;45(9):1890-2. X-1. [pmid: 20850639].
2973 Rasalkar DD, Chu WC, Cheng FW, et al. An institutional review of paediatric haemangiomas: prevalence, imaging features, and outcomes. Hong Kong Med J. Oct. 2010;16(5):334-40. X-4. [pmid: 20889996].
2974 Rempel GR, Borton BL. Is aspiration during swalowing more common in children with indigenous herita ge?. Paediatr Child Health. May–June. 2010;15:65A. X-1.
2975 Rimella Le Huu A, North PE, Hohl D, et al. Expression of prox-1, a lymphatic endothelial transcription factor, in kaposiform hemangioendo thelioma and tufted hemangioma. European Journal of Pediatric Dermatology. January–March. 2010;20(1):47. PMID: X-1.
2976 Rosbe KW, Suh KY, Meyer AK, et al. Propranolol in the management of airway infantile hemangiomas. Arch Otolaryngol Head Neck Surg. Jul. 2010;136(7):658-65. X-3, X-4. [pmid: 20644059].
2977 Saafan AM, Salah MM. Using pulsed dual-wavelength 595 and 1064 nm is more effective in the management of hemangiomas. J Drugs Dermatol. Apr. 2010;9(4):310-4. X-3, X-4. [pmid: 20514786].
2978 Sachdeva R, Dadgostar H, Kaiser PK, et al. Verteporfin photodynamic therapy of six eyes with retinal capillary haemangioma. Acta Ophthalmol. Dec. 2010;88(8):e334-40. X-1. [pmid: 20946329].
2979 Salunke P, Sinha R, Khandelwal NK, et al. Primary intraosseus cavernous hemangioma of the skull base. Br J Neurosurg. Feb. 2010;24(1):84-5. X-1. [pmid: 20158361].
2980 Sarialioglu F, Erbay A, Demir S. Response of infantile hepatic hemangioma to propranolol resistant to high-dose methylprednisolone and interferon-alpha therapy. Pediatr Blood Cancer. Dec. 15. 2010;55(7):1433-4. X-2. [pmid: 20981697].
2981 Sarikaya-Seiwert S, Gierga K, Wessalowski R, et al. Solitary spinal epidural cavernous angiomas in children presenting with acute neurological symptoms caused by hemorrhage. J Neurosurg Pediatr. Jan. 2010;5(1):89-93. X-1. [pmid: 20043742].
2982 Sato Y, Nozawa S, Yoshiike M, et al. Xenografting of testicular tissue from an infant human donor results in accelerated testicular maturation. Hum Reprod. May. 2010;25(5):1113-22. X-1. [pmid: 20172867].
2983 Schupp CJ, Holland-Cunz S, Schenk JP, et al. Multiple hemangiomas and hemangiomatosis--risk factors and outcome over an eight year period. Eur J Pediatr Surg. Nov. 2010;20(6):379-81. X-3. [pmid: 20665431].
2984 Schwanke J. Birthmarks in newborns can signal later problems. Contemp Pediatr. 2010;27(7):24-6. PMID: X-2.
2985 Senchak AJ, Dann M, Cable B, et al. Successful treatment of cutaneous hemangioma of infancy with topical imiquimod 5%: a report of 3 cases. Ear Nose Throat J. Mar. 2010;89(3):E21-5. X-3, X-4. [pmid: 20229466].
2986 Serra AM, Soares FM, Cunha Junior AG, et al. Therapeutic management of skin hemangiomas in children. An Bras Dermatol. May–Jun. 2010;85(3):307-17. X-3, X-4. [pmid: 20676463].
2987 Sharma S, Sankhyan N, Gulati S, et al. Intracranial cavernomatous hemangiomas as a cause of childhood temporal lobe epilepsy. J Child Neurol. Nov. 2010;25(11):1423-4. X-1. [pmid: 20519670].
2988 Shen W, Cui J, Chen J, et al. Kasabach-Merritt syndrome: case reports of successful treatment with partial tumor resection and vincristine chemotherapy. Ann Plast Surg. Sep. 2010;65(3):361-3. X-1. [pmid: 20733375].
2989 Shen W, Cui J, Chen J, et al. Kasabach-Merritt syndrome with partial resection of tumor, reduction of tumor blood, and vincristine chemotherapy. J Craniofac Surg. Jan. 2010;21(1):215-6. X-1. [pmid: 20098187].
2990 Sigamani E, Iyer VK, Agarwala S. Fine needle aspiration cytology of infantile haemangioendothelioma of the liver: a report of two cases. Cytopathology. Dec. 2010;21(6):398-402. X-1. [pmid: 20337692].
2991 Sinno H, Thibaudeau S, Coughlin R, et al. Management of infantile parotid gland hemangiomas: a 40-year experience. Plast Reconstr Surg. Jan. 2010;125(1):265-73. X-2, X-4. [pmid: 19910858].
2992 Snyder H, Pope AW. Psychosocial adjustment in children and adolescents with a craniofacial anomaly: diagnosis-specific patterns. Cleft Palate Craniofac J. May. 2010;47(3):264-72. X-1, X-3. [pmid: 19860517].
2993 Sorrell J, Carmichael C, Chamlin S. Oral sucrose for pain relief in young infants with hemangiomas treated with intralesional steroids. Pediatr Dermatol. Mar–Apr. 2010;27(2):154-5. X-1. [pmid: 20537065].
2994 Spinks J. A clue on the face. BMJ Case Rep. 2010;2010. X-2. [pmid: 22736736].
2995 Storch CH, Hoeger PH. Propranolol for infantile haemangiomas: insights into the molecular mechanisms of action. Br J Dermatol. Aug. 2010;163(2):269-74. X-1, X-2. [pmid: 20456345].
2996 Suh KY, Frieden IJ. Infantile hemangiomas with minimal or arrested growth: a retrospective case series. Arch Dermatol. Sep. 2010;146(9):971-6. X-3, X-4. [pmid: 20855695].
2997 Sukop A, Malis J, Tvrdek M, et al. Diagnostic dilemmas of infantile sarcoma of the forearm. Acta Chir Plast. 2010;52(1):19-21. X-1. [pmid: 21110498].
2998 Suskauer SJ, Trovato MK, Zabel TA, et al. Physiatric findings in individuals with Sturge-Weber syndrome. Am J Phys Med Rehabil. Apr. 2010;89(4):323-30. X-1. [pmid: 20068437].
2999 Suurmeijer AJ. Papillary hemangiomas and glomeruloid hemangiomas are distinct clinicopathological entities. Int J Surg Pathol. Feb. 2010;18(1):48-54. X-1. [pmid: 18805868].
3000 Taban M, Goldberg RA. Propranolol for orbital hemangioma. Ophthalmology. Jan. 2010;117(1):195-e4. X-2, X-4. [pmid: 20114117].
3001 Tabatabaii SA, Khanbabaii G, Khatami AR, et al. Characteristic and follow-up of subglottic hemangiomas in Iranian children. J Res Med Sci. 2010;15(4). X-2.
3002 Tamai N, Hashii Y, Osuga K, et al. Kaposiform hemangioendothelioma arising in the deltoid muscle without the Kasabach-Merritt phenomenon. Skeletal Radiol. Oct. 2010;39(10):1043-6. X-1. [pmid: 20309545].
3003 Tanwar M, Sihota R, Dada T, et al. Sturge-Weber syndrome with congenital glaucoma and cytochrome P450 (CYP1B1) gene mutations. J Glaucoma. Aug. 2010;19(6):398-404. X-1. [pmid: 20051892].
3004 Terui K, Nakatani Y, Kambe M, et al. Kaposiform hemangioendothelioma of the choledochus. J Pediatr Surg. Sep. 2010;45(9):1887-9. X-1. [pmid: 20850638].
3005 Thiex R, Mulliken JB, Revencu N, et al. A novel association between RASA1 mutations and spinal arteriovenous anomalies. AJNR Am J Neuroradiol. Apr. 2010;31(4):775-9. X-1. [pmid: 20007727].
3006 Torre M, Yankovic F, Herrera O, et al. Granular cell tumor mimicking a subglottic hemangioma. J Pediatr Surg. Dec. 2010;45(12):e9-11. X-1, X-2. [pmid: 21129532].
3007 Truong MT, Chang KW, Berk DR, et al. Propranolol for the treatment of a life-threatening subglottic and mediastinal infantile hemangioma. J Pediatr. Feb. 2010;156(2):335-8. X-2. [pmid: 20105647].
3008 Truong MT, Perkins JA, Messner AH, et al. Propranolol for the treatment of airway hemangiomas: a case series and treatment algorithm. Int J Pediatr Otorhinolaryngol. Sep. 2010;74(9):1043-8. X-4. [pmid: 20674045].
3009 Turin E, Grados MA, Tierney E, et al. Behavioral and psychiatric features of Sturge-Weber syndrome. J Nerv Ment Dis. Dec. 2010;198(12):905-13. X-1. [pmid: 21135644].
3010 Ulku R, Onat S, Avci A, et al. Resection of intercostal hemangioma with involved chest wall and ribs: in an 11-year-old girl. Tex Heart Inst J. 2010;37(4):486-9. X-1. [pmid: 20844630].
3011 Utsumi K, Ogasawara N, Sasaki M, et al. Intussusception in a child caused by capillary hemangioma of the colon. Clin J Gastroenterol. April. 2010;3(2):83-7. X-1, X-2. [pmid: 26190000].
3012 Vanlander A, Decaluwe W, Vandelanotte M, et al. Propranolol as a novel treatment for congenital visceral haemangioma. Neonatology. 2010;98(3):229-31. X-1, X-2. [pmid: 20389127].
3013 Veening MA, Verbeke JI, Witbreuk MM, et al. Kaposiform (spindle cell) hemangioendotelioma in a child with an unusual presentation. J Pediatr Hematol Oncol. Apr. 2010;32(3):240-2. X-1. [pmid: 20387265].
3014 Waliuddin A, Jamjoom AA, Kutub H. A unique case of an epidural cavernous haemangioma presenting with lumbar radiculopathy in a child. Pan Arab Journal of Neurosurgery. April. 2010;14(1):75-8+135. PMID: X-1.
3015 Walter C, Mbebe T, Caragounis E, et al. Blue rubber bleb naevus syndrome: a rare cause of gastrointestinal bleeding in an African child. Afr J Paediatr Surg. Sep–Dec. 2010;7(3):206-8. X-1. [pmid: 20859034].
3016 Wang NK, Hung KL, Liao HC, et al. A patient with PHACE syndrome with marked ipsilateral cerebral atrophy. Pediatr Neonatol. Apr. 2010;51(2):130-4. X-1, X-2. [pmid: 20417465].
3017 Warren SM, Zide BM. Reconstruction of temporal and suprabrow defects. Ann Plast Surg. Mar. 2010;64(3):298-301. X-1. [pmid: 20179477].
3018 Watanabe M, Abe M, Ogawa S. A case of neonatal cardiac tamponade associated with benign hemangioma. J Nippon Med Sch. Feb. 2010;77(1):2-3. X-1, X-2. [pmid: 20154451].
3019 Watanabe S, Takahashi T, Fujibuchi T, et al. Synovial hemangioma of the knee joint in a 3-year-old girl. J Pediatr Orthop B. Nov. 2010;19(6):515-20. X-1, X-2. [pmid: 20697297].
3020 Wiegand S, Zimmermann AP, Eivazi B, et al. Analysis of clinically suspected orbital cavernomas. Br J Ophthalmol. Dec. 2010;94(12):1653-6. X-1. [pmid: 20494913].
3021 Wiygul JB, Palmer L. Isolated hemangioma causing gross painless hematuria in an adolescent male. Urology. Aug. 2010;76(2):463-4. X-1, X-2. [pmid: 20163837].
3022 Wortsman X, Wortsman J, Arellano J, et al. Pilomatrixomas presenting as vascular tumors on color Doppler ultrasound. J Pediatr Surg. Oct. 2010;45(10):2094-8. X-1. [pmid: 20920738].
3023 Xie CM, Kubba H. Parotidectomy in children: indications and complications. J Laryngol Otol. Dec. 2010;124(12):1289-93. X-3, X-4. [pmid: 20519039].
3024 Xu QW, Xu R, Du ZY, et al. Surgical treatment for hemangioblastomas in the medulla oblongata. Acta Neurochir (Wien). Aug. 2010;152(8):1331-5. discussion 5. X-1. [pmid: 20419458].
3025 Yadav N, Prabhakar H, Singh GP, et al. Acute hemodynamic instability during alcohol ablation of symptomatic vertebral hemangioma: a prospective study. J Clin Neurosci. Jun. 2010;17(6):810-1. X-1. [pmid: 20400319].
3026 Yang CY, Hsu JF, Lin KL, et al. An extra-axial hemangioma mimicking a large prenatal brain tumor. Brain Dev. Nov. 2010;32(10):883-6. X-1, X-2. [pmid: 20347240].
3027 Yu DC, Grabowski MJ, Kozakewich HP, et al. Primary lung tumors in children and adolescents: a 90-year experience. J Pediatr Surg. Jun. 2010;45(6):1090-5. X-1. [pmid: 20620301].
3028 Zanardini C, Papageorghiou A, Bhide A, et al. Giant placental chorioangioma: natural history and pregnancy outcome. Ultrasound Obstet Gynecol. Mar. 2010;35(3):332-6. X-1. [pmid: 19859897].
3029 Zhang Z, Chen HJ, Yang WJ, et al. Infantile hepatic hemangioendothelioma: a clinicopathologic study in a Chinese population. World J Gastroenterol. Sep. 28. 2010;16(36):4549-57. X-1. [pmid: 20857525].
3030 Zhou Q, Yang XJ, Zheng JW, et al. Short-term high-dose oral prednisone on alternate days is safe and effective for treatment of infantile hemangiomas. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Feb. 2010;109(2):166-7. X-4. [pmid: 20123404].
3031 In brief: oral propranolol infantile hemangiomas. Med Lett Drugs Ther. Oct. 31. 2011;53(1376):88. X-2. [pmid: 22033213].
3032 Propranolol effective in shrinking infantile hemangioma. Contemp Pediatr. 2011;28(9):11-2. PMID: X-1, X-2.
3033 CME Quiz: New Developments in the Management of Periocular Capillary Hemangioma in Children. J Pediatr Ophthalmol Strabismus. Sep. 1. 2011;48(5):268-77. X-1. [pmid: 24133235].
3034 Abdul Aziz DA, Khandasamy Y, Tamba RP, et al. Bleeding small bowel cavernous haemangioma following blunt trauma to the abdomen presenting as subacute intestinal obstruction in a child. BMJ Case Rep. 2011;2011. X-1. [pmid: 22679168].
3035 Abujarir R, Salama H, Alsulaiti G, et al. Congenital scalp myofibroma: A case report. J Neonatal Perinatal Med. 2011;4(1):75-8. X-1.
3036 Ackermann O, Fabre M, Franchi S, et al. Widening spectrum of liver angiosarcoma in children. J Pediatr Gastroenterol Nutr. Dec. 2011;53(6):615-9. X-1, X-3. [pmid: 21832953].
3037 Adepoju O, Wong A, Kitajewski A, et al. Expression of HES and HEY genes in infantile hemangiomas. Vasc Cell. 2011;3(19). X-1, X-3.
3038 Al Dhaybi R, Superstein R, Milet A, et al. Treatment of periocular infantile hemangiomas with propranolol: case series of 18 children. Ophthalmology. Jun. 2011;118(6):1184-8. X-4. [pmid: 21292326].
3039 Albertini AF, Brousse N, Bodemer C, et al. Retiform hemangioendothelioma developed on the site of an earlier cystic lymphangioma in a six-year-old girl. Am J Dermatopathol. Oct. 2011;33(7):e84-7. X-1. [pmid: 21915027].
3040 Alexiou GA, Moschovi M, Prodromou N. Treatment options for central nervous system cavernous malformations in children. Eur J Paediatr Neurol. May. 2011;15(3):281. X-3, X-4. [pmid: 21168351].
3041 Alexiou GA, Prodromou N. Treatment strategies and outcome of pediatric cerebral cavernomas. Neurol Sci. Aug. 2011;32(4):735. X-1. [pmid: 20596740].
3042 Alkonyi B, Chugani HT, Juhasz C. Transient focal cortical increase of interictal glucose metabolism in Sturge-Weber syndrome: implications for epileptogenesis. Epilepsia. Jul. 2011;52(7):1265-72. X-1. [pmid: 21480889].
3043 Alkonyi B, Chugani HT, Karia S, et al. Clinical outcomes in bilateral Sturge-Weber syndrome. Pediatr Neurol. Jun. 2011;44(6):443-9. X-1. [pmid: 21555056].
3044 Annamalai A, Puri V, Mehta S. Radium implant treatment of a birthmark at infancy and its association with malignancy. Am Surg. Mar. 2011;77(3):372-3. X-1. [pmid: 21375861].
3045 Antonio MT, Maia SF, Dionisio MT, et al. Superior sternal cleft, supraumbilical midline raphe and haemangiomas in a baby girl with an ostium secundum ASD. Clin Dysmorphol. Apr. 2011;20(2):95-7. X-2. [pmid: 21233709].
3046 Athavale SM, Ries WR, Carniol PJ. Laser treatment of cutaneous vascular tumors and malformations. Facial Plast Surg Clin North Am. May. 2011;19(2):303-12. X-1. [pmid: 21763991].
3047 Avery G, Davis C, Tan ST. Hemangioma causing deformational plagiocephaly. J Craniofac Surg. Jan. 2011;22(1):223-5. X-3, X-4. [pmid: 21233747].
3048 Bagazgoitia L, Hernandez-Martin A, Torrelo A. Recurrence of infantile hemangiomas treated with propranolol. Pediatr Dermatol. Nov–Dec. 2011;28(6):658-62. X-3, X-4. [pmid: 22082463].
3049 Ballah D, Cahill AM, Fontalvo L, et al. Vascular anomalies: what they are, how to diagnose them, and how to treat them. Curr Probl Diagn Radiol. Nov–Dec. 2011;40(6):233-47. X-1, X-2. [pmid: 21939817].
3050 Barros A, Freitas AC, Cabral AJ, et al. Giant placental chorioangioma: a rare cause of fetal hydrops. BMJ Case Rep. 2011;2011. X-1. [pmid: 22696752].
3051 Bauland CG, Luning TH, Smit JM, et al. Untreated hemangiomas: growth pattern and residual lesions. Plast Reconstr Surg. Apr. 2011;127(4):1643-8. X-3, X-4. [pmid: 21460670].
3052 Bay MJ, Kossoff EH, Lehmann CU, et al. Survey of aspirin use in Sturge-Weber syndrome. J Child Neurol. Jun. 2011;26(6):692-702. X-1. [pmid: 21427442].
3053 Behen ME, Juhasz C, Wolfe-Christensen C, et al. Brain damage and IQ in unilateral Sturge-Weber syndrome: support for a “fresh start” hypothesis. Epilepsy Behav. Oct. 2011;22(2):352-7. X-1. [pmid: 21852199].
3054 Behnke NM, Patel M, Davidson T, et al. Orthopaedic case of the month: Rapidly progressive shoulder soft tissue mass in an 8-week-old girl. Clin Orthop Relat Res. Feb. 2011;469(2):624-9. X-1. [pmid: 21128034].
3055 Beltran C, Garcia RJ, Tevah J, et al. Severe recurrent epistaxis in children: A case report involving two complex underlying conditions. Int J Pediatr Otorhinolaryngol Extra. December. 2011;6(4):335-8. X-2.
3056 Bigi S, Capone Mori A, Steinlin M, et al. Cavernous malformations of the central nervous system in children: presentation, treatment and outcome of 20 cases. Eur J Paediatr Neurol. Mar. 2011;15(2):109-16. X-1. [pmid: 21041104].
3057 Bonanno C, Paccanaro M, Fontanellilea A. Propranolol for severe hemangioma of infancy. J Cardiovasc Med (Hagerstown). Jan. 2011;12(1):73. X-3, X-4. [pmid: 21263236].
3058 Bonet-Coloma C, Minguez-Martinez I, Palma-Carrio C, et al. Clinical characteristics, treatment and outcome of 28 oral haemangiomas in pediatric patients. Med Oral Patol Oral Cir Bucal. Jan. 2011;16(1):e19-22. X-3, X-4. [pmid: 20711165].
3059 Bonini FK, Bellodi FS, Souza EM. Propranolol treatment for hemangioma of infancy. An Bras Dermatol. Jul–Aug. 2011;86(4):763-6. X-2. [pmid: 21987146].
3060 Boscolo E, Mulliken JB, Bischoff J. VEGFR-1 mediates endothelial differentiation and formation of blood vessels in a murine model of infantile hemangioma. Am J Pathol. Nov. 2011;179(5):2266-77. X-1. [pmid: 21945324].
3061 Boscolo E, Stewart CL, Greenberger S, et al. JAGGED1 signaling regulates hemangioma stem cell-to-pericyte/vascular smooth muscle cell differentiation. Arterioscler Thromb Vasc Biol. Oct. 2011;31(10):2181-92. X-1. [pmid: 21757656].
3062 Bracken J, Robinson I, Snow A, et al. PHACE syndrome: MRI of intracerebral vascular anomalies and clinical findings in a series of 12 patients. Pediatr Radiol. Sep. 2011;41(9):1129-38. X-3, X-4. [pmid: 21674285].
3063 Breur JM, de Graaf M, Breugem CC, et al. Hypoglycemia as a result of propranolol during treatment of infantile hemangioma: a case report. Pediatr Dermatol. Mar–Apr. 2011;28(2):169-71. X-2. [pmid: 20738795].
3064 Campolmi P, Bonan P, Cannarozzo G, et al. Importance of laser treatment in vascular malformations in the child. Giornale Italiano di Dermatologia e Venereologia. August. 2011;146(4):313-5. PMID: X-4. [pmid: 21785402].
3065 Cavaleiro LHS, Viana FO, Unger DAA, et al. Propranolol for extensive hemangiomas of infancy: Two case reports. Hemangiomas extensos da infancia tratados com propranolol: Relato de dois casos. Jornal Vascular Brasileiro. June. 2011;10(2):173-6. X-2.
3066 Cavaleiro LHS, Viana FO, Unger DAA, et al. Propranolol for extensive hemangiomas of infancy: Two case reports. Jornal Vascular Brasileiro. June. 2011;10(2):173-6. PMID: X-4.
3067 Chaudhary SC, Sonkar SK, Kumar V, et al. Sturge Weber syndrome. J Assoc Physicians India. May. 2011;59:327-9. X-1. [pmid: 21751615].
3068 Chen TH, Lin JY, Chen WF, et al. Elevated serum alpha-fetoprotein in a neonate with cutaneous infantile hemangioendothelioma. Pediatr Int. Apr. 2011;53(2):258-61. X-1, X-2. [pmid: 21501314].
3069 Chen YC, Wu JC, Liu L, et al. Correlation between ventriculoperitoneal shunts and inguinal hernias in children: an 8-year follow-up. Pediatrics. Jul. 2011;128(1):e121-6. X-1. [pmid: 21690112].
3070 Chim H, Gosain AK. Discussion: Oral prednisolone for infantile hemangioma: efficacy and safety using a standardized treatment protocol. Plast Reconstr Surg. Sep. 2011;128(3):753-4. X-3, X-4. [pmid: 21866002].
3071 Chkioua L, Khedhiri S, Ben Turkia H, et al. Hurler disease (mucopolysaccharidosis type IH): clinical features and consanguinity in Tunisian population. Diagn Pathol. 2011;6:113. X-1. [pmid: 22074387].
3072 Cho JH, Choi JY, Noh HI, et al. Giant lobular capillary hemangioma of the palate associated with Kasabach-Merritt syndrome. Int J Pediatr Otorhinolaryngol Extra. January. 2011;6(1):48-50. X-1, X-2.
3073 Cho MW, Johnston S, Neitzschman HR. Radiology case of the month: 11-year-old girl with intramuscular hemangioma. Intramuscular hemangioma within the right soleus muscle. J La State Med Soc. Jul–Aug. 2011;163(4):234. 6. X-2. [pmid: 21954659].
3074 Choi GH, Kim KN, Lee S, et al. The clinical features and surgical outcomes of patients with intramedullary spinal cord cavernous malformations. Acta Neurochir (Wien). Aug. 2011;153(8):1677-84. discussion 85. X-1. [pmid: 21720938].
3075 Chow WC, Ha SY, Chan GCF. Vincristine can induce regression of vascular malformation in long standing refractory Kasabach Merritt phenomenon. Hong Kong Journal of Paediatrics. 2011;16(2):121-4. X-1.
3076 Claerhout I, Buijsrogge M, Delbeke P, et al. The use of propranolol in the treatment of periocular infantile haemangiomas: a review. Br J Ophthalmol. Sep. 2011;95(9):1199-202. X-1. [pmid: 21131380].
3077 Collins D, Sebire NJ, Barnacle A, et al. ‘Mini’ free groin flap for treatment of a tufted angioma of the finger. J Plast Reconstr Aesthet Surg. May. 2011;64(5):e128-31. X-1. [pmid: 21277269].
3078 Cong X, Ludington-Hoe SM, Walsh S. Randomized crossover trial of kangaroo care to reduce biobehavioral pain responses in preterm infants: a pilot study. Biol Res Nurs. Apr. 2011;13(2):204-16. X-1. [pmid: 21196428].
3079 Corapcioglu F, Buyukkapu-Bay S, Binnetoglu K, et al. Preliminary results of propranolol treatment for patients with infantile hemangioma. Turk J Pediatr. Mar–Apr. 2011;53(2):137-41. X-4. [pmid: 21853649].
3080 del Pozo J, Lopez-Gutierrez JC, Gomez-Tellado M, et al. Capillary-lymphatic malformation, kaposiform hemangioendothelioma and delayed Kasabach-Merritt phenomenon. Pediatr Dermatol. Jul–Aug. 2011;28(4):439-43. X-1. [pmid: 20403115].
3081 Dempers J, Wadee SA, Boyd T, et al. Hepatic hemangioendothelioma presenting as sudden unexpected death in infancy: a case report. Pediatr Dev Pathol. Jan–Feb. 2011;14(1):71-4. X-1. [pmid: 20465426].
3082 Deyrup AT, Miettinen M, North PE, et al. Pediatric cutaneous angiosarcomas: a clinicopathologic study of 10 cases. Am J Surg Pathol. Jan. 2011;35(1):70-5. X-1. [pmid: 21164289].
3083 Di Pisa M, Chiaramonte G, Arcadipane A, et al. Air embolism during endoscopic retrograde cholangiopancreatography in a pediatric patient. Minerva Anestesiol. Jan. 2011;77(1):90-2. X-1. [pmid: 21150852].
3084 Dickison P, Christou E, Wargon O. A prospective study of infantile hemangiomas with a focus on incidence and risk factors. Pediatr Dermatol. Nov–Dec. 2011;28(6):663-9. X-3. [pmid: 21995808].
3085 Draus JM Jr, Kamel S, Seims A, et al. The role of laparoscopic evaluation to detect a contralateral defect at initial presentation for inguinal hernia repair. Am Surg. Nov. 2011;77(11):1463-6. X-1. [pmid: 22196658].
3086 Dukatz T, Sarnthein J, Sitter H, et al. Quality of life after brainstem cavernoma surgery in 71 patients. Neurosurgery. Sep. 2011;69(3):689-95. X-1. [pmid: 21508880].
3087 Dutra AK, Lopes A, Ikeda MK, et al. The role of surgical treatment in orbital vascular anomalies. Aesthetic Plast Surg. Dec. 2011;35(6):1087-96. X-1. [pmid: 21556982].
3088 Dyer SR, Saraiya S, Sirigiri R, et al. Congenital lobular capillary hemangioma of the larynx: A case report. Int J Pediatr Otorhinolaryngol Extra. December. 2011;6(4):339-45. X-1, X-2.
3089 Eivazi B, Cremer HJ, Mangold C, et al. Hemangiomas of the nasal tip: an approach to a therapeutic challenge. Int J Pediatr Otorhinolaryngol. Mar. 2011;75(3):368-75. X-4. [pmid: 21208666].
3090 El-Badrawy A, Elzaafarany M, Youssef TF, et al. Role of diffusion-weighted MR imaging in chest wall masses. Egyptian Journal of Radiology and Nuclear Medicine. June. 2011;42(2):147-51. X-1.
3091 El-Essawy R, Galal R, Abdelbaki S. Nonselective beta-blocker propranolol for orbital and periorbital hemangiomas in infants: A new first-line of treatment?. Clin Ophthalmol. 17. Nov. 2011;5(1):1639-44. X-4. [pmid: 22140311].
3092 El-Koussy M, Stepper F, Spreng A, et al. Incidence, clinical presentation and imaging findings of cavernous malformations of the CNS. A twenty-year experience. Swiss Med Wkly. 2011;141:w13172. X-1. [pmid: 21491213].
3093 Eltaybe AA, Hassen YS. Non invasive management of haemangioma and vascular malformation using intralesional bleomycin injection. Eur Surg. April. 2011;43:19-20. PMID: X-1.
3094 Enomoto Y, Yoshimura S, Egashira Y, et al. Transarterial embolization for cervical hemangioma associated with Kasabach-merritt syndrome. Neurol Med Chir (Tokyo). 2011;51(5):375-8. X-2. [pmid: 21613765].
3095 Fabian ID, Ben-Zion I, Samuel C, et al. Reduction in astigmatism using propranolol as first-line therapy for periocular capillary hemangioma. Am J Ophthalmol. Jan. 2011;151(1):53-8. X-3, X-4. [pmid: 20970771].
3096 Faraci M, Morana G, Bagnasco F, et al. Magnetic resonance imaging in childhood leukemia survivors treated with cranial radiotherapy: a cross sectional, single center study. Pediatr Blood Cancer. Aug. 2011;57(2):240-6. X-1. [pmid: 21671360].
3097 Fernandez-Pineda I, Lopez-Gutierrez JC. Liver allograft with hemangioma in pediatric living donor liver transplantation. Ann Transplant. Apr–Jun. 2011;16(2):117-8. X-3, X-4. [pmid: 21716196].
3098 Ferreira Rda C, Wolff FR, Morschbacher R. Oral propranolol as a new treatment for facial infantile hemangioma: case report. Arq Bras Oftalmol. May–Jun. 2011;74(3):207-8. X-1, X-2. [pmid: 21915449].
3099 Fleming P, Fitzgerald K, Watson R, et al. Response to “Dental caries as a side effect of infantile hemangioma treatment with propranolol solution”. Pediatr Dermatol. Sep–Oct. 2011;28(5):602. author reply. X-3, X-4. [pmid: 21916966].
3100 Freshwater MF. Treatment of vascular anomalies of the upper extremity. J Hand Surg Am. Feb. 2011;36(2):370. X-3, X-4. [pmid: 21276909].
3101 Fridman G, Grieser E, Hill R, et al. Propranolol for the treatment of orbital infantile hemangiomas. Ophthal Plast Reconstr Surg. May–Jun. 2011;27(3):190-4. X-3, X-4. [pmid: 21283032].
3102 Frieden IJ. Infantile hemangioma research: looking backward and forward. J Invest Dermatol. Dec. 2011;131(12):2345-8. X-1, X-2. [pmid: 22071540].
3103 Fukushima H, Kudo T, Fuskushima T, et al. An infant with life-threatening hemangioma successfully treated with low-dose cyclophosphamide. Pediatr Int. Dec. 2011;53(6):1073-5. X-1. [pmid: 22181565].
3104 Fussell JN, Wilson T, Pride H. Case report: Congenital dacryocystocele and dacryocystitis. Pediatr Dermatol. Jan–Feb. 2011;28(1):70-2. X-1. [pmid: 21276064].
3105 Gao W, Qiao X, Ma S, et al. Contribution of skin trauma to infantile skin hemangioma. Med Hypotheses. Apr. 2011;76(4):512-3. X-1, X-2. [pmid: 21220189].
3106 Gardner R, Dwyer C, Morrison C. MINERVA. Bmj. 2011;343(7821):486. PMID: X-2.
3107 Gaudric A, Krivosic V, Duguid G, et al. Vitreoretinal surgery for severe retinal capillary hemangiomas in von hippel-lindau disease. Ophthalmology. Jan. 2011;118(1):142-9. X-1. [pmid: 20801520].
3108 Gawley SD, Bingham EA, McGinnity G. Visual outcomes of treated periocular capillary haemangiomas in childhood: a 10-year review. Acta Ophthalmol. Jun. 2011;89(4):396-401. X-4. [pmid: 20156200].
3109 Ghosh C, Marchi N, Desai NK, et al. Cellular localization and functional significance of CYP3A4 in the human epileptic brain. Epilepsia. Mar. 2011;52(3):562-71. X-1. [pmid: 21294720].
3110 Ghosh PS, Ghosh D. Infantile intraspinal and extensive cutaneous hemangiomas: excellent response to propranolol. Neurology. May. 17. 2011;76(20):1771. X-2. [pmid: 21576696].
3111 Gidaris D, Economou M, Hatzidemetriou V, et al. Use of propranolol in infantile haemangiomas: Report of five cases and review of the literature. Hippokratia. 2011;15(1):81-3. X-2. [pmid: 21607042].
3112 Gonc N, Engiz O, Neumann HP, et al. Two pediatric patients with Von Hippel-Lindau disease type 2b: from patient to screening, from screening to patient. J Pediatr Endocrinol Metab. 2011;24(1–2):109-12. X-1. [pmid: 21528828].
3113 Goodman SH, Rouse MH, Long Q, et al. Deconstructing antenatal depression: What is it that matters for neonatal behavioral functioning?. Infant Ment Health J. May/June. 2011;32(3):339-61. X-1.
3114 Goswamy J, Rothera MP, Bruce IA. Failure of propranolol in the treatment of childhood haemangiomas of the head and neck. J Laryngol Otol. Nov. 2011;125(11):1164-72. X-3, X-4. [pmid: 21846414].
3115 Greenberger S, Yuan S, Walsh LA, et al. Rapamycin suppresses self-renewal and vasculogenic potential of stem cells isolated from infantile hemangioma. J Invest Dermatol. Dec. 2011;131(12):2467-76. X-1. [pmid: 21938011].
3116 Greene AK, Liu AS, Mulliken JB, et al. Vascular anomalies in 5,621 patients: guidelines for referral. J Pediatr Surg. Sep. 2011;46(9):1784-9. X-3, X-4. [pmid: 21929990].
3117 Greenhill NB, Deacon GB, Phillips RJ. Giving propranolol tablets to infants with hemangiomas - solubility in water. J Paediatr Child Health. Jul. 2011;47(7):484-5. X-3, X-4. [pmid: 21771149].
3118 Grimmer JF, Williams MS, Pimentel R, et al. Familial clustering of hemangiomas. Arch Otolaryngol Head Neck Surg. Aug. 2011;137(8):757-60. X-2, X-3. [pmid: 21844408].
3119 Grover C, Kedar A, Arora P, et al. Efficacy of oral prednisolone use in the treatment of infantile hemangiomas in Indian children. Pediatr Dermatol. Sep–Oct. 2011;28(5):502-6. X-4. [pmid: 21692837].
3120 Guye E, Chollet-Rivier M, Schroder D, et al. Propranolol treatment for subglottic haemangioma. Arch Dis Child Fetal Neonatal Ed. Jul. 2011;96(4):F263-4. X-2. [pmid: 21242239].
3121 Haggstrom AN, Skillman S, Garzon MC, et al. Clinical spectrum and risk of PHACE syndrome in cutaneous and airway hemangiomas. Arch Otolaryngol Head Neck Surg. Jul. 2011;137(7):680-7. X-3, X-4. [pmid: 21768412].
3122 Halilbasic A, Hotic N, Husaric E, et al. Initial experiences with propranolol treatment of infantile hemangiomas: report of three cases. Med Arh. 2011;65(6):380-2. X-3, X-4. [pmid: 22299307].
3123 Hamidah A, Reena M, Halim AR, et al. Successful treatment of very large congenital infantile fibrosarcoma. Pediatr Int. Oct. 2011;53(5):768-70. X-1. [pmid: 21955012].
3124 Hammill AM, Wentzel M, Gupta A, et al. Sirolimus for the treatment of complicated vascular anomalies in children. Pediatr Blood Cancer. Dec. 1. 2011;57(6):1018-24. X-1. [pmid: 21445948].
3125 Handra-Luca A, Montgomery E. Vascular malformations and hemangiolymphangiomas of the gastrointestinal tract: morphological features and clinical impact. Int J Clin Exp Pathol. Jun. 20. 2011;4(5):430-43. X-1. [pmid: 21738815].
3126 Harikrishna B, Ganesh A, Al-Zuahibi S, et al. Oral propranolol for the treatment of periorbital infantile hemangioma: a preliminary report from oman. Middle East Afr J Ophthalmol. Oct. 2011;18(4):298-303. X-4. [pmid: 22224018].
3127 Hassanein AH, Alomari AI, Schmidt BA, et al. Pilomatrixoma imitating infantile hemangioma. J Craniofac Surg. Mar. 2011;22(2):734-6. X-1. [pmid: 21415649].
3128 Hermans DJ, van Beynum IM, van der Vijver RJ, et al. Kaposiform hemangioendothelioma with Kasabach-Merritt syndrome: a new indication for propranolol treatment. J Pediatr Hematol Oncol. May. 2011;33(4):e171-3. X-1. [pmid: 21516018].
3129 Hochman M, Adams DM, Reeves TD. Current knowledge and management of vascular anomalies: I. Hemangiomas. Arch Facial Plast Surg. May–Jun. 2011;13(3):145-51. X-1, X-2. [pmid: 21576660].
3130 Hoque S, Das BK. Treatment of venous malformations with ethanolamine oleate: a descriptive study of 83 cases. Pediatr Surg Int. May. 2011;27(5):527-31. X-1. [pmid: 21290138].
3131 Horii KA, Drolet BA, Frieden IJ, et al. Prospective study of the frequency of hepatic hemangiomas in infants with multiple cutaneous infantile hemangiomas. Pediatr Dermatol. May–Jun. 2011;28(3):245-53. X-3. [pmid: 21517952].
3132 Hospach T, Langendorfer M, Kalle TV, et al. Mimicry of lyme arthritis by synovial hemangioma. Rheumatol Int. Dec. 2011;31(12):1639-43. X-1, X-2. [pmid: 20013264].
3133 Hou J, Wang M, Tang H, et al. Pingyangmycin sclerotherapy for infantile hemangiomas in oral and maxillofacial regions: an evaluation of 66 consecutive patients. Int J Oral Maxillofac Surg. Nov. 2011;40(11):1246-51. X-3. [pmid: 21893396].
3134 Hussain K, Makura ZG. Pyriform sinus haemangioma: an unusual presentation of an unusual condition. J Laryngol Otol. Nov. 2011;125(11):1196-8. X-1. [pmid: 21729438].
3135 Incesoy Ozdemir S, Bozkurt C, Orun UA, et al. Successful treatment of pulmonary arteriovenous malformation and infantile hepatic hemangioendothelioma with alpha-interferon. Anadolu Kardiyol Derg. Mar. 2011;11(2):181-3. X-1, X-2. [pmid: 21362599].
3136 Itinteang T, Brasch HD, Tan ST, et al. Expression of components of the renin-angiotensin system in proliferating infantile haemangioma may account for the propranolol-induced accelerated involution. J Plast Reconstr Aesthet Surg. Jun. 2011;64(6):759-65. X-1. [pmid: 20870476].
3137 Jaganathan S, Gamanagatti S, Mukund A, et al. Bleeding scrotal vascular lesions: interventional management with transcatheter embolization. Cardiovasc Intervent Radiol. Feb. 2011;34(Suppl 2):S113-6. X-1. [pmid: 21052669].
3138 Janmohamed SR, de Laat PC, Madern GC, et al. Do we have to check glucose in patients with haemangioma of infancy treated with beta-blockers?. J Eur Acad Dermatol Venereol. Dec. 2011;25(12):1490. X-3, X-4. [pmid: 21797931].
3139 Janmohamed SR, de Waard-van der Spek FB, Madern GC, et al. Scoring the proliferative activity of haemangioma of infancy: the Haemangioma Activity Score (HAS). Clin Exp Dermatol. Oct. 2011;36(7):715-23. X-1, X-2. [pmid: 21933230].
3140 Janmohamed SR, Madern GC, De Laat PCJ, et al. Haemangioma of infancy: Two case reports with an overdose of propranolol. Case Rep Dermatol. January–April. 2011;3(1):18-21. X-2. [pmid: 21931573].
3141 Javia LR, Zur KB, Jacobs IN. Evolving treatments in the management of laryngotracheal hemangiomas: will propranolol supplant steroids and surgery?. Int J Pediatr Otorhinolaryngol. Nov. 2011;75(11):1450-4. X-4. [pmid: 21880377].
3142 Jerjes W, Upile T, Hamdoon Z, et al. Interstitial PDT for vascular anomalies. Lasers Surg Med. Jul. 2011;43(5):357-65. X-1. [pmid: 21674540].
3143 Jia W, Ma Z, Liu IY, et al. Transcallosal interforniceal approach to pineal region tumors in 150 children. J Neurosurg Pediatr. Jan. 2011;7(1):98-103. X-1. [pmid: 21194293].
3144 Jiang C, Hu X, Ma G, et al. A prospective self-controlled phase II study of imiquimod 5% cream in the treatment of infantile hemangioma. Pediatr Dermatol. May–Jun. 2011;28(3):259-66. X-3. [pmid: 21615472].
3145 Jiruska P, Marusic P, Jefferys JG, et al. Sturge-Weber syndrome: a favourable surgical outcome in a case with contralateral seizure onset and myoclonic-astatic seizures. Epileptic Disord. Mar. 2011;13(1):76-81. X-1. [pmid: 21393095].
3146 Johnson S. as they grow: 0–12 MONTHS. Birthmark Questions. Parents. 2011;86(11):176-9. PMID: X-2.
3147 Jones SM, Rahman RS, Bourgeois DJ 3rd, et al. Hemihyperplasia in a 4-month-old. Clin Pediatr (Phila). Apr. 2011;50(4):367-71. X-1. [pmid: 21339252].
3148 Jurek T, Czuba M, Smigiel R, et al. Giant heart tumors in infants leading to sudden, unexpected death: description of two cases. Pediatr Int. Dec. 2011;53(6):1090-3. X-1. [pmid: 22181571].
3149 Kaddah RO, Lotfi U, Haggag M, et al. The role of radiology in the planning management of Klippel Trenaunay Syndrome (KTS). Egyptian Journal of Radiology and Nuclear Medicine. June. 2011;42(2):201-10. X-1.
3150 Khera S, Gupta R. Incidence of thrombocytopenia following phototherapy in hyperbilirubinemic neonates. Med J Armed Forces India. October. 2011;67(4):329-32. X-1.
3151 Kier C, Balluz R, Modi V, et al. Visual diagnosis: respiratory distress: a great masquerader. Pediatr Rev. Oct. 2011;32(10):e95-101. X-2. [pmid: 21965715].
3152 Kim LH, Hogeling M, Wargon O, et al. Propranolol: useful therapeutic agent for the treatment of ulcerated infantile hemangiomas. J Pediatr Surg. Apr. 2011;46(4):759-63. X-3, X-4. [pmid: 21496551].
3153 Kim MG, Choi YS, Park SJ, et al. Kaposiform hemangioendothelioma of the breast in an adult female. Clin Breast Cancer. Apr. 2011;11(2):135-7. X-1. [pmid: 21570000].
3154 Kim YT, Kang SW, Lee JI. Gamma knife radiosurgery for choroidal hemangioma. Int J Radiat Oncol Biol Phys. Dec. 1. 2011;81(5):1399-404. X-1. [pmid: 20950946].
3155 Kirkham FJ, Durnford A, Rodgers W, et al. Inter-rater reliability of engel and ILAE seizure outcome classifications. Epilepsy Curr. 2011;(1). X-1.
3156 Kivelev J, Laakso A, Niemela M, et al. A proposed grading system of brain and spinal cavernomas. Neurosurgery. Oct. 2011;69(4):807-13. discussion 13–4. X-1. [pmid: 21508872].
3157 Koay AC, Choo MM, Nathan AM, et al. Combined low-dose oral propranolol and oral prednisolone as first-line treatment in periocular infantile hemangiomas. J Ocul Pharmacol Ther. Jun. 2011;27(3):309-11. X-3, X-4. [pmid: 21542771].
3158 Kochin IN, Miloh TA, Arnon R, et al. Benign liver masses and lesions in children: 53 cases over 12 years. Isr Med Assoc J. Sep. 2011;13(9):542-7. X-1. [pmid: 21991714].
3159 Kolokythas A, Al-Ghamian H, Miloro M. Does a difference exist in inferior alveolar canal displacement caused by commonly encountered pathologic entities? An observational study. J Oral Maxillofac Surg. Jul. 2011;69(7):1944-51. X-1. [pmid: 21419544].
3160 Kosemehmetoglu K, Gedikoglu G, Ruacan S. Morphological and immunohistochemical features of malignant vascular tumors with special emphasis on GLUT1, and FKBP12 expressions. Turk Patoloji Derg. Jan. 2011;27(1):57-67. X-1. [pmid: 21469428].
3161 Kulungowski AM, Schook CC, Alomari AI, et al. Vascular anomalies of the male genitalia. J Pediatr Surg. Jun. 2011;46(6):1214-21. X-3, X-4. [pmid: 21683225].
3162 Kuroda T, Kumagai M, Nosaka S, et al. Critical infantile hepatic hemangioma: results of a nationwide survey by the Japanese Infantile Hepatic Hemangioma Study Group. J Pediatr Surg. Dec. 2011;46(12):2239-43. X-3, X-4. [pmid: 22152857].
3163 Lau K, Massad M, Pollak C, et al. Clinical patterns and outcome in epithelioid hemangioendothelioma with or without pulmonary involvement: insights from an internet registry in the study of a rare cancer. Chest. Nov. 2011;140(5):1312-8. X-1. [pmid: 21546438].
3164 Lazar DA, Olutoye OO, Moise KJ Jr, et al. Ex-utero intrapartum treatment procedure for giant neck masses--fetal and maternal outcomes. J Pediatr Surg. May. 2011;46(5):817-22. X-1. [pmid: 21616233].
3165 Leaute-Labreze C, Prey S, Ezzedine K. Infantile haemangioma: part II. Risks, complications and treatment. J Eur Acad Dermatol Venereol. Nov. 2011;25(11):1254-60. X-1, X-2. [pmid: 21569113].
3166 Leonardi-Bee J, Batta K, O’Brien C, et al. Interventions for infantile haemangiomas (strawberry birthmarks) of the skin. Cochrane Database Syst Rev. 2011;(5). PMID: X-2.
3167 Li J, Chen X, Zhao S, et al. Demographic and clinical characteristics and risk factors for infantile hemangioma: a Chinese case-control study. Arch Dermatol. Sep. 2011;147(9):1049-56. X-3. [pmid: 21576550].
3168 Liang JT, Bao YH, Zhang HQ, et al. Management and prognosis of symptomatic patients with intramedullary spinal cord cavernoma: clinical article. J Neurosurg Spine. Oct. 2011;15(4):447-56. X-1. [pmid: 21740129].
3169 Lin HK, Wang JD, Fu LS. Recurrent hemarthrosis in a boy with synovial hemangioma: a case report. J Pediatr Orthop B. Mar. 2011;20(2):81-3. X-2. [pmid: 21088622].
3170 Locke R, Kubba H. The external rhinoplasty approach for congenital nasal lesions in children. Int J Pediatr Otorhinolaryngol. Mar. 2011;75(3):337-41. X-1. [pmid: 21183230].
3171 Luo Q, Zhao F. How to use bleomycin A5 for infantile maxillofacial haemangiomas: clinical evaluation of 82 consecutive cases. J Craniomaxillofac Surg. Oct. 2011;39(7):482-6. X-3. [pmid: 20675147].
3172 Luo QF, Zhao FY. The effects of Bleomycin A5 on infantile maxillofacial haemangioma. Head Face Med. 2011;7:11. X-3. [pmid: 21736714].
3173 Ma J, Shi QL, Jiang SJ, et al. Primary kaposiform hemangioendothelioma of a long bone: two cases in unusual locations with long-term follow up. Pathol Int. Jun. 2011;61(6):382-6. X-1. [pmid: 21615616].
3174 Mahadevan M, Cheng A, Barber C. Treatment of subglottic hemangiomas with propranolol: initial experience in 10 infants. ANZ J Surg. Jun. 2011;81(6):456-61. X-4. [pmid: 22295350].
3175 Makdoumi K, Crafoord S. Vasoproliferative retinal tumours in a Swedish population. Acta Ophthalmol. Feb. 2011;89(1):91-4. X-1. [pmid: 19860770].
3176 Margo CE. Analysis of clinical misdiagnoses in children treated with enucleation. Arch Ophthalmol. May. 2011;129(5):673-4. author reply 4–5. X-3, X-4. [pmid: 21555629].
3177 Martin MC, Harrington H, Wong WW. Massive congenital kaposiform hemangioendothelioma of the eyelid in a neonate. J Craniofac Surg. Nov. 2011;22(6):e38-41. X-1. [pmid: 22134318].
3178 Martin TC, Careskey JM, Harle H, et al. Case 1: abdominal pain and coffee ground emesis in a 9-year-old boy. Case 2: vomiting, headache, and seizures in a 7-year-old boy. Case 3: primary amenorrhea in a 15-year-old girl. Pediatr Rev. May. 2011;32(5):209-14. X-1. [pmid: 21536781].
3179 Mascarenhas R, Guiote V, Agro J, et al. Ulcerated infantile hemangioma treated with imiquimod. Dermatol Online J. 2011;17(9):13. X-2. [pmid: 21971278].
3180 Masters IB. Stridor in the neonate. Curr Pediatr Rev. June. 2011;7(1):20-32. X-1.
3181 Matsuda S, Sato Y, Marutsuka K, et al. Hemangioma of the umbilical cord with pseudocyst. Fetal Pediatr Pathol. 2011;30(1):16-21. X-1, X-2. [pmid: 21204661].
3182 Maugans T, Sheridan RM, Adams D, et al. Cutaneous vascular anomalies associated with neural tube defects: nomenclature and pathology revisited. Neurosurgery. Jul. 2011;69(1):112-8. discussion 8. X-3, X-4. [pmid: 21368703].
3183 Meena M. Re: “propranolol for the treatment of orbital infantile hemangiomas”. Ophthal Plast Reconstr Surg. Sep–Oct. 2011;27(5):392. author reply 3. X-3, X-4. [pmid: 21904175].
3184 Menezes MD, McCarter R, Greene EA, et al. Status of propranolol for treatment of infantile hemangioma and description of a randomized clinical trial. Ann Otol Rhinol Laryngol. Oct. 2011;120(10):686-95. X-2. [pmid: 22097156].
3185 Menke J, Schaefer IM. A large liver tumor in a 3-month-old girl. Diagnosis: GLUT1-negative hepatic vascular malformation with capillary proliferation. Gastroenterology. Jun. 2011;140(7):1883. 2151. X-1. [pmid: 21521642].
3186 Menon G, Gopalakrishnan CV, Rao BR, et al. A single institution series of cavernomas of the brainstem. J Clin Neurosci. Sep. 2011;18(9):1210-4. X-1. [pmid: 21745743].
3187 Menon RN, Baheti NN, Cherian A, et al. Post-irradiation “acquired cavernous angiomas” with drug resistant seizures. Epilepsy Res. Sep. 2011;96(1–2):161-5. X-1. [pmid: 21680152].
3188 Mhanna A, Franklin WH, Mancini AJ. Hepatic infantile hemangiomas treated with oral propranolol--a case series. Pediatr Dermatol. Jan–Feb. 2011;28(1):39-45. X-3, X-4. [pmid: 21261702].
3189 Miebach E, Church H, Cooper A, et al. The craniocervical junction following successful haematopoietic stem cell transplantation for mucopolysaccharidosis type I H (Hurler syndrome). J Inherit Metab Dis. Jun. 2011;34(3):755-61. X-1. [pmid: 21416193].
3190 Mishra A, Holmes W, Gorst C, et al. Management of complicated facial hemangiomas with Beta-blocker (propranolol) therapy. Plast Reconstr Surg. Apr. 2011;127(4):1742-3. author reply 3. X-2, X-4. [pmid: 21460687].
3191 Mishra A, Holmes WJ, Liew S. The Cyrano nose: different treatment approaches to management of hemangiomas of the nasal tip. Plast Reconstr Surg. Jun. 2011;127(6):2507-8. author reply 8–9. X-3, X-4. [pmid: 21617487].
3192 Missoi TG, Lueder GT, Gilbertson K, et al. Oral propranolol for treatment of periocular infantile hemangiomas. Arch Ophthalmol. Jul. 2011;129(7):899-903. X-4. [pmid: 21402978].
3193 Mnif H, Zrig M, Maazoun K, et al. Congenital infantile fibrosarcoma of the forearm. Chir Main. Apr. 2011;30(2):148-51. X-1. [pmid: 21411358].
3194 Montouris G, Harden C, Alekar S, et al. UCB antiepileptic drug pregnancy Registrykeppra data. Epilepsy Curr. 2011;(1). X-1.
3195 Morais P, Magina S, Mateus M, et al. Efficacy and safety of propranolol in the treatment of parotid hemangioma. Cutan Ocul Toxicol. Sep. 2011;30(3):245-8. X-2. [pmid: 21338243].
3196 Morkane C, Gregory JW, Watts P, et al. Adrenal suppression following intralesional corticosteroids for periocular haemangiomas. Arch Dis Child. Jun. 2011;96(6):587-9. X-4. [pmid: 21321258].
3197 Moskowitz HS, Jaffe R, Hirsch BE. Epithelioid hemangioendothelioma of the middle ear in a child. Am J Otolaryngol. May–Jun. 2011;32(3):259-62. X-1. [pmid: 20444524].
3198 Mungan S, Turgutalp H, Ersoz S, et al. A rare neoplasm of the testis: capillary hemangioma. Turk Patoloji Derg. Jan. 2011;27(1):80-3. X-1, X-2. [pmid: 21469432].
3199 Nabatian AS, Milgraum SS, Hess CP, et al. PHACE without face? Infantile hemangiomas of the upper body region with minimal or absent facial hemangiomas and associated structural malformations. Pediatr Dermatol. May–Jun. 2011;28(3):235-41. X-1, X-4. [pmid: 21453307].
3200 Nakamura H, Makino K, Ushio Y, et al. Therapy-associated secondary tumors in patients with non-germinomatous malignant germ cell tumors. J Neurooncol. Nov. 2011;105(2):359-64. X-1. [pmid: 21533838].
3201 Nale P. Propranolol treatment promising for infantile capillary hemangioma. Ocular Surgery News. 2011;29(10):16. PMID: X-2.
3202 Nandi M, Mondal RK, Chandra PK. A rare case of giant cutaneous and extracutaneous haemangiomas. J Indian Med Assoc. Jul. 2011;109(7):516. X-1, X-2. [pmid: 22315855].
3203 Navarini S, Bucher B, Pavlovic M, et al. Pulmonary hypertension presenting with apnea, cyanosis, and failure to thrive in a young child. Chest. Oct. 2011;140(4):1086-9. X-1. [pmid: 21972389].
3204 Ni N, Langer P, Wagner R, et al. Topical timolol for periocular hemangioma: report of further study. Arch Ophthalmol. Mar. 2011;129(3):377-9. X-4. [pmid: 21403002].
3205 Nigwekar SP, Nigwekar PV. Atypical presentation of capillary hemangioma of upper eyelid: A case report. Pravara Medical Review. 2011;3(3):34-6. X-2.
3206 Noto R, Maneatis T, Frane J, et al. Intracranial hypertension in pediatric patients treated with recombinant human growth hormone: data from 25 years of the Genentech National Cooperative Growth Study. J Pediatr Endocrinol Metab. 2011;24(9–10):627-31. X-1. [pmid: 22145447].
3207 Nunn A, Shah U, Ford J. Giving propranolol tablets to infants with hemangiomas. J Paediatr Child Health. Dec. 2011;47(12):927. X-3, X-4. [pmid: 22171835].
3208 O’Loughlin A, O’Donnell BF, Watson R. Mature infantile haemangiomas role for propranolol. J Eur Acad Dermatol Venereol. Nov. 2011;25(11):1363-4. X-3, X-4. [pmid: 21108669].
3209 Onan B, Haydin S, Onan IS, et al. Giant tumor of the right atrium in infancy. Ann Thorac Surg. Aug. 2011;92(2):737-40. X-2. [pmid: 21801937].
3210 Oranje AP, Janmohamed SR, Madern GC, et al. Treatment of small superficial haemangioma with timolol 0.5% ophthalmic solution: a series of 20 cases. Dermatology. 2011;223(4):330-4. X-3, X-4. [pmid: 22179543].
3211 Osifo OD, Evbuomwan I. Hemangiomas in children: Challenges and outcome of surgical management in Benin city, Nigeria. Iran J Pediatr. Sep. 2011;21(3):350-6. X-3, X-4. [pmid: 23056812].
3212 Padhi S, Sarangi R, Challa S, et al. A 10-year retrospective study of hemangioblastomas of the central nervous system with reference to von Hippel-Lindau (VHL) disease. J Clin Neurosci. Jul. 2011;18(7):939-44. X-1. [pmid: 21570297].
3213 Parashette KR, Cuffari C. Sclerotherapy of rectal hemangiomas in a child with Klippel-Trenaunay-Weber syndrome. J Pediatr Gastroenterol Nutr. Jan. 2011;52(1):111-2. X-1. [pmid: 21057326].
3214 Parhizkar N, Manning SC, Inglis AF Jr, et al. How airway venous malformations differ from airway infantile hemangiomas. Arch Otolaryngol Head Neck Surg. Apr. 2011;137(4):352-7. X-3, X-4. [pmid: 21242531].
3215 Pascual-Castroviejo I, Parron Pajares M, Pascual-Pascual SI, et al. Cutaneous, mediastinal and hepatic hemangiomas in a girl followed during 12 years. Neuropediatrics. Feb. 2011;42(1):24-7. X-2. [pmid: 21557145].
3216 Pastore S, Londero M, Cont G, et al. Refractory iron-deficiency anaemia in a child with portal cavernoma. Gut. Mar. 2011;60(3):317. 77. X-1. [pmid: 21051450].
3217 Peng Q, Liu W, Zhou F, et al. An experimental study on the therapy of infantile hemangioma with recombinant interferon gamma. J Pediatr Surg. Mar. 2011;46(3):496-501. X-1. [pmid: 21376199].
3218 Pereira PM, Rodrigues CA, Lima LL, et al. Periorbital hemangiomas: the need for active management - report of two cases. An Bras Dermatol. May–Jun. 2011;86(3):545-8. X-3, X-4. [pmid: 21738973].
3219 Peridis S, Pilgrim G, Athanasopoulos I, et al. A meta-analysis on the effectiveness of propranolol for the treatment of infantile airway haemangiomas. Int J Pediatr Otorhinolaryngol. Apr. 2011;75(4):455-60. X-1, X-2. [pmid: 21333364].
3220 Pithon MM, de Andrade AC, de Andrade AP, et al. Sturge-Weber syndrome in an orthodontic patient. Am J Orthod Dentofacial Orthop. Sep. 2011;140(3):418-22. X-1. [pmid: 21889087].
3221 Prasad R, Johnston LB, Savage MO, et al. Pediatric endocrine screening for von Hippel-Lindau disease: benefits and the challenge of compliance. J Endocrinol Invest. Apr. 2011;34(4):296-9. X-1. [pmid: 20585202].
3222 Purkait R, Samanta T, Sinhamahapatra T, et al. Overlap of Sturge-Weber syndrome and Klippel-Trenaunay syndrome. Indian J Dermatol. November–December. 2011;56(6):755-7. X-1. [pmid: 22345790].
3223 Raiskarami SR, Jafarieh H, Foomani RS, et al. Maffucci’s syndrome: A misdiagnosed 9-year-old female patient. Am J Case Rep. 2011;12:35-8. X-1, X-2.
3224 Raol N, Metry D, Edmonds J, et al. Propranolol for the treatment of subglottic hemangiomas. Int J Pediatr Otorhinolaryngol. Dec. 2011;75(12):1510-4. X-3, X-4. [pmid: 21944056].
3225 Raphael MF, de Graaf M, Breugem CC, et al. Atenolol: a promising alternative to propranolol for the treatment of hemangiomas. J Am Acad Dermatol. Aug. 2011;65(2):420-1. X-4. [pmid: 21763565].
3226 Rekhi B, Sethi S, Kulkarni SS, et al. Kaposiform hemangioendothelioma in tonsil of a child associated with cervical lymphangioma: a rare case report. World J Surg Oncol. 2011;9:57. X-1. [pmid: 21605441].
3227 Remlova E, Dostalova T, Michalusova I, et al. Hemangioma curative effect of PDL, alexandrite, Er:YAG and CO(2) lasers. Photomed Laser Surg. Dec. 2011;29(12):815-25. X-1. [pmid: 21793735].
3228 Saigal G, Hildoer D, Parra-Herran C, et al. Case report. Unusual presentation of a pancreatic mass in an infant: pancreatic haemangioendotheliomatosis. Br J Radiol. Dec. 2011;84(1008):e232-5. X-1. [pmid: 22101589].
3229 Sainsbury DC, Kessell G, Fall AJ, et al. Intralesional bleomycin injection treatment for vascular birthmarks: a 5-year experience at a single United Kingdom unit. Plast Reconstr Surg. May. 2011;127(5):2031-44. X-3, X-4. [pmid: 21532430].
3230 Sakamoto S, Kasahara M, Shigeta T, et al. Living donor liver transplantation for multiple intrahepatic portosystemic shunts after involution of infantile hepatic hemangiomas. J Pediatr Surg. Jun. 2011;46(6):1288-91. X-2. [pmid: 21683241].
3231 Sanada Y, Mizuta K, Urahashi T, et al. Pediatric living donor liver transplantation using liver allograft with hemangioma. Ann Transplant. Jan–Mar. 2011;16(1):66-9. X-1. [pmid: 21436777].
3232 Sanz-Marco E, Gallego R, Diaz-Llopis M. Oral propranolol for circumscribed choroidal hemangioma. Case Rep Ophthalmol. January–April. 2011;2(1):84-90. X-1. [pmid: 21475606].
3233 Say EA, Shields CL, Bianciotto C, et al. Perilymphatic subcutaneous fat atrophy and cutaneous depigmentation after periocular triamcinolone acetonide injection in a child. J aapos. Feb. 2011;15(1):107-8. X-1. [pmid: 21397819].
3234 Scheinfeld NS. Dermatologic Look-Alikes. Vascular nodules and papules. Clinical Advisor. 2011;14(7):109-12. PMID: X-2.
3235 Schneider D, Lee MS, Harrison AR, et al. Excision of periorbital hemangiomas to correct visual abnormalities. Arch Facial Plast Surg. May–Jun. 2011;13(3):195-8. X-4. [pmid: 21576666].
3236 Sciveres M, Marrone G, Pipitone S, et al. Successful first-line treatment with propranolol of multifocal infantile hepatic hemangioma with high-flow cardiac overload. J Pediatr Gastroenterol Nutr. Dec. 2011;53(6):693-5. X-2. [pmid: 21519284].
3237 Sharma J, Hsu D, Weinstein S. Obstructive right ventricular outflow tract hemangioma in an adolescent. Congenit Heart Dis. Nov–Dec. 2011;6(6):657-60. X-1, X-2. [pmid: 21702885].
3238 Shayan YR, Prendiville JS, Goldman RD. Use of propranolol in treating hemangiomas. Can Fam Physician. Mar. 2011;57(3):302-3. X-2. [pmid: 21402965].
3239 Shields JA, Mashayekhi A, Kligman BE, et al. Vascular tumors of the conjunctiva in 140 cases. Ophthalmology. Sep. 2011;118(9):1747-53. X-1. [pmid: 21788081].
3240 Shukla S, Acharya N, Acharya S, et al. Kasabach merrit syndrome in a third trimester pregnancy. Journal of Medicine. 2011;12(1):66-9. X-1.
3241 Singh P, Mishra NK, Dash HH, et al. Treatment of vertebral hemangiomas with absolute alcohol (ethanol) embolization, cord decompression, and single level instrumentation: a pilot study. Neurosurgery. Jan. 2011;68(1):78-84. discussion. X-1. [pmid: 21099721].
3242 Solomon T, Ninnis J, Deming D, et al. Use of propranolol for treatment of hemangiomas in PHACE syndrome. J Perinatol. Nov. 2011;31(11):739-41. X-1, X-2. [pmid: 22037156].
3243 Soltani AM, Reinisch JF. Algorithmic approach to the management of hemangiomas. J Craniofac Surg. Mar. 2011;22(2):585-8. X-1, X-2. [pmid: 21403532].
3244 Sood D, Mohan N, Singh A, et al. Living donor liver transplantation for giant cavernous hemangioma of liver in a child. Pediatr Transplant. Nov. 2011;15(7):E135-8. X-1. [pmid: 20598089].
3245 Steno J, Bizik I, Stenova J, et al. Subtemporal transtentorial resection of cavernous malformations involving the pyramidal tract in the upper pons and mesencephalon. Acta Neurochir (Wien). Oct. 2011;153(10):1955-62. discussion 62. X-1. [pmid: 21845370].
3246 Suh KY, Rosbe KW, Meyer AK, et al. Extensive airway hemangiomas in two patients without beard hemangiomas. Pediatr Dermatol. May–Jun. 2011;28(3):347-8. X-3, X-4. [pmid: 20561239].
3247 Tadrous R, Ni Mhuirchteagh R, McCaul C. Anaesthesia for caesarean section in a patient with Sturge-Weber syndrome following acute neurological deterioration. Int J Obstet Anesth. Jul. 2011;20(3):259-62. X-1. [pmid: 21315576].
3248 Takemoto J, Yamazaki Y, Sakai K. A case of large bladder hemangioma successfully treated with endoscopic yttrium aluminium garnet laser irradiation. Int J Urol. Dec. 2011;18(12):854-6. X-1. [pmid: 22142464].
3249 Tallen G, Hernaiz Driever P, Degenhardt P, et al. High reliability of scrotal ultrasonography in the management of childhood primary testicular neoplasms. Klin Padiatr. May. 2011;223(3):131-7. X-1. [pmid: 21462100].
3250 Talmon GA, Stanley SM, Lager DJ. Capillary hemangioma of the testis. Int J Surg Pathol. Jun. 2011;19(3):398-400. X-1, X-2. [pmid: 19147509].
3251 Tamagno M, Bibas BJ, Minamoto H, et al. Subglottic and mediastinal hemangioma in a child: treatment with propranolol. J Bras Pneumol. May–Jun. 2011;37(3):416-8. X-2, X-4. [pmid: 21755201].
3252 Tan BH, Leadbitter PH, Aburn NH, et al. Steroid therapy for problematic proliferating haemangioma. N Z Med J. Feb. 11. 2011;124(1329):57-65. X-4. [pmid: 21475361].
3253 Tan ST, Itinteang T, Leadbitter P. Low-dose propranolol for multiple hepatic and cutaneous hemangiomas with deranged liver function. Pediatrics. Mar. 2011;127(3):e772-6. X-2. [pmid: 21357335].
3254 Tan ST, Itinteang T, Leadbitter P. Low-dose propranolol for infantile haemangioma. J Plast Reconstr Aesthet Surg. Mar. 2011;64(3):292-9. X-4. [pmid: 20615772].
3255 Tandon A, Jain B, Tandon R, et al. Infantile Hemangioendothelioma of the Parotid Gland: A Sonographic Diagnosis. Journal of Diagnostic Medical Sonography. 2011;27(3):131-4. PMID: X-1.
3256 Tang V, Daneman A, Navarro OM, et al. Internal hernias in children: spectrum of clinical and imaging findings. Pediatr Radiol. Dec. 2011;41(12):1559-68. X-1. [pmid: 21735180].
3257 Tarantino CC, Vercelli A, Canepari E. Angioma of the chest wall: A report of 2 cases. J Ultrasound. March. 2011;14(1):18-21. X-1. [pmid: 23396649].
3258 Tlougan BE, Gonzalez ME, Orlow SJ. Abortive segmental perineal hemangioma. Dermatol Online J. 2011;17(10):8. X-1, X-2. [pmid: 22031634].
3259 Tolar J, Park IH, Xia L, et al. Hematopoietic differentiation of induced pluripotent stem cells from patients with mucopolysaccharidosis type I (Hurler syndrome). Blood. Jan. 20. 2011;117(3):839-47. X-1. [pmid: 21037085].
3260 Tomazic PV, Stammberger H, Habermann W, et al. Intraoperative medialization of medial rectus muscle as a new endoscopic technique for approaching intraconal lesions. Am J Rhinol Allergy. Sep–Oct. 2011;25(5):363-7. X-1. [pmid: 22186253].
3261 Tsang FH, Lun KS, Cheng LC. Hemangioma of the diaphragm presenting with cardiac tamponade. J Card Surg. Nov. 2011;26(6):620-3. X-1, X-2. [pmid: 22004551].
3262 Vasaiwala R, Sajja K, Setabutr P. Novel management of the microphthalmic orbit in a patient with PHACE syndrome. Ophthal Plast Reconstr Surg. Nov–Dec. 2011;27(6):e156-8. X-2. [pmid: 21629142].
3263 Velayudam K, Paolicchi J. Wolf - Hirschhorn syndrome presenting with intractable epilepsy and distinct unilateral cutaneous finding: A case report. Epilepsy Curr. 2011;(1). X-1.
3264 Verdegaal SH, Bovee JV, Pansuriya TC, et al. Incidence, predictive factors, and prognosis of chondrosarcoma in patients with Ollier disease and Maffucci syndrome: an international multicenter study of 161 patients. Oncologist. 2011;16(12):1771-9. X-1. [pmid: 22147000].
3265 Vinchon M, Leblond P, Caron S, et al. Radiation-induced tumors in children irradiated for brain tumor: a longitudinal study. Childs Nerv Syst. Mar. 2011;27(3):445-53. X-1. [pmid: 21234575].
3266 Weibel L. Vascular anomalies in children. Vasa. Nov. 2011;40(6):439-47. X-1, X-2. [pmid: 22090176].
3267 Weiss I, O TM, Lipari BA, et al. Current treatment of parotid hemangiomas. Laryngoscope. Aug. 2011;121(8):1642-50. X-3, X-4. [pmid: 21766313].
3268 Wester ST, Johnson TE. Echographic evidence of regression of a periocular infantile capillary hemangioma treated with systemic propranolol. Ophthalmic Surg Lasers Imaging. Online. 2011;42:e18-21. X-2. [pmid: 21323190].
3269 Williams K, Woolf R, Morrison D. Periocular lesion in an infant. Bmj. 2011;343:d7461. X-2. [pmid: 22123913].
3270 Wind JJ, Bakhtian KD, Sweet JA, et al. Long-term outcome after resection of brainstem hemangioblastomas in von Hippel-Lindau disease. J Neurosurg. May. 2011;114(5):1312-8. X-1. [pmid: 20932100].
3271 Winland RD. Something is better than nothing. AGD Impact. 2011;39(6):4. PMID: X-1.
3272 Wou K, Chen MF, Mallozzi A, et al. Pregnancy outcomes and ultrasonographic diagnosis in patients with histologically-proven placental chorioangioma. Placenta. Sep. 2011;32(9):671-4. X-1. [pmid: 21745690].
3273 Wu J, Tarabishy B, Hu J, et al. Cortical calcification in Sturge-Weber Syndrome on MRI-SWI: relation to brain perfusion status and seizure severity. J Magn Reson Imaging. Oct. 2011;34(4):791-8. X-1. [pmid: 21769978].
3274 Xu D, O TM, Shartava A, et al. Isolation, characterization, and in vitro propagation of infantile hemangioma stem cells and an in vivo mouse model. J Hematol Oncol. 2011;4:54. X-1. [pmid: 22192404].
3275 Ye C, Pan L, Huang Y, et al. Somatic mutations in exon 17 of the TEK gene in vascular tumors and vascular malformations. J Vasc Surg. Dec. 2011;54(6):1760-8. X-1. [pmid: 21962923].
3276 Ye CS, Pan LX, Huang YB, et al. Clinical analysis of vascular anomalies: a hospital-based retrospective study of 592 patients in southeast China. Chin Med J (Engl). Oct. 2011;124(19):3008-12. X-3, X-4. [pmid: 22040545].
3277 Yeh I, Bruckner AL, Sanchez R, et al. Diffuse infantile hepatic hemangiomas: a report of four cases successfully managed with medical therapy. Pediatr Dermatol. May–Jun. 2011;28(3):267-75. X-3, X-4. [pmid: 21517953].
3278 Yilmaz KB, Canter HI, Vargel I, et al. Use of three-dimensional MRI-angiography in preoperative evaluation and postoperative management of hemangiomas of head and neck region. J Craniofac Surg. Sep. 2011;22(5):1814-8. X-2. [pmid: 21959441].
3279 Yousefi P, Cyrus A, Dorreha F, et al. Effect of hydrochlorothiazide on reducing recurrent abdominal pain in girls with idiopathic hypercalciuria. J Res Med Sci. 2011;16(SPEC. ISSUE):433-6. X-1.
3280 Yu L, Yang SJ. Kaposiform hemangioendothelioma of the spleen in an adult: an initial case report. Pathol Oncol Res. Dec. 2011;17(4):969-72. X-1. [pmid: 21190143].
3281 Yucel E, Akkaya H, Gurkanlar D, et al. Congenital cavernous hemangioma of the skull. Turk Neurosurg. 2011;21(4):645-7. X-1. [pmid: 22194130].
3282 Zheng JW. Invited commentary. J Plast Reconstr Aesthet Surg. Mar. 2011;64(3):299-300. X-1. [pmid: 21071294].
3283 Zheng JW. Comment on efficacy and safety of propranolol in the treatment of parotid hemangioma. Cutan Ocul Toxicol. Dec. 2011;30(4):333-4. X-2, X-4. [pmid: 21609250].
3284 Zur E. Infantile hemangiomas, part 2: topical treatment with beta blockers. Int J Pharm Compd. 2011;15(6):458-63. PMID: X-1, X-2.
3285 Zur E. Infantile Hemangiomas, Part 1: Treatment with Oral Propranolol Hydrochloride. Int J Pharm Compd. 2011;15(5):358-66. PMID: X-2.
3286 Derm Dx. Clinical Advisor. 2012;15(6):53. PMID: X-6.
3287 Endgames. Bmj. 2012;344(7842):56-46. PMID: X-2.
3288 Abdellatif A. Ultrasound-guided ilioinguinal/iliohypogastric nerve blocks versus caudal block for postoperative analgesia in children undergoing unilateral groin surgery. Saudi J Anaesth. October–December. 2012;6(4):367-72. X-1. [pmid: 23493806].
3289 Adeyiga AO, Lee EY, Eisenberg RL. Focal hepatic masses in pediatric patients. AJR Am J Roentgenol. Oct. 2012;199(4):W422-40. X-1. [pmid: 22997391].
3290 Adhisivam B, Femitha P, Joy R, et al. Born with a balloon. J Pediatr. Aug. 2012;161(2):366-e1. X-1, X-2. [pmid: 22494874].
3291 Admani S, Krakowski AC, Nelson JS, et al. Beneficial effects of early pulsed dye laser therapy in individuals with infantile hemangiomas. Dermatol Surg. Oct. 2012;38(10):1732-8. X-3, X-4. [pmid: 22776100].
3292 Ajler P, Goldschmidt E, Bendersky D, et al. Sellar hemangioblastoma mimicking a macroadenoma. Acta Neurol Taiwan. Dec. 2012;21(4):176-9. X-1. [pmid: 23329549].
3293 Akcay A, Karakas Z, Saribeyoglu ET, et al. Infantile hemangiomas, complications and follow-up. Indian Pediatr. Oct. 2012;49(10):805-9. X-3, X-4. [pmid: 22791668].
3294 Akhtar S, Shamim AA, Ghaffar S, et al. Adult laryngeal haemangioma; a rare entity. J Pak Med Assoc. Feb. 2012;62(2):173-4. X-1. [pmid: 22755385].
3295 Albinana V, Recio-Poveda L, Zarrabeitia R, et al. Propranolol as antiangiogenic candidate for the therapy of hereditary haemorrhagic telangiectasia. Thromb Haemost. Jul. 2012;108(1):41-53. X-1. [pmid: 22552254].
3296 Alcantara Gonzalez J, Boixeda P, Truchuelo Diez MT, et al. Ablative fractional yttrium-scandium-gallium-garnet laser for scarring residual haemangiomas and scars secondary to their surgical treatment. J Eur Acad Dermatol Venereol. Apr. 2012;26(4):477-82. X-4. [pmid: 21564327].
3297 Aletaha M, Salour H, Bagheri A, et al. Successful treatment of orbital hemangioma with propranolol in a 5-year-old girl. Orbit. Feb. 2012;31(1):18-20. X-1, X-2. [pmid: 22132796].
3298 Al-Holou WN, O’Lynnger TM, Pandey AS, et al. Natural history and imaging prevalence of cavernous malformations in children and young adults. J Neurosurg Pediatr. Feb. 2012;9(2):198-205. X-1. [pmid: 22295927].
3299 Alsuwaidan S. PHACES syndrome in association with airway hemangioma: First report from Saudi Arabia and literature review. Ann Thorac Med. January–March. 2012;7(1):44-7. X-2. [pmid: 22347351].
3300 Altin H, Alp H, Sap F, et al. PHACE syndrome with growth hormone deficiency and absence of bilateral internal carotid arteries: a case report. Pediatr Dermatol. May–Jun. 2012;29(3):316-9. X-1, X-2. [pmid: 22010790].
3301 Ammerman RT, Peugh JL, Putnam FW, et al. Predictors of treatment response in depressed mothers receiving in-home cognitive-behavioral therapy and concurrent home visiting. Behav Modif. Jul. 2012;36(4):462-81. X-1. [pmid: 22718282].
3302 Ang M, Lee SY. Multifocal photodynamic therapy for diffuse choroidal hemangioma. Clin Ophthalmol. 06. Sep. 2012;6(1):1467-9. X-1. [pmid: 23055665].
3303 Annagur A, Altunhan H, Konak M, et al. Successful use of topical “Ankaferd Blood Stopper” for repetitive bleedings in an infant with infantile hemangioma. Int J Clin Exp Med. 15. Sep. 2012;5(4):342-5. X-2. [pmid: 22993655].
3304 Ardelean MA, Schimke C, Schimpl G. Treatment of hemangiomas with topical beta blockers. European Surgery - Acta Chirurgica Austriaca. June. 2012;44:91. PMID: X-4.
3305 Arneja JS. Pharmacologic therapies for infantile hemangioma: is there a rational basis?. Plast Reconstr Surg. Apr. 2012;129(4):724e-5e. author reply 5e–7e. X-3, X-4. [pmid: 22456390].
3306 Attash SM, Ali MS, Al-Nuaimy HA. Isolated cavernous haemangioma of the stomach in a 3-year-old child: an unusual cause of upper GI bleeding. BMJ Case Rep. 2012;2012. X-1. [pmid: 23045447].
3307 Avallone AN, Avallone MA, Share S, et al. Epithelioid hemangioma-a rare scrotal tumor of childhood. Urology. Sep. 2012;80(3):707-9. X-2. [pmid: 22698477].
3308 Baird C, Blalock S, Bengur R, et al. Right atrial hemangioma in the newborn: Utility of fetal imaging. Ann Pediatr Cardiol. January–June. 2012;5(1):81-4. X-1. [pmid: 22529610].
3309 Bartosiewicz K, Tuziak M, Stecewicz I, et al. Klippel-trenaunay syndrome as a cause of the lower extremities enlargement in infants - a diagnostic dilemma. Zespol Klippel-Trenaunay’A Jako Jedna Z Przyczyn Przerostu Konczyn U Niemowla{ogonek}t - Trudnosci Diagnostyczne. Przeglad Pediatryczny. 2012;42(3):157-9. X-1, X-2.
3310 Bartosiewicz K, Tuziak M, Stecewicz I, et al. Klippel-trenaunay syndrome as a cause of the lower extremities enlargement in infants - a diagnostic dilemma. Przeglad Pediatryczny. 2012;42(3):157-9. PMID: X-1.
3311 Bauland CG, Smit JM, Scheffers SM, et al. Similar risk for hemangiomas after amniocentesis and transabdominal chorionic villus sampling. J Obstet Gynaecol Res. Feb. 2012;38(2):371-5. X-1, X-3. [pmid: 22229643].
3312 Behr GG, Fishman SJ, Caty MG, et al. Hepatic mesenchymal hamartoma and infantile hemangioma: a rare association. J Pediatr Surg. Mar. 2012;47(3):448-52. X-1, X-3. [pmid: 22424336].
3313 Ben-Amitai D, Halachmi S, Zvulunov A, et al. Hemangiomas of the nasal tip treated with propranolol. Dermatology. 2012;225(4):371-5. X-4. [pmid: 23428617].
3314 Betlloch-Mas I, Martinez-Miravete MT, Lucas-Costa A, et al. Outpatient treatment of infantile hemangiomas with propranolol: a prospective study. Actas Dermosifiliogr. Nov. 2012;103(9):806-15. X-4. [pmid: 22727954].
3315 Bieniek R, Godzinski J, Bieniek A. The treatment of infantile hemangiomas. Leczenie naczyniakow krwionosnych dzieciecych. [Polish, English]. Przegl Dermatol. 2012;99(4):420. X-11.
3316 Bingham MM, Saltzman B, Vo NJ, et al. Propranolol reduces infantile hemangioma volume and vessel density. Otolaryngol Head Neck Surg. Aug. 2012;147(2):338-44. X-3, X-4. [pmid: 22691693].
3317 Blei F. Oral prednisolone for infantile hemangioma: efficacy and safety using a standardized treatment protocol. Plast Reconstr Surg. May. 2012;129(5):840e-1e. author reply 1e. X-3, X-4. [pmid: 22544114].
3318 Bonifazi E. Juvenile xanthogranuloma regresses more rapidly than hemangioma. European Journal of Pediatric Dermatology. July–September. 2012;22(3):225. X-1.
3319 Bonniaud B, Martin SP, Bonnet C, et al. Safe treat ment of infantile haemangiomas with propranolol despite baseline bradycardia. European Journal of Pediatric Dermatology. March. 2012;22(1):38-9. X-4.
3320 Bozena DB. HEMANGIOL STUDY: The first worldwide dose-effect study concerning propranolol in infantile hemangiomas. Badanie HEMANGIOL - pierwsze ogolnoswiatowe badanie zaleznosci dawka-efekt dotyczace stosowania propranololu u pacjentow z naczyniakami niemowlecymi. [Polish, English]. Przegl Dermatol. 2012;99(4):419. X-11.
3321 Bruscino N, Bonan P, Cannarozzo G, et al. Laser use in infantile hemangiomas, when and how. Dermatol Ther. Jul–Aug. 2012;25(4):314-21. X-1, X-2. [pmid: 22950558].
3322 Burroni L, Borsari G, Pichierri P, et al. Preoperative diagnosis of orbital cavernous hemangioma: a 99mTc-RBC SPECT study. Clin Nucl Med. Nov. 2012;37(11):1041-6. X-1. [pmid: 23047756].
3323 Callahan AB, Yoon MK. Infantile hemangiomas: A review. Saudi J Ophthalmol. July. 2012;26(3):283-91. X-1, X-2. [pmid: 23961007].
3324 Cavalli R, Buffon RB, de Souza M, et al. Tumor lysis syndrome after propranolol therapy in ulcerative infantile hemangioma: rare complication or incidental finding?. Dermatology. 2012;224(2):106-9. X-2. [pmid: 22516868].
3325 Chang CS, Wong A, Rohde CH, et al. Management of lip hemangiomas: Minimizing peri-oral scars. J Plast Reconstr Aesthet Surg. Feb. 2012;65(2):163-8. X-3, X-4. [pmid: 21937296].
3326 Chang YT, Lin JY, Lee JY, et al. Comparative mid-term results between inguinal herniotomy and single-port laparoscopic herniorrhaphy for pediatric inguinal hernia. Surg Laparosc Endosc Percutan Tech. Dec. 2012;22(6):526-31. X-1. [pmid: 23238381].
3327 Charters L. Beta-blocker explored. Ophthalmology Times. 2012;37(7):22. PMID: X-1.
3328 Chaudry MI, Manzoor MU, Turner RD, et al. Diagnostic imaging of vascular anomalies. Facial Plast Surg. Dec. 2012;28(6):563-74. X-1. [pmid: 23188683].
3329 Chim H, Armijo BS, Miller E, et al. Propranolol induces regression of hemangioma cells through HIF-1alpha-mediated inhibition of VEGF-A. Ann Surg. Jul. 2012;256(1):146-56. X-1, X-3. [pmid: 22580939].
3330 Chisholm KM, Chang KW, Truong MT, et al. beta-Adrenergic receptor expression in vascular tumors. Mod Pathol. Nov. 2012;25(11):1446-51. X-1. [pmid: 22743651].
3331 Chisti M, Banka N, Alfadley A. Pallor sign: an indicator of hemangioma in evolution. J Cutan Med Surg. Nov–Dec. 2012;16(6):451-2. X-2. [pmid: 23149206].
3332 Chiu YE, Drolet BA, Blei F, et al. Variable response to propranolol treatment of kaposiform hemangioendothelioma, tufted angioma, and Kasabach-Merritt phenomenon. Pediatr Blood Cancer. Nov. 2012;59(5):934-8. X-1. [pmid: 22648868].
3333 Christou EM, Wargon O. Effect of captopril on infantile haemangiomas: a retrospective case series. Australas J Dermatol. Aug. 2012;53(3):216-8. X-4. [pmid: 22671578].
3334 Chun YH, Moon CJ, Yoon JS, et al. Successful treatment of infantile subglottic hemangioma with oral propranolol. Clin Pediatr (Phila). Oct. 2012;51(10):983-6. X-3, X-4. [pmid: 21642231].
3335 Chung SH, Park DH, Jung HL, et al. Successful and safe treatment of hemangioma with oral propranolol in a single institution. Korean J Pediatr. May. 2012;55(5):164-70. X-4. [pmid: 22670151].
3336 Cichon K, Schon CA. Influences on the amount of intraperitoneal haemorrhage after blunt liver injury: a retrospective autopsy study. Eur J Gastroenterol Hepatol. Nov. 2012;24(11):1333-40. X-1. [pmid: 22872075].
3337 Cobb AR, Sebire NJ, Anderson J, et al. Congenital malignant rhabdoid tumor of the scalp. J Craniomaxillofac Surg. Dec. 2012;40(8):e258-60. X-1. [pmid: 22079123].
3338 Constantinides J, Prowse P, Gorst C, et al. Adrenal suppression following steroid treatment of infantile hemangiomas: expediting the move toward propranolol?. Plast Reconstr Surg. Feb. 2012;129(2):377e-8e. X-4. [pmid: 22286472].
3339 Couto RA, Maclellan RA, Zurakowski D, et al. Infantile hemangioma: clinical assessment of the involuting phase and implications for management. Plast Reconstr Surg. Sep. 2012;130(3):619-24. X-3, X-4. [pmid: 22575857].
3340 Dai Y, Hou F, Buckmiller L, et al. Decreased eNOS protein expression in involuting and propranolol-treated hemangiomas. Arch Otolaryngol Head Neck Surg. Feb. 2012;138(2):177-82. X-1. [pmid: 22351865].
3341 Dalmonte P, Granata C, Fulcheri E, et al. Intra-articular venous malformations of the knee. J Pediatr Orthop. Jun. 2012;32(4):394-8. X-1. [pmid: 22584841].
3342 Daramola OO, Chun RH, Kerschner JE. Surgical management of auricular infantile hemangiomas. Arch Otolaryngol Head Neck Surg. Jan. 2012;138(1):72-5. X-4. [pmid: 22249633].
3343 de Oliveira DA, Valenca MM. The characteristics of head pain in response to an experimental cold stimulus to the palate: An observational study of 414 volunteers. Cephalalgia. Nov. 2012;32(15):1123-30. X-1. [pmid: 22914815].
3344 Denzer F, Denzer C, Lennerz BS, et al. A case of phace syndrome and acquired hypopituitarism?. Int J Pediatr Endocrinol. 30. Jun. 2012;2012(1). X-2.
3345 Di Fiore JM, Kaffashi F, Loparo K, et al. The relationship between patterns of intermittent hypoxia and retinopathy of prematurity in preterm infants. Pediatr Res. Dec. 2012;72(6):606-12. X-1. [pmid: 23037873].
3346 Dilek N, Ustuner P, Saral Y. Solitar Y fa UN tail nevus without spinal dysraphism: A case report. European Journal of Pediatric Dermatology. March. 2012;22(1):19. X-1.
3347 Dinand V, Yadav SP, Bellanne-Chantelot C, et al. Hepatic hemangioendothelioma in an infant with severe congenital neutropenia. J Pediatr Hematol Oncol. May. 2012;34(4):298-300. X-1. [pmid: 22510773].
3348 Doege C, Pritsch M, Fruhwald MC, et al. An association between infantile haemangiomas and erythropoietin treatment in preterm infants. Arch Dis Child Fetal Neonatal Ed. Jan. 2012;97(1):F45-9. X-3. [pmid: 21546402].
3349 Drolet BA, Pope E, Juern AM, et al. Gastrointestinal bleeding in infantile hemangioma: a complication of segmental, rather than multifocal, infantile hemangiomas. J Pediatr. Jun. 2012;160(6):1021-6.e3. X-3, X-4. [pmid: 22240112].
3350 Durham KC, Hebert AA. A beta-Antagonist for the treatment of infantile hemangiomas. Clinical Practice. November. 2012;9(6):611-3. PMID: X-3, X-4.
3351 Durr ML, Meyer AK, Huoh KC, et al. Airway hemangiomas in PHACE syndrome. Laryngoscope. Oct. 2012;122(10):2323-9. X-3, X-4. [pmid: 22865344].
3352 Dyme JL, Thampan A, Han EJ, et al. Propranolol for infantile haemangiomas: initiating treatment on an outpatient basis. Cardiol Young. Aug. 2012;22(4):424-9. X-4. [pmid: 22166728].
3353 Engelmann C, Mutschler U, Zoller C, et al. Systematic assessment of propranolol therapy of infancy hemangiomas. A new online tool. Monatsschr Kinderheilkd. August. 2012;160:60. X-6.
3354 Ercan CM, Coksuer H, Karasahin KE, et al. Combined approach in a large placental chorioangioma case with intratumoral alcohol injection, cordocentesis, IU transfusion, and amnioreduction. Fetal Pediatr Pathol. Dec. 2012;31(6):374-8. X-1. [pmid: 22432544].
3355 Feng J, Wu Q, Zhang D, et al. Hippocampal impairments are associated with intermittent hypoxia of obstructive sleep apnea. Chin Med J (Engl). Feb. 2012;125(4):696-701. X-1. [pmid: 22490498].
3356 Feng Y, Ma Z. Transscleral diode photocoagulation of large retinal and choroidal vascular lesions. PLoS One. 2012;7(7):e39340. X-1. [pmid: 22792170].
3357 Figueiredo LM, Trindade SC, Sarmento VA, et al. Extensive gingival hemangioma in a 10-year-old boy treated by sclerotherapy: a case report. J Oral Maxillofac Surg. Nov. 2012;70(11):2585-9. X-1, X-2. [pmid: 22305874].
3358 Franchi-Abella S, Gorincour G, Avni F, et al. Hepatic haemangioma-prenatal imaging findings, complications and perinatal outcome in a case series. Pediatr Radiol. Mar. 2012;42(3):298-307. X-3, X-4. [pmid: 21928049].
3359 Freeman I, Ganesan K, Emmerson AJ. Kasabach-Merritt syndrome in a term neonate. Arch Dis Child Fetal Neonatal Ed. Mar. 2012;97(2):F139-40. X-1, X-2. [pmid: 21697235].
3360 Fuchimoto Y, Morikawa N, Kuroda T, et al. Vincristine, actinomycin D, cyclophosphamide chemotherapy resolves Kasabach-Merritt syndrome resistant to conventional therapies. Pediatr Int. Apr. 2012;54(2):285-7. X-1. [pmid: 22507155].
3361 Garcia-Monaco R, Giachetti A, Peralta O, et al. Kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon: successful treatment with embolization and vincristine in two newborns. J Vasc Interv Radiol. Mar. 2012;23(3):417-22. X-1. [pmid: 22365299].
3362 Garcia-Nieto V, Monge-Zamorano M, Gonzalez-Garcia M, et al. Effect of thiazides on bone mineral density in children with idiopathic hypercalciuria. Pediatr Nephrol. Feb. 2012;27(2):261-8. X-1. [pmid: 21874585].
3363 Gawrych E, Walecka A, Kwas A, et al. Coexistence of splenic hemangioma and vascular malformation of the lower extremity in a child: a case report. Turk J Pediatr. Jul–Aug. 2012;54(4):436-9. X-1, X-2. [pmid: 23692730].
3364 Geronemus RG. Commentary: beneficial effects of early pulsed dye laser therapy in patients with infantile hemangiomas. Dermatol Surg. Oct. 2012;38(10):1739-40. X-3, X-4. [pmid: 23030371].
3365 Ginat DT, Meyers SP. Intracranial lesions with high signal intensity on T1-weighted MR images: differential diagnosis. Radiographics. Mar–Apr. 2012;32(2):499-516. X-1. [pmid: 22411945].
3366 Grimmer JF, Williams MS, Pimentel R, et al. Hemangioma is associated with atopic disease. Otolaryngol Head Neck Surg. Feb. 2012;146(2):206-9. X-3. [pmid: 22031593].
3367 Gross BC, Janus JR, Orvidas LJ. Response of infantile airway and facial hemangiomas to propranolol in a patient with PHACE syndrome. Int J Pediatr Otorhinolaryngol Extra. December. 2012;7(4):183-9. X-2.
3368 Hadaschik E, Scheiba N, Engstner M, et al. High levels of beta2-adrenoceptors are expressed in infantile capillary hemangiomas and may mediate the therapeutic effect of propranolol. J Cutan Pathol. Sep. 2012;39(9):881-3. X-3, X-4. [pmid: 22764832].
3369 Haddy N, Mousannif A, Paoletti C, et al. Radiotherapy as a risk factor for malignant melanoma after childhood skin hemangioma. Melanoma Res. Feb. 2012;22(1):77-85. X-1. [pmid: 22082956].
3370 Haggstrom AN, Beaumont JL, Lai JS, et al. Measuring the severity of infantile hemangiomas: instrument development and reliability. Arch Dermatol. Feb. 2012;148(2):197-202. X-1. [pmid: 22351819].
3371 Harjai MM, Jha M. Intralesional bleomycin and sodium tetradecyl sulphate for haemangiomas and lymphangiomas. Afr J Paediatr Surg. Jan–Apr. 2012;9(1):47-51. X-4. [pmid: 22382104].
3372 Haugen TW, Wood WE, Helwig C. Postcricoid vascular abnormalities: hemangiomas, venous malformations, or anatomic variant. Int J Pediatr Otorhinolaryngol. Jun. 2012;76(6):805-8. X-1. [pmid: 22424609].
3373 Heah SS, Ng SY, Leong KF, et al. Two cases of congenita l haemangiomas with serious complications. European Journal of Pediatric Dermatology. March. 2012;22(1):42-3. X-2.
3374 Hiraoka K, Mota De Queiroz A, Aparecida Marinho S, et al. Sclerotherapy with monoethanolamine oleate in benign oral vascular lesions. Minerva Stomatol. Jan–Feb. 2012;61(1–2):31-6. X-1. [pmid: 22274308].
3375 Hogeling M. Propranolol for Infantile Hemangiomas: A Review. Current Dermatology Reports. 2012;1(4):179-85. PMID: X-1, X-2.
3376 Hom S, Modi V, Chandran L, et al. Stridor in the neonate. Contemp Pediatr. 2012;29(2):42-7. PMID: X-2.
3377 Hon LQ, Connolly DJA, Chan JTK, et al. Pediatric orbit and periorbital pathology: A pictorial review of imaging strategies using CT and MRI. Journal of Pediatric Neuroradiology. 2012;1(1):7-17. PMID: X-1, X-2.
3378 Hong E, Fischer G. Propranolol for recalcitrant ulcerated hemangioma of infancy. Pediatr Dermatol. Jan–Feb. 2012;29(1):64-7. X-3, X-4. [pmid: 21854419].
3379 Hoornweg MJ, Smeulders MJ, Ubbink DT, et al. The prevalence and risk factors of infantile haemangiomas: a case-control study in the Dutch population. Paediatr Perinat Epidemiol. Mar. 2012;26(2):156-62. X-3. [pmid: 22324502].
3380 Hsu TC, Wang JD, Chen CH, et al. Treatment with propranolol for infantile hemangioma in 13 Taiwanese newborns and young infants. Pediatr Neonatol. Apr. 2012;53(2):125-32. X-4. [pmid: 22503260].
3381 Hunter JB. Infant tongue lesions: A case presentation and review of the literature. International Journal of Pediatric Otorhinolaryngology Extra. September. 2012;7(3):122-5. PMID: X-1, X-4.
3382 Imteyaz H, Karnsakul W, Levine MA, et al. Unusual case of hypothyroidism in an infant with hepatic hemangioma. J Pediatr Gastroenterol Nutr. May. 2012;54(5):692-5. X-1, X-2. [pmid: 21716131].
3383 Jahnel J, Lackner H, Reiterer F, et al. Kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon: from vincristine to sirolimus. Klin Padiatr. Oct. 2012;224(6):395-7. X-1. [pmid: 23070861].
3384 Jain V, Roychoudhury S, Chadha R, et al. Variable response to propranolol therapy for infantile hemangiomas. Indian J Dermatol. March–April. 2012;57(2):126-7. X-2. [pmid: 22615510].
3385 James CA, Schwartz DR, Roberts KE, et al. Childhood Emotional Abuse and Psychological Distress in Gay and Bisexual Men. J Aggress Maltreat Trauma. 2012;21(8):851-69. PMID: X-1.
3386 Ji Y, Chen S, Xiao X, et al. beta-blockers: A novel class of antitumor agents. OncoTargets and Therapy. 2012;5:391-401. PMID: X-1, X-2. [pmid: 23226026].
3387 Ji Y, Li K, Xiao X, et al. Effects of propranolol on the proliferation and apoptosis of hemangioma-derived endothelial cells. J Pediatr Surg. Dec. 2012;47(12):2216-23. X-1. [pmid: 23217879].
3388 Jiang RS, Hu R. Successful treatment of Kasabach-Merritt syndrome arising from kaposiform hemangioendothelioma by systemic corticosteroid therapy and surgery. Int J Clin Oncol. Oct. 2012;17(5):512-6. X-1. [pmid: 21947597].
3389 Kalicki B, Jung A, Ring F, et al. Infrared thermography assessment of infantile hemangjoma treatment by propanolol. Thermology International. July. 2012;22(3):102-3. X-3, X-4.
3390 Kalicki B, Jung A, Rustecka A, et al. Evaluation of skin changes using infrared thermography. Thermology International. April. 2012;22(2):69-70. X-6.
3391 Kalicki B, Jung A, Rustecka A, et al. Infantile hemangiomas - The possibility of using infrared thermography in the assessment of propranolol efficacy-preliminary study. Thermology International. April. 2012;22(2):71. X-6.
3392 Katona G, Csakanyi Z, Gacs E, et al. Propranolol for infantile haemangioma: striking effect in the first weeks. Int J Pediatr Otorhinolaryngol. Dec. 2012;76(12):1746-50. X-4. [pmid: 22944359].
3393 Keating LJ, Soares GM, Muratore CS. Rapidly involuting congenital hemangioma. Med Health R I. May. 2012;95(5):149. 52. X-1. [pmid: 22808633].
3394 Kelly JB 3rd, Makkar HS. Ethics in pediatric dermatology. Clin Dermatol. Sep–Oct. 2012;30(5):471-5. X-1. [pmid: 22902215].
3395 Kerl K, Nowacki M, Leuschner I, et al. Infantile fibrosarcoma - an important differential diagnosis of congenital vascular tumors. Pediatr Hematol Oncol. Sep. 2012;29(6):545-8. X-1. [pmid: 22812410].
3396 Khan SN, Sepahdari AR. Orbital masses: CT and MRI of common vascular lesions, benign tumors, and malignancies. Saudi J Ophthalmol. October. 2012;26(4):373-83. X-2. [pmid: 23961022].
3397 Kim DH, Choi JH, Lee JH, et al. PHACE association with intracranial, oropharyngeal hemangiomas, and an atypical patent ductus arteriosus arising from the tortuous left subclavian artery in a premature infant. Korean J Pediatr. January. 2012;55(1):29-33. X-2. [pmid: 22359528].
3398 Kim KH, Chung SB, Kong DS, et al. Neurocutaneous melanosis associated with Dandy-Walker complex and an intracranial cavernous angioma. Childs Nerv Syst. Feb. 2012;28(2):309-14. X-1. [pmid: 22134415].
3399 Kiratli H, Uzun S, Tarlan B, et al. Recurrent subconjunctival hemorrhage due to cavernous hemangioma of the conjunctiva. Can J Ophthalmol. Jun. 2012;47(3):318-20. X-1. [pmid: 22687315].
3400 Kivelev J, Koskela E, Setala K, et al. Long-term visual outcome after microsurgical removal of occipital lobe cavernomas. J Neurosurg. Aug. 2012;117(2):295-301. X-1. [pmid: 22702480].
3401 Kleber CJ, Spiess A, Kleber JB, et al. Urinary matrix metalloproteinases-2/9 in healthy infants and haemangioma patients prior to and during propranolol therapy. Eur J Pediatr. Jun. 2012;171(6):941-6. X-2. [pmid: 22203431].
3402 Knott EM, Valusek PA, St Peter SD. Laparoscopic excision of a giant splenic vascular tumor. J Pediatr Surg. Jul. 2012;47(7):E21-3. X-1, X-2. [pmid: 22813826].
3403 Koike T, Yanagimachi N, Ishiguro H, et al. High incidence of radiation-induced cavernous hemangioma in long-term survivors who underwent hematopoietic stem cell transplantation with radiation therapy during childhood or adolescence. Biol Blood Marrow Transplant. Jul. 2012;18(7):1090-8. X-1. [pmid: 22198541].
3404 Kota SK, Meher LK, Kota SK, et al. Sturge-Weber syndrome: presentation with partial hypopituitarism. J Pediatr Endocrinol Metab. 2012;25(7–8):785-9. X-1. [pmid: 23155711].
3405 Kotecha UH, Movva S, Puri RD, et al. Trichohepatoenteric syndrome: Founder mutation in Asian Indians. Molecular Syndromology. August. 2012;3(2):89-93. X-1. [pmid: 23326254].
3406 Kulungowski AM, Alomari AI, Chawla A, et al. Lessons from a liver hemangioma registry: subtype classification. J Pediatr Surg. Jan. 2012;47(1):165-70. X-3. [pmid: 22244411].
3407 Kupeli S. Use of propranolol for infantile hemangiomas. Pediatr Hematol Oncol. Apr. 2012;29(3):293-8. X-4. [pmid: 22303875].
3408 Kupeli S, Cimen D, Kupeli BY. Successful treatment with propranolol in a patient with a segmental hemangioma: A case report. Segmental Hemanjiyomun propranolol ile Basari{dotless}li{dotless} Tedavisi: Bir Olgu Sunumu. Turk J Haematol. 2012;29(2):170-3. X-2. [pmid: 24744649].
3409 Kupeli S, Cimen D, Kupeli BY. Successful treatment with propranolol in a patient with a segmental hemangioma: A case report. Turkish Journal of Hematology. 2012;29(2):170-3. PMID: X-4. [pmid: 24744649].
3410 Lanoel A, Tosi V, Bocian M, et al. Perianal ulcers on a segmental hemangioma with minimal or arrested growth. Actas Dermosifiliogr. Nov. 2012;103(9):820-3. X-2. [pmid: 22421500].
3411 Lauren C, Garzon MC. Treatment of infantile hemangiomas. Pediatr Ann. Aug. 2012;41(8):1-7. X-1, X-2. [pmid: 22881415].
3412 Leavitt DA, Hottinger DG, Reed RC, et al. A case series of genital vascular anomalies in children and their management: lessons learned. Urology. Oct. 2012;80(4):914-8. X-3, X-4. [pmid: 22951002].
3413 Lee JJ, Lin LY, Hsieh SW, et al. Successful treatment of Kasabach-Merritt phenomenon with intralesional corticosteroid injections: a case series. Ann Plast Surg. Dec. 2012;69(6):627-32. X-1. [pmid: 23154333].
3414 Lee N, Isenstein A, Zedek D, et al. A case of childhood subcutaneous pyogenic granuloma (lobular capillary hemangioma). Clin Pediatr (Phila). Jan. 2012;51(1):88-90. X-1, X-2. [pmid: 21196416].
3415 Lembo S, Balato A, Raimondo A, et al. A preterm infant with benign neonatal hemangiomatosis and persistent patent ductus arteriosus: a curious comorbidity. G Ital Dermatol Venereol. Jun. 2012;147(3):321-4. X-1, X-3. [pmid: 22648333].
3416 Levy ML. Propranolol for infantile hemangiomas. Glob Adv Health Med. 2012;1(2):14-6. X-2. [pmid: 24278812].
3417 Liu C, Qin ZP, Fan ZN, et al. New treatment strategy for granulomatous epulis: intralesional injection of propranolol. Med Hypotheses. Feb. 2012;78(2):327-9. X-1. [pmid: 22133559].
3418 Liu Y, Huang ZH, Xu SQ, et al. Value of histopathologic examination in differential diagnosis of infantile cholestasis. World Chinese Journal of Digestology. 2012;20(23):2200-4. X-1.
3419 Maguiness SM, Frieden IJ. Management of difficult infantile haemangiomas. Arch Dis Child. Mar. 2012;97(3):266-71. X-1, X-2, X-4. [pmid: 22215816].
3420 Mankowski B, Osmola-Mankowska A, Olszanski R, et al. Squamous cell carcinoma as a long-term effect after skin vascular malformation radiotherapy. Postepy Dermatol Alergol. 2012;29(6):471-4. X-1.
3421 Mao XH, Wang JY, Yan JL. Topical imiquimod treatment of cutaneous vascular disorders in pediatric patients: clinical evaluation on the efficacy and safety. J Zhejiang Univ Sci B. Sep. 2012;13(9):745-50. X-4. [pmid: 22949365].
3422 Martens D, Oster I, Gottschlling S, et al. Cerebral MRI and EEG studies in the initial management of pediatric headaches. Swiss Med Wkly. 2012;142:w13625. X-1. [pmid: 22782255].
3423 Martinez-Escaname M, Castillo-Martinez C, Torres-Alvarez B, et al. Diffuse neonatal hemangiomatosis: a case report. Int J Dermatol. Oct. 2012;51(10):1228-30. X-1, X-2. [pmid: 21470219].
3424 Masnari O, Landolt MA, Roessler J, et al. Self- and parent-perceived stigmatisation in children and adolescents with congenital or acquired facial differences. J Plast Reconstr Aesthet Surg. Dec. 2012;65(12):1664-70. X-3. [pmid: 22770573].
3425 Matuszczak E, Reszec J, Debek W, et al. Is littoral cell angioma of the spleen as rare as previously believed in the pediatric population?. Folia Histochem Cytobiol. 2012;50(3):480-5. X-1. [pmid: 23042283].
3426 Mavrogenis AF, Rossi G, Calabro T, et al. The role of embolization for hemangiomas. Musculoskelet Surg. Aug. 2012;96(2):125-35. X-1, X-2. [pmid: 22684541].
3427 Mazroa JA, Elrakhawy MM. What can 3D CT angiography add in evaluation of facial vascular lesions?. Egyptian Journal of Radiology and Nuclear Medicine. March. 2012;43(1):67-75. X-3, X-4.
3428 McCanlies EC, Fekedulegn D, Mnatsakanova A, et al. Parental occupational exposures and autism spectrum disorder. J Autism Dev Disord. Nov. 2012;42(11):2323-34. X-1. [pmid: 22399411].
3429 McMahon P, Oza V, Frieden IJ. Topical timolol for infantile hemangiomas: putting a note of caution in “cautiously optimistic”. Pediatr Dermatol. Jan–Feb. 2012;29(1):127-30. X-1, X-2. [pmid: 22256996].
3430 Mikhail MA, Ng J, Mathew J, et al. Von Hippel Lindau disease: keep it in the family. BMJ Case Rep. 2012;2012. X-1. [pmid: 23242101].
3431 Mills SA, Oh MC, Rutkowski MJ, et al. Supratentorial hemangioblastoma: clinical features, prognosis, and predictive value of location for von Hippel-Lindau disease. Neuro Oncol. Aug. 2012;14(8):1097-104. X-1. [pmid: 22723428].
3432 Moon SB, Jung SM, Kwon CH, et al. Posteromedial diaphragmatic hernia following pediatric liver transplantation. Pediatr Transplant. Jun. 2012;16(4):E106-9. X-1. [pmid: 21235708].
3433 Moreira Guimaraes Penido MG, de Sousa Tavares M, Campos Linhares M, et al. Longitudinal study of bone mineral density in children with idiopathic hypercalciuria. Pediatr Nephrol. Jan. 2012;27(1):123-30. X-1. [pmid: 21779854].
3434 Moss HB, Sines DT, Blatt J, et al. Epithelioid hemangioma responsive to oral propranolol. Ophthal Plast Reconstr Surg. Jul–Aug. 2012;28(4):e88-90. X-1. [pmid: 22186982].
3435 Murthy GJ, Goswami M. Management of adult onset orbital hemangioma by oral propranalol: a case report. Orbit. Oct. 2012;31(5):373-5. X-1. [pmid: 22877318].
3436 Nolan M, Hartin CW Jr, Pierre J, et al. Life-threatening hemorrhage from a congenital hemangioma caused by birth trauma. J Pediatr Surg. May. 2012;47(5):1016-8. X-1. [pmid: 22595593].
3437 Ogawa A, Miyaji K, Yamadori I, et al. Safety and efficacy of epoprostenol therapy in pulmonary veno-occlusive disease and pulmonary capillary hemangiomatosis. Circ J. 2012;76(7):1729-36. X-1. [pmid: 22481098].
3438 Ozsahin M, Uslu M, Inanmaz E, et al. Intramuscular hemangioma of flexor digitorum brevis muscle. Am J Phys Med Rehabil. Oct. 2012;91(10):910. X-1. [pmid: 21904191].
3439 Parlak AH, Atasoy HI, Polat M, et al. Is there a potential role of photo herapy for development of infantile hemangiomas: A case report. European Journal of Pediatric Dermatology. March. 2012;22(1):41. X-2.
3440 Patiroglu T, Sarici D, Unal E, et al. Cerebellar hemangioblastoma associated with diffuse neonatal hemangiomatosis in an infant. Childs Nerv Syst. Oct. 2012;28(10):1801-5. X-1. [pmid: 22820755].
3441 Peralta L, Rocha G, Morais P, et al. Skin disorders in the neonatal intensive care unit of a central hospital. Eur J Dermatol. Jan–Feb. 2012;22(1):88-92. X-1. [pmid: 22157797].
3442 Phi JH, Kim SK, Cho A, et al. Intracranial capillary hemangioma: extra-axial tumorous lesions closely mimicking meningioma. J Neurooncol. Aug. 2012;109(1):177-85. X-1. [pmid: 22544652].
3443 Pompa V, Brauner E, Bresadola L, et al. Treatment of facial vascular malformations with embolisation and surgical resection. Eur Rev Med Pharmacol Sci. Mar. 2012;16(3):407-13. X-1. [pmid: 22530359].
3444 Portnow LH, Scott M, Morris CG, et al. Fractionated radiotherapy in the management of benign vascular tumors. Am J Clin Oncol. Dec. 2012;35(6):557-61. X-1. [pmid: 21659831].
3445 Potts MB, Chang EF, Young WL, et al. Transsylvian-transinsular approaches to the insula and basal ganglia: operative techniques and results with vascular lesions. Neurosurgery. Apr. 2012;70(4):824-34. discussion 34. X-1. [pmid: 21937930].
3446 Powell J, Blouin MM, David M, et al. Bleeding in congenital hemangiomas: crusting as a clinical predictive sign and usefulness of tranexamic acid. Pediatr Dermatol. Mar–Apr. 2012;29(2):182-5. X-1. [pmid: 21995591].
3447 Prashanth GP. How “unsafe” is propranolol when used in the treatment of infantile hemangioma?. J Am Acad Dermatol. May. 2012;66(5):854-5. author reply 5–6. X-3, X-4. [pmid: 22507576].
3448 Raches D, Hiscock M, Chapieski L. Behavioral and academic problems in children with Sturge-Weber syndrome: differences between children with and without seizures. Epilepsy Behav. Nov. 2012;25(3):457-63. X-1. [pmid: 23000106].
3449 Rai P, Shab SIA, Das D. Outcome of low dose intralesional steroid injections in Superficial Infantile Capillary Hemangioma (SICH) of eyelid. Medical Forum Monthly. November. 2012;23(11):32-4. X-6.
3450 Rajewska J, Gawrych E, Fischer K, et al. Estimation of vascular endothelial growth factor and placental growth factor serum levels’ in infant with hemangioma and population of healthy infants. Ann Acad Med Stetin. 2012;58(2):5-10. X-2. [pmid: 23767175].
3451 Rapp M, Rapp M, Berg C, et al. Prenatal suspicion of Kaposiform hemangioendothelioma in siblings: different clinical manifestation and emergency relief. Klin Padiatr. Oct. 2012;224(6):390-1. X-1. [pmid: 23143766].
3452 Roach EE, Chakrabarti R, Park NI, et al. Intrinsic regulation of hemangioma involution by platelet-derived growth factor. Cell Death Dis. 2012;3:e328. X-1. [pmid: 22717583].
3453 Roebuck D. RICH depuis la lettre. Pediatr Radiol. Mar. 2012;42(3):296-7. X-1. [pmid: 22207138].
3454 Roebuck D, Sebire N, Lehmann E, et al. Rapidly involuting congenital haemangioma (RICH) of the liver. Pediatr Radiol. Mar. 2012;42(3):308-14. X-1. [pmid: 22302317].
3455 Ryan E, Warren L. Birthmarks--identification and management. Aust Fam Physician. May. 2012;41(5):274-7. X-1, X-2. [pmid: 22558616].
3456 Sakamoto N, Ishikawa E, Nakai Y, et al. Preoperative endovascular embolization for hemangioblastoma in the posterior fossa. Neurol Med Chir (Tokyo). 2012;52(12):878-84. X-1. [pmid: 23269042].
3457 Schafer FK, Biernath-Wuepping J, Eckmann-Scholz C, et al. Rare Benign Entities of the Breast - Myoid Hamartoma and Capillary Hemangioma. Geburtshilfe Frauenheilkd. May. 2012;72(5):412-8. X-1. [pmid: 25298546].
3458 Schramm J, Kuczaty S, Sassen R, et al. Pediatric functional hemispherectomy: outcome in 92 patients. Acta Neurochir (Wien). Nov. 2012;154(11):2017-28. X-1. [pmid: 22941395].
3459 Segura Palacios JM, Boixeda P, Rocha J, et al. Laser treatment for verrucous hemangioma. Lasers Med Sci. May. 2012;27(3):681-4. X-1. [pmid: 21975688].
3460 Seirafi H, Ehsani A, Jesri S, et al. Treatment of infantile hemangioma with topical imiquimod 5% cream. Iranian Journal of Dermatology. 2012;15(62):117-21. X-4.
3461 Seo S, Takahashi T, Marusasa T, et al. Management of inguinal hernia in children can be enhanced by closer follow-up by consultant pediatric surgeons. Pediatr Surg Int. Jan. 2012;28(1):33-6. X-1. [pmid: 22033770].
3462 Shapiro E, Guler OE, Rudser K, et al. An exploratory study of brain function and structure in mucopolysaccharidosis type I: long term observations following hematopoietic cell transplantation (HCT). Mol Genet Metab. Sep. 2012;107(1–2):116-21. X-1. [pmid: 22867884].
3463 Shepherd D, Adams S, Wargon O, et al. Childhood wheeze while taking propranolol for treatment of infantile hemangiomas. Pediatr Pulmonol. Jul. 2012;47(7):713-5. X-3, X-4. [pmid: 22170856].
3464 Sheu GL, Hammer Y, Kirsch AJ. Testicular capillary hemangioma presenting as an incidental contralateral lesion in a child with cryptorchidism. Urology. Nov. 2012;80(5):1135-7. X-1. [pmid: 22990059].
3465 Shi CB, Yuan B, Lu JR, et al. Continuous low-dose-rate radiation of radionuclide phosphorus-32 for hemangiomas. Cancer Biother Radiopharm. Apr. 2012;27(3):198-203. X-3. [pmid: 22364418].
3466 Shiau T, Armogan N, Yan DB, et al. The role of episcleral venous pressure in glaucoma associated with Sturge-Weber syndrome. J aapos. Feb. 2012;16(1):61-4. X-1. [pmid: 22370668].
3467 Shukla S, Acharya S, Bhola N, et al. Central haemangioma (intraosseous) of jaw. Journal of Medicine (Bangladesh). 2012;13(2):222-6. X-1, X-2.
3468 Siklos K, Sapy Z, Szalai Z. Infantile myofibroma: Report of two patients. European Journal of Pediatric Dermatology. March. 2012;22(1):79. X-1.
3469 Simonini VM, Lodi L. Encephalofacial angiomatosis (Sturge-Weber syndrome): report of three cases. Acta Clin Croat. Dec. 2012;51(Suppl 1):91-8. X-1. [pmid: 23431731].
3470 Slowinska M, Rakowska A, Maj M, et al. Dermoscopy of proliferative lesions of the scalp-12 years of experience. Dermoskopia zmian rozrostowych skory owlosionej glowy - podsumowanie 12 lat doswiadczen. [Polish, English]. Przegl Dermatol. 2012;99(4):461. X-1.
3471 Smadja DM, Mulliken JB, Bischoff J. E-selectin mediates stem cell adhesion and formation of blood vessels in a murine model of infantile hemangioma. Am J Pathol. Dec. 2012;181(6):2239-47. X-1. [pmid: 23041613].
3472 Smit DP, Meyer D. Intralesional bleomycin for the treatment of periocular capillary hemangiomas. Indian J Ophthalmol. Jul. 2012;60(4):326-8. X-3, X-4. [pmid: 22824608].
3473 Soldado F, Fontecha CG, Haddad S, et al. Composite vascularized fibular epiphyseo-osteo-periosteal transfer for hip reconstruction after proximal femoral tumoral resection in a 4-year-old child. Microsurgery. Sep. 2012;32(6):489-92. X-1. [pmid: 22511340].
3474 Sondhi V, Kurkure PA, Vora T, et al. Successful management of multi-focal hepatic infantile hemangioendothelioma using TACE/surgery followed by maintenance metronomic therapy. BMJ Case Rep. 2012;2012. X-1. [pmid: 22605610].
3475 Song JN, Jung SL, Lee SH, et al. A case of large auricular lymphangioma. Int J Pediatr Otorhinolaryngol Extra. September. 2012;7(3):100-2. X-1.
3476 Sovinz P, Schwinger W, Lackner H, et al. Allogeneic stem cell transplantation for mucopolysaccharidosis I hurler with unrelated CD 3/19 depleted peripheral stem cell grafts. Memo - Magazine of European Medical Oncology. April. 2012;(1):12. PMID: X-1.
3477 Spierer O, Neudorfer M, Leibovitch I, et al. Colour Doppler ultrasound imaging findings in paediatric periocular and orbital haemangiomas. Acta Ophthalmol. Dec. 2012;90(8):727-32. X-3. [pmid: 21457487].
3478 Stiles J, Amaya C, Pham R, et al. Propranolol treatment of infantile hemangioma endothelial cells: A molecular analysis. Exp Ther Med. 2012;4(4):594-604. X-1, X-3. [pmid: 23170111].
3479 Strand M, Smidt AC. Pain management for ulcerated infantile hemangiomas. Pediatr Dermatol. Jan–Feb. 2012;29(1):124-6. X-2. [pmid: 22256995].
3480 Takahashi H, Nagatoshi Y, Kato M, et al. Multifocal skin lesions and melena with thrombocytopenia in an infant. J Pediatr. Mar. 2012;160(3):524-e1. X-1. [pmid: 22074937].
3481 Tan ST, Itinteang T, Day DJ, et al. Treatment of infantile haemangioma with captopril. Br J Dermatol. Sep. 2012;167(3):619-24. X-4. [pmid: 22533490].
3482 Tan ST, Itinteang T, Leadbitter P. Reply to the letter to the Editor on “Low-dose propranolol for infantile haemangioma”. J Plast Reconstr Aesthet Surg. Aug. 2012;65(8):1124-6. X-1, X-2. [pmid: 22265964].
3483 Taylor SRJ, Singh J, Sagoo MS, et al. Clinical and molecular features associated with cystic visceral lesions in von hippel-lindau disease. Open J Ophthalmol. 2012;6:83-5. X-1.
3484 Tchidjou HK, Vescio F, Avellis L, et al. An atypical case of multifocal infantile haemangioma in a child after Highly Active Antiretroviral Therapy (HAART) during pregnancy. Clin Neurol Neurosurg. Oct. 2012;114(8):1161-3. X-2. [pmid: 22763192].
3485 Templeton C, Harnett D. Successful use of atenolol in the treatment of a severe infantile hemangioma. European Journal of Pediatric Dermatology. July–September. 2012;22(3):179-81. X-2.
3486 Thomas MW, Burkhart CN, Vaghani SP, et al. Failure to thrive in infants with complicated facial hemangiomas. Pediatr Dermatol. Jan–Feb. 2012;29(1):49-52. X-3, X-4. [pmid: 21950618].
3487 Thompson CV, Wells JM, Bowen C, et al. Intra-abdominal Kaposiform hemangioendothelioma and the benefits of laparoscopic surveillance. Pediatr Blood Cancer. Jun. 2012;58(6):992-3. X-1. [pmid: 22431247].
3488 Thoumazet F, Leaute-Labreze C, Colin J, et al. Efficacy of systemic propranolol for severe infantile haemangioma of the orbit and eyelid: a case study of eight patients. Br J Ophthalmol. Mar. 2012;96(3):370-4. X-4. [pmid: 21673014].
3489 Tollefson MM, Frieden IJ. Early growth of infantile hemangiomas: what parents’ photographs tell us. Pediatrics. Aug. 2012;130(2):e314-20. X-3. [pmid: 22826568].
3490 Traivaree C, Lumkul R, Torcharus K, et al. Outcome of Kasabach-Merritt phenomenon: the role of vincristine as monotherapy: report of a case. J Med Assoc Thai. May. 2012;95(Suppl 5):S181-5. X-1. [pmid: 22934467].
3491 Tu JB, Dong Q, Hu XY, et al. Proteomic analysis of mitochondria from infantile hemangioma endothelial cells treated with sodium morrhuate and its liposomal formulation. J Biochem Mol Toxicol. Sep. 2012;26(9):374-80. X-1. [pmid: 22987598].
3492 Ueba T, Abe H, Matsumoto J, et al. Efficacy of indocyanine green videography and real-time evaluation by FLOW 800 in the resection of a spinal cord hemangioblastoma in a child: case report. J Neurosurg Pediatr. Apr. 2012;9(4):428-31. X-1. [pmid: 22462710].
3493 Veras TN, Benvenutti RC, Hornburg G, et al. Subglottic hemangiome in childhood. Braz J Otorhinolaryngol. Feb. 2012;78(1):143. X-2. [pmid: 22392255].
3494 Vergine G, Marsciani A, Pedini A, et al. Efficacy of propranolol treatment in thyroid dysfunction associated with severe infantile hepatic hemangioma. Horm Res Paediatr. 2012;78(4):256-60. X-2. [pmid: 22907522].
3495 Vigone MC, Cortinovis F, Rabbiosi S, et al. Difficult treatment of consumptive hypothyroidism in a child with massive parotid hemangioma. J Pediatr Endocrinol Metab. 2012;25(1–2):153-5. X-2. [pmid: 22570966].
3496 Virbalas JM, Bent JP, Parikh SR. Pediatric nasal lobular capillary hemangioma. Case Rep Med. 2012;2012(769630). X-1, X-2.
3497 Virginia C, Florentina F, Sabina ZA, et al. Study of clinical and dermoscopic features in acquired hemangioma for a correct therapeutic attitude. Therapeutics, Pharmacology and Clinical Toxicology. June. 2012;16(2):101-5. X-1.
3498 Vitoria Minana I. Most common skin disorders of the newborn and infant. Diaper rash. Trastornos cutaneos mas frecuentes del recien nacido y del lactante. Dermatitis del panal. Pediatria Integral. April. 2012;16(3):195-208. X-1, X-2.
3499 Vitoria Minana I. Most common skin disorders of the newborn and infant. Diaper rash. Pediatria Integral. April. 2012;16(3):195-208. PMID: X-1.
3500 Vladareanu R, Zvanca M, Andrei C. Pathology of the fetal neck. Donald School Journal of Ultrasound in Obstetrics and Gynecology. January–March. 2012;6(1):55-65. X-1.
3501 Wang YJ, Zhang ZW, Yu J, et al. Hemangioendothelioma of the right atrial appendage associated with pericardial effusion in an infant. World J Pediatr. Feb. 2012;8(1):83-5. X-1. [pmid: 22282383].
3502 Watson T, Martinez E, Crabbe D, et al. Renal lymphangiomatosis, interrupted IVC with persistent primitive hepatic venous plexus and multiple anomalous venous channels: parts of an overlap syndrome?. Pediatr Radiol. Feb. 2012;42(2):253-6. X-1. [pmid: 21773796].
3503 Weibel L, Scheer HS, Barysch M, et al. Topical betablo-ckers for infantile hemangiomas are effective but systemically absorbed. European Journal of Pediatric Dermatology. March. 2012;22(1):10-1. X-2.
3504 Weissenstein A, Straeter A, Villalon G, et al. Topical timolol for small infantile hemangioma: a new therapy option. Turk J Pediatr. Mar–Apr. 2012;54(2):156-8. X-4. [pmid: 22734302].
3505 Weissenstein A, Villalon G, Luchter E, et al. Children’s haemangiomas: use of new topical therapies. Br J Nurs. Mar. 8–21. 2012;21(5):274. X-4. [pmid: 22398997].
3506 Wittig M, Fischer M, Baur MO, et al. A newborn infant with sepsis-like clinical picture and petechial bleeding (case presentation). Acta Paediatr. Jul. 2012;101(7):685-6. 792. 3. X-1. [pmid: 22672692].
3507 Wong A, Hardy KL, Kitajewski AM, et al. Propranolol accelerates adipogenesis in hemangioma stem cells and causes apoptosis of hemangioma endothelial cells. Plast Reconstr Surg. Nov. 2012;130(5):1012-21. X-1. [pmid: 23096601].
3508 Wu JC, Chen YC, Liu L, et al. Younger boys have a higher risk of inguinal hernia after ventriculo-peritoneal shunt: a 13-year nationwide cohort study. J Am Coll Surg. May. 2012;214(5):845-51. X-1. [pmid: 22520694].
3509 Wu S, Liu G, Chen R, et al. Role of ultrasound in the assessment of benignity and malignancy of parotid masses. Dentomaxillofac Radiol. Feb. 2012;41(2):131-5. X-1. [pmid: 22116132].
3510 Xie WM, Dai HP, Jin ML, et al. Clinical features and imaging findings in pulmonary capillary hemangiomatosis: report of two cases and a pooled analysis. Chin Med J (Engl). Sep. 2012;125(17):3069-73. X-1. [pmid: 22932183].
3511 Xue K, Hildebrand GD. Topical timolol maleate 0.5% for infantile capillary haemangioma of the eyelid. Br J Ophthalmol. Dec. 2012;96(12):1536-7. X-3, X-4. [pmid: 23014679].
3512 Yan AC. Infantile hemangiomas: new frontiers. Pediatr Ann. Aug. 2012;41(8):318-9. X-3, X-4. [pmid: 22881422].
3513 Yan J, Zhou S, Li Y. Benign orbital tumors with bone destruction in children. PLoS One. 2012;7(2):e32111. X-1, X-2. [pmid: 22384155].
3514 Yu Y, Sanderson SR, Reyes M, et al. Novel NaPi-IIc mutations causing HHRH and idiopathic hypercalciuria in several unrelated families: long-term follow-up in one kindred. Bone. May. 2012;50(5):1100-6. X-1. [pmid: 22387237].
3515 Yuen NS, Wong IY. Congenital glaucoma from Sturge-Weber syndrome: a modified surgical approach. Korean J Ophthalmol. Dec. 2012;26(6):481-4. X-1. [pmid: 23204808].
3516 Zaidi SN, Fathaddin AA. Testicular capillary hemangioma--a case report of a rare tumor. Indian J Pathol Microbiol. Oct–Dec. 2012;55(4):557-9. X-1. [pmid: 23455806].
3517 Zakaria Z, Kaliaperumal C, Caird J, et al. Unilateral facial palsy in an infant: an unusual presentation of familial multiple cerebral cavernous malformation. BMJ Case Rep. 2012;2012. X-1. [pmid: 23203183].
3518 Zavras N, Christianakis E, Ereikat K, et al. Intracranial hypertension secondary to abdominal compartment syndrome in a girl with giant ovarian cystic mass. Indian J Pediatr. Apr. 2012;79(4):541-2. X-1. [pmid: 21842281].
3519 Zhang H, Luo J, Feng X. Kaposiform hemangioendothelioma in the uterine cervix of a 5-year girl. Fetal Pediatr Pathol. Oct. 2012;31(5):273-7. X-1. [pmid: 22432747].
3520 Zheng SP, Ju Y, You C. Giant intracranial capillary hemangioma in a 3-year-old child: case report and literature review. Clin Neurol Neurosurg. Nov. 2012;114(9):1270-3. X-1. [pmid: 22425365].
3521 Carefully consider the best approach when treating infantile haemangiomas. Drugs and Therapy Perspectives. October. 2013;29(10):314-9. X-1, X-2.
3522 Birthmark Check. Parents. 2013;88(3):62. PMID: X-1.
3523 Ahogo CK, Ezzedine K, Prey S, et al. Factors associated with the relapse of infantile haemangiomas in children treated with oral propranolol. Br J Dermatol. Dec. 2013;169(6):1252-6. X-3, X-4. [pmid: 23662995].
3524 Ajitsaria R, Quinn E, Mew RC, et al. Rare tumour presenting in a newborn infant. Arch Dis Child. May. 2013;98(5):362. X-1. [pmid: 23178397].
3525 Al Dosari S, Riad H. Ulcerated nasal infantile haemangioma treated by oral propranolol. Dermatol Online J. May. 2013;19(5):18298. X-2, X-4. [pmid: 24011285].
3526 Al Masalmeh O, Shaikh R, Chaudry G, et al. Transjugular retrograde cannulation of the portal vein via patent ductus venosus: alternative access for endovascular hepatic interventions. J Vasc Interv Radiol. Jan. 2013;24(1):81-4. X-1. [pmid: 23273700].
3527 Al-Breiki S, Shaikh L. An extensive bilateral cervicofacial hemangioma managed successfully with propranolol, a case report and literature review. Journal of the Saudi Society of Dermatology and Dermatologic Surgery. July. 2013;17(2):65-8. X-2.
3528 Alcantara-Gonzalez J, Boixeda P, Truchuelo-Diez MT, et al. Infantile hemangiomas treated by sequential application of pulsed dye laser and Nd:YAG laser radiation: a retrospective study. Actas Dermosifiliogr. Jul–Aug. 2013;104(6):504-11. X-4. [pmid: 23522740].
3529 Altomare M, La Vignera S, Asero P, et al. High prevalence of thyroid dysfunction in pregnant women. J Endocrinol Invest. Jun. 2013;36(6):407-11. X-1. [pmid: 23095459].
3530 Amato MC, Madureira JF, Oliveira RS. Intracranial cavernous malformation in children: a single-centered experience with 30 consecutive cases. Arq Neuropsiquiatr. Apr. 2013;71(4):220-8. X-1. [pmid: 23588283].
3531 Ambika H, Sujatha C, Kumar YH. Topical timolol: A safer alternative for complicated and un-complicated infantile hemangiomas. Indian Journal of Dermatology. July–August. 2013;58(4):330. PMID: X-3, X-4. [pmid: 23919041].
3532 Ammerman RT, Putnam FW, Altaye M, et al. A clinical trial of in-home CBT for depressed mothers in home visitation. Behav Ther. Sep. 2013;44(3):359-72. X-1. [pmid: 23768664].
3533 Ammerman RT, Putnam FW, Altaye M, et al. Treatment of depressed mothers in home visiting: impact on psychological distress and social functioning. Child Abuse Negl. Aug. 2013;37(8):544-54. X-1. [pmid: 23623623].
3534 Anderson de Moreno LC, Matt BH, Montgomery G, et al. Propranolol in the treatment of upper airway hemangiomas. Ear Nose Throat J. Apr–May. 2013;92(4–5):209-14. X-4. [pmid: 23599104].
3535 Anderson JC, Brown KK. Masson tumor arising in a congenital vascular anomaly. Pediatr Dermatol. 2013;30(6):745-7. X-1, X-3. [pmid: 24033678].
3536 Arepalli S, Shields CL, Kaliki S, et al. Diffuse choroidal hemangioma management with plaque radiotherapy in 5 cases. Ophthalmology. Nov. 2013;120(11):2358-59. 9 e1. 2. X-1, X-4. [pmid: 24182566].
3537 Arica DA, Arica IE, Yayli S, et al. Spitz nevus arising upon a congenital glomuvenous malformation. Pediatr Dermatol. May–Jun. 2013;30(3):e25-6. X-1. [pmid: 22304367].
3538 Aslan H, Dural O, Yildirim G, et al. Prenatal diagnosis of a liver cavernous hemangioma. Fetal Pediatr Pathol. Oct. 2013;32(5):341-5. X-1, X-2. [pmid: 23421545].
3539 Atsali E, Stathopoulos KD, Bournazos I, et al. PReS-FINAL-2243: Reduced volumetric trabecular bone mineral density in children with idiopathic hypercalciuria. A peripheral quantitative computed tomography (PQCT) study (preliminary results). Pediatric Rheumatology. 05. Dec. 2013;11. PMID: X-1.
3540 Attra J, Sina-Khadiv M, Lin A. Pyogenic granuloma of the epiglottis. International Journal of Pediatric Otorhinolaryngology Extra. September. 2013;8(3):97-8. PMID: X-1, X-4.
3541 Avagyan S, Klein M, Kerkar N, et al. Propranolol as a first-line treatment for diffuse infantile hepatic hemangioendothelioma. J Pediatr Gastroenterol Nutr. Mar. 2013;56(3):e17-20. X-1. [pmid: 22331019].
3542 Avolio L, Rispoli GA, Morbini P, et al. Intralobar pulmonary sequestration associated with hemangioma. Am J Respir Crit Care Med. Jun. 15. 2013;187(12):1388-9. X-2. [pmid: 23767903].
3543 Aziz AS, Hui D, Chinnappa V, et al. Successful pregnancy, epidural anaesthesia, labour, and delivery in a woman with Sturge-Weber syndrome and previous hemispherectomy. J Obstet Gynaecol Can. Oct. 2013;35(10):917-9. X-1. [pmid: 24165060].
3544 Bajaj Y, Kapoor K, Ifeacho S, et al. Great Ormond Street Hospital treatment guidelines for use of propranolol in infantile isolated subglottic haemangioma. J Laryngol Otol. Mar. 2013;127(3):295-8. X-1. [pmid: 23369213].
3545 Bayer ML, Frommelt PC, Blei F, et al. Congenital cardiac, aortic arch, and vascular bed anomalies in PHACE syndrome (from the International PHACE Syndrome Registry). Am J Cardiol. Dec. 15. 2013;112(12):1948-52. X-3, X-4. [pmid: 24079520].
3546 Berk DR, Culican SM, Bayliss SJ. Scleral hemangioma: case report and response to propranolol. Pediatr Dermatol. May–Jun. 2013;30(3):e16-7. X-2. [pmid: 22486338].
3547 Berk DR, Lehman PA, Franz TJ, et al. On topical timolol gel-forming solution for infantile hemangiomas. Pediatr Dermatol. Jan–Feb. 2013;30(1):160-1. X-3, X-4. [pmid: 23316722].
3548 Bertozzi M, Melissa B, Magrini E, et al. Laparoscopic herniorrhaphy in the pediatric age group: what about the learning curve?. J Endourol. Jul. 2013;27(7):840-4. X-1. [pmid: 23384349].
3549 Biggs S, Nixon G, Davey M, et al. Slow wave activity in children with excessive daytime sleepiness: A potential role in identification of narcolepsy. Sleep Biol Rhythms. October. 2013;11:39-40. X-1.
3550 Bilodi AKS, Singh S, Ebenezer DA, et al. Capillary haemangioma of the right elbow and forearm in new born child. J Clin Diagn Res. 15. Dec. 2013;7(12):2941-2. X-2. [pmid: 24551681].
3551 Blanke K, Dahnert I, Salameh A. Role of connexins in infantile hemangiomas. Front Pharmacol. 2013;4. APR. (Article 41). X-1, X-2.
3552 Block SL, Blackmon L. Treating infantile hemangiomatosis: a case study. Pediatr Ann. Jun. 1. 2013;42(6):230-3. X-2. [pmid: 23718244].
3553 Boscolo E, Mulliken JB, Bischoff J. Pericytes from infantile hemangioma display proangiogenic properties and dysregulated angiopoietin-1. Arterioscler Thromb Vasc Biol. Mar. 2013;33(3):501-9. X-1, X-3. [pmid: 23288163].
3554 Boucek RJ Jr, Kirsh AL, Majesky MW, et al. Propranolol responsiveness in vascular tumors is not determined by qualitative differences in adrenergic receptors. Otolaryngol Head Neck Surg. Nov. 2013;149(5):772-6. X-1. [pmid: 24009211].
3555 Broeks IJ, Hermans DJ, Dassel AC, et al. Propranolol treatment in life-threatening airway hemangiomas: a case series and review of literature. Int J Pediatr Otorhinolaryngol. Nov. 2013;77(11):1791-800. X-4. [pmid: 24074695].
3556 Burch EA, Garzon MC, Parikh A, et al. A 65-year-old woman diagnosed with PHACE syndrome. Pediatr Dermatol. 2013;30(6):e153-6. X-1. [pmid: 23278462].
3557 Burgemeister AL, Behnecke A, Pietz J, et al. PHACES syndrome-a case with Moya-Moya-like vasculopathy. Medizinische Genetik. March. 2013;25(1):115. X-2.
3558 Calvo M, Garcia-Millan C, Villegas C, et al. Topical timolol for infantile hemangioma of the eyelid. Int J Dermatol. May. 2013;52(5):603-4. X-2. [pmid: 22417222].
3559 Capone F, Profice P, Pilato F, et al. Spinal hemangioblastoma presenting with low back pain in pregnancy. Spine J. Dec. 2013;13(12):e27-9. X-1. [pmid: 24051331].
3560 Causse S, Aubert H, Saint-Jean M, et al. Propranolol-resistant infantile haemangiomas. Br J Dermatol. Jul. 2013;169(1):125-9. X-4. [pmid: 23659587].
3561 Cavalli R, Novotna V, Buffon RB, et al. Multiple cutaneous and hepatic infantile hemangiomas having a successful response to propranolol as monotherapy at neonatal period. G Ital Dermatol Venereol. October. 2013;148(5):525-30. X-2. [pmid: 24005146].
3562 Chachad S, Khan A. Klippel-Trénaunay- Weber Syndrome. Consultant. 2013;53(6):470. PMID: X-1.
3563 Chaithirayanon S, Boonyaleephan S, Treesirichod A, et al. Early onset and rapid progression of glaucoma in a neonate with Sturge-Weber syndrome. J Med Assoc Thai. Mar. 2013;96(3):374-7. X-1. [pmid: 23539944].
3564 Chan S, Cassarino DS. Rapidly enlarging “bruise” on the back of an infant. Kaposiform hemangioendothelioma complicated by Kasabach-Merritt syndrome. JAMA Dermatol. Nov. 2013;149(11):1337-8. X-1. [pmid: 24005816].
3565 Chantasart D, Hao J, Li SK. Evaluation of skin permeation of beta-blockers for topical drug delivery. Pharm Res. Mar. 2013;30(3):866-77. X-1. [pmid: 23208385].
3566 Chaudhry TA, Kamal M, Ahmad K. Periocular infantile haemangioma and the role of propranolol. J Coll Physicians Surg Pak. Aug. 2013;23(8):593-5. X-2. [pmid: 23930881].
3567 Chavala SH, Williamson JF. Bilateral exudative retinal detachments in Sturge-Weber syndrome. Lancet. Jul. 20. 2013;382(9888):259. X-1. [pmid: 23375876].
3568 Chen LF, Yang Y, Yu XG, et al. Operative management of brainstem hemangioblastomas. J Clin Neurosci. Dec. 2013;20(12):1727-33. X-1. [pmid: 24055208].
3569 Chen XD, Ma G, Chen H, et al. Maternal and perinatal risk factors for infantile hemangioma: a case-control study. Pediatr Dermatol. Jul–Aug. 2013;30(4):457-61. X-1, X-3. [pmid: 23278441].
3570 Chen XD, Ma G, Huang JL, et al. Serum-level changes of vascular endothelial growth factor in children with infantile hemangioma after oral propranolol therapy. Pediatr Dermatol. Sep–Oct. 2013;30(5):549-53. X-3, X-4. [pmid: 23909679].
3571 Cheng J, Hatten K, Jacobs I. Postcricoid infantile hemangioma: Management of a case in the propranolol era. International Journal of Pediatric Otorhinolaryngology Extra. September. 2013;8(3):102-3. PMID: X-4.
3572 Cho BS, Hahn WH, Cheong HI, et al. A nationwide study of mass urine screening tests on Korean school children and implications for chronic kidney disease management. Clin Exp Nephrol. Apr. 2013;17(2):205-10. X-1. [pmid: 23135862].
3573 Chou S, Subramanian V, Lau HM, et al. Renal Anastomosing Hemangiomas With a Diverse Morphologic Spectrum: Report of Two Cases and Review of Literature. Int J Surg Pathol. Jul. 1. 2013;22(4):369-73. X-1. [pmid: 23816823].
3574 Chu MB, Searcy G, Siegfried E. Efficacy of topical brimonidine-timolol for haemangioma of infancy and perils of off-label prescribing. BMJ Case Rep. 2013;2013. X-2. [pmid: 23598940].
3575 Ciampolini M, David Lovell-Smith H, Kenealy T, et al. Hunger can be taught: Hunger Recognition regulates eating and improves energy balance. International Journal of General Medicine. 2013;6:465-78. PMID: x-1. [pmid: 23825928].
3576 Cloke A, Lim LT, Blaikie A. Capillary haemangioma successfully treated with oral beta-blocker in Dar es Salaam, Tanzania: a case report. Semin Ophthalmol. Jan. 2013;28(1):32-3. X-1, X-2. [pmid: 23305438].
3577 Cohen-Barak E, Rozenman D, Shani Adir A. Infantile haemangiomas and quality of life. Arch Dis Child. Sep. 2013;98(9):676-9. X-3, X-4. [pmid: 23864355].
3578 Consiglieri GD, Killory BD, Germain RS, et al. Utility of the CO2 laser in the microsurgical resection of cavernous malformations. World Neurosurg. May–Jun. 2013;79(5–6):714-8. X-1. [pmid: 22381271].
3579 Criado PR, Alavi A, Halpern I, et al. Unilateral livedoid vasculopathy associated with involutional phase of cutaneous infantile hemangioma: the connection to coagulation disorders. Int J Low Extrem Wounds. Dec. 2013;12(4):306-9. X-1, X-4. [pmid: 24043683].
3580 Croteau SE, Liang MG, Kozakewich HP, et al. Kaposiform hemangioendothelioma: atypical features and risks of Kasabach-Merritt phenomenon in 107 referrals. J Pediatr. Jan. 2013;162(1):142-7. X-1. [pmid: 22871490].
3581 DelRosso LM, Chesson AL Jr, Hoque R. Characterization of REM sleep without atonia in patients with narcolepsy and idiopathic hypersomnia using AASM scoring manual criteria. J Clin Sleep Med. Jul. 15. 2013;9(7):675-80. X-1. [pmid: 23853561].
3582 Downing A, Chauhan A, Lotterman C, et al. Giant vascular malformation with thrombocytopenia in a newborn. Clin Pediatr (Phila). Nov. 2013;52(11):1079-82. X-1. [pmid: 24002050].
3583 Du W, Gerald D, Perruzzi CA, et al. Vascular tumors have increased p70 S6-kinase activation and are inhibited by topical rapamycin. Lab Invest. Oct. 2013;93(10):1115-27. X-1. [pmid: 23938603].
3584 Eisengart JB, Rudser KD, Tolar J, et al. Enzyme replacement is associated with better cognitive outcomes after transplant in Hurler syndrome. J Pediatr. Feb. 2013;162(2):375-80.e1. X-1. [pmid: 22974573].
3585 El Essawy R, Galal RE. Parenteral corticosteroids followed by early surgical resection of large amblyogenic eyelid hemangiomas in infants. Clin Ophthalmol. 27. May. 2013;7:955-8. X-4. [pmid: 23761960].
3586 Eladl T, Elassal M, Dabbour A, et al. Dynamic contrast enhanced MRI versus histology in diagnosis of hepatocellular tumors. Hepatol Int. June. 2013;7:S685-S6. X-1.
3587 Ercan TE, Oztunc F, Celkan T, et al. Macrocephaly-capillary malformation syndrome in a newborn with tetralogy of fallot and sagittal sinus thrombosis. J Child Neurol. Jan. 2013;28(1):115-9. X-1. [pmid: 22451530].
3588 Erdem E, Gokdemir Y, Unal F, et al. Flexible bronchoscopy as a valuable tool in the evaluation of infants with stridor. Eur Arch Otorhinolaryngol. Jan. 2013;270(1):21-5. X-1. [pmid: 22639201].
3589 Eyesan SU, Olawepo A, Obalum DC, et al. Deep calf cavernous haemangioma in a 10 year- old girl: a case report. Niger Postgrad Med J. Jun. 2013;20(2):162-4. X-1. [pmid: 23959360].
3590 Falardeau J, Lobb BM, Golden S, et al. The use of acetazolamide during pregnancy in intracranial hypertension patients. J Neuroophthalmol. Mar. 2013;33(1):9-12. X-1. [pmid: 22635167].
3591 Fernandez-Pineda I, Lopez-Gutierrez JC, Chocarro G, et al. Long-term outcome of vincristine-aspirin-ticlopidine (VAT) therapy for vascular tumors associated with Kasabach-Merritt phenomenon. Pediatr Blood Cancer. Sep. 2013;60(9):1478-81. X-1. [pmid: 23609996].
3592 Fisher MM, Palomo P, Zapatta F. INDEX OF SUSPICION. Case 2: Hematochezia in a Neonate. Pediatrics. 2013:280-3. PMID: X-1. [pmid: 23729777].
3593 Francisco T, Goncalves RM, Borges C, et al. Multiple haemangiomas, diaphragmatic eventration and Beckwith-Wiedemann syndrome: an unusual association. BMJ Case Rep. 2013;2013. X-1, X-2. [pmid: 23964040].
3594 Friedman BJ, Shah KN, Taylor JA, et al. Congenital myofibroma masquerading as an ulcerated infantile hemangioma in a neonate. Pediatr Dermatol. 2013;30(6):e248-9. X-1, X-3. [pmid: 22276856].
3595 Gaines SA, Blum C, Chiu ES. Nasal tip infantile hemangioma, a case of mistaken identity. J La State Med Soc. Sep–Oct. 2013;165(5):269-72. X-1. [pmid: 24350527].
3596 Gallarreta FW, Pieroni KA, Mantovani CP, et al. Oral changes stemming from hemangioma of the tongue. Pediatr Dent. Mar–Apr. 2013;35(2):E75-8. X-2. [pmid: 23635974].
3597 Giron-Vallejo O, Lopez-Gutierrez JC, Fernandez-Pineda I. Diagnosis and treatment of Parkes Weber syndrome: a review of 10 consecutive patients. Ann Vasc Surg. Aug. 2013;27(6):820-5. X-1. [pmid: 23880459].
3598 Gold RS, Correa M, Fox C, et al. Systemic propranolol effective in infantile capillary hemangiomas of eyelid... including commentary by Gold RS. Ocular Surgery News. 2013;31(6):30. PMID: X-2.
3599 Gomulka J, Siegel DH, Drolet BA. Dramatic shift in the infantile hemangioma treatment paradigm at a single institution. Pediatr Dermatol. 2013;30(6):751-2. X-3, X-4. [pmid: 24117504].
3600 Goswamy J, Aggarwal R, Bruce IA, et al. Kasabach-Merritt syndrome in a child with upper airway compromise and spontaneous periorbital bruising. Ear Nose Throat J. Jun. 2013;92(6):E16. X-1, X-2. [pmid: 23780597].
3601 Gunes M, Keles MO, NS CI, et al. Cavernous hemangioma of the scrotum treated with local steroid: Case report. Lokal steroid ile tedavi edilen skrotumun kavernoz hemanjiyomu. Turkiye Klinikleri Journal of Medical Sciences. 2013;33(1):241-3. X-1, X-2.
3602 Gunes M, Keles MO, NS CI, et al. Cavernous hemangioma of the scrotum treated with local steroid: Case report. Turkiye Klinikleri Journal of Medical Sciences. 2013;33(1):241-3. PMID: X-1, X-4.
3603 Hackett BC, Phelan E, Ryan A, et al. Use of systemic corticosteroids in management of a large congenital haemangioma of the scalp. Pediatr Dermatol. 2013;30(6):e121-4. X-1. [pmid: 23004357].
3604 Hasan M, Rahman M, Hoque S, et al. Propranolol for hemangiomas. Pediatr Surg Int. Mar. 2013;29(3):257-62. X-3. [pmid: 23247833].
3605 Hassan Y, Osman AK, Altyeb A. Noninvasive management of hemangioma and vascular malformation using intralesional bleomycin injection. Ann Plast Surg. Jan. 2013;70(1):70-3. X-3, X-4. [pmid: 23249476].
3606 Hermans DJ, Zweegers J, Evers AW, et al. Parental experiences with propranolol versus oral corticosteroids for complicated infantile hemangioma, a retrospective questionnaire study. Eur J Dermatol. Nov–Dec. 2013;23(6):857-63. X-3, X-4. [pmid: 24185746].
3607 Hernandez JA, Chia A, Long Quah B, et al. Periocular capillary hemangioma: Management practices in recent years. Clinical Ophthalmology. 20. Jun. 2013;7:1227-32. PMID: X-4. [pmid: 23814460].
3608 Herschthal J, Wulkan A, George M, et al. Additive effect of propranolol and pulsed dye laser for infantile hemangioma. Dermatol Online J. Jun. 2013;19(6):18570. X-2. [pmid: 24011319].
3609 Hery G, Quarello E, Gorincour G, et al. Extrahepatic vitelline vein aneurysm: prenatal diagnosis and follow up. J Pediatr Surg. Aug. 2013;48(8):e1-4. X-1. [pmid: 23932633].
3610 Higashino M, Kawata R, Haginomori S, et al. Novel differential diagnostic method for superficial/deep tumor of the parotid gland using ultrasonography. Head Neck. Aug. 2013;35(8):1153-7. X-1. [pmid: 22907914].
3611 Hoeger PH. An update on infantile haemangiomas. Br J Dermatol. Jul. 2013;169(1):11. X-2, X-4. [pmid: 23834115].
3612 Hou F, Dai Y, Dornhoffer JR, et al. Expression of endoglin (CD105) and endothelial nitric oxide synthase in head and neck arteriovenous malformations. JAMA Otolaryngol Head Neck Surg. Mar. 2013;139(3):237-43. X-1. [pmid: 23657220].
3613 Howell CM, Davis MS, Callanan DL. Stepping outside the box: an adolescent with a new-onset seizure. Pediatr Emerg Care. Sep. 2013;29(9):1011-2. X-1. [pmid: 24201984].
3614 Hyland RM, Komlosi K, Alleman BW, et al. Infantile hemangiomas and retinopathy of prematurity: common mechanisms of pathogenesis?. Biopolymers and Cell. 2013;29:21. PMID: X-1.
3615 Hynes S, Narasimhan K, Courtemanche DJ, et al. Complicated infantile hemangioma of the lip: outcomes of early versus late resection. Plast Reconstr Surg. Mar. 2013;131(3):373e-9e. X-4. [pmid: 23446587].
3616 Ideguchi M, Kajiwara K, Yoshikawa K, et al. Characteristics of intraoperative abnormal hemodynamics during resection of an intra-fourth ventricular tumor located on the dorsal medulla oblongata. Neurol Med Chir (Tokyo). 2013;53(10):655-62. X-1. [pmid: 24077276].
3617 Izadpanah A, Izadpanah A, Kanevsky J, et al. Propranolol versus corticosteroids in the treatment of infantile hemangioma: a systematic review and meta-analysis. Plast Reconstr Surg. Mar. 2013;131(3):601-13. X-2. [pmid: 23142941].
3618 Jakubowski LA, Chun RH, Drolet BA, et al. Misdiagnosed as infantile hemangioma: Early presentation of small vessel-rich AVM. Int J Pediatr Otorhinolaryngol Extra. September. 2013;8(3):71-4. X-1.
3619 Jashari H, Hyseni N, Llullaku S, et al. Hemangiomas of the anterior urethra - Presentation and treatment in children. Eur Urol. October. 2013;12(4):e1184. X-2.
3620 Javvaji S, Frieden IJ. Response of tufted angiomas to low-dose aspirin. Pediatr Dermatol. Jan–Feb. 2013;30(1):124-7. X-1. [pmid: 22429045].
3621 Jennings S, Tharion J, Jones P, et al. Bronchial haemangioma: exceptionally rare cause of haemoptysis. Heart Lung Circ. Dec. 2013;22(12):1030-2. X-1. [pmid: 24314894].
3622 Jia H, Huang Q, Lu J, et al. Microdebrider removal under suspension laryngoscopy: an alternative surgical technique for subglottic hemangioma. Int J Pediatr Otorhinolaryngol. Sep. 2013;77(9):1424-9. X-4. [pmid: 23845535].
3623 Kagami S, Kuwano Y, Shibata S, et al. Propranolol is more effective than pulsed dye laser and cryosurgery for infantile hemangiomas. Eur J Pediatr. Nov. 2013;172(11):1521-6. X-3, X-4. [pmid: 23812512].
3624 Kanno H, Kuratsu J, Nishikawa R, et al. Clinical features of patients bearing central nervous system hemangioblastoma in von Hippel-Lindau disease. Acta Neurochir (Wien). Jan. 2013;155(1):1-7. X-1. [pmid: 23080552].
3625 Karpe A, Suganeswari G. Spontaneous vitreous hemorrhage in a case of retinal cavernous hemangioma: a rare presentation. JAMA Ophthalmol. Jul. 2013;131(7):897. X-1. [pmid: 23846203].
3626 Kasapoglu F, Ozdemircan T, Erisen L. Laryngeal plexiform neurofibroma in a child. Ear Nose Throat J. Jun. 2013;92(6):E31. X-1. [pmid: 23780601].
3627 Kaushik SB, Kwatra SG, McLean TW, et al. Segmental ulcerated perineal hemangioma of infancy: a complex case of PELVIS syndrome successfully treated using a multidisciplinary approach. Pediatr Dermatol. 2013;30(6):e257-8. X-1, X-2. [pmid: 23278237].
3628 Kawano R, Takemoto S, Shimamatsu K, et al. Fetomaternal hemorrhage with intraplacental chorioangioma. J Obstet Gynaecol Res. Feb. 2013;39(2):583-7. X-1. [pmid: 22925543].
3629 Kaylani S, Theos AJ, Pressey JG. Treatment of infantile hemangiomas with sirolimus in a patient with PHACE syndrome. Pediatr Dermatol. 2013;30(6):e194-7. X-2. [pmid: 23316753].
3630 Khalatbari MR, Hamidi M, Moharamzad Y. Acute presentation of solitary spinal epidural cavernous angioma in a child. J Coll Physicians Surg Pak. May. 2013;23(5):364-6. X-1. [pmid: 23673181].
3631 Kim YH, Lee GH, Lee SH, et al. An acquired tufted angioma of the nasal cavity. Auris Nasus Larynx. Dec. 2013;40(6):581-3. X-1. [pmid: 23518006].
3632 Krishna CV, Reddy GM, Senthil Kumar AL, et al. Hobnail hemangioma on the trunk. Dermatol Online J. May. 2013;19(5):18179. X-1. [pmid: 24011279].
3633 Kryvenko ON, Epstein JI. Testicular hemangioma: a series of 8 cases. Am J Surg Pathol. Jun. 2013;37(6):860-6. X-1. [pmid: 23665824].
3634 Kumar GV, Deenadayalan M, Hemalatha, et al. Kaposiform hemangioendothelioma in a 3 month old infant-a case report. Indian J Hematol Blood Transfus. December. 2013;29(4):332. X-1.
3635 Kumar S, Taneja B, Saxena KN, et al. Anaesthetic management of a neonate with Kasabach-Merritt syndrome. Indian J Anaesth. May–June. 2013;57(3):292-4. X-1. [pmid: 23983291].
3636 Kumbhar S, Saraf R, Limaye U. Middle ear and mastoid hemangioma treated by neurointerventional techniques. Indian J Otolaryngol. April–June. 2013;19(2):85-7. X-2.
3637 Kwon CS, Sheth SA, Walcott BP, et al. Long-term seizure outcomes following resection of supratentorial cavernous malformations. Clin Neurol Neurosurg. Nov. 2013;115(11):2377-81. X-1. [pmid: 24075713].
3638 Laing EL, Brasch HD, Steel R, et al. Verrucous hemangioma expresses primitive markers. J Cutan Pathol. Apr. 2013;40(4):391-6. X-1. [pmid: 23379586].
3639 Lance EI, Sreenivasan AK, Zabel TA, et al. Aspirin use in Sturge-Weber syndrome: side effects and clinical outcomes. J Child Neurol. Feb. 2013;28(2):213-8. X-1. [pmid: 23112247].
3640 Leaute-Labreze C. Beta-blockers: An unexpected but beneffcial effect on infantile hemangiomas. Les betabloquants: Un effet inattendu mais benefique sur l’evolution des hemangiomes infantiles. Sang Thrombose Vaisseaux. March–June. 2013;25(3):149-54. X-11.
3641 Leaute-Labreze C. Beta-blockers: An unexpected but beneffcial effect on infantile hemangiomas. Sang Thrombose Vaisseaux. March–June. 2013;25(3):149-54. PMID: X-1, X-2.
3642 Lee NY, Cho HK, Kim KH, et al. A girl with sternal malformation/vascular dysplasia association. Korean J Pediatr. 2013;56(3):135-8. X-2. [pmid: 23559976].
3643 Lee S, Tan JS. Ultrasonography-guided ilioinguinal-iliohypogastric nerve block for inguinal herniotomies in ex-premature neonates. Singapore Med J. Nov. 2013;54(11):e218-20. X-1. [pmid: 24276107].
3644 Li D, Yang Y, Hao SY, et al. Hemorrhage risk, surgical management, and functional outcome of brainstem cavernous malformations. J Neurosurg. Oct. 2013;119(4):996-1008. X-1. [pmid: 23952884].
3645 Liu AH, Peng TM, Wu Z, et al. Clinical effectiveness of preoperative embolization for cerebellar hemangioblastoma. Asian Pac J Cancer Prev. 2013;14(9):5179-83. X-1. [pmid: 24175797].
3646 Loizzi M, De Palma A, Pagliarulo V, et al. Propranolol as first-line treatment of a severe subglottic haemangioma. Eur J Cardiothorac Surg. Jan. 2013;43(1):187-9. X-2. [pmid: 23045296].
3647 Luke RR, Malik SI, Hernandez AW, et al. Atypical imaging evolution of sturge-weber syndrome without facial nevus. Pediatr Neurol. Feb. 2013;48(2):143-5. X-1. [pmid: 23337009].
3648 Mahelkova G, Filous A, Odehnal M, et al. Corneal changes assessed using confocal microscopy in patients with unilateral buphthalmos. Invest Ophthalmol Vis Sci. Jun. 2013;54(6):4048-53. X-1. [pmid: 23696604].
3649 Mai HM, Zheng JW, Wang YA, et al. CD133 selected stem cells from proliferating infantile hemangioma and establishment of an in vivo mice model of hemangioma. Chin Med J (Engl). Jan. 2013;126(1):88-94. X-1, X-3. [pmid: 23286484].
3650 Mai JC, Ramanathan D, Kim LJ, et al. Surgical resection of cavernous malformations of the brainstem: evolution of a minimally invasive technique. World Neurosurg. May–Jun. 2013;79(5–6):691-703. X-1. [pmid: 23017589].
3651 Maleki M, Farhat AS, Nahidi Y, et al. A prevalence survey of pigmented and vascular birthmarks in 1000 newborns from the Northeast of Iran. Iranian Journal of Dermatology. 2013;16(64):64-8. X-2.
3652 Marqueling AL, Oza V, Frieden IJ, et al. Propranolol and infantile hemangiomas four years later: a systematic review. Pediatr Dermatol. Mar–Apr. 2013;30(2):182-91. X-1, X-2. [pmid: 23405852].
3653 Martin K, Blei F, Chamlin SL, et al. Propranolol treatment of infantile hemangiomas: anticipatory guidance for parents and caretakers. Pediatr Dermatol. Jan–Feb. 2013;30(1):155-9. X-2. [pmid: 23316721].
3654 Maruani A, Brown S, Lorette G, et al. Lack of effect of propranolol in the treatment of lymphangioma in two children. Pediatr Dermatol. May–Jun. 2013;30(3):383-5. X-1. [pmid: 23005572].
3655 Masetti R, Colecchia A, Rondelli R, et al. Benign hepatic nodular lesions after treatment for childhood cancer. J Pediatr Gastroenterol Nutr. Feb. 2013;56(2):151-5. X-1. [pmid: 22922376].
3656 Matuszczak E, Oksiuta M, Debek W, et al. Topical timolol gel for the treatment of residual facial hemangioma previously treated with propranolol. Pediatr Pol. February. 2013;88(1):116-9. X-2.
3657 Maya J, Blanco G, Maldonado R. Diffuse neonatal hemangiomatosis. Bol Med Hosp Infant Mex. 2013;70(1):35-40. X-1, X-2.
3658 Mayer M, Minichmayr A, Klement F, et al. Tocolysis with the beta-2-sympathomimetic hexoprenaline increases occurrence of infantile haemangioma in preterm infants. Arch Dis Child Fetal Neonatal Ed. Mar. 2013;98(2):F108-11. X-3. [pmid: 22611112].
3659 McGee P, Miller S, Black C, et al. Propranolol for infantile haemangioma: a review of current dosing regime in a regional paediatric hospital. Ulster Med J. Jan. 2013;82(1):16-20. X-4. [pmid: 23620625].
3660 McMahon P, Goddard D, Frieden IJ. Pediatric dermatology inpatient consultations: a retrospective study of 427 cases. J Am Acad Dermatol. Jun. 2013;68(6):926-31. X-1. [pmid: 23352278].
3661 Melo JN, Rotter A, Rivitti-Machado MC, et al. Propranolol for treatment of infantile hemangiomas. An Bras Dermatol. Nov–Dec. 2013;88(6 Suppl 1):220-3. X-3, X-4. [pmid: 24346925].
3662 Melo JN, Rotter A, Rivitti-Machado MC, et al. Propranolol for treatment of infantile hemangiomas. An Bras Dermatol. Nov–Dec. 2013;88(6 Suppl 1):220-3. X-4. [pmid: 24346925].
3663 Mendiratta V, Varghese B, Chander R, et al. Successful management of airway hemangioma with propranolol. Int J Dermatol. Jun. 2013;52(6):750-2. X-2. [pmid: 23679882].
3664 Mendoza-Cruz AC, Wargon O, Adams S, et al. Hypothalamic-pituitary-adrenal axis recovery following prolonged prednisolone therapy in infants. J Clin Endocrinol Metab. Dec. 2013;98(12):E1936-40. X-3, X-4. [pmid: 24081733].
3665 Menon P, Rao KL. Infantile hemangiomas--role of propranolol. Indian Pediatr. May. 8. 2013;50(5):521. X-3, X-4. [pmid: 23778734].
3666 Metwalley KA, Farghaly HS. Consumptive hypothyroidism in an Egyptian baby with benign neonatal hemangiomatosis: A case report. J Med Case Rep. 2013;7(48). X-1.
3667 Mezhir JJ, Fourman LT, Do RK, et al. Changes in the management of benign liver tumours: an analysis of 285 patients. HPB (Oxford). Feb. 2013;15(2):156-63. X-1. [pmid: 23297727].
3668 Mirza B, Shi WY, Phadke R, et al. Strawberries on the brain--intracranial capillary hemangioma: two case reports and systematic literature review in children and adults. World Neurosurg. Dec. 2013;80(6):900.e13-21. X-1. [pmid: 23247022].
3669 Miura A, Akagi S, Nakamura K, et al. Different sizes of centrilobular ground-glass opacities in chest high-resolution computed tomography of patients with pulmonary veno-occlusive disease and patients with pulmonary capillary hemangiomatosis. Cardiovasc Pathol. Jul–Aug. 2013;22(4):287-93. X-1. [pmid: 23312620].
3670 Moehrle M, Leaute-Labreze C, Schmidt V, et al. Topical timolol for small hemangiomas of infancy. Pediatr Dermatol. Mar–Apr. 2013;30(2):245-9. X-4. [pmid: 22471694].
3671 Mohindra S, Sodhi HS, Rane S. Tumefactive presentation of a supratentorial cavernous hemangioma: A report of two cases. J Pediatr Neurosci. September–December. 2013;8(3):232-4. X-1. [pmid: 24470821].
3672 Mullen M, Rabban J, Frieden IJ. Sacrococcygeal teratoma masquerading as congenital hemangioma. Pediatr Dermatol. Jan–Feb. 2013;30(1):112-6. X-1. [pmid: 22353016].
3673 Murphy RK, Reynolds MR, Mansur DB, et al. Gamma knife surgery for a hemangioma of the cavernous sinus in a child. J Neurosurg Pediatr. Jan. 2013;11(1):74-8. X-1. [pmid: 23082966].
3674 Najafi Sani M. Fatty liver disease in children. Iran J Pediatr. October. 2013;23:S17. X-1.
3675 Nakagawa T, Watanabe H, Nakazato K, et al. Periodic appearance and disappearance of a chest wall (serratus anterior development) cavernous hemangioma that was finally resected in a child. Gen Thorac Cardiovasc Surg. Aug. 2013;61(8):469-72. X-1. [pmid: 23011518].
3676 Nanduri J. Epigenetic factors and the pathophysiological manifestation of sleep apnea. Somnologie. October. 2013;17:18. X-1.
3677 Neri I, Piccolo V, Russo T, et al. Congenital primarily ulcerated hemangioma mimicking cleft lip. J Pediatr. Apr. 2013;162(4):882-e1. X-1, X-2. [pmid: 23375363].
3678 Nieuwenhuis K, de Laat PC, Janmohamed SR, et al. Infantile hemangioma: treatment with short course systemic corticosteroid therapy as an alternative for propranolol. Pediatr Dermatol. Jan–Feb. 2013;30(1):64-70. X-4. [pmid: 22958179].
3679 Nikoubashman O, Wiesmann M, Tournier-Lasserve E, et al. Natural history of cerebral dot-like cavernomas. Clin Radiol. Aug. 2013;68(8):e453-9. X-1. [pmid: 23663874].
3680 Niwald A, Lewandowska M, Moll A, et al. The rare case of periocular vascular malformations. Rzadki przypadek malformacji naczyniowej umiejscowionej w okolicy okologalkowej. Family Medicine and Primary Care Review. April\June. 2013;15(2):275-7. X-1.
3681 Niwald A, Lewandowska M, Moll A, et al. The rare case of periocular vascular malformations. Family Medicine and Primary Care Review. April\June. 2013;15(2):275-7. PMID: X-1.
3682 Niwald A, Lewandowska M, Orawiec B, et al. Interdisciplinary collaboration in the treatment of infantile hemangiomas. Wielospecjalistyczna wspolpraca medyczna w leczeniu naczyniakow wczesnodziecie{ogonek}cych. Family Medicine and Primary Care Review. July/September. 2013;15(3):502-3. X-2.
3683 Niwald A, Lewandowska M, Orawiec B, et al. Interdisciplinary collaboration in the treatment of infantile hemangiomas. Family Medicine and Primary Care Review. July/September. 2013;15(3):502-3. PMID: X-4.
3684 Nozaki T, Matsusako M, Mimura H, et al. Imaging of vascular tumors with an emphasis on ISSVA classification. Jpn J Radiol. Dec. 2013;31(12):775-85. X-3, X-4. [pmid: 24135879].
3685 O TM, Scheuermann-Poley C, Tan M, et al. Distribution, clinical characteristics, and surgical treatment of lip infantile hemangiomas. JAMA Facial Plast Surg. Jul–Aug. 2013;15(4):292-304. X-3, X-4. [pmid: 23752875].
3686 Osaki TH, Jakobiec FA, Mendoza PR, et al. Immunohistochemical investigations of orbital infantile hemangiomas and adult encapsulated cavernous venous lesions (malformation versus hemangioma). Ophthal Plast Reconstr Surg. May–Jun. 2013;29(3):183-95. X-1, X-2. [pmid: 23584448].
3687 Osorio MJ, Gajardo OP, Tapia MC. Propranolol for the treatment of subglotic hemangioma- A new therapeutic alternative. Hemangioma subglotico tratado con propranolol. Una nueva alternativa terapeutica. Caso clinico. Rev Chil Pediatr. April. 2013;84(2):182-8. X-2.
3688 Osorio MJ, Gajardo OP, Tapia MC. Propranolol for the treatment of subglotic hemangioma- A new therapeutic alternative. Revista Chilena de Pediatria. April. 2013;84(2):182-8. PMID: X-4.
3689 Ozcan KM, Ozdas T, Baran H, et al. Hemolacria: case report. Int J Pediatr Otorhinolaryngol. Jan. 2013;77(1):137-8. X-1. [pmid: 23040961].
3690 Ozdemir T, Arikan A. Postoperative apnea after inguinal hernia repair in formerly premature infants: impacts of gestational age, postconceptional age and comorbidities. Pediatr Surg Int. Aug. 2013;29(8):801-4. X-1. [pmid: 23780479].
3691 Ozeki M, Kanda K, Kawamoto N, et al. Propranolol as an alternative treatment option for pediatric lymphatic malformation. Tohoku J Exp Med. 2013;229(1):61-6. X-1. [pmid: 23257321].
3692 Ozkiris M, Aydin R, Seckin S, et al. A rare cause of pediatric nasal obstruction and epistaxis: Nasal septal mixed hemangioma. Int J Pediatr Otorhinolaryngol Extra. September. 2013;8(3):104-7. X-1, X-2.
3693 Parikh SR, Darrow DH, Grimmer JF, et al. Propranolol use for infantile hemangiomas: American Society of Pediatric Otolaryngology Vascular Anomalies Task Force practice patterns. JAMA Otolaryngol Head Neck Surg. Feb. 2013;139(2):153-6. X-1. [pmid: 23429945].
3694 Partanen TA, Vuola P, Jauhiainen S, et al. Neuropilin-2 and vascular endothelial growth factor receptor-3 are up-regulated in human vascular malformations. Angiogenesis. Jan. 2013;16(1):137-46. X-1. [pmid: 22961441].
3695 Patil A, Pattanshetti C, Varekar A, et al. Oral capillary haemangioma mimicking pyogenic granuloma: a challenge for diagnosis and management. BMJ Case Rep. 2013;2013. X-1, X-2. [pmid: 23417375].
3696 Phung J, Krogstad P, Mathern GW. Etiology associated with developing posthemispherectomy hydrocephalus after resection-disconnection procedures. J Neurosurg Pediatr. Nov. 2013;12(5):469-75. X-1. [pmid: 24011367].
3697 Popescu E, Trandafir V, Negru D, et al. Hemangioma of the parotid gland: case report. Rev Med Chir Soc Med Nat Iasi. Jan–Mar. 2013;117(1):227-32. X-2. [pmid: 24505920].
3698 Pride HB, Tollefson M, Silverman R. What’s new in pediatric dermatology?: part II. Treatment. J Am Acad Dermatol. Jun. 2013;68(6):899.e1-11. quiz 910–2. X-2. [pmid: 23680205].
3699 Qiu Y, Ma G, Lin X, et al. Treating protruding infantile hemangiomas with topical imiquimod 5% cream caused severe local reactions and disfiguring scars. Pediatr Dermatol. May–Jun. 2013;30(3):342-7. X-4. [pmid: 23046440].
3700 Quintard B, Gana K, Constant A, et al. Social isolation in parents of children with hemangiomas: effects of coping styles and emotional distress. Psychol Health Med. 2013;18(6):698-704. X-1. [pmid: 23387298].
3701 Radvany MG, Rigamonti D, Gailloud P. Angiographic detection of cerebral cavernous malformations with C-arm cone beam CT imaging in three patients. BMJ Case Rep. 2013;2013. X-1. [pmid: 23704473].
3702 Raigani S, Agamanolis D, Soldes OS, et al. Intra-abdominal (Type IV) sacrococcygeal teratoma presenting with buttock hemangioma. Pediatr Surg Int. Dec. 2013;29(12):1341-4. X-2. [pmid: 24057924].
3703 Rao AA, Naheedy JH, Chen JYY, et al. A clinical update and radiologic review of pediatric orbital and ocular tumors. Journal of Oncology. 2013;(975908). PMID: X-1, X-2.
3704 Rees A. CME/CE. CASE #1. Red scalp plaque with painful ulceration. Clinical Advisor. 2013;16(2):55-7. X-1.
3705 Restrepo R. Multimodality imaging of vascular anomalies. Pediatr Radiol. Mar. 2013;43(Suppl 1):S141-54. X-2. [pmid: 23478930].
3706 Robbins K. CME/CE Dermatologic Look A-likes. Vascular papules. Clinical Advisor. 2013;16(7):77-80. PMID: X-1.
3707 Rodriguez-Ayala G, de la Vega A, Correa-Rivas M, et al. Chorioangioma: an uncommon cause of hydramnios and consequent preterm labor in second trimester of pregnancy. Bol Asoc Med P R. 2013;105(1):36-9. X-1. [pmid: 23767383].
3708 Rosler J, Laute-Labreze C, Adams D. Medical therapy for vascular anomalies: From propranolol for infantile hemangioma to sirolimus for lymphangiomatosis. Monatsschr Kinderheilkd. November. 2013;161(11):1077. X-1, X-2.
3709 Rossler J, Haubold M, Gilsbach R, et al. beta1-Adrenoceptor mRNA level reveals distinctions between infantile hemangioma and vascular malformations. Pediatr Res. Apr. 2013;73(4 Pt 1):409-13. X-1, X-3. [pmid: 23370410].
3710 Saia M, Mantoan D, Buja A, et al. Increased rate of day surgery use for inguinal and femoral hernia repair in a decade of hospital admissions in the Veneto Region (north-east Italy): a record linkage study. BMC Health Serv Res. 2013;13:349. X-1. [pmid: 24028397].
3711 Sajan JA, Tibesar R, Jabbour N, et al. Assessment of pulsed-dye laser therapy for pediatric cutaneous vascular anomalies. JAMA Facial Plast Surg. Nov–Dec. 2013;15(6):434-8. X-4. [pmid: 24008312].
3712 Sakai K, Tanigawa K, Odate T, et al. A cardiac hemangioma treated by a right minithoracotomy approach with thoracoscopic assistance. Gen Thorac Cardiovasc Surg. 2013. Dec. 7. X-1. [pmid: 24317742].
3713 Savku E, Gunduz K. Our treatment results of circumscribed and diffuse choroidal hemangiomas. Si{dotless}ni{dotless}rli{dotless} ve difuz koroid hemanjiomlari{dotless}nda tedavi sonuclari{dotless}mi{dotless}z. Turk Oftalmoloiji Dergisi. 2013;43(4):216-20. X-1.
3714 Savku E, Gunduz K. Our treatment results of circumscribed and diffuse choroidal hemangiomas. Turk Oftalmoloiji Dergisi. 2013;43(4):216-20. PMID: X-1.
3715 Schwartz C, Grillhosl A, Schichor C, et al. Symptomatic cavernous malformations of the brainstem: functional outcome after microsurgical resection. J Neurol. Nov. 2013;260(11):2815-22. X-1. [pmid: 23974645].
3716 Sharma P, Williams R, Monaghan A. Spontaneous mandibular regeneration: another option for mandibular reconstruction in children?. Br J Oral Maxillofac Surg. Jul. 2013;51(5):e63-6. X-1. [pmid: 22578705].
3717 Shatriah I, Norazizah MA, Wan-Hitam WH, et al. Extensive facial and orbital infantile hemangiomas associated with high intraocular pressure. Pediatr Dermatol. Jan–Feb. 2013;30(1):151-4. X-2. [pmid: 22329437].
3718 Shehata N, Powell J, Dubois J, et al. Late rebound of infantile hemangioma after cessation of oral propranolol. Pediatr Dermatol. Sep–Oct. 2013;30(5):587-91. X-4. [pmid: 24016283].
3719 Shekhtman Y, Kim I, Riviello JJ Jr, et al. Focal resection of leptomeningeal angioma in a rare case of Sturge-Weber syndrome without facial nevus. Pediatr Neurosurg. 2013;49(2):99-104. X-1. [pmid: 24434861].
3720 Shields CL, Kaliki S, Al-Dahmash S, et al. Retinal vasoproliferative tumors: comparative clinical features of primary vs secondary tumors in 334 cases. JAMA Ophthalmol. Mar. 2013;131(3):328-34. X-1. [pmid: 23494037].
3721 Shirol SS, Nimbaragi G, Choukimath SM, et al. Lobular capillary hemangioma in a post-burn scar. Eur J Plast Surg. May. 2013;36(5):323-6. X-1, X-2.
3722 Siddique L, Sreenivasan A, Comi AM, et al. Importance of utilizing a sensitive free thyroxine assay in Sturge-Weber syndrome. J Child Neurol. Feb. 2013;28(2):269-74. X-1. [pmid: 23112245].
3723 Singla A, Brace O’Neill JE, Smith E, et al. Cavernous malformations of the brain after treatment for acute lymphocytic leukemia: presentation and long-term follow-up. J Neurosurg Pediatr. Feb. 2013;11(2):127-32. X-1. [pmid: 23215773].
3724 Siri L, Giordano L, Accorsi P, et al. Clinical features of Sturge-Weber syndrome without facial nevus: five novel cases. Eur J Paediatr Neurol. Jan. 2013;17(1):91-6. X-1. [pmid: 22819211].
3725 Smith A, Wargon O. Propranolol: A promising new treatment for infantile haemangioma. Medicine Today. April. 2013;14(4):61-3. PMID: X-1, X-2.
3726 Smith SC, Patel RM, Lucas DR, et al. Sinonasal lobular capillary hemangioma: a clinicopathologic study of 34 cases characterizing potential for local recurrence. Head Neck Pathol. Jun. 2013;7(2):129-34. X-1. [pmid: 23184353].
3727 Soejima Y, Shirabe K, Yoshizumi T, et al. Rex shunt for portal vein thrombosis after adult living donor liver transplantation. Fukuoka Igaku Zasshi. Nov. 2013;104(11):464-8. X-1. [pmid: 24620643].
3728 Soomro MZ, Arshad M, Ahmad S, et al. New arsenal for infantile haemangioma. Pakistan Journal of Medical and Health Sciences. 2013;7(2):578. X-2.
3729 Sorrell J, Chamlin SL. Topical timolol 0.5% gel-forming solution for small deep facial infantile hemangiomas. Pediatr Dermatol. Sep–Oct. 2013;30(5):592-4. X-3, X-4. [pmid: 23889228].
3730 Sreenivasan AK, Bachur CD, Lanier KE, et al. Urine vascular biomarkers in Sturge-Weber syndrome. Vasc Med. Jun. 2013;18(3):122-8. X-1. [pmid: 23720035].
3731 Steiner F, FitzJohn T, Tan ST. Surgical treatment for venous malformation. J Plast Reconstr Aesthet Surg. Dec. 2013;66(12):1741-9. X-1. [pmid: 24012651].
3732 Stiles JM, Amaya C, Rains S, et al. Targeting of beta adrenergic receptors results in therapeutic efficacy against models of hemangioendothelioma and angiosarcoma. PLoS One. 2013;8(3):e60021. X-1. [pmid: 23555867].
3733 Stiles JM, Rowntree RK, Amaya C, et al. Gene expression analysis reveals marked differences in the transcriptome of infantile hemangioma endothelial cells compared to normal dermal microvascular endothelial cells. Vasc Cell. 2013;5(1). X-1.
3734 Su IC, Krishnan P, Rawal S, et al. Magnetic resonance evolution of de novo formation of a cavernoma in a thrombosed developmental venous anomaly: a case report. Neurosurgery. Oct. 2013;73(4):E739-44. discussion E45. X-1. [pmid: 23728455].
3735 Sullivan CT, Christian SL, Shieh JTC, et al. X chromosome-inactivation patterns in 31 individuals with PHACE syndrome. Molecular Syndromology. March. 2013;4(3):114-8. X-1. [pmid: 23653582].
3736 Szavay P, Kurth R, Schaefer J, et al. A rare cause for extrahepatic biliary tract obstruction: juvenile hepatic hilar hemangioma. Eur J Pediatr Surg. Oct. 2013;23(5):415-7. X-2. [pmid: 23093433].
3737 Takasugi M, Fujii S, Shinohara Y, et al. Parenchymal hypointense foci associated with developmental venous anomalies: evaluation by phase-sensitive MR Imaging at 3T. AJNR Am J Neuroradiol. Oct. 2013;34(10):1940-4. X-1. [pmid: 23598832].
3738 Tanabe H, Sahashi K, Kitano T, et al. Effects of oral propranolol on circumscribed choroidal hemangioma: a pilot study. JAMA Ophthalmol. Dec. 2013;131(12):1617-22. X-1. [pmid: 24158615].
3739 Tanriverdi S, Terek D, Koroglu OA, et al. Neonatal status epilepticus controlled with levetiracetam at Sturge Weber syndrome. Brain Dev. Apr. 2013;35(4):367-71. X-1. [pmid: 22804835].
3740 Taran K, Bojanowska E, Przewratil P, et al. Childhood vascular lesions. Zmiany naczyniowe wieku rozwojowego. Family Medicine and Primary Care Review. April\June. 2013;15(2):181-2. X-2, X-3.
3741 Taran K, Bojanowska E, Przewratil P, et al. Childhood vascular lesions. Family Medicine and Primary Care Review. April\June. 2013;15(2):181-2. PMID: X-1.
3742 Tarchichi T, Wong K, Fisher MM, et al. Index of suspicion. Pediatr Rev. Jun. 2013;34(6):280-4. X-1. [pmid: 23729777].
3743 Thaivalappil S, Bauman N, Saieg A, et al. Propranolol-mediated attenuation of MMP-9 excretion in infants with hemangiomas. JAMA Otolaryngol Head Neck Surg. Oct. 2013;139(10):1026-31. X-3. [pmid: 24135743].
3744 Thakral A, Sharma SM. Cervicofacial hemangiomas: pattern, clinical management, and treatment outcomes. Oral Surg Oral Med Oral Pathol Oral Radiol. Dec. 2013;116(6):e457-64. X-4. [pmid: 22901655].
3745 Todorovich SM, Khan ZA. Elevated T-box 2 in infantile hemangioma stem cells maintains an adipogenic differentiation-competent state. Dermatoendocrinol. June–December. 2013;5(3):352-7. X-1. [pmid: 24516689].
3746 Tongsong T, Luewan S, Srisupundit K, et al. Hemodynamic assessment of indomethacin-induced fetal heart failure in high-output state. J Clin Ultrasound. Sep. 2013;41(7):438-40. X-1. [pmid: 23712591].
3747 Tsutsumi S, Ogino I, Miyajima M, et al. Genomic causes of multiple cerebral cavernous malformations in a Japanese population. J Clin Neurosci. May. 2013;20(5):667-9. X-1. [pmid: 23485406].
3748 Tu JB, Ma RZ, Dong Q, et al. Induction of apoptosis in infantile hemangioma endothelial cells by propranolol. Exp Ther Med. August. 2013;6(2):574-8. X-1, X-3. [pmid: 24137229].
3749 Vassallo P, Forte R, Di Mezza A, et al. Treatment of infantile capillary hemangioma of the eyelid with systemic propranolol. Am J Ophthalmol. Jan. 2013;155(1):165-70.e2. X-4. [pmid: 22967870].
3750 Wang L, Liu L, Wang G, et al. Congenital disseminated tufted angioma. J Cutan Pathol. Apr. 2013;40(4):405-8. X-1. [pmid: 23373432].
3751 Wang X, Tao Z, You C, et al. Extended resection of hemosiderin fringe is better for seizure outcome: a study in patients with cavernous malformation associated with refractory epilepsy. Neurol India. May–Jun. 2013;61(3):288-92. X-1. [pmid: 23860150].
3752 Watanabe Y, Kanamori Y, Uchida K, et al. Isolated hypoganglionosis: results of a nationwide survey in Japan. Pediatr Surg Int. Nov. 2013;29(11):1127-30. X-1. [pmid: 23975018].
3753 Wilmanska D, Antosik-Biernacka A, Przewratil P, et al. The role of MRI in diagnostic algorithm of cervicofacial vascular anomalies in children. Pol J Radiol. 2013;78(2):7-14. X-4. [pmid: 23807878].
3754 Wiseman DH, Mercer J, Tylee K, et al. Management of mucopolysaccharidosis type IH (Hurler’s syndrome) presenting in infancy with severe dilated cardiomyopathy: a single institution’s experience. J Inherit Metab Dis. Mar. 2013;36(2):263-70. X-1. [pmid: 22718273].
3755 Wu CH, Tsai TM, Liau JY, et al. Expansile kaposiform hemangioendothelioma deformed thoracic cage in an adult. Ann Thorac Surg. Nov. 2013;96(5):1854-7. X-1. [pmid: 24182473].
3756 Xie W, Xie H, Liu F, et al. Propranolol induces apoptosis of human umbilical vein endothelial cells through downregulation of CD147. Br J Dermatol. Apr. 2013;168(4):739-48. X-1. [pmid: 23528058].
3757 Yang GZ, Li J, Jin H. Giant mesenteric hemangioma of cavernous and venous mixed type: a rare case report. BMC Surg. 2013;13:50. X-1. [pmid: 24168418].
3758 Yao Q, Hu X, Huang G, et al. A case of diaphragmatic infantile hemangioma. J Perinatol. Jul. 2013;33(7):576-7. X-2. [pmid: 23803680].
3759 Yasui N, Koh K, Kato M, et al. Kasabach-Merritt phenomenon: a report of 11 cases from a single institution. J Pediatr Hematol Oncol. Oct. 2013;35(7):554-8. X-1. [pmid: 23389504].
3760 Yen KG, Hussein MA. Oral propranolol in the management of periocular capillary hemangiomas. Int Ophthalmol Clin. Summer. 2013;53(3):143-51. X-2. [pmid: 23751438].
3761 Yeo KK, Puscasiu E, Keating RF, et al. Durable response of intracranial cellular hemangioma to bevacizumab and temozolomide. J Neurosurg Pediatr. Jun. 2013;11(6):682-6. X-1. [pmid: 23540527].
3762 Yin J, Li H, Yin N, et al. Autologous fat grafting in lip reconstruction following hemangioma treatment. J Craniofac Surg. Mar. 2013;24(2):346-9. X-3, X-4. [pmid: 23524690].
3763 Yonekawa Y, MacDonald SM, Shildkrot Y, et al. Standard fractionation low-dose proton radiotherapy for diffuse choroidal hemangiomas in pediatric Sturge-Weber syndrome. J aapos. Jun. 2013;17(3):318-22. X-1. [pmid: 23618630].
3764 Yonekawa Y, Orbach DB, Trief D, et al. Intra-arterial chemotherapy for group C retinoblastoma with adjacent high-flow infantile hemangioma. Ophthalmic Surg Lasers Imaging Retina. Sep–Oct. 2013;44(5):490-2. X-3. [pmid: 24044714].
3765 Young PC, Korgenski K, Buchi KF. Early readmission of newborns in a large health care system. Pediatrics. May. 2013;131(5):e1538-44. X-1. [pmid: 23569092].
3766 Yuan SM, Hong ZJ, Chen HN, et al. Kaposiform hemangioendothelioma complicated by Kasabach-Merritt phenomenon: ultrastructural observation and immunohistochemistry staining reveal the trapping of blood components. Ultrastruct Pathol. Dec. 2013;37(6):452-5. X-1. [pmid: 24134598].
3767 Zhang L, Mai HM, Zheng J, et al. Preliminary study on plasma RPN concentration of patients with infantile hemangioma treated with propranolol. Int J Clin Exp Med. 01. Jun. 2013;6(5):342-5. X-2, X-3. [pmid: 23724152].
3768 Zhang P, Liu L, Cao Y, et al. Cerebellar cavernous malformations with and without associated developmental venous anomalies. BMC Neurol. 2013;13:134. X-1. [pmid: 24088363].
3769 Zheng JW, Zhang L, Zhou Q, et al. A practical guide to treatment of infantile hemangiomas of the head and neck. International Journal of Clinical and Experimental Medicine. 30. Oct. 2013;6(10):851-60. PMID: X-1, X-2. [pmid: 24260591].
3770 Zhou SY, Li HB, Mao YM, et al. Successful treatment of Kasabach-Merritt syndrome with transarterial embolization and corticosteroids. J Pediatr Surg. Mar. 2013;48(3):673-6. X-1, X-2. [pmid: 23480932].
3771 Zoller B, Ji J, Sundquist J, et al. Shared and nonshared familial susceptibility to surgically treated inguinal hernia, femoral hernia, incisional hernia, epigastric hernia, and umbilical hernia. J Am Coll Surg. Aug. 2013;217(2):289-99.e1. X-1. [pmid: 23870221].
3772 Zou HX, Jia J, Zhang WF, et al. Propranolol inhibits endothelial progenitor cell homing: a possible treatment mechanism of infantile hemangioma. Cardiovasc Pathol. May–Jun. 2013;22(3):203-10. X-1. [pmid: 23151525].
3773 Oral propranolol (Hemangeol) for infantile hemangioma. Med Lett Drugs Ther. Jul. 21. 2014;56(1447):61-2. X-3, X-4. [pmid: 25046418].
3774 Abelin Genevois K, Garin C, Solla F, et al. Surgical management of thoracolumbar kyphosis in mucopolysaccharidosis type 1 in a reference center. J Inherit Metab Dis. Jan. 2014;37(1):69-78. X-1. [pmid: 23813121].
3775 Aboagye J, Goldstein SD, Salazar JH, et al. Age at presentation of common pediatric surgical conditions: Reexamining dogma. J Pediatr Surg. Jun. 2014;49(6):995-9. X-1. [pmid: 24888850].
3776 Abrahim MJ, Gregory ND, Chennupati SK. Epithelioid hemangioma of the internal carotid artery: a case report supporting the reactive pathogenesis hypothesis of this vascular tumor. Int J Pediatr Otorhinolaryngol. Jul. 2014;78(7):1186-9. X-1, X-4. [pmid: 24837865].
3777 Adini I, Ghosh K, Adini A, et al. Melanocyte-secreted fibromodulin promotes an angiogenic microenvironment. J Clin Invest. Jan. 2. 2014;124(1):425-36. X-1. [pmid: 24355922].
3778 Admani S, Feldstein S, Gonzalez EM, et al. Beta blockers: An innovation in the treatment of infantile hemangiomas. Journal of Clinical and Aesthetic Dermatology. July. 2014;7(7):37-45. PMID: X-2, X-4. [pmid: 25053982].
3779 Aiello VD, Thomaz AM, Pozzan G, et al. Capillary hemangiomatosis like-lesions in lung biopsies from children with congenital heart defects. Pediatr Pulmonol. Mar. 2014;49(3):E82-5. X-1. [pmid: 24019248].
3780 Albuquerque JC, Magalhaes RA, Felix JA, et al. Treatment of children and adolescents with hemangioma using propranolol: preliminary results from a retrospective study. Sao Paulo Med J. 2014;132(1):48-54. X-3, X-4. [pmid: 24474080].
3781 Alimchandani M, Wang ZF, Miettinen M. CD30 expression in malignant vascular tumors and its diagnostic and clinical implications: a study of 146 cases. Appl Immunohistochem Mol Morphol. May–Jun. 2014;22(5):358-62. X-1. [pmid: 24805132].
3782 Angelini A, Mavrogenis AF, Gambarotti M, et al. Surgical treatment and results of 62 patients with epithelioid hemangioendothelioma of bone. J Surg Oncol. Jun. 2014;109(8):791-7. X-1. [pmid: 24643837].
3783 Asztalos L, Gray J, Chamlin SL. A 20-day-old boy with a blue skin lesion. Noninvoluting congenital hemangioma. Pediatr Ann. Jan. 1. 2014;43(1):e19-21. X-1. [pmid: 24549083].
3784 Barrick B, Lehman J, Tollefson M. Agminated pyogenic granuloma-like growth arising in a congenital hemangioma. JAMA Dermatol. Jul. 2014;150(7):781-3. X-1, X-4. [pmid: 24647574].
3785 Barrick B, Tollefson M. Clinical presentation, complications, and management of infantile hemangiomas : A case report and review of the literature. Journal of the Dermatology Nurses’ Association. January–February. 2014;6(1):20-4. PMID: X-4.
3786 Bassareo PP, Fanos V. Editorial: cardiovascular drug therapy in paediatric age: from metabolomics to clinical practice. Curr Med Chem. 2014;21(27):3107. X-1. [pmid: 24606512].
3787 Battagliotti C, Villarruel I. Differential diagnosis of chronic monoarthritis in chidren. Pediatric Rheumatology. 17. Sep. 2014;12. PMID: X-1.
3788 Belen B, Oguz A, Okur A, et al. A complication to be aware of: hyperkalaemia following propranolol therapy for an infant with intestinal haemangiomatozis. BMJ Case Rep. 2014;2014. X-1, X-2, X-4. [pmid: 24842358].
3789 Bellfield EJ, Beets-Shay L. Congenital infantile fibrosarcoma of the lip. Pediatr Dermatol. Jan–Feb. 2014;31(1):88-9. X-1. [pmid: 24138391].
3790 Berti I, Marchetti F, Skabar A, et al. Propranolol for cerebral cavernous angiomatosis: a magic bullet. Clin Pediatr (Phila). Feb. 2014;53(2):189-90. X-1. [pmid: 23804539].
3791 Bertocchini A, d’Ambrosio G, Grimaldi C, et al. Prehepatic portal hypertension with aneurysm of the portal vein: unusual but treatable malformative pattern. J Pediatr Surg. Mar. 2014;49(3):436-40. X-1. [pmid: 24650473].
3792 Blei F, McElhinney DB, Guarini A, et al. Cardiac screening in infants with infantile hemangiomas before propranolol treatment. Pediatr Dermatol. Jul–Aug. 2014;31(4):465-70. X-1. [pmid: 24889812].
3793 Blomstrand M, Holmberg E, Aberg MA, et al. No clinically relevant effect on cognitive outcomes after low-dose radiation to the infant brain: a population-based cohort study in Sweden. Acta Oncol. Sep. 2014;53(9):1143-50. X-1, X-4. [pmid: 24697746].
3794 Bonifazi E, Milano A, Foti C. Allergic contact dermatitis caused by topical propranolol in a 5-month-old baby. Contact Dermatitis. Oct. 2014;71(4):250-1. X-2, X-4. [pmid: 25231389].
3795 Burgmeier C, Dreyhaupt J, Schier F. Comparison of inguinal hernia and asymptomatic patent processus vaginalis in term and preterm infants. J Pediatr Surg. Sep. 2014;49(9):1416-8. X-1. [pmid: 25148750].
3796 Burne R, Taylor R. Monitoring propranolol treatment in periocular infantile haemangioma. Eye (Lond). Nov. 2014;28(11):1281-4. quiz 5. X-4. [pmid: 25323853].
3797 Canty KM, Horii KA, Ahmad H, et al. Multiple cutaneous and hepatic hemangiomas in infants. South Med J. Mar. 2014;107(3):159-64. X-3, X-4. [pmid: 24937333].
3798 Casiraghi A, Musazzi UM, Franceschini I, et al. Is propranolol compounding from tablet safe for pediatric use? Results from an experimental test. Minerva Pediatr. Oct. 2014;66(5):355-62. X-1. [pmid: 25253183].
3799 Celiksoy MH, Paksu MS, Atmaca S, et al. Management of subglottic hemangioma with propranolol. Am J Otolaryngol. May–Jun. 2014;35(3):414-6. X-2, X-4. [pmid: 24602457].
3800 Chang L, Ma G, Jin Y, et al. Recurrence of infantile hemangioma after termination of propranolol treatment. Ann Plast Surg. Feb. 2014;72(2):173-5. X-3, X-4. [pmid: 24406852].
3801 Chang TC, Estes R. Beta blocker treatment of infantile conjunctival hemangiomas--observations from 2 cases. J AAPOS. Feb. 2014;18(1):80-2. X-4. [pmid: 24568991].
3802 Charles E, Milroy C, Goldstraw NK, et al. A 3 month old infant with a “strawberry” red mass on her nose. Bmj. 2014;348:g3810. X-2. [pmid: 24923589].
3803 Choi J, Kim WJ, Park SW, et al. Photodynamic therapy suppresses tumor growth in an in vivo model of human hemangioma. Arch Dermatol Res. Jan. 2014;306(1):81-91. X-1. [pmid: 23784382].
3804 Choquet H, Nelson J, Pawlikowska L, et al. Association of cardiovascular risk factors with disease severity in cerebral cavernous malformation type 1 subjects with the common Hispanic mutation. Cerebrovasc Dis. 2014;37(1):57-63. X-1. [pmid: 24401931].
3805 Choudhari P, Ajmera A. Haemangioma of knee joint: A case report. Malaysian Orthopaedic Journal. July. 2014;8(2):43-5. PMID: X-1. [pmid: 25279092].
3806 Christou E, Parsi K. Non-involuting congenital haemangioma of the eyelid: successful treatment with fluroscopic ultrasound guided sclerotherapy and surgical excision. Phlebology. Feb. 2014;29(1):4-8. X-1. [pmid: 23188816].
3807 Costanzo L, Caruso E, Agati S, et al. Double aortic arch with hypoplastic right aortic arch and type C atresia of left aortic arch. Interact Cardiovasc Thorac Surg. Aug. 2014;19(2):331-3. X-1. [pmid: 24833732].
3808 Croteau SE, Kozakewich HP, Perez-Atayde AR, et al. Kaposiform lymphangiomatosis: a distinct aggressive lymphatic anomaly. J Pediatr. Feb. 2014;164(2):383-8. X-1. [pmid: 24252784].
3809 Cyrulnik AA, Dawkins MC, Smalberger GJ, et al. Kaposiform hemangioendothelioma with Kasabach-Merritt syndrome mistaken for child abuse in a newborn. Cutis. Mar. 2014;93(3):E17-20. X-1. [pmid: 24738105].
3810 de Graaf M, Knol MJ, Totte JE, et al. E-learning enables parents to assess an infantile hemangioma. J Am Acad Dermatol. May. 2014;70(5):893-8. X-1. [pmid: 24524882].
3811 de Graaf M, Raphael MF, Breugem CC, et al. Response from the authors of ‘Treatment of infantile haemangiomas with atenolol: comparison with a historical propranolol group’. J Plast Reconstr Aesthet Surg. Mar. 2014;67(3):411-2. X-1, X-2, X-4. [pmid: 24238766].
3812 Demertzis JL, Kyriakos M, Loomans R, et al. Synovial hemangioma of the hip joint in a pediatric patient. Skeletal Radiol. Jan. 2014;43(1):107-13. X-1. [pmid: 24061493].
3813 Deng X, Wang K, Wu L, et al. Intraspinal hemangioblastomas: analysis of 92 cases in a single institution: clinical article. J Neurosurg Spine. Aug. 2014;21(2):260-9. X-1. [pmid: 24836658].
3814 Di Giannatale A, Morana G, Rossi A, et al. Natural history of cavernous malformations in children with brain tumors treated with radiotherapy and chemotherapy. J Neurooncol. Apr. 2014;117(2):311-20. X-1. [pmid: 24515423].
3815 Elder PT, Cairns C, Dick A, et al. A severe bleeding diathesis in a 6-year-old girl secondary to a composite diagnosis of splenic hemangiomatosis and small bowel lymphangiomatosis. J Pediatr Hematol Oncol. Jul. 2014;36(5):404-6. X-1. [pmid: 24136025].
3816 Emiralioglu N, Oguz B, Akyuz C, et al. Successful treatment of pulmonary hemangioma with propranolol. Pediatr Pulmonol. Aug. 2014;49(8):829-33. X-2, X-4. [pmid: 24574160].
3817 Endele S, Kraus C, Reis A, et al. A novel de novo mutation in PIK3CA in a boy with megalencephaly, hemangiomas and multiple anomalies. Medizinische Genetik. March. 2014;26(1):135-6. PMID: X-1, X-4.
3818 Engberg Damsgaard T, Vandborg Bjerre J. Haemangioma and propranolol. J Plast Surg Hand Surg. Feb. 2014;48(1):86-8. X-2, X-4. [pmid: 23837510].
3819 England RW, Hardy KL, Kitajewski AM, et al. Propranolol promotes accelerated and dysregulated adipogenesis in hemangioma stem cells. Ann Plast Surg. Sep. 2014;73(Suppl 1):S119-24. X-1. [pmid: 25115372].
3820 Eyssartier E, Ang P, Bonnemaison E, et al. Characteristics of endobronchial primitive tumors in children. Pediatr Pulmonol. Jun. 2014;49(6):E121-5. X-1. [pmid: 24532419].
3821 Frischer JM, Gatterbauer B, Holzer S, et al. Microsurgery and radiosurgery for brainstem cavernomas: effective and complementary treatment options. World Neurosurg. Mar–Apr. 2014;81(3–4):520-8. X-1. [pmid: 24440458].
3822 Funk T, Prok L, Brown LD, et al. Multifocal vascular tumors and fetal hydrops. J Pediatr. May. 2014;164(5):1214-8. X-1, X-2. [pmid: 24433827].
3823 Garcia-Monaco RD, Giachetti A. Infantile hemangioma or kaposiform hemangioendothelioma?. J Vasc Interv Radiol. May. 2014;25(5):810. X-3, X-4. [pmid: 24745913].
3824 Gawad N, Davies DA, Langer JC. Determinants of wait time for infant inguinal hernia repair in a Canadian children’s hospital. J Pediatr Surg. May. 2014;49(5):766-9. X-1. [pmid: 24851766].
3825 Gelmetti C, Cavalli R. Beta-blockers for hemangiomas. Giornale Italiano di Dermatologia e Venereologia. 01. Dec. 2014;149(6):703-9. PMID: X-1, X-2, X-4. [pmid: 25366892].
3826 George E. The Challenges of Anesthesia and Trisomy 13. International Student Journal of Nurse Anesthesia. 2014;13(3):33-5. Language: English. Entry Date: 20150206. Revision Date: 20150213. Publication Type: journal article. X-1.
3827 Glasman P, Chandna A, Nayak H, et al. Propranolol and periocular capillary hemangiomas: assessment of refractive effect. J Pediatr Ophthalmol Strabismus. May–Jun. 2014;51(3):165-70. X-4. [pmid: 24877527].
3828 Gordillo GM, Biswas A, Khanna S, et al. Dicer knockdown inhibits endothelial cell tumor growth via microRNA 21a-3p targeting of Nox-4. J Biol Chem. Mar. 28. 2014;289(13):9027-38. X-1. [pmid: 24497637].
3829 Greco A, D’Erme AM, Zamma Gallarati B, et al. A further experience of propranolol for severe infantile hemangiomas of the face: an observational study. Dermatol Ther. Jul–Aug. 2014;27(4):198-202. X-4. [pmid: 24548454].
3830 Haanstra HB, Kupers EM, van der Vleuten CJM. An infant with multiple hemangiomas. Tijdschrift voor Kindergeneeskunde. 2014;82(6):227-8. PMID: X-4.
3831 Han EC, Kim SH, Kim HY, et al. Gastrointestinal hemangioma in childhood: A rare cause of gastrointestinal bleeding. Korean J Pediatr. May. 2014;57(5):245-9. X-1, X-2. [pmid: 25045368].
3832 Han JS, Lee MW, Choi JH, et al. Congenital myofibroma mimicking an infantile hemangioma in an infant. Indian Journal of Dermatology. May–June. 2014;59(3):317. PMID: X-1. [pmid: 24891688].
3833 Harman M, Nart D, Acar T, et al. Primary mesenchymal liver tumors: radiological spectrum, differential diagnosis, and pathologic correlation. Abdom Imaging. 2014. Oct. 14. X-1, X-2. [pmid: 25311993].
3834 Heaton P, Kennedy C, Amin S. Severe infantile haemangioma: complications and treatment. J Paediatr Child Health. Apr. 2014;50(4):325. 30. X-3, X-4. [pmid: 24698064].
3835 Hermans DJ, Maal TJ, Berge SJ, et al. Three-dimensional stereophotogrammetry: a novel method in volumetric measurement of infantile hemangioma. Pediatr Dermatol. Jan–Feb. 2014;31(1):118-22. X-3, X-4. [pmid: 24106998].
3836 Huntoon K, Lonser RR. Findings from the natural history of central nervous system hemangioblastomas in von Hippel-Lindau disease. Neurosurgery. Aug. 2014;61(Suppl 1):N159-62. X-1. [pmid: 25032659].
3837 Hussain S, Butt IH, Ali S. Treatment of bleeding nasal polyp. Pakistan Journal of Medical and Health Sciences. January–March. 2014;8(1):25-7. X-1.
3838 Iacovella C, Chandrasekaran N, Khalil A, et al. Fetal and placental vascular tumors: persistent fetal hyperdynamic status predisposes to poorer long-term neurodevelopmental outcome. Ultrasound Obstet Gynecol. Jun. 2014;43(6):658-61. X-1. [pmid: 24307134].
3839 Imada T, Okutani R, Oda Y. Anesthesia for aortic reconstruction in a child with PHACE syndrome. J Anesth. Dec. 2014;28(6):919-23. X-1, X-4. [pmid: 24748401].
3840 Inal FY, Celebi S, Uysal AI, et al. Comparison of the effects of laparoscopic and open repair techniques on postoperative pain and analgesic consumption in pediatric unilateral inguinal hernia. Tek tarafli{dotless} Inguinal herni operasyonu uygulanan cocuklarda aci{dotless}k ve laparoskopik cerrahi tekniklerinin anestezi suresi, postoperatif agri{dotless} ve analjezik tuketimi uzerine etkilerinin karsi{dotless}lasti{dotless}ri{dotless}lmasi{dotless}. Haseki Tip Bulteni. 2014;52(2):84-8. X-1.
3841 Inal FY, Celebi S, Uysal AI, et al. Comparison of the effects of laparoscopic and open repair techniques on postoperative pain and analgesic consumption in pediatric unilateral inguinal hernia. Haseki Tip Bulteni. 2014;52(2):84-8. X-1.
3842 Jacobson D, Hollinger S, Seelisch J, et al. Case 1: A premature infant with stridor. Paediatrics and Child Health (Canada). 01. Oct. 2014;19(8):401-2. PMID: X-4.
3843 Jakimovski D, Schneider H, Frei K, et al. Bleeding propensity of cavernous malformations: impact of tight junction alterations on the occurrence of overt hematoma. J Neurosurg. Sep. 2014;121(3):613-20. X-1. [pmid: 25014440].
3844 Jeng MR, Fuh B, Blatt J, et al. Malignant transformation of infantile hemangioma to angiosarcoma: response to chemotherapy with bevacizumab. Pediatr Blood Cancer. Nov. 2014;61(11):2115-7. X-2, X-4. [pmid: 24740626].
3845 Joyce JC, Keith PJ, Szabo S, et al. Superficial hemosiderotic lymphovascular malformation (hobnail hemangioma): a report of six cases. Pediatr Dermatol. May–Jun. 2014;31(3):281-5. X-1. [pmid: 24601986].
3846 Kai L, Wang Z, Yao W, et al. Sirolimus, a promising treatment for refractory Kaposiform hemangioendothelioma. J Cancer Res Clin Oncol. Mar. 2014;140(3):471-6. X-1. [pmid: 24464150].
3847 Kajbafzadeh AM, Sabetkish S, Mahboubi AH, et al. Single incisional approach for reconstruction of hypospadias and concomitant inguinal hernia. J Pediatr Urol. Feb. 2014;10(1):45-51. X-1. [pmid: 23806276].
3848 Kamath MP, Bhojwani KM, Bhandarkar AM, et al. Angiolymphoid hyperplasia with eosinophilia of root of nose: A rare phenomenon. J Clin Diagn Res. 15. Mar. 2014;8(3):144-5. X-1.
3849 Kamson DO, Juhasz C, Shin J, et al. Patterns of structural reorganization of the corticospinal tract in children with Sturge-Weber syndrome. Pediatr Neurol. Apr. 2014;50(4):337-42. X-1. [pmid: 24507695].
3850 Kaushik S, Kaur S, Pandav SS, et al. Intractable choroidal effusion with exudative retinal detachment in Sturge-Weber syndrome. JAMA Ophthalmol. Sep. 2014;132(9):1143-4. X-1. [pmid: 25210989].
3851 Khorsand K, Backus S, Sidbury R. What’s New in Pediatric Dermatology. Current Dermatology Reports. 2014;3(4):187-90. PMID: X-1, X-2.
3852 Kilicaslan A, Erol A, Gundeslioglu AO, et al. Airway management and anesthesia in posterior fossa malformations, hemangiomas, arterial anomalies, coarctation of the aorta and cardiac defects and eye abnormalities syndrome: A case with laryngotracheal hemangiomas. Journal of Anaesthesiology Clinical Pharmacology. 01. Oct. 2014;30(4):575-7. PMID: X-4.
3853 Kim H, Yi JH, Kwon HJ, et al. Therapeutic outcomes of retinal hemangioblastomas. Retina. Dec. 2014;34(12):2479-86. X-1. [pmid: 25072649].
3854 Kim J, Kim CH, Chung CK. Longitudinal changes in seizure outcomes after resection of cerebral cavernous malformations in patients presenting with seizures: a long-term follow-up of 46 patients. Acta Neurochir (Wien). Aug. 2014;156(8):1539-47. discussion 46–7. X-1. [pmid: 24829156].
3855 Kishi K, Morita N, Terada T, et al. Physiological interpretations of radiographic findings on malformations of small veins: seriality of cisterns, communications to systemic veins and relationship to muscles. Phlebology. Feb. 2014;29(1):9-15. X-1. [pmid: 23223003].
3856 Koga H, Makimura M, Tanaka H, et al. Placental mesenchymal dysplasia and fetal hematologic disorder. J Pediatr Hematol Oncol. Aug. 2014;36(6):e389-91. X-1. [pmid: 23799527].
3857 Kum JJ, Khan ZA. Propranolol inhibits growth of hemangioma-initiating cells but does not induce apoptosis. Pediatr Res. Mar. 2014;75(3):381-8. X-1. [pmid: 24296797].
3858 Larralde M, Abad ME, Luna PC, et al. Capillary malformation-arteriovenous malformation: a clinical review of 45 patients. Int J Dermatol. Apr. 2014;53(4):458-61. X-1. [pmid: 24168113].
3859 Lee AH, Hardy KL, Goltsman D, et al. A retrospective study to classify surgical indications for infantile hemangiomas. J Plast Reconstr Aesthet Surg. Sep. 2014;67(9):1215-21. X-3, X-4. [pmid: 24923525].
3860 Lee PW, Frieden IJ, Streicher JL, et al. Characteristics of noninvoluting congenital hemangioma: a retrospective review. J Am Acad Dermatol. May. 2014;70(5):899-903. X-1, X-3. [pmid: 24630000].
3861 Lee YC, Hsu YH, Yang SH, et al. Congenital Eyelid Rhabdomyosarcoma. Ophthal Plast Reconstr Surg. 2014. Sep. 11. X-1. [pmid: 25216197].
3862 Len A, Roth Y, Mandelberg A, et al. Supraglottic hemangioma in an infant. International Journal of Pediatric Otorhinolaryngology Extra. September. 2014;9(3):114-5. PMID: X-4.
3863 Levitt M, Coumou AD, Groeneveld L, et al. Propranolol as first-line treatment in orbital infantile haemangiomas: a case series. Orbit. Jun. 2014;33(3):178-83. X-4. [pmid: 24568543].
3864 Li D, Hao SY, Tang J, et al. Surgical management of pediatric brainstem cavernous malformations. J Neurosurg Pediatr. May. 2014;13(5):484-502. X-1. [pmid: 24679081].
3865 Li D, Hao SY, Tang J, et al. Clinical course of untreated pediatric brainstem cavernous malformations: hemorrhage risk and functional recovery. J Neurosurg Pediatr. May. 2014;13(5):471-83. X-1, X-3. [pmid: 24635136].
3866 Livne O, Harel R, Hadani M, et al. Intraoperative magnetic resonance imaging for resection of intra-axial brain lesions: a decade of experience using low-field magnetic resonance imaging, Polestar N-10, 20, 30 systems. World Neurosurg. Nov. 2014;82(5):770-6. X-1. [pmid: 24518885].
3867 Lonser RR, Butman JA, Huntoon K, et al. Prospective natural history study of central nervous system hemangioblastomas in von Hippel-Lindau disease. J Neurosurg. May. 2014;120(5):1055-62. X-1. [pmid: 24579662].
3868 Ma G, Wu P, Lin X, et al. Fractional carbon dioxide laser-assisted drug delivery of topical timolol solution for the treatment of deep infantile hemangioma: a pilot study. Pediatr Dermatol. May–Jun. 2014;31(3):286-91. X-4. [pmid: 24602019].
3869 Ma X, Zhao T, Ouyang T, et al. Propranolol enhanced adipogenesis instead of induction of apoptosis of hemangiomas stem cells. Int J Clin Exp Pathol. 2014;7(7):3809-17. X-1. [pmid: 25120757].
3870 Maguiness S, Uihlein LC, Liang MG, et al. Rapidly Involuting Congenital Hemangioma with Fetal Involution. Pediatr Dermatol. 2014. Dec. 10. X-1. [pmid: 25492638].
3871 Malhotra Y, Yang CS, McNamara J, et al. Congenital kaposiform hemangioendothelioma with Kasabach-Merritt phenomenon successfully treated with low-dose radiation therapy. Pediatr Dermatol. Sep–Oct. 2014;31(5):595-8. X-1. [pmid: 23458157].
3872 Manunza F, Ferreli C, Cordisco MR, et al. Possible PHACES syndrome: Segmental thoracobrachial hemangioma associated with extracutaneous manifestations. European Journal of Pediatric Dermatology. April–June. 2014;24(2):78-81. PMID: X-4.
3873 Mardegan V, Doglioni N, De Bernardo G, et al. Kasabach-Merritt phenomenon in a neonatal kaposiform haemangioendothelioma. BMJ Case Rep. 2014;2014. X-1. [pmid: 25115785].
3874 McSwiney E, Murray D, Murphy M. Propranolol therapy for cutaneous infantile haemangiomas initiated safely as a day-case procedure. Eur J Pediatr. Jan. 2014;173(1):63-8. X-4. [pmid: 23933667].
3875 Mettin RR, Merkenschlager A, Bernhard MK, et al. Wide spectrum of clinical manifestations in children with tuberous sclerosis complex--follow-up of 20 children. Brain Dev. Apr. 2014;36(4):306-14. X-1. [pmid: 23751858].
3876 Mikati AG, Tan H, Shenkar R, et al. Dynamic permeability and quantitative susceptibility: related imaging biomarkers in cerebral cavernous malformations. Stroke. Feb. 2014;45(2):598-601. X-1. [pmid: 24302484].
3877 Mohammed JA, Balma-Mena A, Chakkittakandiyil A, et al. Infrared thermography to assess proliferation and involution of infantile hemangiomas: a prospective cohort study. JAMA Dermatol. Sep. 2014;150(9):964-9. X-3, X-4. [pmid: 25073587].
3878 Mridha AR, Kinra P, Sable M, et al. Epithelioid hemangioma of distal femoral epiphysis in a patient with congenital talipes equinovarus. Malays J Pathol. Apr. 2014;36(1):63-6. X-1. [pmid: 24763238].
3879 Nakajima M, Sugano H, Iimura Y, et al. Sturge-Weber syndrome with spontaneous intracerebral hemorrhage in childhood. J Neurosurg Pediatr. Jan. 2014;13(1):90-3. X-1. [pmid: 24160667].
3880 Nakaya T, Morita K, Kurata A, et al. Multifocal kaposiform hemangioendothelioma in multiple visceral organs: an autopsy of 9-day-old female baby. Hum Pathol. Aug. 2014;45(8):1773-7. X-1. [pmid: 24931465].
3881 Nayyar S, Liaqat N, Sultan N, et al. Cavernous haemangioma mimicking as clitoral hypertrophy. Afr J Paediatr Surg. Jan–Mar. 2014;11(1):65-6. X-1. [pmid: 24647298].
3882 Nevoux J, Nowak C, Vellin JF, et al. Management of endolymphatic sac tumors: sporadic cases and von Hippel-Lindau disease. Otol Neurotol. Jun. 2014;35(5):899-904. X-1. [pmid: 24662627].
3883 Nguyen R, Kim J, Shet N, et al. A 2-year-old boy with knee pain, fever, and multiple birthmarks. Clin Pediatr (Phila). Jan. 2014;53(1):98-100. X-2. [pmid: 24317699].
3884 Northcutt AD, Tschen JA. The routine use of iron stain for biopsies of dermatoses of the legs. J Cutan Pathol. 2014. Feb. 12. X-1. [pmid: 24517257].
3885 O’Brien A, Bompadre V, Hale S, et al. Musculoskeletal function in patients with mucopolysaccharidosis using the pediatric outcomes data collection instrument. J Pediatr Orthop. Sep. 2014;34(6):650-4. X-1. [pmid: 24598580].
3886 Oliveira CC, Marques ME. Meningitis and pneumococcal pyomyositis in a child with intramuscular hemangiomas: an autopsy case report. Int J Clin Exp Pathol. 2014;7(7):4523-7. X-1, X-4. [pmid: 25120847].
3887 Ozcan HN, Oguz B, Talim B, et al. Unusual splenic hemangioma of a pediatric patient: hypointense on T2-weighted image. Clin Imaging. Jul–Aug. 2014;38(4):553-5. X-2, X-4. [pmid: 24667046].
3888 Ozyoruk D, Zengin E. Propranolol treatment of complicated hemangiomas. Indian J Pediatr. Apr. 2014;81(4):368-70. X-4. [pmid: 23832624].
3889 Patel NJ, Bauman NM. How should propranolol be initiated for infantile hemangiomas: inpatient versus outpatient?. Laryngoscope. Jun. 2014;124(6):1279-81. X-2. [pmid: 24347141].
3890 Phillips RJ, Lokmic Z, Crock CM, et al. Infantile haemangiomas that failed treatment with propranolol: clinical and histopathological features. J Paediatr Child Health. Aug. 2014;50(8):619-25. X-3, X-4. [pmid: 24905852].
3891 Piccillo GA, Saitta R, Mondati EGM, et al. The dramatic and unforgettable story of Eusebio and his children. Italian Journal of Medicine. May. 2014;8:102. X-1.
3892 Prada F, Perin A, Martegani A, et al. Intraoperative contrast-enhanced ultrasound for brain tumor surgery. Neurosurgery. May. 2014;74(5):542-52. discussion 52. X-1. [pmid: 24598809].
3893 Pranitha V, Puppala N, Deshmukh SN, et al. Cavernous hemangioma of tongue: Management of two cases. Journal of Clinical and Diagnostic Research. Octeber. 2014;8(10):ZD15-ZD7. PMID: X-1.
3894 Puri A, Pruthi M, Gulia A. Outcomes after limb sparing resection in primary malignant pelvic tumors. Eur J Surg Oncol. Jan. 2014;40(1):27-33. X-1. [pmid: 24239184].
3895 Rafiq U, Shah AA, Rizwan M. Treatment of infantile hemangioma with intense pulsed-light: A case report. Journal of Pakistan Association of Dermatologists. 2014;24(3):267-9. PMID: X-4.
3896 Raju A, Khundkar R. Reply to ‘Treatment of infantile haemangiomas with atenolol: comparison with a historical propranolol group.’. J Plast Reconstr Aesthet Surg. Mar. 2014;67(3):412-3. X-2, X-4. [pmid: 24200706].
3897 Rangwala S, Wysong A, Tollefson MM, et al. Rapidly involuting congenital hemangioma associated with profound, transient thrombocytopenia. Pediatr Dermatol. May–Jun. 2014;31(3):402-4. X-1. [pmid: 22937785].
3898 Rapini N, Lidano R, Pietrosanti S, et al. De novo 13q13.3–21.31 deletion involving RB1 gene in a patient with hemangioendothelioma of the liver. Ital J Pediatr. 2014;40:5. X-1. [pmid: 24433316].
3899 Rasul S. Clinical characteristics and risk factors for infantile hemangioma--a case control study. Eur J Pediatr Surg. Feb. 2014;24(1):102-12. X-1. [pmid: 24008548].
3900 Rehder KJ, Cheifetz IM, Willson DF, et al. Perceptions of 24/7 in-hospital intensivist coverage on pediatric housestaff education. Pediatrics. Jan. 2014;133(1):88-95. X-1. [pmid: 24323998].
3901 Rhein LM, Dobson NR, Darnall RA, et al. Effects of caffeine on intermittent hypoxia in infants born prematurely: a randomized clinical trial. JAMA Pediatr. Mar. 2014;168(3):250-7. X-1. [pmid: 24445955].
3902 Rialon KL, Murillo R, Fevurly RD, et al. Risk factors for mortality in patients with multifocal and diffuse hepatic hemangiomas. J Pediatr Surg. 2014. Dec. 5. X-3, X-4. [pmid: 25783331].
3903 Rodgaard JC, Foged T, Bjerre JV, et al. Treatment of infantile hemangiomas before and after the introduction of propranolol: A retrospective study. Eur J Plast Surg. April. 2014;37(4):195-200. X-3, X-4.
3904 Rodriguez-Nunez A, Lopez-Herce J, del Castillo J, et al. Shockable rhythms and defibrillation during in-hospital pediatric cardiac arrest. Resuscitation. Mar. 2014;85(3):387-91. X-1. [pmid: 24291590].
3905 Ruth N, Kirk J, Kelly D. Hepatic haemangioma and conjugated hyperbilirubinemia. J Pediatr Gastroenterol Nutr. Feb. 2014;58(2):e17-9. X-3, X-4. [pmid: 22955451].
3906 Sachdeva S, Kapoor R, Paul P, et al. Recurrent meningitis with upper airway obstruction in a child: Frontonasal encephalocele - A case report. Journal of Clinical and Diagnostic Research. 2014;8(8):PD01-PD2. PMID: X-1. [pmid: 25302244].
3907 Sajad P, Hassan I, Jehangir M, et al. A rare case of deep hemangioma presenting as a periorbital swelling and its excellent response to intralesional steroids. Journal of Pakistan Association of Dermatologists. 2014;24(3):263-6. PMID: X-4.
3908 Saka R, Okuyama H, Sasaki T, et al. Laparoscopic treatment of pediatric hydrocele and the evaluation of the internal inguinal ring. J Laparoendosc Adv Surg Tech A. Sep. 2014;24(9):664-8. X-1. [pmid: 24959922].
3909 Schneider C, Hidalgo ET, Schmitt-Mechelke T, et al. Quality of life after surgical treatment of primary intramedullary spinal cord tumors in children. J Neurosurg Pediatr. Feb. 2014;13(2):170-7. X-1. [pmid: 24359210].
3910 Selmin A, Foltran F, Chiarelli S, et al. An epidemiological study investigating the relationship between chorangioma and infantile hemangioma. Pathol Res Pract. Sep. 2014;210(9):548-53. X-1. [pmid: 24836731].
3911 Semkova K, Kazandjieva J. Rapid complete regression of an early infantile hemangioma with topical timolol gel. Int J Dermatol. Feb. 2014;53(2):241-2. X-2, X-4. [pmid: 24261914].
3912 Shields JA, Pellegrini M, Kaliki S, et al. Retinal vasoproliferative tumors in 6 patients with neurofibromatosis type 1. JAMA Ophthalmol. Feb. 2014;132(2):190-6. X-1. [pmid: 24357334].
3913 Shih TY. Transverse testicular ectopia associated with hemiscrotal hemangioma. Formosan Journal of Surgery. 01. Dec. 2014;47(6):240-2. PMID: X-1, X-4.
3914 Singh A, Pugh A, Sharif K, et al. A preterm infant with progressive abdominal distension. Infant. 2014;10(2):65-8. PMID: X-1.
3915 Singh J, Priyadarshi S, Yadav SS, et al. Large labial hemangioma presenting as lower urinary tract symptom: A Case Report. Indian J Urol. January. 2014;30:S143. X-1.
3916 Smadja DM, Guerin CL, Boscolo E, et al. alpha6-Integrin is required for the adhesion and vasculogenic potential of hemangioma stem cells. Stem Cells. Mar. 2014;32(3):684-93. X-1. [pmid: 24022922].
3917 Sohns JM, Schwarz A, Menke J, et al. Prevalence and clinical relevance of extracardiac findings at cardiac MRI. J Magn Reson Imaging. Jan. 2014;39(1):68-76. X-1. [pmid: 23589475].
3918 Stass-Isern M. Periorbital and orbital infantile hemangiomas. Int Ophthalmol Clin. Summer. 2014;54(3):73-82. X-3, X-4. [pmid: 24879105].
3919 Sugano H, Nakanishi H, Nakajima M, et al. Posterior quadrant disconnection surgery for Sturge-Weber syndrome. Epilepsia. May. 2014;55(5):683-9. X-1. [pmid: 24621276].
3920 Sun J, Karmazyn B, Lin J, et al. Newborn with an underrecognized triad: skin lesion, abdominal distention, and hypothyroidism. J Pediatr. Feb. 2014;164(2):419-20. X-2. [pmid: 24183208].
3921 Torres-Pradilla M, Baselga E. Failure of intralesional propranolol in infantile hemangiomas. Pediatr Dermatol. Mar–Apr. 2014;31(2):156-8. X-4. [pmid: 24000875].
3922 Tu JB, Li QY, Jiang F, et al. Pingyangmycin stimulates apoptosis in human hemangioma-derived endothelial cells through activation of the p53 pathway. Mol Med Rep. Jul. 2014;10(1):301-5. X-1. [pmid: 24789513].
3923 Uihlein LC, Garzon MC, Goodwin G, et al. Growth hormone replacement in patients with PHACE association and hypopituitarism. Pediatr Dermatol. May–Jun. 2014;31(3):337-40. X-1, X-4. [pmid: 24602073].
3924 Ulrich NH, Kockro RA, Bellut D, et al. Brainstem cavernoma surgery with the support of pre- and postoperative diffusion tensor imaging: initial experiences and clinical course of 23 patients. Neurosurg Rev. Jul. 2014;37(3):481-91. discussion 92. X-1. [pmid: 24801720].
3925 Urs AN, Martinelli M, Rao P, et al. Diagnostic and therapeutic utility of double-balloon enteroscopy in children. J Pediatr Gastroenterol Nutr. Feb. 2014;58(2):204-12. X-1. [pmid: 24126830].
3926 Verma SB, Wollina U. Infantile perianal pyramidal protrusion with coexisting perineal and perianal hemangiomas: A fortuitous association or incomplete PELVIS syndrome?. Indian J Dermatol. January–February. 2014;59(1):71-4. X-1, X-2. [pmid: 24470664].
3927 von der Brelie C, Kuczaty S, von Lehe M. Surgical management and long-term outcome of pediatric patients with different subtypes of epilepsy associated with cerebral cavernous malformations. J Neurosurg Pediatr. Jun. 2014;13(6):699-705. X-1. [pmid: 24702617].
3928 Wadhwa R, Toms J, Chittiboina P, et al. Dysphagia following posterior fossa surgery in adults. World Neurosurg. Nov. 2014;82(5):822-7. X-1. [pmid: 23318935].
3929 Wang P, Zhou W, Tao L, et al. Clinical analysis of Kasabach-Merritt syndrome in 17 neonates. BMC Pediatr. 2014;14:146. X-4. [pmid: 24920221].
3930 Weil AG, Bhatia S. Resection of a ventral intramedullary cervical spinal cord cavernous malformation through an anterior approach. Neurosurg Focus. Sep. 2014;37(Suppl 2). Video 18. X-1. [pmid: 25175579].
3931 Weitz NA, Bayer ML, Baselga E, et al. The “biker-glove” pattern of segmental infantile hemangiomas on the hands and feet. J Am Acad Dermatol. Sep. 2014;71(3):542-7. X-3, X-4. [pmid: 24929885].
3932 Wijeratne NG, Kao KT, Simm PJ, et al. A baby boy with hypothyroidism and hemangioendothelioma. Clin Chem. Jun. 2014;60(6):818-21. X-1. [pmid: 24872366].
3933 Wilartratsami S, Muangsomboon S, Benjarassameroj S, et al. Prevalence of primary spinal tumors: 15-year data from Siriraj Hospital. J Med Assoc Thai. Sep. 2014;97(Suppl 9):S83-7. X-1. [pmid: 25365896].
3934 Wine Lee L, Goff KL, Lam JM, et al. Treatment of pediatric pyogenic granulomas using beta-adrenergic receptor antagonists. Pediatr Dermatol. Mar–Apr. 2014;31(2):203-7. X-1. [pmid: 24138457].
3935 Wong BL, Dwivedi RC, Masterson L, et al. Kaposiform hemangioendothelioma of paranasal sinus. Laryngoscope. Sep. 2014;124(9):2103-6. X-1. [pmid: 24619771].
3936 Wu X, Chen K, Sun L, et al. Magnetic resonance imaging-detected inner ear hemorrhage as a potential cause of sudden sensorineural hearing loss. Am J Otolaryngol. May–Jun. 2014;35(3):318-23. X-1. [pmid: 24629585].
3937 Yang CC, Chen YA, Tsai YL, et al. Neoplastic skin lesions of the scalp in children: a retrospective study of 265 cases in Taiwan. Eur J Dermatol. Jan–Feb. 2014;24(1):70-5. X-1. [pmid: 24334149].
3938 Yang G, Li C, Chen X, et al. Large capillary hemangioma of the temporal bone with a dural tail sign: A case report. Oncol Lett. Jul. 2014;8(1):183-6. X-1. [pmid: 24959241].
3939 Yang T, Tariq F, Chabot J, et al. Cerebral revascularization for difficult skull base tumors: a contemporary series of 18 patients. World Neurosurg. Nov. 2014;82(5):660-71. X-1. [pmid: 23403341].
3940 Zhai Y, Xu H, Shen Q, et al. Renal histological features of school-age children with asymptomatic haematuria and/or proteinuria: a multicenter study. Nephrology (Carlton). Jul. 2014;19(7):426-31. X-1. [pmid: 24720478].
3941 Zhang D, Zhang H, Sun P, et al. A creative therapy in treating cavernous hemangioma of penis with copper wire. J Sex Med. Oct. 2014;11(10):2605-10. X-1. [pmid: 24119068].
3942 Zhang L, Mai HM, Zheng J, et al. Propranolol inhibits angiogenesis via down-regulating the expression of vascular endothelial growth factor in hemangioma derived stem cell. Int J Clin Exp Pathol. 2014;7(1):48-55. X-1. [pmid: 24427325].
3943 Zhang Y, Chen XM, Sun DL, et al. Treatment of hemolymphangioma of the spleen by laparoscopic partial splenectomy: a case report. World J Surg Oncol. 2014;12:60. X-1. [pmid: 24656049].
3944 Zhou W, He S, Yang Y, et al. Formulation, characterization and clinical evaluation of propranolol hydrochloride gel for transdermal treatment of superficial infantile hemangioma. Drug Dev Ind Pharm. Aug. 25. 2014:1-11. X-1. [pmid: 23802149].
3945 Zhu Y, Tuerxun A, Hui Y, et al. Effects of propranolol and isoproterenol on infantile hemangioma endothelial cells in vitro. Exp Ther Med. August. 2014;8(2):647-51. X-1. [pmid: 25009634].
3946 Zhu Y, Tuerxun A, Hui Y, et al. Effects of propranolol and isoproterenol on infantile hemangioma endothelial cells. Exp Ther Med. Aug. 2014;8(2):647-51. X-1. [pmid: 25009634].
3947 Abdel Kareem H, Abou Samra MF, Farouk Osman M. The role of multidetector computed tomography and magnetic resonance recent imaging techniques in the evaluation of intraconal orbital lesions. Egyptian Journal of Radiology and Nuclear Medicine. 01. Mar. 2015;46(1):53-61. PMID: X-1.
3948 Alobaid A, Bennardo MR, Cenic A, et al. Mixed capillary-cavernous extramedullary intradural hemangioma of the spinal cord mimicking meningioma: Case report. Br J Neurosurg. Jan. 6. 2015:1-2. X-1. [pmid: 25562682].
3949 Bello L, Cruz E, Manganaro S, et al. Analysis of pediatric electroencephalogram characteristics during therapeutic hypothermia in post cardiac arrest patients. Epilepsy Currents. January–February. 2015;15:63. PMID: X-1.
3950 Chamlin SL, Mancini AJ, Lai JS, et al. Development and Validation of a Quality-of-Life Instrument for Infantile Hemangiomas. J Invest Dermatol. 2015. Jan. 23. X-1. [pmid: 25615551].
3951 Chen ZG, Zheng JW, Zhang L, et al. A survey on clinical use of propranolol for infantile hemangiomas in mainland China. International Journal of Clinical and Experimental Medicine. 28. Feb. 2015;8(2):2138-46. X-3. [pmid: 25932144].
3952 Chhablani J, Balakrishnan D. CHANDELIER-ASSISTED EXTERNAL DRAINAGE OF SUBRETINAL FLUID. Retin Cases Brief Rep. 2015. Mar. 12. X-1. [pmid: 25767900].
3953 Chong JH, Liew HM, Koh MJ. A lumbosacral hemangioma with spinal dysraphism. J Pediatr. Feb. 2015;166(2):495. X-1, X-2, X-4. [pmid: 25449217].
3954 Durack A, Gass JK. Assessing skin disease in children. Paediatrics and Child Health (United Kingdom). 01. Feb. 2015;25(2):49-53. PMID: X-2, X-4.
3955 Dutkiewicz AS, Ezzedine K, Mazereeuw-Hautier J, et al. A prospective study of risk for Sturge-Weber syndrome in children with upper facial port-wine stain. J Am Acad Dermatol. Mar. 2015;72(3):473-80. X-3, X-4. [pmid: 25592619].
3956 Emir S, Gurlek Gokcebay D, Demirel F, et al. Efficacy and safety of intralesional corticosteroid application for hemangiomas. Turkish Journal of Medical Sciences. 2015;45(2):335-8. PMID: X-4. [pmid: 26084124].
3957 Hasson M, Kahl KL, Te N. in the journals. Ocular Surgery News. 2015;33(5):25-7. Language: English. Entry Date: 20150327. Revision Date: 20150403. Publication Type: journal article. Journal Subset: Biomedical. X-6.
3958 Imai H, Hidaka N, Murakami T, et al. In utero sonographic findings of giant hepatic hemangioma and associated perinatal complications: A report of two cases. Journal of Medical Ultrasound. 01. Mar. 2015;23(1):46-51. PMID: X-4.
3959 Joseph NA, Vijaya Sai GC. Cavernous hemangioma of the tonsil. International Journal of Pharma and Bio Sciences. 2015;6(2):P42-P6. PMID: X-1.
3960 Karikari IO, Nimjee SM, Hodges TR, et al. Impact of tumor histology on resectability and neurological outcome in primary intramedullary spinal cord tumors: a single-center experience with 102 patients. Neurosurgery. Mar. 2015;76(Suppl 1):S4-13. discussion S. X-1. [pmid: 25692367].
3961 Krema H. Primary surgical excision for pediatric orbital capillary hemangioma. Semin Ophthalmol. May. 2015;30(3):214-7. X-4. [pmid: 24117453].
3962 Li P, Guo Z, Gao Y, et al. Propranolol represses infantile hemangioma cell growth through the beta2-adrenergic receptor in a HIF-1alpha-dependent manner. Oncol Rep. 2015. Apr. 14. X-1. [pmid: 25872592].
3963 Liu H, Yang MB, Li SK, et al. Effects of Dosing Protocol on Distribution of Propranolol in Periocular Tissues after Topical Ocular Instillation. Curr Eye Res. May. 2015;40(6):638-45. X-1. [pmid: 25167079].
3964 Mishra AK, Tomer V, Yadav SS, et al. Adult giant genital hemangioma & pure intrascrotal hemangioma: A rare benign genital tumor of adult. Indian Journal of Urology. January. 2015;31:S113. PMID: X-1.
3965 Munabi NC, Tan QK, Garzon MC, et al. Growth Hormone Induces Recurrence of Infantile Hemangiomas After Apparent Involution: Evidence of Growth Hormone Receptors in Infantile Hemangioma. Pediatr Dermatol. 2015. Feb. 18. X-4. [pmid: 25690955].
3966 Pan WK, Li P, Guo ZT, et al. Propranolol induces regression of hemangioma cells via the down-regulation of the PI3K/Akt/eNOS/VEGF pathway. Pediatr Blood Cancer. 2015. Mar. 1. X-1. [pmid: 25728347].
3967 Pievani A, Azario I, Antolini L, et al. Neonatal bone marrow transplantation prevents bone pathology in a mouse model of mucopolysaccharidosis type I. Blood. Mar. 5. 2015;125(10):1662-71. X-1. [pmid: 25298037].
3968 Rashid R, Goodyear H. Management of paediatric dermatological emergencies. Paediatrics and Child Health (United Kingdom). 01. Feb. 2015;25(2):78-83. PMID: X-1, X-2.
3969 Ravenscroft J. Management of infantile haemangioma. Paediatrics and Child Health (United Kingdom). 01. Feb. 2015;25(2):60-5. PMID: X-2, X-4.
3970 Schoolmeester JK, Greipp PT, Keeney GL, et al. Ovarian Hemangiomas Do Not Harbor EWSR1 Rearrangements: Clinicopathologic Characterization of 10 Cases. Int J Gynecol Pathol. 2015. Apr. 3. X-1. [pmid: 25851709].
3971 Siaghani PJ, Chavez C, Anselmo DM, et al. Pulmonary infantile hemangioma presenting as a mass in a premature male infant: a case report focusing on pathological features. Pediatr Dev Pathol. Jan–Feb. 2015;18(1):66-70. X-2, X-4. [pmid: 25360560].
3972 Soukoulis IW, Liang MG, Fox VL, et al. Gastrointestinal Infantile Hemangioma: Presentation and Management. J Pediatr Gastroenterol Nutr. 2015. Apr. 6. X-1, X-4. [pmid: 25859824].
3973 Su L, Wang D, Fan X. Comprehensive therapy for hemangioma presenting with Kasabach-Merritt syndrome in the maxillofacial region. J Oral Maxillofac Surg. Jan. 2015;73(1):92-8. X-4. [pmid: 25511959].
3974 Uno T, Ito S, Nakazawa A, et al. Successful treatment of Kaposiform hemangioendothelioma with everolimus. Pediatr Blood Cancer. Mar. 2015;62(3):536-8. X-1. [pmid: 25306933].
3975 Van Onselen J. Birthmarks in infants - cause for concern?. J Fam Health Care. Jan–Feb. 2015;25(1):27-30. X-6. [pmid: 25842693].
3976 Verma SK, Singh PK, Garg K, et al. Giant calvarial cavernous hemangioma. Journal of Pediatric Neurosciences. 01. Jan. 2015;10(1):41-4. PMID: X-1. [pmid: 25878743].
3977 Vivas-Colmenares GV, Bernabeu-Wittel J, Alonso-Arroyo V, et al. Effectiveness of Propranolol in the Treatment of Infantile Hemangioma Beyond the Proliferation Phase. Pediatr Dermatol. 2015. Feb. 26. X-4. [pmid: 25721095].
3978 Wang G, Zhong J, Li J, et al. Computer-aided three-dimensional reconstruction of main vessels in hemangiomas. International Journal of Clinical and Experimental Medicine. 28. Feb. 2015;8(2):1747-54. PMID: X-1. [pmid: 25932103].
3979 Wygnanski-Jaffe T, Spierer A, Melamed S, et al. The effect of oral propranolol on intraocular pressure in infants with Sturge-Weber syndrome glaucoma. Eur J Ophthalmol. Mar–Apr. 2015;25(2):134-6. X-1. [pmid: 25044138].