# Screening and Quality Assessment Forms

Infantile Hemangioma Abstract Review Form

Infantile Hemangioma Full Text Review Form

Harms Risk of Bias Assessment Form

QUADAS Diagnostic Accuracy Rating Tool – For Diagnosis studies Form

Newcastle-Ottawa Quality Assessment Form for Cohort Studies Form

Infantile Hemangioma CER: Risk of Bias for RCTs Form