# Search Strategies

## Searches for Contextual Questions

Table A-1 MEDLINE (PubMed)

| Search Terms | Search Results
#1 | hemangioma[mh] OR hemangioma, capillary infantile[nm] OR infantile hemangioma*[tiab] OR infantile haemangioma*[tiab] OR capillary hemangioma*[tiab] OR capillary haemangioma*[tiab] OR congenital hemangioma*[tiab] OR congenital haemangioma*[tiab] OR IH[tiab] | 33,062
#2 | infant[mh] OR infant[tiab] OR infants[tiab] OR infantile[tiab] OR child[mh] OR Children[tiab] OR youth[tiab] OR pediatric[tiab] OR neonat*[tiab] | 2,235,431
#3 | #1 AND #2 | 10,049
#4 | #3 AND eng[la] | 7,297
#5 | #4 AND (review[pt] OR historical article[pt] OR practice guideline[pt] OR meta-analysis[pt]) | 897
#6 | #5 AND Humans[mh] | 892
#7 | #6 AND (Therapeutics[mh] OR therapy[sh] OR Treatment Outcome[mh] OR therapy[tiab] OR therapies[tiab] OR therapeutic[tiab] OR therapeutics[tiab] OR outcome[tiab] OR outcomes[tiab] OR surgical[tiab] OR surgery[sh] OR surgery[tiab] OR Embolization, Therapeutic[mh] OR embolization[tiab] OR embolization[tiab] OR cryotherapy[mh] OR cryotherapy[tiab] OR Catheter Ablation[mh] OR radiofrequency ablation[tiab ]OR Laser, dye [mh] OR Laser, Gas/therapeutic use[mh] OR Laser Therapy[mh] OR “carbon dioxide laser”[tiab] OR “carbon dioxide lasers”[tiab] OR CO2 laser[tiab] OR CO2 lasers[tiab] OR “fractionated laser”[tiab] OR “fractionated lasers”[tiab] OR argon[tiab] OR Lasers, Solid-State[mh] OR Neodymium YAG[tiab] OR YAG[tiab] OR Erbium[tiab] OR Propranolol[mh] OR propranolol[tiab] OR Timolol[mh] OR timolol[tiab] OR Imiquimod[NM] OR angiotensin OR Adrenergic beta-Antagonists[mh] OR Angiotensin-converting enzyme inhibitors[mh] OR Immunosuppressive agents[mh] OR Angiogenesis Inhibitors[mh] OR Bleomycin[mh] OR bleomycin[tiab] OR Antineoplastic agents[mh] OR Vincristine[mh] OR vincristine[tiab] OR corticosteroids[tiab] OR beta-blockers[tiab] OR beta blockers[tiab] OR beta blocker[tiab] OR beta-blockers[tiab] OR angiotensin[tiab] OR intralesional interferon[tiab]) | 630

Key: [mh] medical subject heading; [nm] supplementary concept; [tiab] keyword in title or abstract; [la] language; [pt] publication type; [sh] subheading

Table A-2 CINAHL search strategies (EBSCO Host interface)

| Search Terms | Search Results
#1 | (MH “Hemangioma”) OR (MH “Hemangioma, Cavernous”) OR “infantile hemangioma” OR “infantile hemangiomas” OR “infantile haemangiomas” OR “infantile haemangiomas” OR “IH” | 1,164
#2 | (MH “ Infant, Newborn, Diseases”) OR (MH “Infant”) OR (MH “Infant, Newborn”) OR (MH “Child”) OR “infant” OR “infants” OR “infantile” OR “newborn” OR “child” OR “children” OR “pediatric” or “neonat*” | 377,138
#3 | S1 AND S2 | 452
#4 | S3 AND limiters: English language | 449
#5 | S4 AND limiters: Exclude MEDLINE records | 90

Key: MH CINAHL medical subject heading; MW CINAHL subheading

Table A-3 EMBASE search strategies (OvidSP interface)

| Search Terms | Search Results
#1 | Capillary hemangioma/or infantile hemangioma.tw. or infantile hemangiomas.tw. or infantile haemangioma.tw. or infantile haemangiomas.tw. or haemangioma.tw. or hemangiomas.tw. or IH.tw. | 15,518
#2 | Infant/ or child/ or newborn/ or congenital disorder/ or infant*.tw. or infantile.tw. or child.tw. or children.tw. or newborn.tw. or newborns.tw. | 2,257,155
#3 | 1 AND 2 | 4658
#4 | Limit 3 to English | 3782
#5 | Limit 4 to human | 3392
#6 | 5 not (editorial.pt. or letter.pt. or note.pt. or short survey.pt. or conference paper.pt.) | 3155
#7 | Limit 6 to exclude MEDLINE journals | 236

Key: / Emtree heading; .tw. abstract, title and drug trade name; /cn congenital; .fs. subheading; si.fs. side effects subheading; th.fs. therapy subheading; su.fs. surgery subheading; co.fs. complications subheading; pt. publication type

## Searches for Comparative Effectiveness Questions

Table A-4 MEDLINE (PubMed)

| Search Terms | Search Results
#1 | hemangioma[mh] OR hemangioma, capillary infantile[nm] OR infantile hemangioma*[tiab] OR infantile haemangioma*[tiab] OR capillary hemangioma*[tiab] OR capillary haemangioma*[tiab] OR congenital hemangioma*[tiab] OR congenital haemangioma*[tiab] OR IH[tiab] | 33,062
#2 | infant[mh] OR infant[tiab] OR infants[tiab] OR infantile[tiab] OR pediatric[tiab] OR neonat*[tiab] OR child[mh] OR children[tiab] OR youth[tiab] | 2,335,431
#3 | Therapeutics[mh] OR therapy[sh] OR Treatment Outcome[mh] OR therapy[tiab] OR therapies[tiab] OR therapeutic[tiab] OR therapeutics[tiab] OR outcome[tiab] OR outcomes[tiab] OR surgical[tiab] OR surgery[sh] OR surgery[tiab] OR Embolization, Therapeutic[mh] OR embolization[tiab] OR embolization[tiab] OR cryotherapy[mh] OR cryotherapy[tiab] OR Catheter Ablation[mh] OR radiofrequency ablation[tiab ]OR Laser, dye [mh] OR Laser, Gas/therapeutic use[mh] OR Laser Therapy[mh] OR “carbon dioxide laser”[tiab] OR “carbon dioxide lasers”[tiab] OR CO2 laser[tiab] OR CO2 lasers[tiab] OR “fractionated laser”[tiab] OR “fractionated lasers”[tiab] OR argon[tiab] OR Lasers, Solid-State[mh] OR Neodymium YAG[tiab] OR YAG[tiab] OR Erbium[tiab] OR Propranolol[mh] OR propranolol[tiab] OR Timolol[mh] OR timolol[tiab] OR Imiquimod[NM] OR Adrenergic beta-Antagonists[mh] OR Angiotensin-converting enzyme inhibitors[mh] OR Immunosuppressive agents[mh] OR Angiogenesis Inhibitors[mh] OR Bleomycin[mh] OR bleomycin[tiab] OR Antineoplastic agents[mh] OR Vincristine[mh] OR vincristine[tiab] OR corticosteroids[tiab] OR beta-blockers[tiab] OR beta blockers[tiab] OR beta blocker[tiab] OR beta-blockers[tiab] OR angiotensin[tiab] OR intralesional interferon[tiab] OR “adverse effects”[Subheading] OR unsafe[tiab] OR safety[tiab] OR harm[tiab] OR harms[tiab] OR harmful[tiab] OR complication[tiab] OR complications[tiab] OR side-effect[tiab] OR “side-effects”[tiab] OR Undesirable effect[tiab] OR undesirable effects[tiab] OR undesirable reaction[tiab] OR undesirable reactions[tiab] OR undesirable event[tiab] OR undesirable events[tiab] OR undesirable outcome[tiab] OR undesirable outcomes[tiab] OR adverse effect[tiab] OR adverse effects[tiab] OR adverse reaction[tiab] OR adverse reactions[tiab] OR adverse event[tiab] OR adverse events[tiab] OR adverse outcome[tiab] OR adverse outcomes[tiab] OR “Postoperative Complications”[Mesh] OR postoperative complication[tiab] OR postoperative complications[tiab] OR post operative complication[tiab] OR post operative complications[tiab] OR surgical complication[tiab] OR surgical complications[tiab] OR postsurgical complication[tiab] OR postsurgical complications[tiab] OR post surgical complication[tiab] OR post surgical complications[tiab] OR adverse effects[Subheading] OR complications[Subheading] OR contraindications[Subheading] OR bleeding[tiab] OR Hemorrhage[mh] OR scarring[tiab] OR scars[tiab] OR residual hemangiomas[tiab] OR residual hemangioma[tiab] OR residual haemangioma[tiab] OR residual haemangiomas[tiab] OR pain[mh] OR pain[tiab] OR “Skin atrophy”[tiab] OR venous prominence[tiab] OR facial injuries[mh] OR skin ulcer[mh] OR ulceration[tiab] OR “surgical wound infection”[mh] OR wound infection[mh] OR infection[tiab] | 10,334,120
#4 | #1 AND #2 AND #3 | 7392
#5 | #4 AND eng[la] | 5441
#6 | #5 AND Humans[mh] | 5203
#7 | #6 AND (“1982/01/01”[Date - Publication] : “3000”[Date - Publication]) | 4358
#8 | #7 NOT (editorial[pt] OR letter[pt] OR comment[pt] OR review[pt] OR news[pt] OR historical article[pt] OR practice guideline[pt] OR meta-analysis[pt]) | 3409

Key: [mh] medical subject heading; [nm] supplementary concept; [tiab] keyword in title or abstract; [la] language; [pt] publication type; [sh] subheading

Table A-5 CINAHL search strategies (EBSCO Host interface)

| Search Terms | Search Results
#1 | (MH “Hemangioma”) OR (MH “Hemangioma, Cavernous”) OR “infantile hemangioma” OR “infantile hemangiomas” OR “infantile haemangiomas” OR “infantile haemangiomas” OR “IH” | 1,163
#2 | (MH “ Infant, Newborn, Diseases”) OR (MH “Infant”) OR (MH “Infant, Newborn”) OR “infant” OR “infants” OR “infantile” OR “newborn” OR “pediatric” OR “neonat*” OR (MH “Child”) OR “child” OR “children” | 376,639
#3 | S1 AND S2 | 452
#4 | S3 AND limiters: English language | 449
#5 | S4 AND limiters: 1982- | 448
#6 | S5 AND limiters: Exclude MEDLINE records | 90

Key: MH CINAHL medical subject heading; MW CINAHL subheading

Table A-6 EMBASE search strategies (OvidSP interface)

| Search Terms | Search Results
#1 | Capillary hemangioma/or infantile hemangioma.tw. or infantile hemangiomas.tw. or infantile haemangioma.tw. or infantile haemangiomas.tw. or haemangioma.tw. or hemangiomas.tw. or IH.tw. | 15,410
#2 | Infant/ or child/ or newborn/ or congenital disorder/ or infant*.tw. or infantile.tw. or child.tw. or children.tw. or newborn.tw. or newborns.tw. or neonat*.tw | 2,316,140
#3 | 1 AND 2 | 4,615
#4 | Limit 3 to English | 3,756
#5 | Limit 4 to human | 3,343
#6 | 5 not (review.pt. or editorial.pt. or letter.pt. or note.pt. or short survey.pt. or conference paper.pt. or meta analysis/ or practice guideline/ or systematic review/) | 2,699
#7 | Limit 6 to 1982- | 2645
#8 | Limit 7 to exclude MEDLINE journals | 207

Key: / Emtree heading; .tw. abstract, title and drug trade name; /cn congenital; .fs. subheading; si.fs. side effects subheading; th.fs. therapy subheading; su.fs. surgery subheading; co.fs. complications subheading; pt. publication type