# Abbreviations and Acronyms Used in This Report

AHRQ: Agency for Healthcare Research and Quality
BCI: Bayesian Credible Interval
CER: Comparative Effectiveness Review
CI: Confidence Interval
cm: Centimeters
CO_2_: Carbon Dioxide
CT: Computed Tomography
CQ: Contextual Questions
EPC: Evidence-based Practice Center
G: Group
HAS: Hemangioma Activity Score
HR: Hazard Ratio
IH: Infantile Hemangioma
IQR: Interquartile Range
IV: Intravenous
kg: Kilograms
KQ: Key Questions
LUMBAR: Lower-body hemangioma and other cutaneous defects, Urogenital anomalies, Ulceration, Myelopathy, Bony deformities, Anorectal malformations, Arterial anomalies, and Renal anomalies
mg: Milligrams
mL: Milliliters
Mm: Millimeters
MRI: Magnetic Resonance Imaging
n: Number
NA: Not Applicable
Nd:YAG: Neodymium Yttrium Aluminum Garnet
NR: Not Reported
NS: Not Significant
OR: Odds ratio
OSD: Occult Spinal Dysraphism
PDL: Pulsed Dye Laser
PELVIS: Perineal hemangioma, External genitalia malformations, Lipomyelomeningocele, Vesicorenal abnormalities, Imperforate anus, and Skin tag
PHACES: Posterior fossa malformations, Hemangiomas, Arterial anomalies, Cardiac defects, Eye abnormalities, Sternal cleft and supraumbilical raphe
PICOTS: Population, Interventions, Outcomes, Timing, and Setting
QoL: Quality of Life
RCT: Randomized, Controlled Trial
SD: Standard Deviation
SOE: Strength of Evidence
TEP: Technical Expert Panel
TSA: Total Surface Area
US: Ultrasound
VAS: Visual Analog Scale