# Results

## Results of the Search

Figure 3 summarizes the results of our searching for relevant studies. The literature search identified 20,829 unique citations. During the title and abstract screening, we excluded 13,912 citations. During the article screening, we excluded 1028 citations. During KQ applicability screening, we excluded an additional 1190 articles that did not meet one or more of the inclusion criteria (See Appendix C for list of excluded articles with reasons for exclusion). As part of the grey literature search, we asked device manufacturers to provide information about pertinent studies conducted with their products (published, unpublished, and ongoing clinical trials). Of the 10 companies contacted, two companies responded. The references provided by these two companies were carefully cross-checked against our existing database. This review focuses on 147 studies, reported in 150 articles that met the inclusion criteria.

Figure 3 Summary of the literature search

* Reviewers were allowed to mark more than one reason for exclusion.

Figure 3 is our summary of the literature search. Moving from left to right, there is text, arrows, boxes, and circles that have text within and around. The first box at the top left corner of the figure shows the electronic databases used for article abstraction. The small box to the right and just below it notes that 100 articles were searched by hand. Following the arrow downward, shows the number of articles retrieved from these two processes (18463). The next two arrows downward link to two boxes, one denoting the duplicates removed (4250) and the other noting the number of title-abstract reviews (14213). The next two arrows downward link to two boxes, one denoting the excluded articles after title-abstract review (12235) and the other noting how many articles were reviewed (1978). The arrow coming off the excluded box points to a larger box on the right noting the reasons for exclusion at title-abstract review level. Moving downward from the article review box, are two arrows pointing to a box noting the articles that were excluded during this review (919), and a box noting the number of articles (1059) reviewed in the key question applicability review phase. The arrow coming off the excluded box after article review has an arrow pointing to the middle box on the right noting the reasons for exclusion during that review. Moving downward, the arrow coming off the key question applicability review box, points to three possible choices. The first box to the right notes the excluded articles (627) during this review. Off of that box there is an arrow to the third large box on the right noting the reasons for exclusion. The second arrow coming off the key questions applicability review box points to the uncontrolled (KQ3) studies included only in appendix 300. The final arrow pointing straight down notes the breakdown of articles that were included into their respective diagnostic categories, KQ1, KQ2 and KQ3a/b.

## Overview of Included Studies by KQs

We list the number of studies identified as addressing each question in Table 4.

Table 4 List of included studies by KQ

Key Question | | Number of Studies
Diagnostic | KQ1 (Pathologic diagnosis compared to the likelihood of malignancy predicted by using a preoperative composite profile of patient characteristics) | 20 studies
Diagnostic | KQ2a (Diagnostic test-related outcomes) | 20 studies
Diagnostic | KQ2b (Harms and adverse events associated with percutaneous renal mass sampling) | 16 studies
Management Strategies | KQ3a (Effectiveness and comparative effectiveness of the available management strategies on health outcomes): included studies by outcomes | 107 studies (reported in 110 articles)
Management Strategies | - Oncology efficacy | 60 cohort studies (reported in 61 articles) 1 RCT
Management Strategies | - Renal functional outcomes | 52 cohort studies 1 RCT (reported in 2 articles)
Management Strategies | - Overall survival | 47 cohort studies (reported in 48 articles) 1 RCT
Management Strategies | - Quality of life | 4 cohort studies
Management Strategies | - Harms | 46 cohort studies 1 RCT (reported in 2 articles)
Management Strategies | - Peri-operative | 37 cohort studies 1 RCT
Management Strategies | - Uncontrolled studies for active surveillance | 8 single arm cohort studies
Management Strategies | KQ3b (Comparative benefits and harms of the available management strategies differ according to a patient's demographic or clinical characteristics, or disease severity) | Cancer-specific survival: 19 Metastases-free survival: 1 Local recurrence-free survival: 3 Overall survival: 22 Renal Functional Outcomes: 27 Quality of Life: 2 Perioperative Outcomes and Harms: 3

KQ = Key Question; RCT = randomized clinical trial

## Organization of Results Chapter

We present our results by KQ. For the studies on each KQ, we provide a summary of study characteristics, population characteristics, intervention characteristics, tumor characteristics, and outcomes.

## KQ 1 Efficacy of Composite Models in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

### Key Points

- Composite models were used to predict benign pathology as well as malignant pathology.
- Twenty studies used a composite model to predict pathologic outcomes; eighteen were retrospective studies.
- Imaging characteristics were included in 19 of 20 models, whereas only one study evaluated laboratory testing.
- Tumor size, tumor characteristics, age, sex, and body mass index (BMI) were commonly used variables in composite models. None were universally predictive of malignant or benign disease.
- In general, increased tumor size (pooled odds ratio of 1.33-fold increased risk of malignancy per cm increase in tumor diameter) and male sex (pooled odd ratio 2.71) were most strongly associated with increased likelihood of malignancy.
- The strength of evidence was moderate for sex and tumor size, based largely on the consistency of findings among studies.
- The strength of evidence was moderate that incidental presentation does not predict benign or malignant pathology.
- The strength of evidence was low for tumor characteristics and age as not being predictive of malignancy and low for composite models as a whole, based on inconsistencies among studies involving inclusion criteria, controlling variables in composite profiles, and study design.
- The data regarding BMI and association with malignant and benign disease in composite models was insufficient to draw conclusions.

### Study Characteristics

Twenty studies evaluated composite models to predict pathologic diagnosis, adjusting for imaging characteristics, demographic characteristics, clinical characteristics, and other diagnostic tests (i.e., blood and urine tests.). Two studies evaluated a composite model in prospective studies,40,41 and the remainder were retrospective analyses of cohort studies. Two studies42,43 involved a five–center consortium of renal surgery outcomes, however the data was sufficiently different from each study to warrant inclusion as separate studies. The remainder of studies were single-center analyses. Ten studies were completed in Asia, 40,44-52 nine in North America, 41-43,53-58 and one in Europe.59 The median study start year was 2000 (1988 to 2010).

### Population Characteristics

In total, 12,149 patients among the 20 studies were included in the analysis. Not all studies reported all population characteristics, and some studies included statistics in sub-groups (indicated by an asterisk in Table 5). Eighteen of 20 studies reported the number or proportion of women in the study (Table 5). For those that provided data that could be analyzed for the entire cohort, women constituted a median 35 percent (24.4 percent to 48.0 percent) of the study populations, and the median of the mean age of the study populations was 60.5 years (range 54–34.8 years).

Table 5 Participant characteristics of studies addressing predictors of pathologic outcomes

Author, Year | Year Start | Patients, n | Women, n | Women, % | Mean or Median Age | Age, min. | Age, max.
Keehn,2014^53^ | 2002 | 125 | 60 | 48.0 | 63 | 53.5 | 70.5
Bazzi,2014^54^ | 1998 | 1,726 | 681 | 39.5 | 60.5 | 51.6 | 69.1
Antonelli, 2014^55^ | 2010 | 506 | 183 | 36.2 | 64.8 | 14 | 85
Nishikawa,2014^44^ | 2002 | 144 | 49 | 34.0 | 60.9 | NR | NR
Koo,2013^45^ | 2005 | 1,129 | 381 | 33.7 | 54 | 18 | 88
Fujita,2013^40^ | 2000 | 149 | 49 | 32.9 | NR^*^ | 23 | 81
Mullins,2012^42^ | 2007 | 873 | NR | NR | NR | NR | NR
Kava,2012^41^ | 1992 | 316 | 137 | 43.4 | NR^*^ | NR^*^ | NR^*^
Soga,2012^46^ | 1991 | 409 | 100 | 24.4 | 60.5 | 22 | 86
Akdogan,2012^59^ | 1990 | 450 | 174 | 38.7 | 54.5 | NR | NR
Park,2011^47^ | 2000 | 1,598 | 517 | 32.4 | NR^*^ | 10 | 86
Xiong,2010^48^ | 1999 | 303 | 112 | 37.0 | NR | NR | NR
Jeon,2010^49^ | 1997 | 376 | 123 | 32.7 | NR^*^ | NR | NR
Murphy,2009^56^ | 1988 | 775 | 243 | 31.4 | NR^*^ | NR | NR
Lane,2007^57^ | 1999 | 851 | NR | 36.0 | 60 | 23 | 87
Rosenkratz,2014^58^ | NR | 86 | 41 | 47.7 | 61 | NR | NR
Chung,2014^50^ | 2008 | 111 | NR | NR | NR | 17 | 78
Choi,2012^60^ | 2000 | 84 | 27 | 32.1 | NR^*^ | 31 | 83
Shin,2013^52^ | 2005 | 1,129 | 381 | 33.7% | 54.9 | NR | NR
Ball,2015^43^ | 2007 | 1,009 | 402 | 39.8% | 59.5 | 52 | 67

* Studies included statistics in sub-groups

### Tumor Characteristics

Tumor characteristics are detailed in Table 6. Not all studies reported all tumor characteristics, and some studies included statistics in sub-groups (indicated by an asterisk in Table 5). Only nine studies reported tumor size for the entire cohort. In these studies, median tumor size was 2.5 cm (0.7 to 4 cm).

Table 6 Tumor characteristics of studies addressing predictors of pathologic outcomes

Author, Year | Tumor (cm) | Clear cell n (%) | Papillary n (%) | Chromophobe n (%) | Oncocytoma n (%) | Angiomyolipoma n (%) | Malignant | Benign
Keehn, 2014^53^ | 2.5 | 54(43) | 27(22) | 9(7) | NR | NR | 72% | 26%
Bazzi, 2014^54^ | 2.5 | 1008(58) | 260(15) | 158(9) | 162(9) | 63(4) | 83% | 13%
Antonelli, 2014^55^ | 2.5 | 293(58) | 54(11) | 43(9) | NR | NR | 77% | 20%
Nishikawa, 2014^44^ | 2.4 | 107(74) | 8(6) | 8(6) | 5(4) | 11(8) | 85% | 11%
Koo, 2013^45^ | 3.0 | 850(75) | 74(7) | 69(6) | NR | NR | 88% | 10%
Fujita, 2013^40^ | NR a | NR | NR | NR | NR | NR | 92% | 8%
Mullins, 2012^42^ | NR a | 431(49) | 156(18) | 62(7) | 77(9) | 63(7) | 74% | 16%
Kava, 2012^41^ | NR a | NR | NR | NR | 26(8) | 29(9) | 76% | 24%
Soga, 2012^46^ | 5.0 | 365(89) | 12(3) | 4(1) | 4(1) | 7(2) | 93% | 3%
Akdogan, 2012^59^ | NR a | 285(63) | 32(7) | 21(5) | 39(9) | 22(5) | 75% | 14%
Park, 2011^47^ | NR a | 1259(79) | 97(6) | 93(6) | 23(1) | 47(3) | 91% | 4%
Xiong, 2010^48^ | NR a | NR | NR | NR | 4(1) | 15(5) | 90% | 10%
Jeon, 2010^49^ | NR a | 238(63) | 26(7) | 14(4) | 11(3) | 35(9) | 74% | 12%
Murphy, 2009^56^ | NR a | 503(65) | 104(13) | 55(7) | 57(7) | 21(3) | 85% | 10%
Lane, 2007^57^ | 3.0 | 467(55) | 148(17) | 55(7) | NR | NR | 79% | 20%
Rosenkratz, 2014^58^ | 1.5 | 30(35) | 25(29) | 9(11) | 13(15) | 8(9) | 74% | 24%
Chung, 2014^50^ | NR a | 59(53) | 10(9) | 12(11) | 2(2) | 22(20) | 73% | 22%
Choi, 2012^60^ | NR a | 57(68) | 4(5) | 5(6) | 8(10) | 6(7) | 79% | 17%
Shin,2013^52^ | NR a | 850(84) | 74(7) | 69(7) | NR | NR | 90% | 10%
Ball,2015^43^ | 2.4 | 472(62) | 175(23) | 68(9) | NR | NR | 76% | 24%

NR=Not reported

a Studies included statistics in sub-groups.

Eleven studies were limited to clinical stage T1a tumors smaller than or equal to 4 cm,40,43-45,49,51,53-55,58,60 and an additional five studies were limited to clinical stage T1 tumors smaller than or equal to 7 cm.41,52,56,57,59 Seventeen of 20 studies reported tumor histology and the proportion of benign and malignant tumors was either provided for or calculated for all studies. The pathology was clear-cell renal cell carcinoma, papillary renal cell carcinoma, chromophobe renal cell carcinoma, oncocytoma, and angiomyolipoma (AML) in a median 63 percent (34.9 percent to 89.2 percent), 9 percent (2.9 percent to 29.1 percent), 7 percent (1.0 percent to 10.8 percent), 7 percent (1.0 percent to 15.1 percent), and 7 percent (1.7 percent to 19.8 percent) respectively. Three studies reported only relative rates of benign and malignant pathology (8.1 percent benign,40 24.1 percent benign,41 and 10.2 percent benign 48), but did not report histologic subtype. Therefore, the median rates of malignant and benign pathology in all twenty studies were 79 percent (62.2 percent to 93.2 percent) and 13 percent (2.7 percent to 37.0 percent) respectively.

### Intervention Characteristics

To meet the inclusion criteria (composite models need to adjust for imaging characteristics [i.e., tumor size] or at least one element from 2 of the categories) for this KQ, two of the 18 studies used imaging alone, 45,50 and the remainder used a composite model (Table 7).

Table 7 Studies addressing predictors of pathologic outcomes, by factors included in composite model

Composite Model | No. Studies
Imaging alone | 2 45,50
Imaging, Demographics, Clinical Features, Other Diagnostic Tests | 1 54
Imaging, Demographics, Clinical Features | 6 40 41 49 57 43,52
Imaging, Demographics | 9 53 55 44 42 46 59 47 48 60
Imaging, Clinical Feature | 1 58
Demographics, Clinical Feature | 1 56

### Risk of Bias

We used the quality assessment tool for diagnostic accuracy studies (QUADAS -2).37 There were no RCTs examining preoperative composite models in the prediction of malignancy in clinically localized renal masses suspicious of malignancy. Overall, 2 of the 20 studies were determined to be of low risk of bias. The majority of studies (12 of 20) were at low risk of bias for patient selection and the index test. The primary sources of bias were unclear evaluation of bias in flow and timing, reference standards, index test, and patient selection (Figure 4).

Figure 4 Risk of bias across studies investigating preoperative composite models in the prediction of malignancy in clinically localized renal masses

Figure 4 shows the risk of bias across studies investigating pre-operative composite models in the prediction of malignancy in clinically localized renal masses.

### Outcomes

The predictive and nonpredictive variables included in the composite (i.e., multivariable) model from each study are detailed in Table 8. Ten studies were designed to predict malignant pathology42-45,52-55,57,58 while the remaining 10 were designed to predict benign pathology.40,41,46-50,56,59,60

Table 8 Variables predictive of malignant or benign disease

Author, Year | Malignant/Benign | Predictive Variables | NonPredictive Variables | Additional Findings
Keehn,2014^53^ | Malignant | None | Age, sex, race, BMI, visceral and subcutaneous fat | Visceral fat predicts high-grade renal cell carcinoma
Bazzi,2014^54^ | Malignant | Tumor size, sex, ASA | Age, race, creatinine
Antonelli,2014^55^ | Malignant | Sex, nephrometry (H) | Age, nephrometry (E.N.L.) | None predictive of grade
Nishikawa,2014^44^ | Malignant | Enhancement pattern | Age, sex, Size, BMI,
Koo,2013^45^ | Malignant | Nephrometry
Fujita,2013^40^ | Benign | Age, sex, nephrometry (E.) | Tumor size, tumor location, tumor complexity, incidental
Mullins,2012^42^ | Malignant | Sex, nephrometry | | Male sex and complexity predict malignancy in cT1a subset. Male sex and nephrometry predict high-grade renal cell carcinoma. Nephrometry predicts clear cell histology.
Kava,2012^41^ | Benign | Age, BMI, tumor location
Soga,2012^46^ | Benign | Sex, tumor size | Age, surgery year | Incidence of benign highest in women with tumors < 2 cm.
Akdogan,2012^59^ | Benign | Sex, tumor size, tumor architecture, partial nephrectomy | Age, symptom, surgery year
Park,2011^47^ | Benign | Sex, tumor size, tumor architecture | Age, incidental
Xiong,2010^48^ | Benign | Sex, tumor size
Jeon,2010^49^ | Benign | Age, sex, surgery year | Tumor size, BMI, incidental
Murphy,2009^56^ | Benign | Sex, tumor size, Surgery year | Age, race, BMI, incidental
Lane,2007^57^ | Malignant | Age, sex, tumor size, smoking | Incidental | This was the only study to create a preoperative nomogram for the prediction of malignant histology at surgery.
Rosenkratz,2014^58^ | Malignant | None | Age, tumor architecture | Clear-cell histology was predicted by MRI enhancement patterns.
Chung,2014^50^ | Benign | Enhancement (MRI) | | MRI enhancement predicts fat-poor AML from renal cell carcinoma.
Choi,2012^60^ | Benign | Sex, enhancement (corticomedullary) | Enhancement (nephrogenic)
Shin,2013^52^ | Malignant | Age, sex, tumor size | Tumor location, exophytic | In subset analysis of T1a tumors, age, male sex, tumor size, and endophytic nature predict malignancy. High-grade pathology was predicted by age, sex, tumor size and endophytic nature for T1 tumors; age, tumor size and endophytic nature for T1a tumors.
Ball,2015^43^ | Malignant | Tumor size, nephrometry, sex | Age, institution | High-grade or T3a upstaging was predicted by tumor size, nephrometry, and sex.

BMI = body mass index; MRI = magnetic resonance imaging; ASA = American Society of Anesthesiologists; R.E.N.A.L. nephrometry score consists of (R)adius (tumor size as maximal diameter), (E)xophytic/endophytic properties of the tumor, (N)earness of tumor deepest portion to the collecting system or sinus, (A)nterior (a)/posterior (p) descriptor and the (L)ocation relative to the polar line

### Variables Predictive of Malignant or Benign Disease

The most common variables included in composite models were tumor size, age, sex, body mass index (BMI), and incidental presentation.

### Imaging Characteristics

Nineteen studies reported on models that included imaging characteristics. The most commonly included tumor-related findings were size. Ten studies included tumor size,40,43,44,46-49,52,54,56,57,59 eight studies included location or complexity (i.e. RENAL nephrometry score)40-45,52,55 and three included enhancement patterns.44,50,60 The RENAL nephrometry scoring system is an objective scoring system to describe the “complexity” of solid renal masses. R refers to the radius (or tumor size) of the tumor; E, exo- or endophytic nature; N, nearness to the renal collecting system; A, anterior or posterior tumor; and L, location relative to the renal polar anatomy. A more detailed explanation can be found at: http://www.nephrometry.com.

#### Tumor Size

Twelve studies evaluated tumor size as a predictor of pathological outcome.40,43,44,46-49,52,54,56, 57,59 Nine of 12 studies (75 percent) found tumor size to be predictive of malignant or benign disease43,46-48,52,54,56,57,59; 3 (25 percent) found tumor size not to be predictive.40,44,49

Five studies included patients with only T1a tumors;40,43,44,49,54 three studies included patients with T1a and T1b masses, but subgroup analyses were not performed.56,57,59 One study evaluated T1 tumors and performed a subset analysis of T1a tumors.52 One study did not report an upper limit for tumor size.48

Only two studies included patients with pathological T2 tumors.46,47 These studies included tumor sizes representative of the largest ranges of clinically localized tumors, ranging from 0.6 cm to 24 cm. Accordingly, the median percentages of malignant tumors were higher in these studies (93.2 percent and 90.7 percent, respectively) than the median across all studies (78.7 percent). These two studies were international studies, conducted in Japan and Korea respectively.

Six studies were included in our meta-analysis, demonstrating an effect size of 1.3 per cm increase in tumor diameter (95% confidence interval (CI): 1.22 to 1.43; Figure 5).40,43,49,52,54,56 Three studies were excluded from meta-analysis as they evaluated tumor size as a categorical variable; all three demonstrated an increased risk of malignancy with increasing tumor size.46,47,59 The three remaining studies had unclear methods or did not provide odds ratios in their multivariate regression and were therefore excluded from meta-analysis.44,48,57 The strength of evidence was moderate.

Figure 5 Meta-analysis showing effect of tumor size as a predictor of malignancy

CI = confidence interval; ES = effect size; OR = odds ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Weighting is based on the inverse of the variance of each study estimate.

Figure 5 is a meta-analysis showing effect of tumor size as a predictor of malignancy.

#### Tumor Characteristics: Location, Complexity, and Architecture

Nine studies evaluated specific tumor characteristics including RENAL nephrometry, tumor location, tumor architecture (cystic versus solid nature), and exophytic/endophytic nature of the tumor.40,42,43,45,47,52,55,58,59 Seven of the nine (77.8 percent) studies demonstrated a tumor characteristic to predict malignant pathology.40,42,43,45,47,55,59

Five studies specifically evaluated the RENAL nephrometry score in a composite model.40,42,43,45,47,52,55,58,59 All five demonstrated the RENAL nephrometry score or one of its components to predict malignancy. Three studies demonstrated increasing overall RENAL nephrometry score to predict malignancy.42,43,45 The study by Antonelli, et al 55 demonstrated only the hilar component to predict malignant pathology, while the study by Fujita, et al. 40 demonstrated the endophytic score to predict malignancy. Heterogeneity of data prevented a meaningful meta-analysis from being performed.

Three studies evaluated tumor architecture.47,58,59 Studies by Akdogan, et al,59 and Park, et al,47 demonstrated solid tumors to predict malignancy while the study by Rosenkrantz, et al,58 did not demonstrate tumor architecture to predict malignancy.

Tumor location, as an independent variable or as a component of the RENAL nephrometry score, did not predict malignancy in three studies.55 The strength of evidence was low.40,52

### Demographic Characteristics

Seventeen studies reported on analyses including demographic characteristics. Fifteen studies included age and 16 included sex.

#### Age

Fifteen studies included age as a predictor of pathological outcome.40,41,43,44,46,47,49,52-59 Five of 15 studies (38.5 percent) found age to be predictive of malignant or benign disease;40,41,49,52,57 10 (69 percent) found age not to be predictive.43,44,46,47,53-56,58,59

Nine studies included data appropriate for meta-analysis,40,43,47,49,52,54-56,59 one study did not provide the odds ratio in the multivariate analysis,57 and two studies44,46 were excluded from meta-analysis as they evaluated age as a categorical variable.

Both of the studies evaluating age as a categorical variable44,46 dichotomized age as less than 60 years and greater than or equal to 60 years. The respective odds ratios predicting malignancy for patients greater than or equal to age 60 were 2.86 (no CI reported, p=0.054)44 and 2.96 (95% CI: 1.00 to 8.77; p = 0.051),46 respectively. The effect size in meta-analysis was 0.998 per increasing year of age (CI: 0.993–1.004; Figure 6). Therefore, age did not have a statistically significant association with malignancy in this analysis. The study by Lane, et al.57 represented a particularly important study regarding age as a predictive factor. This study contained the largest age range of all relevant studies, with ages ranging from 23 to 87 years. This study identified age as a significant predictor of benign disease and further identified age as a predictor of indolent or aggressive disease. However, this study did not include data that could be extracted into meta-analysis. 57 The strength of evidence was low that age was not predictive of pathology.

Figure 6 Meta-analysis showing effect of age as a predictor of malignancy

CI = confidence interval; ES = effect size; OR = odds ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Weighting is based on the inverse of the variance of each study estimate.

Figure 6 is a meta-analysis showing effect of age as a predictor of malignancy.

#### Sex

Sixteen studies included sex as a predictor of pathological outcome.40,42-44,46-49,52-57,59,60

Fourteen of 16 (88 percent) studies found sex to be predictive of malignant or benign disease40,42,43,46-49,52,54-57,59,60; 2 found sex not to be predictive.44,53

The two studies that found sex not to be predictive of histology were not included in a meta-analysis because one study 53 did not report a relative risk for malignancy based on sex, and the other study44 did not provide CIs for the multivariable analysis but found that 9 out of 95 men (9.5 percent) and 11 out of 49 women (22.4 percent) had benign pathologies (multivariate odds ratio: 2.62, p = 0.079). The meta-analysis therefore included fourteen studies and indicated an effect size of 2.71 (95% CI: 2.39 to 3.02; Figure 7).

Figure 7 Meta-analysis showing effect of sex as a predictor of malignancy

CI = confidence interval; ES = effect size; OR = odds ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Weighting is based on the inverse of the variance of each study estimate.

Figure 7 is a meta-analysis showing effect of sex as a predictor of malignancy.

Of all composite model studies, Bazzi, et al. included the largest overall patient cohort (1726 patients), and the percent of women in the study (39.5 percent) was similar to the median percent across all studies (35.0 percent).54 The results of this study demonstrated that females had an odds ratio of 0.44 (95% CI: 0.34 to 0.58; p < 0.01) on multivariable analysis. Multivariable logistic regression was performed after differentiating patients based on sex, revealing different and significant sex-specific variables that predicted malignancy. This study was limited, however, in that it included only renal masses smaller than 4 cm. The strength of evidence was moderate (Table 9).

Table 9 Strength of evidence for predictors of malignant or benign pathology

Key Outcomes | No. Studies (N) | Study limitation | Directness | Consistency | Precision | Reporting Bias | Strength of evidence Finding
Pre-operative composite profiles | 20 (12,149) | Medium | Direct | Inconsistent | Precise | Undetected | Low Pre-operative composite models were created using different populations (i.e. inclusion criteria), included different variables in their models, and, in some cases, were examining a specific outcome or measure as part of a composite model. For instance, the study by Keehn 53 used a composite model in the context of evaluating visceral and subcutaneous fat content on CT imaging. Only one study was explicitly designed as a “nomogram” to predict malignant pathology. 57
Individual predictors of malignant or benign pathology
Tumor Size | 12 (9,401) | Medium | Direct | Consistent | Precise | Undetected | Moderate Increasing tumor size consistently is associated with an increased risk of malignancy.
Tumor Characteristics | 9 (6,942) | Medium | Direct | Consistent | Precise | Undetected | Low Increasing RENAL nephrometry score is consistently associated with malignancy. The data regarding individual components of the RENAL nephrometry score and other tumor characteristics is insufficient to draw conclusions.
Age | 15 (10,150) | Medium | Direct | Inconsistent | Precise | Undetected | Low While the relationship between age and malignant pathology varies among studies, the effect size due to age is small in all studies.
Sex | 16 (10,475) | Medium | Direct | Consistent | Precise | Undetected | Moderate Women are more likely to have benign tumors in all studies. The effect size varied by inclusion criteria and other variables (i.e. age, tumor size).
Body Mass Index | 5 (2,224) | Medium | Direct | Inconsistent | Imprecise | Undetected | Insufficient Conflicting and nonsignificant results in studies make it difficult to form meaningful conclusions. In addition, geographic and population-based differences in body mass index make interpretation of the association of body mass index with malignant disease difficult.
Incidental Presentation | 5 (4,229) | Medium | Direct | Consistent | Precise | Undetected | Moderate All studies demonstrate no relationship between an incidental finding and malignant pathology.
Harms | 12 (1,097) | Medium | Direct | inconsistent | Precise | Undetected | Low A small, but notable, proportions of patients experience harms due to renal mass biopsy with hematoma (5%) being the most common direct complication. Studies were inconsistent in which harms, if any, were reported.

N = number; NA = not applicable

### Clinical Characteristics

Seven studies reported on analyses including clinical characteristics. Five studies included BMI and five included incidental presentation.

#### BMI

Five studies included BMI as a potential predictor of pathological diagnosis.41,44,49,53,56 The data could not be sufficiently combined for a meta-analysis of BMI. The study by Keehn 53 did not provide any details of multivariate analysis. The other four studies reported conflicting odds ratio (OR) point estimates of greater than and less than one for the likelihood of benign disease associated with a BMI greater than 25 (i.e. overweight).44,41,49,56 However, the study by Nishikawa 44 did not provide upper and lower limits of the OR in the multivariate model, and the studies by Jeon and Murphy 56 used multiple different categories of BMI. For instance, Jeon reported on the relationship between increased BMI and benign disease and found conflicting, nonsignificant results with increasing BMI. Compared to those patients with BMI less than 23 kg/m^2^, patients with a BMI 23 to 25 kg/m^2^ had an increased likelihood of benign disease (OR: 1.19 (95% CI: 0.59-2.41), p=0.61), and patients with a BMI greater than 25 kg/m^2^ had an decreased likelihood of benign disease (OR: 0.8 (95% CI: 0.4-1.59), p=0.54). Murphy et al.56 reported an OR of 1.61 for an increased likelihood of benign disease in patients who were overweight (95% CI: 0.84-3.09) and an OR of 2.35 for patients who were obese (95% CI: 1.01-5.84).However, none of these relationships reached traditional levels of statistical significance. The study by Kava,et al. directly addressed the relationship between BMI and benign histology and found decreasing BMI to be associated with an increased likelihood of benign disease.41 The reported percentages of malignant versus benign tumors (75.9 percent vs. 24.1 percent, respectively) were similar to the median reported percentages across all relevant composite model studies (78.7 percent vs. 13.3 percent, respectively). Mean BMI in patients with benign and malignant tumors was 26.5 +/- 4.5 kg/m^2^ (standard deviation) and 28.6 +/- 5.6 kg/m^2^ respectively (P=0.012). Thirty-two percent of patients with BMI <25 kg/m^2^ had benign disease and 20 percent of patients with BMI ≥25 kg/m^2^ had malignant tumors (P=0.023). On multivariate analysis, BMI <25 kg/m^2^ was independently associated with benign disease (OR: 1.5 (95% CI: 1.12-1.94), p=0.015). It should be noted that these studies originate in difference geographic regions: studies by Kava, et al. and Murphy, et al. investigate US populations, while the studies by Nishikawa, et al. and Jeon, et al. are from Japan and Korea. Population-based differences in BMI may explain differences in observed rates of malignant and benign disease that cannot be determined by the current literature. The stenght of evidence was insufficient on BMI (Table 9).

#### Incidental Presentation

Five studies included incidental presentation in the analysis of predictors of pathological outcome.40,47,49,56,57 The study by Lane 57 did not provide data that could be included in meta-analysis. Five of five (100 percent) studies found incidental presentation not to be predictive of malignancy and the meta-analysis indicated an aggregate effect size of 0.78 (95% CI: 0.48 to 1.08; Figure 8). The strength of evidence was moderate (Table 9).

Figure 8 Meta-analysis showing pooled odds ratio of incidental presentation

CI=Confidence Interval; ES=Effect size; OR=Odds Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Weighting is based on the inverse of the variance of each study estimate.

Figure 8 is a meta-analysis showing pooled odds ratio of incidental presentation.

### Other Characteristics

Of the seven studies incorporating a clinical feature into analysis of factors predictive of malignancy, three (43 percent) included surgery year.49,56,59 The one study that included laboratory testing used serum creatinine.54

## KQs 2a and 2b Accuracy and Efficacy of Renal Mass Biopsy in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

### Key Points

- Most included studies focus on core biopsy as it has been the preferred diagnostic renal mass sampling technique over fine needle aspiration in recent years. Only one study directly evaluated fine needle aspiration.
- About 14 percent of biopsies lead to a nondiagnostic result; of these patients who underwent surgery, the majority (90.4 percent) possess malignant tumors.
- Repeat biopsy led to a diagnosis in 80 percent of patients with initially nondiagnostic results, but was only performed in 20 percent of cases.
- Percutaneous renal mass biopsies have a low false positive rate (4.0 percent) for localized renal masses, as well as substantial histologic (77.5 percent to 100 percent) and RCC subtype identification rates (~90 percent), instilling confidence in a malignant biopsy result.
- [underlined: Among patients who undergo extirpative surgery for tumor removal], about one-third of those with negative biopsy results are found to have malignant disease on surgical pathology (36.7 percent), leading to a negative predictive value of 63.3 percent (CI, 52.4 percent to 74.2%) overall and 68.5 percent (CI, 57.6-79.4%) for the core biopsy subset.
- Core biopsy is highly sensitive (97.5%; 95% CI: 96.5% to 98.5%) in the diagnosis of localized malignant renal masses, when a diagnostic result is obtained. However, most patients (~80 percent) do not undergo surgery after a benign biopsy result, leading to uncertainty about the true proportion of false negatives.
- The majority of patients with RCC on biopsy have a sufficient specimen size to assign a Fuhrman grade, but a portion of these patients (16 percent) are upgraded from a low grade (1–2) to a high grade (3–4) on final surgical pathology.
- Strength of evidence is moderate for diagnostic accuracy. The primary limitation was the lack of surgical pathology for benign biopsies to augment true negative and false negative results (verification bias).
- Percutaneous renal mass sampling is associated with infrequent direct complications, including hematoma (4.9 percent), clinically significant pain (1.2 percent), gross hematuria (1.0 percent), pneumothorax (0.6 percent), and hemorrhage (0.4 percent).
- Indirect considerations include percutaneous renal mass sampling being performed with radiation exposure due to CT guidance (44 percent of the time). Nondiagnostic biopsies may lead to a need for further intervention, and false negative results have the potential to lead to inappropriately conservative management.
- Strength of evidence was rated as low for the evaluation of harms of renal mass biopsy including the finding of hematoma (4.9 percent) as the most common direct complication. Studies were inconsistent in which harms were reported with multiple studies missing harms of interest (hemorrhage, hematoma, pain) and less than half-including pneumothorax and gross hematuria.
- The studies had no reports of tumor seeding.

### Study Characteristics

Twenty studies evaluated percutaneous renal mass sampling via fine needle aspiration or core biopsy for localized renal masses (Table 10).51,61-79 Only one study meeting the inclusion criteria evaluated fine needle aspiration with cytopathology alone.61 All other studies evaluated core needle biopsy with surgical pathology, and three included patients also undergoing fine needle aspiration at the time of core biopsy.64,74,77 Four studies were designated prospective cohorts61,72,76,77 while the remainder were retrospective cohorts; all 20 were single center experiences.

Table 10 Characteristics of studies evaluating percutaneous renal mass sampling

Author, Year | n | Women: n (%) | Age (years): Mean, Median, Range, SD | Race: n (%)
Campbell, 1997^61^ | 25 | NR | NR | NR
Chyhrai, 2010^62^ | 25 | NR | Mean:63.0 SD:7.7 | NR
Halverson, 2013^63^ | 151 | NR | Mean:59.0 SD:14 | NR
Harisinghani, 2003^64^ | 28 | 10(36) | Range:40-70 | NR
Leveridge, 2011^65^ | 294 | NR | Median:64 Range:26-90 | NR
Londono, 2013^66^ | 126 | 42(33) | Mean:65.3 SD:14.6 | W: 96(76)
Menogue, 2012^67^ | 250 | NR | Median:64 Range:22-88 | NR
Millet, 2012^68,a^ | 187 | 30^a^(50^a^) | Median:60 Range:20-85 | NR
Neuzillet, 2003^69^ | 88 | 40(45) | Mean:61.32 Median:64 Range:21-88 SD:13.19 | NR
Park, 2013^51^ | 58 | 18(31) | Mean:56.8 Range:24-79 | NR
Prince, 2015^79^ | 525 | 191(36) | Median:65 | NR
Reichelt, 2007^76^ | 30 | 12(40) | Mean:63.0 SD:7.7 | NR
Richard, 2015^78^ | 509 | 210(40) | Mean:64.0 | NR
Salem, 2012^70^ | 145 | 46(31) | Mean:67.2 SD:11.6 | NR
Schmidbauer, 2008^77^ | 78 | 15(19) | | NR
Shannon, 2008^71,b^ | 221 | NR | Mean:64.0 Range:22-92 | NR
Sofikerim, 2009^72^ | 42 | 21(50) | Mean:56.1 Range:21-77 | NR
Vasudevan, 2006^73,b^ | 92 | NR | Mean:62.0 Range:22-92 | NR
Volpe, 2008^74^ | 91 | NR | Median:60 Range:25-89 | NR
Wang, 2009^75^ | 106 | 38(36) | Mean:60.4 Range:28-91 SD:15.4 | W:92(87)
Summary^b^ | 2979^b^ | 673 (38) | Mean:56.1-67.2 Median: 60-64 Range: 20-92 | 188 (81)

N = sample size; NR = not reported; SD = standard deviation; W = White

a Only reported for patients with surgical pathology (N=60).

b Summarized for unique patients; Shannon 2008 is an update of Vasudevan 2006.

Ten studies included consecutively performed biopsies.51,61,69,71-74,76-78 Nine studies were performed in North America61,63-66,74,75,78,79, five in Europe62,68,69,76,77, and three each were performed in Asia 51,70,72 and Australia.67,71,73 No study reported funding source. One study71 was an update of a previously published series.73

### Population Characteristics

A total of 2979 unique patients were included across all studies; the patient populations for each study varied between 25 and 525. For the studies that reported mean (N=13) and median (N=7) ages, the mean age ranged from 56.1 to 67.2 years, while the median age ranged from 60 to 65 years. Gender was reported for 1795 patients (60.3 percent), of which 673 (37.5 percent) were female (N=12 studies). Only two studies reported race, with the majority of patients classified as white (81.0 percent). Ten studies reported biopsies performed on consecutively eligible patients meeting inclusion criteria (Table 10).51,61,69,71-74,76-78

### Intervention Characteristics

Type of biopsy, needle size, and image guidance varied among percutaneous renal mass sampling interventions. Only one study61 reported results of fine needle aspiration with cytopathology, while all others focused primarily on the performance of percutaneous core biopsy with surgical pathology.51,62-79 One study included the concomitant performance of fine needle aspiration on all patients64 while two other studies included a subset of patients receiving both core biopsy and fine needle aspiration.74,77

Three studies including the performance of fine needle aspiration used 22 gauge needles61,64,74 while one did not specify.77 Fifteen of the 19 core biopsy studies used 18 gauge needles,51,62,64,65,67,69,71-79 2 included a variety of needle sizes,66,70 1 used 17 gauge needles,68 and 1 did not report needle size.63

Eleven of the 20 studies included a combination of biopsies performed under different imaging modalities (modalities were primarily computed tomography or ultrasound). Six studies used solely computed tomography (CT) guidance,61,64,68-70,77 and 3 only used ultrasound guidance.51,62,76

### Tumor Characteristics

A total of 3074 tumors were biopsied in the included studies. Eleven studies focused specifically on localized clinical T1a tumors51,62,63,65,67-70,74,75,78 and another three 61,71,73 focused on tumors smaller than or equal to 5 cm; among these studies, mean tumor size ranged from 2.3 to 3 cm (Table 11). Two studies reported on larger tumors with mean size of 5.5 cm66 and 6.4 cm,72 and one study did not provide tumor size.64 Seven studies reported on tumor laterality with a total of 1090 tumors of which 563 (51.7 percent) were located in the right kidney.69,70,72,74,75,77,78

Table 11 Characteristics of tumors in the studies evaluating percutaneous renal mass sampling

Author, Year | n^a^ | T1, n (%) | T1a, n (%) | T1-2, n (%) | Tumor Size (cm) | Tumor Location-Right, n (%)
Campbell, 1997^61^ | 25 | 25 (100) | NR | NR | Mean: 3.0 Median: 2.7 Range: 1.2-5.0 SD: 1.1 | NR
Chyhrai, 2010^62^ | 25 | NR | 25(100) | NR | Mean: 2.5 Range: 1.5-4.0 SD: 1.03 | NR
Halverson, 2013^63,b^ | 151 | NR | 151(100) | NR | Mean: 2.8* Range: 1.0-4.0 SD: 0.8 | NR
Harisinghani, 2003^64^ | 28 | NR | NR | 28(100) | NR | NR
Leveridge, 2011^65^ | 314 | NR | 314(100) | NR | Median: 2.5 Range: 0.6-4.0 | NR
Londono, 2013^66^ | 126 | NR | NR | 126(100) | Mean: 5.5 SD: 3.7 | NR
Menogue, 2012^67^ | 250 | NR | 250(100) | NR | Median: 2.5 Range: 0.9-4.0 | NR
Millet, 2012^68^ | 187 | NR | 187(100) | NR | Median: 3 Range: 0.9-4.0 | NR
Neuzillet, 2003^69^ | 88 | NR | 88(100) | NR | Median: 2.8 Range: 0.2-4.0 | 40(46)
Park, 2013^51^ | 59 | NR | 59(100) | NR | Mean: 2.3 Range: 1.1-3.9 | NR
Prince, 2015^79,c^ | 565 | NR | 413(73) | 152(27) | Mean: 2.9, 2.2 | NR
Reichelt, 2007^76^ | 30 | 30 | NR | NR | Mean: 2.9 SD: 1.1 | NR
Richard, 2015^78^ | 529 | NR | 529(100) | NR | Mean: 2.5 | 289(55)
Salem, 2012^70^ | 145 | NR | 145(100) | NR | Mean: 2.4 SD: 1.1 | 77(53)
Schmidbauer, 2008^77^ | 78 | NR | 44(56) | 34(44) | Mean: 4.0 Median: 3.9 Range: 0.8-9.0 SD: 1.8 | 39(50)
Shannon, 2008^71,d^ | 222 | 222(100) | NR | NR | Median: 2.9 Range: 1.0-4.9 | NR
Sofikerim, 2009^72^ | 42 | NR | NR | 42 100 | Mean: 6.4 Range: 2.5-14.0 | 21(50)
Vasudevan, 2006^73,d^ | 92 | 92(100) | NR | NR | NR | NR
Volpe, 2008^74^ | 100 | NR | 100(100) | NR | Median: 2.4 Range: 0.8-4.0 | 47(47)
Wang, 2009^75^ | 110 | NR | 110(100) | NR | Mean: 2.7 Range: 0.5-4.0 SD: 0.9 | 50(46)
Summary^b^ | 3074 | 277 (9) | 2415 (79) | 382 (12) | Mean: 2.3-6.4 Median: 2.2-3.9 Range: 0.5-14.0 | 563(52)

N = sample size; NR = not reported; SD = standard deviation

a 51,65,71,74,75 include a few patients with multiple tumors biopsied.

b Tumor size only reported for patients with malignant results on biopsy (N=133).

c Tumor size given for diagnostic and nondiagnostic groups separately as listed in table, respectively

d Summarized for unique patients; Shannon 2008 is an update of Vasudevan 2006.

### Risk of Bias

We used the quality assessment tool for diagnostic accuracy studies (QUADAS -2).37 Overall, 5 of the 20 studies were determined to be of low risk of bias (Figure 9).61,63,72,76,77 All studies were at low risk of bias for the reference standard test and the index test. The majority of studies (17 of 20) were also at low risk of bias for patient selection. However, the assessment of flow and timing showed 14 of 20 studies to have high potential risk of bias due to missing reference standard evaluations (surgical pathology) among patients with benign biopsy results limiting the tabulation of data on true negatives and false negatives.

Figure 9 Risk of bias assessment for studies evaluating percutaneous renal mass sampling

Figure 9 shows the risk of bias assessment for studies evaluating percutaneous renal mass sampling.

### Percutaneous Renal Mass Sampling

#### Histology

A total of 3,113 biopsies were performed, including 39 tumors in three studies on which more than one biopsy was performed (Tables 12a and 12b).65,66,71 Overall, 67.6 percent of the eligible biopsies were reported as malignant and 19.0 percent were reported as benign. The proportion of nondiagnostic biopsies was 14.1 percent overall and 13.9 percent when limited to core biopsy studies. Fourteen biopsies from one study were classified as normal and considered diagnostic benign lesions.75 These lesions were managed with observation or ablation. However, these biopsies could be considered nondiagnostic, as no etiology of the renal mass was given (i.e., cystic process or fibrosis), which would lead to estimates of nondiagnostic rates of 14.5 percent overall and 14.3 percent for core biopsy only, respectively. Clear cell renal cell carcinoma was the most common diagnosis across all studies, ranging from 30.4 percent to 80.0 percent of biopsies, depending on nondiagnostic rates. Other histologic results are given in Table 12a and 12b, and details of other malignant tumors, benign tumors, and conditions determined not to be neoplastic (Table 13).

Table 12a Details of biopsy pathology results across included studies

Author, Year | N | Nondiagnostic n (%) | Malignant n (%) | Benign n (%) | Clear cell RCC n (%) | Papillary RCC n (%) | Chromophobe RCC, n (%) | RCC (Uncategorized) n (%)
Campbell, 1997^61^ | 25 | 9(36) | 10(40) | 6(24) | NR | NR | NR | NR
Chyhrai, 2010^62^ | 25 | 2(8) | 16(64) | 7(28) | 14(56) | 1(4) | NR | NR
Halverson, 2013^63^ | 151 | 14(9) | 130(86) | 7(5) | 97(64) | 25(17) | 3(2) | 3(2)
Harisinghani, 2003^64^ | 28 | 0 | 17(61) | 11(39) | NR | NR | NR | 16(57)
Leveridge, 2011^65^ | 345 | 67(19) | 221(64) | 57(17) | 122(35) | 48(14) | 13(4) | 25(7)
Londono, 2013^66^ | 132 | 7(5) | 87(66) | 38(29) | NR | NR | NR | NR
Menogue, 2012^67^ | 250 | 52(21) | 148(59) | 50(20) | 100(40) | 33(13) | 11(4) | NR
Millet, 2012^68,a^ | 187 | NR | 145(78) | NR | NR | NR | NR | 132(71)
Neuzillet, 2003^69^ | 88 | 8(9) | 66(75) | 14(16) | 49(56) | 10(11) | 6(7) | NR
Park, 2013^51^ | 59 | 11(19) | 37(63) | 11(19) | NR | NR | NR | 29(49)
Prince, 2015^79^ | 565 | 83(15) | 393(70) | 89(16) | 260(46) | 48(9) | 5 | 33(6)
Reichelt, 2007^76^ | 30 | 5(17) | 17(57) | 8(27) | NR | NR | NR | 16(53)
Richard, 2015^78,b^ | 529 | 53(10) | 353(67) | 123(23) | 214(41) | 95(18) | 26(5) | 17(3)
Salem, 2012^70^ | 145 | 19(13) | 107(74) | 19(13) | 57(39) | 22(15) | 8(6) | 2(1)
Schmidbauer, 2008^77^ | 78 | 2(3) | 60(77) | 16(21) | 48(80) | 3(4) | 3(4) | 4(5)
Shannon, 2008^71,c^ | 224 | 50(22) | 132(59) | 42(19) | 85(38) | 25(11) | 11(5) | 3(1)
Sofikerim, 2009^72^ | 42 | 3(7) | 33(79) | 6(14) | 32(76) | 1(2) | 0 | NR
Vasudevan, 2006^73,c^ | 92 | 29(32) | 43(47) | 20(22) | 28(30) | 4(4) | 5(5) | NR
Volpe, 2008^74^ | 100 | 16(16) | 66(66) | 18(18) | 37(37) | 16(16) | 3(3) | 4(4)
Wang, 2009^75^ | 110 | 10(9) | 65(59) | 35(32) | NR | NR | NR | 56(51)
Summary^c^ | 3113 | 411(14.1^a^) | 2103 (68) | 557(19^a^) | 1115(36) | 327(11) | 89(3) | 340(11)

AML = angiomyolipoma; n = sample size; NR = not reported; RCC = renal cell carcinoma

a 42 (22.5%) biopsies were benign or nondiagnostic but the proportion of each was not reported; therefore, Millet, 2012is excluded from calculation of proportion of nondiagnostic and benign biopsies.

b Biopsy pathology results includes 20 repeat biopsies which were diagnostic.

c Summarized for unique patients/biopsies; Shannon 2008 is an update of Vasudevan 2006; histology percentages add to 100% after inclusion of 42 unclassified benign and nondiagnostic biopsies 68 and absence of histologies from 125 Londono, 2013 and 16 Campbell, 1997 biopsies.

Table 12b Details of biopsy pathology results across included studies

Author, Year | N | Other Malignant n (%) | Oncocytoma n (%) | AML n (%) | No Neoplasm n (%) | Other Benign n (%)
Campbell, 1997^61^ | 25 | NR | NR | NR | NR | NR
Chyhrai, 2010^62^ | 25 | 1(4) | 6(24) | NR | NR | 1(NR)
Halverson, 2013^63^ | 151 | 2(1) | 3(2) | NR | NR | 4(3)
Harisinghani, 2003^64^ | 28 | 1(4) | 1(4) | NR | 9(32) | 1(4)
Leveridge, 2011^65^ | 345 | 13(4) | 32(9) | 11(3) | NR | 14(4)
Londono, 2013^66^ | 132 | NR | NR | NR | NR | NR
Menogue, 2012^67^ | 250 | 4(2) | 33(13) | 9(4) | 6(2) | 2(1)
Millet, 2012^68,a^ | 187 | 13(7) | NR | NR | NR | NR
Neuzillet, 2003^69^ | 88 | 1(1) | 10(11) | 3(3) | NR | 1(1)
Park, 2013^51^ | 59 | 8(14) | 2(3) | 6(10) | 3(5.) | NR
Prince, 2015^79^ | 565 | 47(8) | 77(14) | 11(2) | NR | 1(0.2)
Reichelt, 2007^76^ | 30 | 1(3) | 6(20) | NR | NR | 2(7)
Richard, 2015^78,b^ | 529 | 13(3) | 80(15) | 36(7) | NR | 15(3)
Salem, 2012^70^ | 145 | 18(12) | 15(10) | NR | 4(3) | NR
Schmidbauer, 2008^77^ | 78 | 2(3) | 13(17) | 2(3) | 1(1) | NR
Shannon, 2008^71,c^ | 224 | 8(4) | 25(11) | 13(6) | 3(1) | 1(0.4)
Sofikerim, 2009^72^ | 42 | NR | 4(10) | 1(2) | NR | 1(2)
Vasudevan, 2006^73,c^ | 92 | 6(7) | 11(12) | 9(10) | NR | NR
Volpe, 2008^74^ | 100 | 6(6) | 7(7) | 5(5) | 4(4) | 2(2)
Wang, 2009^75^ | 110 | 11(10) | 13(12) | 3(3) | 16(15) | 1(1)
Summary^b^ | 3113 | 149(5) | 327(11) | 100(3) | 46(2) | 46(2)

AML = angiomyolipoma; cc = clear cell; N = sample size; NR = not reported; p = papilloma; RCC = renal cell carcinoma

a 42 (22.5%) biopsies were benign or nondiagnostic but the proportion of each was not reported; therefore, Millet, 2012is excluded from calculation of proportion of nondiagnostic and benign biopsies.

b Biopsy Pathology Results includes 20 repeat biopsies which were diagnostic.

c Summarized for unique patients/biopsies; Shannon 2008 is an update of Vasudevan 2006; histology percentages add to 100 percent after inclusion of 42 unclassified benign and nondiagnostic biopsies 68 and absence of histologies from 125 Londono, 2013 and 16 Campbell, 1997 biopsies.

Table 13 Details about patients with biopsies showing no neoplasm or other malignant or benign results

Author, Year | No Neoplasm: n (details) | Other Malignant: n (details) | Other Benign: n (details)
Campbell, 1997^61^ | NR | NR | NR
Chyhrai, 2010^62^ | NR | 1 (1 adenocarcinoma) | 1 (1 leiomyoma)
Halverson, 2013^63^ | NR | 2 (1 urothelial, 1 sarcomatoid renal cell carcinoma) | 4 (4 unspecified benign biopsies)
Harisinghani, 2003^64^ | 9 (6 hemorrhagic cysts, 3 inflammatory cysts) | 1 (1 lymphoma) | 1 (1 metanephric adenoma)
Leveridge, 2011^65^ | NR | 13 (13 unspecified malignant) | 14 (14 “other” benign)
Londono, 2013^66^ | NR | NR | NR
Menogue, 2012^67^ | 6 (6 cysts) | 4 (1 multilocular renal cell carcinoma, 1 urothelial, 1 TCC 1 metastasis) | 2 (1 metanephric adenoma, 1 leiomyoma)
Millet, 2012^68^ | NR | 13 (13 “other’ malignant) | NR (42 benign or nondiagnostic biopsies
Neuzillet, 2003^69^ | NR | 1 (1 lymphoma) | 1 (1 cystadenoma)
Park, 2013^51^ | 3 (3 inflammatory cysts) | 8 (4 metastasis, 2 urothelial, 1 PTLD, 1 lymphoma) | NR
Prince, 2015^79^ | NR | 47 (unspecified urothelial, collecting duct, lymphoma, leukemia)
Reichelt, 2007^76^ | NR | 1 (1 collecting duct carcinoma)
Richard, 2015^78^ | NR | 13 (1 mucinous tubular and spindle cell carcinoma, 9 metastasis, 3 “other” malignant) | 15 (3 metanephric adenoma, 2 leiomyoma, 10 “other” benign)
Salem, 2012^70^ | 4 (4 cysts) | 18 (1 renal medullary, 2 lympoma, 15 metastasis) | NR
Schmidbauer, 2008^77^ | 1 (1 cyst) | 2 (1 TCC, 1 metastasis) | NR
Shannon, 2008^71^ | 3 (3 cysts) | 8 (5 metastasis, 2 TCC, 1 collecting duct carcinoma) | 1 (1 metanephric adenoma)
Sofikerim, 2009^72^ | NR | NR | 1 (1 leiomyoma)
Vasudevan, 2006^73^ | NR | 6 (6 metastasis) | NR
Volpe, 2008^74^ | 4 (2 inflammatory cysts, 2 fibrosis) | 6 (2 metastasis, 1 TCC, 1 SCC, 2 other malignant) | 2 (2 leiomyoma)
Wang, 2009^75^ | 16 (14 normal tissue, 1 fibrosis, 1 sarcoid lesion) | 11 (3 lymphoma, 5 metastasis, 1 PTLD, 2 mixed epithelial/stroma tumor) | 1 (1 metanephric adenoma)
Summary | 46 | 149 | 46

n = sample size; NR = not reported; PTLD = post-transplant lymph proliferative disorder

#### Fuhrman Grade

Twelve studies 51,61,63,65,67-70,72,74,77,78 provided data on the Fuhrman grade assigned at biopsy (Table 14), including one using fine needle aspiration;61 the remainder used core biopsy. Grades were assigned for the 67.3 percent of biopsies showing RCC. Results showed 688 (87.8 percent) of patients with low grade (1–2) and 96 (12.2 percent) with high grade (3–4) tumors on biopsy. Surgical pathology was available for 489 tumors.

Table 14 Fuhrman grading results for studies reporting grade at biopsy

Author, Year | N | Renal Cell Carcinoma, n | Grade Assigned, n (%) | Fuhrman Grade: 1-2: n (%) 3-4: n (%) | Surgical Path | Upgraded: n (%)
Campbell,1997^61^ | 25 | 10 | 10(100) | 1-2: 7(70) 3-4: 3(3) | 10 | 1(10)
Halverson, 2013^63^ | 151 | 125 | 97(78) | 1-2: 85(88) 3-4:12(12) | 97 | 37(38)
Leveridge, 2011^65^ | 345 | 183 | 100(55) | 1-2: 89(89) 3-4:11(1) | NR | NR
Menogue, 2012^67^ | 250 | 144 | 122(85) | 1-2: 115(94) 3-4: 7(5.7) | 72 | 17(24)
Millet, 2012^68^ | 187 | 132 | NR^a^ | 1-2: 53(87) 3-4: 8(13) | 61 | 0(0
Neuzillet, 2003^69^ | 88 | 65 | 61(94) | 1-2: 55(90) 3-4:6(9.83) | 52 | 7(13)
Park, 2013^51^ | 59 | 29 | 4(14) | NR | 4 | 2(50)
Richard, 2015^78^ | 529 | 352 | 211(60) | 1-2: 194(92) 3-4: 17(8) | 101 | 6(6)
Salem, 2012^70^ | 145 | 90 | 47(52) | 1-2: 28(60) 3-4: 19(40) | 33 | NR
Schmidbauer, 2008^77^ | 78 | 58 | 47(81) | NR | 47 | 2(4)
Sofikerim, 2009^72^ | 42 | 34 | 34(100) | 1-2: 32(94) 3-4: 2(6) | 33 | 6(18)
Volpe, 2008^74^ | 100 | 60 | 41(68) | 1-2: 30(73) 3-4: 11(27) | 12 | 0(0)
Summary | 1999 | 1282 | 774(67^b^) | 1-2: 688(88) 3-4: 96(12) | 489^c^ | 78(16)

n = sample size; NR = not reported; SD = standard deviation; W = White

a Proportion of biopsies showing renal cell carcinoma that had grade assigned not reported; however, biopsy grade for 61 with surgical pathology available is reported.

b Denominator excludes 68 (N=132) as overall proportion assigned grade at biopsy not reported.

c Total excludes 68 and 70 as proportion upgraded on surgical pathology not given.

Ten studies51,61,63,67-69,72,74,77,78 reported tumor upgrading from low to high Fuhrman grade, resulting in an overall proportion of 16.0 percent being upgraded at surgical pathology. The accuracy of grades between biopsy and surgical pathology results varied, with studies reporting concordances of 51.5 percent,72 63.4 percent,78 65 percent,63 66.7 percent,74 69.8 percent,69 75 percent,68 and 75.9 percent.77 Two studies reported no low to high upgrading.68,74 Millet, et al. (2012),68 reporting one of the highest grade concordances (75 percent) and no upgrading, also grouped grades as low and high which showed a concordance of 93 percent and a kappa of 0.71. Other studies did not routinely report kappa statistics. The strength of evidence was low (Table 18).

Table 18 Strength of evidence for renal mass biopsy outcomes

Key Outcomes | No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Diagnostic Accuracy | 18 (2,203) | Medium | Direct | Consistent | Precise | Undetected | Moderate Renal mass biopsy has a high positive predictive value (99.8%) for the diagnosis of renal malignancy but also a notable nondiagnostic (~14%) rate and low negative predictive value (<70%). The primary limitation is the absence of surgical pathology for benign biopsies, but sensitivity and specificity of a diagnostic biopsy result appear to be over 90.
Fuhrman Grade | 12 (1,999) | High | Direct | Consistent | Imprecise | Undetected | Low Fuhrman upgrading on final pathology occurred in 20.5% of biopsies, but many studies did not provide data on grade concordance.
Harms | 16 (2,422) | Medium | Direct | Inconsistent | Precise | Undetected | Low A small, but notable, proportion of patients experience harms due to renal mass biopsy with hematoma (5%) being the most common direct complication. Studies were inconsistent in which harms, if any, were reported.

N = number; NA = not applicable

### Outcomes

#### Diagnostic Test-Related Outcomes (KQ2a)

Studies varied on which diagnostic test performance characteristics were reported and how these accuracy measures were calculated for renal mass biopsy. To standardize results, we cross-tabulated percutaneous renal mass biopsy results from the first attempted biopsy into contingency tables based on surgical pathology findings. Benign biopsy results were classified as true negatives or false negatives, and malignant biopsy results were classified as true positives or false positives. Nondiagnostic biopsy rate was considered a separate measure and was excluded from the primary diagnostic accuracy calculations. Nondiagnostic biopsies are NOT considered negative results in this analysis. After pooling patients from all studies, we performed diagnostic accuracy calculations for the pooled samples and the core biopsy subset.

##### False Positives, False Negatives and Nondiagnostic Biopsies

Of the 20 included studies, 19 reported at least some data on these outcomes (Table 15).51,61-78 Importantly, among 1710 malignant biopsies from these studies, 965 (56.4 percent) proceeded to surgery with available pathology results, among which only 2 (0.21 percent) were false positives. In contrast, only 79 (16.9 percent) of 468 benign biopsies had surgical pathology available; 29 (36.7 percent) of the 79 were false negatives. The false negative rate (percentage of specimens having malignancy on surgical pathology for which the biopsy was falsely negative) was 3.1 percent (29/931), and the false positive rate was 4.0 percent (2/50). Of note is that nondiagnostic biopsies are NOT used to calculate these parameters and only diagnostic biopsies were considered for calculation of true positives, true negatives, false positives, and false negatives. Among the 73 (22.3 percent) nondiagnostic biopsies with surgical pathology available, 90.4 percent of the tumors were found to be malignant.

Table 15 Calculated performance characteristics from each individual study based on patients with available surgical pathology

Author, Year | Biopsy n | Surgery n (%) | Nondiagnostic Biopsy | | Benign Biopsy | | Malignant Biopsy | | Sensitivity (%) | Specificity (%) | PPV (%) | NPV (%)
Author, Year | Biopsy n | Surgery n (%) | Surgery n | Malignant n (%) | True Negative | False Negative | True Positive | False Positive | Sensitivity (%) | Specificity (%) | PPV (%) | NPV (%)
Campbell, 1997^61^ | 25 | 25(100) | 9 | 9(100) | 0 | 6 | 10 | 0 | 63 | NA | 100 | 0
Chyhrai, 2010^62^ | 25 | 21(84) | 1 | 1(100) | 5 | 1 | 14 | 0 | 94 | 100 | 100 | 83
Halverson, 2013^63^ | 151 | 151(100) | NR | NR | 4 | 3 | 130 | 0 | 98 | 100 | 100 | 57
Harisinghani, 2003^64^ | 28 | 16(57) | 0 | NR | 1 | 0 | 16 | 0 | 100 | 100 | 100 | 100
Leveridge, 2011^65^ | 345 | 74(21) | 6 | 5(83) | NR | NR | NR | NR | NA | NA | NA | NA
Londono, 2013^66^ | 132 | 63(48) | 2 | 2(100) | 2 | 13 | 46 | 0 | 78 | 100 | 100 | 13
Menogue, 2012^67^ | 250 | 129(52) | 9 | 8(89) | 6 | 0 | 114 | 0 | 100 | 100 | 100 | 100
Millet, 2012^68,a^ | 187 | 61(33) | NR | NR | NR | NR | 61 | 0 | NA | NA | 100 | NA
Neuzillet, 2003^69^ | 88 | 62(70) | 5 | 5(100) | 1 | 0 | 56 | 0 | 100 | 100 | 100 | 100
Park, 2013^51^ | 59 | 13(22) | 2 | 2(100) | 0 | 0 | 11 | 0 | 100 | NA | 100 | NA
Prince, 2015^79^ | 565 | NR | NR | NR | NR | NR | NR | NR | NA | NA | NA | NA
Reichelt, 2007^76^ | 30 | 22(73) | 4 | 4(100) | 4 | 0 | 14 | 0 | 100 | 100 | 100 | 100
Richard, 2015^78^ | 529 | 171(32) | 4 | 4(100) | 3 | 0 | 163 | 1 | 100 | 75 | 99.4 | 100
Salem, 2012^70^ | 145 | 93(64) | 6 | 6(100) | 0 | 0 | 87 | 0 | 100 | NA | 100 | NA
Schmidbauer, 2008^77^ | 78 | 78(100) | 2 | 2(100) | 13 | 3 | 60 | 0 | 95.2 | 100 | 100 | 81.3
Shannon, 2008 71,b | 224 | 118(53) | 15 | 12(80) | 7 | 0 | 96 | 0 | 100 | 100 | 100 | 100
Sofikerim, 2009^72^ | 42 | 42(100) | 3 | 3(100) | 3 | 3 | 32 | 1 | 91 | 75 | 97 | 50
Vasudevan, 2006 73,b | 92 | 48(52) | 9 | 8(89) | 3 | 0 | 36 | 0 | 100 | 100 | 100 | 100
Volpe, 2008^74^ | 100 | 23(23) | 3 | 1(33) | 0 | 0 | 20 | 0 | 100 | NA | 100 | NA
Wang, 2009^75^ | 110 | 36(33) | 2 | 2(100) | 1 | 0 | 33 | 0 | 100 | 100 | 100 | 100
Summary | 2640^b^ | 1246(47) | 73 | 66(90.4)

n = sample size; NA = not applicable; NPV = negative predictive value; NR = not reported; PPV = positive predictive value

a 42 (22.5%) biopsies were benign or nondiagnostic but the proportion of each is not reported.

b Summarized for unique patients/biopsies; Shannon 2008 is an update of Vasudevan 2006.

###### Sensitivity, Specificity, and Positive and Negative Predictive Value

The one study evaluating fine needle aspiration had a sensitivity of 62.5 percent, which was related to the detection of malignant renal masses among diagnostic biopsies.61 Only two studies included consecutive patients undergoing core biopsy with surgery pathology available for all tumors.72,77 The larger of these included 78 patients and showed a sensitivity of 95.2 percent, specificity of 100 percent, positive predictive value of 100 percent, and negative predictive value of 81.3 percent.77 The other study included 42 patients and showed a sensitivity of 91.4 percent, specificity of 75.0 percent, positive predictive value of 97.0 percent, and negative predictive value of 50.5 percent.72 Table 16 presents pooled diagnostic accuracy estimates for all diagnostic biopsies as well as the core biopsy subset. Core biopsy had a sensitivity of 97.5 percent, specificity 96.2 percent, positive predictive value of 99.8 percent, and negative predictive value of 68.5 percent. The negative predictive value indicates the percentage of negative (nonmalignant) biopsies confirmed negative (nonmalignant) on surgical pathology. Calculated likelihood ratios for core biopsy based on pooled estimates lead to a positive likelihood ratio of 25.3 and negative likelihood ratio of 0.026. However, likelihood ratios are derived only from sensitivity and specificity, which are prone to verification bias among the included studies. Given the studies appear to include a representative prevalence of small renal mass histologies, predictive values from the data may be more clinically relevant than likelihood ratios. Among core biopsy studies judged to be at low risk of bias, similar diagnostic accuracy estimates were obtained with sensitivity of 96.3%, specificity 96.0%, positive predictive value 99.6%, and negative predictive value 72.7%.63,72,76,77

Table 16 Pooled diagnostic accuracy estimates

| Sensitivity (%) | 95% CI | Specificity (%) | 95% CI | PPV* (%) | 95% CI | NPV (%) | 95% CI
Diagnostic Biopsies Only | 96.9 | 95.8-98.0 | 96.2 | 90.7-100 | 99.8 | 99.5-100 | 63.3 | 52.4-74.2
Core Biopsy Subset | 97.5 | 96.5-98.5 | 96.2 | 90.7-100 | 99.8 | 99.5-100 | 68.5 | 57.6-79.4

NPV = negative predictive value; PPV = positive predictive value

###### Histologic Concordance and Repeat Biopsies

Histologic concordance was generally high among studies reporting specific histology. Three studies68,74,75 reported 100 percent histopathology concordance, and one each reported 94.7 percent,77 93 percent,78 92 percent,69 and 77.5 percent.72 The RCC subtype concordance was also substantial with studies reporting concordance in 53 of 58 masses,77 28 of 29 masses,75 27 of 29 masses,66 and a final study reporting a kappa of 0.69.^65^

There was variation in the performance and reporting on repeat biopsies for nondiagnostic lesions. Repeat biopsies were reported for 84 of 411 (20.4 percent) nondiagnostic biopsies. A single repeat biopsy helped diagnose 19 of 24,^79^ 20 of 24,^78^ 6 of 9,^70^ 10 of 12,^65^ 9 of 12,^71^ and 3 of 3^51^ initially nondiagnostic lesions among studies for an overall rate of 67 (79.8 percent) out of 84. A third biopsy led to diagnosis in a 10^th^ patient in one study.71

#### Harms and Adverse Events Associated With Percutaneous Renal Mass Sampling (KQ2b)

##### Direct Complications

Direct complications for percutaneous renal mass sampling were infrequent (Table 17). The most common complications were development of a hematoma (4.9 percent) and clinically significant pain (1.2 percent). The definition for hematoma varied between studies, but the majority of patients underwent CT to check for any procedure-related complications, including hematoma development. No study reported any cases of tumor seeding.

Table 17 Studies reporting harms and adverse events associated with percutaneous renal mass sampling

Author, Year | N | Radiation Exposure, n (%) | Hemorrhage, n (%) | Hematoma, n (%) | Pain, n (%) | Pneumothorax, n (%) | Tumor Seeding, n (%) | Hematuria, n (%) | Other
Campbell, 1997^61^ | 25 | 25(100) | 0 | 10(40) | NR | 0 | 0 | NR
Chyhrai, 2010^62^ | 25 | 0 | 1(4) | NR | 1(4) | 0 | 0 | NR
Harisinghani, 2003^64^ | 28 | 28(100) | NR | NR | NR | NR | NR | NR
Leveridge, 2011^65^ | 227^a^ | 151 (of 336) (45) | 0 | 22(10) | NR | 2(1) | 0(0) | 3(1)^a^ | 1 syncope
Millet, 2012^68^ | 187 | 187(100) | NR | NR | NR | NR | NR | NR
Neuzillet, 2003^69^ | 88 | 88(100) | 0 | 0 | 0 | NR | 0 | NR
Park, 2013^51^ | 59 | 0 | 0 | 9(15) | 3(5) | 0 | NR | 0
Prince, 2015^79^ | 565 | 48(9) | 3(0.5)^b^ | NR | NR | NR | NR | NR | 7 hospital admissions
Reichelt, 2007^76^ | 30 | 0 | 1(3) | 1(3) | 1(3) | NR | NR | NR
Richard, 2015^78^ | 492 | 115 (of 503) (23) | NR | 24(5)^c^ | 3(0.6) | NR | 0 | 5(1) | 12 coaxial sheath venous bleeding, 2 dizziness, 2 nausea/vomiting, 1 skin hematoma
Salem, 2012^70^ | 145 | 145(100) | 0 | 2(1) | 0 | NR | 0 | NR | 1 flank ecchymosis
Schmidbauer, 2008^77^ | 78 | 78(100) | 0 | 4(5) | NR | 1(1) | NR | NR
Shannon, 2008^71^ | 221 | NR | 1(0.4) | 1(0.4) | NR | NR | 0 | NR
Sofikerim, 2009^72^ | 42 | 42(100) | 0 | 0 | 0 | NR | 0 | 0
Volpe, 2008^74^ | 100 | 55(55) | 0 | NR | 1(1) | 1(1) | 0 | NR | 1 syncope
Wang, 2009^75^ | 110 | 66(60) | NR | 2(2) | 4(4) | 0 | NR | NR | 1 wound infection, 1 hypotension requiring fluid resuscitation
Summary | | 1028(44) | 6(0.4) | 75(5) | 13(1.2) | 4(0.6) | 0(0) | 8(1)

n = sample size; NR = not reported

a 67 patients without complication data available; Clavien 1 complications in 10.1 percent of patients; one Clavien 3a complication (0.3%) noted involving gross hematuria leading to urinary retention due to formation of clots.

b One Clavien 3a complication (selective renal artery embolization for bleeding leading to hemodynamic instability).

c One Clavien 3b complication (required percutaneous embolization).

Clinically significant pain was defined as requiring medication51 or emergency department evaluation.75 Gross hematuria (1.0 percent), pneumothorax (0.6 percent), and hemorrhage (0.4 percent) were rarer events but were noted in some patients. Three studies specifically referenced Clavien graded complications.65,78,79 One study noted Clavien 1 complications in 10.1 percent of patients and observed a single Clavien 3a complication (0.3 percent).65 The Clavien 3a complication involved gross hematuria leading to urinary retention due to formation of clots. A second study noted a Clavien 3b complication (percutaneous angioemolization)78 and third study noted a Clavien 3a complication (selective renal artery embolization for bleeding leading to hemodynamic instability).79

##### Indirect Diagnostic Test-Related Considerations

Percutaneous renal mass sampling often requires radiation exposure when computed tomography (CT) is used. Biopsy was performed under computed tomography (CT) guidance with or without ultrasound in 44.3 percent of patients. Three studies used ultrasound guidance only.51,62,76 False positives were rare (as previously noted) with only two cases (0.21 percent) among the included studies. False negative results presented a greater potential harm, as 36.7 percent of negative biopsies in these studies were found to be malignant on surgical pathology.

However, the majority of patients with benign biopsies do not undergo extirpative management, leading to greater uncertainty in the true proportion of false negatives, which may lead to inappropriately conservative management. Furthermore, the majority of nondiagnostic biopsies that undergo surgical management are found to be malignant (90.4 percent), indicating that further workup or intervention may be needed for a nondiagnostic biopsy. Additional considerations include lack of individual-level details in some studies for patients developing perirenal hematomas, such as preexisting risk factors contributing to hematoma, harms of needing to be off anticoagulation therapy to perform a biopsy, and effect of hematoma on delay to surgery or the ability to perform partial nephrectomy.

## KQ 3a Efficacy and Comparative Efficacy of Different Interventions for the Management of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

### Key Points

#### Controlled Studies

##### Oncologic Efficacy and Overall Survival

- In the only comparative study including active surveillance as a management option, active surveillance was similar to radical nephrectomy in overall survival and cancer-specific survival in patients more than 75 years old, after adjustment for age and comorbidity.
- Nonsurgical management (in studies of the Surveillance, Epidemiology, and End Results (SEER) database) was associated with a two-fold inferior overall survival and cancer-specific survival compared with radical nephrectomy and partial nephrectomy (low strength of evidence).
- Overall survival was similar between radical nephrectomy and partial nephrectomy (low strength of evidence). The only randomized trial confirmed this finding in patients with RCC. Population-based studies using the SEER database consistently revealed a higher overall survival for partial nephrectomy compared with radical nephrectomy in patients with T1a tumors (hazard ratio (HR) 1.23, CI 1.13 to 1.33).
- Partial nephrectomy was associated with equivalent cancer-specific survival compared with radical nephrectomy for T1 tumors (moderate strength of evidence) across SEER (HR 1.18, CI 0.94 to 1.42) and non-SEER (HR 1.08, CI 0.87 to 1.33) studies. Only one study compared partial nephrectomy with radical nephrectomy specifically for T2 tumors and demonstrated similar cancer-specific survival.
- Thermal ablation was generally associated with similar or worse overall survival compared with partial nephrectomy (low strength of evidence) due to the selection of older patients with greater comorbidity to undergo the procedure. Strength of evidence was insufficient for the comparison of overall survival between thermal ablation and radical nephrectomy.
- Thermal ablation demonstrated similar cancer-specific survival and metastasis-free survival compared with radical nephrectomy (moderate strength of evidence) and partial nephrectomy (low strength of evidence).
- Thermal ablation was associated with worse local recurrence-free survival compared with radical nephrectomy (low strength of evidence) and partial nephrectomy (moderate strength of evidence). The interquartile ratio was 84.7 percent to 94.7 percent for thermal ablation compared to 97 percent to 100 percent for partial nephrectomy across studies. After repeat treatments, secondary efficacy of thermal ablation more closely approximated the local cancer control rates of radical nephrectomy and partial nephrectomy.

##### Renal Functional Outcomes

- In patients undergoing treatment for a renal mass suspicious for stage T1 or T2 RCC, kidney function (measured through estimated glomerular filtration rate (eGFR)) consistently appeared to worsen by 1-40 ml/min/1.73 m^2^ in the immediate postoperative setting but improved over the next 1 to 6 months and remained relatively stable after that point.
  ○ This improvement was more pronounced in thermal ablation arms, where final eGFR was on average 2.83 ml/min//1.73 m^2^ better than postoperative eGFR.
  ○ This improvement was not as common in radical nephrectomy arms, where final eGFR was on average 0.83 ml/min//1.73 m^2^ better than postoperative eGFR.
- Radical nephrectomy was associated with worse renal outcomes when compared with partial nephrectomy and with thermal ablation:
  ○ The final eGFR rate fell, on average, 3.6 ml/min/1.73 m^2^ lower (range -1.2 to 37.5) with radical nephrectomy than with partial nephrectomy (moderate strength of evidence), with an increased risk of all stages of chronic kidney disease (1.3 to 2.7 times higher risk, moderate strength of evidence). The incidence of chronic kidney disease was estimated at 32 percent for radical nephrectomy, with range of average incidence across studies 2 to 70 percent.
    ■ Significant heterogeneity in the estimated glomerular filtration rate outcome existed, with one of the largest studies showing the smallest difference between partial nephrectomy and radical nephrectomy.
    ■ Individual decline in eGFR and risk of chronic kidney disease therefore can be more or less extreme than this (range of average decline seen across studies was -1.2 to 37.5 ml/min/1.73 m2 more for radical nephrectomy)
  ○ The final eGFR fell, on average, 9.9 ml/min/1.73 m^2^ (range -1.5 to 22.4) more with radical nephrectomy than with thermal ablation (moderate strength of evidence), with 3.48-fold [95% CI 1.08-11.15] higher risk of chronic kidney disease stage 3 for those receiving radical nephrectomy (moderate strength of evidence).
- Partial nephrectomy was associated with similar renal outcomes when compared with thermal ablation, with all comparisons not reaching statistical significance:
  ○ The final eGFR rate fell, on average, 1.0 ml/min/1.73 m^2^ [95% CI -0.2-2.1] less with thermal ablation than with partial nephrectomy (low strength of evidence).
  ○ The risk of all stages of chronic kidney disease were not significantly different between groups (1.14 [95% CI 0.77-1.67] times higher risk of CKD stage 3 for thermal ablation; 2.78 [95% CI 0.47-16.54] times higher risk of CKD stage 4 for partial nephrectomy; 1.09 [95% CI 0.23-5.20] times higher risk of ESRD for partial nephrectomy; low strength of evidence).
- Only two comparative studies of renal functional outcomes included active surveillance. These studies demonstrated higher final eGFR, a smaller change in eGFR, and a lower incidence of stage III chronic kidney disease with active surveillance than with radical nephrectomy, and similar final kidney function between active surveillance and the nephron sparing arms. The strength of evidence was insufficient to support a conclusion.
- The incidence of end stage renal disease was low in all interventions; however, most studies have limitations of few patients and events, and only short term followup.

##### Quality of Life

- The strength of evidence was insufficient for health-related quality of life given only four studies evaluated comparative health-related quality of life outcomes after radical nephrectomy and partial nephrectomy.
- No studies evaluated comparative health-related quality of life for thermal ablation or active surveillance.
- Results among studies were not directly comparable. However, the evaluable studies demonstrated:
  ○ Cancer-specific health-related quality of life (as specified by the CARES-SF questionnaire) was better in patients undergoing radical nephrectomy in comparison to partial nephrectomy.80.
  ○ Anxiety and depression following surgery were less with partial nephrectomy than with radical nephrectomy. 81
  ○ Physical function was better after partial nephrectomy than after radical nephrectomy in one study, 82 and was not significantly different in two other studies. 80,83
  ○ General and mental health-related quality of life after surgery was not different between radical and partial nephrectomy.
  ○ Health-related quality of life was related to complications, regardless of the surgical approach.

##### Perioperative Outcomes and Harms

###### Perioperative Outcomes

- The strength of evidence was moderate for perioperative outcomes comparing radical and partial nephrectomy, and partial nephrectomy and thermal ablation. Strength of evidence was low or insufficient for other comparisons.
- Thermal ablation had the most favorable perioperative outcomes with fewer conversions to open surgery and shorter length of stay when compared to radical nephrectomy (low strength of evidence); and less estimated blood loss, less blood transfusions, no conversions to open surgery or radical nephrectomy, and shorter length of stay when compared to partial nephrectomy (moderate strength of evidence).
- Partial nephrectomy had a higher blood transfusion rate than radical nephrectomy (16.3 percent vs. 7.3 percent respectively) and thermal ablation (4.6 percent vs. 0.4 percent respectively).
  ○ These data are supported by meta-analysis that demonstrates a relative risk (RR) of blood transfusion that favors radical nephrectomy (RR 0.8, 95% CI: 0.6-0.9) and thermal ablation (RR: 1.6, 95% CI: 1.1-2.5) in comparison to partial nephrectomy.
- Other perioperative outcomes were similar between radical nephrectomy and partial nephrectomy.

###### Harms

- In meta-analysis, minor and major complication rates were similar for patients undergoing radical nephrectomy, partial nephrectomy and for those undergoing thermal ablation.
- While overall rates of harms were similar, specific complications varied among management strategies:
  ○ Patients undergoing partial nephrectomy had higher rates of urologic complications including renal abscess, subsequent intervention, ureteral injury, urine leak, and other urologic complications in comparison to patients undergoing radical nephrectomy (low strength of evidence).
  ○ Patients undergoing radical nephrectomy had higher rates of acute kidney injury and nonurological complications, but lower rates of bleeding or urine leak when compared to patients undergoing thermal ablation (low strength of evidence).
  ○ Patients undergoing partial nephrectomy had higher rates of acute kidney injury, cardiovascular, hematologic and respiratory harms, but lower rates of infectious disease and wound complications in comparison to patients undergoing thermal ablation (low strength of evidence).
- No study reported on the perioperative (i.e., procedural) outcomes or harms in patients receiving active surveillance.

#### Uncontrolled Studies

##### Active Surveillance

- Objective selection criteria for active surveillance were not indicated in any study.
- Patients were primarily more than 70 years old and had clinically localized tumors on the order of 2 cm in diameter.
- There was no standard active surveillance protocol.
  ○ Two prospective studies84,85 and one, detailed retrospective series86-88 described interval imaging every 3-6 months for 2-3 years and annually thereafter, annual metastatic evaluation including chest imaging and laboratory evaluations, and inconsistent use of renal mass biopsy.
  ○ Data from retrospective studies included a variety of imaging modalities at various imaging intervals, ranging primarily from 3 to 6 months.
- Cancer-specific survival rates and metastasis-free survival rates were excellent, on the order of 98 percent to 100 percent with short followup (12-36 months). Few patients developed metastatic disease or died of renal cancer. Overall survival ranged from 69 percent to 94 percent over the same time interval.

### Controlled Studies

#### Study Characteristics

Ninety-nine comparative studies (reported in 102 articles) addressed the effectiveness of management strategies for localized renal masses concerning for RCC. There was one RCT (reported in 3 articles),89,90 91 and the remainder were cohort studies. There were 28 multi-institutional studies and 67 single-institution studies. Fifteen of the studies were conducted in Asia, 16 were conducted primarily in Europe, one was a collaborative effort between European and American institutions, and 62 were conducted in North America. Eleven studies received government or nonprofit funding, 3 received industry funding,92,93 94 and the remainder did not report any funding source.

#### Population Characteristics

In total, 179,740 patients were included in the comparative studies on KQ 3a. The characteristics of the study populations are summarized in Table 19. The median of the reported mean age of patients was lower for radical nephrectomy and partial nephrectomy than for thermal ablation and active surveillance. Gender was reported in 87 studies, with women accounting for 45 percent or less of patients in most studies except for the studies on active surveillance. Most studies did not report details on race/ethnicity, making it difficult to determine the typical racial/ethnic distribution of the study populations. Only a minority of studies reported on the baseline body mass index (25 studies), smoking status (9 studies), and specific comorbid conditions of the study populations, such as hypertension (26 studies), diabetes mellitus (35 studies), cardiovascular disease (12 studies), or chronic kidney disease (16 studies). Fifty-nine studies reported data on estimated glomerular filtration rate or serum creatinine at baseline, showing a mean estimated glomerular filtration rate that was somewhat lower in patients undergoing thermal ablation than in patients undergoing radial or partial nephrectomy.

Table 19 Participant characteristics of included studies by interventions

Participant Characteristics | Radical Nephrectomy | Partial Nephrectomy | Thermal Ablation | Active Surveillance
# of studies | 80 | 97 | 29 | 5
# of patients (median; range) | 119,328 (171.5; 13 to 14,807) | 53,928 (100; 6 to 7704) | 4089 (51; 9 to 1114) | 4952 (754; 68 to 3271)
median of mean age, years (# of studies) | 61.9(56) | 60.1 (71) | 66.6 (23) | 73.4 (2)
Age range, years | 18 to 97 | 18 to 92 | 19 to 90 | Not reported
Median of % women (# of studies) | 40 (65) | 37 (74) | 36.0 (20) | 45 (3)
Mean of % nonwhite (# of studies) | 20.1 (25) | 21.1 (28) | 31.1 (9) | 24.2% (4)
Median of mean BMI, kg/m^2^ (# of studies) | 25 (14) | 28.5 (24) | 29.3 (11) | 28.7(1)
Mean % of smokers (# of studies) | 39.4 (8) | 35.1(10) | 20.2 (2) | 0
Mean % of hypertensive patients (# of studies) | 56.3 (26) | 54.6 (29) | 30.9 (4) | 62 (2)
Mean % of diabetes patients (# of studies) | 20.4 (26) | 21.5 (29) | 23.4(8) | 32 (1)
Mean % of cardiovascular disease patients | 37.5 (11) | 27.1 (12) | 28.7(5) | 7(1)
Mean % of chronic kidney disease patients (# of studies) | 38 (8) | 53.2 (9) | 52.8 (7) | 28 (2)
Mean % of solitary kidney patients (# of studies) | 0.24 (20) | 11.04 (28) | 24.9 (13) | 4.5 (2)
# of studies with > 50% solitary kidney | 0 | 2 | 2 | 0
Median of mean GFR,mL/min (# of studies) | 75.1 (20) | 74.95 (27) | 61.1 (13) | 81.45(1)
Median of mean Creatinine, mg/dL (# of studies) | 1(18) | 1.01 (28) | 1.3 (12) | Not reported
Median of mean followup, months (# of studies) | 30 (38) | 30 (51) | 32.7 (19) | 58.2 (2)

#### Tumor Characteristics

Most of the comparative studies included in our review on KQ 3a focused on patients with clinical stage T1 tumors, but some studies focused on clinical stage T2 tumors or included patients with either T1 or T2 tumors (see Table 20). In the studies of radical or partial nephrectomy that reported on postsurgical upstaging to pathologic stage T3, a small percentage of tumors were upstaged. The median of the reported mean tumor size was greater for patients receiving radical nephrectomy than for patients receiving partial nephrectomy, thermal ablation, or active surveillance. Although many studies did not report on the histologic subtypes of the tumors, the most commonly reported histologic type was clear cell carcinoma for patients undergoing nephrectomy or thermal ablation. Data on intra-operative ischemia time was reported in only 15 studies. Data on surgical margin status was reported in only 15 studies.

Table 20 Tumor characteristics of included studies by intervention

Tumor Characteristics | Radical Nephrectomy | Partial Nephrectomy | Thermal Ablation | Active Surveillance
No. of studies | 80 | 97 | 29 | 5
No. studies with clinical Stage T1 (T1a, T1b, combined T1) | T1a:28 T1b:19 T1:28 | T1a:41 T1b:22 T1:30 | T1a:15 T1b:4 T1:5 | T1a:3 T1b:1 T1:2
No. studies with clinical Stage T2 | 9 | 10 | 0 | 0
No. studies with combined clinical Stage T1 and T2 | 7 | 7 | 2 | 1
Median % upstaging to pT3 (no. of studies) | 11 (25) | 5.8 (23) | 0 (1) | Not reported
Median of mean tumor size, cm (no. of studies) | 4.7 (47) | 2.9 (73) | 2.5 (20) | 2.92 (2)
Range of mean tumor size, cm | 2.8 to 6.1 | 1.7 to 8.8 | 2 to 5 | 2.04 to 3.8
Median % with clear cell carcinoma (no. of studies) | 79.5 (39) | 72.5 (55) | 66.7 (13) | 31.6 (1)
Median % with papillary renal cell carcinoma (no. of studies) | 8.4 (33) | 13.6 (48) | 8 (12) | 5.5 (1)
Median % with chromophobe renal cell carcinoma (no. of studies) | 5.1 (30) | 6.3 (44) | 2.65 (10) | 3 (1)
Median % with Fuhrman grade 1 or 2 renal cell carcinoma (no. of studies) | 70.3 (26) | 70.9 (34) | 85 (5) | 41.4 (1)

pT3 = pathologic stage T3

#### Intervention Characteristics

##### Radical Nephrectomy

Radical nephrectomy was evaluated in 80 of the comparative studies on KQ 3a. Studies included minimally invasive (laparoscopic or robotic-assisted laparoscopic) surgery, open surgery, or both. Sixteen studies were exclusively minimally invasive surgery, and 12 studies were exclusively open surgery. The remainder of the studies either contained a combination of the two techniques or did not specify the technique.

##### Partial Nephrectomy

Partial nephrectomy was evaluated in 97 of the comparative studies on KQ 3a. Studies included minimally invasive (laparoscopic or robotic-assisted laparoscopic) surgery, open surgery, or both. Twenty-three studies were exclusively minimally invasive surgery. Fifteen studies were exclusively laparoscopic surgery, 3 studies were exclusively robotic-assisted laparoscopic surgery, and 5 were a combination of laparoscopic approaches. Eighteen studies were exclusively open surgery. The remainder of the studies either had a combination of open and laparoscopic techniques or did not specify the technique.

##### Thermal Ablation

Thermal ablation was evaluated in 29 of the comparative studies on KQ 3a. Studies included cryoablation, radiofrequency ablation, or both. The approach to these techniques included laparoscopic, percutaneous (image guided), or both. Eleven studies were exclusively cryoablation and 13 were exclusively radiofrequency ablation. The remainder of the studies either had a combination of the two techniques or did not specify the technique. Nine studies were exclusively laparoscopic, and the remainder of the studies either had a combination of the two techniques or did not specify the technique.

##### Active Surveillance

Active surveillance was evaluated in five of the comparative studies on KQ 3a. These studies included patients who were placed on a surveillance protocol as well as those who underwent delayed primary intervention.

### Outcomes

#### Oncologic Efficacy

Sixty studies (reported in 61 articles) provided data on at least one oncologic efficacy outcome (cancer-specific survival, metastasis-free survival, or local recurrence-free survival) (Table 21). A specific distinction is made for nonsurgical management in the SEER database. As SEER is encoded by diagnostic and surgical codes, patients can only be identified by disease state and the presence or absence of surgical management. The SEER database does not identify the reason for nonsurgical management. Therefore, in SEER, patients cannot be identified as undergoing active surveillance, but only as not having undergone surgery. A further limitation of the SEER database is a potential selection bias for patients selected to undergo partial nephrectomy as compared to radical nephrectomy, which has been repeatedly suggested in the literature as well as analyzed in a well-designed study.95 Therefore, when possible, results are stratified by SEER and SEER studies to account for this potential bias.

Table 21 Number of studies comparing oncologic efficacy outcomes between management strategies

Management Strategy | Cancer-Specific Survival | Metastasis-Free Survival | Local Recurrence-Free Survival
Radical nephrectomy vs. partial nephrectomy | 37 studies | 13 studies | 21 studies
Radical nephrectomy vs. thermal ablation | 2 studies | 2 studies | 2 studies
Radical nephrectomy vs. active surveillance | 1 study | 1 study | 1 study
Partial nephrectomy vs. thermal ablation | 9 studies | 8 studies | 14 studies
Partial nephrectomy vs. active surveillance | 0 | 0 | 0
Nonsurgical management vs. radical nephrectomy vs. partial nephrectomy | 3 studies | 0 | 0

The studies were grouped into the following categories: one RCT,90 48 institutional cohorts,82,83,92,96-140 and 11 studies (in 12 articles) of the SEER dataset.141-152 Three of the institutional cohorts evaluated patients with solitary kidneys.126,137,138 One of these studies 137 is an update to a previous study 138 from the same institution with overlap of cohorts.

It is important to distinguish large, institutional comparisons from the national SEER analyses, as both sources of data have significant benefits and shortcomings. In general, institutional databases have more granular data, but are often limited to one location. The SEER Registry provides a wider, national perspective, but lacks important granular data to help account for all potential confounding variables.

In addition, a number of studies reported on stage-specific and time-specific outcomes. These stratified results are also reported within the tables in this document. Meta-analyses were conducted where appropriate, using effect measures if provided or absolute survival estimates based on empirically selected followup time windows (at 60 months or 48 months ± 12 months).

#### Risk of Bias

We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies. For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for NonRandomized Studies of Interventions (ACROBAT-NRSI).36 Two studies used identical patient cohorts and were considered as one study for risk of bias assessment.147,148 Among nonrandomized cohort studies, the overall risk of bias was moderate in 34 (58 percent) studies and serious in 25 (42 percent) studies (see Figure 10). The risk of bias ratings were largely driven by potential bias in selection of participants into the study (no study received a low risk of bias rating for this component) and by potential bias due to confounding (only 6 studies received low risk of bias ratings). The majority of studies were rated low on bias due to missing data, departure from intended interventions, measurement of outcomes, selection of reported result, and measurement of interventions. One randomized trial was also assessed for bias and rated in the middle category of unclear risk of bias due to unclear assessments of allocation concealment (varied by center), blinding of personnel, blinding of assessors, and blinding of outcome assessors.90 It was rated as low risk of bias for random sequence generation, incomplete outcome data, selective outcome reporting, and any other source of bias.

Figure 10 Risk of bias assessment for nonrandomized studies evaluating oncologic efficacy

Figure 10 shows the risk of bias assessment for nonrandomized studies evaluating oncologic efficacy.

##### Cancer-Specific Survival

Cancer-specific survival is defined as the proportion of patients surviving without death due to cancer in the absence of other causes of death.38 Individuals who die of other causes or are alive at the end of followup are censored at that time. The product limit estimator, or Kaplan-Meier method, was the preferred method employed in many of the larger studies to calculate cancer-specific survival. Smaller studies often only reported the absolute proportion of patients who survived without death due to cancer at median followup. These methods may generally overestimate cancer-specific survival but were consistently employed and defined in the available literature. Cancer-specific survival (as defined above) is the predominant oncologic outcome reported in the literature surrounding this topic. Other measures of oncologic outcome, specifically cancer-free survival (the proportion of patients free of cancer or alive), are inconsistently reported in the literature and therefore not included in this systematic review.

The summary statistics for the cancer-specific survival rates for the reviewed studies are detailed in Table 22.

Table 22 Number of studies and patients for cancer-specific survival comparisons between management strategies (41 studies in total)

Comparisons of Cancer-Specific Survival | Partial Nephrectomy | | Ablative Therapies | | Active Surveillance
| Studies | Patients | Studies | (Patients) | Studies | (Patients)
Radical Nephrectomy | 37 | 77,671 | 2 | 10,803 | 1 | 251
Partial Nephrectomy | X | X | 9 | 14,625 | 0 | 0
Ablative Therapies | X | X | X | X | 0 | 0

###### Radical Nephrectomy Versus Partial Nephrectomy

Thirty-seven studies assessed cancer-specific survival for radical nephrectomy versus partial nephrectomy.83,90,92,97-117,139-150,152 One RCT compared cancer-specific survival between partial nephrectomy and radical nephrectomy90 for tumors that were smaller than or equal to 5 cm and found no statistically significant differences, with a hazard ratio of 2.06 (95% CI, 0.62 to 6.18), after a relatively long median followup of 111.6 months.

Institutional cohorts generally showed comparable cancer-specific survival when comparing radical nephrectomy with partial nephrectomy. One study, primarily assessing the impact of intra-operative ischemia in partial nephrectomy, reported on a statistically significant cancer-specific survival advantage for partial nephrectomy over radical nephrectomy of 98.7–99.1 percent (cancer-specific survival reported separately for limited, unknown, and extended ischemia) versus 93.8 percent, respectively, at 5 years.105

Eleven SEER studies comprised the majority of patients for comparing partial nephrectomy and radical nephrectomy.141-150,152 Results were mixed among four studies of T1a tumors, with two studies showing a statistically significant cancer-specific survival benefit for partial nephrectomy and two studies demonstrating no difference.145,147,150,152 Three studies of T1b tumors showed no cancer-specific survival difference between partial nephrectomy and radical nephrectomy.141,143,146

The cancer-specific survival estimates from all studies were generally greater than 90-95 percent (followup ranged from 22 to 120 months), and showed a similar decrease in cancer-specific survival with increasing tumor size for both radical nephrectomy and partial nephrectomy (see Table 23a). For instance, cancer-specific survival for patients undergoing radical and partial nephrectomy with T1a tumors was 97 and 98.8 percent, and 91 and 90 percent for T1b tumors respectively (Table 23b). Only one study specifically compared radical nephrectomy with partial nephrectomy for T2 tumors, and this study showed no statistically significant difference in cancer-specific survival (82.5 percent versus 86.7 percent, respectively, at 5 years; p = 0.41).103 Lack of granularity among studies prevented evaluation of sub-staging in comparisons of other modalities.

Table 23a Cancer-specific survival for studies comparing radical nephrectomy versus partial nephrectomy

| No. Studies | Radical Nephrectomy | | | | | | Partial Nephrectomy
| No. Studies | No. Patients | Median F/U, months | Range of F/U, months | Median Survival % | Range of Survival | IQR of Survival | No. Patients | Median F/U | Range | Median Survival % | Range | IQR
CSS | 37 | 57171 | 60 | 22-120 | 95.5 | 66.8-100 | 91-97.5 | 20500 | 60 | 22-120 | 97.8 | 80.6-100 | 94.4-99.3
SEER | 11 | 48908 | 60 | 24-120 | 95.7 | 89.6-98.3 | 93.5-97.5 | 13814 | 60 | 24-120 | 98.1 | 91.4-100 | 96.7-98.6
Non-SEER | 26 | 8263 | 60 | 22-120 | 95 | 66.8-100 | 90.7-97.4 | 6686 | 60 | 22-120 | 97.7 | 80.6-100 | 94.4-99.8
T1a | 11 PN, 10 RN | 16710 | 60 | 25-120 | 97 | 90.4-100 | 95.7-98.3 | 7558 | 60 | 31-120 | 98.8 | 94.9-100 | 98.9-100
T1b | 8 | 15176 | 60 | 41-120 | 91 | 66.8-95.3 | 69.6-94.3 | 2496 | 58.8 | 31.3-120 | 90 | 80.6-99 | 80.8-93.8
T2 | 1 | 122 | 60 | NA | 82.5 | NA | NA | 80 | 60 | NA | 86.7 | NA | NA
5-year Survival | 11 | 15903 | 60 | NA | 94.8 | 82.5-98.4 | 93.5-97.5 | 6965 | 60 | NA | 97.2 | 86.7-99.6 | 93.8-98.9
10-year Survival | 6 | 9549 | 120 | NA | 89.6 | 69.6-98.3 | 87-95 | 3481 | 120 | NA | 93.9 | 80.6-100 | 90-94.9

Table 23b Cancer-specific survival for studies comparing partial nephrectomy versus thermal ablation

| No. Studies | Partial Nephrectomy | | | | | | Thermal Ablation
| No. Studies | No. Patients | Median F/U | Range | Median Survival | Range | IQR | No. Patients | Median F/U | Range | Median Survival | Range | IQR
CSS | 9 | 12464 | 60 | 24-60 | 100 | 96.6-100 | 99.3-100 | 2161 | 46.8 | 24-60 | 95.4 | 83.9-100 | 92-98
SEER | 2 | 11962 | 42 | 24-60 | 98.8 | 98.2-99.3 | 98.2-99.3 | 1654 | 42 | 24-60 | 96.2 | 94.4-98 | 94.4-98
Non-SEER | 7 | 502 | 60 | 24-60 | 100 | 96.6-100 | 100-100 | 507 | 46.8 | 24-60 | 94.5 | 83.9-100 | 90.3-98.6
< 5 year Survival | 3 | 4557 | 28.8 | 24-47 | 100 | 99.3-100 | 99.7-100 | 724 | 24 | 24-33.6 | 98 | 83.9-100 | 88.5-100
5-year Survival | 5 | 7907 | 60 | NA | 100 | 96.6-100 | 98.2-100 | 1437 | 60 | NA | 94.4 | 92-97.2 | 92.6-96.4

CSS = cancer-specific survival; F/U = followup; IQR = interquartile range; NA = not available; PN = partial nephrectomy; RN = radical nephrectomy

Meta-analyses were conducted for studies providing effect measures. Results were similar among both SEER studies (See Figure 11) and non-SEER studies (See Figure 12) with no statistically significant difference in cancer-specific survival for radical versus partial nephrectomy. The strength of evidence was moderate.

Figure 11 Meta-analysis of cancer-specific survival for radical nephrectomy versus partial nephrectomy among SEER studies providing effect measures

CI = confidence interval; ES = effect size; HR = hazard ratio; SEER = Surveillance, Epidemiology, and End Results

Note: Weighting is based on the inverse of the variance of each study estimate.

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 11 is a meta-analysis of cancer-specific survival for radical nephrectomy versus partial nephrectomy among SEER studies providing effect measures.

Figure 12 Meta-analysis of cancer-specific survival for radical nephrectomy versus partial nephrectomy among non-SEER studies providing effect measures

CI = confidence interval; ES = effect size; HR = hazard ratio; SEER = Surveillance, Epidemiology, and End Results

Note: Weighting is based on the inverse of the variance of each study estimate.

The width of the horizontal lines represents the 95 percent confidence intervals for each study.

The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 12 is a meta-analysis of cancer-specific survival for radical nephrectomy versus partial nephrectomy among non-SEER studies providing effect measures.

###### Radical Nephrectomy Versus Thermal Ablation

Two studies assessed cancer-specific survival for radical nephrectomy versus thermal ablation.134,142 A SEER study comparing radical nephrectomy with thermal ablation showed similar cancer-specific survival rates (p = 0.7).142 A second small institutional study, which had shown inferior overall survival for thermal ablation compared with radical nephrectomy, demonstrated similar cancer-specific survival rates (94 percent versus 100 percent, respectively) at 5 years.134 The strength of evidence was moderate.

###### Radical Nephrectomy Versus Active Surveillance

One study assessed cancer-specific survival for radical nephrectomy versus active surveillance.135 This single institutional study included older patients (age ≥75 years) and showed similar cancer-specific survival rates (p = 0.33) even though the radical nephrectomy tumors had greater oncologic potential.135 The strength of evidence was low.

###### Partial Nephrectomy Versus Thermal Ablation

Nine studies assessed cancer-specific survival for partial nephrectomy versus thermal ablation.122-125,136-138,142,151 Two of these studies were based on the SEER database.142,151 One, with shorter followup, demonstrated comparable 2-year cancer-specific survival for partial nephrectomy versus thermal ablation (99.3 percent vs. 98 percent; adjusted p = 0.2).142 However, the second study demonstrated 5-year cancer-specific survival for partial nephrectomy versus thermal ablation of 98.2 percent and 94.4 percent, respectively, which was statistically significant after adjustment, with a hazard ratio equal to 1.9 (95% CI, 1.1 to 3.3) for thermal ablation versus partial nephrectomy.151

An important note is that histologic diagnosis with biopsy for thermal ablation patients is not uniformly practiced. Thus, some enrichment with benign lesions is expected in the thermal ablation cohorts from SEER, which would be a bias favoring thermal ablation for oncologic outcomes in general.

Five institutional studies demonstrated similar cancer-specific survival for partial nephrectomy versus thermal ablation.122-125,136 In contrast to the SEER studies, institutional cohorts reported histology based on biopsy at the time of thermal ablation. Notably, among solitary kidney studies, an institutional report noted no difference in cancer-specific survival for partial nephrectomy versus thermal ablation at 2 years (p = 0.25) 138 but reported worse cancer-specific survival for thermal ablation in an update to the study for cancer-specific survival at 5 years (p<0.05) 137.

A meta-analysis of absolute cancer-specific survival for partial nephrectomy versus thermal ablation was conducted for studies reporting 5-year survival with significant benefit noted for partial nephrectomy among the 4 studies 122,125,136,151(Appendix F). The effect was driven by Whitson et al.151, which is a study rated to be at serious risk of bias due to patient selection. The strength of evidence was low.

###### Partial Nephrectomy Versus Active Surveillance

No study reported cancer-specific survival for radical nephrectomy versus active surveillance.

###### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

Three studies assessed cancer-specific survival for nonsurgical management versus radical nephrectomy versus partial nephrectomy.147-149

Radical nephrectomy and partial nephrectomy both demonstrated statistically significant improved cancer-specific survival compared with nonsurgical management in two SEER-Medicare studies of patients with T1a tumors.147,149 A separate study of the same population found comparable cancer-specific survival between the management strategies among patients at high cardiovascular risk.148

##### Metastasis-Free Survival Outcome

A few of the comparative studies reported on metastasis-free survival, as shown in Table 24.

Table 24 Number of studies and patients for metastasis-free survival comparisons between management strategies (20 studies in total)

Comparisons of Metastasis-Free Survival | Partial Nephrectomy | | Ablative Therapies | | Active Surveillance
Comparisons of Metastasis-Free Survival | Studies | (Patients) | Studies | (Patients) | Studies | (Patients)
Radical nephrectomy | 13 | 2,513 | 2 | 217 | 1 | 251
Partial nephrectomy | X | X | 8 | 2,462 | 0 | 0
Ablative therapies | X | X | X | X | 0 | 0

###### Radical Nephrectomy Versus Partial Nephrectomy

Thirteen studies assessed metastasis-free survival for radical nephrectomy versus partial nephrectomy.82,83,90,96,101,102,104,106,107,114,115,118,119

The single RCT comparing partial nephrectomy and radical nephrectomy for tumors smaller than or equal to 5 cm90 showed low rates of metastasis for both interventions with metastasis-free survival of 97.4 percent versus 96.3 percent, respectively, at a relatively long median followup of 111.6 months. The results were similar across institutional cohorts. Few studies provided any direct measures of comparison. One study, of Korean patients who were 70 years of age or older, showed similar rates of metastasis-free survival for radical nephrectomy versus partial nephrectomy (93.9 percent versus 98.1 percent; p = 0.40) at a mean followup of 59.7 months.104 We conducted a meta-analysis for studies reporting absolute metastasis-free survival with 48 months ± 12 months of followup, which showed no difference in metastasis-free survival for radical versus partial nephrectomy (Appendix F). The strength of evidence was low.

###### Radical Nephrectomy Versus Thermal Ablation

Two studies, both institutional analyses, assessed metastasis-free survival for radical nephrectomy versus thermal ablation.96,134 Two patients in the radical nephrectomy group of the larger study (71 patients) developed metastasis shortly after surgery, possibly indicating preexisting metastatic disease; none of the patients undergoing radiofrequency ablation (86 patients) developed metastasis after the procedure (metastasis-free survival 97.2 percent versus 100 percent, respectively).96 The rate of metastasis-free survival was also similar in the second, smaller study, with 92.3 percent versus 90.5 percent for radical nephrectomy (39 patients) compared with radiofrequency ablation (21 patients), respectively.134 The strength of evidence was low.

###### Radical Nephrectomy Versus Active Surveillance

One study assessed metastasis-free survival for radical nephrectomy versus active surveillance.135 The single institutional study of older patients (age ≥ 75 years) showed similar metastasis-free survival for radical nephrectomy versus active surveillance (94.5 percent versus 94.3 percent) at median followup of 52.8 and 44.4 months, respectively.135 The strength of evidence was low.

###### Partial Nephrectomy Versus Thermal Ablation

Eight studies assessed metastasis-free survival for partial nephrectomy versus thermal ablation.96,123,126-129,136,137 The rates of metastasis-free survival in studies comparing partial nephrectomy and thermal ablation were generally high (see Table 6). Three studies observed no development of distant metastatic disease. 96,123,128 Two studies demonstrated similar metastasis-free survival; one compared partial nephrectomy with a mixed thermal ablation group for patients with solitary kidneys (p = 0.33),126 and the other compared partial nephrectomy with a radiofrequency ablation group (p = 0.35).136

One study showed similar metastasis-free survival for partial nephrectomy compared with percutaneous cryoablation for both T1a (p = 0.31) and T1b (p = 0.45) disease; however, the same study found radiofrequency ablation inferior in terms of metastasis-free survival to both partial nephrectomy and cryoablation for T1a tumors.127 One study suggested partial nephrectomy led to better metastasis-free survival compared with laparoscopic cryoablation (p = 0.002) but mean followup dramatically differed between the partial nephrectomy (4.8 months) and thermal ablation (44.5 months) groups.129 A solitary kidney study reported 4 (13.3 percent) cases of metastasis in their cryoablation cohort compared to 1 (2.1 percent) in the partial nephrectomy cohort, which had borderline statistical significance (p = 0.05).137

We conducted a meta-analysis for studies reporting absolute metastasis-free survival with 48 months ± 12 months of followup, which showed no difference in metastasis-free survival for partial nephrectomy versus thermal ablation (Appendix F). The strength of evidence was moderate.

###### Partial Nephrectomy Versus Active Surveillance

No study reported metastasis-free survival for radical nephrectomy versus active surveillance.

##### Local Recurrence-Free Survival Outcome

Local recurrence-free survival is defined as any persistent or recurrent disease present in the treated region of the kidney or associated renal fossa after a single, curative-intent initial treatment. The recurrence can include persistent enhancement of any treated mass, a visually enlarging neoplasm, new nodularity, failure of regression in size of the treated lesion(s), or new satellite or port site lesions. Local recurrence or persistence after thermal ablation is determined after a single, curative-intent initial treatment (i.e., primary efficacy), but some studies also report a measure of secondary efficacy, which is determined after multiple ablations. These results are addressed below (Table 25).

Table 25 Number of studies and patients for local recurrence-free survival comparisons between management strategies (36 studies in total)

Comparisons of Local Recurrence-Free Survival | Partial Nephrectomy | | Ablative Therapies | | Active Surveillance
| Studies | (Patients) | Studies | (Patients) | Studies | (Patients)
Radical nephrectomy | 21 | 10,090 | 2 | 217 | 1 | 251
Partial nephrectomy | X | X | 14 | 3,916 | 0 | 0
Ablative therapies | X | X | X | X | 0 | 0

###### Radical Nephrectomy Versus Partial Nephrectomy

Twenty-one studies assessed local recurrence-free survival for radical nephrectomy versus partial nephrectomy.82,90,96-98,101,102,106,107,110-112,114-116,118-121,139,140 The RCT comparing partial nephrectomy and radical nephrectomy for tumors smaller than or equal to 5 cm90 did not provide a statistical test but reported a somewhat higher rate of local recurrence for partial nephrectomy (6 patients) compared with radical nephrectomy (1 patient) at a median followup of 111.6 months. No institutional cohort study found a statistically significant difference in local recurrence rates between radical nephrectomy and partial nephrectomy with comparable estimates and followup time. We conducted a meta-analysis for studies reporting absolute local recurrence-free survival with 48 months ± 12 months of followup, which showed no difference in local recurrence-free survival for radical versus partial nephrectomy (Appendix F). The strength of evidence was moderate (Table 27).

Table 27 Strength of evidence domains for oncologic outcomes

Comparison | Key Outcomes | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Partial Nephrectomy Versus Active Surveillance | Cancer-specific survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Active Surveillance | Metastasis-free survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Active Surveillance | Local recurrence-free survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Thermal Ablation | Cancer-specific survival | 9 (14,625) | High | Direct | Inconsistent | Precise | Undetected | Low Cancer-specific survival was comparable between partial nephrectomy and thermal ablation. One study, at high risk of bias, suggested partial nephrectomy may be associated with better long-term cancer-specific survival.
Partial Nephrectomy Versus Thermal Ablation | Metastasis-free survival | 8 (2,462) | Medium | Direct | Consistent | Precise | Undetected | Moderate Metastasis-free survival was comparable between partial nephrectomy and thermal ablation.
Partial Nephrectomy Versus Thermal Ablation | Local recurrence-free survival | 14 (3,916) | Medium | Direct | Consistent | Precise | Undetected | Moderate Partial nephrectomy was associated with better local recurrence-free survival compared to thermal ablation across studies. Allowing for multiple retreatments led to a more comparable secondary efficacy rate for thermal ablation.
Radical Nephrectomy Versus Active Surveillance | Cancer-specific survival | 1 (251) | Medium | Direct | Unknown | Imprecise | Undetected | Low A single study demonstrated a similar cancer-specific survival despite greater oncologic potential of tumors undergoing radical nephrectomy.
Radical Nephrectomy Versus Active Surveillance | Metastasis-free survival | 1 (251) | Medium | Direct | Unknown | Imprecise | Undetected | Low A single study showed similar metastasis-free survival for radical nephrectomy vs. active surveillance.
Radical Nephrectomy Versus Active Surveillance | Local recurrence-free survival | 1 (251) | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient No local recurrences were reported in this single study.
Radical Nephrectomy Versus Partial Nephrectomy | Cancer-specific survival | 37 (77,671) RCT: 1 Institutional: 25 SEER: 11 | Medium | Direct | Consistent | Precise | Undetected | Moderate Cancer-specific survival was comparable for radical nephrectomy and partial nephrectomy across the SEER and institutional studies. The one RCT reported few cancer deaths.
Radical Nephrectomy Versus Partial Nephrectomy | Metastasis-free survival | 13 (2,513) | Medium | Direct | Consistent | Imprecise | Undetected | Low Metastasis-free survival for radical nephrectomy compared to partial nephrectomy was similar across all 13 studies.
Radical Nephrectomy Versus Partial Nephrectomy | Local recurrence-free survival | 21 (10,090) | Medium | Direct | Consistent | Precise | Undetected | Moderate Local-recurrence free survival for radical nephrectomy compared to partial nephrectomy was similar across studies. No study reported a statistically significant difference.
Radical Nephrectomy Versus Thermal Ablation | Cancer-specific survival | 2 (10,803) | Medium | Direct | Consistent | Precise | Undetected | Moderate Both studies reported comparable cancer-specific survival for radical nephrectomy compared to thermal ablation.
Radical Nephrectomy Versus Thermal Ablation | Metastasis-free survival | 2 (217) | Medium | Direct | Consistent | Imprecise | Undetected | Low Both studies reported comparable metastasis-free survival for radical nephrectomy compared to thermal ablation but included few patients and events.
Radical Nephrectomy Versus Thermal Ablation | Local recurrence-free survival | 2 (217) | Medium | Direct | Consistent | Imprecise | Undetected | Low Both studies reported better local recurrence-free survival for RN compared to thermal ablation but included small sample sizes.
Thermal Ablation Versus Active Surveillance | Cancer-specific survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Thermal Ablation Versus Active Surveillance | Metastasis-free survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Thermal Ablation Versus Active Surveillance | Local recurrence-free survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies

SEER = Surveillance, Epidemiology, and End Results

###### Radical Nephrectomy Versus Thermal Ablation

Two instutional studies assessed local recurrence-free survival for radical nephrectomy versus thermal ablation.96,134 Using the definition of local recurrence as occurring after a single, curative-intent initial treatment, both studies reported worse local recurrence-free survival for thermal ablation as compared with radical nephrectomy. The larger study reported local recurrence-free survival of 100 percent versus 93.0 percent for radical nephrectomy versus thermal ablation, respectively.96 Three of the six local recurrences among the thermal ablation group went on to be re-ablated. The smaller study reported a local recurrence-free survival of 97.4 percent for radical nephrectomy versus 81.0 percent for thermal ablation.134 All four tumors with residual enhancement in the thermal ablation group (21 patients) were re-ablated after 1 week, for a secondary efficacy of 100 percent. The strength of evidence was low (Table 27).

###### Radical Nephrectomy Versus Active Surveillance

One study assessed local recurrence-free survival for radical nephrectomy versus active surveillance.135 The single institutional study of older patients (age ≥ 75 years) showed no local progression of disease in the cohort.135

###### Partial Nephrectomy Versus Thermal Ablation

Fourteen studies assessed local recurrence-free survival for partial nephrectomy versus thermal ablation.96,123,124,126-133,136-138 Local recurrence-free survival rates were generally higher in studies for partial nephrectomy as compared with thermal ablation (median 98.9 percent (interquartile ratio 94.6 percent to 100 percent) versus 93.0 percent (IQR 89.9 percent to 96.0 percent) (Table 6). Although followup differed between groups (4.8 versus 44.5 months, respectively), a large series from the Cleveland Clinic reported no local recurrences in the partial nephrectomy group (210 patients) and 25 local recurrences (out of 226 patients) in the laparoscopic cryoablation cohort (local recurrence-free survival 100 percent versus 88.9 percent; p < 0.01).129 Of these recurrences, nine were monitored with surveillance while eight underwent repeat cryoablation, four underwent radiofrequency ablation, and four underwent radical nephrectomy. A different study from the same institution on solitary kidneys also showed worse 5-year local recurrence-free survival for cryoablation compared to partial nephrectomy (p = 0.02).138

Similarly, a cohort from Austria showed statistically significant improved 3-year local recurrence-free survival after partial nephrectomy compared with laparoscopic cryoablation (100 percent versus 83 percent; p = 0.015) with no technical failures in the cryoablation group and all four local recurrences occurring after prior imaging had shown no evidence of persistent enhancement. One study showed similar 3-year local recurrence-free survival for partial nephrectomy and radiofrequency ablation (95.8 percent versus 93.4 percent, respectively; p = 0.67).124

Although four studies126,128,132,136 reported both local recurrence-free survival as well as secondary efficacy, three127,130,131 only noted secondary efficacy estimates for thermal ablation. Retreatment can lead to secondary efficacy rates for thermal ablation that are more comparable with local recurrence-free survival for partial nephrectomy. Two retreatments with cryoablation led to a secondary efficacy rate of 100 percent for thermal ablation compared with local recurrence-free survival of 100 percent for partial nephrectomy in one study.132 A large institutional cohort from the Mayo Clinic (1771 patients) showed comparable estimates for partial nephrectomy compared with radiofrequency ablation and cryoablation for T1a tumors at 3 years (p = 0.49) as well as for partial nephrectomy compared with cryoablation for T1b tumors at 3 years (p = 0.81).127

The study with the longest reported followup reported similar secondary efficacy at 5 years (p = 0.96).136 Another cohort showed secondary efficacy for thermal ablation that was still slightly inferior to local recurrence-free survival after partial nephrectomy for patients with solitary kidneys (92.9 percent versus 97 percent; p = 0.04) (Tables 26a and 26b).126

Table 26a Metastasis-free survival and local recurrence-free survival for studies comparing radical nephrectomy versus partial nephrectomy

| No. Studies | Radical Nephrectomy | | | | | | Partial Nephrectomy
| No. Studies | No. Patients | Median F/U, Months | Range of F/U, Months | Median Survival, % | Range of Survival, % | IQR of Survival, % | No. Patients | Median F/U | Range | Median Survival, % | Range of Survival, % | IQR of Survival, %
Metastasis-free survival | 13 | 1296 | 50.4 | 18.6-111.6 | 97.2 | 86-100 | 93.9-100 | 1217 | 44 | 15-111.6 | 98 | 93-100 | 97.1-100
Local recurrence free survival | 21 | 5870 | 51.3 | 12-111.6 | 99.6 | 93-100 | 98.5-100 | 4220 | 46.1 | 12-111.6 | 98.8 | 92.7-100 | 96.4-100

Table 26b Metastasis-free survival and local recurrence-free survival for studies comparing partial nephrectomy versus thermal ablation

| No. Studies | Partial Nephrectomy | | | | | | Thermal Ablation
| No. Studies | No. Patients | Median F/U | Range | Median Survival | Range | IQR | No. Patients | Median F/U | Range | Median Survival | Range | IQR
Metastasis-free survival | 8 | 1686 | 39.3 | 4.8-60 | 99 | 91.8-100 | 97.9-100 | 776 | 42.3 | 31-60 | 97.6 | 86.7-100 | 93-100
Local recurrence free survival^a^ | 12 PN, 11 TA | 2374 | 36 | 4.8-60 | 99.4 | 94.6-100 | 97-100 | 795 | 36 | 14-60 | 89.3 | 55.2-97.6 | 84.7-94.7
Secondary Efficacy | 7 TA | - | - | - | - | - | - | 747 | 31.3 | 24.6-60 | 97.4 | 91.7-100 | 97-98

MFS = metastasis-free survival; LRFS = local recurrence-free survival; PN = partial nephrectomy; RN = radical nephrectomy; TA = thermal ablation

a After single, curative-intent initial treatment.

We conducted a meta-analysis for studies reporting absolute local recurrence-free survival with 48 months ± 12 months of followup, which showed a borderline significant result in improved local recurrence-free survival for partial nephrectomy as compared to thermal ablation (see Figure 13). A meta-analysis looking at secondary efficacy of thermal ablation showed more similar results when compared to local recurrence-free survival for partial nephrectomy (Figure 14). The strength of evidence was moderate (Table 27).

Figure 13 Meta-analysis of local recurrence rates for partial nephrectomy versus thermal ablation among studies with followup of 48 months ± 12 months

CI = confidence interval; N = number; PN = partial nephrectomy; RN = radical nephrectomy; RR = risk ratio for local recurrence; TA = thermal ablation

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 13 is a meta-analysis of local recurrence rates for partial nephrectomy versus thermal ablation among studies with follow-up of 48 months ± 12 months.

Figure 14 Meta-analysis of local recurrence-free survival for partial nephrectomy versus secondary efficacy of thermal ablation among studies with followup of 48 months ± 12 months

N = number; RN = radical nephrectomy; PN = partial nephrectomy, TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 14 is a meta-analysis of local recurrence-free survival for partial nephrectomy versus secondary efficacy of thermal ablation among studies with follow-up of 48 months ± 12 months.

###### Partial Nephrectomy Versus Active Surveillance

No study reported local recurrence-free survival for partial nephrectomy versus active surveillance.

##### Overall Survival

A total of 48 comparative studies (reported in 49 articles) addressed overall survival, of which one was an RCT90 and 9 were studies (reported in 10 articles) of the SEER dataset (see Table 28).141,142,144,145,147,148,150,153-155

Table 28 Number of studies and patients for overall survival comparisons between management strategies (4,242 studies in total)

Comparisons of Overall Survival | Partial Nephrectomy | | Ablative Therapies | | Active Surveillance
Comparisons of Overall Survival | Studies | (Patients) | Studies | (Patients) | Studies | (Patients)
Radical Nephrectomy | 36 | 72,308 | 3 | 10,908 | 1 | 251
Partial Nephrectomy | X | X | 13 | 8,451 | 0 | 0
Ablative Therapies | X | X | X | X | 0 | 0

#### Risk of Bias

We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies. 35 For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 Two studies used identical patient cohorts and are considered as one study for risk of bias assessment.147,148 Among nonrandomized cohort studies, overall risk of bias was moderate in 30 studies and serious in 17 studies (Figure 15). The risk of bias ratings were largely driven by potential bias in selection of participants into the study (no study received a low risk of bias rating for this component) and by potential bias due to confounding (5 studies received low risk of bias ratings). The majority of studies were rated low on bias due to missing data, departure from intended interventions, selection of reported result, measurement of outcomes, and measurement of interventions.

Figure 15 Risk of bias assessment for nonrandomized studies evaluating overall survival

Figure 15 shows the risk of bias assessment for nonrandomized studies evaluating overall survival.

One randomized trial was also assessed for bias and rated in the middle category of unclear risk of bias due to unclear assessments of allocation concealment (varied by center), blinding of personnel, blinding of assessors, and blinding of outcome assessors.90 It was rated as low risk of bias for random sequence generation, incomplete outcome data, selective outcome reporting, and any other source of bias.

##### Radical Nephrectomy Versus Partial Nephrectomy

Thirty-six studies evaluated overall survival for radical nephrectomy versus partial nephrectomy.83,90,92,94,100-110,113,114,117,118,139-142,144,145,147,148,150,153-160

One RCT compared overall survival for tumors smaller than or equal to 5 cm between partial nephrectomy and radical nephrectomy, and demonstrated a statistically significant difference in an “intent to treat” analysis, with a hazards ratio equal to 1.50 (95% CI, 1.03 to 2.16), in favor of radical nephrectomy.90 A separate analysis of RCC patients showed no difference in overall survival between the partial nephrectomy and radical nephrectomy groups in this study.

Institutional cohorts generally showed minimal difference in overall survival between radical nephrectomy and partial nephrectomy, with the majority showing no statistically significant differences.92,100,101,103,104,106,109,110,113,114,140,156-158 Three retrospective studies commented on a statistically significant overall survival advantage for partial nephrectomy over radical nephrectomy, but acknowledged differences in baseline characteristics (i.e., selection bias) that may have contributed.105,107,108,159 One study found an overall survival advantage for partial nephrectomy compared to radical nephrectomy among younger Korean patients (<65 years of age; p=0.015) but not older patients (p=0.698).139

Ten studies derived groups from SEER databases and comprised the majority of patients.141,142,144,145,147,148,150,153-155 In these SEER studies, partial nephrectomy was found to be associated with a statistically significant overall survival benefit compared with radical nephrectomy for T1a tumors.144,145,147,148,150,153-155 In a SEER analysis of T1b tumors, no significant difference in overall survival was found.141

Fifteen studies reported survival probabilities out to as far as 5 years,92,103-107,139-141,145,147,156, 158-160 and seven reported survival probabilities out to 10 years90,101,109,110,114,144,155 for radical nephrectomy versus partial nephrectomy, with median estimates of 86.4 percent and 93.9 percent at 5 years, and 71.5 percent and 73.8 percent at 10 years, respectively.

Meta-analyses were conducted for studies providing effect measures. Results were different for SEER studies (Figure 16) and non-SEER studies (Figure 17), with the former showing a significant overall survival benefit for patients receiving partial nephrectomy while the latter showed no statistically significant difference. The strength of evidence was low.

Figure 16 Meta-analysis of overall survival for radical nephrectomy versus partial nephrectomy among SEER studies providing effect measures

CI=Confidence Interval; ES=Effect Size; HR=Hazard Ratio; SEER=Surveillance, Epidemiology, and End Results Weighting is based on the inverse of the variance of each study estimate.

The width of the horizontal lines represents the 95 percent confidence intervals for each study.

The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 16 is a meta-analysis of overall survival for radical nephrectomy versus partial nephrectomy among SEER studies providing effect measures.

Figure 17 Meta-analysis of overall survival for radical nephrectomy versus partial nephrectomy among non-SEER studies providing effect measures

CI = confidence interval; ES = effect size; HR = hazard ratio; SEER = Surveillance, Epidemiology, and End Results

Note: Weighting is based on the inverse of the variance of each study estimate.

The width of the horizontal lines represents the 95 percent confidence intervals for each study.

The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 17 is a meta-analysis of overall survival for radical nephrectomy versus partial nephrectomy among non-SEER studies providing effect measures.

##### Radical Nephrectomy Versus Thermal Ablation

Three studies evaluated overall survival for radical nephrectomy versus thermal ablation.134,142,160 One was a SEER study consisting of a combined radiofrequency ablation and cryoablation cohort compared with radical nephrectomy (overall survival 92.5 percent versus 94.6 percent, respectively, at 2 years; p = 0.73).142 The institutional studies were smaller cohorts (60 patients and 105 patients) comparing radiofrequency ablation with radical nephrectomy.134 The majority of radiofrequency ablation patients (86 percent) in one study were not surgical candidates,134 and patients in the other study were generally older and had multiple comorbidities,160 which led to lower overall survival compared with radical nephrectomy. The evidence was insufficient.

##### Radical Nephrectomy Versus Active Surveillance

One study evaluated overall survival for radical nephrectomy versus active surveillance.135 The single institutional study included older patients (age ≥75 years) and compared overall survival for radical nephrectomy with active surveillance, showing similar overall survival with an adjusted hazard ratio equal to 0.75 (95% CI, 0.45 to 1.26).135 The multivariable analysis adjusted for the greater comorbidity burden and age among active surveillance patients. The strength of evidence was low.

##### Partial Nephrectomy Versus Thermal Ablation

Thirteen studies evaluated overall survival for partial nephrectomy versus thermal ablation.122,125-127,130-133,136-138,142,160

All studies demonstrated lower overall survival probabilities for thermal ablation compared with partial nephrectomy (Table 29), with the acknowledgment that thermal ablation was often chosen based on presence of comorbidity and surgical risk. However, the difference was not statistically significant in a subset of studies providing comparative measures.122,126,131,136,142

Table 29 Overall survival for studies comparing radical nephrectomy versus partial nephrectomy and partial nephrectomy versus thermal ablation

Comparison | | No. Studies | Radical Nephrectomy | | | | | | Partial Nephrectomy
Comparison | | No. Studies | No. Patients | Median F/U | Range | Median Survival | Range | IQR | No. Patients | Median F/U | Range | Median Survival | Range | IQR
Radical Nephrectomy Versus Partial Nephrectomy | Overall Survival | 36 | 50110 | 60 | 12-120 | 86.3 | 53.7-100 | 76-91.9 | 22198 | 60 | 12-120 | 92.3 | 55.2-100 | 82.7-96.7
Radical Nephrectomy Versus Partial Nephrectomy | SEER | 10 | 44452 | 60 | 24-120 | 80.6 | 58.5-94.6 | 68.1-88.7 | 16120 | 60 | 24-120 | 82.8 | 71.3-97.6 | 74.4-94.9
Radical Nephrectomy Versus Partial Nephrectomy | Non-SEER | 26 | 5658 | 60 | 12-120 | 88.7 | 53.7-100 | 78-94 | 6078 | 60 | 12-120 | 93.8 | 55.2-100 | 85-97.7
Radical Nephrectomy Versus Partial Nephrectomy | 5-Year Survival | 15 | 19863 | 60 | NA | 86.4 | 65-94 | 79-93.0 | 71445 | 60 | NA | 93.9 | 74-100 | 85-99.7
Radical Nephrectomy Versus Partial Nephrectomy | 10-Year Survival | 7 | 7184 | 120 | NA | 71.5 | 53.7-89.7 | 67.2-81.1 | 3501 | 120 | NA | 73.8 | 55.2-94 | 67.7-87.6
| | | Partial Nephrectomy | | | | | | Thermal Ablation
Partial Nephrectomy Versus Thermal Ablation | Overall Survival | 13 | 6620 | 30 | 5.8-60 | 97.8 | 91.2-100 | 93-100 | 1831 | 33.7 | 14-60 | 88 | 74-98.7 | 83.0-95.3
Partial Nephrectomy Versus Thermal Ablation | SEER | 1 | 4402 | 24 | NA | 97.6 | NA | NA | 578 | 24 | NA | 92.5 | NA | NA
Partial Nephrectomy Versus Thermal Ablation | Non-SEER | 12 | 2218 | 36 | 5.8-60 | 98 | 91.2-100 | 93-100 | 1253 | 36 | 14-60 | 88 | 74-98.7 | 82-95.9
Partial Nephrectomy Versus Thermal Ablation | <3-Years F/U | 7 | 4880 | 19.2 | 5.8-24 | 99.5 | 97.6-100 | 98-100 | 999 | 24.3 | 14-31.3 | 93.6 | 83.9-98.7 | 86.4-96.3
Partial Nephrectomy Versus Thermal Ablation | ≥3-Years F/U | 6 | 1740 | 60 | 36-60 | 95 | 91.7-100 | 93-100 | 832 | 60 | 36-60 | 83.8 | 74-97.2 | 76.1-88

F/U = followup, SEER=Surveillance, Epidemiology, and End Results

The largest institutional comparison showed no statistical difference in overall survival when comparing partial nephrectomy with radiofrequency ablation for T1a tumors after multivariable adjustment.127 A statistically significant overall survival advantage for partial nephrectomy over cryoablation persisted for both T1a and T1b tumors after adjustment.127

A meta-analysis of absolute overall survival for partial nephrectomy versus thermal ablation was conducted for studies reporting 5-year survival with significant benefit noted for partial nephrectomy in the 4 studies122,125,136,160(Appendix F). The strength of evidence was low.

##### Partial Nephrectomy Versus Active Surveillance

No study evaluated overall survival for partial nephrectomy versus active surveillance.

##### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

Two studies evaluated overall survival for nonsurgical management versus radical nephrectomy versus partial nephrectomy.147,148 Radical nephrectomy and partial nephrectomy both demonstrated statistically significant improved overall survival compared with nonsurgical management in a SEER-Medicare cohort of patients with T1a tumors.147

Table 30 presents the strength of evidence domains for overall survival.

Table 30 Strength of evidence domains for overall survival

Comparison | Key Outcomes | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Partial Nephrectomy Versus Active Surveillance | Overall Survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Thermal Ablation | Overall Survival | 13 (8,451) | High | Direct | Consistent | Precise | Undetected | Low All 13 studies demonstrated worse overall survival for thermal ablation compared to partial nephrectomy, likely due to age and comorbidity.
Radical Nephrectomy Versus Active Surveillance | Overall Survival | 1 (251) | Medium | Direct | Unknown | Imprecise | Undetected | Low Single study demonstrated comparable overall survival with radical nephrectomy and active surveillance with a wide confidence interval [hazard ratio 0.75 (95% CI, 0.45 to 1.26)].
Radical Nephrectomy Versus Partial Nephrectomy | Overall Survival | 36 (72,308) RCT: 1 Institutional: 25 SEER: 10 | Medium | Direct | Inconsistent | Imprecise | Undetected | Low Overall survival was similar for radical nephrectomy and partial nephrectomy, but studies were inconsistent. SEER analyses showed a survival advantage for partial nephrectomy while institutional cohorts and the 1 RCT did not demonstrate this.
Radical Nephrectomy Versus Thermal Ablation | Overall Survival | 3 (10,908) | High | Direct | Inconsistent | Imprecise | Undetected | Insufficient The results of the three studies were too inconsistent to support a conclusion, especially given the limitations of the studies.
Thermal Ablation Versus Active Surveillance | Overall Survival | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies

RCT = randomized controlled trial; SEER = Surveillance, Epidemiology, and End Results

#### Renal Functional Outcomes

Fifty-three studies (reported in 54 articles, total of 17,784 patients) addressed renal functional outcomes in comparative studies (Table 31). Seven studies reported renal functional outcomes for more than one management strategy.96,160-165 Only two studies reported comparative effectiveness that included active surveillance.135,165 The baseline kidney function reported in the studies is presented in Table 32. Studies reported both continuous and categorical renal functional outcomes, including evaluation of postoperative serum creatinine and estimated glomerular filtration rate, as well as the incidence and prevalence of chronic kidney disease and end stage renal disease. The median eGFR across studies was 73 (standard deviation 20) ml/min/1.73 m^2^ (Table 33).

Table 31 Number of studies reporting renal functional outcomes^a^ by management comparison

Comparison | Number of studies
Radical Nephrectomy versus Partial Nephrectomy | 38 studies83,89,90,93,94,96,98,101,104-08,113,114,118,119,121,139,156,158, 160-176
Radical Nephrectomy versus Thermal Ablation | 8 studies96,134,160-165
Partial Nephrectomy versus Thermal Ablation | 21 studies96,123,125,126,128,129,131-133,137,138,160-165,177-180
Radical Nephrectomy versus Active Surveillance | 2 studies135,165
Partial Nephrectomy versus Active Surveillance | 1 study165
Thermal Ablation versus Active Surveillance | 1 study165

a Renal functional outcomes included change in creatinine, change in estimated glomerular filtration rate, incidence of chronic kidney stages 3, 3b, and 4, and incidence of end stage renal disease.

Table 32 Renal function characteristics of patients in comparative studies of management of small renal masses

Author, Year | Radical Nephrectomy | | Partial Nephrectomy | | Thermal Ablation | | Active Surveillance
Author, Year | Number of Patients | Baseline eGFR Mean (SD) | Number of Patients | Baseline eGFR Mean (SD) | Number of Patients | Baseline eGFR Mean (SD) | Number of Patients | Baseline eGFR Mean (SD)
Antoniewicz,2012^171^ | 33 | 71 (18) | 18 | 74 (21) | - | - | - | -
Barbalias, 1999^98^ | 48 | 107 (6) | 41 | 105 (6) | - | - | - | -
Brewer, 2012^170^ | 108 | 70 (21) | 45 | 75 (26) | - | - | - | -
Chang, 2014^94^ | 339 | 80.1 (17.6) | 218 | 83.9 (15.1) | - | - | - | -
Chang, 2015^180^ | - | - | 29 | 86 (29) | 27 | 79 (29) | - | -
Chung, 2014^139^ | 622 | 80 (15) | 622 | 80 (15) | - | - | - | -
Cooper, 2015^164^ | 31 | 53 (13) | 9 | 57 (7) | 9 | 52 (12) | - | -
Danzig, 2015^165^ | 15 | 73 (18) | 65 | 90 (12) | 14 | 89 (13) | 68 | 82 (12)
Dash, 2006^175^ | 151 | NR^a^ | 45 | NR^a^ | - | - | - | -
Deklaj, 2010^162^ | 19 | 63 (16) | 28 | 63 (18) | 19 | 65 (26) | - | -
Deklaj, 2010^118^ | 52 | 101 (42) | 33 | 87 (39) | - | - | - | -
Desai, 2005^131^ b | - | - | 153 | NR* | 78 | NR* | - | -
Emara, 2014^132^ | - | - | 47 | NR* | 56 | NR* | - | -
Faddegon, 2013^177^ | - | - | 142 | 75 (23) | 205 | 81 (22) | - | -
Foyil, 2008^163^ b | 50 | 56 (25) | 98 | 67 (27) | 49 | 56 (28) | - | -
Gratzke, 2009^83^ | 73 | NR | 44 | NR | 0 | 0 | - | -
Guillotreau,2012^129^ b | - | - | 210 | 86 (36) | 226 | 66 (29) | - | -
Haramis, 2012^133^ | - | - | 92 | NR^a^ | 75 | NR^a^ | - | -
Huang, 2006^174^ | 262 | 69 (13) | 385 | 70 (16) | - | - | - | -
Iizuka, 2012^101^ | 195 | 70 (29) | 67 | 71 (25) | - | - | - | -
Jeon, 2009^172^ | 129 | 83 (17) | 96 | 84 (16) | - | - | - | -
Kim, 2003^119^ | 35 | NR^a^ | 79 | NR^a^ | - | - | - | -
Kim, 2010^158^ | 52 | 81 (20) | 18 | 86 (20) | - | - | - | -
Kiriluk, 2011^179^ | - | - | 51 | 87 (30) | 51 | 88 (39) | - | -
Klatte, 2011^123^ | - | - | 82 | 64 (27) | 41 | 64 (22) | - | -
Kowalczyk, 2013^161^ b | 939 | NR | 490 | NR | 211 | NR | - | -
Kyung, 2014^104^ | 82 | 68 (23) | 53 | 69 (22) | - | - | - | -
Lane, 2010^105^ | 569 | 83 (21) | 1833 | 83 (20) | - | - | - | -
Lane, 2010^135,b^ | 146 | 64 (16) | - | - | - | - | 105 | 54 (19)
Li, 2007^106^ | 86 | NR^a^ | 35 | NR^a^ | - | - | - | -
Lucas, 2007^96^ | 71 | 75 (10) | 85 | 71 (7) | 86 | 73 (8) | - | -
Mariusdottir, 2013^107^ | 44 | 65 (16) | 44 | 69 (16) | - | - | - | -
Matin, 2002^176^ | 35 | NR^a^ | 82 | NR^a^ | - | - | - | -
McKiernan, 2002^121^ | 173 | NR^a^ | 117 | NR^a^ | - | - | - | -
Medina-Polo, 2011^108^ | 174 | 78 (20) | 116 | 76 (22) | - | - | - | -
Mitchell, 2011^178^ | - | - | 62 | 54 (26) | 50 | 53 (14) | - | -
Miyamoto, 2012^168^ | 152 | 71 (16) | 59 | 71 (20) | - | - | - | -
Mues, 2012^126^ | - | - | 100 | 59 (59) | 98 | 59 (59) | - | -
Pascal, 2011^137^ | - | - | 48 | 62 (19) | 30 | 54 (19) | - | -
Roos, 2010^113^ | 100 | 77 (22) | 69 | 82 (40) | - | - | - | -
Roos, 2012^114^ | 146 | 78 (18) | 101 | 79 (32) | - | - | - | -
Scosyrev, 2014^89^ | 259 | NR^a^ | 255 | NR^a^ | - | - | - | -
Snow, 2008^93^ | 37 | 90 (17) | 48 | 90 (22) | - | - | - | -
Sun, 2012^169^ | 840 | NR | 840 | NR | - | - | - | -
Takagi, 2011^156^ | 51 | 50 (7) | 44 | 50 (8) | - | - | - | -
Takaki, 2010,^160^ | 54 | 68 (20) | 10 | 69 (17) | 46 | 49 (18) | - | -
Takaki, 2014^134^ | 39 | 88 (22) | - | - | 21 | 63 (28) | - | -
Tanagho, 2013^125^ b | - | - | 233 | 85 (21) | 267 | 66 (25) | - | -
Turna, 2009^138^ | - | - | 36 | 65 (24) | 65 | 53 (18) | - | -
Van Poppel, 2010^90^ | 273 | NR^a^ | 268 | NR^a^ | - | - | - | -
Woldu, 2014^166^ | 767 | 76 (20) | 539 | 81 (21) | - | - | - | -
Yasuda, 2012^167^ | 103 | 104 (22) | 97 | 106 (15) | - | - | - | -
Youn, 2013^128^ | - | - | 14 | 73 (2) | 41 | 74 (3) | - | -
Zorn, 2007^173^ | 55 | 101 (64) | 42 | 94 (64) | - | - | - | -
Overall median | 7409 | 76 (18) | 8437 | 75 (21) | 1765 | 64 (22) | 173 | 68 (16)

NR = not reported; eGFR = estimated glomerular filtration rate; SD = standard deviation

a Baseline creatinine reported but not eGFR.

b Six studies reported statistically significant differences in baseline preoperative kidney function, with lower estimated kidney function.

Table 33 Renal functional outcomes reported in 54 studies of comparative management for small renal masses

Comparison | Author, Year | Continuous Outcomes | | | | Categorical Outcomes
Comparison | Author, Year | Final Serum Creatinine (mg/dL) | Change in Serum Creatinine (mg/dL) | Final eGFR (ml/min/1.73 m^2^) | Change in eGFR (ml/min/1.73 m^2^) | Incidence ≥ Mild-Moderate CKD (Stage ≥ III) | Incidence ≥ Moderate-Severe CKD (Stage ≥ IIIb) | Incidence ≥ Severe CKD (Stage ≥ IV) | Incidence Kidney Failure (Stage 5/ESRD)
Partial Nephrectomy Versus Thermal Ablation | Chang, 2015^180^ | -- | -- | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Cooper, 2014^164^ | Y | Y | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Partial Nephrectomy Versus Thermal Ablation | Deklaj, 2010^162^ | -- | -- | Y | Y | Y | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Desai, 2005^131^ | Y | Y | -- | -- | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Emara, 2014^132^ | Y | Y | -- | -- | Y | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Faddegon, 2013^177^ | -- | -- | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Foyil, 2008^163^ | -- | -- | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Guillotreau, 2012^129^ | -- | -- | Y | Y | Y | -- | -- | Y
Partial Nephrectomy Versus Thermal Ablation | Haramis, 2012^133^ | Y | Y | -- | -- | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Kiriluk, 2011^179^ | -- | -- | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Klatte, 2011^123^ | -- | -- | Y | Y | Y | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Kowalczyk, 2013^161^ | -- | -- | -- | -- | Y | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Lucas, 2007^96^ | -- | -- | -- | Y | Y | Y | -- | Y
Partial Nephrectomy Versus Thermal Ablation | Mitchell, 2011^178^ | Y | Y | Y | Y | Y | -- | Y | --
Partial Nephrectomy Versus Thermal Ablation | Mues, 2012^126^ | -- | -- | Y | Y | -- | -- | -- | Y
Partial Nephrectomy Versus Thermal Ablation | Pascal, 2011^137^ | Y | Y | Y | Y | Y | -- | Y | Y
Partial Nephrectomy Versus Thermal Ablation | Takaki, 2010^160^ | -- | -- | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Tanagho, 2013^125^ | Y | Y | Y | Y | -- | -- | -- | --
Partial Nephrectomy Versus Thermal Ablation | Turna, 2009^138^ | Y | Y | Y | Y | Y | -- | -- | Y
Partial Nephrectomy Versus Thermal Ablation | Youn, 2013^128^ | Y | Y | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Active Surveillance | Lane, 2010^135^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Active Surveillance | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Partial Nephrectomy Versus Active Surveillance | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Thermal Ablation Versus Active Surveillance | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Antoniewicz, 2012^171^ | Y | Y | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Barbalias, 1999^98^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Brewer, 2012^170^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Chang, 2014^94^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Cooper, 2014^164^ | Y | Y | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Chung, 2014^139^ | -- | -- | Y | Y | Y | -- | Y | --
Radical Nephrectomy Versus Partial Nephrectomy | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Dash, 2006^175^ | Y | Y | -- | -- | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Deklaj, 2010^118^ | -- | -- | Y | Y | Y | -- | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Deklaj, 2010^162^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Foyil, 2008^163^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Gratzke, 2009^83^ | -- | -- | -- | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Huang, 2006^174^ | -- | -- | -- | -- | Y | Y | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Iizuka, 2012^101^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Jeon, 2009^172^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Kim, 2003^119^ | Y | Y | -- | -- | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Kim, 2010^158^ | Y | Y | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Kowalczyk, 2013^161^ | -- | -- | -- | -- | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Kyung, 2014^104^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Lane, 2010^105^ | -- | -- | Y | Y | -- | Y | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Li, 2007^106^ | Y | Y | -- | -- | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Lucas, 2007^96^ | -- | -- | -- | Y | Y | Y | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Mariusdottir, 2013^107^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Matin, 2002^176^ | Y | Y | -- | -- | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | McKiernan, 2002^121^ | Y | Y | -- | -- | Y | -- | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Medina-Polo, 2011^108^ | -- | -- | Y | Y | Y | Y | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Miyamoto, 2012^168^ | Y | Y | Y | Y | Y | -- | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Roos, 2010^113^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Roos, 2012^114^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Scosyrev, 2014^89^ | -- | -- | Y | Y | Y | Y | Y | Y
Radical Nephrectomy Versus Partial Nephrectomy | Snow, 2008^93^ | Y | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Sun, 2012^169^ | -- | -- | -- | -- | Y | -- | -- | Y
Radical Nephrectomy Versus Partial Nephrectomy | Takagi, 2011^156^ | -- | -- | -- | -- | -- | Y | Y | Y
Radical Nephrectomy Versus Partial Nephrectomy | Takaki, 2010^160^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Van Poppel, 2010^90^ | Y | Y | -- | -- | -- | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Woldu, 2014^166^ | -- | -- | Y | Y | -- | Y | Y | --
Radical Nephrectomy Versus Partial Nephrectomy | Yasuda, 2012^167^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Partial Nephrectomy | Zorn, 2007^173^ | Y | Y | Y | Y | Y | -- | Y | --
Radical Nephrectomy Versus Thermal Ablation | Cooper, 2014^164^ | Y | Y | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Thermal Ablation | Danzig, 2015^165^ | -- | -- | Y | Y | Y | Y | -- | --
Radical Nephrectomy Versus Thermal Ablation | Deklaj, 2010^162^ | -- | -- | Y | Y | Y | -- | -- | --
Radical Nephrectomy Versus Thermal Ablation | Foyil, 2008^163^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Thermal Ablation | Kowalczyk, 2013^161^ | -- | -- | -- | -- | Y | -- | -- | --
Radical Nephrectomy Versus Thermal Ablation | Lucas, 2007^96^ | -- | -- | -- | Y | Y | Y | -- | Y
Radical Nephrectomy Versus Thermal Ablation | Takaki, 2010^160^ | -- | -- | Y | Y | -- | -- | -- | --
Radical Nephrectomy Versus Thermal Ablation | Takaki, 2014^134^ | -- | -- | Y | Y | -- | -- | -- | --
No. of studies reported each outcome^a^ | | 20 | 20 | 39 | 41 | 28 | 8 | 7 | 14

NR = not reported; CKD = chronic kidney disease; ESRD = end-stage renal disease; eGFR = estimated glomerular filtration rate

a 7 studies had multiple management comparisons.

##### Time Points for Renal Functional Outcomes

Time points for renal functional outcomes after surgery ranged from 1 month to 10 years. Seventy-nine percent of primary outcomes were greater than or equal to 1 year, and 35 percent of primary renal functional outcomes were reported at time of last followup. Where possible, we used the primary renal functional outcomes from the Kaplan-Meier curves that were closest to 1 year (or tabulated data), to avoid including competing causes of chronic kidney disease other than the surgical procedure.

#### Risk of Bias

We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies.35 For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 The overall risk of bias in studies assessing the renal functional outcomes is outlined in Figure 18. The use of an RCT examining renal functional outcomes was reported in two articles;89,90 the rest were observational studies. For those observational studies, risk of bias in studies was graded as moderate or severe. The primary sources of bias were in the selection of participants and bias due to confounding.

Figure 18 Risk of bias across studies of renal functional outcomesa

^a^ Renal functional outcomes included change in creatinine, change in estimated glomerular filtration rate, incidence of chronic kidney stages 3, 3b, and 4, and incidence of end stage renal disease.

Figure 18 shows the risk of bias across studies of renal functional outcomes.

##### Continuous Renal Functional Outcomes

###### Definitions for Continuous Functional Outcomes

Studies reported several different definitions for continuous functional outcomes, including—

1. Serum creatinine at followup and change in creatinine were reported in 20 studies.90,93,106,119,121,125,128,131-133,137,138,158,164,168,171,173,175,176,178 When change in creatinine was not provided, we calculated this from the preoperative and postoperative values provided.
2. eGFR at followup and change in eGFR were reported in 39 studies.89,93,94,98,101,104,105,107,108,113,114,118,123,125,126,128,129,134,135,137-139,158,160,162-168,170-173,177-180
3. Two additional studies reported change in eGFR but not baseline or followup eGFR.83,96
4. When change in eGFR was not provided, we calculated the change from the preoperative and postoperative values provided.

###### Radical Nephrectomy Versus Partial Nephrectomy

Thirty four studies assessed continuous renal functional outcomes for radical nephrectomy versus partial nephrectomy.83,89,90,93,94,96,98,101,104-108,113,114,118,119,121,139,158,160,162-168,170-173,175,176 Six studies addressed only continuous creatinine changes,90,106,119,121,175,176 twenty two addressed exclusively continuous estimated glomerular filtration rate changes,83,89,94,96,98,101,104,105,107,108,113,114,118,139,160,162,163,165-167,170,172 and six addressed both outcome measures.93,158,164,168,171,173 Most of the 28 studies analyzed management of any localized small renal mass; however, important subgroups were addressed as well, including seven studies that included patients with T1a tumors,93,94,101,160,162,172,176 seven with T1b and T2 tumors,94,101,113,114,118,158,170 four with the young or elderly,104,113,139,162 and four with patients having underlying chronic kidney disease.96,107,108,166 When comparing the final compiled continuous changes in creatinine and estimated glomerular filtration rate, those receiving radical nephrectomy showed more evidence of kidney dysfunction than those receiving partial nephrectomy (Table 34a). The strength of evidence was moderate.

Table 34a Continuous renal functional outcomes for radical nephrectomy versus partial nephrectomy

Outcome | No. Studies | Radical Nephrectomy | | | Partial Nephrectomy
Outcome | No. Studies | No. Patients | Median Measure | Range | No. Patients | Median Measure | Range
Followup creatinine (mg/dl) | 12 | 966 | 1.46 | 1.24 to 1.70 | 708 | 1.03 | 0.96 to 1.70
The change in creatinine | 12 | 966 | 0.47 | 0.30 to 0.51 | 708 | 0.12 | -0.05 to 0.40
Followup eGFR (ml/min/1.73 m^2^) | 26 | 3713 | 54.6 | 42.9 to 90 | 4080 | 71.1 | 55.3 to 98.0
eGFR change (ml/min/1.73 m^2^) | 27 | 3719 | -22.4 | -39.1 to -0.1 | 4098 | -7.4 | -16.2 to 4.1

eGFR: Estimated glomerular filtration rate

Four studies did not report significant p-values for the relationship of lower renal outcomes for radical nephrectomy.83,96,98,106 In meta-analysis, the mean change in creatinine was 0.35 mg/dl (95% CI, 0.29 to 0.41) higher (increasing by a larger amount) in the radical nephrectomy group while the mean change in estimated glomerular filtration rate was 3.6 ml/min/1.73 m^2^ (95% CI, 3.2 to 4.1) higher (decreasing by a larger amount) in the radical nephrectomy group than in the partial nephrectomy group (Figure 19). Significant heterogeneity in the estimated glomerular filtration rate outcome existed, with one of the largest studies 166 showing the smallest difference between partial nephrectomy and radical nephrectomy. This small difference may have been due to the yearly change in estimated glomerular filtration rate being averaged over the 5 years of the study.

Figure 19 Mean change in estimated glomerular filtration rate for radical nephrectomy versus partial nephrectomy

eGFR = estimated glomerular filtration rate; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 19 shows the mean change in estimated glomerular filtration rate for radical nephrectomy versus partial nephrectomy.

Important subgroup information emerged. Similar overall findings were seen in studies that included patients with T1a, T1b, and T2 tumors, with the exception of two studies, which found only a nonsignificant trend toward poorer radical nephrectomy outcomes in tumors 4 to 7 cm (p = 0.12) or greater than 7 cm (p = 0.07 and p=0.16).114,158

The effects of the radical nephrectomy strategy were also similar between subgroups defined by age, with elderly and young patients receiving radical nephrectomy both experiencing approximately an 8-15 ml/min/1.73 m^2^ lower estimated glomerular filtration rate compared with partial nephrectomy.113,139 The interaction of prior chronic kidney disease and estimated glomerular filtration rate change was less clear, with one study showing similar findings for radical nephrectomy versus partial nephrectomy in those with an estimate glomerular filtration rate greater than 60 ml/min/1.73 m^2^ versus an estimated glomerular filtration rate less than 60 ml/min/1.73 m^2^.108 One study showed that the baseline estimated glomerular filtration rate was predictive of larger changes in estimated glomerular filtration rate.107

Two studies showed no differences in estimated glomerular filtration rate change between radical nephrectomy and partial nephrectomy.96,166 These two studies suggested that the greatest benefit on renal function for partial nephrectomy occurred when baseline estimated glomerular filtration rate was greater than 60 ml/min/1.73 m^2^.

Eleven studies reported the long-term trends in creatinine and/or estimated glomerular filtration rate.83,89,94,101,105,118,139,163,168,171,175 Most of these studies showed an initial drop in creatinine and/or estimated glomerular filtration rate immediately postoperatively, which was followed by improvement in serum creatinine and/or estimated glomerular filtration rate from 1 to 3 days until approximately 3 to 6 months, when levels stabilized for as long as 15 years.89 Three studies suggested that the lower final estimated glomerular filtration rate in the radical nephrectomy group occurred because an equivalent improvement in estimated glomerular filtration rate in this initial 3 to 6 month time window was not present.101,118,163

###### Radical Nephrectomy Versus Thermal Ablation

Seven studies assessed continuous renal functional outcomes for radical nephrectomy versus thermal ablation.96,134,160,162-165 Two studies included patients with T1a tumors 96,160 and one had additional stratification by chronic kidney disease.96 One study included elderly patients with T1a tumors.162 One study included patients with T1b tumors,134 and one compared laparoscopic management strategies.163 Six studies examined the last estimated glomerular filtration rate as well as the change in estimated glomerular filtration.134,160,162-165 One study only reported change in estimated glomerular filtration rate.96 When comparing the final compiled health outcomes, those receiving radical nephrectomy showed more evidence of kidney dysfunction than those receiving thermal ablation (Table 34b). The strength of evidence was moderate.

Table 34b Continuous renal functional outcomes for radical nephrectomy versus thermal ablation

Outcome | No. Studies | Radical Nephrectomy | | | Thermal Ablation
Outcome | No. Studies | No. Patients | Median Measure | Range | No. Patients | Median Measure | Range
Followup creatinine (mg/dl) | 1 | 31 | 1.63 | 1.63 | 9 | 1.37 | 1.37
Creatinine change | 1 | 31 | 0.53 | 0.53 | 9 | 0.23 | 0.23
Followup eGFR (ml/min/1.73 m^2^) | 6 | 207 | 50.8 | 42.9 to 59.6 | 158 | 55.5 | 49.8 to 85.7
eGFR change (ml/min/1.73 m^2^) | 7 | 213 | -13.2 | -28.8 to -0.1 | 177 | -2.9 | -6.4 to -1.7

eGFR = estimated glomerular filtration rate

Five of the seven studies reported significant p-values for the association of worse renal outcomes with radical nephrectomy. The exceptions were 164 which had only 9 patients in the thermal ablation group and 96 which reported statistically equivalent outcomes in those with estimated glomerular filtration less than 60 ml/min/1.73 m^2^ or less than 45 ml/min/1.73 m^2^. In meta-analysis, the mean change in estimated glomerular filtration rate was 9.94 ml/min/1.73 m^2^ (95% CI, 7.61 to12.26) more (decreasing by a larger amount) in the radical nephrectomy group than in the thermal ablation group (Figure 20).

Figure 20 Mean change in estimated glomerular filtration for thermal ablation versus radical nephrectomy

eGFR = estimated glomerular filtration rate; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 20 shows the mean change in estimated glomerular filtration for thermal ablation versus radical nephrectomy.

###### Partial Nephrectomy Versus Thermal Ablation

Nineteen studies assessed continuous renal functional outcomes for partial nephrectomy versus thermal ablation.96,123,125,126,128,129,131-133,137,138,160,162-165,177-180 Three studies reported only continuous creatinine changes,131-133 11 reported exclusively continuous estimated glomerular filtration rate changes,96,123,126,129,160,162,163,165,177,179,180 and 6 reported both outcome measures (Table 34c).125,128,137,138,164,178

Table 34c Continuous renal functional outcomes for partial nephrectomy versus thermal ablation

Outcome | No. Studies | Partial Nephrectomy | | | Thermal Ablation
Outcome | No. Studies | No. Patients | Median Measure | Range | No. Patients | Median Measure | Range
Followup creatinine (mg/dl) | 9 | 683 | 1.31 | 0.89 to1.70 | 673 | 1.40 | 0.88 to 1.70
Creatinine change (mg/dl) | 9 | 683 | 0.23 | 0.06 to 0.40 | 673 | 0.13 | -0.10-0.22
Followup eGFR (ml/min/1.73 m^2^) | 16 | 1080 | 66.1 | 47.5 to 87.8 | 1238 | 58.8 | 47.5 to 85.7
eGFR change (ml/min/1.73 m^2^) | 17 | 1098 | -6.2 | -18 to 4.1 | 1257 | -4.9 | -8.0 to -1.5

eGFR = estimated glomerular filtration rate

Important subgroups were included, including 10 studies examining T1a tumors,96,123,128,129,131-133,160,162,177 3 examining solitary tumors,126,138,178 3 examining the role of preexisting chronic kidney disease,96,131,179 1 reporting on the elderly,162 and 5 employing multivariable models to predict postoperative estimated glomerular filtration rate.125,129,138,165,177

When comparing the final compiled health outcomes, those patients undergoing partial nephrectomy had kidney function outcomes similar to those receiving thermal ablation (Table 34c). Four of the 16 studies reported significant p-values for the association of worse renal outcomes for partial nephrectomy.125,137,138,180 In meta-analysis, the mean change in creatinine was 0.07 mg/dl (95% CI, 0.00 to 0.15) higher (increased by a larger amount) in the partial nephrectomy group (see Appendix F), while the mean change in estimated glomerular filtration rate was 1.0 ml/min/1.73 m^2^ (95% CI, -0.2 to 2.1) more (decreased by a larger amount) in the partial nephrectomy group than in the thermal ablation group (Figure 21); however, neither reached statistical significance. Significant heterogeneity in the estimated glomerular filtration rate outcome did exist. The strength of evidence was low.

Figure 21 Mean change in estimated glomerular filtration rate for thermal ablation versus partial nephrectomy

eGFR = estimated glomerular filtration rate; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 21 shows the mean change in estimated glomerular filtration rate for thermal ablation versus partial nephrectomy.

Important subgroup information did emerge. Four studies reported on T1a tumors and showed similar outcomes between groups.126,138,160,178 Two studies126,178 showed that patients with solitary kidneys had similar outcomes between groups, while the other138 found a larger drop in estimated glomerular filtration rate for those with underlying stage 3 chronic kidney disease who also received thermal ablation. In multivariable models, tumor size and hilar location were associated with lower estimated glomerular filtration rate in one study,125 and preoperative estimated glomerular filtration rate was associated with greater decline in estimated glomerular filtration rate in one study.138 In two other studies, other demographic factors were not associated with the change in estimated glomerular filtration rate.129,177

Six studies addressed long-term trends in creatinine and/or estimated glomerular filtration rate.123,129,160,163,179,180 Two studies129,163 described the partial nephrectomy group as having lower kidney function one day after surgery, but then improving to similar levels as thermal ablation at 1 to 6 months. Three studies160,179,180 described estimated glomerular filtration rate falling for both groups early after surgery and remaining at that level, and one study123 described both groups' estimated glomerular filtration rate falling until 3 months, but also showed that the patients receiving thermal ablation had their estimated glomerular filtration rate levels rise after that point.

###### Radical Nephrectomy Versus Active Surveillance

Two studies assessed continuous renal functional outcomes for radical nephrectomy versus active surveillance.135,165 One study 135 included patients over the age of 75 years with T1 tumors. The authors found that the followup estimated glomerular filtration rate was 10 ml/min/1.73 m^2^ higher in those assigned active surveillance, and with the estimated glomerular filtration rate decreasing by 23 ml/min/1.73 m^2^ in the radical nephrectomy group compared with a decrease of only 3 ml/min/1.73 m2 in the active surveillance group; these differences were statistically significant. The other study 165 compared all four management strategies for patients with small renal masses. Mean final eGFR was higher in the active surveillance group, while mean eGFR change was -9.19 ml/min/1.73 m^2^ in the radical nephrectomy group and -0.55 ml/min/1.73 m^2^ in the active surveillance group; these results were statistically significant (Table 34d). The strength of evidence was low.

Table 34d Continuous renal functional outcomes for radical nephrectomy versus active surveillance

Outcome | No. Studies | Radical Nephrectomy | | | Active Surveillance
Outcome | No. Studies | No. Patients | Median Measure | Median of SD Measure | No. Patients | Median Measure | Median of SD Measure
Followup creatinine (mg/dl) | 0 | - | - | - | - | - | -
Creatinine change | 0 | - | - | - | - | - | -
Followup eGFR (ml/min/1.73 m^2^) | 2 | 161 | 52.6 | 13.6 | 173 | 66 | 18
eGFR change (ml/min/1.73 m^2^) | 2 | 161 | -16.1 | 16.6 | 173 | -1.8 | 19

eGFR = estimated glomerular filtration rate

###### Partial Nephrectomy Versus Active Surveillance

Only two studies compared partial nephrectomy with active surveillance.135,165 One study 135 combined both partial nephrectomy and thermal ablation in this arm, without the ability to separate the groups. The other study 165 compared all four management strategies for patients with small renal masses. Mean final eGFR was statistically lower in the active surveillance group than in the partial nephrectomy group, while mean eGFR change was similar between groups. (Table 34e). The evidence was insufficient.

Table 34e Continuous renal functional outcomes for partial nephrectomy versus active surveillance

Outcome | No. Studies | Partial Nephrectomy | | | Active Surveillance
Outcome | No. Studies | No. Patients | Median Measure | Median of SD Measure | No. Patients | Median Measure | Median of SD Measure
Followup creatinine (mg/dl) | 0 | - | - | - | - | - | -
Creatinine change | 0 | - | - | - | - | - | -
Followup eGFR (ml/min/1.73 m^2^) | 1 | 65 | 87.8 | 12 | 68 | 80.9 | 13.1
eGFR change (ml/min/1.73 m^2^) | 1 | 65 | -1.9 | 6.2 | 68 | -0.6 | 8

eGFR = estimated glomerular filtration rate

###### Thermal Ablation Versus Active Surveillance

Only two studies compared thermal ablation with active surveillance.135,165 One study 135 combined both partial nephrectomy and thermal ablation in one arm, without the ability to separate the groups. The other study 165 compared all four management strategies for patients with small renal masses. Both mean final eGFR and mean eGFR change were similar between groups. (Table 34f). The evidene was insufficient.

Table 34f Continuous renal functional outcomes for thermal ablation versus active surveillance

Outcome | No. Studies | Thermal Ablation | | | Active Surveillance
Outcome | No. Studies | No. Patients | Median Measure | Median of SD Measure | No. Patients | Median Measure | Median of SD Measure
Followup creatinine (mg/dl) | 0 | - | - | - | - | - | -
Creatinine change | 0 | - | - | - | - | - | -
Followup eGFR (ml/min/1.73 m^2^) | 1 | 14 | 85.7 | 12.8 | 68 | 80.9 | 13.1
eGFR change (ml/min/1.73 m^2^) | 1 | 14 | -2.9 | 5.5 | 68 | -0.6 | 8

eGFR = estimated glomerular filtration rate

##### Categorical Renal Functional Outcomes

###### Definitions for Categorical Functional Outcomes

Studies reported several different definitions for categorical functional outcomes.

1. Twenty-eight studies reported the number of patients reaching greater than or equal to mild to moderate chronic kidney disease.
  a. Incidence of chronic kidney disease stage III or greater was used as our primary outcome. This was noted in each study as estimated glomerular filtration rate less than 60 ml/min/1.73 m^2^ or estimated creatinine clearance less than 60 ml/min (reported in 14 studies).94,96,104,107,108,123,129,135,139,162,167,168,172,174
  b. Prevalence of chronic kidney disease greater than or equal to stage III was reported in 12 studies.89,104,113,114,118,132,135,162,165,168,170,178 In four studies that reported prevalence,104,135,162,168 incidence was also reported, and thus incidence was used as the primary outcome. For five studies that reported prevalence,113,118,165,170,178 incidence outcomes could be calculated using baseline chronic kidney disease and followup prevalence data. For three studies,89,114,132 neither the baseline stage of chronic kidney diseases nor the incidence of chronic kidney disease were available; in those three studies, prevalence was used as the outcome.
  c. Two studies used administrative and billing codes for chronic kidney disease outcomes.161,169
  d. Incidence of creatinine greater than 1.5 mg/dl was used in one study.173
  e. Incidence of creatinine greater than 2 mg/dl in those without other renal functional outcomes was used in one study.121
  f. Incidence of estimated glomerular filtration rate decrease by more than 20 percent was used in one study.138
  g. Incidence of a one-stage increase in chronic kidney disease was used in one study.137
2. Eight studies reported a number of patients with greater than or equal to moderate to severe chronic kidney disease.
  a. Incidence of chronic kidney disease greater than or equal to stage III was used as the primary outcome. This was noted in five studies as estimated glomerular filtration rate less than 45 ml/min/1.73 m^2^, estimated creatinine clearance less than 45 ml/min,96,105,156,166,174 or estimated glomerular filtration rate less than 40 ml/min/1.73 m^2^ (one study108).
  b. Two studies reported the prevalence of chronic kidney disease greater than or equal to stage IIIb.89,165 For one study that reported prevalence, 165 incidence outcomes could be calculated using baseline chronic kidney disease and followup prevalence data. Neither baseline stage of chronic kidney disease nor incidence of chronic kidney disease were available for one study;89 therefore, prevalence was used as the outcome.
3. Seven studies reported number of patients with chronic kidney disease greater than or equal to severe.
  a. Incidence of chronic kidney disease greater than or equal to stage IV was used as the primary outcome. This was noted in each study as estimated glomerular filtration rate less than 30 ml/min/1.73 m^2^ or an estimated creatinine clearance less than 30 ml/min (three studies139,156,166).
  b. Two studies reported the prevalence of chronic kidney disease greater than or equal to stage IV.89,178 For one study that reported prevalence,178 incidence outcomes could be calculated using baseline chronic kidney disease and followup prevalence data. For one study,89 neither baseline stage of chronic kidney disease nor incidence of chronic kidney disease were available; therefore, prevalence was used as the outcome.
  c. One study reported the incidence of creatinine levels greater than 2 mg/dl in those with other milder renal functional outcomes available 121.
  d. One study reported the incidence of a two-stage increase in chronic kidney disease.137
4. Fourteen studies reported outcomes in terms of the risk of kidney failure.
  a. In those studies, the incidence of end stage renal disease was used as the primary outcome. This was noted in each study as need for permanent dialysis, chronic kidney disease stage V, estimate glomerular filtration rate less than 15 ml/min/1.73 m^2^ or estimated creatinine clearance less than 15 ml/min (14 studies89,96,105,108,118,121,126,129,137,138,156,168,169,174).
5. Only one study examined the presence of proteinuria postoperatively.98

###### Radical Nephrectomy Versus Partial Nephrectomy

Twenty-four studies assessed categorical renal functional outcomes for radical nephrectomy versus partial nephrectomy.89,94,96,104,105,107,108,113,114,118,121,139,156,161,162,165-170,172-174 Twenty-one studies addressed incidence of mild to moderate chronic kidney disease (greater than or equal to stage III).89,94,96,104,107,108,113,114,118,121,139,161,162,165,167-170,172-174 Eight of these studies reported incidence of moderate to severe kidney disease greater than or equal to stage III b, 89,96,105,108,156,165,166,174 5 reported incidence of severe kidney disease greater than or equal to stage IV,89,139,156,166,173 and 10 reported the incidence of end stage renal disease (Table 35a).89,96,105,108,118,121,156,168,169,174

Table 35a Categorical renal functional outcomes for radical nephrectomy versus partial nephrectomy

Outcome | No. Studies | Radical Nephrectomy | | | Partial Nephrectomy
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III | 21 | 3,598 | 1,168 | 32 | 2,901 | 341 | 12
CKD Stage ≥IIIb | 8 | 2,068 | 451 | 22 | 3,232 | 319 | 10
CKD Stage ≥IV | 5 | 1,613 | 86 | 5 | 1,385 | 50 | 4
ESRD | 10 | 2,807 | 23 | 1 | 3,954 | 16 | 0.4

CKD = chronic kidney disease; ESRD = end-stage renal disease

There was one RCT,89 while two of the largest studies used SEER data and administrative codes for outcomes.161,169. For tumor size, five studies only included T1 tumors,94,104,108,139,167 five included T1a only,96,161,162,169,172 and four included T1b and T2.^113,114,118,170^ Important subgroups included the elderly104,113,139,162 and those patients with chronic kidney disease.166 The strength of evidene was moderate.89,96

In a meta-analysis comparing partial nephrectomy to radical nephrectomy, the pooled risk ratios of each categorical chronic kidney disease outcome were as follows, indicating lower risk with partial nephrectomy:

- Greater than or equal to stage III, risk ratio 0.39 (95% CI, 0.30 to 0.51) (Figure 22);
- Greater than or equal to stage IIIb, risk ratio 0.37 (95% CI, 0.26 to 0.53) (Appendix F, Figure 3);
- Greater than or equal to stage IV, risk ratio 0.76 (95% CI, 0.54 to 1.07) (Appendix F, Figure 4); and
- End stage renal disease, risk ratio 0.47 (95% CI, 0.25 to 0.86) (Appendix F, Figure 5).

Figure 22 Meta-analysis of the incidence of stage 3 chronic kidney disease with radical nephrectomy versus partial nephrectomy

CKD = chronic kidney disease; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; RR = risk ratio; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 22 is a meta-analysis of the incidence of stage 3 chronic kidney disease with radical nephrectomy versus partial nephrectomy.

Similar relative risk findings were obtained across all tumor sizes and age groups, though the absolute risk in elderly patients was two to four times higher than the risk in younger patients despite similar baseline estimated glomerular filtration rates.113 While the risks of incident chronic kidney disease at greater than or equal to stage III b and stage IV were higher overall for the radical nephrectomy group, several studies reported that the risk of incident chronic kidney disease greater than or equal to stage III b89,166 or stage IV89,156,166 across radical nephrectomy and partial nephrectomy groups was similar if only those with underlying chronic kidney disease were examined. However, multivariate adjustment in other studies suggested that baseline estimated glomerular filtration rate was an independent predictor of the development of chronic kidney disease.96,107,114,174

###### Radical Nephrectomy Versus Thermal Ablation

Four studies assessed continuous renal functional outcomes for radical nephrectomy versus thermal ablation.96,161,162,165 All of these studies examined incidence of chronic kidney disease greater than or equal to stage III; however, only two examined the risk of chronic kidney disease greater than or equal to stage IIIb 96,165 and only one examined the risk of end stage renal disease.96 Two of these studies only included patients with T1a tumors,96,161 and one included patients with T1b tumors (Table 35b).162

Table 35b Categorical renal functional outcomes for radical nephrectomy versus thermal ablation

Outcome | No. Studies | Radical Nephrectomy | | | Thermal Ablation
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III | 4 | 819 | 275 | 34 | 264 | 35 | 13
CKD Stage ≥IIIb | 2 | 82 | 17 | 21 | 92 | 2 | 2
CKD Stage ≥IV | 0 | -- | -- | -- | -- | -- | --
ESRD | 1 | 71 | 2 | 3 | 86 | 1 | 1

CKD = chronic kidney disease; ESRD = end-stage renal disease

In a meta-analysis comparing radical nephrectomy to thermal ablation, only the pooled risks for chronic kidney disease greater than or equal to stage III were obtained. There was a 3.48 fold higher risk of chronic kidney disease stage 3 in those receiving radical nephrectomy, with significant pooled risk ratio at 0.3.48 (95% CI, 1.08 to 11.15) (Figure 23). In multivariable analysis after accounting for baseline estimated glomerular filtration rate, age, and tumor characteristics, one study found that patients receiving radical nephrectomy were at 34.3 times higher risk of developing stage III chronic kidney disease over thermal ablation and at 7.9 times higher risk of developing stage IIIb chronic kidney disease.96 The strength of evidene was moderate.

Figure 23 Meta-analysis of the incidence of stage 3 chronic kidney disease with radical nephrectomy versus thermal ablation

CKD = chronic kidney disease; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; RR = risk ratio; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 23 is a meta-analysis of the incidence of stage 3 chronic kidney disease with thermal ablation versus radical nephrectomy.

###### Partial Nephrectomy Versus Thermal Ablation

Eleven studies assessed categorical renal functional outcomes for partial nephrectomy versus thermal ablation.96,123,126,129,132,137,138,161,162,165,178

Ten of these studies examined the incidence of chronic kidney disease greater than or equal to stage III;96,123,129,132,137,138,161,162,165,178 however, only two reported the risk of chronic kidney disease greater than or equal to stage IIIb,96,165 two examined the risk of chronic kidney disease greater than or equal to stage IV,137,178 and five reported the risk of end stage renal disease.96,126,129,137,138 Important subgroups were examined, including five studies examining T1a tumors,96,123,129,132,161 three examining solitary tumors,126,138,178 one examining the role of preexisting chronic kidney disease,96 one reporting on the elderly,162 and one employing multivariable models to predict the risk of chronic kidney disease96 (Table 35c). The strength of evidene was low.

Table 35c Categorical renal functional outcomes for partial nephrectomy versus thermal ablation

Outcome | No. Studies | Partial Nephrectomy | | | Thermal Ablation
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III | 10 | 880 | 181 | 20 | 571 | 158 | 28
CKD Stage ≥IIIb | 2 | 137 | 3 | 2 | 92 | 2 | 2
CKD Stage ≥IV | 2 | 106 | 6 | 6 | 78 | 1 | 1
ESRD | 5 | 477 | 6 | 1 | 502 | 9 | 2

CKD = chronic kidney disease; ESRD = end-stage renal disease

In a meta-analysis comparing partial nephrectomy with thermal ablation, the pooled risk ratios of each categorical chronic kidney disease outcome were not statistically significant. Risk estimates were the following:

- Greater than or equal to stage III, risk ratio RR 0.88 (0.60 to 1.30) (Figure 24);
- Greater than or equal to stage IV, risk ratio 0.36 (95% CI, 0.06 to 0.13) (see Appendix F, Figure 6); and
- End stage renal disease, risk ratio 0.92 (95% CI, 0.19 to 4.39) (see Appendix F, Figure 7).

Figure 24 Meta-analysis of the incidence of stage 3 chronic kidney disease with partial nephrectomy versus thermal ablation

CKD = chronic kidney disease; No. = number; PN = partial nephrectomy; RN = radical nephrectomy; RR = risk ratio; TA = thermal ablation; WMD = weighted mean difference

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 24 is a meta-analysis of the incidence of stage 3 chronic kidney disease with thermal ablation versus partial nephrectomy.

In a single study that employed multivariable models including tumor and patient characteristics, there was a 10.9 times higher risk of developing chronic kidney disease greater than or equal to stage III for the partial nephrectomy group (p = 0.024) but a nonsignificant 1.2 times higher risk of developing chronic kidney disease greater than or equal to stage IIIb (p = 0.9).96

###### Radical Nephrectomy Versus Active Surveillance

Two studies compared categorical renal functional outcomes between radical nephrectomy and active surveillance, and also compared continuous outcomes earlier.135,165 In one study,135 56 patients were diagnosed with chronic kidney disease greater than or equal to stage III postoperatively in the active surveillance group; however, 53 of them had prevalent chronic kidney disease in the preoperative setting, giving an incidence of 5.8 percent. Likewise, 125 patients were diagnosed with chronic kidney disease greater than or equal to stage III postoperatively in the radical nephrectomy group, though 57 of these patients had prevalent chronic kidney disease in the preoperative setting, giving an incidence of 76.4 percent. In the other study,165 40 percent of patients had prevalent chronic kidney disease at followup (incidence 40 percent) in the radical nephrectomy group while 3 percent of patients had chronic kidney disease in the active surveillance group (see Table 35d). The strength of evidence was low (Table 36).

Table 35d Categorical renal functional outcomes for radical nephrectomy versus active surveillance

Outcome | No. Studies | Radical Nephrectomy | | | Active Surveillance
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III^a^ | 2 | 101 | 71 | 70 | 119 | 4 | 3
CKD Stage ≥IIIb | 1 | 15 | 1 | 7 | 68 | 0 | 0
CKD Stage ≥IV | 0 | -- | -- | -- | -- | -- | --
ESRD | 0 | -- | -- | -- | -- | -- | --

CKD = chronic kidney disease; ESRD = end-stage renal disease

a Patients were free of CKD at baseline.

Table 36 Strength of evidence for renal outcome

Comparison | Key Outcomes^a^ | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Partial Nephrectomy Versus Active Surveillance | Continuous renal functional outcomes | 2 (524) | High | Direct | Unknown | Imprecise | Undetected | Insufficient One study combined both partial nephrectomy and cryoablation without the ability to separate the groups. The other study found no difference in GFR change between groups. The evidence was insufficient to determine effectiveness of partial nephrectomy alone.
Partial Nephrectomy Versus Active Surveillance | Categorical renal functional outcomes | 2 (312) | High | Direct | Unknown | Imprecise | Undetected | Insufficient One study combined both partial nephrectomy and cryoablation without the ability to separate the groups. The other study found no difference in rates of CKD between groups. The evidence was insufficient to determine effectiveness of partial nephrectomy alone.
Partial Nephrectomy Versus Thermal Ablation | Continuous renal functional outcomes | 19 (2,867) | Medium | Direct | Inconsistent | Imprecise | Undetected | Low eGFR fell more with partial nephrectomy than with thermal ablation, by an average of 1.0 ml/min/1.73 m2 (95% CI -0.2-2.1 ml/min/1.73 m2), but the result was not statistically significant and there was significant heterogeneity.
Partial Nephrectomy Versus Thermal Ablation | Categorical renal functional outcomes | 11 (1,893) | Medium | Direct | Inconsistent | Imprecise | Undetected | Low No statistically significant differences were seen in rates of CKD stage ≥3, ≥3b, ≥4, or ESRD.
Radical Nephrectomy Versus Active Surveillance | Continuous renal functional outcomes | 2 (334) | Medium | Direct | Consistent | Imprecise | Undetected | Low While results are limited by having only two studies, decline in eGFR was 14 ml/min/1.73 m^2^ less in those assigned active surveillance.
Radical Nephrectomy Versus Active Surveillance | Categorical renal functional outcomes | 2 (471) | Medium | Direct | Consistent | Imprecise | Undetected | Low While results are limited by having only two studies, rates of new onset CKD Stage ≥3 were 3-6% with active surveillance and 40-76% with radical nephrectomy.
Radical Nephrectomy Versus Partial Nephrectomy | Continuous renal functional outcomes | 34 (9,221) | Medium | Direct | Consistent | Precise | Undetected | Moderate eGFR fell more with radical than partial nephrectomy, by an average of 3.6 ml/min/1.73 m2 (95% CI 3.2-4.1 ml/min/1.73 m2, , with significant heterogeneity in the magnitude of the difference.
Radical Nephrectomy Versus Partial Nephrectomy | Categorical renal functional outcomes | 24 (11,236) | Medium | Direct | Consistent | Precise | Undetected | Moderate Incidence of all stages of CKD were lower in those undergoing partial nephrectomy compared to radical nephrectomy, with risk 0.39 times lower for CKD stage 3, 0.37 times lower for CKD stage 3b, 0.76 times lower for CKD stage 4, and 0.47 times lower for ESRD. Heterogeneity did exist in the magnitude of the findings.
Radical Nephrectomy Versus Thermal Ablation | Continuous renal functional outcomes | 7 (390) | Medium | Direct | Consistent | Precise | Undetected | Moderate eGFR fell more with radical nephrectomy than with thermal ablation, by an average of 9.9 ml/min/1.73 m2 (95% CI 7.6-12.3 ml/min/1.72 m2).
Radical Nephrectomy Versus Thermal Ablation | Categorical renal functional outcomes | 4 (1,125) | Medium | Direct | Consistent | Precise | Undetected | Moderate Rate of CKD Stage >3 was 3.5 fold higher (95% CI 1.1-12.7) for those receiving radical nephrectomyt. Rates of CKD stage 3b and ESRD were limited to two studies.
Thermal Ablation Versus Active Surveillance | Continuous renal functional outcomes | 2 (473) | High | Direct | Unknown | Imprecise | Undetected | Insufficient One study combined both partial nephrectomy and cryoablation without the ability to separate the groups. The other study found no difference in eGFR change between groups. The evidence was insufficient to determine effectiveness of thermal ablation alone
Thermal Ablation Versus Active Surveillance | Categorical renal functional outcomes | 2 (312) | High | Direct | Unknown | Imprecise | Undetected | Insufficient One study combined both partial nephrectomy and cryoablation without the ability to separate the groups. The other study found no difference in rates of CKD between groups. The evidence was insufficient to determine effectiveness of thermal ablation alone.

CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; ESRD = end-stage renal disease

a Continuous renal functional outcomes included change in serum creatinine and/or change in eGFR; categorical renal functional outcomes included incidence of CKD stage 3, 3b, or 4 or incidence of ESRD.

###### Partial Nephrectomy Versus Active Surveillance

Two studies compared categorical renal functional outcomes between partial nephrectomy and active surveillance, and also compared continuous outcomes earlier.135,165. One study 135 combined both partial nephrectomy and thermal ablation in this arm, without the ability to separate the groups. The other study 165 compared categorical renal functional outcomes between partial nephrectomy and active surveillance, and also compared continuous outcomes earlier. Two percent of patients had prevalent chronic kidney disease at followup in the partial nephrectomy group while 3 percent of patients had chronic kidney disease in the active surveillance group (see Table 35e). The evidence was insufficient (Table 36).

Table 35e Categorical renal functional outcomes for partial nephrectomy versus active surveillance

Outcome | No. Studies | Partial Nephrectomy | | | Active Surveillance
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III^a^ | 1 | 65 | 1 | 2 | 119 | 4 | 3
CKD Stage ≥IIIb | 1 | 65 | 0 | 0 | 68 | 0 | 0
CKD Stage ≥IV | 0 | -- | -- | -- | -- | -- | --
ESRD | 0 | -- | -- | -- | -- | -- | --

CKD = chronic kidney disease; ESRD = end-stage renal disease

a Patients were free of CKD at baseline.

###### Thermal Ablation Versus Active Surveillance

Two studies compared categorical renal functional outcomes between thermal ablation and active surveillance, and also compared continuous outcomes earlier.135,165. One study 135 combined both partial nephrectomy and thermal ablation in this arm, without the ability to separate the groups. The other study 165 compared categorical renal functional outcomes between thermal ablation and active surveillance, and also compared continuous outcomes earlier. 165 No patients had chronic kidney disease at followup in the thermal ablation group while 3 percent of patients had chronic kidney disease in the active surveillance group (see Table 35f). The evidence was insuffient (Table 36).

Table 35f Categorical renal functional outcomes for thermal ablation versus active surveillance

Outcome | No. Studies | Thermal Ablation | | | Active Surveillance
Outcome | No. Studies | No. Patients | No. Outcomes | %. Outcomes | No. Patients | No. Outcomes | %. Outcomes
CKD Stage ≥III^a^ | 1 | 14 | 0 | 0 | 119 | 4 | 3
CKD Stage ≥IIIb | 1 | 14 | 0 | 0 | 68 | 0 | 0
CKD Stage ≥IV | 0 | -- | -- | -- | -- | -- | --
ESRD | 0 | -- | -- | -- | -- | -- | --

CKD = chronic kidney disease; ESRD = end-stage renal disease

a Patients were free of CKD at baseline.

##### Quality of Life

Four studies reported comparative health-related quality of life outcomes.80-83 All four studies evaluated radical nephrectomy against partial nephrectomy. There were no studies evaluating comparative health-related quality of life among thermal ablation or active surveillance.

Each study used different health-related quality of life questionnaires, preventing any direct comparison or pooling of data among studies. Three studies were cross-sectional, evaluating health-related quality of life at a single, variable time point after surgery.81-83 The study by Parker, et al. evaluated quality of life at predetermined time points in a prospective study.80

##### Risk of Bias

We used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 Four studies were included in the risk of bias assessment.80-83 The overall risk of bias was moderate in 1 (25 percent) study and serious in 3 studies. Bias due to confounding was the primary source of bias (Figure 25).

Figure 25 Risk of bias for comparative studies on health-related quality of life

Figure 25 shows the risk of bias for comparative studies on health-related quality of life.

###### Radical Nephrectomy Versus Partial Nephrectomy

In the study by Parker, et al., prospective health-related quality of life measures were evaluated at baseline and three weeks, as well as at two, three, six, and 12 months following open and laparoscopic radical and partial nephrectomy. 80 In this study, validated Medical Outcomes Study Short Form 36 (SF-36) and Cancer Rehabilitation Evaluation System-Short Form (CARES-SF) questionnaires were used.

Better cancer-specific health-related quality of life, as substantiated by lower Cancer Rehabilitation Evaluation System-Short Form scores, was reported in patients undergoing radical nephrectomy. However, in the comparison between radical and partial nephrectomy, no difference was seen in the impact on physical or mental health-related quality of life, intrusive thoughts, avoidance behaviors, or fear of recurrence. Age, type of surgery (i.e., open vs. laparoscopic), and time from surgery were shown to impact health-related quality of life in ways that included physical health, cancer-specific quality of life, intrusive thoughts, avoidance behaviors, and fear of recurrence.

The study by Ficarra, et al.81 compared the health-related quality of life of 88 patients undergoing radical nephrectomy and 56 undergoing partial nephrectomy at an average 55 months after surgery. This study evaluated general health, hospital anxiety and depression, social problems, and distressing events through validated questionnaires addressing each health-related quality of life domain. The proportion reporting an adverse health-related quality of life outcome and the raw scores are shown in Table 37. The evidence was insufficient (Table 38).

Table 37 Health-related quality of life outcomes reported in the study by Ficara et al.81

Outcome | Definition | Proportion Reporting | | Questionnaire Score | | p-Value
Outcome | Definition | Radical Nephrectomy | Partial Nephrectomy | Radical Nephrectomy | Partial Nephrectomy | p-Value
Anxiety | Low | 11.4% | 1.8% | 2.77±2.77 | 1.79±2.47 | 0.003
Depression | Mild | 7% | 2.3% | 2.08±2.32 | 1.72±2.80 | 0.01
General Health | Impaired | 12.5% | 7% | 0.78±1.88 | 0.50±1.46 | 0.46
Social Problems | Present | 18% | 18% | 0.31±0.79 | 0.46±1.15 | 0.75

Note: Definitions of “low,” “mild,” “impaired,” and “present” are arbitrary and defined by the authors.

Table 38 Strength of evidence for quality of life

Comparison | Key Outcomes | No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Partial Nephrectomy Versus Active Surveillance | QOL | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Thermal Ablation | QOL | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Radical Nephrectomy Versus Active Surveillance | QOL | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Radical Nephrectomy Versus Partial Nephrectomy | Comparative Studies | 4 (498) | Medium | Direct | Unknown (Each study reports different outcome measures and results are not directly comparable.) | Imprecise | Undetected | Insufficient Conclusions cannot be drawn based on limited number of studies, heterogeneity of outcome measures, and inconsistency of results.
Radical Nephrectomy Versus Thermal Ablation | Comparative Studies | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Thermal Ablation Versus Active Surveillance | Comparative Studies | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies

In the study by Shinohara, et al.,82 51 patients undergoing radical nephrectomy and 15 undergoing partial nephrectomy completed the standardized European Organization for Research and Treatment of Cancer Quality of Life Questionnaire Core 30 (EORTC QLQ-C30) questionnaire at a mean 60 and 47 months respectively. Without the evaluation of baseline scores, those undergoing partial nephrectomy demonstrated higher physical functioning scores (p < 0.05) including elements of constipation (p < 0.05), fatigue (p < 0.1), pain (p < 0.1), and sleep (p < 0.1). There were no differences in role, emotional, cognitive or social functioning among groups. Actual scores were not reported in this study.

The study by Gratzke, et al.83 compared the health-related quality of life of 73 patients undergoing radical nephrectomy and 44 undergoing partial nephrectomy using the standardized, SF36 questionnaire. This study made a distinction between patients undergoing laparoscopic radical nephrectomy (N = 37) and those undergoing open radical nephrectomy (N = 36). Mean SF36 scores did not differ among groups. Mental component scores were 48.3 and 48.0 for patients undergoing radical nephrectomy and 44.5 for patients undergoing partial nephrectomy (p = 0.50). Physical component scores were also similar (48.0, 47.4, and 47.2, respectively, with p =0.97). Overall, health-related quality of life scores were shown to be related to complications regardless of the type of surgery (p < 0.05).

#### Perioperative Outcomes

Perioperative outcomes include metrics of the intervention that occur during or immediately following the intervention. These are defined in the PICOTS (Table 1) and include estimated blood loss, blood transfusion rate, conversion to open surgery (if minimally-invasive or percutaneous), conversion to radical nephrectomy (if nephron-sparing approach initially employed), and length of stay.

Thirty-eight studies (with a total of 11,802 patients) addressed perioperative outcomes in comparative studies (see Table 39). Three studies reported perioperative outcomes for all three management strategies (radical nephrectomy, partial nephrectomy, and thermal ablation).161,162,181 No study reported outcomes for active surveillance.

Table 39 Number of studies reporting perioperative outcomes by management option

Comparison (Number of Patients) | Number of Studies
Radical Nephrectomy (4,089) versus Partial Nephrectomy (2,887) | 24 studies82,83,90,98,101-103,113-116,118-120,140,161,162,167,168,170, 173,176,181,182
Radical Nephrectomy (11103) versus Thermal Ablation (311) | 3 studies161,162,181
Partial Nephrectomy (2,008) versus Thermal Ablation (1,404) | 16 studies123,125,126,128-133,137,138,161,162,179-181

Most of the studies did not detail the perioperative period. Five studies specified a minimal followup and reported outcomes between 30 days and 82 months.98,102,140,161,180

Perioperative outcomes are summarized in Table 40. Very few studies reported comparative statistics (or p-values) among treatment groups, preventing the reporting of meaningful comparative statistics in this systematic review. Differences were considered clinically meaningful for perioperative outcomes if a reported value or proportion for one treatment modality was 100 percent greater than the contrasting modality, or if a zero value was reported for one of the treatment modalities with a percentage greater than one percent for the other treatment modality.

Table 40 Comparative perioperative outcomes for radical nephrectomy, partial nephrectomy, and thermal ablation

Outcome | No. Studies | No. Patients | Median Value | Median Range | Min Range | Max Range | No. Patients | Median Value | Median Range | Min Range | Max Range
Outcome | | Radical Nephrectomy | | | | | Partial Nephrectomy
Estimated blood loss | 17 | 2,236 | 225cc | 20-895cc | 0-100cc | 390-1900cc | 1,844 | 257cc | 60-600cc | 5-150cc | 150-3400cc
Blood transfusion rate | 13 | 1,819 | 7.3% | 0.9-27.0% | NA | NA | 1,102 | 16.3% | 0.8-43.8% | NA | NA
Conversion to open surgery | 5 | 801 | 1.0% | 0-2.9% | NA | NA | 476 | 3.5% | 0-9.1% | NA | NA
Conversion to radical nephrectomy | 2 | NA | NA | NA | NA | NA | 124 | 2.9% | 1.3-4.4% | NA | NA
Length of stay | 14 | 2,229 | 7.0 days | 1.8-9.2 days | 1-5 days | 9-32 days | 1,364 | 7.0 days | 1-9.6 days | 1-7 days | 2-19 days
| | Radical Nephrectomy | | | | | Thermal ablation
Estimated blood loss | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Blood transfusion rate | 2 | 958 | 5.8% | 5.3-9.2% | NA | NA | 230 | 6.0% | 5.3-6.6% | NA | NA
Conversion to open surgery | 2 | 568 | 1.5% | 0-2.9% | NA | NA | 100 | 0.0% | 0.0% | NA | NA
Conversion to radical nephrectomy | 0 | NA | NA | NA | NA | NA | NR | NR | NR | NA | NA
Length of stay | 2 | 958 | 5.3 days | 3.9-5.4 days | NR | NR | 230 | 3.8 days | 2.3-5.3 days | NR | NR
| | Partial Nephrectomy | | | | | Thermal Ablation
Estimated blood loss | 9 | 867 | 200cc | 94-408cc | 10-50cc | 600-4500cc | 906 | 66cc | 24-162cc | 0-10cc | 300-800cc
Blood transfusion rate | 11 | 1,338 | 4.6% | 0-16.7% | NA | NA | 967 | 0.4% | 0-9.8% | NA | NA
Conversion to open surgery | 8 | 927 | 3.6% | 0.7-8.3% | NA | NA | 560 | 0.0% | 0.0% | NA | NA
Conversion to radical nephrectomy | 2 | 139 | 3.8% | 3.3-4.3% | NA | NA | 131 | 0.0% | 0.0% | NA | NA
Length of stay | 11 | 1,245 | 3.9 days | 1.3-12.3 days | 1-1.3 days | 5-21 days | 975 | 1.8 days | 0.7-8.3 days | 0-1 days | 1-12 days

No. = number; Min = minimum; Max = maximum

Note: Differences were considered potentially clinically meaningful (highlighted in bold) if a reported value or proportion for one treatment modality was 100% greater than the other treatment modality, or if a zero value was reported for one of the treatment modalities and a percentage greater than 1% was reported for the other modality.

When compared with radical nephrectomy, partial nephrectomy had a higher blood transfusion rate and conversion to open surgery, while estimated blood loss and length of stay were similar. Only three studies reported comparative perioperative outcomes for radical nephrectomy and thermal ablation, limiting the conclusions that could be drawn from these data. 161,162,181 When compared with thermal ablation, partial nephrectomy had higher blood transfusion rates, conversions to open surgery, and conversions to radical nephrectomy, as well as longer length of hospital stay.

Meta-analyses were performed on the blood transfusion data, as a significant number of studies reported this outcome. Data were recorded in a similar fashion and the analysis provided a meaningful outcome. Meta-analyses were not performed for estimated blood loss, conversions to open surgery, conversions to radical nephrectomy, or length of stay. Blood transfusion rate was determined to be a more valuable, clinically relevant outcome measure than estimated blood loss. Conversions to open surgery or radical surgery were a low frequency occurrence, and few studies reported these outcomes reliably. Conversion to open surgery does not necessarily indicate a complication or “failure of treatment” (hence why it is not included in the harms section) and may have been in the best interest of the patient. However, the rate of conversions to open surgery is an important perioperative metric to note for minimally invasive and percutaneous surgeries. Length of hospital stay varied dramatically based on the technique used, whether minimally invasive or open technique, as well as by geographic location – the hospital stays in European centers were much longer than stays in the United States. Due to heterogeneity in the data based on a number of confounding variables, the conclusions to be drawn from a meta-analysis of length of stay were of minimal clinical significance – therefore meta-analysis was not performed.

No study evaluated predictors of perioperative outcomes.

#### Risk of Bias

We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies.35 For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI). One RCT examined perioperative outcomes with results reported in two articles 89,90 with an overall unclear risk of bias. This study had low risk of bias regarding sources of bias, selective outcome reporting, and incomplete data reporting. However, there was unclear bias regarding the assessing blinding by outcome, blinding of outcome assessors, blinding of personnel, allocation concealment, and random sequence generation. The other studies were observational in design. For those observational studies, the risk of bias was graded as moderate or severe. Bias in selection of participants and bias due to confounding were the primary sources of bias. Overall risk of bias in the included studies for perioperative outcomes was moderate to serious (Figure 26).

Figure 26 Risk of bias across noncontrolled studies investigating perioperative outcomes

Figure 26 shows the risk of bias across non-controlled studies investigating perioperative outcomes.

##### Estimated Blood Loss

###### Radical Nephrectomy Versus Partial Nephrectomy

Seventeen studies evaluated estimated blood loss with radical nephrectomy and partial nephrectomy.82,83,90,101-103,115,118-120,140,167,168,170,173,176,182 While the median estimated blood loss was similar across studies, partial nephrectomy had a higher upper boundary of estimated blood loss in many but not all of the studies.101-103,115,120,140,176 Three studies demonstrating estimated blood loss of greater than or equal to 1500 cc for partial nephrectomy also demonstrated an estimated blood loss of greater than 1000 cc for radical nephrectomy.101,115,119

###### Radical Nephrectomy Versus Thermal Ablation

No study evaluated estimated blood loss for radical nephrectomy compared with thermal ablation.

###### Partial Nephrectomy Versus Thermal Ablation

In the nine studies comparing partial nephrectomy and thermal ablation, the median estimated blood loss was lower for thermal ablation than for partial nephrectomy.125,126,129,130,132,133,137,138,179 In addition, two of these studies demonstrated excessive blood loss for partial nephrectomy with upper ranges of 3900 cc and 4500 cc, respectively.126,138

##### Blood Transfusion Rate

###### Radical Nephrectomy Versus Partial Nephrectomy

Thirteen studies reported blood transfusion rates.82,83,98,102,103,113,114,118,119,161,162,170,173 The average rate of blood transfusion was highest for partial nephrectomy compared with radical nephrectomy (16.3 percent vs. 7.3 percent, respectively). Two studies reported the number of units transfused and not the number/proportion of patients receiving blood transfusions.98,102 Neither of these studies showed a difference between units transfused for radical nephrectomy versus those transfused for partial nephrectomy (0.8 versus 1.1 units,98 0.85 (range 0–3) versus 1.7 (range 0–4) units,102 respectively].

Eleven studies contained data for meta-analysis (Figure 27). Seven of the 11 studies demonstrated a higher blood transfusion rate for partial nephrectomy, although no individual study demonstrated statistical significance. In the meta-analysis, the risk ratio for blood transfusion favored radical nephrectomy (risk ratio: 0.75; 95% CI, 0.60 to 0.94).

Figure 27 Meta-analysis of the blood transfusion rate for radical nephrectomy versus partial nephrectomy

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 27 is a meta-analysis of the blood transfusion rate for radical nephrectomy versus partial Nephrectomy.

Five studies comparing radical nephrectomy and partial nephrectomy analyzed patients by clinical stage subgroups.82,119,161,162,173 Two studies161,162 evaluated blood transfusion rates in patients with clinical stage T1a tumors (≤4 cm) with results that favored radical nephrectomy but did not reach statistical significance [risk ratio:0.79 (95% CI 0.55 to 1.12), see Appendix F]. Three studies82,119,173 evaluated blood transfusion rates in patients with clinical stage T1 tumors (≤7 cm) with results that favored radical nephrectomy but did not reach statistical significance [risk ratio:0.75 (0.33–1.75), figure in appendix F].

###### Radical Nephrectomy Versus Thermal Ablation

In the two studies comparing radical nephrectomy and thermal ablation, the median blood transfusion rate was 5.8 percent (range: 5.3 percent–9.2 percent; multiple arm study) and 6.0 percent (5.3–6.6 percent), respectively.161,162 Meta-analysis failed to demonstrate a difference in blood transfusion rates between radical nephrectomy and thermal ablation [risk ratio: 1.08 (0.63–1.87), see Figure 28].

Figure 28 Meta-analysis of the blood transfusion rate for radical nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 28 is a meta-analysis of the blood transfusion rate for radical nephrectomy versus thermal ablation.

###### Partial Nephrectomy Versus Thermal Ablation

In the 11 studies evaluating blood transfusion between partial nephrectomy and thermal ablation,125,126,128,132,133,161,179 123,131,137,162 the median average transfusion rates were 4.6 percent and. 0.4 percent, respectively – corresponding to data regarding estimated blood loss. All 11 studies were included in the meta-analysis. In 10 of the studies, blood transfusion rates were higher for patients undergoing partial nephrectomy, although no individual study demonstrated a statistically significant difference. In meta-analysis, the relative risk of blood transfusion favored thermal ablation [risk ratio:1.62 (1.07–2.46), see Figure 29)].

Figure 29 Meta-analysis showing blood transfusion rate for Partial Nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .5 was applied.

Figure 29 is a meta-analysis showing blood transfusion rate for Partial Nephrectomy versus thermal ablation.

Five studies evaluated blood transfusion rates only in patients with clinical stage T1a tumors (≤4 cm). While the meta-analysis failed to reach traditional levels of statistical significance, the blood transfusion rates also favored thermal ablation in this subgroup [risk ratio:1.50 (0.91–2.49), see Figure 30].

Figure 30 Meta-analysis showing blood transfusion rate for partial nephrectomy versus thermal ablation in patients with clinical stage T1a tumors

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .5 was applied.

Figure 30 is a meta-analysis showing blood transfusion rate for Partial Nephrectomy versus thermal ablation in patients with clinical stage T1a tumors.

##### Conversion to Open Surgery

Very few patients in 15 studies experienced conversions from laparoscopic or percutaneous surgery to open surgery.

###### Radical Nephrectomy Versus Partial Nephrectomy

Five studies compared radical nephrectomy with partial nephrectomy, and the median average conversion rates were 1.0 percent (range: 0–2.9 percent) and 3.5 percent (0–9.1 percent), respectively.118,120,162,170,181

###### Radical Nephrectomy Versus Thermal Ablation

In the two studies that compared thermal ablation with radical nephrectomy, no patients undergoing thermal ablation were converted to open surgery. In these studies, the rate of conversion to open surgery for partial nephrectomy was 3.6 percent, which is consistent with the formal comparative studies of radical nephrectomy with partial nephrectomy.

###### Partial Nephrectomy Versus Thermal Ablation

In the eight studies that compared thermal ablation with partial nephrectomy, no patients undergoing thermal ablation were converted to open surgery. In these studies, the rate of conversion to open surgery for radical nephrectomy was 1.5 percent, which is consistent with the formal comparative studies of radical nephrectomy with partial nephrectomy.

##### Conversion to Radical Nephrectomy

Very few patients in four studies converted from partial nephrectomy or thermal ablation to radical nephrectomy. The median average rate of conversion to radical nephrectomy from partial nephrectomy was 2.9 percent in two studies comparing partial nephrectomy with radical nephrectomy,119,170 and 3.8 percent in two studies comparing partial nephrectomy with thermal ablation.132,133 No study reported a conversion of thermal ablation to radical nephrectomy in the perioperative period.

##### Length of Stay

###### Radical Nephrectomy Versus Partial Nephrectomy

Fourteen studies compared length of hospital stay for radical nephrectomy with length of stay for partial nephrectomy.83,98,102,103,113,116,118-120,161,162,173,176,182 The length of stay following surgery was similar in patients in these studies (7.0 days for both).

###### Radical Nephrectomy Versus Thermal Ablation

Two studies compared length of hospital stay for radical nephrectomy with length of stay for thermal ablation.161,162 Length of stay favored thermal ablation over radical nephrectomy (3.8 days versus 5.3 days) and partial nephrectomy (1.7 days versus 3.9 days).

###### Partial Nephrectomy Versus Thermal Ablation

Twelve studies compared hospital length of stay for partial nephrectomy with length of stay for thermal ablation.126,128-130,132,133,137,138,161,162,179,180 The length of stay favored thermal ablation compared with partial nephrectomy (1.8 days versus 3.9 days).

Table 41 provides strength of evidence domains for perioperative outcomes.

Table 41 Strength of evidence domains for perioperative outcomes

Comparison | Key Outcomes | No. Studies (N) | Study limitations | Directness | Consistency | Precision | Reporting Bias | Strength of evidence Finding
Partial Nephrectomy Versus Active Surveillance | Perioperative Outcomes | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Thermal Ablation | Perioperative Outcomes | 15 (3,356) | Medium | Direct | Consistent | Precise | Undetected | Moderate Estimated blood loss, transfusion rate, rate of conversions, and length of hospital stay favored thermal ablation consistently.
Radical Nephrectomy Versus Active Surveillance | Perioperative Outcomes | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Radical Nephrectomy Versus Partial Nephrectomy | Perioperative Outcomes | 23 (6,587) RCT: 1 Retrospective: 22 | Medium RCT: low Retro: medium | Direct | Consistent | Precise | Undetected | Moderate Partial nephrectomy demonstrated consistently higher estimated blood loss and transfusion rate with similar conversion to open rate and length of hospital stay.
Radical Nephrectomy Versus Thermal Ablation | Perioperative Outcomes | 3 (11,404) | Medium | Direct | Inconsistent | Precise | Undetected | Low No study evaluated estimated blood loss. Blood transfusion rate was similar, and length of hospital stay favored thermal ablation. However, no more than two studies reported each outcome.
Thermal Ablation Versus Active Surveillance | Perioperative Outcomes | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies

#### Harms Outcomes

Harms were defined as adverse outcomes directly related to the management strategy and categorized as urological or nonurological in nature (specified in PICOTS, Table 1). While temporality was not strictly defined, harms were considered as short-term “complications” and not long-term sequelae of a given management strategy.

Forty-six cohort studies (with a total of 18,009 patients) and one RCT (reported in 2 articles) addressed harms across the different management strategies (Table 42). Six studies compared three management strategies,160-162,164,180,181 and no study reported adverse events or harms of active surveillance compared with other management strategies.

Table 42 Number of studies reporting harms outcomes by management comparison

Comparison (Number of Patients) | Number of Studies
Radical Nephrectomy (8,859) versus Partial Nephrectomy (8,106) | 32 studies82,83,90,91,94,98,102-105,111,113-116,118-120,140,160-162, 164,167,169,170,176,181-185
Radical Nephrectomy (1,581) versus Thermal Ablation (419) | 7 studies134,160-162,164,180,181
Partial Nephrectomy (2,215) versus Thermal Ablation (1,531) | 21 studies94,122-126,128-133,137,138,160-162,164,179-181

Harms were evaluated as urologic and nonurologic complications. However, inconsistencies in data collection and reporting across studies prevented the estimation of overall urologic and nonurologic complications. For instance, the same specific complications were not reported among all studies and, as a result, overall complication rates could not be calculated without assuming zero complication rates for a number of studies. In addition, a single patient could experience more than one complication, and studies were inconsistent about reporting rates of multiple complications per patient. Differences were considered clinically meaningful differences for comparative harms if a reported value or proportion for one treatment modality was 100 percent greater than the contrasting modality, or if a zero value was encountered in one of the treatment modalities, and a proportion greater than one percent was present in the other modality. Clinically meaningful differences in specific urologic and nonurologic complications are detailed in the text that follows.

Meta-analyses were performed for major and minor complications between treatment strategies. A meta-analysis was also performed for acute kidney injury, as this specific urologic complication was reported almost uniformly across studies and has implications for renal functional outcomes (see the Renal Functional Outcomes section of this report). Inconsistencies in reporting of specific urologic and nonurologic complications prevented meta-analyses of specific complications, other than acute kidney injury and composite urologic or nonurologic complications.

A number of studies examined management strategy and a number of additional variables as predictors of harms. These findings are summarized in the sections below (see Tables 42 and 43).

Table 43 Harms in comparative studies of radical nephrectomy and partial nephrectomy

Complication Type | Harm | No. Studies | Radical Nephrectomy | | | | Partial Nephrectomy
Complication Type | Harm | No. Studies | Patients w/ Event | Total Patients | Median % | % Range | Patients w/ Event | Total Patients | Median % | % Range
Urologic Complications | Renal abscess | 1 | 0 | 28 | 0.0% | 0% | 1 | 52 | 1.9% | 1.90%
Urologic Complications | Acute kidney injury | 17 | 569 | 5,245 | 1.6% | 0-70.1% | 277 | 5,249 | 1.4% | 0-24.3%
Urologic Complications | Bleeding (w or w/out transfusion) | 18 | 110 | 2,787 | 1.9% | 0-38.7% | 128 | 2,458 | 3.7% | 0-26.7%
Urologic Complications | Intraoperative injury | 4 | 8 | 393 | 1.9% | 0-5.7% | 7 | 382 | 0% | 0-10.7%
Urologic Complications | Subsequent intervention | 1 | 0 | 940 | 0.0% | 0% | 12 | 490 | 1.9% | 0-3.8%
Urologic Complications | Ureteral injury | 3 | 8 | 895 | 0.0% | 0-1.3% | 10 | 291 | 0.6% | 0-16.1%
Urologic Complications | Urinary tract infection | 1 | 3 | 307 | 0.3% | 0-0.6% | 1 | 229 | 0.3% | 0-0.5%
Urologic Complications | Urine leak | 15 | 17 | 1,723 | 0.0% | 0-9.1% | 77 | 2,141 | 2.8% | 0-20.5%
Urologic Complications | Other urologic complications | 4 | 6 | 1,715 | 0.6% | 0-13.0% | 2 | 1,613 | 1.6% | 0-20.0%
Non-urologic Complications | Cardiovascular | 16 | 134 | 3,506 | 1.9% | 0-42.2% | 91 | 3,162 | 3.0% | 0-11.1%
Non-urologic Complications | Gastrointestinal | 12 | 266 | 2,489 | 2.0% | 0-23.1% | 215 | 2,615 | 2.2% | 0-14.3
Non-urologic Complications | Hematologic | 9 | 24 | 2,262 | 0.2% | 0-5.1% | 27 | 2,485 | 0% | 0-4.8%
Non-urologic Complications | Infectious disease | 8 | 177 | 2,273 | 1.9% | 0-18.0% | 194 | 2,364 | 1.1 | 0-15.0%
Non-urologic Complications | Neurologic | 8 | 12 | 1,986 | 0.2% | 0-5.7% | 12 | 580 | 0% | 0-9.7%
Non-urologic Complications | Respiratory | 16 | 432 | 3,633 | 1.1 | 0-45.5% | 361 | 3,202 | 2.4% | 0-28.8
Non-urologic Complications | Wound complications | 11 | 60 | 3,020 | 1.4% | 0-4.2% | 42 | 2,214 | 0.8% | 0-4.9%
Complication Severity | Minor (Clavien I-II) | 7 | 329 | 1,774 | 18.7% | 11-31.5% | 308 | 1,667 | 24.1% | 13.4-43.6%
Complication Severity | Major (Clavien III-IV) | 7 | 56 | 1,774 | 2.8% | 1.0-8.6% | 89 | 1,667 | 5.9% | 0-6.2%
Complication Severity | Death | 3 | 4 | 1,519 | 0% | 0-0.5% | 0 | 1,436 | 0.0% | 0%

Note: Differences were considered potentially clinically meaningful (highlighted in bold) if a reported value or proportion for one treatment modality was 100 percent greater than the other treatment modality, or if a zero value was reported for one of the treatment modalities and a percentage greater than 1 percent was reported for the other modality.

Most studies referenced a perioperative time when evaluating harms, but did not reference a specific followup time. However, in the six studies that included a followup period, the length of followup ranged from 30 days to 3 years.94,102,130,137,161,183

#### Risk of Bias

We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies.35 For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 One RCT examined harms, with reports in two articles89,90 with an overall unclear risk of bias. This study had low risk of bias regarding sources of bias, selective outcome reporting, and incomplete data reporting. However, there was unclear bias regarding the assessing blinding by outcome, blinding of outcome assessors, blinding of personnel, allocation concealment and random sequence generation. The remainder of the studies were observational in design. For those observational studies, the risk of bias was graded as moderate or severe. Bias in selection of participants and bias due to confounding were the primary sources of bias. The overall risk of bias in studies on perioperative outcomes are detailed in Figure 31.

Figure 31 Risk of bias across studies investigating harms

Figure 31 shows the risk of bias across studies investigating perioperative outcomes.

##### Radical Nephrectomy Versus Partial Nephrectomy

Thirty-two comparative studies (including a total of 16,965 patients) compared the harms of radical nephrectomy with those of partial nephrectomy. The only RCT comparing radical nephrectomy with partial nephrectomy demonstrated a slightly higher rate of severe bleeding in patients undergoing partial nephrectomy (3.1 percent versus 1.2 percent respectively), higher rates of urinary fistula (i.e. urinary leak; 4.4 percent versus 0 percent respectively) and re-operative complications (4.4 percent versus 2.4 percent respectively) for partial nephrectomy. Rates of pleural damage (11.5 percent versus 9.3 percent respectively) and splenic injuries (0.4 percent versus 0.4 percent respectively) were similar among groups. Comparative statistics were not provided in the study reports.90,91

While overall rates of urologic and nonurologic complications were similar between radical nephrectomy and partial nephrectomy, a number of meaningful differences were observed. Rates of specific urologic complications including renal abscess, subsequent intervention, ureteral injury, urine leak, and other urological complications were higher for partial nephrectomy; rates of respiratory complications and major Clavien complications were higher for partial nephrectomy. Twelve studies reported rates of acute kidney injury.82,83,94,98,105,119,161,164,169,182-184 Of note, definitions of acute kidney injury varied by study and no attempt to reconcile differences among studies was undertaken. The meta-analysis in this section reflects the author's definition of acute kidney injury from each study. No differences were observed between studies comparing radical nephrectomy and partial nephrectomy [risk ratio: 1.3 (0.9–2.0) see Figure 32]. The strength of evidence was low.

Figure 32 Meta-analysis of the incidence of acute kidney injury after radical nephrectomy versus partial nephrectomy

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .5 was applied.

Figure 32 is a meta-analysis of the incidence of acute kidney injury after radical nephrectomy versus partial nephrectomy.

Four studies reported rates of acute kidney injury in patients with clinical stage T1a tumors82,161,164,169 and found that rates of acute kidney injury were higher in patients undergoing radical nephrectomy (RR 1.37 with 95% CI 1.13 to 1.66) (see Figure 33). This relationship was not observed in the three studies that only evaluated clinical stage T1 tumors (risk ratio 0.87 with 95% CI 0.29 to 2.63).105,119,183 Excluding studies with only cT1a patients, no differences were observed between studies comparing radical nephrectomy and partial nephrectomy (RR: 1.18 with 95% CI 0.29 to 4.83) [see appendix F].

Figure 33 Meta-analysis of the incidence of acute kidney injury after radical nephrectomy versus partial nephrectomy in patients with clinical stage T1a tumors

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .1 was applied.

Figure 33 is a meta-analysis of the incidence of acute kidney injury after radical nephrectomy versus partial nephrectomy in patients with clinical stage T1a tumors.

#### Minor and Major Complications

Seven studies evaluated minor and major operative complications.114,120,167,170,182,184,185 Rates of minor complications (Clavien I-II) were similar between radical nephrectomy and partial nephrectomy, as confirmed in meta-analysis (Figure 34). Two studies114,184 evaluated complications in patients with clinical stage T1b or greater tumors (≥ 4 cm), and two studies120,167 evaluated complications in patients with clinical stage T1 tumors (≤ 7 cm). Neither subgroup analysis demonstrated a difference in rates of minor complications (RR 1.02 with 95% CI 0.76 to 1.31, and RR 0.28 with 95% CI 0.02 to 3.31, respectively) [see Appendix F].

Figure 34 Meta-analysis of the incidence of minor Clavien complications associated with radical nephrectomy versus partial nephrectomy

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 34 is a meta-analysis of the incidence of minor Clavien complications associated with radical nephrectomy versus partial nephrectomy.

In these seven studies, major complications (Clavien III-IV) occurred in a median of 2.8 percent of patients undergoing radical nephrectomy and 5.9 percent of patients undergoing partial nephrectomy (Table 43). In meta-analysis, the rate of major complications favored partial nephrectomy, however it did not reach traditional levels of statistical significance (RR 0.71 with 95% CI 0.49 to 1.05; see Figure 35). Rates of major complications in the two studies of patients with clinical stage T1b tumors114,184 were not significantly different between radical and partial nephrectomy (RR 1.22 with 95% CI 0.65 to 2.28; see Appendix F]. While traditional levels of statistical significance were not met, meta-analysis of the two studies of patients with clinical stage 1 tumors,120,167 indicated that rates of major complications may favor radical nephrectomy (RR 0.52 with 95% CI 0.24 to 1.14; see Appendix F).

Figure 35 Meta-analysis of the incidence of major Clavien complications associated with radical nephrectomy versus partial nephrectomy

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 35 is a meta-analysis of the incidence of major Clavien complications associated with radical nephrectomy versus partial nephrectomy.

##### Radical Nephrectomy Versus Thermal Ablation

Seven studies (with a total of 2,000 patients) compared the harms of radical nephrectomy with the harms of thermal ablation.134,160-162,164,180,181 When considering urologic complications, the rate of acute kidney injury for radical nephrectomy and thermal ablation were 11.7 percent and 0 percent respectively. In addition, bleeding rates (including hematuria and hemorrhage) for radical nephrectomy and thermal ablation were zero percent and 3.7 percent respectively. In the one study reporting rate of urine leak, no patient undergoing radical nephrectomy and only one patient (3.7 percent) undergoing thermal ablation experienced a urine leak.180 Non-urologic complications, including cardiovascular, gastrointestinal, respiratory and wound complications, were lower for thermal ablation. Median rates of respiratory complications were 10.2 percent for radical nephrectomy and 4.0 percent for thermal ablation, while rates of cardiovascular, gastrointestinal, and wound complications were zero for thermal ablation.

Three studies134,161,164 reported rates of acute kidney injury, showing that the rates were lower for thermal ablation but did not reach traditional levels of statistical significance (risk ratio 1.6 with 95% CI 0.9 to 2.80; see Figure 36]. The strength of evidence was low.

Figure 36 Meta-analysis of the incidence of acute kidney injury associated with radical nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .5 was applied.

Figure 36 is a meta-analysis of the incidence of acute kidney injury associated with radical nephrectomy versus thermal ablation.

Only one study addressed minor and major procedural complications;134 and therefore a meta-analysis was not performed. While major complication (Clavien III-IV) rates were similar in patients undergoing radical nephrectomy and thermal ablation, rates of minor complications (Clavien I-II) were 16.0 percent for thermal ablation and 2.6 percent for radical nephrectomy. No comparative study reported deaths after radical nephrectomy or thermal ablation (see Table 44).

Table 44 Harms in comparative studies of radical nephrectomy and thermal ablation

Complication Type | Harm | No. Studies | Radical Nephrectomy | | | | Thermal Ablation
Complication Type | Harm | No. Studies | Patients w/ Event | Total Patients | Median % | % Range | Patients w/ Event | Total Patients | Median % | % Range
Urologic Complications | Acute kidney injury | 4 | 113 | 1,009 | 11.7% | 2.6-12.8% | 12 | 241 | 0% | 0-5.8%
Urologic Complications | Bleeding (w or w/out transfusion) | 4 | 4 | 132 | 0 | 0-4% | 8 | 135 | 3.7% | 0-28.5%
Urologic Complications | Intraoperative injury | 1 | 1 | 19 | 5.3% | 5.3% | 1 | 19 | 5.3% | 5.3%
Urologic Complications | Subsequent intervention | 1 | 0 | 939 | 0.0% | 0% | 0 | 211 | 0.0% | 0.0%
Urologic Complications | Urine leak | 1 | 0 | 52 | 0.0% | 0% | 1 | 27 | 3.7% | 3.7%
Nonurologic Complications | Cardiovascular | 2 | 13 | 991 | 2.5% | 1.9-3.0% | 0 | 211 | 0.0% | 0.0%
Nonurologic Complications | Gastrointestinal | 1 | 1 | 39 | 2.6% | 2.6% | 0 | 21 | 0.0% | 0.0%
Nonurologic Complications | Respiratory | 2 | 210 | 1,032 | 10.2% | 0-25.1% | 28 | 283 | 4% | 0-12.8%
Nonurologic Complications | Wound complications | 1 | 14 | 939 | 1.7% | 0-3.4% | 0 | 211 | 0.0% | 0.0%
Complication Severity | Minor (Clavien I-II) | 1 | 1 | 39 | 2.6% | 2.6% | 4 | 21 | 16.0% | 16.0%
Complication Severity | Major (Clavien III-IV) | 1 | 2 | 39 | 5.1% | 5.1% | 2 | 21 | 8.0% | 8.0%
Complication Severity | Death | NR | NR | NR | NR | NR | NR | NR | NR | NR

Note: Differences were considered potentially clinically meaningful (highlighted in bold) if a reported value or proportion for one treatment modality was 100% greater than the other treatment modality, or if a zero value was reported for one of the treatment modalities and a percentage greater than 1% was reported for the other modality.

##### Partial Nephrectomy Versus Thermal Ablation

Twenty-one studies (including a total of 3,746 patients) compared the harms of partial nephrectomy with the harms of thermal ablation. Median rates of harms were similarly low between partial nephrectomy and thermal ablation, with the exception of other urological complications, which in one study138 were 25 percent for partial nephrectomy and 5.9 percent for thermal ablation. Rates of acute kidney injury (2.1 versus 0 percent respectively), intraoperative injuries (9.4 versus 3.2 percent respectively), and urine leak (2.6 versus 0 percent respectively) favored thermal ablation in these studies. Rates of ureteral injury were higher in thermal ablation (1.8 versus 0 percent respectively) – albeit a small sample size. In addition, loss of kidney (0 versus 2.6 percent respectively) and urinary tract infection (0 versus 2 percent respectively) favored partial nephrectomy (Table 45).

Table 45 Harms in comparative studies of partial nephrectomy and thermal ablation

Complication Type | Harm | No. Studies | Partial Nephrectomy | | | | Thermal Ablation
Complication Type | Harm | No. Studies | Patients w/ Event | Total Patients | Median % | % Range | Patients w/ Event | Total Patients | Median % | % Range
Urologic Complications | Renal Abscess | 1 | 1 | 153 | 0.7% | 0.7% | 0 | 78 | 0.0% | 0.00%
Urologic Complications | Acute kidney injury | 7 | 87 | 1,116 | 2.1% | 0-24.3% | 13 | 623 | 0.0% | 0-5.8%
Urologic Complications | Bleeding (w or w/out transfusion) | 11 | 39 | 865 | 2.4% | 0-14.5% | 21 | 625 | 2.4% | 0-9.8%
Urologic Complications | Intraoperative injury | 2 | 11 | 128 | 9.4% | 8-10.7% | 1 | 117 | 3.2% | 0-5.3%
Urologic Complications | Loss of kidney | 1 | 0 | 50 | 0.0% | 0.0% | 1 | 38 | 2.6% | 2.6%
Urologic Complications | Subsequent intervention | 3 | 19 | 743 | 3.5% | 0-6.0% | 4 | 392 | 2.5% | 0-3.7%
Urologic Complications | Ureteral injury | 5 | 3 | 312 | 0.7% | 0-2.1% | 3 | 243 | 1.8% | 0-2.6%
Urologic Complications | Urinary tract infection | 1 | 0 | 51 | 0.0% | 0.0% | 1 | 51 | 2.0% | 2.0%
Urologic Complications | Urine leak | 8 | 12 | 624 | 2.6% | 0-4.2% | 2 | 508 | 0.0% | 0-3.7%
Urologic Complications | Other urologic complications | 1 | 9 | 36 | 25.0% | 25.0% | 4 | 65 | 5.9% | 3.4-8.3%
Nonurologic Complications | Cardiovascular | 5 | 7 | 957 | 2.0% | 0.9-3.0% | 2 | 586 | 0.0% | 0-0.7%
Nonurologic Complications | Gastrointestinal | 5 | 7 | 548 | 1.3% | 0-3.0% | 7 | 460 | 1.3% | 1.1-5.0%
Nonurologic Complications | Hematologic | 6 | 13 | 543 | 3.4% | 0.9-6.3% | 3 | 480 | 0.0% | 0-3.7%
Nonurologic Complications | Infectious disease | 4 | 0 | 119 | 0.0% | 0.0% | 2 | 178 | 0.9% | 0-3.3%
Nonurologic Complications | Respiratory | 9 | 137 | 1,145 | 3.3% | 0-28.8% | 33 | 793 | 0.2% | 0-12.8%
Nonurologic Complications | Wound complications | 5 | 16 | 778 | 0.0% | 0-3.7% | 3 | 436 | 1.9% | 0-2.5%
Complication Severity | Minor (Clavien I-II) | 9 | 48 | 663 | 11.0% | 0-12.0% | 37 | 375 | 6.9% | 1.1-23.5%
Complication Severity | Major (Clavien III-IV) | 9 | 19 | 612 | 3.9% | 1.1-6.9% | 15 | 632 | 3.0% | 1.3-11.1%
Complication Severity | Death | NR | NR | NR | NR | NR | NR | NR | NR | NR

Note: Differences were considered potentially clinically meaningful (highlighted in bold) if a reported value or proportion for one treatment modality was 100% greater than the other treatment modality, or if a zero value was reported for one of the treatment modalities and a percentage greater than 1% was reported for the other modality.

When considering nonurologic complications, cardiovascular, hematologic, and respiratory complications were higher for patients undergoing partial nephrectomy, while patients undergoing thermal ablation had higher rates of infection and wound complications.

While a crude evaluation of acute kidney injury indicated higher rates for patients undergoing partial nephrectomy (2.1 versus 0 percent respectively), in a meta-analysis of six studies reporting rates of acute kidney injury,123,125,137,138,161,164 no difference was observed (risk ratio 1.0 with 95% CI 0.6 to 1.9; see Figure 37). The strength of evidenc was low (Table 46).

Figure 37 Meta-analysis of the incidence of acute kidney injury associated with partial nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

* Correction factor of .5 was applied.

Figure 37 is a meta-analysis of the incidence of acute kidney injury associated with partial nephrectomy versus thermal ablation.

Table 46 Strength of evidence domains for comparative studies of harms

Comparison | Key Outcomes | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Partial Nephrectomy Versus Active Surveillance | Harms | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Partial Nephrectomy Versus Thermal Ablation | Harms | 21 (3,746) | Medium | Direct | Inconsistent | Imprecise | Undetected | Low Rates of harms (specifically urologic, nonurologic, minor and major) varied significantly among studies. Some urologic and nonurologic complications occurred less often after partial nephrectomy and other urologic and nonurologic complications occurred less often after thermal ablation, but the rate of acute kidney injury and the rate of minor or major Clavien complications did not differ between partial nephrectomy and thermal ablation.
Radical Nephrectomy Versus Active Surveillance | Harms | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies
Radical Nephrectomy Versus Partial Nephrectomy | Harms | 32 (16,965) RCT: 1 Retrospective: 31 | Medium RCT: low Retro: medium | Direct | Inconsistent | Imprecise | Undetected | Low The only RCT in this literature demonstrates higher rates of urologic complications in patients undergoing partial nephrectomy. This is corroborated by the retrospective data. However, rates of harms were modest among studies. The rate of acute kidney injury did not differ between radical and partial nephrectomy, but the rate of major Clavien complications was higher with partial nephrectomy than with radical nephrectomy. Non-urologic complications did not differ between radical and partial nephrectomy.
Radical Nephrectomy Versus Thermal Ablation | Harms | 7 (2,000) | Medium | Direct | Inconsistent | Imprecise | Undetected | Low Harms were inconsistently reported among the four studies, making it difficult to draw conclusions about the differences that were observed in specific urologic or nonurologic complications. The rate of acute kidney injury did not differ significantly between radical nephrectomy and thermal ablation, but the data were insufficient to rule out a clinically important increased risk with radical nephrectomy. Minor and major Clavien complications were only reported in one study.
Thermal Ablation Versus Active Surveillance | Harms | 0 (0) | NA | NA | NA | NA | NA | Insufficient No eligible studies

Rates of minor and major complications were similar in the nine studies comparing partial nephrectomy and thermal ablation (Figures 38 and 39). Four studies123,129,133,164 evaluated minor and major complications only in patients with clinical stage T1a tumors; in meta-analyses, there were no differences in rates of minor (risk ratio 1.48 with 95% CI 0.90 to 2.45; see Appendix) or major complications (risk ratio 0.91 with 95% CI 0.40 to 2.09; see Appendix F). There were no reported deaths in any of the studies comparing partial nephrectomy with thermal ablation.

Figure 38 Meta-analysis of the incidence of minor Clavien complications associated with partial nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure 38 is a meta-analysis of the incidence of minor Clavien complications associated with partial nephrectomy versus thermal ablation.

Figure 39 Meta-analysis of the incidence of major Clavien complications associated with partial nephrectomy versus thermal ablation

N = number; RN = radical nephrectomy; PN = partial nephrectomy; TA = thermal ablation; RR = risk ratio

Note: The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

* Correction factor of .5 was applied.

Figure 39 is a meta-analysis of the incidence of major Clavien complications associated with partial nephrectomy versus thermal ablation.

### Uncontrolled Studies

#### Active Surveillance

Two studies evaluated surgical treatment and active surveillance in comparative studies. The first compared radical nephrectomy and active surveillance – the results were discussed previously in the KQ3a “Oncologic Outcomes” section.135 The second study compared active surveillance to “primary intervention,” a composite group of patients undergoing radical nephrectomy, partial nephrectomy and thermal ablation.85 As the outcomes of each surgical management strategies could not be distinguished, the study was considered uncontrolled. However, two additional reports from this study reported comparative renal functional outcomes for each management strategy.165,186 This comparative analysis is included in the renal functional outcomes section of KQ3a and not discussed in this section. In addition, three studies evaluated nonsurgical management in a SEER-Medicare cohort (The important distinction between active surveillance and nonsurgical management was previously described in the KQ3a “Oncologic Outcomes” section).147-149 Therefore, due to a paucity of data regarding active surveillance, uncontrolled studies were included for analysis. To prevent the inclusion of small case series and series with immature oncologic followup, only studies with greater than fifty patients and at least two years of followup were included. In addition, by only including studies with 50 patients and two years of followup, outcomes could be evaluated in comparison to the outcomes of surgical series.

##### Study Characteristics

Eight studies were analyzed.84-88,187-189 Three of these studies came from the same institution, Fox Chase Cancer Center (Philadelphia, Pennsylvania), and its institutional database.86,87,189 Only one study was used to consider study and population characteristics, as well as oncologic outcomes, as it was the most recent and largest iteration of this analysis.86 However, the data reported were significantly different between studies and warranted inclusion of data from all three studies. Five studies were single-institution, retrospective cohort studies of active surveillance cohorts.86-88,188,189 One was defined as a multicenter, prospective phase 2 clinical trial84 and one was a prospective, multicenter registry.85 One was a retrospective, population-based analysis of the TUCAN (Tayside Urologic Cancers Network) Registry of Scotland. 187 Seven studies were performed in North America; the multicenter, prospective phase 2 study was performed in Canada, and the rest originated in the United States (Table 47).

Table 47 Study characteristics of uncontrolled studies of active surveillance for clinically localized renal masses suspicious of malignancy

Author, Year | Study Design | Location | Start Year | No. Patients | Mean/Median Followup
Leonard, 2013^187^ | Retrospective, population-based registry | Europe (Scotland) | 2007 | 133 | 28/NR months
Jewett, 2011^84^ | Prospective, multicenter phase 2 trial | North America (Canada) | 2004 | 178 | 12/NR months
Rosales, 2010^188^ | Retrospective, single-institution cohort | North America (US) | 1993 | 212 | 35/NR months
Crispen, 2009^86^ | Retrospective, single-institution cohort | North America (US) | 2000 | 173 | 31/24 months
Crispen, 2008^87^ a | Retrospective, single-institution cohort | North America (US) | 2000 | 109 | NR/26 months
Abouassaly, 2008^189^ | Retrospective, single-institution cohort | North America (US) | 2000 | 110 | NR/24 months
Kunkle, 2007^88,a^ | Retrospective, single-institution cohort | North America (US) | NR | 89 | NR/29 months
Pierorazio, 2015 85 | Prospective, multi-institution registry | North America (US) | 2009 | 223 | NR/25 months

NR=not reported

a Earlier iterations of the same cohort were described in86

##### Population Characteristics

The mean or median age ranged from 69 to 81 years, with the median age being 71 years. Of the three studies reporting gender, women made up 28, 45 and 48 percent, respectively.85,86,188 Comorbidity conditions were rarely reported; one study reported 84 percent of participants as hypertensive,188 and one reported a mean baseline creatinine level of 1.2 mg/dl (range 0.5–5.0 mg/dL).189 The same study189 reported a Charlson comorbidity index of 0, 1, 2, and 3 and greater than or equal to 3 in 15, 18, 30, 19 and 33 percent, respectively. The prospective DISSRM Registry reported comprehensive demographic and comorbidity data: 75 percent were Caucasian, median body mass index was 28.8 kg/m2, and 91 percent of tumors were incidentally discovered. Common comorbidities included hypertension (67 percent), a history of tobacco smoking (35 percent), diabetes mellitus (27 percent), and history of myocardial infarction (10 percent) or peripheral vascular disease (7 percent). The Charlson comorbidity index was 0, 1-3 and ≥4 in 39, 51 and 10 percent of patients respectively; Eastern Cooperative Oncology Group Performance Status was 0, 1 and 2-4 in 69, 23 and 8 percent respectively; 48 percent of patients had a history of cardiovascular disease, of which 21 percent had congestive heart failure or more than one cardiovascular disease.85 Patients with solitary kidneys were included in three studies, and ranged from 1 to 14 percent of the cohort (Table 48).88,188,189

Table 48 Population characteristics of uncontrolled studies of active surveillance for clinically localized renal masses suspicious of malignancy

Author, Year | Women, % | Age Mean/Median | Age Range | Tumor Size Mean/Median | Tumor Size Range
Leonard, 2013^187^ | NR | 70.6/NR years | NR | 2.36/NR cm | 0.6-4
Jewett, 2011^84^ | NR | NR/74 years | 41-96 | 2.1/2.1 cm | 0.4-4
Rosales, 2010^188^ | 45 | NR/71 years | 50-92 | NR/2.8 cm | 0.5-13.1
Crispen, 2009^86^ | 28 | 69/71 years | 35-88 | 2.45/2 cm | 0.4-12
Crispen, 2008^87,a^ | 28 | 69.8/73 years | 35-87 | 2.61/2 cm | 0.4-12
Abouassaly, 2008^189^ | NR | NR/81 years | 76-79 | NR/2.5 cm | 0.9-11.2
Kunkle, 2007^88,a^ | 27 | NR/71.5 years | 35-87 | NR/2 cm | 0.0-12
Pierorazio, 2015 85 | 47.5 | NR/70.6 years | 34-93 | NR/1.9 cm | 0.4-7.7

NR = not reported

a Earlier iterations of the same cohort described in86

All eight studies included only patients with clinically localized renal tumors. The multicenter, prospective phase 2 clinical trial84, DISSRM Registry 85 and population-based registry187 included only patients with clinical stage T1a tumors (less than or equal to 4 cm). The median size of the tumors was 2 cm and ranged from sub-centimeter to 13 cm. Bilateral tumors were reported in two percent of patients in one study188 and 4.7 percent of patients in DISSRM; 85 multiple tumors were reported between 12 percent and 20 percent of three studies, respectively.85,88,189

While the DISSRM Registry is considered an uncontrolled study in this systematic review, active surveillance patients were enrolled contemporaneously with patients undergoing primary intervention (radical nephrectomy, partial nephrectomy and thermal ablation). Patients electing active surveillance were, in general, older (71 versus 62 years, P<0.001), had more comorbidities when considering Eastern Cooperative Oncology Group Performance Status, Charlson Comorbidity Index or individual comorbidities (congestive heart failure, diabetes mellitus, cardiovascular disease); and had smaller tumors (1.9 versus 2.5 cm, P=0.001).Three studies reported pathologic tumor findings at enrollment.84,85,188 The multicenter, prospective phase 2 clinical trial84 biopsied 99 of 178 patients (finding101 masses) at enrollment. Malignancy (i.e., renal cell carcinoma) was confirmed in 56 patients (55 percent); 12 masses (12 percent) were benign and 33 (33 percent) were nondiagnostic. In an additional study,188 40 patients (19 percent) underwent biopsies: of those, 32 (80 percent) were determined to be clear-cell renal cell carcinoma, 4 (10 percent) were papillary renal cell carcinoma, and 1 (2.5 percent) was chromophobe renal cell carcinoma; there were benign masses in 2 patients, (5 percent) and 1 mass (2.5 percent) was undetermined. Thirty-one patients in the DISSRM Registry underwent renal biopsy: 4 percent of primary intervention patients and 9 percent of active surveillance patients.85 Of patients undergoing active surveillance, 30 percent of biopsies demonstrated renal cell carcinoma, 43 percent were oncocytoma/oncocytic cells, and 24 percent were nondiagnostic.

##### Intervention Characteristics

The multicenter, prospective phase 2 clinical trial active surveillance protocol included clinical T1a tumor detection by imaging and baseline chest x-ray (to evaluate for pulmonary metastases). 84 All patients were offered percutaneous renal biopsies, as well as serial imaging with computed tomography, MRI, or ultrasound at their 3- and 6-month followup, then every six months until three years, and then annually. No study endpoint was specified.

The DISSRM Registry included patients with cT1a tumors detected or confirmed with axial imaging. The surveillance protocol includes serial imaging every 4 to 6 months for two years, followed by annual imaging thereafter. Ultrasound is the preferred surveillance modality in DISSRM. Chest x-ray and laboratory tests (complete blood count, complete metabolic panel) were obtained annually. Percutaneous renal biopsy was offered to all patients, but only 6.4 percent of patients enrolled in the registry elected biopsy (biopsy results discussed above).85

Three retrospective cohort studies from Fox Chase Cancer Center stated that regular radiographic followup was performed at 3- to 6-month intervals, metastatic surveillance was performed annually (chest x-ray, hepatic function tests, and bone scan in symptomatic patients), and percutaneous renal biopsy was not routinely offered.86-88 One study stated only that patients were followed every 6 months with imaging.189 Two studies did not specify a protocol for active surveillance.187,188

##### Risk of Bias

We used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 For uncontrolled studies of active surveillance, the risk of bias was graded as moderate or serious. Bias in selection of participants and bias due to confounding were the primary sources of bias (Figure 40).

Figure 40 Risk of bias across noncontrolled studies investigating active surveillance

Figure 40 shows the risk of bias across non-controlled studies investigating active surveillance.

##### Final Health Outcomes

###### Oncologic Efficacy

Of the 1,029 patients in the six included studies,84-86,187-189 three died of renal cell carcinoma, eight developed metastases, and 72 died of any cause The rate of cancer-specific survival in this population ranged from 98.9 percent to 100 percent, the rate of metastasis-free survival ranged from 98.1 percent to 100 percent, and the rate of overall survival ranged from 69 percent to 94.4 percent at 12 to 35 months (Table 49). The DISSRM Registry was the only study to report actuarial survival rates.85 Overall survival in patients undergoing active surveillance and primary intervention in the DISSRM Registry were 98 percent and 96 percent at 2 years, and 92 percent and 75 percent at 5 years, respectively (log rank, p = 0.06); cancer-specific survival was 99 percent and 100 percent at 5 years, respectively (p = 0.3). In regression modeling, active surveillance was not associated with an increased risk of all-cause mortality while age and cardiovascular comorbidity were.

Table 49 Oncologic and survival outcomes of uncontrolled studies of active surveillance for clinically localized renal masses suspicious of malignancy

Survival Outcome | Category | Leonard, 2013^187^ | Jewett, 2011^84^ | Rosales, 2010^188^ | Crispen, 2009^86^ | Abouassaly, 2008^189^ | Pierorazio, 2015 85
Cancer-Specific Survival | Patients (events) | NR | 178 (2) | 212 (1) | 173 (0) | 110 (0) | 223 (0)
Cancer-Specific Survival | Rate | NR | 98.9% | 99.5% | 100% | 100% | 100%
Cancer-Specific Survival | Time | NR | >12 months (mean) | 35 months (median) | 24 months (median) | 24 months (median) | 25 months (median) / 60 months (max)
Metastases-Free Survival | Patients (events) | 133 (1) | 178 (0) | 212 (4) | 173 (1) | 110 (2) | 223 (0)
Metastases-Free Survival | Rate | 99.20% | 100% | 98.10% | 99.40% | 98.20% | 100%
Metastases-Free Survival | Time | 27.86 months (mean) | >12 months (mean) | 35 months (median) | 31 months (mean) | 24 months (median) | 25 months (median) / 60 months (max)
Overall Survival | Patients (events) | NR | 178 (10) | 212 (15) | NR | 1104) | 223 (13)
Overall Survival | Rate | NR | 94.40% | 93% | NR | 69% | 96% at 25 months, 75% at 60 months
Overall Survival | Time | NR | >12 months (mean) | 35 months (median) | NR | 24 months (median) | 25 months (median) / 60 months (max)

NR = not reported

###### Renal Functional Outcomes

Renal functional outcomes were not reported in any of the studies. Comparative renal functional outcomes from the DISSRM Registry are reported in KQ3a. In brief, patients undergoing active surveillance had small but significant decreases in estimated glomerular filtration rate (of approximately -0.55 ml/min/1.73 m^2^) during active surveillance. Approximately 3 percent of patients who did not have chronic kidney disease at the time of enrollment developed chronic kidney disease during active surveillance (Table 50).165,186

Table 50 Strength of evidence domains for uncontrolled studies of active surveillance

Key Outcomes | No. Studies (N) | Study limitation | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Cancer-specific survival | 5 896) | Medium | Direct | Consistent | Precise | Undetected | Low While two studies are prospective in nature, all studies are subject to selection bias. All retrospective studies are subject to selection and recall bias. All studies have relatively short oncologic followup (12-35 months); and oncologic outcomes include a combination of benign and malignant lesions as renal mass biopsy is not uniformly utilized.
Metastases-free survival | 5 (806) | Medium | Direct | Consistent | Precise | Undetected | Low (see above)
Local recurrence-free survival | Not applicable for active surveillance | NA | NA | NA | NA | NA | Insufficient
Overall survival | 4 (723) | Medium | Direct | Consistent | Precise | Undetected | Low (see above)
Renal Functional Outcomes | Not reported | NA | NA | NA | NA | NA | Insufficient
Quality of Life | 1 (264) | Medium | Direct | Unknown | Precise | NA | Insufficient Only one study addresses quality of life and this is a watchful waiting cohort, not technically active surveillance with a regimented surveillance protocol.
Perioperative Outcomes and Harms | Not reported | NA | NA | NA | NA | NA | Insufficient

###### Quality of Life

One uncontrolled study evaluated HRQOL in an active surveillance cohort.190 Technically, the cohort was a “watchful waiting” cohort, which meant that the surveillance protocol was not well-defined (i.e., the use of specific imaging modalities was not specified nor was the timing of serial imaging). However, validated questionnaires (Mishel Uncertainty in Illness Study [MUIS], Medical Outcomes Study 36-item short-form, Cancer Rehabilitation Evaluation System Short-form, and Impact of Events Scale [IES]) were collected in a prospective fashion at enrollment, as well as at 6, 12, and 24 months.

The study found that greater illness uncertainty (mean total MUIS) was associated with poor general HRQOL, especially in physical and medical domains, and it was associated with higher distress. However, the study also found that intrusive thoughts and avoidance behaviors (IES) decreased over the 24-month period. As this study was noncomparative in design, the researchers were not able to demonstrate that active surveillance (watchful waiting) was associated with greater illness uncertainty or adverse HRQOL outcomes. Therefore, the implications of the HRQOL findings in this analysis are uncertain.

###### Harms and Perioperative Outcomes

Harms and perioperative outcomes were not reported in any of the studies. Twenty-one patients (9.4 percent) initially electing active surveillance in the DISSRM Registry crossed-over to receive delayed intervention. No patient undergoing delayed intervention experience cancer recurrence, progression, or died of renal cancer.85

## KQ 3b Comparative Benefits and Harms of Management Strategies Based on Patient Demographics, Clinical Characteristics, or Disease Severity

KQ 3a evaluated the comparative effectiveness of each management strategy for the major outcomes of interest (oncologic efficacy, renal functional outcomes, overall survival, and quality of life). Key Question 3b was designed to investigate clinical predictors (patient and tumor characteristics, renal mass sampling, or laboratory evaluations) of oncological efficacy, renal functional outcomes, overall survival, and quality of life as they relate to comparative effectiveness. While a number of studies evaluated multivariate predictors of oncological efficacy, renal functional outcomes, overall survival, and quality of life, few studies evaluated comparative efficacy of the given management strategies in relation to these predictors. Therefore, there are limited conclusions that can be drawn from these data. The results are detailed in this section.

### Key Points

- The most robust data regarding clinical predictors of outcome were derived from comparative studies of radical nephrectomy and partial nephrectomy. Other comparative studies were included, but the paucity of data prevented generalizable conclusions.

#### Cancer-Specific Survival

- The strength of evidence was insufficient for the predictors of cancer-specific survival in comparative studies. Increasing age, larger tumor size, and higher tumor grade were the most common predictors of cancer-specific survival in comparative studies of radical nephrectomy and partial nephrectomy.
  ○ Increasing age was associated with lower cancer-specific survival.
  ○ However, large population-based studies showed no difference in cancer-specific survival between partial nephrectomy and radical nephrectomy when stratified by age.
  ○ There were no differences in cancer-specific survival among patients undergoing radical and partial nephrectomy based on tumor stage, although most studies examined the relationship in patients with T1, T1a and/or T1b tumors and only little data exists for patients with T2 tumors.
  ○ Analyses of SEER indicate that radical and partial nephrectomy portend a cancer-specific survival benefit over nonsurgical management that may be attenuated in patients ≥75 years-old or with high cardiovascular risk.

#### Overall Survival

- The strength of evidence was low on the predictors of overall survival in comparative studies. Increasing age and comorbidity were predictive of lower overall survival.
  ○ In SEER-Medicare studies, an overall survival benefit exists for patients undergoing radical or partial nephrectomy in comparison to nonsurgical management.
    ■ The overall survival benefit existed in patients with both low and high cardiovascular risk and among different age groups (65 to 75, 75 to 80, and ≥ 80).

#### Renal Functional Outcomes

- The strength of evidence was low on the predictors of renal functional outcomes in comparative studies. Baseline renal function was associated with long-term renal functional outcomes, regardless of type of surgery.
  ○ Evidence suggested that patients with optimal baseline renal function (estimated glomerular filtration rate greater than 90 mL/min/1.73 m^2^) experience less decline in estimated glomerular filtration rate but no difference in incidence of chronic kidney disease after undergoing partial nephrectomy compared with those undergoing radical nephrectomy.
  ○ Evidence suggested that patients with poor baseline renal function (estimated glomerular filtration rate less than 45 mL/min/1.73 m^2^) may not experience a renal functional outcome benefit after undergoing partial nephrectomy compared with those undergoing radical nephrectomy.

#### Quality of Life

- The strength of evidence was insufficient on the predictors of health-related quality of life in comparative studies.

#### Harms and Perioperative Outcome

- The evidence was insufficient to evaluate the predictors of harms and perioperative outcomes in comparative studies.

### Oncological Efficacy

#### Cancer-Specific Survival

##### Radical Nephrectomy Versus Partial Nephrectomy

Eighteen studies (reported in 19 articles) evaluated predictors of cancer-specific survival for radical nephrectomy versus partial nephrectomy.148,92,97,99,103,109,110,112,117,142,143,146,147,149,154,155, 159,191 Five of these studies evaluated radical nephrectomy, and nonsurgical management in the Surveillance, Epidemiology, and End Results (SEER) dataset. Variation in study populations, data analysis, and reporting prevented meaningful meta-analyses from being performed. Age, tumor size (or stage), and pathological tumor grade were the most common variables among the studies (Table 51).

Table 51 Summary of predictors of cancer-specific survival and analyses of comparative efficacy among studies of comparative oncologic efficacy

Comparison | Author, Year | N | Study Design | Multivariate Analysis Predicting CSS | | Analyses of Comparative Efficacy
Comparison | Author, Year | N | Study Design | Predictive of CSS | Not Predictive of CSS | Analyses of Comparative Efficacy
Radical Nephrectomy Versus Partial Nephrectomy | Kopp ,2014^103^ | 202 | Retro. Single Institution | Grade, transfusion | Nephrometry score | No difference in T2 tumors
Radical Nephrectomy Versus Partial Nephrectomy | Milonas, 2013^109^ | 351 | Retro. Single Institution | Age, stage, ASA, grade | Tumor size | No difference in T1b tumors
Radical Nephrectomy Versus Partial Nephrectomy | Meskawi, 2014^146^ | 16333 | SEER | Age, race, tumor size, grade, year of surgery | Sex, marital status, socioeconomic status, histology, region | No difference in T1b tumors
Radical Nephrectomy Versus Partial Nephrectomy | Smaldone, 2012^154^ | 2496 | SEER | Multivariate analysis not presented
Radical Nephrectomy Versus Partial Nephrectomy | Badalato, 2011^141^ | 11256 | SEER | | Age and tumor size | No difference based on age
Radical Nephrectomy Versus Partial Nephrectomy | Badalato, 2011^141^ | | | | | No difference in T1b tumors
Radical Nephrectomy Versus Partial Nephrectomy | Antonelli, 2011^97^ | 3480 | Retro. Multi-Institution | In cT1a patients: age, pT3a, grade 4. | In cT1a patients: pT1b, grade 2 or 3. | No difference in patients with T1, T1a, or T1b tumors.
Radical Nephrectomy Versus Partial Nephrectomy | | | | In cT1b patients: age, pT3a, grade 4, surgical margins | In cT1b patients: sex, incidental, pT1b, grade 2 or 3
Radical Nephrectomy Versus Partial Nephrectomy | Minervini, 2012^110^ | 475 | Retro. Single Institution | Grade 3 or 4 | Incidental, grade 2, tumor size | No difference in patients with T1, T1a, or T1b tumors
Radical Nephrectomy Versus Partial Nephrectomy | | | | | | No difference in patients with Grade 1-2, 3 or 4 tumors
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2011 117 | 1981 | Retro. Single Institution | Grade and pT stage | Age, tumor size | PN CSS equivalent or improved for patients with cT1 disease with grade 4 tumors or those upstaged to pT2, pT3a, and/or pT3b disease.
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2010 159 | 510 | Retro. Single Institution | Multivariate analysis not presented | | No difference for cT1b patients when compared by grade and stage.
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2009^92^ | 1004 | Retro. Single Institution | Grade 4, pT stage | Tumor size, baseline, or final glomerular filtration rate
Radical Nephrectomy Versus Partial Nephrectomy | Crepel, 2010^143^ | 5141 | SEER | Multivariate analysis not provided
Radical Nephrectomy Versus Partial Nephrectomy | Zini , 2009^155^ | 9809 | SEER | Multivariate analysis not provided
Radical Nephrectomy Versus Partial Nephrectomy | Bedke, 2008^99^ | 464 | Retro. Single Institution | Tumor size (7cm), grade 3, age | Sex, Karnofsky performance status , histology | No difference in T1-2 tumors
Radical Nephrectomy Versus Partial Nephrectomy | Patard, 2004^112^ | 1454 | Retro. Multi-Institution | Univariate: ECOG, grade 3-4, incidental | Univariate: histology, pTstage | No difference in T1b tumors
Radical Nephrectomy Versus Partial Nephrectomy | O'Malley, 2015^191^ | 12,757 108 | SEER Retro. Single Institution | SEER: age, year of diagnosis <2003, tumor size, grade 3-4 and tumor stage | SEER: sex, marital status, race, clear-cell histology | No difference in patients with high-grade and/or high-stage (pT3) disease
Partial Nephrectomy Versus Thermal Ablation | Whitson, 2011^151^ | 8818 | SEER | Age, sex, marital status, tumor size | Year of diagnosis, race, urban or rural, socioeconomic status | Two-fold increased risk of cancer-specific mortality in cT1a patients undergoing thermal ablation.
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Patel, 2014^148^ | 7177 | SEER | Cardiovascular risk | | Compared to NSM, 2- to 4-fold benefit to RN or PN only in patients with low cardiovascular risk.
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Patel, 2014^147^ | 7177 | SEER | Age | Tumor size, Charlson comorbidity index | Compared to NSM, benefit to PN for age 75 or greater (no benefit age 65-75).
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | | | | | | Compared to NSM, benefit to RN at age 75-80 (no benefit for age 65-75 or >80).
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | | | | | | No difference to RN or PN at any age
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Sun, 2014^149^ | 10595 | SEER | Multivariate analysis not provided | | Compared to NSM, improved CSS for PN and RN in the entire cohort, T1a only, and in patients diagnosed 2000-2005.
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | | | | | | Compared to NSM, no benefit to RN or PN based on age, or if cT1a and age>75.
Radical Nephrectomy Versus Partial Nephrectomy Versus Thermal Ablation | Choueiri, 2011^142^ | 15145 | SEER | Multivariate analysis not provided | | No benefit to RN or PN in patients with T1, T1a, or T1b tumors

CSS = cancer-specific survival; SEER = Surveillance, Epidemiology, and End Results; ASA = American Society of Anesthesiologists; ECOG = Eastern Cooperative Oncology Group performance status; NSM = nonsurgical management; PN = partial nephrectomy; pT1 = pathology T1; Retro.= retrospective; RN = radical nephrectomy

###### Age

Five studies97,99,109,146,191 found increasing age to be predictive of cancer-specific mortality after radical or partial nephrectomy. Four studies97,109,146,191 demonstrated a hazard ratio of 1.02 to 1.03 for cancer-specific mortality, while the remaining study85 demonstrated a hazard ratio of 2.99 for patients greater than 60 years old. When examining age in the context of surgical approach, three SEER studies demonstrated no difference between radical nephrectomy and partial nephrectomy when stratified by age.141,147,149 The study by Patel, et al.,147 evaluated cancer-specific survival between radical nephrectomy and partial nephrectomy in three age strata (65–75, 75–80, and ≥ 80 years) and found no cancer-specific survival benefit between radical nephrectomy and partial nephrectomy in any age strata. Similarly, the study by Sun, et al.149 found no difference in cancer-specific survival between radical nephrectomy and partial nephrectomy in patients older than 75 years. Badalato, et al.141 found no difference among radical nephrectomy and partial nephrectomy when age was dichotomized at 60 years old. Increasing age in multivariable models was predictive of cancer specific mortality; however when comparing radical nephrectomy with partial nephrectomy, there was no clear benefit to either surgical approach based on age.

###### Tumor Size, Pathological Stage, and Grade

Tumor size, as well as pathological stage, and pathological tumor grade were predictive of cancer-specific survival after radical or partial nephrectomy in three studies99,146,191 and not predictive in four studies,92,109,110,141 although the studies varied in inclusion criteria and tumor characteristics. Increasing tumor stage was predictive of lower cancer-specific survival after radical or partial nephrectomy in two studies.92,97 Both studies demonstrated a lower cancer-specific survival in clinically localized patients, with T1 and T2 tumors, who were upgraded to pT3a disease at surgery. The study by O'Malley, et al. 191 evaluated patients with “high-risk” clinically localized renal cancers – defined as high-grade and/or upstaged (to pT3a) tumors. They also demonstrated worse cancer-specific survival for upstaged patients with and without a high-grade component in the tumor.

Importantly, no study demonstrated a benefit to radical or partial nephrectomy based on stage or tumor size. Four studies found no difference among radical and partial nephrectomy when evaluating cancer-specific survival in patients with T1 tumors.110 97 142 112 In sub-group analyses, three studies97,110,112 evaluated patients with T1a tumors and found no benefit to radical or partial nephrectomy. Eight studies109,125, 92,97,110,112,146,159 (three in sub-group analyses 97,110,112) evaluated patients with T1b tumors and found no benefit to radical or partial nephrectomy. One study evaluated patients with T1-2 tumors 99 and one study evaluated only patients with T2 tumors 103, neither demonstrated a benefit to radical or partial nephrectomy. The study by Weight, et al. 117 demonstrated equivalent or improved cancer-specific survival for patients with cT1 tumors who underwent partial nephrectomy and were upstaged to pT2, pT3a and/or pT3b tumors in comparison to those undergoing radical nephrectomy; however, multivariate regression could not be performed due to infrequency of events.

Pathological tumor grade (Fuhrman grade 3 or 4) was predictive of cancer-specific survival in nine studies.92,97,99,103,109,110,112,142,146,191 The study by Minervini, et al.110 evaluated differences in cancer-specific survival based on tumor grade, and found no difference among patients undergoing radical and partial nephrectomy for grade 1 and 2 (log rank p = 0.48), grade 3 (log rank p = 0.89) or grade 4 (log rank p = 0.62) tumors. Similarly, the study by Weight, et al.117 demonstrated equivalent or improved cancer-specific survival for patients between patients undergoing partial and radical nephrectomy who had grade 4 tumors; however, multivariate regression could not be performed due to infrequency of events. No other study demonstrated a benefit or radical or partial nephrectomy based on tumor grade.

##### Radical Nephrectomy Versus Thermal Ablation

Two studies assessed cancer-specific survival for radical nephrectomy versus thermal ablation.134,142 Neither study demonstrated a benefit to radical nephrectomy or thermal ablation. The study by Choueiri, et al.142 demonstrated an equivalent cancer-specific mortality rate (1.8 percent vs. 1.6 percent at 2 years, p=0.7) which was substantiated in multivariate regression – however the data was not provided. In the study by Takaki, et al. 134, one patient undergoing thermal ablation died of renal cancer and no patient undergoing radical nephrectomy died of renal cancer, therefore statistical analyses were not performed. Therefore, predictors of cancer-specific survival and comparative outcomes could not be assessed (Table 51).

##### Partial Nephrectomy Versus Thermal Ablation

One study evaluated predictors of cancer-specific survival in patients with clinical T1a tumors in the SEER dataset and found that age, sex, marital status, and tumor size were predictive of cancer-specific survival, while year of diagnosis, race or ethnicity, setting (rural or urban), and socioeconomic status were not.151 This study demonstrated a twofold greater risk of cancer-specific mortality in patients with cT1a tumors undergoing thermal ablation (hazard ratio: 1.9 (95% confidence interval: 1.1-3.3), p=0.02) (Table 51).

##### Surgical Management Versus Active Surveillance

No study evaluated predictors of cancer-specific survival for surgical management versus active surveillance.

##### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

Two studies (reported in 3 articles) assessed cancer-specific survival for nonsurgical management versus radical nephrectomy and partial nephrectomy in the SEER dataset.147-149 In the study by Patel, et al.148, a two-fold to four-fold cancer-specific survival benefit was shown in patients with low cardiovascular risk undergoing either radical nephrectomy or partial nephrectomy compared with patients undergoing nonsurgical management. The benefit of surgery on cancer-specific survival was not significant in patients with high cardiovascular risk.

###### Age

Age was evaluated in the study by Patel, et al.,147 where a benefit in cancer-specific survival was shown for both radical and partial nephrectomy compared with nonsurgical management for patients 65 to 75 and 75 to 80 years old. The cancer-specific survival benefit for partial nephrectomy remained in patients 80 years of age or older (p = 0.03) but was nonsignificant for patients undergoing radical nephrectomy (p = 0.08).

###### Tumor Stage

In the study by Sun, et al.,149 an improved cancer-specific survival was noted for patients undergoing partial nephrectomy compared with nonsurgical management for the entire cohort (p = 0.01), in patients with only T1a tumors (p = 0.03), and in patients diagnosed from 2000-2005 (compared to those from 1988-2000) (p < 0.001). A similar benefit was noted for radical nephrectomy in the entire cohort (p = 0.03), in patients with only T1a tumors (p = 0.04), and in patients diagnosed from 2000-2005 (p = 0.01).

The benefit in cancer-specific survival was attenuated for both partial nephrectomy and radical nephrectomy if a patient was older than 75 (i.e., the difference was no longer statistically significant, p = 0.1), or if T1a tumor and age was greater than 75 (i.e., the difference was no longer statistically significant, p = 0.1). In summary, data from SEER indicated that partial nephrectomy and radical nephrectomy portended a cancer-specific survival advantage over nonsurgical management. However, the cancer-specific survival benefits of radical nephrectomy or partial nephrectomy may be attenuated in patients older than 75 to 80 or those with high cardiovascular risk.

#### Metastasis-Free Survival

##### Radical Nephrectomy Versus Partial Nephrectomy

One study evaluated predictors of metastasis-free survival among patients undergoing radical nephrectomy and partial nephrectomy. 110 This study found Fuhrman grade 3 to 4 predicted metastatic recurrence, while Fuhrman grade 2, tumor size, and incidental presentation were not predictive of metastatic recurrence. There was no demonstrable difference in metastatic progression in patients undergoing radical or partial nephrectomy based on tumor stage or grade in this study.

##### Radical Nephrectomy Versus Thermal Ablation

No study evaluated predictors of metastasis-free survival for radical nephrectomy versus thermal ablation.

##### Partial Nephrectomy Versus Thermal Ablation

No study addressed metastasis-free survival for partial nephrectomy versus thermal ablation.

##### Surgical Management Versus Active Surveillance

No study addressed predictors of metastasis-free survival for partial nephrectomy versus thermal ablation

##### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

No study evaluated predictors of metastasis-free survival for nonsurgical management versus radical nephrectomy versus partial nephrectomy.

#### Local Recurrence-Free Survival

##### Radical Nephrectomy Versus Partial Nephrectomy

No study evaluated predictors of local recurrence-free survival for radical nephrectomy versus partial nephrectomy.

##### Radical Nephrectomy Versus Thermal Ablation

No study evaluated predictors of local recurrence-free survival for radical nephrectomy versus thermal ablation.

##### Partial Nephrectomy Versus Thermal Ablation

No study specifically addressed local recurrence-free survival for partial nephrectomy versus thermal ablation. However, three studies122,125,136 evaluated predictors of recurrence-free survival (local and metastatic) among patients undergoing partial nephrectomy or thermal ablation. In a study of cT1b tumors only, Chang, et al.122 demonstrated increasing age, tumor size, surgical approach; histology and nephrometry score were not predictive of recurrence. The study by Tanagho, et al.125 determined that endophytic tumor location and cryoablation predicted recurrence but did not demonstrate a direct benefit to partial nephrectomy in patients with endophytic tumors. In examining age, tumor size, followup, histology, and surgery type, Olweny, et al.136 found no predictors of recurrence. No study demonstrated a benefit to partial nephrectomy or thermal ablation based on patient or tumor characteristics.

##### Surgical Management Versus Active Surveillance

No study specifically addressed predictors of local recurrence -free survival for surgical management versus active surveillance.

##### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

No study evaluated predictors of local recurrence-free survival for nonsurgical management versus radical nephrectomy versus partial nephrectomy.

#### Overall Survival

##### Radical Nephrectomy versus Partial Nephrectomy

Eighteen studies (reported in 19 articles) evaluated predictors of overall survival for radical nephrectomy versus partial nephrectomy.90,92,101,103,104,109,117,141,145,147-150,153-155,157,159,191 (Table 52). Age and comorbidities were the most commonly used predictors of overall survival in these studies.

Table 52 Summary of predictors and analyses of comparative efficacy of overall survival among studies of comparative oncologic efficacy

Comparison | Author, Year | N | Study Design | Multivariate Analysis Predicting Overall Survival | | Analyses of Comparative Efficacy
Comparison | Author, Year | N | Study Design | Predictive | Not Predictive | Analyses of Comparative Efficacy
Radical Nephrectomy Versus Partial Nephrectomy | Kyung, 2014^104^ | 135 | Retro. Single Institution | Charlson comorbidity index | Surgery, tumor size, preoperative CKD, postoperative eGFR
Radical Nephrectomy Versus Partial Nephrectomy | Kopp, 2014^103^ | 202 | Retro. Single Institution | Nephrometry score, grade, transfusion | Partial nephrectomy
Radical Nephrectomy Versus Partial Nephrectomy | Milonas, 2013^109^ | 351 | Retro. Single Institution | Age, stage, American Society of Anesthesiologists score, grade | Tumor size, Radical nephrectomy
Radical Nephrectomy Versus Partial Nephrectomy | Smaldone, 2012^154^ | 2,496 | SEER | Age at diagnosis | | Benefit to PN in patients ages 68-85, no benefit if younger than 68 or greater than 85.
Radical Nephrectomy Versus Partial Nephrectomy | Iizuka, 2012^101^ | 586 | Retro. Single Institution | Multivariate analysis not provided | | Benefit to PN in cT1a vs RN for cT1b (p<0.01), no difference for PN cT1b vs. RN cT1b, or PN cT1b vs. PN cT1a.
Radical Nephrectomy Versus Partial Nephrectomy | Tan, 2012^150^ | 7,138 | SEER | Age, Charlson comorbidity index, residence setting, year of surgery | | Benefit to PN in entire cohort, age <75, Charlson index score ≥1, urban residence or year of surgery 2000-2007. No benefit if age≥75, Charlson comorbidity index =0, rural residence, year of surgery 1992-1999
Radical Nephrectomy Versus Partial Nephrectomy | Badalato, 2011^141^ | 11,256 | SEER | | Age and tumor size | No benefit based on age or tumor size.
Radical Nephrectomy Versus Partial Nephrectomy | Kates, 2011^153^ | 4,216 | SEER | Age, sex, marital status, black race | Race other than black, US region
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2011^117^ | 2,511 | Retro. Single Institution | Charlson comorbidity index, age, grade 4 | Pathological T-stage (cohort includes only those patients upstaged from cT1 to pT2 or pT3) | PN equivalent or improved outcome in high-grade tumors and cT1 tumors upstaged to pT2, pT3a and pT3b.
Radical Nephrectomy Versus Partial Nephrectomy | VanPoppel, 2010^90^ | 541 | RCT | Age, World Health Organization performance status, associated chronic diseases “were prognostic factors of overall survival, but none were predictive factors.”
Radical Nephrectomy Versus Partial Nephrectomy | | | | Multivariate analysis not provided
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2010 159 | 510 | Retro. Single Institution | Age-adjusted Charlson comorbidity index, postoperative eGFR, pathological T-stage | | Benefit to PN when controlling for other variables (left).
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2009^92^ | 1,004 | Retro. Single Institution | Postoperative eGFR, pathological T-stage
Radical Nephrectomy Versus Partial Nephrectomy | Zini, 2009^155^ | 9,809 | SEER | Multivariate analysis not provided
Radical Nephrectomy Versus Partial Nephrectomy | Huang, 2009^145^ | 2,991 | SEER | Multivariate analysis not provided
Radical Nephrectomy Versus Partial Nephrectomy | Thompson, 2008^157^ | 648 | Retro. Single Institution | Radical nephrectomy predictive of overall survival in patients <65, including year of surgery, baseline eGFR, Charlson comorbidity index, sex, incidental presentation, diabetes, histology
Radical Nephrectomy Versus Partial Nephrectomy | O'Malley, 2015 191 | 12,757 108 | SEER Retro. Single Institution | [underlined: SEER]: age, male sex, marital status, black race, year of diagnosis <2003, tumor size, tumor grade and stage [underlined: Institutional data]: new postoperative CKD stage 3 or greater | [underlined: SEER]: clear-cell histology, race other than white or black [underlined: Institutional data]: sex, smoking status, body mass index, tumor size, RENAL score, nonclear cell histology, positive margins, preoperative eGFR, preoperative CKD stage 3 or greater, postoperative eGFR, decrease in eGFR, any complication | [underlined: SEER]: RN associated with increased risk of all-cause mortality. [underlined: Institutional data]: RN associated with worse all-cause mortality controlling for age-adjusted Charlson comorbidity index.
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Patel, 2014^148^ | 7,177 | SEER | Cardiovascular risk (low and high) | | Compared to NSM, benefit to PN and RN in patients with low and high cardiovascular risk
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Patel, 2014^147^ | 7,177 | SEER | Age, Charlson comorbidity index | | Compared to NSM, PN and RN associated with improved survival among all ages. In comparison to RN only, PN has improved survival in patients ≥80 years old, no benefit if age 65-80.
Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy | Sun, 2014^149^ | 10,595 | SEER | Multivariate analysis not provided | | Compared to NSM, benefit to PN and RN in the entire cohort, T1a only, >75 years old, cT1a and >75 years old, and year of diagnosis 2000-2005.
Partial Nephrectomy Versus Thermal Ablation | Thompson, 2014^127^ | 1,424 | Retro. Single Institution | For cT1a: age, Charlson comorbidity index, and cryoablation | For cT1a: Radiofrequency ablation | Benefit to PN vs. cryoablation in cT1a and cT1b tumors, no benefit to PN vs. radiofrequency ablation for cT1a tumors.
Partial Nephrectomy Versus Thermal Ablation | | | | For cT1b: age, Charlson comorbidity index and cryoablation | For cT1b: none | Benefit to PN vs. cryoablation in cT1a and cT1b tumors, no benefit to PN vs. radiofrequency ablation for cT1a tumors.
Radical Nephrectomy Versus Thermal Ablation | Choueiri, 2011^142^ | 15,145 | SEER | Multivariate analysis not provided
Surgical Intervention Versus Active Surveillance | Lane, 2010^135^ | 537 | Retro. Single Institution | Age, Charlson comorbidity index | Tumor size, preoperative eGFR, sex, race, solitary kidney

ASA = American Society of Anesthesiologists; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; NSM = nonsurgical management; PN = partial nephrectomy; RN = radical nephrectomy; SEER = Surveillance, Epidemiology, and End Results; TA = thermal ablation; RCT = randomized controlled trial

###### Age

Six studies reported increasing age to be associated with overall survival.90,109,153,154,159,191 The study by Smaldone, et al. 154 demonstrated a one and three-year overall survival benefit to partial nephrectomy for patients ages 68 to 85. The benefit was insignificant in patients younger than 68 and older than 85. Another study by Iizuka, et al.101 found that overall survival for patients with clinical T1a tumors undergoing partial nephrectomy was superior to patients undergoing radical nephrectomy for clinical T1b tumors. A study by Tan, et al.150 found an overall survival benefit for patients undergoing partial nephrectomy who were both younger and older than age 75 years. One study by Thompson, et al.157 determined that radical nephrectomy was predictive of lower overall survival for patients younger than 65 years of age. One study evaluated patients with only T1b tumors and determined that age was not predictive of overall survival.141 Heterogeneity in study design, selection bias, and variation in conclusions prevent meaningful conclusions from being drawn about the comparative efficacy of radical and partial nephrectomy based on age.

###### Comorbidity

Eight studies evaluated comorbidity or composite comorbidity indices as predictors of overall survival.90,104,109,117,148,150,157,159 Five reported on use of the Charlson comorbidity index to predict mortality,104,117,150,157,159 while other studies evaluated cardiovascular risk,148 American Society of Anesthesiologists score,109 and World Health Organization (WHO) performance status.90 All studies reported lower overall survival with increasing comorbidity. The study by Tan, et al.150 found no difference in overall survival among patients undergoing radical nephrectomy and partial nephrectomy if the Charlson Comorbidity Index was zero. The study by Thompson, et al. 157 demonstrated an inferior overall survival for patients undergoing radical nephrectomy in comparison to partial nephrectomy, even after adjusting for Charlson Comorbidity Index in multivariate regression.

##### Radical Nephrectomy Versus Thermal Ablation

Two studies evaluated overall survival for radical nephrectomy versus thermal ablation.134,142 The study by Chouieri, et al.142 did not provide details of the multivariate analysis, while the study by Takaki, et al.134 did not investigate predictors of overall survival.

##### Partial Nephrectomy Versus Thermal Ablation

One study evaluated the effect of tumor size and stage as a predictor of overall survival.127 This study found a statistically significant overall survival advantage for partial nephrectomy over cryoablation for both T1a and T1b tumors after adjustment. The overall survival advantage was not evident for patients with T1a tumors undergoing radiofrequency ablation.

##### Surgical Intervention Versus Active Surveillance

One study evaluated radical nephrectomy, partial nephrectomy, and active surveillance among patients older than 75 years.135 Multivariate regression modeling indicated that the Charlson Comorbidity Index and age were the strongest predictors of all-cause mortality, but not surgical intervention or active surveillance.

##### Nonsurgical Management Versus Radical Nephrectomy Versus Partial Nephrectomy

Two studies (reported in 3 articles) evaluated overall survival for nonsurgical management versus radical nephrectomy and partial nephrectomy.147-149 The study by Patel, et al.148 evaluated overall survival in relation to cardiovascular risk. There was a significant benefit to both partial nephrectomy and radical nephrectomy compared with patients undergoing nonsurgical management in both low-cardiovascular and high-cardiovascular risk patients. The study by Patel, et al.147 evaluated overall survival in relation to age and found an overall survival benefit to both partial nephrectomy and radical nephrectomy over nonsurgical management among patients ages 65 to 75, 75 to 80, and older than 80 years. An overall survival benefit did not exist for partial nephrectomy over radical nephrectomy in patients 65 to 75 years old (p = 0.09) and 75 to 80 years old (p = 0.8); however the benefit was significant for patients 80 or older (p = 0.02).

#### Renal Functional Outcomes

##### Radical Nephrectomy Versus Partial Nephrectomy

Seventeen studies evaluated clinical patient and tumor characteristics predictive of differential renal functional outcomes.89,96,101,105,107,108,113,114,121,156,159,166,168,169,172,174,176,191 Factors evaluated in these studies included baseline renal function (estimated glomerular filtration rate, serum creatinine, or chronic kidney disease stage, age, sex, tumor size (or stage), composite comorbidity scores (American Society of Anesthesiologists score or Charlson comorbidity index), individual comorbidities (hypertension, diabetes mellitus, heart disease, and smoking), body mass index, and pathologic features (renal cell carcinoma histology) (Table 53).

Table 53 Studies evaluating predictors of comparative postoperative renal function

Comparison | Author, Year | N | Study Design | Summary
Radical Nephrectomy Versus Partial Nephrectomy | Woldu, 2014^166^ | 1,306 | Retro Single Institution | Partial nephrectomy associated with lower rate of eGFR decline in CKD I and CKD II, not CKD III. No difference in the probability of developing CKD IIIb in CKD I or CKD IIIa patients, partial nephrectomy had favorable outcomes in CKD II only. In multivariate analysis of patients with CKD I, no variables were predictive of renal function. In multivariate analysis of patients with CKD II and CKD III, age, sex, and radical nephrectomy were predictive of postoperative renal function.
Radical Nephrectomy Versus Partial Nephrectomy | Scosyrev, 2013^89^ | 259 | RCT | Partial nephrectomy associated with improved eGFR outcome in patients with baseline creatinine <1.25 and those patients with and without chronic illnesses. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Mariusdottir, 2013^107^ | 88 | Retro Single Institution | Radical nephrectomy and baseline chronic kidney disease predict new onset chronic kidney disease.
Radical Nephrectomy Versus Partial Nephrectomy | Miyamoto, 2012^168^ | 253 | Retro Single Inst. | In multivariate analysis, age, sex, radical nephrectomy predict new onset eGFR<60 in multivariate analysis, tumor size, and hypertension were not predictive.
Radical Nephrectomy Versus Partial Nephrectomy | Iizuka, 2012^101^ | 586 | Retro Single Institution | Radical nephrectomy associated with new onset chronic kidney disease in patients with T1b tumors. Rate of new onset chronic kidney disease similar for T1a and T1b undergoing partial nephrectomy. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Sun, 2012^169^ | 4,633 | SEER | Propensity scores analysis demonstrates superior renal functional outcomes for PN, age, sex, race, preexisting illness, Charlson, year of surgery, marital status, socioeconomic status, population density, hypercalcemia, hyperlipidemia, anemia, tumor size are controlled for but details are not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Roos, 2012^114^ | 247 | Retro Single Institution | In multivariate analysis, age, ASA score, baseline eGFR, radical nephrectomy predict new onset chronic kidney disease; hypertension, Charlson, diabetes, histology, tumor size are not predictive.
Radical Nephrectomy Versus Partial Nephrectomy | Takagi, 2011^156^ | 95 | Retro Single Institution | In patients with preexisting chronic kidney disease, partial nephrectomy was associated with improved renal function in patients with preoperative eGFR 45-59, but not patients with eGFR 30-44.
Radical Nephrectomy Versus Partial Nephrectomy | Medina-Polo, 2011^108^ | 290 | Retro Single Inst. | In univariate analysis only, age, hypertension, diabetes mellitus predictive of new onset chronic kidney disease; heart disease, smoking, body mass index, and radical nephrectomy were not predictive.
Radical Nephrectomy Versus Partial Nephrectomy | Lane, 2010^105^ | 2,402 | Retro Single Institution | Radical nephrectomy predicts a postoperative eGFR<45 mL/min/1.73 m^2^ controlling for age, comorbidity, baseline eGFR, and tumor size. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Roos, 2010^113^ | 829 | Retro Single Institution | Higher rates of new onset chronic kidney disease after radical nephrectomy in both elderly and young patients. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Weight, 2010 159 | 510 | Retro. Single Institution | Age, male sex, and preoperative eGFR predict new-onset CKD (Charlson Comorbidity Index not predictive). When controlling for age, sex, Charlson Comorbidity Index, and preoperative renal function, radical nephrectomy increased the odds of CKD by 3.4-fold.
Radical Nephrectomy Versus Partial Nephrectomy | Jeon, 2009^172^ | 225 | Retro Single Institution | Age, radical nephrectomy, and diabetes predict new onset chronic kidney disease. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | Huang, 2006^174^ | 662 | Retro Single Institution | In multivariate analysis, radical nephrectomy, age, and preoperative eGFR predicted eGFR<60 and eGFR<45 mL/min/1.73 m^2^ after surgery.
Radical Nephrectomy Versus Partial Nephrectomy | Matin, 2002^176^ | 117 | Retro Single Institution | Radical nephrectomy associated with lower postoperative creatinine controlling for age and sex. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | McKiernan, 2002^121^ | 173 | Retro Single Institution | Age, serum creatinine, and smoking not associated with postop creatinine in radical nephrectomy cohort. Multivariate analysis not provided.
Radical Nephrectomy Versus Partial Nephrectomy | O'Malley, 2015 191 | 12,757 108 | SEER Retro. Single Institution | Institutional data: In univariate analysis only, age, RENAL score, tumor size, preoperative eGFR, and radical nephrectomy are associated with decreasing postoperative eGFR. Propensity score analysis demonstrates increased risk of CKD stage 3 with radical nephrectomy.
Partial Nephrectomy Versus Thermal Ablation | Tanagho, 2013^125^ | 267 | Retro Single Institution | In multivariate analysis, tumor size, hilar location, and thermal ablation are predictive of preservation of eGFR; age, sex, BMI, Charlson, preoperative creatinine, nephrometry score, operative time, blood loss are not predictive.
Partial Nephrectomy Versus Thermal Ablation | Faddegon, 2013^177^ | 347 | Retro Single Institution | In multivariate analysis, followup time is the only predictor of GFR at last followup, thermal ablation, hypertension, diabetes, age, and tumor size are not predictive.
Partial Nephrectomy Versus Thermal Ablation | Mues, 2012^126^ | 198 | Retro Single Institution | No difference in eGFR based on tumor size, congenital or acquired solitary kidney. Multivariate analysis not provided.
Partial Nephrectomy Versus Thermal Ablation | Mitchell, 2011^178^ | 112 | Retro Single Institution | No difference among partial nephrectomy or thermal ablation when controlling for age, nephrometry score, and tumor size.
Partial Nephrectomy Versus Thermal Ablation | Kiriluk, 2011^179^ | 112 | Retro Single Institution | Significant differences in eGFR in patients with baseline eGFR>90, no difference in percentage decrease in eGFR.
Partial Nephrectomy Versus Thermal Ablation | Turna, 2009^138^ | 101 | Retro Single Institution | Baseline eGFR and partial nephrectomy predict eGFR decrease; tumor location and size are not predictive.
Partial Nephrectomy Versus Thermal Ablation | Desai, 2005^131^ | 131 | Retro Single Institution | In patients with preexisting chronic kidney disease (eGFR>123 mL/min/1.73 m^2^), no difference in postoperative eGFR/creatinine.
Radical Nephrectomy Versus Thermal Ablation | Takaki, 2014^134^ | 60 | Retro Single Institution | One month and last eGFR lower for radical nephrectomy compared with thermal ablation when controlling for baseline eGFR. Multivariate analysis not provided.
Surgical Intervention Versus Active Surveillance | Lane ,2010^135^ | 537 | Retro Single Institution | In patients >75 years of age, a greater reduction in eGFR occurred in radical nephrectomy relative to partial nephrectomy or active surveillance
Radical Nephrectomy Versus Partial Nephrectomy Versus Thermal Ablation | Lucas ,2007^96^ | 242 | Retro Single Institution | In multivariate analysis, compared with thermal ablation: partial nephrectomy, radical nephrectomy, and age predict eGFR<60 mL/min/1.73 m^2^; radical nephrectomy, baseline eGFR predict eGFR<45 mL/min/1.73 m^2^. Charlson and tumor size were not predictive.

SEER = Surveillance, Epidemiology, and End Results; ASA = American Society of Anesthesiologists; eGFR = estimated glomerular filtration rate; CKD = chronic kidney disease; pT3 = pathologic stage T3; PN = partial nephrectomy; RCT = randomized controlled trial; RN = radical nephrectomy; TA = thermal ablation

The study by Lucas, et al.96 evaluated thermal ablation, radical nephrectomy, and partial nephrectomy; all other studies directly compared radical nephrectomy with partial nephrectomy. In addition, inconsistencies in data gathering and reporting among studies prevented a meaningful meta-analysis to be performed for any given variable. Specifically, some studies reported serum creatinine while others reported estimated glomerular filtration rate. Some studies reported continuous outcomes (e.g., change in estimated glomerular filtration rate), while others reported categorical outcomes (e.g., new onset chronic kidney disease). The reporting of the complete multivariate analysis, odds ratios, confidence intervals, and/or p-values varied among studies (Table 54).

Table 54 Strength of evidence domains for clinical predictors of the comparative benefits and harms of the available management strategies

Key Outcomes | No. Studies (N) | Study limitation | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Finding
Cancer-specific survival | 19 (114,752) | Medium | Indirect | Inconsistent | Precise | Undetected | Low Most data was derived from studies of radical nephrectomy in comparison to partial nephrectomy. In addition, inclusion criteria varied among studies and the relationship of age, tumor size, stage and grade to oncological outcomes were inconsistent among studies. However, the data indicates that differences in cancer-specific survival among modalities is likely unrelated to age or tumor stage.
Metastases-free survival | 1 (475) | Medium | Indirect | Unknown | Precise | NA | Insufficient
Local recurrence-free survival | 3 (360) (local and metastatic recurrence combined in these studies) | Medium | Indirect | Inconsistent | Imprecise | NA | Insufficient Variations in data collection and presentation prevent meaningful conclusions from these studies.
Overall survival | 22 (99,314) | Medium | Indirect | Consistent | Precise | Undetected | Low Based mostly on studies of radical nephrectomy compared to partial nephrectomy, age and comorbidities consistently predicted overall survival.
Renal Functional Outcomes | 27 (27,647) | Medium | Direct | Consistent | Imprecise | Undetected | Low Most data was derived from studies of radical and partial nephrectomy. The effects of baseline renal function and age were consistent among studies, but inconsistencies in other evaluable parameters limit the strength of evidence.
Quality of Life | 2 (247) | Medium | Indirect | Inconsistent | Imprecise | Undetected | Insufficient Both studies demonstrated surgical approach (laparoscopic versus open) to predict outcome, but sparse data and inconsistencies among studies prevented determination of whether any factors were predictive of differences in the effects on health-related quality of life.
Perioperative Outcomes and Harms | 3 (2,168) | Medium | Indirect | Inconsistent | Imprecise | NA | Insufficient One study evaluated age113 and two evaluated tumor size.114,184 All studies were inconclusive preventing meaningful conclusions from being drawn.

###### Baseline Renal Function

Baseline renal function was the most consistently reported outcome. Nine studies with an association between baseline and postoperative renal function demonstrated that poor baseline renal function was associated with lower postoperative renal function.89,96,101,105,107,108,113,114, 156,159,166,168,172,174,176,191

Woldu, et al.166 found that partial nephrectomy was only beneficial in patients with stage II chronic kidney disease (i.e. partial nephrectomy was associated with greater preservation of glomerular filtration rate) and not predictive in patients with stage I or stage III at the extremes of baseline renal function. Similarly, Scosyrev, et al.89 found that partial nephrectomy was associated with an improved postoperative estimated glomerular filtration rate only in those patients with a baseline creatinine less than or equal to 1.25 but not greater than 1.25. Takagi, et al.156 demonstrated that partial nephrectomy was associated with improved renal function after surgery (relative to patients receiving radical nephrectomy) only in those patients with a preoperative estimated glomerular filtration rate of 45 to 90 mL/min/1.73 m^2^ and not among patients with estimated glomerular filtration rate of 30 to 45 mL/min/1.73 m^2^ before surgery. To the contrary, the study by McKiernan, et al.121 examined baseline serum creatinine only in patients undergoing radical nephrectomy and found this to be a nonsignificant predictor of postoperative serum creatinine.

Baseline renal function is associated with long-term renal functional outcomes regardless of type of surgery. While the evidence was not overwhelming, the evidence indicated that patients with optimal baseline renal function (estimated glomerular filtration rate >90 mL/min/1.73 m^2^) experienced less decline in estimated glomerular filtration rate but no difference in incidence of chronic kidney disease, while patients with poor baseline renal function (estimated glomerular filtration rate < 45 mL/min/1.73 m^2^) may not experience a renal functional outcome benefit after undergoing partial nephrectomy compared with those undergoing radical nephrectomy.

###### Age

Twelve studies reported renal functional outcomes in relation to age.90,105,108,113,114,121,159,168,169,172,174,191 Seven of those studies reported increasing age associated with lower postoperative renal function.108,114,159,168,172,174,191 Two studies demonstrated no effect of age on postoperative renal function.113,121

The study by Roos, et al.113 found an approximate 8 mL/min/1.73 m^2^ lower estimated glomerular filtration rate among elderly (≥65 years old) and young (<55 years old) patients undergoing radical nephrectomy compared with partial nephrectomy.

Three studies reported age as a controlling variable in multivariate regression, but did not provide the multivariate analysis.90,105,169

###### Tumor Size

Seven studies evaluated tumor size as predictive of postoperative renal function.96,101,105,114,168,169,191 The study by Roos, et al.114 found a nonsignificant, lower estimated glomerular filtration rate for patients undergoing radical nephrectomy in comparison to patients undergoing partial nephrectomy for tumors 4 to 7 cm (p = 0.12) or larger than 7 cm (p = 0.07). The study by Iizuka, et al.101 found that radical nephrectomy was associated with worse renal functional outcomes compared to partial nephrectomy, specifically in the cohort of patients with T1b tumors. The remainder of studies found similar renal functional outcomes when stratified by tumor size.

##### Radical Nephrectomy Versus Thermal Ablation

Two studies evaluated predictors of renal function comparative outcomes.96,134 In the study by Takaki, et al.,134 even when controlling for baseline estimated glomerular filtration rate, patients undergoing thermal ablation had a better estimated glomerular filtration rate than patients undergoing radical nephrectomy at one month following surgery and at last followup (multivariate analysis was not provided). In the study by Lucas, et al.,96 in both patients with a baseline estimated glomerular filtration rate less than 60 mL/min/1.73 m^2^ and estimated glomerular filtration rate less than 45 mL/min/1.73 m^2^, thermal ablation showed superior renal functional outcomes than for patients undergoing radical nephrectomy.

##### Partial Nephrectomy Versus Thermal Ablation

Eight studies evaluated predictions of renal functional comparative outcomes.96,125,126,131,138, 177-179 Renal outcomes were inconsistently reported across these studies and thus the predictive abilities of different factors could not be meaningfully compared. Some studies reported renal functional outcomes as a continuous variable (estimated glomerular filtration rate) while others reported categorical outcomes (chronic kidney disease). In five studies, tumor size and characteristics had no impact on renal functional outcomes.96,126,138,177,178 However, the study by Tanagho, et al.125 demonstrated that decreasing tumor size and thermal ablation were predictive of renal function, while hilar tumor location was associated with lower renal function.

##### Surgical Intervention Versus Active Surveillance

One study135 evaluated radical nephrectomy, partial nephrectomy, and active surveillance among patients older than 75 years. Analyses of patients younger than 75 years or other variables predictive of renal functional outcomes were not performed.

#### Quality of Life

Two studies evaluated predictors of health-related quality of life among surgical management strategies.80,83 The study by Parker, et al.80 found that age, the use of open versus laparoscopic surgery, and time from surgery all influenced health-related quality of life. The study by Gratzke, et al.83 found that complications following surgery predicted health-related quality of life, regardless of type of surgery (i.e., partial nephrectomy or radical nephrectomy). Interestingly, the noncomparative study by Becker, et al.192 did not demonstrate a relationship between complications and health-related quality of life in patients undergoing partial nephrectomy. The noncomparative study evaluating thermal ablation by Beemster, et al.193 found that age and comorbidity status affected health-related quality of life. Due to a paucity of data, no meaningful conclusions could be drawn regarding clinical patient or tumor characteristics as they affect health-related quality of life (Table 54).

#### Harms

Only three studies evaluated additional patient and tumor factors predictive of harms. These included age113 and tumor size114,184 – these were not found to be predictive of harms.