# References

1 Kutikov A, Fossett LK, Ramchandani P, et al. Incidence of benign pathologic findings at partial nephrectomy for solitary renal mass presumed to be renal cell carcinoma on preoperative imaging. Urology. 2006;68(4):737-40. [pmid: 17070344].
2 Thompson RH, Hill JR, Babayev Y, et al. Metastatic renal cell carcinoma risk according to tumor size. J Urol. 2009;182(1):41-5. [pmid: 19450840].
3 Lane BR, Babineau D, Kattan MW, et al. A preoperative prognostic nomogram for solid enhancing renal tumors 7 cm or less amenable to partial nephrectomy. J Urol. 2007;178(2):429-34. [pmid: 17561141].
4 American Cancer Society. Cancer Facts &Figures. 2014. 2014.
5 Mathew A, Devesa SS, Fraumeni JF Jr, Chow WH. Global increases in kidney cancer incidence, 1973-1992. Eur J Cancer Prev. 2002;11(2):171-8. [pmid: 11984136].
6 Nguyen MM, Gill IS, Ellison LM. The evolving presentation of renal carcinoma in the United States: trends from the Surveillance, Epidemiology, and End Results program. J Urol. 2006;176(6 Pt 1):2397-400. discussion 2400. [pmid: 17085111].
7 Kane CJ, Mallin K, Ritchey J, Cooperberg MR, Carroll PR. Renal cell cancer stage migration: analysis of the National Cancer Data Base. Cancer. 2008;113(1):78-83. [pmid: 18491376].
8 Frank I, Blute ML, Leibovich BC, Cheville JC, Lohse CM, Zincke H. Independent validation of the 2002 American Joint Committee on cancer primary tumor classification for renal cell carcinoma using a large, single institution cohort. J Urol. 2005;173(6):1889-92. [pmid: 15879769].
9 Ficarra V, Schips L, Guille F, et al. Multiinstitutional European validation of the 2002 TNM staging system in conventional and papillary localized renal cell carcinoma. Cancer. 2005;104(5):968-74. [pmid: 16007683].
10 Rothman J, Egleston B, Wong YN, et al. Histopathological characteristics of localized renal cell carcinoma correlate with tumor size: a SEER analysis. J Urol. 2009;181(1):29-33. PMID:. [pmid: 19012902].
11 Campbell SC, Novick AC, Belldegrun A, et al. Guideline for management of the clinical T1 renal mass. J Urol. 2009;182(4):1271-9. [pmid: 19683266].
12 Pierorazio PM, Hyams ES, Lin BM, Mullins JK, Allaf ME. Laparoscopic radical nephrectomy for large renal masses: critical assessment of perioperative and oncologic outcomes of stage T2a and T2b tumors. Urology. 2012;79(3):570-5. [pmid: 22386399].
13 Long JA, Arnoux V, Fiard G, et al. External validation of the RENAL nephrometry score in renal tumours treated by partial nephrectomy. BJU Int. 2013;111(2):233-9. [pmid: 22788546].
14 Kanao K, Mizuno R, Kikuchi E, et al. Preoperative prognostic nomogram (probability table) for renal cell carcinoma based on TNM classification. J Urol. 2009;181(2):480-5. discussion 485. [pmid: 19100568].
15 Haggstrom C, Rapp K, Stocks T, et al. Metabolic factors associated with risk of renal cell carcinoma. PLoS One. 2013;8(2):e57475. [pmid: 23468995].
16 Yaycioglu O, Eskicorapci S, Karabulut E, et al. A preoperative prognostic model predicting recurrence-free survival for patients with kidney cancer. Jpn J Clin Oncol. 2013;43(1):63-8. [pmid: 23159766].
17 Karakiewicz PI, Suardi N, Capitanio U, et al. A preoperative prognostic model for patients treated with nephrectomy for renal cell carcinoma. Eur Urol. 2009;55(2):287-95. [pmid: 18715700].
18 Kutikov A, Smaldone MC, Egleston BL, et al. Anatomic features of enhancing renal masses predict malignant and high-grade pathology: a preoperative nomogram using the RENAL Nephrometry score. Eur Urol. 2011;60(2):241-8. [pmid: 21458155].
19 Cindolo L, de la Taille A, Messina G, et al. A preoperative clinical prognostic model for non-metastatic renal cell carcinoma. BJU Int. 2003;92(9):901-5. [pmid: 14632843].
20 Pierorazio PM, Hyams ES, Tsai S, et al. Multiphasic enhancement patterns of small renal masses (</=4 cm) on preoperative computed tomography: utility for distinguishing subtypes of renal cell carcinoma, angiomyolipoma, and oncocytoma. Urology. 2013;81(6):1265-71. [pmid: 23601445].
21 Snyder ME, Bach A, Kattan MW, Raj GV, Reuter VE, Russo P. Incidence of benign lesions for clinically localized renal masses smaller than 7 cm in radiological diameter: influence of sex. J Urol. 2006;176(6 Pt 1):2391-5. discussion 2395-6. [pmid: 17085108].
22 Young JR, Margolis D, Sauk S, Pantuck AJ, Sayre J, Raman SS. Clear cell renal cell carcinoma: discrimination from other renal cell carcinoma subtypes and oncocytoma at multiphasic multidetector CT. Radiology. 2013;267(2):444-53. [pmid: 23382290].
23 Mullins JK, Kaouk JH, Bhayani S, et al. Tumor complexity predicts malignant disease for small renal masses. J Urol. 2012;188(6):2072-6. [pmid: 23083863].
24 Leveridge MJ, Finelli A, Kachura JR, et al. Outcomes of small renal mass needle core biopsy, nondiagnostic percutaneous biopsy, and the role of repeat biopsy. Eur Urol. 2011;60(3):578-84. [pmid: 21704449].
25 Ljungberg B, Cowan NC, Hanbury DC, et al. EAU guidelines on renal cell carcinoma: the 2010 update. Eur Urol. 2010;58(3):398-406. [pmid: 20633979].
26 National Comprehensive Cancer Network (NCCN). NCCN Clinical Practice Guidelines in Oncology (NCCN Guidelines). [Web Page]. Available at http://www.nccn.org/professionals/physician_gls/f_guidelines_nojava.asp. September 2014.
27 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective, randomised EORTC intergroup phase 3 study comparing the oncologic outcome of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Eur Urol. 2011;59(4):543-52. [pmid: 21186077].
28 Aziz A, May M, Zigeuner R, et al. Do young patients with renal cell carcinoma feature a distinct outcome after surgery? A comparative analysis of patient age based on the multinational CORONA database. J Urol. 2014;191(2):310-5. [pmid: 23973516].
29 Kim EH, Tanagho YS, Saad NE, Bhayani SB, Figenshau RS. Comparison of laparoscopic and percutaneous cryoablation for treatment of renal masses. Urology. 2014;83(5):1081-7. [pmid: 24560975].
30 Huang WC, Levey AS, Serio AM, et al. Chronic kidney disease after nephrectomy in patients with renal cortical tumours: a retrospective cohort study. Lancet Oncol. 2006;7(9):735-40. [pmid: 16945768].
31 Kim EH, Tanagho YS, Bhayani SB, Saad NE, Benway BM, Figenshau RS. Percutaneous cryoablation of renal masses: Washington University experience of treating 129 tumours. BJU Int. 2013;111(6):872-9. [pmid: 23145500].
32 National Guidline Clearinghouse. ACR Appropriateness Criteria® indeterminate renal mass. [Web Page]. Available at http://www.guideline.gov/content.aspx?f=rss&id=48291&osrc=12. September 2014.
33 Demirjian S, Lane BR, Derweesh IH, Takagi T, Fergany A, Campbell SC. Chronic Kidney Disease Due to Surgical Removal of Nephrons: Relative Rates of Progression and Survival. J Urol. 2014. [pmid: 24747655].
34 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No.10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
35 Higgins JPT, Green S, editors. Cochrane handbook for systemic reviews of interventions Version 5.1.0. The Cochrane Collaboration. 2011. Oxford, England. [cited 2013 11/4]. Available from:http://handbook.cochrane.org.
36 Sterne JAC, H J, R B, obotdgfA. A Cochrane Risk Of Bias Assessment Tool: for Non-Randomized Studies of Interventions (ACROBATNRSI), Version 1.0.0. 24. September. 2014. Available from http://www.riskofbias.info.
37 Whiting PF, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
38 Marubini E, Valsecchi MG. Analysing Survival Data from Clinical Trials and Observational Studies. 1995.
39 Dindo D. Classification of surgical complications: a new proposal with evaluation in a cohort of 6336 patients and results of a survey. Ann Surg. 2004;244:931-7.
40 Fujita T, Iwamura M, Wakatabe Y, et al. Predictors of benign histology in clinical T1a renal cell carcinoma tumors undergoing partial nephrectomy. Int J Urol. 2014;21(1):100-2. [pmid: 23635425].
41 Kava BR, Eldefrawy A, Ayyathurai R, et al. Impact of body mass index and tumor location on the incidence of benign histology at the time of nephron-sparing surgery. Int Urol Nephrol. 2012;44(5):1319-24. [pmid: 22678516].
42 Mullins JK, Kaouk JH, Bhayani S, et al. Tumor complexity predicts malignant disease for small renal masses. J Urol. 2012;188(6):2072-6. [pmid: 23083863].
43 Ball MW, Gorin MA, Bhayani SB, et al. Preoperative predictors of malignancy and unfavorable pathology for clinical T1a tumors treated with partial nephrectomy: A multi-institutional analysis. Urol Oncol Semin Orig Invest. 2015;33(3):112.e9-112.e14.
44 Nishikawa M, Miyake H, Kitajima K, Takahashi S, Sugimura K, Fujisawa M. Preoperative differentiation between benign and malignant renal masses smaller than 4 cm treated with partial nephrectomy. Int J Clin Oncol. 2014. [pmid: 24526391].
45 Koo KC, Yoo H, Shin TY, et al. External validation of the RENAL nephrometry score nomogram for predicting high-grade renal cell carcinoma in solid, enhancing, and small renal masses. World J Urol. 2014;32(1):249-55. [pmid: 24013182].
46 Soga N, Nishikawa K, Takaki H, et al. Low incidence of benign lesions in resected suspicious renal masses greater than 2 cm: Single-center experience from Japan. Int J Urol. 2012;19(8):729-34. [pmid: 22515572].
47 Park SY, Jeon SS, Lee SY, et al. Incidence and predictive factors of benign renal lesions in Korean patients with preoperative imaging diagnoses of renal cell carcinoma. J Korean Med Sci. 2011;26(3):360-4. [pmid: 21394303].
48 Xiong YH, Zhang ZL, Li YH, et al. Benign pathological findings in 303 Chinese patients undergoing surgery for presumed localized renal cell carcinoma. Int J Urol. 2010;17(6):517-21. [pmid: 20370841].
49 Jeon HG, Lee SR, Kim KH, et al. Benign lesions after partial nephrectomy for presumed renal cell carcinoma in masses 4 cm or less: prevalence and predictors in Korean patients. Urology. 2010;76(3):574-9. [pmid: 20303148].
50 Chung MS, Choi HJ, Kim MH, Cho KS. Comparison of T2-weighted MRI with and without fat suppression for differentiating renal angiomyolipomas without visible fat from other renal tumors. AJR Am J Roentgenol. 2014;202(4):765-71. [pmid: 24660704].
51 Park SY, Park BK, Kim CK, Kwon GY. Ultrasound-guided core biopsy of small renal masses: diagnostic rate and limitations. J Vasc Interv Radiol. 2013;24(1):90-6. [pmid: 23206333].
52 Shin TY, Kim J, Koo KC, et al. Assessing the anatomical characteristics of renal masses has a limited effect on the prediction of pathological outcomes in solid, enhancing, small renal masses: Results using the PADUA classification system. BJU Int. 2014;113(5):754-61. [pmid: 24053790].
53 Keehn A, Srivastava A, Maiman R, et al. The Relationship Between Visceral Obesity and the Clinicopathologic Features of Patients with Small Renal Masses. J Endourol. 2014. [pmid: 25203393].
54 Bazzi WM, Dejbakhsh SZ, Bernstein M, Russo P. The association of baseline health and gender with small renal mass pathology. Can J Urol. 2014;21(3):7271-6. [pmid: 24978356].
55 Antonelli A, Furlan M, Sandri M, et al. The R.e.N.a.L. Nephrometric nomogram cannot accurately predict malignancy or aggressiveness of small renal masses amenable to partial nephrectomy. Clin Genitourin Cancer. 2014;12(5):366-72. [pmid: 24637340].
56 Murphy AM, Buck AM, Benson MC, McKiernan JM. Increasing detection rate of benign renal tumors: evaluation of factors predicting for benign tumor histologic features during past two decades. Urology. 2009;73(6):1293-7. [pmid: 19371933].
57 Lane BR, Babineau D, Kattan MW, et al. A preoperative prognostic nomogram for solid enhancing renal tumors 7 cm or less amenable to partial nephrectomy. J Urol. 2007;178(2):429-34. [pmid: 17561141].
58 Rosenkrantz AB, Wehrli NE, Melamed J, Taneja SS, Shaikh MB. Renal masses measuring under 2 cm: Pathologic outcomes and associations with MRI features. Eur J Radiol. 2014;83(8):1311-6. [pmid: 24882784].
59 Akdogan B, Gudeloglu A, Inci K, Gunay LM, Koni A, Ozen H. Prevalence and predictors of benign lesions in renal masses smaller than 7 cm presumed to be renal cell carcinoma. Clin Genitourin Cancer. 2012;10(2):121-5. [pmid: 22401753].
60 Choi SK, Jeon SH, Chang SG. Characterization of small renal masses less than 4 cm with quadriphasic multidetector helical computed tomography: differentiation of benign and malignant lesions. Korean J Urol. 2012;53(3):159-64. [pmid: 22468210].
61 Campbell SC, Novick AC, Herts B, et al. Prospective evaluation of fine needle aspiration of small, solid renal masses: accuracy and morbidity. Urology. 1997;50(1):25-9. [pmid: 9218014].
62 Chyhrai A, Sanjmyatav J, Gajda M, et al. Multi-colour FISH on preoperative renal tumour biopsies to confirm the diagnosis of uncertain renal masses. World J Urol. 2010;28(3):269-74. [pmid: 20390284].
63 Halverson SJ, Kunju LP, Bhalla R, et al. Accuracy of determining small renal mass management with risk stratified biopsies: confirmation by final pathology. J Urol. 2013;189(2):441-6. [pmid: 23253955].
64 Harisinghani MG, Maher MM, Gervais DA, et al. Incidence of malignancy in complex cystic renal masses (Bosniak category III): should imaging-guided biopsy precede surgery?. AJR Am J Roentgenol. 2003;180(3):755-8. [pmid: 12591691].
65 Leveridge MJ, Finelli A, Kachura JR, et al. Outcomes of small renal mass needle core biopsy, nondiagnostic percutaneous biopsy, and the role of repeat biopsy. Eur Urol. 2011;60(3):578-84. [pmid: 21704449].
66 Londono DC, Wuerstle MC, Thomas AA, et al. Accuracy and implications of percutaneous renal biopsy in the management of renal masses. Perm J. 2013;17(3):4-7. [pmid: 24355883].
67 Menogue SR, O'Brien BA, Brown AL, Cohen RJ. Percutaneous core biopsy of small renal mass lesions: a diagnostic tool to better stratify patients for surgical intervention. BJU Int. 2013;111(4 Pt B):E146-51. [pmid: 22805186].
68 Millet I, Curros F, Serre I, Taourel P, Thuret R. Can renal biopsy accurately predict histological subtype and Fuhrman grade of renal cell carcinoma?. J Urol. 2012;188(5):1690-4. [pmid: 22998910].
69 Neuzillet Y, Lechevallier E, Andre M, Daniel L, Coulange C. Accuracy and clinical role of fine needle percutaneous biopsy with computerized tomography guidance of small (less than 4.0 cm) renal masses. J Urol. 2004;171(5):1802-5. [pmid: 15076280].
70 Salem S, Ponsky LE, Abouassaly R, et al. Image-guided biopsy of small renal masses in the era of ablative therapies. Int J Urol. 2013;20(6):580-4. [pmid: 23190309].
71 Shannon BA, Cohen RJ, de Bruto H, Davies RJ. The Value of Preoperative Needle Core Biopsy for Diagnosing Benign Lesions Among Small, Incidentally Detected Renal Masses. J Urol. 2008;180(4):1257-61. [pmid: 18707712].
72 Sofikerim M, Tatlisen A, Canoz O, Tokat F, Demirtas A, Mavili E. What is the role of percutaneous needle core biopsy in diagnosis of renal masses?. Urology. 2010;76(3):614-8. [pmid: 20110106].
73 Vasudevan A, Davies RJ, Shannon BA, Cohen RJ. Incidental renal tumours: the frequency of benign lesions and the role of preoperative core biopsy. BJU Int. 2006;97(5):946-9. [pmid: 16643475].
74 Volpe A, Mattar K, Finelli A, et al. Contemporary results of percutaneous biopsy of 100 small renal masses: a single center experience. J Urol. 2008;180(6):2333-7. [pmid: 18930274].
75 Wang R, Wolf JS Jr, Wood DP Jr, Higgins EJ, Hafez KS. Accuracy of percutaneous core biopsy in management of small renal masses. Urology. 2009;73(3):586-90. discussion 590-1. [pmid: 19118884].
76 Reichelt O, Gajda M, Chyhrai A, Wunderlich H, Junker K, Schubert J. Ultrasound-guided biopsy of homogenous solid renal masses. Eur Urol. 2007;52(5):1421-6. [pmid: 17306920].
77 Schmidbauer J, Remzi M, Memarsadeghi M, et al. Diagnostic accuracy of computed tomography-guided percutaneous biopsy of renal masses. Eur Urol. 2008;53(5):1003-11. [pmid: 18061339].
78 Richard PO, Jewett MA, Bhatt JR, et al. Renal Tumor Biopsy for Small Renal Masses: A Single-center 13-year Experience. Eur Urol. 2015. [pmid: 25900781].
79 Prince J, Bultman E, Hinshaw L, et al. Patient and Tumor Characteristics can Predict Nondiagnostic Renal Mass Biopsy Findings. J Urol. 2014. [pmid: 25498574].
80 Parker PA, Swartz R, Fellman B, et al. Comprehensive assessment of quality of life and psychosocial adjustment in patients with renal tumors undergoing open, laparoscopic and nephron sparing surgery. J Urol. 2012;187(3):822-6. [pmid: 22245327].
81 Ficarra V, Novella G, Sarti A, et al. Psycho-social well-being and general health status after surgical treatment for localized renal cell carcinoma. Int Urol Nephrol. 2002-2003;34(4):441-6. [pmid: 14577481].
82 Shinohara N, Harabayashi T, Sato S, Hioka T, Tsuchiya K, Koyanagi T. Impact of nephron-sparing surgery on quality of life in patients with localized renal cell carcinoma. Eur Urol. 2001;39(1):114-9. [pmid: 11173949].
83 Gratzke C, Seitz M, Bayrle F, et al. Quality of life and perioperative outcomes after retroperitoneoscopic radical nephrectomy (RN), open RN and nephron-sparing surgery in patients with renal cell carcinoma. BJU Int. 2009;104(4):470-5. [pmid: 19239445].
84 Jewett MA, Mattar K, Basiuk J, et al. Active surveillance of small renal masses: progression patterns of early stage kidney cancer. Eur Urol. 2011;60(1):39-44. [pmid: 21477920].
85 Pierorazio PM, Johnson MH, Ball MW, et al. Five-year Analysis of a Multi-institutional Prospective Clinical Trial of Delayed Intervention and Surveillance for Small Renal Masses: The DISSRM Registry. Eur Urol. 2015.
86 Crispen PL, Viterbo R, Boorjian SA, Greenberg RE, Chen DY, Uzzo RG. Natural history, growth kinetics, and outcomes of untreated clinically localized renal tumors under active surveillance. Cancer. 2009;115(13):2844-52. [pmid: 19402168].
87 Crispen PL, Wong YN, Greenberg RE, Chen DY, Uzzo RG. Predicting growth of solid renal masses under active surveillance. Urol Oncol. 2008;26(5):555-9. [pmid: 18774473].
88 Kunkle DA, Crispen PL, Chen DY, Greenberg RE, Uzzo RG. Enhancing renal masses with zero net growth during active surveillance. J Urol. 2007;177(3):849-53. discussion 853-4. [pmid: 17296355].
89 Scosyrev E, Messing EM, Sylvester R, Campbell S, Van Poppel H. Renal function after nephron-sparing surgery versus radical nephrectomy: results from EORTC randomized trial 30904. Eur Urol. 2014;65(2):372-7. [pmid: 23850254].
90 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective, randomised EORTC intergroup phase 3 study comparing the oncologic outcome of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Eur Urol. 2011;59(4):543-52. [pmid: 21186077].
91 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective randomized EORTC intergroup phase 3 study comparing the complications of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Eur Urol. 2007;51(6):1606-15. [pmid: 17140723].
92 Weight CJ, Larson BT, Fergany AF, et al. Nephrectomy induced chronic renal insufficiency is associated with increased risk of cardiovascular death and death from any cause in patients with localized cT1b renal masses. J Urol. 2010;183(4):1317-23. [pmid: 20171688].
93 Snow DC, Bhayani SB. Rapid communication: chronic renal insufficiency after laparoscopic partial nephrectomy and radical nephrectomy for pathologic t1a lesions. J Endourol. 2008;22(2):337-41. [pmid: 18257672].
94 Kim CS, Bae EH, Ma SK, Kweon SS, Kim SW. Impact of partial nephrectomy on kidney function in patients with renal cell carcinoma. BMC Nephrol. 2014;15:181. [pmid: 25410757].
95 Shuch B, Hanley J, Lai J, et al. Overall survival advantage with partial nephrectomy: a bias of observational data?. Cancer. 2013;119(16):2981-9. [pmid: 23674264].
96 Lucas SM, Stern JM, Adibi M, Zeltser IS, Cadeddu JA, Raj GV. Renal function outcomes in patients treated for renal masses smaller than 4 cm by ablative and extirpative techniques. J Urol. 2008;179(1):75-9. discussion 79-80. [pmid: 17997440].
97 Antonelli A, Ficarra V, Bertini R, et al. Elective partial nephrectomy is equivalent to radical nephrectomy in patients with clinical T1 renal cell carcinoma: results of a retrospective, comparative, multi-institutional study. BJU Int. 2012;109(7):1013-8. [pmid: 21883829].
98 Barbalias GA, Liatsikos EN, Tsintavis A, Nikiforidis G. Adenocarcinoma of the kidney: nephron-sparing surgical approach vs. radical nephrectomy. J Surg Oncol. 1999;72(3):156-61. [pmid: 10562362].
99 Bedke J, Pritsch M, Buse S, et al. Prognostic stratification of localized renal cell carcinoma by tumor size. J Urol. 2008;180(1):62-7. [pmid: 18485376].
100 Thompson RH, Siddiqui S, Lohse CM, Leibovich BC, Russo P, Blute ML. Partial versus radical nephrectomy for 4 to 7 cm renal cortical tumors. J Urol. 2009;182(6):2601-6. [pmid: 19836797].
101 Iizuka J, Kondo T, Hashimoto Y, et al. Similar functional outcomes after partial nephrectomy for clinical T1b and T1a renal cell carcinoma. Int J Urol. 2012;19(11):980-6. [pmid: 22735049].
102 Indudhara R, Bueschen AJ, Urban DA, Burns JR, Lloyd LK. Nephron-sparing surgery compared with radical nephrectomy for renal tumors: current indications and results. South Med J. 1997;90(10):982-5. [pmid: 9347807].
103 Kopp RP, Mehrazin R, Palazzi KL, et al. Survival outcomes after radical and partial nephrectomy for clinical T2 renal tumours categorised by R.E.N.A.L. nephrometry score. BJU Int. 2013. [pmid: 24274650].
104 Kyung YS, You D, Kwon T, et al. The type of nephrectomy has little effect on overall survival or cardiac events in patients of 70 years and older with localized clinical t1 stage renal masses. Korean J Urol. 2014;55(7):446-52. [pmid: 25045442].
105 Lane BR, Fergany AF, Weight CJ, Campbell SC. Renal functional outcomes after partial nephrectomy with extended ischemic intervals are better than after radical nephrectomy. J Urol. 2010;184(4):1286-90. [pmid: 20723936].
106 Li JR, Yang CR, Cheng CL, et al. Partial nephrectomy in the treatment of localized renal cell carcinoma: experience of Taichung Veterans General Hospital. J Chin Med Assoc. 2007;70(7):281-5. [pmid: 17631464].
107 Mariusdottir E, Jonsson E, Marteinsson VT, Sigurdsson MI, Gudbjartsson T. Kidney function following partial or radical nephrectomy for renal cell carcinoma: a population-based study. Scand J Urol. 2013;47(6):476-82. [pmid: 23597159].
108 Medina-Polo J, Romero-Otero J, Rodriguez-Antolin A, et al. Can partial nephrectomy preserve renal function and modify survival in comparison with radical nephrectomy?. Scand J Urol Nephrol. 2011;45(2):143-50. [pmid: 21247272].
109 Milonas D, Skulcius G, Baltrimavicius R, et al. Comparison of long-term results after nephron-sparing surgery and radical nephrectomy in treating 4- to 7-cm renal cell carcinoma. Medicina (Kaunas). 2013;49(5):223-8. [pmid: 24247918].
110 Minervini A, Serni S, Tuccio A, et al. Simple enucleation versus radical nephrectomy in the treatment of pT1a and pT1b renal cell carcinoma. Ann Surg Oncol. 2012;19(2):694-700. [pmid: 21861225].
111 Mitchell RE, Gilbert SM, Murphy AM, Olsson CA, Benson MC, McKiernan JM. Partial nephrectomy and radical nephrectomy offer similar cancer outcomes in renal cortical tumors 4 cm or larger. Urology. 2006;67(2):260-4. [pmid: 16461075].
112 Patard JJ, Shvarts O, Lam JS, et al. Safety and efficacy of partial nephrectomy for all T1 tumors based on an international multicenter experience. J Urol. 2004;171(6 Pt 1):2181-5. quiz 2435. [pmid: 15126781].
113 Roos FC, Brenner W, Jager W, et al. Perioperative morbidity and renal function in young and elderly patients undergoing elective nephron-sparing surgery or radical nephrectomy for renal tumours larger than 4 cm. BJU Int. 2011;107(4):554-61. [pmid: 20707798].
114 Roos FC, Brenner W, Thomas C, et al. Functional analysis of elective nephron-sparing surgery vs radical nephrectomy for renal tumors larger than 4 cm. Urology. 2012;79(3):607-13. [pmid: 22386408].
115 Uchida K, Takahashi A, Masumori N, Yanase M, Itoh N, Tsukamoto T. Partial nephrectomy for small localized renal cell carcinoma. Hinyokika Kiyo. 2004;50(6):389-95. [pmid: 15293735].
116 Uzzo RG, Wei JT, Hafez K, Kay R, Novick AC. Comparison of direct hospital costs and length of stay for radical nephrectomy versus nephron-sparing surgery in the management of localized renal cell carcinoma. Urology. 1999;54(6):994-8. [pmid: 10604696].
117 Weight CJ, Lythgoe C, Unnikrishnan R, Lane BR, Campbell SC, Fergany AF. Partial nephrectomy does not compromise survival in patients with pathologic upstaging to pT2/pT3 or high-grade renal tumors compared with radical nephrectomy. Urology. 2011;77(5):1142-6. [pmid: 21420154].
118 Deklaj T, Lifshitz DA, Shikanov SA, Katz MH, Zorn KC, Shalhav AL. Laparoscopic radical versus laparoscopic partial nephrectomy for clinical T1bN0M0 renal tumors: comparison of perioperative, pathological, and functional outcomes. J Endourol. 2010;24(10):1603-7. [pmid: 20932215].
119 Kim FJ, Rha KH, Hernandez F, Jarrett TW, Pinto PA, Kavoussi LR. Laparoscopic radical versus partial nephrectomy: assessment of complications. J Urol. 2003;170(2 Pt 1):408-11. [pmid: 12853787].
120 Janetschek G, Jeschke K, Peschel R, Strohmeyer D, Henning K, Bartsch G. Laparoscopic surgery for stage T1 renal cell carcinoma: radical nephrectomy and wedge resection. Eur Urol. 2000;38(2):131-8. [pmid: 10895002].
121 McKiernan J, Simmons R, Katz J, Russo P. Natural history of chronic renal insufficiency after partial and radical nephrectomy. Urology. 2002;59(6):816-20. [pmid: 12031359].
122 Chang X, Zhang F, Liu T, et al. Radiofrequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: long-term clinical and oncologic outcomes. J Urol. 2014. [pmid: 25106899].
123 Klatte T, Mauermann J, Heinz-Peer G, et al. Perioperative, oncologic, and functional outcomes of laparoscopic renal cryoablation and open partial nephrectomy: a matched pair analysis. J Endourol. 2011;25(6):991-7. [pmid: 21568698].
124 Stern JM, Svatek R, Park S, et al. Intermediate comparison of partial nephrectomy and radiofrequency ablation for clinical T1a renal tumours. BJU Int. 2007;100(2):287-90. [pmid: 17617136].
125 Tanagho YS, Bhayani S, Kim EH, Figenshau RS. Renal Cryoablation versus Robot-Assisted Partial Nephrectomy:Washington University Long-Term Experience. J Endourol. 2013.
126 Mues AC, Korets R, Graversen JA, et al. Clinical, pathologic, and functional outcomes after nephron-sparing surgery in patients with a solitary kidney: a multicenter experience. J Endourol. 2012;26(10):1361-6. [pmid: 22667344].
127 Thompson RH, Atwell T, Schmit G, et al. Comparison of Partial Nephrectomy and Percutaneous Ablation for cT1 Renal Masses. Eur Urol. 2014. [pmid: 25108580].
128 Youn CS, Park JM, Lee JY, et al. Comparison of laparoscopic radiofrequency ablation and open partial nephrectomy in patients with a small renal mass. Korean J Urol. 2013;54(9):603-8. [pmid: 24044094].
129 Guillotreau J, Haber GP, Autorino R, et al. Robotic partial nephrectomy versus laparoscopic cryoablation for the small renal mass. Eur Urol. 2012;61(5):899-904. [pmid: 22264680].
130 Bensalah K, Zeltser I, Tuncel A, Cadeddu J, Lotan Y. Evaluation of costs and morbidity associated with laparoscopic radiofrequency ablation and laparoscopic partial nephrectomy for treating small renal tumours. BJU Int. 2008;101(4):467-71. [pmid: 17922853].
131 Desai MM, Aron M, Gill IS. Laparoscopic partial nephrectomy versus laparoscopic cryoablation for the small renal tumor. Urology. 2005;66(5 Suppl):23-8. [pmid: 16194703].
132 Emara AM, Kommu SS, Hindley RG, Barber NJ. Robot-assisted partial nephrectomy vs laparoscopic cryoablation for the small renal mass: redefining the minimally invasive ‘gold standard’. BJU Int. 2014;113(1):92-9. [pmid: 24053473].
133 Haramis G, Graversen JA, Mues AC, et al. Retrospective comparison of laparoscopic partial nephrectomy versus laparoscopic renal cryoablation for small (<3.5 cm) cortical renal masses. J Laparoendosc Adv Surg Tech A. 2012;22(2):152-7. [pmid: 22145574].
134 Takaki H, Soga N, Kanda H, et al. Radiofrequency ablation versus radical nephrectomy: clinical outcomes for stage T1b renal cell carcinoma. Radiology. 2014;270(1):292-9. [pmid: 23925272].
135 Lane BR, Abouassaly R, Gao T, et al. Active treatment of localized renal tumors may not impact overall survival in patients aged 75 years or older. Cancer. 2010;116(13):3119-26. [pmid: 20564627].
136 Olweny EO, Park SK, Tan YK, Best SL, Trimmer C, Cadeddu JA. Radiofrequency ablation versus partial nephrectomy in patients with solitary clinical T1a renal cell carcinoma: comparable oncologic outcomes at a minimum of 5 years of follow-up. Eur Urol. 2012;61(6):1156-61. [pmid: 22257424].
137 Haber GP, Lee MC, Crouzet S, Kamoi K, Gill IS. Tumour in solitary kidney: laparoscopic partial nephrectomy vs laparoscopic cryoablation. BJU Int. 2012;109(1):118-24. [pmid: 21895929].
138 Turna B, Kaouk JH, Frota R, et al. Minimally invasive nephron sparing management for renal tumors in solitary kidneys. J Urol. 2009;182(5):2150-7. [pmid: 19758655].
139 Chung JS, Son NH, Lee SE, et al. Overall survival and renal function after partial and radical nephrectomy among older patients with localised renal cell carcinoma: A propensity-matched multicentre study. Eur J Cancer. 2015;51(4):489-97. [pmid: 25576517].
140 Li Q, Guan H, Qin J, Jiang T. Mini-Margin nephron sparing surgery for renal cell carcinoma 4 cm or less. Adv Urol. 2010. [pmid: 20862196].
141 Badalato GM, Kates M, Wisnivesky JP, Choudhury AR, McKiernan JM. Survival after partial and radical nephrectomy for the treatment of stage T1bN0M0 renal cell carcinoma (RCC) in the USA: a propensity scoring approach. BJU Int. 2012;109(10):1457-62. [pmid: 21933334].
142 Choueiri TK, Schutz FA, Hevelone ND, et al. Thermal ablation vs surgery for localized kidney cancer: a Surveillance, Epidemiology, and End Results (SEER) database analysis. Urology. 2011;78(1):93-8. [pmid: 21550636].
143 Crepel M, Jeldres C, Perrotte P, et al. Nephron-sparing surgery is equally effective to radical nephrectomy for T1BN0M0 renal cell carcinoma: a population-based assessment. Urology. 2010;75(2):271-5. [pmid: 19962740].
144 Daugherty M, Bratslavsky G. Compared with radical nephrectomy, nephron-sparing surgery offers a long-term survival advantage in patients between the ages of 20 and 44 years with renal cell carcinomas (</=4 cm): an analysis of the SEER database. Urol Oncol. 2014;32(5):549-54. [pmid: 24495447].
145 Huang WC, Elkin EB, Levey AS, Jang TL, Russo P. Partial nephrectomy versus radical nephrectomy in patients with small renal tumors--is there a difference in mortality and cardiovascular outcomes?. J Urol. 2009;181(1):55-61. discussion 61-2. [pmid: 19012918].
146 Meskawi M, Becker A, Bianchi M, et al. Partial and radical nephrectomy provide comparable long-term cancer control for T1b renal cell carcinoma. Int J Urol. 2014;21(2):122-8. [pmid: 23819700].
147 Patel HD, Kates M, Pierorazio PM, et al. Survival after diagnosis of localized T1a kidney cancer: current population-based practice of surgery and nonsurgical management. Urology. 2014;83(1):126-32. [pmid: 24246317].
148 Patel HD, Kates M, Pierorazio PM, Allaf ME. Balancing cardiovascular (CV) and cancer death among patients with small renal masses: modification by CV risk. BJU Int. 2014. [pmid: 24589376].
149 Sun M, Becker A, Tian Z, et al. Management of localized kidney cancer: calculating cancer-specific mortality and competing risks of death for surgery and nonsurgical management. Eur Urol. 2014;65(1):235-41. [pmid: 23567066].
150 Tan HJ, Norton EC, Ye Z, Hafez KS, Gore JL, Miller DC. Long-term survival following partial vs radical nephrectomy among older patients with early-stage kidney cancer. JAMA. 2012;307(15):1629-35. [pmid: 22511691].
151 Whitson JM, Harris CR, Meng MV. Population-based comparative effectiveness of nephron-sparing surgery vs ablation for small renal masses. BJU Int. 2012;110(10):1438-43. discussion 1443. [pmid: 22639860].
152 Crepel M, Jeldres C, Sun M, et al. A population-based comparison of cancer-control rates between radical and partial nephrectomy for T1A renal cell carcinoma. Urology. 2010;76(4):883-8. [pmid: 20932408].
153 Kates M, Badalato GM, Pitman M, McKiernan JM. Increased risk of overall and cardiovascular mortality after radical nephrectomy for renal cell carcinoma 2 cm or less. J Urol. 2011;186(4):1247-53. [pmid: 21849201].
154 Smaldone MC, Egleston B, Uzzo RG, Kutikov A. Does partial nephrectomy result in a durable overall survival benefit in the Medicare population?. J Urol. 2012;188(6):2089-94. [pmid: 23083877].
155 Zini L, Perrotte P, Capitanio U, et al. Radical versus partial nephrectomy: effect on overall and noncancer mortality. Cancer. 2009;115(7):1465-71. [pmid: 19195042].
156 Takagi T, Kondo T, Iizuka J, et al. Postoperative renal function after partial nephrectomy for renal cell carcinoma in patients with pre-existing chronic kidney disease: a comparison with radical nephrectomy. Int J Urol. 2011;18(6):472-6. [pmid: 21481013].
157 Thompson RH, Boorjian SA, Lohse CM, et al. Radical nephrectomy for pT1a renal masses may be associated with decreased overall survival compared with partial nephrectomy. J Urol. 2008;179(2):468-71. discussion 472-3. [pmid: 18076931].
158 Kim JM, Song PH, Kim HT, Park TC. Comparison of Partial and Radical Nephrectomy for pT1b Renal Cell Carcinoma. Korean J Urol. 2010;51(9):596-600. [pmid: 20856643].
159 Weight CJ, Larson BT, Gao T, et al. Elective partial nephrectomy in patients with clinical T1b renal tumors is associated with improved overall survival. Urology. 2010;76(3):631-7. [pmid: 20451967].
160 Takaki H, Yamakado K, Soga N, et al. Midterm results of radiofrequency ablation versus nephrectomy for T1a renal cell carcinoma. Jpn J Radiol. 2010;28(6):460-8. [pmid: 20661697].
161 Kowalczyk KJ, Choueiri TK, Hevelone ND, et al. Comparative effectiveness, costs and trends in treatment of small renal masses from 2005 to 2007. BJU Int. 2013;112(4):E273-80. [pmid: 23452093].
162 Deklaj T, Lifshitz DA, Shikanov SA, et al. Localized T1a renal lesions in the elderly: outcomes of laparoscopic renal surgery. J Endourol. 2010;24(3):397-401. [pmid: 20334557].
163 Foyil KV, Ames CD, Ferguson GG, et al. Longterm changes in creatinine clearance after laparoscopic renal surgery. J Am Coll Surg. 2008;206(3):511-5. [pmid: 18308223].
164 Cooper CJ, Teleb M, Dwivedi A, et al. Comparative Outcome of Computed Tomography-guided Percutaneous Radiofrequency Ablation, Partial Nephrectomy or Radical Nephrectomy in the Treatment of Stage T1 Renal Cell Carcinoma. Rare Tumors. 2015;7(1):5583. [pmid: 25918603].
165 Danzig MR, Chang P, Wagner AA, Pierorazio PM, Allaf ME, McKiernan JM. Active Surveillance is Superior to Radical Nephrectomy and Equivalent to Partial Nephrectomy in Preserving Renal Function Among Patients with Small Renal Masses; Results from the DISSRM Registry. J Urol. 2015. [pmid: 25813449].
166 Woldu SL, Weinberg AC, Korets R, et al. Who Really Benefits From Nephron-sparing Surgery?. Urology. 2014;84(4):860-8. [pmid: 25260447].
167 Yasuda Y, Yuasa T, Yamamoto S, et al. Evaluation of the RENAL nephrometry scoring system in adopting nephron-sparing surgery for cT1 renal cancer. Urol Int. 2013;90(2):179-83. [pmid: 23146865].
168 Miyamoto K, Inoue S, Kajiwara M, Teishima J, Matsubara A. Comparison of renal function after partial nephrectomy and radical nephrectomy for renal cell carcinoma. Urol Int. 2012;89(2):227-32. [pmid: 22846207].
169 Sun M, Bianchi M, Hansen J, et al. Chronic kidney disease after nephrectomy in patients with small renal masses: a retrospective observational analysis. Eur Urol. 2012;62(4):696-703. [pmid: 22483407].
170 Brewer K, O'Malley RL, Hayn M, et al. Perioperative and renal function outcomes of minimally invasive partial nephrectomy for T1b and T2a kidney tumors. J Endourol. 2012;26(3):244-8. [pmid: 22192099].
171 Antoniewicz AA, Poletajew S, Borowka A, Pasierski T, Rostek M, Pikto-Pietkiewicz W. Renal function and adaptive changes in patients after radical or partial nephrectomy. Int Urol Nephrol. 2012;44(3):745-51. [pmid: 21947980].
172 Jeon HG, Jeong IG, Lee JW, Lee SE, Lee E. Prognostic factors for chronic kidney disease after curative surgery in patients with small renal tumors. Urology. 2009;74(5):1064-8. [pmid: 19758688].
173 Zorn KC, Gong EM, Orvieto MA, et al. Comparison of laparoscopic radical and partial nephrectomy: effects on long-term serum creatinine. Urology. 2007;69(6):1035-40. [pmid: 17572181].
174 Huang WC, Levey AS, Serio AM, et al. Chronic kidney disease after nephrectomy in patients with renal cortical tumours: a retrospective cohort study. Lancet Oncol. 2006;7(9):735-40. [pmid: 16945768].
175 Dash A, Vickers AJ, Schachter LR, Bach AM, Snyder ME, Russo P. Comparison of outcomes in elective partial vs radical nephrectomy for clear cell renal cell carcinoma of 4-7 cm. BJU Int. 2006;97(5):939-45. [pmid: 16643474].
176 Matin SF, Gill IS, Worley S, Novick AC. Outcome of laparoscopic radical and open partial nephrectomy for the sporadic 4 cm. or less renal tumor with a normal contralateral kidney. J Urol. 2002;168(4 Pt 1):1356-9. discussion 1359-60. [pmid: 12352392].
177 Faddegon S, Ju T, Olweny EO, et al. A comparison of long term renal functional outcomes following partial nephrectomy and radiofrequency ablation. Can J Urol. 2013;20(3):6785-9. [pmid: 23783048].
178 Mitchell CR, Atwell TD, Weisbrod AJ, et al. Renal function outcomes in patients treated with partial nephrectomy versus percutaneous ablation for renal tumors in a solitary kidney. J Urol. 2011;186(5):1786-90. [pmid: 21944103].
179 Kiriluk KJ, Shikanov SA, Steinberg GD, Shalhav AL, Lifshitz DA. Laparoscopic partial nephrectomy versus laparoscopic ablative therapy: a comparison of surgical and functional outcomes in a matched control study. J Endourol. 2011;25(12):1867-72. [pmid: 21902540].
180 Chang X, Zhang F, Liu T, et al. Radio frequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: Long-term clinical and oncologic outcomes. J Urol. 2015;193(2):430-5. [pmid: 25106899].
181 Permpongkosol S, Link RE, Su LM, et al. Complications of 2,775 urological laparoscopic procedures: 1993 to 2005. J Urol. 2007;177(2):580-5. [pmid: 17222637].
182 Xu H, Ding Q, Jiang HW. Fewer complications after laparoscopic nephrectomy as compared to the open procedure with the modified Clavien classification system - a retrospective analysis from Southern China. World J Surg Oncol. 2014;12(1).
183 Becker A, Ravi P, Roghmann F, et al. Laparoscopic radical nephrectomy vs laparoscopic or open partial nephrectomy for T1 renal cell carcinoma: comparison of complication rates in elderly patients during the initial phase of adoption. Urology. 2014;83(6):1285-91. [pmid: 24862392].
184 Tomaszewski JJ, Uzzo RG, Kutikov A, et al. Assessing the burden of complications after surgery for clinically localized kidney cancer by age and comorbidity status. Urology. 2014;83(4):843-9. [pmid: 24680455].
185 Lowrance WT, Yee DS, Savage C, et al. Complications after radical and partial nephrectomy as a function of age. J Urol. 2010;183(5):1725-30. [pmid: 20299040].
186 Castaneda CV, Danzig MR, Finkelstein JB, et al. The natural history of renal functional decline in patients undergoing surveillance in the DISSRM registry. Urol Oncol Semin Orig Invest. 2015.
187 Leonard M, Tait CD, Gillan AS, Rai BP, Byrne DJ, Nabi G. Impact of multiple deprivations on detection, progression and interventions in small renal masses (less than 4 cm) in a population based study. Eur J Surg Oncol. 2013;39(10):1157-63. [pmid: 23886896].
188 Rosales JC, Haramis G, Moreno J, et al. Active surveillance for renal cortical neoplasms. J Urol. 2010;183(5):1698-702. [pmid: 20299038].
189 Abouassaly R, Lane BR, Novick AC. Active surveillance of renal masses in elderly patients. J Urol. 2008;180(2):505-8. discussion 508-9. [pmid: 18550113].
190 Parker PA, Alba F, Fellman B, et al. Illness uncertainty and quality of life of patients with small renal tumors undergoing watchful waiting: a 2-year prospective study. Eur Urol. 2013;63(6):1122-7. [pmid: 23419322].
191 O'Malley RL, Hayn MH, Brewer KA, et al. Cancer control of partial nephrectomy for high-risk localized renal cell carcinoma: population-based and single-institutional analysis. World J Urol. 2015. [pmid: 25805189].
192 Becker A, Pradel L, Kluth L, et al. Laparoscopic versus open partial nephrectomy for clinical T1 renal masses: no impact of surgical approach on perioperative complications and long-term postoperative quality of life. World J Urol. 2014. [pmid: 24879404].
193 Beemster PW, Wijkstra H, de la Rosette JJ, Zwinderman AH, Pes MP. Quality of life and perceived pain after laparoscopic-assisted renal cryoablation. J Endourol. 2010;24(5):713-9. [pmid: 20443715].
194 Rowe SP, Gorin MA, Gordetsky J, et al. Initial experience using 99mTc-MIBI SPECT/CT for the differentiation of oncocytoma from renal cell carcinoma. (1536-0229 (Electronic). 0363-9762 (Linking)).
195 Morrissey JJ, Mobley J, Figenshau RS, et al. Urine aquaporin 1 and perilipin 2 differentiate renal carcinomas from other imaged renal masses and bladder and prostate cancer: Initial experience using 99mTc-MIBI SPECT/CT for the differentiation of oncocytoma from renal cell carcinoma. Mayo Clinic Proc. Jan. 2015;90(1):35-42. [pmid: 25572193].