# Methods

The methods for this review follow the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”34

## Protocol Development

Representatives from the AUA posed the questions for this review. With feedback from these representatives, AHRQ representatives, our Key Informants, and Technical Expert Panel, we refined these questions and developed a protocol for this systematic review. Our protocol was registered on PROSPERO (CRD42015015878).

## Search Strategy

We searched MEDLINE, Embase^®^, and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 1997 (the year the TNM Classification of Malignant Tumor staging system for renal cell carcinoma was modified and the distinctions of T1a/T1b and T2a/T2b were created) through May 1, 2015. We developed a search strategy for MEDLINE, which was accessed via PubMed^®^ and based on medical subject headings (MeSH^®^) terms and text words of key articles (Appendix A), and we requested Scientific Information Packets from device manufacturers. There were no language restrictions in the search strategies. Additionally, we searched Clinicaltrials.gov to identify relevant registered trials.

## Study Selection

Study selection was based on predefined eligibility criteria of patient populations, interventions, outcome measures, and study design (see Tables 1 and 2). Abstracts were screened independently by two reviewers and were excluded if both reviewers agreed that one or more of the exclusion criteria was met (see the Abstract Screen Form in Appendix B). Differences between reviewers regarding abstract eligibility were resolved through consensus. We used DistillerSR (Evidence Partners, 2010) to manage the screening process.

Table 1 PICOTS (population, interventions, comparators, outcomes, timing, and setting) for the KQs

PICOTS | Diagnostic (KQs 1, 2a, and 2b) | Management (KQs 3a and 3b)
Population(s) | Newly diagnosed adults (18 years or older) with solid renal masses (or cystic renal masses with a solid component) suspicious for stage I and II renal cell carcinoma, which corresponds to clinical stage T1 (less than 7 cm and organ confined) or T2 (greater than 7 cm and organ confined) renal masses
Interventions | - Percutaneous renal mass sampling (fine needle aspiration or biopsy); - Composite models (e.g., combination of demographics, clinical characteristics, blood/urine tests, and tumor imaging characteristics) for predicting malignancy; - Demographic characteristics: age, sex, smoking, race, marital status, education; - Clinical characteristics: obesity and comorbidities, specifically cardiovascular disease and chronic kidney disease; - Blood/urine tests: measures of kidney function, markers of paraneoplastic syndromes and predictors of advanced/metastatic disease (e.g., complete metabolic panel, complete blood count, coagulation parameters, erythrocyte sedimentation rate); - Imaging characteristics: computed tomography, ultrasonography, magnetic resonance imaging | - Radical nephrectomy (open and minimally invasive); - Partial nephrectomy (open and minimally invasive); - Thermal ablation (e.g., radiofrequency ablation, cryoablation; surgical versus image-guided); - Active surveillance; - Minimally invasive surgery may refer to standard laparoscopy or robot-assisted laparoscopy; - No microwave ablation
Comparators | Comparisons are between biopsy results, composite models, and pathologic diagnosis after surgical intervention | Comparisons include all of the management options listed above
Outcomes | Diagnostic test-related Outcomes; - False positives; - False negatives; - Radiation exposure; Adverse effects of percutaneous renal mass sampling; - Pain; - Hemorrhage; - Tumor seeding | Final health outcomes; - Oncologic efficacy; ○ Local recurrence-free survival; ○ Metastasis-free survival; ○ Cancer-specific survival; - Renal functional outcomes; ○ Glomerular filtration rate decline; ○ Incidence of chronic kidney disease; ○ Incidence of end-stage renal disease; - Overall survival; - Quality of life; Adverse effects of management strategies; - Urologic complications; ○ Acute kidney Injury; ○ Hemorrhage; ○ Urine leak; ○ Hematuria; ○ Loss of kidney; ○ Ureteral injury (any injury of collecting system and ureter); ○ Urinary tract infection; - Nonurologic complications (by organ system); ○ Hematologic (thromboembolic); ○ Gastrointestinal; ○ Cardiovascular; ○ Respiratory; ○ Neurologic; ○ Wound complications (e.g. hernia and dehiscence); ○ Infectious disease; ○ Listed by severity of complications (using the Clavien Grading System if available):; ○ Minor versus major; – Minor (Clavien 1-2)^a^: conservative management or medications only; – Major (Clavien 3-4)^b^: requiring intervention, resulting in permanent disability or death; ○ Need for subsequent interventions: embolization, drain placement, stent placement, etc.; - Perioperative outcomes; ○ Blood loss (cc or mL); ○ Blood transfusion (yes or no); ○ Conversion to open surgery (%); ○ Conversion to radical nephrectomy (%); ○ Length of stay (days)
Type of study | Any study design except case report | Controlled studies (randomized controlled trials, nonrandomized controlled trials, and comparative cohort studies): All comparisons between interventions Uncontrolled studies (single cohort studies): Data from uncontrolled studies that addressed active surveillance are described in the report. Every other uncontrolled study that addressed KQ 3 is listed in the appendix with the following data:; - Author, publication year; - Study design; - Intervention name; - Number of patients; - Followup; - List of outcomes
Timing and Setting | Any time point and setting

KQ= Key Question

Clavien-Dindo system currently used for reporting of complications related to urologic surgical interventions:

a Grade I: Any deviation from the normal postoperative course without the need for pharmacological treatment or surgical, endoscopic and radiological interventions. Allowed therapeutic regimens are: drugs as antiemetics, antipyretics, analgetics, diuretics and electrolytes and physiotherapy. This grade also includes wound infections opened at the bedside.

a Grade II: Requiring pharmacological treatment with drugs other than such allowed for grade I complications. Blood transfusions and total parenteral nutrition are also included.

b Grade III: Requiring surgical, endoscopic or radiological intervention.

1. (a) not under general anesthesia
2. (b) under general anesthesia

b Grade IV: Life-threatening complication (including CNS complications) requiring IC/ICU-management.

1. (a) single organ dysfunction (including dialysis)
2. (b) multi-organ dysfunction

Table 2 List of exclusion criteria at the abstract screening, article screening, and KQ applicability levels

Exclusion criteria at abstract screening, article screening, and key question applicability levels | - Does not evaluate renal masses (solid renal masses (or cystic renal masses with a solid component) suspicious for stage I and II renal cell carcinoma, which corresponds to clinical stage T1 (≤ 7 cm, organ confined) or T2 (> 7 cm, organ confined) renal masses); - Patients with recurrent renal cell carcinoma; - Clinically nonlocalized patients; - Study published before 1997; - Not conducted in humans; - No original data (systematic reviews, meta-analysis, editorial, commentary); - Study of children only; - Not relevant to key questions
Additional exclusion criteria at the article screening and key question applicability levels | - Patients on hemodialysis and transplant; - Study focuses on familial carcinomas; - Evaluating novel techniques; - Tumor stage not specified^a^; - Study addresses KQ 1 but does not include imaging or one element from at least 2 of the categories - demographic characteristics, clinical characteristics, and blood/urine tests; - KQ 3a : Do not give an adequate description (Clavien grading ) of how complications and peri-operative outcomes were assessed or report only selected complications or peri-operative outcomes of interest unless primary objective of the study was to assess the complications; - Address management strategy question (KQ 3) but compare two different forms of the same management intervention (e.g., open partial nephrectomy vs robotic partial nephrectomy); - Does not provide any outcome of interest

a We included patents with clinically localized tumors but for partial nephrectomy and thermal ablation, we assumed patients had a clinically localized mass because nephron sparing treatments (partial nephrectomy, thermal ablation) are only indicated for clinically localized tumors, otherwise radical nephrectomy is indicated for advanced disease.

Citations promoted on the basis of the abstract screen underwent another independent screen using the full text of the articles. Additional exclusion criteria were applied at this level (see Table 2 and the Abstract Screen Form in Appendix B). Differences regarding citation eligibility were resolved through consensus.

Full text articles underwent an additional independent review by paired investigators to determine whether or not they should be included in the full data abstraction. (See the KQ Applicability Form in Appendix B).

## Data Abstraction and Data Management

We created and pilot tested data extraction forms in Excel (Microsoft, Redmond, WA, see Appendix B). Reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, gender, race/ethnicity, etc.), eligibility criteria, interventions, outcome measures, and the method of ascertainment, as well as the results of each outcome, including measures of variability.

One reviewer completed the data abstraction, and a second reviewer checked the first reviewer's abstraction for completeness and accuracy. We resolved differences through discussion and, as needed, through consensus among our team.

## Risk of Bias Assessment

Two reviewers independently assessed risk of bias for individual studies. We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies.35 For nonrandomized studies of treatment interventions, we used the Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).36 For diagnostic studies, we used the quality assessment tool for diagnostic accuracy studies (QUADAS -2).37 Differences between reviewers were resolved through consensus.

## Data Synthesis

For each KQ, we created a detailed set of evidence tables containing all of the information abstracted from eligible studies.

1. For KQ2, biopsies were considered diagnostic if sufficient tissue was obtained to demonstrate etiology of the renal lesion and nondiagnostic if insufficient tissue for diagnosis was obtained or benign renal parenchyma was found without an etiology for the renal lesion (e.g., benign fibrosis). The following definitions were used for diagnostic performance characteristics:
  a. Sensitivity: the proportion of all patients with malignancy identified as positive on biopsy (true positives divided by (true positives plus false negative));
  b. Specificity: the proportion of all patients without malignancy identified as negative on biopsy (true negatives divided by (true negatives plus false positives));
  c. Positive predictive value (PPV): the proportion of patients with malignancy out of all those testing positive on biopsy (true positives divided by (true positives plus false positives));
  d. Negative predictive value (NPV): the proportion of patients without malignancy out of all those testing negative on biopsy (true negatives divided by (true negatives plus false negatives));
  e. False positive rate: the proportion of patients who falsely test positive out of all patients without malignancy (false positives divided by (false positives plus true negatives));
  f. False negative rate: the proportion of patients who falsely test negative out of all patients with malignancy (false negatives divided by (false negatives plus true positives).
2. For KQ3a and KQ3b, only comparative studies of clinically localized renal masses were included. When clinical staging was not available, comparative arms of radical nephrectomy were excluded and the study was considered uncontrolled. This methodology was rationalized given the indication for partial nephrectomy or thermal ablation is a clinically localized renal mass suspicious for malignancy, while the indications for radical nephrectomy may include clinically localized, locally advanced, and metastatic (i.e. cytoreductive) renal masses. We excluded the emerging literature on partial nephrectomy for locally advanced disease. We also excluded the studies on microwave ablation.
3. All studies (diagnostic and management) were summarized qualitatively except the uncontrolled studies included for KQ3a and b.
4. The data from uncontrolled studies that addressed active surveillance were described in the report. Every other uncontrolled study that addressed KQ3 was simply listed in Appendix E.
5. We used the following definition for [underlined: cancer-specific survival] :
  a. Cancer-specific survival is defined as the proportion of patients surviving without death due to cancer in the absence of other causes of death.38 Individuals who die of other causes or are alive at the end of followup are censored at that time. The product limit estimator, or Kaplan-Meier method, was the preferred method employed in many of the larger studies to calculate cancer-specific survival. Smaller studies often only reported the absolute proportion of patients who survived without death due to cancer at median followup. These methods may generally overestimate cancer-specific survival but were consistently employed and defined in the available literature. Cancer-specific survival (as defined above) is the predominant oncologic outcome reported in the literature surrounding this topic. Other measures of oncologic outcome, specifically cancer-free survival (the proportion of patients free of cancer or alive), are inconsistently reported in the literature and therefore not included in this systematic review.
6. Renal functional outcomes were assessed at the time point closest to one year after intervention. We chose this time point as the timing of assessment was not standardized across studies, one year was a common measure seen in multiple studies, and one year was likely sufficient for postoperative changes and any immediate adaptive changes to occur.
7. When examining [underlined: harms, which generally were infrequent], differences were considered clinically important if a reported value or proportion for one treatment modality was 100 percent greater than the contrasting modality, or if a zero value was encountered in one of the treatment modalities, and an incidence greater than 1 percent was present in the other modality.
  a. The Clavien-Dindo system for surgical harms was utilized.39
    i. Grade I: Any deviation from the normal postoperative course without the need for pharmacological treatment or surgical, endoscopic and radiological interventions. Allowed therapeutic regimens are: drugs as antiemetics, antipyretics, analgetics, diuretics and electrolytes and physiotherapy. This grade also includes wound infections opened at the bedside.
    ii. Grade II: Requiring pharmacological treatment with drugs other than such allowed for grade I complications. Blood transfusions and total parenteral nutrition are also included.
    iii. Grade III: Requiring surgical, endoscopic or radiological intervention.
      1. (a) not under general anesthesia
      2. (b) under general anesthesia
    iv. Grade IV: Life-threatening complication (including CNS complications: brain hemorrhage, ischemic stroke, subarrachnoidal bleeding,but excluding transient ischemic attacks (TIA);IC: Intermediate care; ICU: Intensive care unit) requiring IC/ICU-management.
      1. (a) single organ dysfunction (including dialysis)
      2. (b) multi-organ dysfunction
    v. Grade V: Death of a patient.
    vi. Grade I and II complications were considered [underlined: minor] complications.
    vii. Grade III and IV complications were considered [underlined: major] complications.
    viii. Grade IV complications were listed as [underlined: death].

We conducted meta-analyses when there were sufficient data (at least 2 studies of the same design that reported or provided data to calculate the standard error for a difference in differences, with effect measures and categorical values of specific outcomes or variables) and studies were judged to be sufficiently homogenous with respect to key variables (population characteristics, intervention, and outcome). For studies amenable to meta-analysis, we calculated a weighted mean difference, effect size, and risk ratios using a random effects model with the DerSimonian and Laird method. We evaluated statistical heterogeneity among studies using an I-squared statistic. We examined the forest plots to identify trials that appeared to have quite different results and considered if these trials had different characteristics. All analyses were conducted using STATA versions 12.0 (StataCorp LP).

## Strength of the Body of Evidence

We graded the strength of evidence using the scheme recommended by the AHRQ EPC “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”34 For this report, we graded the strength of evidence for the outcomes we classified during protocol development as the most important or critical outcomes, including oncologic efficacy, renal functional outcomes, quality of life, and overall survival. We considered five domains: study limitations, directness, consistency, precision, and reporting bias. We classified the strength of evidence pertaining to the KQs into four basic categories or grades: high, moderate, low, and insufficient (see Table 3).

Table 3 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. The body of evidence may have unacceptable deficiencies, precluding judgment.

The investigators writing each section completed the strength of evidence grading. Throughout the report writing process, team members reviewed the grading and discussed the process they each used to grade the evidence.

## Applicability

For the entire body of work, applicability was assessed separately for the different outcomes and was guided by the PICOTS framework as recommended in the Methods Guide for Comparative Effectiveness Reviews of Interventions. We considered important population characteristics (e.g., gender, race, and ethnicity), comorbidities (e.g., cardiovascular disease and chronic kidney disease), and intervention features (e.g., co-intervention) that may cause heterogeneity of treatment effects and affect generalizability of the findings.

## Peer Review and Public Comment

The draft report was peer reviewed and posted for public comment from May 28, 2015, through June 25, 2015. Comments received from invited reviewers and through the public comment website were compiled and addressed. A disposition of comments will be posted on the AHRQ Web site 3 months after the release of the final report.