# Introduction

## Background

### Epidemiology and Population of Interest

Renal masses are a biologically heterogeneous group of tumors ranging from benign masses to cancers that can be indolent or aggressive.1,2 The true incidence of renal masses (including benign lesions) is unknown, but benign lesions comprise approximately 20 percent of surgically resected tumors.1,3

Kidney cancer affects approximately 65,000 new patients each year, with more than 13,000 deaths annually.4 The incidence of kidney cancer has increased significantly by 2-3 percent over the past few decades presumably due to the increased use of cross-sectional imaging such as computed tomography.5 Frequently, tumors are discovered incidentally and are asymptomatic at presentation.5 The greatest increase in incidence has been noted in small (less than 4 cm), clinically localized tumors (i.e., tumors within the kidney with no evidence of local spread, lymph node involvement, or distant metastases), which now account for upwards of 40 percent of all kidney cancers reported.6,7

Despite this increase in early-stage cancer detection, the death rate from kidney cancer did not change significantly during the same time period.4 This lack of change in death rate may be reflective of the stable rates of patients presenting with advanced and metastatic cancer or a changing biology of kidney cancer.

Renal cell carcinoma (RCC) is the most common type of cancer affecting the kidneys in the United States, accounting for more than 94 percent of kidney malignancies.4 While RCC only represents two percent of adult cancers, it is among the most lethal; approximately 35 percent of patients die within 5 years of diagnosis.4 However, the deaths due to RCC are driven by the failure of systemic treatments in metastatic (later stage) patients. Localized RCC (stage T1N0M0, less than or equal to 7 cm in diameter without lymph node involvement or metastasis, and stage T2N0M0, greater than 7 cm in diameter without lymph node involvement or metastasis) has excellent outcomes, with 5-year survival rates better than 85 percent.8,9 There is significant heterogeneity within the clinically localized renal mass population. Upwards of 30 percent of clinical stage T1a tumors (≤4cm) are benign tumors, and of the malignancies the majority are believe to be low-grade, indolent tumors. 1,2,10 Therefore, the cancer-specific survival for clinical stage T1a tumors is greater than 95 percent.11 Conversely, up to 40 percent of clinically localized tumors are determined to be locally advanced cancers (stage T3, with invasion of perinephric fat or venous structures) at pathological examination, and locally advanced cancers are responsible for nearly all the cancer deaths in this population.12

### Diagnostic Evaluation and Detection of Disease

All solid renal masses and cystic lesions with solid components are suspicious for RCC. No test screens effectively for RCC, and most tumors are detected incidentally during an evaluation for unrelated or nonspecific complaints. Preoperative patient and tumor (imaging) characteristics are used to stratify the risk of benign versus malignant renal masses and indolent versus aggressive renal cancers. Demographic, clinical, and imaging characteristics are used to risk-stratify patients, and nomograms exist that combine these characteristics into composite models to predict the malignant status of tumors preoperatively.13-16

In small studies, such models have modest concordance indices for malignancy, in the range of 0.55 to 0.65.^3,17-19^ The best predictors of malignancy are patient sex and tumor size, although computed tomography enhancement patterns have been able to predict histology in up to 85 percent of cases.1,20-22 In addition, all current standard imaging modalities (i.e., computed tomography (CT), magnetic resonance imaging (MRI), and ultrasonography) are able to provide insight into whether or not renal masses are localized or locally advanced, which suggests pathologic aggressiveness. Larger or central tumors are more likely to be invasive, but small peripheral tumors may also be invasive.18,23

Percutaneous renal mass sampling may be offered as a diagnostic adjunct to imaging studies such as CT, MRI, and ultrasonography. Percutaneous renal mass sampling can be done by fine needle aspiration with a reading of the sample by a cytopathologist or via core biopsy with a reading by a surgical pathologist. In one retrospective study, percutaneous renal mass biopsy was diagnostic in 81 percent of cases, with 79 percent of diagnostic biopsies showing evidence of malignancy.24 However, percutaneous renal mass sampling carries a small risk of bleeding and a theoretical risk of tumor seeding, limiting its widespread use and a well-defined role in the evaluation of localized renal masses. Despite the shortcomings in diagnostic testing, management decisions are made based on estimates of malignant potential and are driven by surgeon advice and patient preference.

### Therapeutic Interventions and Outcomes

Several options exist for the management of clinically localized renal masses suspicious for RCC, including active surveillance, surgical removal, and thermal ablation. Given the increased incidence in early, low-stage tumors without improvement in cancer-related deaths (see the discussion above), active surveillance has emerged as an option for patients with small renal masses, a low likelihood of aggressive malignancy, procedure-limiting comorbidity, and/or a limited life-expectancy. It is important to note a difference between active surveillance with curative intent versus watchful waiting. The latter constitutes a strategy where treatment is never entertained and surveillance imaging is infrequent or does not occur at all. Studies of watchful waiting are not examined in this report. Surgical removal options partial nephrectomy (removal of the tumor and a margin of surrounding normal kidney) or radical nephrectomy (removal of the entire kidney), which can be performed through a minimally invasive or open approach. Minimally invasive options include both standard laparoscopy and robot-assisted laparoscopy as well as percutaneous options for thermal ablation. Surgical removal (either radical or partial nephrectomy) is the gold standard for the treatment of RCC. The American Urological Association (AUA) Guideline, which only considers clinical stage 1 renal masses, considers partial nephrectomy and radical nephrectomy as “standard” treatment modalities for clinical stage T1a tumors (≤ 4 cm in diameter) and T1b (4-7cm) tumors. Thermal ablation and active surveillance are considered “options” or “recommendations” for T1a tumors, but are only considered “options” (no longer a “recommendation”) for T1b tumors.11 Thermal ablation, which may include cryoablation or radiofrequency ablation, can either be performed laparoscopically or percutaneously. However, professional organizations refrain from defining strict selection criteria (i.e., patient or tumor) for particular management strategies, and the existing selection criteria vary by organizational guideline.11,25,26

Controversies exist regarding the ideal management for renal masses of different stages. For example, partial nephrectomy has emerged as the recommended treatment for T1 renal masses, yet the single randomized, prospective study demonstrated no difference in overall survival between radical and partial nephrectomy in patients with kidney cancer.27

The role of age in selecting patients for surgery and type of surgery is not well established. Older patients may have very different tumors than young patients, and may appear to need nephron-sparing approaches based on their co-morbidities, but may not live long enough to see the outcome of end-stage renal disease.28 Moreover, cryoablation and partial nephrectomy may have comparable oncologic outcomes to partial nephrectomy for some tumors, although it is not clear which patients are best served with each treatment modality.29

The main outcomes of interest in this population are cancer-specific and recurrence-free survival, renal functional outcomes, and the complications associated with each procedure. All extirpative options are associated with an excellent oncologic cure rate (greater than 95 percent 5-year disease specific survival for stage T1 tumors, and greater than 85 percent 5-year disease specific survival for stage T2 tumors). Based on the current literature, it is generally believed that nephron-sparing approaches (i.e., partial nephrectomy or thermal ablation) are associated with improved renal functional outcomes, but may not have an overall survival benefit.27,30,31 It is also believed that surgical options (i.e., partial nephrectomy and radical nephrectomy) may have better oncologic outcomes than active surveillance or thermal ablation. However, surgical interventions (i.e., partial nephrectomy and radical nephrectomy) are associated with significantly higher complication rates than thermal ablation or active surveillance; in general, partial nephrectomy has a higher complication rate than radical nephrectomy.11 All of the technologies described here are approved in the United States, and are established treatment options for renal tumors.

### Current Guidelines and Shortcomings

Numerous leading organizations have put forth clinical guidelines on the management of renal masses, including the AUA, the European Association of Urology, and the National Comprehensive Cancer Network.11,25,26 The American College of Radiology published a guideline in 2010 to evaluate the appropriateness of radiologic examinations for patients with an indeterminate renal mass (defined as a mass unable to be confidently diagnosed as benign or malignant at the time of discovery).32

In 2009, the AUA published the guideline used most widely by the United States urological community. This guideline was based on expert opinions and a meta-analysis of the best studies available at the time, which were observational and retrospective in design.11 Since its publication, multiple significant advances in renal mass detection, diagnosis, risk stratification, and treatment have been made, making a systematic, evidenced-based update of the guidelines necessary. For example, an important recent contribution to the literature is a randomized trial of partial nephrectomy and radical nephrectomy that failed to demonstrate a clinically significant benefit for partial nephrectomy with respect to oncologic or renal functional outcomes.22 Additionally, a relatively new concept around chronic kidney disease that is related to surgical and medical disease has emerged that could change how clinicians view existing evidence on the benefits and harms of different strategies for managing a renal mass.33 Patients with medical chronic kidney disease have a progressive loss of renal function and poor prognosis related to global renal function and overall survival. Patients with surgical chronic kidney disease (defined as chronic kidney disease as a result of surgical nephron loss or injury) are different, with more stable long-term renal function and improved overall survival for most, compared to patients with chronic kidney disease resulting from medical renal disease.

Determining the best approach to management of clinically localized renal masses is a complex task. Creating a patient-centered treatment strategy that incorporates factors related to the renal mass (e.g., oncologic outcomes, renal functional outcomes, and complications) as well as competing health risks was not feasible in the 2009 AUA guidelines. Treatments such as robotic partial nephrectomy were still in their infancy, and the large clinical data sets lacked the granularity of more recent data.

## Scope and Key Questions

We conducted a systematic review of the effectiveness and comparative effectiveness of different strategies for treating patients with a renal mass suspicious for RCC. The questions were nominated for the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program. We developed analytic frameworks to illustrate the different questions and outcomes we considered (Figures 1 and 2), and we sought to address the following Key Questions (KQ):

Figure 1 Analytic framework for systematic review of the management of renal masses and localized kidney cancer

KQ = Key Question

Figure 1 is our preliminary analytic framework for systematic review of the management of renal masses and localized kidney cancer. Moving from left to right, there are text, arrows, boxes and circles that have text within and around. The first text on the left notes renal mass suspicious for stage I or II and renal cell carcinoma. There is an arrow pointing to the box noting composite profile. Then it breaks off into two arrows. The top arrow goes from the composite profile box to the box noting risk stratification for management of renal mass suspicious for stage I or II renal cell carcinoma. The bottom arrow goes from the composite profile box to the box noting percutaneous renal mass sampling. From percutaneous renal mass sampling, an arrow guides you downward to the circle labeled adverse events which denotes KQ2b. Another arrow from percutaneous renal mass sampling box points you toward 3 boxes denoted in KQ2a, which are malignant, non-diagnostic and benign. From the non-diagnostic box, there is an arrow pointing to the risk stratification box, and from there 2 more arrows point to the pathological diagnosis outcome or to the false positives and false negatives that are denoted in KQ2b.

Figure 2 Analytic framework for systematic review of the management of renal masses and localized kidney cancer

KQ = Key Question

Figure 2 is our preliminary analytic framework for systematic review of the management of renal masses and localized kidney cancer. This figure is a continuation from figure one which is denoted by the dashed line on the left. Moving from left to right, there is text, arrows, boxes, and circles that have text within and around. The first arrow on the left is going from the pathological diagnosis outcomes from figure 1 to the box noting management of renal mass suspicious for stage I or II renal cell carcinoma. This then breaks into four arrows to four separate boxes of radical nephrectomy, partial nephrectomy, thermal ablation, and active surveillance. These four boxes then have arrows pointing from each of them to two different outcomes. The first straight across from the boxes is final health outcomes, and the second pointing downward notes adverse effects. All three components on figure 2 denote the KQ3a and KQ3b. All of figure 1 and half of figure two denote KQ1.

KQ 1: In patients that undergo surgery for a renal mass that is suspicious for stage I or II renal cell carcinoma, how does the pathologic diagnosis compare to the likelihood of malignancy predicted by using a preoperative composite profile of patient characteristics, including demographics, clinical characteristics, blood/urine markers, and/or imaging?

For the purpose of this question and further Key Questions, a renal mass suspicious for stage I or II RCC includes all solid renal masses and cystic renal masses with a solid component.

KQ 2a: In patients that undergo surgery for a renal mass suspicious for stage I or II renal cell carcinoma, what is the accuracy (i.e., sensitivity, specificity, positive and negative predictive value) of percutaneous renal mass sampling (using fine needle aspiration with cytopathology or core biopsy with surgical pathology) in establishing a diagnosis (e.g., malignancy, histology, and grade)?

KQ 2b: In patients with a renal mass suspicious for stage I or II renal cell carcinoma, what are the adverse effects associated with using renal mass sampling (see KQ2a) to estimate the risk of malignancy, including direct complications (e.g., pain, infection, hemorrhage, and radiation exposure) and harms related to false positives, false negatives, or nondiagnostic results?

KQ 3a: In patients with a renal mass suspicious for stage I or II renal cell carcinoma, what is the effectiveness and comparative effectiveness of the available management strategies on health outcomes?

KQ 3b: Do the comparative benefits and harms of the available management strategies differ according to a patient's demographic or clinical characteristics, or disease severity defined in terms of clinical presentation, tumor characteristics (imaging), renal mass sampling results, or laboratory evaluations?