# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Philipp Dahm, M.D., M.H.Sc.
  Minneapolis Veterans Affairs Health System and University of Minnesota
  Minneapolis, MN
- Bradley Leibovich M.D
  Mayo Clinic
  Rochester, MN
- Adam Metwalli, M.D.
  National Cancer Institute,
  National Institutes of Health
  Bethesda, MD