# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- KoKo Aung, M.D., M.P.H, C.P.H., FACP^*^
  * Also provided comments on the draft report
  University of Texas Health Science Center
  San Antonio, TX
- Sam Bhayani, M.D., M.S.
  Washington University Institute for Minimally Invasive Surgery
  St. Louis, MO
- Steven Campbell, M.D., Ph.D.^*^
  Cleveland Clinic
  Cleveland, OH
- Ying-Bei Chen, M.D., Ph.D.
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- Csaba Kovesdy, M.D.
  University of Tennessee Health Science Center
  Memphis, TN
- Pari Pandharipande, M.D., M.P.H
  Massachusetts General Hospital
  Concord, MA
- Steven Solomon, M.D.^*^
  Cornell University
  New York, NY