# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Bill Bro
  Kidney Cancer Association
  Ft. Myers, FL
- Steven Campbell, M.D., Ph.D.
  Cleveland Clinic,
  Cleveland, OH
- Ying-Bei Chen, M.D., Ph.D.
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- Tina Groat, M.D., M.B.A, FACOG
  United Healthcare
  Detroit, MI
- Csaba Kovesdy, M.D.
  University of Tennessee Health Science Center
  Memphis, TN
- Stephen Solomon, M.D.
  Cornell University
  New York, NY