# Acknowledgments

The authors gratefully acknowledge the support of our AHRQ Task Order Officer, Aysegul Gozu, M.D., M.P.H. We thank our Associate Editor, Tim Carey, M.D., M.P.H. for revisions and commentary. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), as well as our internal advisors (Hans-Joerg Hammers, M.D., Ph.D., and Kelvin Hong, M.D.), and lead statistician (Eliseo Guallar, M.D., Dr.P.H.) all of whom provided thoughtful advice and input during our research process. The Evidence-based Practice Center also thanks Allen Zhang and Emily Little for their assistance in data abstraction, Faye Rivkin for copy editing, and Ellen Tambor for assistance with the process of obtaining input from stakeholders.