# Discussion

## Key Findings and the Strength of Evidence

### KQ 1 Efficacy of Composite Models in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

The evidence showed that composite models have a predictive utility in differentiating benign and malignant pathology. Imaging characteristics, which included mass size and anatomic location, were the most heavily used variables in the models, but no single variable was predictive of benign or malignant pathology across all composite models.

In general, increased tumor size and male sex were best correlated with malignant pathology, supporting historical predictors of malignancy in prior guidelines and retrospective studies. In several studies, the RENAL nephrometry score was predictive of malignant pathology. However, heterogeneity of data among studies limited the strength of evidence about the predictive utility of the components of the RENAL nephrometry score. The evidence was insufficient to identify other strong predictors of malignant versus benign pathology in this sample population. Without further prospective studies examining these variables, it is not possible to conclude that any particular composite model variables can be successfully applied as a predictive tool. However, these data can inform clinicians about general variables that are useful to predict benign or malignant pathology, and should be used to guide further well-designed clinical trials. Although male sex and increased tumor size were consistently associated with an increased risk of malignancy, the strength of evidence was low to support use of any particular composite model for diagnosis of renal masses suspicious for localized RCC.

The strength of evidence was moderate for increased tumor size and male sex being associated with increased risk of malignancy, and for incidental presentation not being associated with the risk of malignancy, based largely on the consistency of findings among studies. Strength of evidence was low for other tumor characteristics and age not being associated with the risk of malignancy; and low for composite profiles as a whole, based on inconsistencies among studies involving inclusion criteria, controlling variables in composite profiles, and study design.

### KQ 2 Accuracy and Efficacy of Renal Mass Biopsy in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

The evidence showed that renal mass sampling is associated with a low risk of complications (≤ 5 percent for each evaluated complication) and excellent positive predictive value (97-100 percent). However, the notable nondiagnostic rate (14 percent), low negative predictive value (68 percent), and bias that surgical pathology is not routinely pursued for benign biopsy samples, prevents strong conclusions from being drawn regarding the exact role of renal mass sampling in the clinical practice. The evidence supported the preference of core biopsy over fine needle aspiration, both of which are well-tolerated by patients and have a low risk of associated harms. Biopsies had a low complication rate, with hematoma being the most common at 5 percent.

The evidence suggested that renal mass sampling is useful primarily if the biopsy reveals a cancer diagnosis. For patients undergoing renal mass sampling, strong evidence supports its high sensitivity (97.5 percent) and low false positive rate (4.0 percent) in the diagnosis of malignancy. However, the current clinical assumption is that the renal masses in question in this report are most likely indolent malignancies and true clinical utility of biopsy will be achieved when aggressive cancers can definitively be ruled out. Contemporary evidence suggests a 14 percent nondiagnostic rate, with 90.4 percent of these patients ultimately found to have malignant disease. Repeat biopsy can improve the diagnostic rate, as 80 percent of repeat biopsies are diagnostic. However, it should be noted that this requires a significant number of patients undergo an additional procedure. The 80 percent diagnostic rate reflects only those patients well-selected for a repeat biopsy. Furthermore, the negative predictive value of renal mass core biopsies is 68.5 percent. This certainly reflects a bias, in that only patients with the most clinically suspicious masses proceeded to surgical extirpation and, therefore, likely underestimates the true negative predictive value. While renal mass core biopsies provide adequate samples, tumor grade on biopsy was only weakly correlated with final pathology, with a 16 percent rate of upgrading from low to high grade.

Based on the available evidence, it is not possible to conclude that renal mass sampling is a universal prerequisite to surgical intervention or active surveillance. However, the research gaps and strength of evidence regarding renal mass sampling can direct future clinical research efforts to better elucidate its utility. The strength of evidence for diagnostic accuracy of renal mass sampling was graded as moderate for diagnostic accuracy. The strength of evidence for harms was graded as low.

### KQ 3a Efficacy and Comparative Efficacy of Different Interventions for the Management of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

The evidence regarding management strategies of renal masses suspicious for localized renal cell carcinoma is based almost entirely on retrospective studies and is susceptible to the inherent limitations of this study design. We found a reasonable number of comparative studies regarding radical nephrectomy, partial nephrectomy, and thermal ablation. We included uncontrolled studies on active surveillance because of the dearth of comparative studies investigating this treatment modality.

#### Overall Survival and Oncological Outcomes

The available literature suggested that overall and oncological outcomes are similar between management strategies. In fact, cancer-specific survival was excellent among all modalities and median 5-year survival approached 95 percent for clinical T1a tumors. We did not find any studies comparing cancer-specific survival between partial nephrectomy and active surveillance.

Overall survival was highly dependent on patient comorbidity and competing risks of mortality. In the retrospective comparative studies, where selection bias exists, patients undergoing partial nephrectomy showed superior overall survival to thermal ablation and active surveillance – likely related to their excellent general health. Nonsurgical management patients in the SEER dataset (i.e., those patients who did not receive treatment or surveillance) had decreased overall survival compared with those who received surgical intervention. However, when confounding factors were considered, active surveillance and radical nephrectomy demonstrated comparable overall survival, based on the single comparative study, although there was a wide associated CI (HR 0.75 (95% CI, 0.45 to 1.26).135

In general, radical nephrectomy and partial nephrectomy had similar overall survival, however the evidence directly comparing partial nephrectomy and radical nephrectomy was conflicted. Multiple, large retrospective studies favored partial nephrectomy for overall survival. However, the single randomized study demonstrated increased overall survival in patients who underwent radical nephrectomy, but equivalent outcomes in the subset of patients with RCC.27 When subdivided by tumor size, partial nephrectomy and radical nephrectomy showed similar survival outcomes for pathologic T1b and T2 tumors. For pathologic T1a tumors, partial nephrectomy was favored.

The evidence suggested that thermal ablation has inferior recurrence-free survival to radical nephrectomy and partial nephrectomy. However, cancer-specific and metastasis-free survival were similar among modalities, and when consideration of multiple treatments were allowed, thermal ablation cancer-specific survival approached that of radical nephrectomy or partial nephrectomy. Importantly, recurrence-free survival was considered only after a single, curative-intent initial treatment. Patients should therefore be counseled that if electing thermal ablation, they may require more than one treatment to achieve the same oncologic efficacy as other treatment modalities. .

In summary, current evidence was insufficient to demonstrate superiority of a single treatment modality. Consideration of competing comorbidity is of paramount importance as differences in overall survival are largely driven by patient selection, and oncologic measures (cancer-specific and metastatic-free survival) are generally equivalent. The remaining caveat is that thermal ablation may require multiple treatments to achieve the same local control. The generally equivalent survival outcomes should encourage prospective clinical research efforts.

The strength of evidence was low among studies examining overall survival. Strength of evidence was moderate for cancer-specific survival for radical versus partial nephrectomy based on data from 1 RCT, 23 institutional studies, and 10 SEER analyses. All other outcomes demonstrated a low to moderate strength of evidence based on the existence of fewer studies for some comparisons (specifically of thermal ablation) and inherent study limitations (selection bias in the majority of cases).

#### Renal Functional Outcomes

All interventions experienced decreased renal function postoperatively, followed by renal functional improvements within 1 to 6 months. The improvement within this window was most notable with thermal ablation, although partial nephrectomy and thermal ablation appeared to have similar renal functional outcomes. The evidence demonstrated worse renal functional outcomes with radical nephrectomy compared with other management strategies when considering changes in eGFR and progression of chronic kidney disease.

The benefits in renal function in comparison to radical nephrectomy need to be posited with oncologic and harms data during choice of management. Importantly, a randomized trial of partial nephrectomy and radical nephrectomy, of which 85 percent of the patients had a World Health Organization performance status of zero (fully active), demonstrated a greater short-term decrease in eGFR with radical nephrectomy than with partial nephrectomy, but similar long-term renal function outcomes –indicating that healthy patients may not benefit from nephron-sparing interventions.90 Our synthesis of studies suggests that patients at the lowest (preoperative eGFR <45 ml/min/1.73 m^2^) and highest levels (preoperative eGFR >90 ml/min/1.73 m^2^) of kidney function may not experience renal functional benefits from nephron sparing procedures compared with radical nephrectomy. However, this is likely due to decreased numbers of studies reporting these subgroups and outcomes, and the few studies reporting followup beyond one year. Further research should strive to identify the patients most likely to benefit from nephron-sparing approaches from a renal functional standpoint, and in particular long-term development of chronic kidney disease and/or end-stage renal disease. Importantly, the incidence of new-onset end-stage renal disease was uncommon (0.4 to 3 percent) across all interventions.

In summary, radical nephrectomy was associated with worse renal functional outcomes, compared with thermal ablation and partial nephrectomy, which have comparable outcomes. Further research is needed to evaluate the clinical relevance of the decline in renal function. Strength of evidence was moderate for the continuous and categorical comparisons of radical and partial nephrectomy, as well as the continuous renal functional outcomes of radical nephrectomy and thermal ablation based on consistent estimated glomerular filtration rate findings among all studies. Strength of evidence was insufficient to low in the remainder of comparisons based on a low number of studies and inconsistencies in reporting of renal functional outcomes.

#### Quality of Life Outcomes

Evaluable evidence was only available for comparing quality of life outcomes between partial nephrectomy and radical nephrectomy. These studies demonstrated that radical nephrectomy may provide better perceived quality of life regarding cancer control. Partial nephrectomy, however, showed decreased anxiety and depression. Quality of life nevertheless hinged upon complications, regardless of management strategy. It was not possible to evaluate the efficacy or comparative efficacy of thermal ablation or active surveillance in terms of quality of life. This limitation should be addressed in future clinical research.

In summary, there is a paucity of evidence on quality of life following management of clinical stage T1 or T2 renal masses, which appears to be influenced by multiple factors including cancer control and complications. The strength of evidence was insufficient for all comparisons.

#### Perioperative Outcomes and Harms

Perioperative harms or complications were generally modest and equivalent across all interventional management strategies. Between the three interventional management strategies, thermal ablation offered the most favorable perioperative outcomes (including estimated blood loss, length of hospital stay, and conversion to open or radical surgery). Partial nephrectomy had higher rates of perioperative blood transfusions than radical nephrectomy or thermal ablation.

In meta-analyses, total rates of minor and major complications were similar among surgical interventions. Patients undergoing partial nephrectomy had higher rates of urologic complications while patients undergoing radical nephrectomy had higher rates of acute kidney injury and nonurologic complications. Patients undergoing thermal ablation had lower rates of acute kidney injury and specific nonurologic harms including cardiovascular, hematologic, and respiratory harms in comparison to radical and partial nephrectomy. Thermal ablation did have higher rates of bleeding and urine leak in comparison to radical nephrectomy; and infectious and wound harms in comparison to partial nephrectomy. Based on the current evidence, it is not possible to evaluate the comparative harms associated with active surveillance.

In summary, all interventional management strategies showed associated harms, and some of these harms were comparatively different between interventions and should be considered when selecting a treatment modality. However, the overall rates of harms were similar across all interventions. Strength of evidence was moderate for the perioperative outcomes of radical and partial nephrectomy, and partial nephrectomy and thermal ablation based on consistent findings among studies. Strength of evidence was insufficient to low for all other comparisons based on inconsistencies in the reporting of harms among studies.

### KQ 3b Comparative Benefits and Harms of Management Strategies Based on Patient Demographics, Clinical Characteristics, or Disease Severity

The evidence was limited regarding the comparative benefits and harms of management strategies based on patient or tumor characteristics. Specifically, data on the comparative benefits and harms associated with thermal ablation and active surveillance were lacking. Limited evidence suggested that age, tumor size, and tumor grade were inversely associated with survival for radical nephrectomy and partial nephrectomy. Understanding the current limitations of the data, nephron-sparing surgery was not demonstrated to offer improved renal functional outcomes compared with radical nephrectomy in patients with poor (estimated glomerular filtration rate < 45ml/min) or normal (estimated glomerular filtration rate > 60ml/min) preoperative renal function. Compared with nonsurgical management, radical nephrectomy and partial nephrectomy offered a survival benefit, although this benefit was inversely related to patient age and comorbidity. Based on the available evidence, it was not possible to identify clinical scenarios in which patient or tumor characteristics would alter the a priori treatment decision. Both retrospective and prospective data are needed to further identify the influence of patient and tumor characteristics on treatment outcomes.

Strength of evidence was low for cancer-specific and overall survival and insufficient for metastases-free and local recurrence-free survival. Baseline renal function was associated with long-term renal functional outcomes, regardless of type of surgery. The strength of evidence was low on the predictors of renal functional outcomes in comparative studies. The strength of evidence was insufficient for quality of life and perioperative outcomes and harms.

## Findings in Relationship to What Is Already Known

Prominent guidelines on this topic include those from the American Urological Association (AUA), European Association of Urology (EAU), and the National Comprehensive Cancer Network (NCCN). The AUA guidelines, published in 2009, were determined following systematic review of the medical literature from 1996 to 2007. Inclusion and exclusion criteria were similar to those used in our review. The guidelines from EAU, published in 2015, were established via a multidisciplinary expert panel discussion. The literature that formed the base of these recommendations were graded on a strength of evidence scale, which included high (grade A), moderate (grade B), or low (grade C) strength of evidence. The majority of the recommendations from these organizations cited grade B and C evidence. The NCCN guidelines, also published in 2015, were established via consensus of an expert panel.

### KQ 1 Efficacy of Composite Models in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

Guidelines from the AUA identified tobacco and obesity as risk factors for renal cell carcinoma. The AUA also suggested that hypertension may increase the risk of renal cell carcinoma, and certain diets may protect against renal cell carcinoma. While the discussion of risk factors was based on large, population-based, epidemiologic studies, there was little evidence regarding hypertension, smoking status or dietary habits in preoperative composite models analyzed in this report. Therefore, while these patient characteristics may demonstrate a relationship to renal cell carcinoma in epidemiological studies, they do not demonstrate an increased risk of malignant histology in patients with a localized renal mass based on this systematic review. Regarding differentiating between benign and malignant pathology, the AUA identified increased tumor size and male sex as correlated with increased likelihood of malignant pathology. The EAU guidelines noted a male predominance in renal cell carcinoma prevalence, but did not comment on factors that are predictive of malignant pathology. In addition, the EAU guidelines cited evidence that larger tumor size and solid pattern on imaging correlate with increased diagnostic accuracy of core biopsy. The NCCN guidelines suggest smoking and obesity as increased risk factors for renal cell carcinoma but do not identify factors that are predictive of malignant versus benign pathology.

Our review provides support for the current (2009) AUA guidelines regarding the use of tumor size and sex to estimate the risk of malignancy. The findings of this systematic review provide further evidence of the strength of the correlation with tumor size and sex. In addition, tumor characteristics, including the RENAL nephrometry score, demonstrate promise and should be considered as new updates and iterations of composite models are created. It is also noteworthy that proposed risk factors from prior research and guidelines, specifically age and BMI, did not have levels of evidence supporting their routine use to predict benign or malignant pathology. It is also important to note that our analysis did not identify a single composite model nor any components of a composite model that could be used to definitively distinguish benign from malignant pathology.

### KQ 2 Accuracy and Efficacy of Renal Mass Biopsy in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

Renal mass sampling (either by fine needle aspiration or by core biopsy) was identified in our analysis as being associated with both a high nondiagnostic rate (14 percent) and high negative predictive value (68.5 percent). The AUA guidelines identify renal mass sampling as a standard intervention “in all patients undergoing thermal ablation and in patients for whom it might impact management, particularly patients with clinical or radiographic findings suggestive of lymphoma, abscess or metastasis.” Renal mass biopsy is also not recommended in patients who would be unable to handle the uncertainty associated with the results. The EAU guidelines recommend biopsy in patients who are to be placed on active surveillance and also recommend the biopsy be completed prior to thermal ablation. Core biopsy is recommended, with tumor size and solid pattern related to increased diagnostic accuracy.

The high rate (up to 22.6 percent) of nondiagnostic biopsies and weak ability to identify tumor grade are mentioned in the EAU guidelines. Peripheral biopsies are suggested, to avoid central necrosis and improve accuracy. Neither the AUA nor the EAU guidelines make recommendations on the number of biopsies needed. Our analysis is consistent with the AUA and EAU guidelines, which recommend using renal mass sampling judiciously, and preferably to use core biopsy over fine needle aspiration in the decision-making algorithm. Our systematic review also demonstrates real limitations to renal mass sampling that should be considered in any recommendation regarding the standard use of renal mass sampling. Given its performance characteristics, renal mass biopsy could be offered in situations where its results could influence management choice. For example, renal mass biopsy could be performed prior to thermal ablation when its results could help determine appropriate followup and treatment efficacy. A young patient determined to have a partial nephrectomy for a small tumor would likely not benefit from biopsy. In contrast, a patient with a solitary kidney in whom surgery will likely lead to an anephric state may benefit from the added information yielded by a biopsy. This decision-making process should include a thorough discussion of expected outcomes, risks and benefits between physician and patient. The implications of the complication profile on special patient populations such as those on anticoagulant therapy was limited in the studies reviewed.

### KQ 3a Efficacy and Comparative Efficacy of Different Interventions for the Management of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

The AUA guidelines identify surgery as the standard of care for management of clinical T1 tumors. Where possible, renal masses considered clinical T1a should be treated with partial nephrectomy, it is generally recommended that clinical T1b tumors be treated with radical nephrectomy. The EAU guidelines state that partial nephrectomy should be attempted when feasible for clinical T1 renal masses, with laparoscopic radical nephrectomy used as an alternate treatment if the mass is not amenable to partial nephrectomy. Due to the paucity of data, the EAU did not make recommendations on the role of thermal ablation, although these should be discussed with patients as treatment alternatives. The NCCN guidelines recommend partial nephrectomy, radical nephrectomy, active surveillance, and thermal ablation for the management of clinical T1a masses, depending on the clinical situation. The NCCN recommends partial nephrectomy with conversion to radical nephrectomy if partial nephrectomy is not technically feasible. Active surveillance should be considered in appropriate candidates, such as older patients with comorbid conditions. Thermal ablation is recommended in patients who are not surgical candidates. Active surveillance and thermal ablation are not recommended for clinical T1b masses, with partial nephrectomy and radical nephrectomy as recommended options. Finally, the NCCN recommends that clinical T2 tumors should be treated with radical nephrectomy.

This systematic review supports the recommendations of the organizations stated above. However, analysis of comparative efficacy and consideration of oncologic efficacy as well as renal functional outcomes, quality of life, perioperative outcomes and harms provides data for the following recommendations when updating guideline statements.

First, this systematic review demonstrates comparable cancer-specific survival among all management strategies. This supports the prior statement from the AUA Guidelines, in which cancer-specific survival outcomes are described as uniformly excellent. Also in support of prior guideline statements, we found thermal ablation to have a higher local recurrence rate, which may indicate the need for multiple procedures to achieve equal efficacy or biological failure of the treatment. Finally, overall survival rates parallel the competing health risks and highlights the selection bias inherent to each management strategy. Data from this systematic review supports the previous statements from the AUA and other organizations that patients who can tolerate partial nephrectomy are often the healthiest and therefore have the most favorable overall survival in comparison to other management strategies. In contrast, patients undergoing thermal ablation and active surveillance often have the highest competing health risks and subsequently have the lowest rates of overall survival. In concordance with the AUA Guidelines, we find it difficult to draw meaningful conclusions regarding the comparative overall survival among all management strategies due to the presence of confounding variables and low levels of evidence.

Given the largely equivalent oncologic outcomes, consideration of secondary endpoints including renal functional outcomes, quality of life, perioperative outcomes, and harms are essential in choosing a management strategy for a given patient. Each management strategy has a risk/benefit profile that varies in terms of renal functional outcomes, quality of life, perioperative outcomes and harms. Radical nephrectomy has the greatest adverse effect on renal function, but favorable perioperative outcomes and low risk of urologic harms. Partial nephrectomy may preserve renal function but has the highest rates of bleeding requiring transfusion and urologic complications. Thermal ablation has favorable renal functional, perioperative and harms outcomes, however may require multiple treatments to achieve a similar oncologic outcome. Active surveillance offers excellent oncologic outcomes in well-selected patients and avoids the harms of a surgical intervention, however remains limited by the paucity of prospective studies reporting detailed selection criteria, surveillance protocol, and long-term outcomes.

When considering patient profiles, the healthy patient with a mass suspicious for malignancy usually will consider surgical extirpation (radical or partial nephrectomy). Compared to partial nephrectomy, radical nephrectomy showed a higher median incidence of chronic kidney disease greater than or equal to stage III (30 percent vs. 12 percent), chronic kidney disease stage greater than or equal to stage IV (7.5 percent vs. 5.4 percent), and end stage renal disease (0.8 percent vs. 0.4 percent). Such evidence provides support for nephron sparing surgery. However, partial nephrectomy carries the highest risk of blood transfusions and harms. In addition, data from our systematic review, including a RCT, indicates that patients without chronic kidney disease (and in the best of health) may not experience a clinically meaningful benefit in renal functional outcomes from nephron-sparing approaches (partial nephrectomy and thermal ablation). Therefore, radical nephrectomy remains a safe and reliable option with a limited risk of harms for patients seeking treatment of a clinically localized renal mass.

For patients with high competing health risks, thermal ablation offers the best perioperative and harm profile, indicating a low risk of complications for patients who may be frail but seeking active treatment of a clinically localized renal mass. As stated above, these benefits are contrasted by worse local recurrence rates and an increased risk of needing for retreatment. While active surveillance demonstrates efficacy in well-selected patients and should be considered as an option for the management of clinically localized small renal masses (data regarding active surveillance is limited to patients with clinical stage 1 tumors), there is insufficient data in comparative studies to draw meaningful conclusions regarding the comparative efficacy of active surveillance. Our results do provide a summary of the available evidence on outcomes that would be expected to occur with active surveillance.

### KQ 3b Comparative Benefits and Harms of Management Strategies Based on Patient Demographics, Clinical Characteristics, or Disease Severity

The AUA, EAU, and NCCN guidelines do not address how the comparative benefits and harms of management strategies may depend on patient characteristics other than to recommend nonsurgical intervention in patients with increased comorbidity. While a number of studies evaluated multivariate predictors of comparative efficacy, few studies evaluated each predictor in the context of comparative efficacy – limiting the conclusions that could be drawn from these data. However, there were a number of important findings from systematic review of this literature. First, radical, and partial nephrectomy demonstrated equivalent cancer-specific survival when stratified by age or tumor stage. Radical and partial nephrectomy demonstrate a cancer-specific and overall survival benefit to patients undergoing nonsurgical management that may be attenuated in patients more than 75 years of age or with high cardiovascular risk profile. Finally, baseline renal function (estimated glomerular filtration rate) was the best predictor of postoperative renal function regardless of management strategy.

## Applicability

### KQ 1 and 2 Diagnosis of Renal Mass Suspicious for Localized Renal Cell Carcinoma

The target population included patients with newly diagnosed, localized renal masses concerning for stage I or II renal cell carcinoma, who were older than age 18, with no family or personal history of renal cell carcinoma.

We evaluated the accuracy of published composite models (e.g., combination of demographics, clinical characteristics, blood/urine tests, and tumor imaging characteristics) for predicting malignancy. We also reviewed the efficacy and safety of percutaneous renal mass sampling, either by fine needle aspiration or core biopsy, in the diagnosis of malignancy. We recorded study information about sex, smoking history, and race, but did not exclude studies based on these variables. We also looked at body mass index, cardiovascular disease, and chronic kidney disease and we did not exclude any studies based on those characteristics of patients. For each composite model and renal sampling technique, we evaluated the false positive and false negative rates. For renal mass sampling, we further evaluated risks of pain, hemorrhage, and tumor seeding. We have detailed our assessment more specifically in Table 55, according to each PICOTS element.

Table 55 Applicability for KQ 1 and KQ 2

PICOTS | Inclusion Criteria | Conditions That Might Limit Applicability
Population(s) | - 18 years or older; - Solid renal masses (or cystic renal masses with a solid component) suspicious for stage I and II renal cell carcinoma | - Most patients were more than 60 years old. Results may not apply to younger patients or very old patients.; - Studies were predominantly in solid renal masses. Partially cystic masses were poorly represented.
Interventions | - Composite models; - Percutaneous renal mass sampling | - Biopsy protocols not standardized
Comparators | - Between biopsy results, composite models, and pathologic diagnosis after surgical intervention | - Benign or nondiagnostic biopsies do not have associated surgical pathology.; - Location and size of renal masses not described.
Outcomes | Diagnostic Outcomes; - False positives; - False negatives; - Radiation exposure; Adverse effects; - Pain; - Hemorrhage; - Tumor seeding | - Limited data on false negative rate since these patients do not progress to treatment.; - No data on harms associated with radiation exposure.; - Effects of hemorrhage on delaying surgery or increasing surgical complexity are not known.
Type of study | - Any study design except case reports | - No limitations on applicability
Timing and Setting | - Any time point and setting | - Earlier studies do not use current imaging technology, which may improve its diagnostic abilities and improve renal mass sampling.

### KQs 3a and 3b Management of Renal Mass Suspicious for Localized Renal Cell Carcinoma

The target population for KQs 3a and 3b included patients with a newly diagnosed, localized renal mass concerning for clinical stage I or II renal cell carcinoma, who were older than age 18, with no family or personal history of renal cell carcinoma. We evaluated the following management strategies: radical nephrectomy (both open and minimally invasive), partial nephrectomy (both open and minimally invasive), thermal ablation (including radiofrequency ablation, cryoablation and surgical vs. image-guided), and active surveillance. For each of these management strategies, we examined final health outcomes, perioperative outcomes, and harms.

Survival outcomes included local recurrence-free survival, metastasis-free survival, cancer-specific survival, and overall survival. Renal functional outcomes included decline in renal function, incidence of chronic kidney disease, and incidence of end-stage renal disease. We further evaluated studies regarding quality of life associated with these strategies.

Perioperative outcomes included estimated blood loss, need for transfusion of blood products, conversion to radical nephrectomy for nephron-sparing approaches, and conversion to open surgery for minimally invasive approaches.

Harms data were subdivided based on organ system, as well as by severity grading (e.g., Clavien classification). Urologic complications included acute kidney injury, renal hemorrhage, urine leak, hematuria, loss of the affected kidney, ureteral injury, and urinary tract infection. Non-urologic subtypes included hematologic/thromboembolic, gastrointestinal, cardiovascular, respiratory, neurologic, infectious diseases, and wound complications

For studies regarding management strategies, both comparative and uncontrolled studies were included. Uncontrolled studies were only used when comparative data were not available. We have detailed our assessment of applicability of the evidence more specifically in Table 56, according to each PICOTS element.

Table 56 Applicability for KQs 3a and 3b

PICOTS | Inclusion Criteria | Conditions That Might Limit Applicability
Population(s) | - 18 years or older; - Solid renal masses (or cystic renal masses with a solid component) suspicious for stage I and II renal cell carcinoma | - Most patients were more than 60 years old. Pathology and outcomes associated with younger patients may be different.
Interventions | - Radical Nephrectomy; - Partial Nephrectomy; - Thermal Ablation; - Active Surveillance | - The interventional management strategies varied a lot.; - Older studies may not reflect current techniques.; - Surveillance data was not robust enough to determine long-term outcomes.; - Conversion from partial to radical nephrectomy was poorly captured.; - Minimally invasive conversion to open surgery was poorly captured.; - Thermal ablations sometimes were aborted due to technical difficulties (e.g., ability to visualize tumor) but were poorly captured.
Comparators | - All of the management options listed above | - Limited prospective or randomized trials.; - Limited comparative studies between ablative and surgical interventions.
Outcomes | - Perioperative harms; - Adverse Outcomes; - Survival Outcomes; - Local-recurrence free survival; - Metastasis-free survival; - Cancer-specific survival; - Overall survival; - Functional Outcomes; - Renal functional outcomes; - Quality of life outcomes | - Non-standardized treatment interventions may result in different rates and types of harms.; - Data may be confounded by the learning curve and maturation associated with interventional techniques.; - Results may vary because of nonstandardized and changing definitions of survival and renal functional outcomes.
Type of study | - Comparative and uncontrolled studies | - Predominance of uncontrolled studies
Timing and Setting | - Any time point and setting | - Interventional techniques are constantly improving and changing, making it unclear as to when an intervention is mature enough to be included for analysis.

## Implications for Clinical and Policy Decision Making

### KQs 1 and 2 Diagnostic Implications

The results of this analysis may improve the judicious and appropriate utilization of medical resources for the diagnosis of renal masses suspicious for localized renal cell carcinoma. The current evidence suggested that there were no criteria universally predictive of benign or malignant pathology.

Tumor size (as detected by standard axial imaging) and sex were the most widely reported predictors of malignant pathology. While data indicates that incidental versus symptomatic presentation has little role in predicting benign or malignant pathology, the role of age and BMI are not well understood and future research may expand our understanding of these characteristics in relation to malignant pathology. Tumor characteristics, most often described by the RENAL nephrometry score, are emerging as predictors of malignancy, however heterogeneity of the current literature prevents characterization of objective criteria on which to judge the risk of malignancy. We did not identify any other new markers, clinical factors, or imaging studies that improved diagnostic abilities.

Our analysis may assist in decision making regarding the judicious use of renal mass sampling. The current data indicates excellent diagnostic performance characteristics for renal mass biopsy when a malignancy is encountered (high specificity, high sensitivity, and low false negative rate). Based on the current clinical paradigm, renal masses are assumed malignant (and of unknown metastatic potential) and therefore treated. Given the uncertain performance of renal mass biopsy when a “negative” biopsy is encountered (14 percent nondiagnostic rate, 68.5 percent negative predictive value), it is difficult to identify the patients and tumors most likely to benefit from biopsy. However, data synthesized in this report may help identify populations enriched for these disease characteristics. For instance, based on tumor size and patient sex, a population may be identified that is more likely to have benign tumors and therefore benefit from having a renal mass biopsy without having further surgical intervention. More importantly, clinical decision and policy makers should strive to identify the patients most likely to benefit from renal mass biopsy.

### KQs 3a and 3b Management Implications

Our findings should help to support informed decision making about appropriate selection of intervention for the management of renal masses suspicious for localized renal cell carcinoma, including discussion of expected outcomes and harms associated with each management option. Given similar survival outcomes, secondary outcomes (renal function, health-related quality of life, perioperative outcomes and harms, etc.) are important discussion points for any consultation regarding the management of a renal mass suspicious for malignancy. Such discussions should include information about the outcome profile associated with each management option. While the data regarding the influence of patient and tumor characteristics is not strong, consideration of mitigating effects of these characteristics should be considered until stronger evidence is acquired. Both the AUA and the EAU guidelines recommend management strategies that include treatment of “poor surgical candidates.” While this recommendation may have been left intentionally vague to allow autonomy for the practicing physician or urologist, the results of our analysis may allow for better discussion of the pros and cons of different management options for individual patients. Moreover, outcomes for these management strategies reflect the relevant postoperative concerns. For example, patients who undergo thermal ablation versus partial nephrectomy may require different postoperative imaging and renal functional assessments due to the reported differences in outcomes.

## Limitations of the Comparative Effectiveness Review Process

Our systematic evaluation of the diagnosis and management of renal masses suspicious for localized renal cell carcinoma is not without limitations. These limitations include:

1. Clinical stage T1 or T2: Localized renal masses were assumed to be clinical stage T1 or T2 in articles evaluating thermal ablation or partial nephrectomy when no clinical stage was stated. Studies addressing radical nephrectomy for tumors of unspecified renal stage were excluded. The assumption that nephron-sparing interventions would be performed only on T1 and T2 renal masses is based on the standard of care in which patients with known renal vein involvement are treated with radical nephrectomy. Radical nephrectomy studies that did not state the clinical stage had to be excluded for this reason. As a result, relevant data regarding radical nephrectomy may have been excluded because of a failure to specify clinical stage.
2. Multiple studies may have used the same data set: Retrospective studies were reported as data were accumulated. As a result, there was the risk that data from the same cohort of patients were reported in multiple articles, thereby biasing the final analysis. To address this, we manually reviewed the data to gauge similarity and possible subsequent exclusion of repeated studies.
3. Accuracy of biopsy: We did not evaluate factors related to accuracy of biopsy (e.g., peripheral biopsies, number of biopsies, etc.). Renal mass sampling has a notable nondiagnostic rate, which may be altered based on the location, quantity, and imaging technique used. This was outside of the scope of this review. As a result, we collapsed almost all variables, but we allowed for the comparison of fine needle aspiration with core biopsy.
4. Surgical pathology: We excluded renal mass sampling data that were not correlated with surgical pathology. To determine the accuracy of renal mass sampling, we looked for biopsy data having corresponding surgical pathology data as the reference. Biopsies that were benign or nondiagnostic did not necessarily result in an intervention. Thus, the true accuracy of renal mass sampling is not known.
5. Standard treatment technique: We excluded variations in management strategies that were not deemed a standard treatment technique. Experimental techniques such as single-port laparoscopy, gasless laparoscopy, selective segmental artery clamping, and zero ischemia techniques, threatened to bias the outcomes data. As a result, we excluded all of these studies, deeming them experimental and acknowledging the absence of these data on these emerging technologies.
6. Solitary kidneys: Data regarding solitary kidneys was limited. Solitary kidney data provides a unique method for evaluating the management strategies with regards to renal function. However, the reason for a patient having a solitary kidney (e.g., previous nephrectomy for renal cell carcinoma, or congenital absence of a kidney) was not always reported. Likewise, other studies contained a minority of patients with solitary kidneys within a cohort of patients with bilateral kidneys, which may have affected treatment decision making and renal functional outcomes. To address this, we included studies deemed as evaluating solitary kidneys if at least 50 percent of the patients had solitary kidneys.
7. Negative markers: Negative predictive markers in composite models were not routinely reported. The development and reporting of composite models focused on markers that were predictive of benign or malignant pathology. Clinical, demographic, laboratory, or imaging characteristics that were not predictive may not have been reported.
8. Studies that used a single biomarker or clinical variable for predicting benign versus malignant pathology were excluded. Multiple biomarkers and laboratory tests were reported in the literature as univariable studies, but these were excluded from our review, as they were not part of a composite model. This was deemed necessary to focus the review on high-quality predictors and avoid the overwhelming number of poor quality studies.

## Limitations of the Evidence Base

### KQ 1 Efficacy of Composite Models in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

1. The literature has a paucity of studies on biomarkers in composite models. While many composite models used clinical and imaging characteristics, few studies evaluated the utility of laboratory values as a biomarker of benign or malignant pathology.
2. Composite models were not validated. Given the lack of a reference or widely accepted composite model, we found no studies aimed at validating established models predicting benign or malignant disease.

### KQ 2 Accuracy and Efficacy of Renal Mass Sampling in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

1. Location and character of tumors was not described in detail. Presumably, renal mass sampling was performed for posteriorly located masses. However, the reported literature did not routinely delineate the anatomic location of the renal mass. As such, sampling of hilar or anteriorly located tumors may not have the same accuracy and safety as posterior tumors, and the results from the reported literature may not be generalizable.
2. Risks and harms from holding anticoagulation are not reported. Bleeding complications are a reported risk for renal mass sampling, and anticoagulation is often held perioperatively. The risks of holding anticoagulation were not addressed in the studies we reviewed.
3. Biopsy protocols were not described in detail. Studies evaluating renal mass sampling did not follow a common protocol, and there was limited published detail on how each biopsy was performed.
4. Management of partially cystic tumors was not well described. Renal masses exist on a spectrum of cystic versus solid components. While the majority of tumors are solid and can be sampled, tumors that are partially cystic and partially solid may have been biopsied and are not well described in the studies.
5. Peri-renal hematoma may complicate subsequent interventions. Renal mass sampling may result in a hematoma. This may delay surgical intervention, complicate nephron-sparing surgery, or complicate conversion of nephron-sparing surgery to radical nephrectomy. The delay in curative-intent treatment as a result of the biopsy is not well known.
6. The effect of renal mass sampling on clinical management is not well understood. While studies report the performance characteristics of renal mass sampling, it is unclear how this practice affects further management.
7. Cost-effectiveness of renal mass sampling was not evaluated. This issue was beyond the scope of this systematic review; however an evaluation of this type may provide additional insight into the utility of renal mass sampling.
8. There is limited data comparing renal mass sampling to cross sectional imaging alone or in composite models (KQ1). While the scope of this review is limited by the paucity of comparative diagnostic studies in the literature, the lack of comparative analyses remains a limitation of this report.

### KQ 3a Efficacy and Comparative Efficacy of Different Interventions for the Management of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

1. Prospective trials with limited biases were lacking. Differences seen in survival data may be a result of selection bias across treatment modalities. Retrospective data, while robust, are at high risk of bias.
2. The true tumor grade of thermally ablated tumors is not known. Biopsy is a standard procedure prior to thermal ablation, yet the reported analysis of biopsy data demonstrates its poor ability to determine tumor grade. Since renal tumors exhibit intra-tumor heterogeneity, it is not possible to assess the true tumor pathology of thermally ablated tumors.
3. Comparative data was weighted toward clinical T1 data, with a limited data on clinical T2 tumors. Of 89 comparative studies, 14 identified patients with clinical T2 tumors and an additional 4 studies included nephron-sparing interventions on localized tumors, which may have been either clinical T1 or T2 tumors. Comparative outcomes by stage and stage sub-groups were available for radical and partial nephrectomy only. A lack of granularity in reported outcomes prevented these comparisons for other modalities.
4. Active surveillance protocols were not standardized. Neither imaging modality nor timing of serial imaging were standardized among studies. These studies had limited numbers of patients and did not universally include renal mass sampling in their protocols. Additionally, there were no standardized criteria for delayed intervention in these patients.
5. Post-treatment followup was not standardized. Patients did not experience the same followup. Patients undergoing nephron-sparing procedures or those with higher-grade tumor pathology may receive closer followup and for a longer duration, improving the outcomes associated with these treatments. Additionally, postoperative surveillance strategies and subsequent risks (i.e. radiation exposure, cost) were not considered in this report.
6. Timing and definitions of survival were not standardized. Most notable, the urologic literature uniformly reports cancer-specific survival (where individuals who die of other causes or are alive at the end of followup are censored at that time) as the primary outcome in most studies. Cancer-specific survival most certainly over-estimates the true survival from this disease. Cancer-free survival (the proportion of patients alive and without cancer at last followup) or alternative measures were not uniformly reported and therefore were not included in this systematic review. In addition, while the Kaplan-Meier method is employed to provide estimated measures of survival in the majority of studies, the time interval for reporting survival was not uniform. Finally, definitions of recurrence-free survival were not standardized across studies.
7. Improvements in medical treatments for recurrent or metastatic disease may confound cancer-specific and overall survival data.
8. Surveillance may include patients with benign disease. Active surveillance assumes that the renal mass is a malignant tumor. However, biopsy was not required to enter active surveillance programs, and benign tumors may be present that would confound metastatic, cancer-specific, and overall survival data.
9. Different definitions of success with thermal ablation. Definition of success following thermal ablation is not easily comparable to surgical interventions. Within surgical interventions, final pathological analysis can confirm the absence of a tumor at the surgical margin, indicating success. Thermal ablation relies on imaging for followup, which is not an accurate comparison since positive margins following surgery are not routinely visible on postoperative imaging.
10. Renal functional data come primarily from patients with two functioning renal units that functioned preoperatively. While our target population generally falls within this category, there are limited data on patients with solitary kidneys and limited literature on the compensatory changes associated with treatment of the affected kidneys.
11. Timing and definitions of renal function were not standardized and changes with time. Studies that reported renal function included serum creatinine, estimated glomerular filtration rate, or both. Measurements were collected at preoperative and postoperative times that were not standardized across studies. As a result, our comparisons of data may have been confounded by time in relation to the treatment or intervention.
12. Surgeon/operator level of expertise was unknown or not routinely reported. It is widely accepted that complications and outcomes related to interventions are related to the level of expertise of the physician performing the intervention. These data were not routinely reported, nor was there a standardized definition of surgical proficiency.
13. Cost-effectiveness of any management strategy was not evaluated. This issue is beyond the scope of this systematic review.
14. The studies provided little information about long-term sequelae (i.e. cardiovascular and metabolic risks) of the management strategies and subsequent chronic kidney disease. The comparative harms examined in this report focused on the short-term risks directly related to the interventions. The long-term risks of cardiovascular disease and metabolic sequelae are believed to be secondary effects of chronic kidney disease, which may be mitigated by various management strategies (i.e. nephron-sparing versus radical treatment). The data regarding such long-term sequelae are limited and conflicting. With improved data, future reports may be able to better address this limitation of the review.
15. High quality, comparative health-related quality-of-life data is lacking. The strength of evidence for the health-related quality-of-life effects is low or insufficient. The existing data cannot be compared among studies due to differences in methodology, questionnaires, and timing of the quality of life assessments. Importantly, quality of life assessments reflect patient perception (i.e. patients may perceive radical nephrectomy to impart an improved cancer-specific survival, which is not supported by the data). Improved education, using information from this report, may help inform patient perceptions of outcome.

### KQ 3b Comparative Benefits and Harms of Management Strategies Based on Patient Demographics, Clinical Characteristics, or Disease Severity

Studies did not universally report patient demographics, clinical characteristics, or disease severity. All studies have the ability to report these data, as they are associated with each patient regardless of management strategy. However, these were not routinely reported, adding bias to the results.

## Research Gaps

### KQ 1 Efficacy of Composite Models in the Diagnosis of a Renal Mass Suspicious for Renal Cell Carcinoma

We note two primary gaps in research regarding composite models: the lack of validation of composite models and the limited use of laboratory biomarkers in composite models. The lack of published studies of composite models using biomarkers may be a result of failure to test potential biomarkers within a composite model or tested biomarkers that are nonpredictive. A comprehensive review of potential biomarkers was beyond the defined scope of this report.

Emerging biomarkers, such as urine aquaporin-1 and perilipin-2, should be incorporated into composite models and validated prospectively in well-controlled studies.194 Additionally, serum biomarkers, such as C-reactive protein, and platelet count, should be prospectively studied. Finally, future composite models should consider new imaging methods, such as carbonic anhydrase-9 or 99m technetium-sestamibi single photon emission computed tomography, to better differentiate between malignant and benign pathology.195

### KQ 2 Accuracy and Efficacy of Renal Mass Biopsy in the Diagnosis of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

Our findings demonstrated a high positive predictive value of renal mass sampling but also a notable nondiagnostic rate and a relatively poor negative predictive value. The findings have a high associated risk of bias, as there often was surgical pathology associated with negative or nondiagnostic biopsies. Further gaps include the lack of a standardized biopsy protocol, lack of correlation with patient characteristics or tumor characteristics (i.e. size, cystic components, anatomic location within kidney, etc.), and the inability to determine the effect of biopsy on definitive treatment. In addition to gathering improved data on the performance characteristics of renal biopsies, more data are needed to determine the patient population in which renal biopsy is most likely to improve outcomes.

To improve analysis of renal mass sampling, we have several recommendations. First, future studies should consider standardization and detailed publication of biopsy protocols, including the number of biopsy attempts, the number of successful biopsies, and the number of patients whose procedures were aborted secondary to technical difficulties. Second, all pathology results should be reported, including negative and inconclusive results. Ideally, details on the tumor and its anatomic location should be reported in relationship to the renal mass sampling outcomes. Prospective studies are needed in which all patients undergo biopsy prior to surgery for true assessment of renal mass sampling accuracy. Finally, thorough investigation of renal mass sampling, as it affects management strategies and ultimately, oncological outcomes, will be critical to determine its true utility. In addition, evaluation of health-related quality-of-life as related to renal mass sampling should be evaluated. Studies should give attention to uncertainty, anxiety, and psychological stresses of an additional procedure, a nondiagnostic biopsy or the diagnosis of an indolent cancer.

### KQ 3a Efficacy and Comparative Efficacy of Different Interventions for the Management of a Renal Mass Suspicious for Localized Renal Cell Carcinoma

Conclusions about the efficacy and comparative efficacy of management strategies are limited by weak study designs, poor reporting of clinical staging, and inconsistent reporting of treatment outcomes. Unreported levels of surgeon/operator expertise allows for confounding of the results.

To address these limitations, we have several recommendations.

1. Greater standardization of treatment data is required. We recommend that all studies report the clinical stage of patients, as not having this information results in exclusion of potentially valuable data when only pathologic staging is provided.
2. Definitions of survival need to be defined precisely, and methods of calculating survival need to be defined. For example, the definition of cancer-specific survival may be confused with recurrence-free survival, disease-specific survival, or cancer-specific mortality. Misclassifying these data has broad implications. In addition to defining the terminology, methods sections should include how survival data were calculated, including when patients were censored from analyses.
3. A standardized definition of surgical competency or expertise is needed. While surgical or procedural case volume may serve as a surrogate measure of experience, careful review of perioperative metrics and long-term outcomes may provide a more rational definition of expertise. Defining surgical or technical proficiency will be an ongoing challenge and standardizing how this is defined is paramount to comparative studies.
4. Renal functional and survival outcomes need to be standardized in the routine reporting of outcomes. Immediate postoperative renal functional data is insufficient and inaccurate for reporting the renal effects of the interventions. We recommend reporting baseline renal function within 1 month of intervention, short-term (1-6 months) and long-term (1 year and longer) outcomes in an attempt to better compare management strategies. Measuring estimated glomerular filtration rate is preferable to measuring serum creatinine, with precise reporting of the data instead of grouping into levels of chronic kidney disease, which are subject to change. At a minimum, survival outcomes (i.e., local recurrence, metastasis, cancer-specific, and overall) should be reported at 1, 3, and 5 years. Finally, the implications of chronic kidney disease on cardiovascular disease and metabolic sequelae are not reported and subsequently not well understood. Rates of long-term cardiovascular and metabolic disease should be documented as an integral component of renal functional outcomes.
5. Prospective studies should be performed when possible. Retrospective studies may not accurately capture minimally invasive procedures that were converted to open procedures, and may not capture partial nephrectomies that were converted into radical nephrectomies. We recognize that a prospective, randomized trial between thermal ablation and partial nephrectomy would be challenging to conduct, perhaps prohibitively so. We propose that accurate and complete collection of preoperative patient data be routinely collected, which will allow for retrospective analysis of outcomes for patients who were eligible for either treatment modality. Finally, we recognize that more quality of life studies are required, which is an area ripe for discovery.
6. A standardized active surveillance protocol is needed to allow direct comparisons of institutional experiences, and has the potential to improve outcomes of patients undergoing active surveillance.

### KQ 3b Comparative Benefits and Harms of Management Strategies Based on Patient Demographics, Clinical Characteristics, or Disease Severity

Patient demographics, clinical characteristics, and disease severity are important in the evaluation of interventions, but were dramatically underreported. To improve understanding of the comparative benefits and harms of the management strategies, studies should be more consistent about reporting clinical stage, tumor characteristics including anatomic location within the kidney, and pre- and postintervention assessments of disease severity and comorbidity.