# Conclusions

## Diagnosis of Renal Mass Suspicious for Localized Renal Cell Carcinoma

A limited set of studies exists regarding the diagnosis of renal cell carcinoma in our target population. Current composite models do not reliably predict malignancy; however, tumor size and male sex are most highly associated with malignancy. Renal mass sampling has a high positive-predictive value, but also notable nondiagnostic and negative predictive value. The evidence is biased by the failure of nonmalignant biopsies to proceed to intervention. Additional research is needed to better define the clinical utility of renal mass sampling.

## Management of Renal Mass Suspicious for Localized Renal Cell Carcinoma

As a result of the paucity of prospective, comparative studies on the management of renal masses suspicious for localized renal cell carcinoma, the current literature has a moderate risk of bias. Despite the limitations, the available evidence indicates that all management strategies have excellent cancer-specific survival in properly selected patients. The findings in this report can be used to create an outcome profile incorporating oncologic, renal functional, quality-of-life, perioperative outcomes and harms for all management strategies, which can be incorporated into any consultation regarding the management of a renal mass. Partial nephrectomy and thermal ablation offer improved short-term renal functional outcomes, but the incidence of end-stage renal disease is low, and generally equivalent, across management strategies. Partial nephrectomy demonstrates the highest rates of blood transfusion and urologic complications, despite similar rates of overall harms among all management strategies. Patients should be counseled that thermal ablation has the most favorable profile of perioperative outcomes and harms, however a significantly higher local recurrence rate compared with other surgical approaches. Active surveillance may have reasonable survival outcomes in selected populations, but comparative data are lacking. The data are sparse on the quality of life effects of the management options. The evidence also is very limited on how the comparative benefits and harms of management strategies depend on patient characteristics.