# Clinical Trials Report

[underlined: Clinical Trials Report]

Evidence-Based Practice Center

Johns Hopkins University School of Medicine

07/21/2015

[underlined: Objective:] To review ongoing (open and closed to recruitment) trials (listed in the clinicaltrials.gov website that contained either the search term “renal masses” OR “renal cell carcinoma” OR “renal cancer”, received from 01/01/1997 to 07/21/2015 and were conducted in those ≥18years of age. Using the preceding search criteria,

Number of Studies found as of 07/21/2015: 1213

Number of Studies relevant to Review: 4

Study ID# | NCT Number | Title | Interventions | Study Types | Study Designs | Outcome Measures
1. | NCT00002473 | Kidney-Sparing Surgery Compared With Kidney Removal in Treating Patients With Kidney Cancer | Procedure: conventional surgery | Interventional | Allocation: Randomized Primary Purpose: Treatment
2. | NCT01608165 | A Feasibility Study for a Multicentre Randomised Controlled Trial to Compare Surgery With Needle Ablation Techniques in People With Small Renal Masses (4cm) (CONSERVE) | Procedure: Surgical treatment for renal mass Patients will be randomised to receive a partial nephrectomy as treatment for their renal cancer mass Procedure: Percutaneous Radiofrequency ablation Patients may be randomised to undergo a radiofrequency ablation treatment for their renal cancer mass Procedure: Laparascopic or percutaneous cryoablation Patients may be randomised to undergo cryoablation as treatment for their renal cancer mass | Interventional | Allocation: Randomized Intervention Model: Parallel Assignment Masking: Open Label | SF-36 quality of life questionnaire [ Time Frame: at 7 days of randomisation and at 3 to 6 months follow up ] [ Designated as safety issue: No ] To review responses and patients willingness to complete this questionnaire over the course of their involvement in the study EQ-5D quality of life questionnaire [ Time Frame: Within 7 days of randomisation, and at 3 and 6 months follow up ] [ Designated as safety issue: No ] To review responses and patient's willingess to complete this questionnaire during the course of their involvement in the study FACT-G quality of life questionnaire [ Time Frame: Within 7 days, and 3 and 6 month follow-up ] [ Designated as safety issue: No ] To review response and patients willingness to complete this questionnaire during the course of their involvement in the study Hospital anxiety and depression questionnaire [ Time Frame: Within 7 days, and 3 and 6 month follow up ] [ Designated as safety issue: No ] To review response and patients willingness to complete this questionnaire during the course of their involvement in the study Differences in results in pre and post treatment CT scans [ Time Frame: at 1, 3 and 6 months after surgery ] [ Designated as safety issue: No ] The timing of these CT scans is dependent on the treatment arm the patient is randomised to. Effectiveness of treatment by a renal biopsy assessment [ Time Frame: 6 months post treatment ] [ Designated as safety issue: No ] This renal biopsy is only applicable to patients undergoing ablative treatment Response within qualitative interviews for patients who decline randomisation [ Time Frame: Two to six weeks after recruitment interaction ] [ Designated as safety issue: No ] Response within qualitative interviews following treatment [ Time Frame: Eight to sixteen weeks after treatment ] [ Designated as safety issue: No ]
3. | NCT02326558 | Comparison of Microwave Ablation-Assisted Enucleation and Conventional Laparoscopic Nephron-Sparing Surgery in the Treatment of T1a Renal Cell Carcinoma | Procedure: laparoscopic microwave ablation-assisted enucleation Procedure: conventional laparoscopic nephron-sparing surgery Device: Microwave generator and ablation antenna | Interventional | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Open Label Primary Purpose: Treatment | Absolute change in glomerular filtration rate (GFR) of the affected kidney [ Time Frame: baseline and 6 months ] [ Designated as safety issue: Yes ] measured by renal scintigraphy Absolute change in eGFR of the affected kidney [ Time Frame: baseline, 1 month and 6 months ] [ Designated as safety issue: Yes ] absolute change in total GFR [ Time Frame: baseline and 6 months ] [ Designated as safety issue: Yes ] measured by renal scintigraphy Blood loss [ Time Frame: during surgery ] [ Designated as safety issue: Yes ] Operation time [ Time Frame: during surgery ] [ Designated as safety issue: Yes ] Surgical margin [ Time Frame: 1 month ] [ Designated as safety issue: Yes ] assessed according to the pathology report of the operation specimen Postoperative complications [ Time Frame: up to 6 months ] [ Designated as safety issue: Yes ]; Number of participants with postoperative complications graded by Clavien- Dindo system Progression-free survival [ Time Frame: 12 months, 3 years and 5 years ] [ Designated as safety issue: Yes ]
4. | NCT02346435 | The Delayed Intervention and Surveillance for Small Renal Masses (DISSRM) Registry | NA | Observational | Time Perspective: Prospective | Disease-specific survival [ Time Frame: 5 years ] [ Designated as safety issue: Yes ] Safety and Efficacy of active surveillance and delayed intervention for the SRM, measured by disease-free survival at 5-years. Objective Safety and Tolerability of Percutaneous Renal Biopsy [ Time Frame: 5 years ] [ Designated as safety issue: Yes ] Measured by observed total (minor and major) complications compared to historical complication rates for this procedure. Quality-of-life outcomes for patients undergoing AS versus definitive therapy. [ Time Frame: 5 years ] [ Designated as safety issue: No ] Measured by SF12 Questionnaire at enrollment, 6 and 12 months and annually thereafter. To determine objective selection criteria for active surveillance. [ Time Frame: 5 years ] [ Designated as safety issue: No ] Demographic (i.e. age, sex, race), clinical (i.e. comorbidities, medications, family history) and imaging characteristics (i.e. tumor size, enhancement patterns, tumor complexity) will be used to determine patients most suitable for active surveillance.