# Meta-Analysis Figures

## Harms meta-analysis figures

Figure F1 Meta-analysis figure showing blood transfusion events in cT1a patients Radical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F2 Meta-analysis figure showing blood transfusion events in cT1 patients Radical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F3 Meta-analysis figure showing incidence of minor clavien complications in cT1b patients Radical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F4 Meta-analysis figure showing incidence of minor clavien complications in cT1 patients Radical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

## Renal functional outcomes meta-analysis figures

Figure F5 Meta-analysis figure showing mean Change in Creatinine Radical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F6 Meta-analysis figure showing mean change in Creatinine Partial Nephrectomy (PN) vs Thermal Ablation (TA)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; WMD=Weighted Mean Difference

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F7 Meta-analysis figure showing incidence of Stage 3b Chronic Kidney Disease (CKD) Radical Nephrectomy (RN) vs partial Nephrectomy

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; CKD=Chronic Kidney Disease; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F8 Meta-analysis figure showing incidence of Stage 3b Chronic Kidney Disease (CKD) Thermal Ablation (TA) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; CKD=Chronic Kidney Disease; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F9 Meta-analysis figure showing incidence of Stage 4 Chronic Kidney Disease (CKD) Radical Nephrectomy (RN) vs partial Nephrectomy

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; CKD=Chronic Kidney Disease; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

## Oncologic outcomes meta-analysis figures

Figure F10 Meta-analysis figure showing incidence of Cancer SpecificMortality at 60monthsPartial Nephrectomy (PN) vs Thermal Ablation (TA)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F11 Meta-analysis figure showing incidence of Metastasis at 50 ± 10monthsRadical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F12 Meta-analysis figure showing incidence of Metastasis 50 ± 10monthsPartial Nephrectomy (PN) vs Thermal Ablation (TA)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F13 Meta-analysis figure showing incidence of Local Recurrence 50 ± 10monthsRadical Nephrectomy (RN) vs Partial Nephrectomy (PN)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.

Figure F14 Meta-analysis figure showing incidence of Overall Mortality at 60monthsPartial Nephrectomy (PN) vsThermal Ablation (TA)

N=number; RN=Radical Nephrectomy; PN=Partial Nephrectomy, TA=Thermal Ablation; RR=Risk Ratio

The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval.