# Uncontrolled Studies

Uncontrolled Studies

## Reference List

1 Larcher A, Fossati N, Mistretta F, et al. Long-term oncologic outcomes of laparoscopic renal cryoablation as primary treatment for small renal masses. Urol Oncol. 2014. [pmid: 25301741].
2 Larson JA, Kaouk J, Stifelman MD, et al. Non-modifiable factors and complications contribute to length of stay in Robot-Assisted Partial Nephrectomy. J Endourol. 2014. [pmid: 25286232].
3 Sandberg JM, Krane LS, Hemal AK. A Nonrandomized Prospective Comparison of Robotic-assisted Partial Nephrectomy in the Elderly to a Younger Cohort: An Analysis of 339 Patients With Intermediate-term Follow-up. Urology. 2014;84(4):838-43. [pmid: 25260445].
4 Takagi T, Mir MC, Campbell RA, et al. Assessment of Outcomes in Partial Nephrectomy Incorporating Detailed Functional Analysis. Urology. 2014. [pmid: 25239254].
5 Miyake H, Furukawa J, Hinata N, Muramaki M, Tanaka K, Fujisawa M. Significant impact of R.E.N.A.L. nephrometry score on changes in postoperative renal function early after robot-assisted partial nephrectomy. Int J Clin Oncol. 2014. [pmid: 25224963].
6 Keehn A, Srivastava A, Maiman R, et al. The Relationship Between Visceral Obesity and the Clinicopathologic Features of Patients with Small Renal Masses. J Endourol. 2014. [pmid: 25203393].
7 Zargar H, Akca O, Ramirez D, et al. THE IMPACT OF EXTENDED WARM ISCHEMIA TIME ON LATE RENAL FUNCTION AFTER ROBOTIC PARTIAL NEPHRECTOMY. J Endourol. 2014. [pmid: 25203268].
8 Kuru TH, Zhu J, Popeneciu IV, et al. Volumetry may predict early renal function after nephron sparing surgery in solitary kidney patients. Springerplus. 2014;3:488. [pmid: 25202653].
9 Maddox M, Mandava S, Liu J, Boonjindasup A, Lee BR. Robotic Partial Nephrectomy for Clinical Stage T1b Tumors: Intermediate Oncologic and Functional Outcomes. Clin Genitourin Cancer. 2014. [pmid: 25176501].
10 Johnson S, Pham KN, See W, Begun FP, Langenstroer P. Laparoscopic cryoablation for clinical stage T1 renal masses: long-term oncologic outcomes at the Medical College of Wisconsin. Urology. 2014;84(3):613-8. [pmid: 25168540].
11 Rodriguez-Faba O, Palou J, Rosales A, et al. Prospective study of ultrasound-guided percutaneous renal cryotherapy: Case selection as an optimization factor for a technique. Actas Urol Esp. 2014. [pmid: 25124045].
12 McClure TD, Chow DS, Tan N, Sayre JA, Pantuck AJ, Raman SS. Intermediate Outcomes and Predictors of Efficacy in the Radiofrequency Ablation of 100 Pathologically Proven Renal Cell Carcinomas. J Vasc Interv Radiol. 2014. [pmid: 25081202].
13 Yap SA, Finelli A, Urbach DR, Tomlinson GA, Alibhai SM. Partial Nephrectomy for the Treatment of Renal Cell Carcinoma and the Risk of End Stage Renal Disease. BJU Int. 2014. [pmid: 25065448].
14 Curtiss KM, Ball MW, Gorin MA, Harris KT, Pierorazio PM, Allaf ME. Perioperative Outcomes of Robotic Partial Nephrectomy for Intrarenal Tumors. J Endourol. 2014. [pmid: 24983384].
15 Cheema Z, Alsinnawi M, Casey RG, Corr J. A single United Kingdom center experience of open partial nephrectomy using regional ischemia. Can J Urol. 2014;21(3):7277-82. [pmid: 24978357].
16 Tomaszewski JJ, Smaldone MC, Cung B, et al. Internal validation of the renal pelvic score: a novel marker of renal pelvic anatomy that predicts urine leak after partial nephrectomy. Urology. 2014;84(2):351-7. [pmid: 24975712].
17 Richards KA, Negron E, Cohn JA, Steinberg Z, Eggener SE, Shalhav AL. The Impact of Body Mass Index on Renal Functional Outcomes Following Minimally Invasive Partial Nephrectomy. J Endourol. 2014. [pmid: 24935823].
18 Tomaszewski JJ, Smaldone MC, Mehrazin R, et al. Anatomic complexity quantitated by nephrometry score is associated with prolonged warm ischemia time during robotic partial nephrectomy. Urology. 2014;84(2):340-4. [pmid: 24925833].
19 Porpiglia F, Bertolo R, Amparore D, et al. Evaluation of functional outcomes following laparoscopic partial nephrectomy by using renal scintigraphy: “clamped” versus “clampless”. BJU Int. 2014. [pmid: 24913695].
20 Hu JC, Treat E, Filson CP, et al. Technique and Outcomes of Robot-assisted Retroperitoneoscopic Partial Nephrectomy: A Multicenter Study. Eur Urol. 2014;66(3):542-9. [pmid: 24857539].
21 Mukkamala A, He C, Weizer AZ, et al. Long-term renal functional outcomes ofminimally invasive partial nephrectomy for renal cell carcinoma. Urol Oncol. 2014. [pmid: 24846342].
22 Aguilera Bazan A, Banuelos B, Alonso-Dorrego JM, Diez J, Cisneros J, De la Pena Barthel J. Oncological outcomes of nephron sparing nephrectomy. 17-year analysis. Arch Esp Urol. 2014;67(3):237-42. [pmid: 24840588].
23 Eggener SE, Clark MA, Shikanov S, et al. Impact of warm versus cold ischemia on renal function following partial nephrectomy. World J Urol. 2014. [pmid: 24817142].
24 Choo SH, Lee SY, Sung HH, et al. Transperitoneal versus retroperitoneal robotic partial nephrectomy: matched-pair comparisons by nephrometry scores. World J Urol. 2014. [pmid: 24817141].
25 Schmit GD, Schenck LA, Thompson RH, et al. Predicting renal cryoablation complications: new risk score based on tumor size and location and patient history. Radiology. 2014;272(3):903-10. [pmid: 24814178].
26 Tay MH, Thamboo TP, Wu FM, et al. High R.e.N.a.L. Nephrometry scores are associated with pathologic upstaging of clinical t1 renal-cell carcinomas in radical nephrectomy specimens: implications for nephron-sparing surgery. J Endourol. 2014;28(9):1138-42. [pmid: 24810993].
27 Wahafu W, Ma X, Li HZ, et al. Evolving renorrhaphy technique for retroperitoneal laparoscopic partial nephrectomy: single-surgeon series. Int J Urol. 2014;21(9):865-73. [pmid: 24780100].
28 Yeon JS, Son SJ, Lee YJ, et al. The nephrometry score: is it effective for predicting perioperative outcome during robot-assisted partial nephrectomy?. Korean J Urol. 2014;55(4):254-9. [pmid: 24741414].
29 Mukkamala A, Allam CL, Ellison JS, et al. Tumor enucleation vs sharp excision in minimally invasive partial nephrectomy: technical benefit without impact on functional or oncologic outcomes. Urology. 2014;83(6):1294-9. [pmid: 24713137].
30 Bessede T, Bigot P, Bernhard JC, et al. Are warm ischemia and ischemia time still predictive factors of poor renal function after partial nephrectomy in the setting of elective indication?. World J Urol. 2014. [pmid: 24700310].
31 Peyronnet B, Baumert H, Mathieu R, et al. Early unclamping technique during robot-assisted laparoscopic partial nephrectomy can minimise warm ischaemia without increasing morbidity. BJU Int. 2014. [pmid: 24690155].
32 Leslie S, Gill IS, de Castro Abreu AL, et al. Renal Tumor Contact Surface Area: A Novel Parameter for Predicting Complexity and Outcomes of Partial Nephrectomy. Eur Urol. 2014. [pmid: 24680360].
33 Park DS, Hwang JH, Kang MH, Oh JJ. Association between R.E.N.A.L. nephrometry score and perioperative outcomes following open partial nephrectomy under cold ischemia. Can Urol Assoc J. 2014;8(3-4):E137-41. [pmid: 24678352].
34 Zeccolini G, Del Biondo D, Cicero C, Casarin A, Guarise A, Celia A. Comparison of Contrast-Enhanced Ultrasound Scan (CEUS) and MRI in the follow-up of cryoablation for small renal tumors. Experience on 25 cases. Urologia. 2014;81(Suppl. 23):1-8. [pmid: 24744215].
35 Pignot G, Mejean A, Bernhard JC, et al. The use of partial nephrectomy: results from a contemporary national prospective multicenter study. World J Urol. 2014. [pmid: 24663965].
36 Schauer I, Theimer O, Klatte T, Waldert M, Klingler HC, Margreiter M. Use of self-retaining barbed sutures decreases cold ischemia time in open nephron-sparing surgery. Wien Klin Wochenschr. 2014;126(11-12):329-34. [pmid: 24652018].
37 Borghesi M, Della Mora L, Brunocilla E, et al. Warm ischemia time and postoperative complications after partial nephrectomy for renal cell carcinoma. Actas Urol Esp. 2014;38(5):313-8. [pmid: 24565512].
38 Wiener S, Kiziloz H, Dorin RP, Finnegan K, Shichman SS, Meraney A. Predictors of postoperative decline in estimated glomerular filtration rate in patients undergoing robotic partial nephrectomy. J Endourol. 2014;28(7):807-13. [pmid: 24548077].
39 Curry D, Yassin M, Thwaini A, et al. Radiofrequency ablation of renal cell carcinoma: a follow up of outcomes. Can J Urol. 2014;21(1):7135-40. [pmid: 24529016].
40 Harris KT, Ball MW, Gorin MA, Curtiss KM, Pierorazio PM, Allaf ME. Transperitoneal robot-assisted partial nephrectomy: a comparison of posterior and anterior renal masses. J Endourol. 2014;28(6):655-9. [pmid: 24422597].
41 Mukkamala A, He C, Weizer AZ, et al. Long-term oncologic outcomes of minimally invasive partial nephrectomy for renal-cell carcinoma. J Endourol. 2014;28(6):649-54. [pmid: 24405274].
42 Georgiades CS, Rodriguez R. Efficacy and Safety of Percutaneous Cryoablation for Stage 1A/B Renal Cell Carcinoma: Results of a Prospective, Single-Arm, 5-Year Study. Cardiovasc Intervent Radiol. 2014. [pmid: 24385225].
43 Takagi T, Mir MC, Campbell RA, et al. Predictors of Precision of Excision and Reconstruction in Partial Nephrectomy. J Urol. 2013. [pmid: 24373802].
44 Chang X, Ji C, Zhao X, et al. The application of R.E.N.A.L. nephrometry scoring system in predicting the complications after laparoscopic renal radiofrequency ablation. J Endourol. 2014;28(4):424-9. [pmid: 24364623].
45 Veltri A, Gazzera C, Busso M, et al. T1a as the Sole Selection Criterion for RFA of Renal Masses: Randomized Controlled Trials versus Surgery Should Not Be Postponed. Cardiovasc Intervent Radiol. 2014;37(5):1292-8. [pmid: 24337348].
46 Ploussard G, Haddad R, Kovac E, Richard P, Anidjar M, Bladou F. Robot-assisted laparoscopic partial nephrectomy: Early single Canadian institution experience. Can Urol Assoc J. 2013;7(9-10):348-54. [pmid: 24319515].
47 Lagerveld BW, Brenninkmeijer M, van der Zee JA, van Haarst EP. Can RENAL and PADUA nephrometry indices predict complications of laparoscopic cryoablation for clinical stage T1 renal tumors?. J Endourol. 2014;28(4):464-71. [pmid: 24228738].
48 Bigot P, Hetet JF, Bernhard JC, et al. Nephron-sparing surgery for renal tumors measuring more than 7 cm: morbidity, and functional and oncological outcomes. Clin Genitourin Cancer. 2014;12(1):e19-27. [pmid: 24210610].
49 Sea JC, Bahler CD, Mendonsa E, Lucas SM, Sundaram CP. Comparison of measured renal tumor size versus R.E.N.A.L. nephrometry score in predicting patient outcomes after robot-assisted laparoscopic partial nephrectomy. J Endourol. 2013;27(12):1471-6. [pmid: 24205980].
50 Ramirez D, Ma YB, Bedir S, Antonelli JA, Cadeddu JA, Gahan JC. Laparoscopic radiofrequency ablation of small renal tumors: long-term oncologic outcomes. J Endourol. 2014;28(3):330-4. [pmid: 24156661].
51 Hakky TS, Baumgarten AS, Allen B, et al. Zonal NePhRO scoring system: a superior renal tumor complexity classification model. Clin Genitourin Cancer. 2014;12(1):e13-8. [pmid: 24120084].
52 George AK, Herati AS, Rais-Bahrami S, Waingankar N, Kavoussi LR. Laparoscopic partial nephrectomy for hilar tumors: oncologic and renal functional outcomes. Urology. 2014;83(1):111-5. [pmid: 24119677].
53 Funahashi Y, Kato M, Yoshino Y, Fujita T, Sassa N, Gotoh M. Comparison of renal ischemic damage during laparoscopic partial nephrectomy with artery-vein and artery-only clamping. J Endourol. 2014;28(3):306-11. [pmid: 24099438].
54 Kreshover JE, Richstone L, Kavoussi LR. Renal cell recurrence for T1 tumors after laparoscopic partial nephrectomy. J Endourol. 2013;27(12):1468-70. [pmid: 24074156].
55 Wah TM, Irving HC, Gregory W, Cartledge J, Joyce AD, Selby PJ. Radiofrequency ablation (RFA) of renal cell carcinoma (RCC): experience in 200 tumours. BJU Int. 2014;113(3):416-28. [pmid: 24053769].
56 Seideman CA, Gahan J, Weaver M, et al. Renal tumour nephrometry score does not correlate with the risk of radiofrequency ablation complications. BJU Int. 2013;112(8):1121-4. [pmid: 24053576].
57 Ma Y, Bedir S, Cadeddu JA, Gahan JC. Long-term outcomes in healthy adults after radiofrequency ablation of T1a renal tumours. BJU Int. 2014;113(1):51-5. [pmid: 24053553].
58 Autorino R, Khalifeh A, Laydner H, et al. Robot-assisted partial nephrectomy (RAPN) for completely endophytic renal masses: a single institution experience. BJU Int. 2014;113(5):762-8. [pmid: 24053421].
59 Seklehner S, Fellner H, Engelhardt PF, Schabauer C, Riedl C. Percutaneous radiofrequency ablation of renal tumors: a single-center experience. Korean J Urol. 2013;54(9):580-6. [pmid: 24044090].
60 Lee JW, Kim H, Choo M, et al. Different methods of hilar clamping during partial nephrectomy: Impact on renal function. Int J Urol. 2014;21(3):232-6. [pmid: 24033600].
61 Golan S, Patel AR, Eggener SE, Shalhav AL. The volume of nonneoplastic parenchyma in a minimally invasive partial nephrectomy specimen: predictive factors and impact on renal function. J Endourol. 2014;28(2):196-200. [pmid: 24033335].
62 Sea JC, Bahler CD, Lucas SM, Mendonsa E, Sundaram C. COMPARISON OF MEASURED RENAL TUMOR SIZE VERSUS RENAL NEPHROMETRY SCORE IN PREDICITING PATIENT OUTCOMES FOLLOWING ROBOT ASSISTED LAPAROSCOPIC PARTIAL NEPHRECTOMY. J Endourol. 2013.
63 Yang R, Lian H, Zhang G, et al. Laparoscopic radiofrequency ablation with intraoperative contrast-enhanced ultrasonography for T1bN0M0 renal tumors: initial functional and oncologic outcomes. J Endourol. 2014;28(1):4-9. [pmid: 23998802].
64 Kobayashi K, Saito T, Kitamura Y, et al. The RENAL nephrometry score and the PADUA classification for the prediction of perioperative outcomes in patients receiving nephron-sparing surgery: feasible tools to predict intraoperative conversion to nephrectomy. Urol Int. 2013;91(3):261-8. [pmid: 23988749].
65 Qi J, Yu Y, Huang T, et al. Predictors of postoperative renal functional damage after nephron-sparing surgery. World J Surg Oncol. 2013;11:216. [pmid: 23987305].
66 Ioffe E, Hakimi AA, Oh SK, et al. Effect of visceral obesity on minimally invasive partial nephrectomy. Urology. 2013;82(3):612-8. [pmid: 23987153].
67 Porpiglia F, Bertolo R, Amparore D, Fiori C. Margins, ischaemia and complications rate after laparoscopic partial nephrectomy: impact of learning curve and tumour anatomical characteristics. BJU Int. 2013;112(8):1125-32. [pmid: 23937616].
68 Schmit GD, Thompson RH, Boorjian SA, et al. Percutaneous renal cryoablation in obese and morbidly obese patients. Urology. 2013;82(3):636-41. [pmid: 23890665].
69 Mathieu R, Verhoest G, Droupy S, et al. Predictive factors of complications after robot-assisted laparoscopic partial nephrectomy: a retrospective multicentre study. BJU Int. 2013;112(4):E283-9. [pmid: 23879913].
70 Krane LS, Manny TB, Mufarrij PW, Hemal AK. Does experience in creating a robot-assisted partial nephrectomy (RAPN) programme in an academic centre impact outcomes or complication rate?. BJU Int. 2013;112(2):207-15. [pmid: 23795787].
71 Mir MC, Campbell RA, Sharma N, et al. Parenchymal volume preservation and ischemia during partial nephrectomy: functional and volumetric analysis. Urology. 2013;82(2):263-8. [pmid: 23791213].
72 Alyami FA, Rendon RA. Laparoscopic partial nephrectomy for >4 cm renal masses. Can Urol Assoc J. 2013;7(5-6):E281-6. [pmid: 23766830].
73 Khalifeh A, Kaouk JH, Bhayani S, et al. Positive surgical margins in robot-assisted partial nephrectomy: a multi-institutional analysis of oncologic outcomes (leave no tumor behind). J Urol. 2013;190(5):1674-9. [pmid: 23764077].
74 Mehrazin R, Palazzi KL, Kopp RP, et al. Impact of tumour morphology on renal function decline after partial nephrectomy. BJU Int. 2013;111(8):E374-82. [pmid: 23714649].
75 Allen BC, Chen MY, Childs DD, Zagoria RJ. Imaging-guided radiofrequency ablation of cystic renal neoplasms. AJR Am J Roentgenol. 2013;200(6):1365-9. [pmid: 23701077].
76 Zhang ZY, Tang Q, Li XS, et al. Clinical analysis of the PADUA and the RENAL scoring systems for renal neoplasms: a retrospective study of 245 patients undergoing laparoscopic partial nephrectomy. Int J Urol. 2014;21(1):40-4. [pmid: 23675903].
77 Khalifeh A, Autorino R, Eyraud R, et al. Three-year oncologic and renal functional outcomes after robot-assisted partial nephrectomy. Eur Urol. 2013;64(5):744-50. [pmid: 23639721].
78 Eyraud R, Long JA, Snow-Lisy D, et al. Robot-assisted partial nephrectomy for hilar tumors: perioperative outcomes. Urology. 2013;81(6):1246-51. [pmid: 23601446].
79 Breen DJ, Bryant TJ, Abbas A, et al. Percutaneous cryoablation of renal tumours: outcomes from 171 tumours in 147 patients. BJU Int. 2013;112(6):758-65. [pmid: 23581293].
80 Masson-Lecomte A, Yates DR, Bensalah K, et al. Robot-assisted laparoscopic nephron sparing surgery for tumors over 4 cm: operative results and preliminary oncologic outcomes from a multicentre French study. Eur J Surg Oncol. 2013;39(7):799-803. [pmid: 23566551].
81 Kiziloz H, Dorin R, Finnegan KT, Shichman S, Meraney A. The impact of body mass index on perioperative outcomes in robot-assisted laparoscopic partial nephrectomy. J Endourol. 2013;27(8):1000-7. [pmid: 23547917].
82 Gorin MA, Mullins JK, Pierorazio PM, Jayram G, Allaf ME. Increased intra-abdominal fat predicts perioperative complications following minimally invasive partial nephrectomy. Urology. 2013;81(6):1225-30. [pmid: 23541439].
83 Karam JA, Ahrar K, Vikram R, et al. Radiofrequency ablation of renal tumours with clinical, radiographical and pathological results. BJU Int. 2013;111(6):997-1005. [pmid: 23510233].
84 Ching CB, Lane BR, Campbell SC, Li J, Fergany AF. Five to 10-year followup of open partial nephrectomy in a solitary kidney. J Urol. 2013;190(2):470-4. [pmid: 23499747].
85 Osawa T, Harada H, Oba K, Seki T, Togashi M. Clinical factor affecting the recovery of kidney function in clinically localized renal cell carcinoma patients who underwent nephron-sparing surgery. Hokkaido Igaku Zasshi. 2013;88(1):15-20. [pmid: 23461068].
86 Tanagho YS, Kaouk JH, Allaf ME, et al. Perioperative complications of robot-assisted partial nephrectomy: analysis of 886 patients at 5 United States centers. Urology. 2013;81(3):573-9. [pmid: 23452807].
87 Balageas P, Cornelis F, Le Bras Y, et al. Ten-year experience of percutaneous image-guided radiofrequency ablation of malignant renal tumours in high-risk patients. Eur Radiol. 2013;23(7):1925-32. [pmid: 23443351].
88 Chen Y, Huang J, Xia L, et al. Monitoring laparoscopic radiofrequency renal lesions in real time using contrast-enhanced ultrasonography: an open-label, randomized, comparative pilot trial. J Endourol. 2013;27(6):697-704. [pmid: 23442174].
89 Abaza R, Shah K. A single overnight stay is possible for most patients undergoing robotic partial nephrectomy. Urology. 2013;81(2):301-6. [pmid: 23374787].
90 Campero JM, Ramos CG, Valdevenito R, Mercado A, Fulla J. Laparoscopic partial nephrectomy: A series of one hundred cases performed by the same surgeon. Urol Ann. 2012;4(3):162-5. [pmid: 23248523].
91 Springer C, Inferrera A, Kawan F, Schumann A, Fornara P, Greco F. Laparoendoscopic single-site versus conventional laparoscopic radical nephrectomy for renal cell cancer in patients with increased comorbidities and previous abdominal surgery: preliminary results of a single-centre retrospective study. World J Urol. 2013;31(1):213-8. [pmid: 23242034].
92 Pertia A, Managadze L, Chkhotua A. The value of nephron-sparing surgery for the treatment of renal cell carcinoma 4 to 7 cm in size. Georgian Med News. 2012;(212):7-12. [pmid: 23221132].
93 Simhan J, Canter DJ, Sterious SN, et al. Pathological concordance and surgical outcomes of sporadic synchronous unilateral multifocal renal masses treated with partial nephrectomy. J Urol. 2013;189(1):43-7. [pmid: 23164383].
94 Hung AJ, Cai J, Simmons MN, Gill IS. “Trifecta” in partial nephrectomy. J Urol. 2013;189(1):36-42. [pmid: 23164381].
95 Erdem S, Tefik T, Mammadov A, et al. The use of self-retaining barbed suture for inner layer renorrhaphy significantly reduces warm ischemia time in laparoscopic partial nephrectomy: outcomes of a matched-pair analysis. J Endourol. 2013;27(4):452-8. [pmid: 23157211].
96 Hillyer SP, Bhayani SB, Allaf ME, et al. Robotic partial nephrectomy for solitary kidney: a multi-institutional analysis. Urology. 2013;81(1):93-7. [pmid: 23153935].
97 Kim EH, Tanagho YS, Bhayani SB, Saad NE, Benway BM, Figenshau RS. Percutaneous cryoablation of renal masses: Washington University experience of treating 129 tumours. BJU Int. 2013;111(6):872-9. [pmid: 23145500].
98 Kaczmarek BF, Tanagho YS, Hillyer SP, et al. Off-clamp robot-assisted partial nephrectomy preserves renal function: a multi-institutional propensity score analysis. Eur Urol. 2013;64(6):988-93. [pmid: 23122834].
99 Cai M, Wei J, Zhang Z, et al. Impact of age on the cancer-specific survival of patients with localized renal cell carcinoma: martingale residual and competing risks analysis. PLoS One. 2012;7(10):e48489. [pmid: 23119034].
100 Shao P, Tang L, Li P, et al. Application of a vasculature model and standardization of the renal hilar approach in laparoscopic partial nephrectomy for precise segmental artery clamping. Eur Urol. 2013;63(6):1072-81. [pmid: 23116655].
101 Blute ML Jr, Okhunov Z, Moreira DM, et al. Image-guided percutaneous renal cryoablation: preoperative risk factors for recurrence and complications. BJU Int. 2013;111(4 Pt B):E181-5. [pmid: 23107011].
102 Isac WE, Autorino R, Hillyer SP, Hernandez AV, Stein RJ, Kaouk JH. The impact of body mass index on surgical outcomes of robotic partial nephrectomy. BJU Int. 2012;110(11 Pt C):E997-E1002. [pmid: 23106799].
103 Yap SA, Alibhai SM, Abouassaly R, Timilshina N, Margel D, Finelli A. Ipsilateral adrenalectomy at the time of radical nephrectomy impacts overall survival. BJU Int. 2013;111(3 Pt B):E54-8. [pmid: 23039377].
104 Akaihata H, Haga N, Yanagida T, et al. Does body habitus of patients affect operative difficulty during retroperitoneal laparoscopic radical nephrectomy?. J Endourol. 2013;27(2):208-13. [pmid: 23039311].
105 Guillotreau J, Yakoubi R, Long JA, et al. Robotic partial nephrectomy for small renal masses in patients with pre-existing chronic kidney disease. Urology. 2012;80(4):845-51. [pmid: 23021665].
106 Long JA, Lee B, Eyraud R, et al. Robotic partial nephrectomy: imperative vs elective indications. Urology. 2012;80(4):833-7. [pmid: 23021664].
107 Abaza R, Prall D. Drain placement can be safely omitted after the majority of robotic partial nephrectomies. J Urol. 2013;189(3):823-7. [pmid: 23009869].
108 Sejima T, Iwamoto H, Masago T, et al. Oncological and functional outcomes after radical nephrectomy for renal cell carcinoma: a comprehensive analysis of prognostic factors. Int J Urol. 2013;20(4):382-9. [pmid: 23003206].
109 Okhunov Z, Shapiro EY, Moreira DM, et al. R.E.N.A.L. nephrometry score accurately predicts complications following laparoscopic renal cryoablation. J Urol. 2012;188(5):1796-800. [pmid: 22999696].
110 Bylund JR, Gayheart D, Fleming T, et al. Association of tumor size, location, R.E.N.A.L., PADUA and centrality index score with perioperative outcomes and postoperative renal function. J Urol. 2012;188(5):1684-9. [pmid: 22998902].
111 Kim SD, Yoon SG, Sung GT. Radiofrequency ablation of renal tumors: four-year follow-up results in 47 patients. Korean J Radiol. 2012;13(5):625-33. [pmid: 22977331].
112 Png KS, Bahler CD, Milgrom DP, Lucas SM, Sundaram CP. The role of R.E.N.A.L. nephrometry score in the era of robot-assisted partial nephrectomy. J Endourol. 2013;27(3):304-8. [pmid: 22967057].
113 Ficarra V, Bhayani S, Porter J, et al. Robot-assisted partial nephrectomy for renal tumors larger than 4 cm: results of a multicenter, international series. World J Urol. 2012;30(5):665-70. [pmid: 22965742].
114 Psutka SP, Feldman AS, McDougal WS, McGovern FJ, Mueller P, Gervais DA. Long-term oncologic outcomes after radiofrequency ablation for T1 renal cell carcinoma. Eur Urol. 2013;63(3):486-92. [pmid: 22959191].
115 Sandhu GS, Kim EH, Tanagho YS, Bhayani SB, Figenshau RS. Robot-assisted partial nephrectomy: off-clamp technique. J Endourol. 2013;27(1):4-7. [pmid: 22957660].
116 Sankin A, Sfakianos JP, Schiff J, Sjoberg D, Coleman JA. Assessing renal function after partial nephrectomy using renal nuclear scintigraphy and estimated glomerular filtration rate. Urology. 2012;80(2):343-6. [pmid: 22857751].
117 Tanagho YS, Roytman TM, Bhayani SB, et al. Laparoscopic cryoablation of renal masses: single-center long-term experience. Urology. 2012;80(2):307-14. [pmid: 22857748].
118 Buethe DD, Moussly S, Lin HY, et al. Is the R.E.N.A.L. nephrometry scoring system predictive of the functional efficacy of nephron sparing surgery in the solitary kidney?. J Urol. 2012;188(3):729-35. [pmid: 22819418].
119 Kim EH, Tanagho YS, Sandhu GS, Bhayani SB, Figenshau RS. Off-clamp robot-assisted partial nephrectomy for complex renal tumors. J Endourol. 2012;26(9):1177-82. [pmid: 22788753].
120 Long JA, Arnoux V, Fiard G, et al. External validation of the RENAL nephrometry score in renal tumours treated by partial nephrectomy. BJU Int. 2013;111(2):233-9. [pmid: 22788546].
121 Favaretto RL, Sanchez-Salas R, Benoist N, et al. Oncologic outcomes after laparoscopic partial nephrectomy: mid-term results. J Endourol. 2013;27(1):52-7. [pmid: 22788241].
122 Simmons MN, Hillyer SP, Lee BH, Fergany AF, Kaouk J, Campbell SC. Diameter-axial-polar nephrometry: integration and optimization of R.E.N.A.L. and centrality index scoring systems. J Urol. 2012;188(2):384-90. [pmid: 22698624].
123 Shao P, Tang L, Li P, et al. Precise segmental renal artery clamping under the guidance of dual-source computed tomography angiography during laparoscopic partial nephrectomy. Eur Urol. 2012;62(6):1001-8. [pmid: 22695243].
124 Berg WT, Rich CR, Badalato GM, et al. The first assistant sparing technique robot-assisted partial nephrectomy decreases warm ischemia time while maintaining good perioperative outcomes. J Endourol. 2012;26(11):1448-53. [pmid: 22691152].
125 Tugcu V, Bitkin A, Sonmezay E, Polat H, Ilbey YO, Tasci AI. Transperitoneal versus retroperitoneal laparoscopic partial nephrectomy: initial experience. Arch Ital Urol Androl. 2011;83(4):175-80. [pmid: 22670314].
126 Takagi T, Kondo T, Iizuka J, et al. Predictors for postoperative renal function after open partial nephrectomy: including postoperative biomarkers. Int J Urol. 2012;19(9):823-8. [pmid: 22568789].
127 Kim SP, Leibovich BC, Shah ND, et al. The relationship of postoperative complications with in-hospital outcomes and costs after renal surgery for kidney cancer. BJU Int. 2013;111(4):580-8. [pmid: 22564425].
128 Tsivian M, Ulusoy S, Abern M, Wandel A, Sidi AA, Tsivian A. Renal mass anatomic characteristics and perioperative outcomes of laparoscopic partial nephrectomy: a critical analysis. J Endourol. 2012;26(10):1307-13. [pmid: 22563868].
129 Mayer WA, Godoy G, Choi JM, Goh AC, Bian SX, Link RE. Higher RENAL Nephrometry Score is predictive of longer warm ischemia time and collecting system entry during laparoscopic and robotic-assisted partial nephrectomy. Urology. 2012;79(5):1052-6. [pmid: 22546382].
130 Kyllo RL, Tanagho YS, Kaouk JH, et al. Prospective multi-center study of oncologic outcomes of robot-assisted partial nephrectomy for pT1 renal cell carcinoma. BMC Urol. 2012;12:11. [pmid: 22546073].
131 Tanagho YS, Bhayani SB, Kim EH, Sandhu GS, Vaughn NP, Figenshau RS. Off-clamp robot-assisted partial nephrectomy: initial Washington University experience. J Endourol. 2012;26(10):1284-9. [pmid: 22524453].
132 Reyes J, Canter D, Putnam S, et al. Thermal ablation of the small renal mass: case selection using the R.E.N.A.L.-Nephrometry Score. Urol Oncol. 2013;31(7):1292-7. [pmid: 22521770].
133 Novak R, Mulligan D, Abaza R. Robotic partial nephrectomy without renal ischemia. Urology. 2012;79(6):1296-301. [pmid: 22503763].
134 Jack GS, Lua M, Chan Y, Bolton DM. Integration of laparoscopic partial nephrectomy into an Australian public hospital: three-year follow-up of our initial 50 cases. BJU Int. Suppl 3. 2012;109:35-9. [pmid: 22458491].
135 Kong W, Zhang J, Dong B, et al. Application of a standardized anatomical classification in a Chinese partial nephrectomy series. Int J Urol. 2012;19(6):551-8. [pmid: 22462720].
136 Tatsugami K, Tanaka S, Ohtsubo S, et al. Causes of diminished renal function in the affected kidney after partial nephrectomy. BJU Int. 2012;110(8 Pt B):E357-61. [pmid: 22416962].
137 Sobey S, Hakimi AA, Faleck D, Ghavamian R. Minimally invasive heminephrectomy: feasibility and outcomes. J Endourol. 2012;26(7):866-70. [pmid: 22360474].
138 Porpiglia F, Fiori C, Bertolo R, et al. Long-term functional evaluation of the treated kidney in a prospective series of patients who underwent laparoscopic partial nephrectomy for small renal tumors. Eur Urol. 2012;62(1):130-5. [pmid: 22349568].
139 Thompson RH, Lane BR, Lohse CM, et al. Renal function after partial nephrectomy: effect of warm ischemia relative to quantity and quality of preserved kidney. Urology. 2012;79(2):356-60. [pmid: 22310752].
140 Kruck S, Anastasiadis AG, Walcher U, Stenzl A, Herrmann TR, Nagele U. Laparoscopic partial nephrectomy: risk stratification according to patient and tumor characteristics. World J Urol. 2012;30(5):639-46. [pmid: 22270261].
141 Ficarra V, Bhayani S, Porter J, et al. Predictors of warm ischemia time and perioperative complications in a multicenter, international series of robot-assisted partial nephrectomy. Eur Urol. 2012;61(2):395-402. [pmid: 22079308].
142 Saito H, Matsuda T, Tanabe K, et al. Surgical and oncologic outcomes of laparoscopic partial nephrectomy: a Japanese multi-institutional study of 1375 patients. J Endourol. 2012;26(6):652-9. [pmid: 22077693].
143 Funahashi Y, Hattori R, Yamamoto T, Sassa N, Fujita T, Gotoh M. Effect of warm ischemia on renal function during partial nephrectomy: assessment with new 99mTc-mercaptoacetyltriglycine scintigraphy parameter. Urology. 2012;79(1):160-4. [pmid: 22070892].
144 Tsivian M, Kim CY, Caso JR, Rosenberg MD, Nelson RC, Polascik TJ. Contrast enhancement on computed tomography after renal cryoablation: an evidence of treatment failure?. J Endourol. 2012;26(4):330-5. [pmid: 22070179].
145 Duffey B, Nguyen V, Lund E, Koopmeiners JS, Hulbert J, Anderson JK. Intermediate-term outcomes after renal cryoablation: results of a multi-institutional study. J Endourol. 2012;26(1):15-20. [pmid: 22050505].
146 Wehrenberg-Klee E, Clark TW, Malkowicz SB, et al. Impact on renal function of percutaneous thermal ablation of renal masses in patients with preexisting chronic kidney disease. J Vasc Interv Radiol. 2012;23(1):41-5. [pmid: 22019179].
147 Erdeljan P, Dhar M, Wignall G, Kozak R, Pautler SE. Thermal ablation of small renal masses: intermediate outcomes from a Canadian center. Can J Urol. 2011;18(5):5903-7. [pmid: 22018153].
148 Wang H, Gao ZL, Lin CH, et al. Laparoscopic partial nephrectomy for T1a renal tumors is safe and feasible. Chin Med J (Engl). 2011;124(15):2243-7. [pmid: 21933551].
149 Kim JH, Kim TH, Kim SD, Lee KS, Sung GT. Radiofrequency ablation of renal tumors: our experience. Korean J Urol. 2011;52(8):531-7. [pmid: 21927699].
150 Mufarrij PW, Krane LS, Rajamahanty S, Hemal AK. Does nephrometry scoring of renal tumors predict outcomes in patients selected for robot-assisted partial nephrectomy?. J Endourol. 2011;25(10):1649-53. [pmid: 21851270].
151 Hyams ES, Pierorazio P, Proteek O, et al. Iatrogenic vascular lesions after minimally invasive partial nephrectomy: a multi-institutional study of clinical and renal functional outcomes. Urology. 2011;78(4):820-6. [pmid: 21813164].
152 Lifshitz DA, Shikanov SA, Razmaria AA, et al. Clinical and histologic predictors of renal function decline after laparoscopic partial nephrectomy. J Endourol. 2011;25(9):1435-41. [pmid: 21797760].
153 Minervini A, Vittori G, Lapini A, et al. Morbidity of tumour enucleation for renal cell carcinoma (RCC): results of a single-centre prospective study. BJU Int. 2012;109(3):372-7. discussion 378. [pmid: 21794068].
154 Porpiglia F, Fiori C, Bertolo R, et al. The effects of warm ischaemia time on renal function after laparoscopic partial nephrectomy in patients with normal contralateral kidney. World J Urol. 2012;30(2):257-63. [pmid: 21769680].
155 Wheat JC, Roberts WW, Hollenbeck BK, Wolf JS Jr, Weizer AZ. Complications of laparoscopic partial nephrectomy. Urol Oncol. 2013;31(1):57-62. [pmid: 21719322].
156 Godoy G, Katz DJ, Adamy A, Jamal JE, Bernstein M, Russo P. Routine drain placement after partial nephrectomy is not always necessary. J Urol. 2011;186(2):411-5. [pmid: 21683403].
157 Caceres F, Nunez-Mora C, Cabrera PM, Garcia-Mediero JM, Garcia-Tello A, Angulo JC. Laparoscopic partial nephrectomy. Actas Urol Esp. 2011;35(8):487-93. [pmid: 21641090].
158 Simhan J, Smaldone MC, Tsai KJ, et al. Objective measures of renal mass anatomic complexity predict rates of major complications following partial nephrectomy. Eur Urol. 2011;60(4):724-30. [pmid: 21621910].
159 Halachmi S, Moskovitz B, Farfara R, Nativ O. Predictors and mechanisms of oncological failure following nephron-sparing surgery for renal cancer. Isr Med Assoc J. 2011;13(3):166-71. [pmid: 21608338].
160 Cha EK, Ng CK, Jeun B, et al. Preoperative radiographic parameters predict long-term renal impairment following partial nephrectomy. World J Urol. 2013;31(4):817-22. [pmid: 21604019].
161 Song C, Park S, Jeong IG, et al. Followup of unilateral renal function after laparoscopic partial nephrectomy. J Urol. 2011;186(1):53-8. [pmid: 21571327].
162 Zagoria RJ, Pettus JA, Rogers M, Werle DM, Childs D, Leyendecker JR. Long-term outcomes after percutaneous radiofrequency ablation for renal cell carcinoma. Urology. 2011;77(6):1393-7. [pmid: 21492910].
163 Mues AC, Okhunov Z, Haramis G, Landman J. Contemporary experience with laparoscopic partial nephrectomy. J Laparoendosc Adv Surg Tech A. 2011;21(4):323-7. [pmid: 21486150].
164 Pouliot F, Pantuck A, Imbeault A, et al. Multivariate analysis of the factors involved in loss of renal differential function after laparoscopic partial nephrectomy: a role for warm ischemia time. Can Urol Assoc J. 2011;5(2):89-95. [pmid: 21470531].
165 Rosenberg MD, Kim CY, Tsivian M, et al. Percutaneous cryoablation of renal lesions with radiographic ice ball involvement of the renal sinus: analysis of hemorrhagic and collecting system complications. AJR Am J Roentgenol. 2011;196(4):935-9. [pmid: 21427348].
166 Lane BR, Gill IS, Fergany AF, Larson BT, Campbell SC. Limited warm ischemia during elective partial nephrectomy has only a marginal impact on renal functional outcomes. J Urol. 2011;185(5):1598-603. [pmid: 21419452].
167 Choi JD, Park JW, Choi JY, et al. Renal damage caused by warm ischaemia during laparoscopic and robot-assisted partial nephrectomy: an assessment using Tc 99m-DTPA glomerular filtration rate. Eur Urol. 2010;58(6):900-5. [pmid: 21414862].
168 Becker F, Roos FC, Janssen M, et al. Short-term functional and oncologic outcomes of nephron-sparing surgery for renal tumours >/= 7 cm. Eur Urol. 2011;59(6):931-7. [pmid: 21371812].
169 White MA, Haber GP, Autorino R, et al. Outcomes of robotic partial nephrectomy for renal masses with nephrometry score of >/=7. Urology. 2011;77(4):809-13. [pmid: 21333338].
170 Arai Y, Kaiho Y, Saito H, et al. Renal hypothermia using ice-cold saline for retroperitoneal laparoscopic partial nephrectomy: evaluation of split renal function with technetium-99m-dimercaptosuccinic acid renal scintigraphy. Urology. 2011;77(4):814-8. [pmid: 21333332].
171 Mottrie A, Schatteman P, De Wil P, De Troyer B, Novara G, Ficarra V. Validation of the preoperative aspects and dimensions used for an anatomical (PADUA) score in a robot-assisted partial nephrectomy series. World J Urol. 2013;31(4):799-804. [pmid: 21286726].
172 Ji C, Li X, Zhang S, et al. Laparoscopic radiofrequency ablation of renal tumors: 32-month mean follow-up results of 106 patients. Urology. 2011;77(4):798-802. [pmid: 21256566].
173 Tsivian A, Tsivian M, Benjamin S, Sidi AA. Laparoscopic partial nephrectomy for multiple tumours: feasibility and analysis of peri-operative outcomes. BJU Int. 2011;108(8):1330-4. [pmid: 21199286].
174 Muramaki M, Miyake H, Sakai I, et al. Age at diagnosis as a powerful predictor for disease recurrence after radical nephrectomy in Japanese patients with pT1 renal cell carcinoma. Int J Urol. 2011;18(2):121-5. [pmid: 21166889].
175 Minervini A, Serni S, Tuccio A, et al. Local recurrence after tumour enucleation for renal cell carcinoma with no ablation of the tumour bed: results of a prospective single-centre study. BJU Int. 2011;107(9):1394-9. [pmid: 21166766].
176 Hayn MH, Schwaab T, Underwood W, Kim HL. RENAL nephrometry score predicts surgical outcomes of laparoscopic partial nephrectomy. BJU Int. 2011;108(6):876-81. [pmid: 21166761].
177 Davis K, Kielar A, Jafari K. Effectiveness of ultrasound-guided radiofrequency ablation in the treatment of 36 renal cell carcinoma tumours compared with published results of using computed tomography guidance. Can Assoc Radiol J. 2012;63(3 Suppl):S23-32. [pmid: 21145195].
178 Dulabon LM, Kaouk JH, Haber GP, et al. Multi-institutional analysis of robotic partial nephrectomy for hilar versus nonhilar lesions in 446 consecutive cases. Eur Urol. 2011;59(3):325-30. [pmid: 21144643].
179 Coffin G, Hupertan V, Taksin L, et al. Impact of elective versus imperative indications on oncologic outcomes after open nephron-sparing surgery for the treatment of sporadic renal cell carcinomas. Ann Surg Oncol. 2011;18(4):1151-7. [pmid: 21136181].
180 Kong WT, Zhang WW, Guo HQ, et al. Application of contrast-enhanced ultrasonography after radiofrequency ablation for renal cell carcinoma: is it sufficient for assessment of therapeutic response?. Abdom Imaging. 2011;36(3):342-7. [pmid: 21107560].
181 Schmit GD, Atwell TD, Leibovich BC, et al. Percutaneous cryoablation of anterior renal masses: technique, efficacy, and safety. AJR Am J Roentgenol. 2010;195(6):1418-22. [pmid: 21098204].
182 Clark MA, Shikanov S, Raman JD, et al. Chronic kidney disease before and after partial nephrectomy. J Urol. 2011;185(1):43-8. [pmid: 21074205].
183 Wszolek MF, Kenney PA, Lee Y, Libertino JA. Comparison of hilar clamping and non-hilar clamping partial nephrectomy for tumours involving a solitary kidney. BJU Int. 2011;107(12):1886-92. [pmid: 21070570].
184 Beemster PW, Barwari K, Mamoulakis C, Wijkstra H, de la Rosette JJ, Laguna MP. Laparoscopic renal cryoablation using ultrathin 17-gauge cryoprobes: mid-term oncological and functional results. BJU Int. 2011;108(4):577-82. [pmid: 21044249].
185 Porpiglia F, Fiori C, Bertolo R, Scarpa RM. Does tumour size really affect the safety of laparoscopic partial nephrectomy?. BJU Int. 2011;108(2):268-73. [pmid: 21044241].
186 Smith GL, Kenney PA, Lee Y, Libertino JA. Non-clamped partial nephrectomy: techniques and surgical outcomes. BJU Int. 2011;107(7):1054-8. [pmid: 21040369].
187 Samplaski MK, Hernandez A, Gill IS, Simmons MN. C-index is associated with functional outcomes after laparoscopic partial nephrectomy. J Urol. 2010;184(6):2259-63. [pmid: 21036370].
188 Marszalek M, Chromecki T, Al-Ali BM, et al. Laparoscopic partial nephrectomy: a matched-pair comparison of the transperitoneal versus the retroperitoneal approach. Urology. 2011;77(1):109-13. [pmid: 20970830].
189 Ferakis N, Bouropoulos C, Granitsas T, Mylona S, Poulias I. Long-term results after computed-tomography-guided percutaneous radiofrequency ablation for small renal tumors. J Endourol. 2010;24(12):1909-13. [pmid: 20946062].
190 Dente D, Paniccia T, Petrone D, et al. Open partial nephrectomy with no clamping of the pedicule: a good surgical option in treatment of renal cancer. Minerva Urol Nefrol. 2010;62(4):341-6. [pmid: 20944534].
191 Montag S, Rais-Bahrami S, Seideman CA, et al. Delayed haemorrhage after laparoscopic partial nephrectomy: frequency and angiographic findings. BJU Int. 2011;107(9):1460-6. [pmid: 20831568].
192 Thompson RH, Lane BR, Lohse CM, et al. Every minute counts when the renal hilum is clamped during partial nephrectomy. Eur Urol. 2010;58(3):340-5. [pmid: 20825756].
193 Pettus JA, Werle DM, Saunders W, et al. Percutaneous radiofrequency ablation does not affect glomerular filtration rate. J Endourol. 2010;24(10):1687-91. [pmid: 20818985].
194 Atwell TD, Callstrom MR, Farrell MA, et al. Percutaneous renal cryoablation: local control at mean 26 months of followup. J Urol. 2010;184(4):1291-5. [pmid: 20719341].
195 Lyrdal D, Andersson M, Hellstrom M, Sternal J, Lundstam S. Ultrasound-guided percutaneous radiofrequency ablation of small renal tumors: Clinical results and radiological evolution during follow-up. Acta Radiol. 2010;51(7):808-18. [pmid: 20707665].
196 Lin YS, Chung HJ, Lin AT, et al. Laparoscopic partial nephrectomy: Taipei veterans general hospital experience. J Chin Med Assoc. 2010;73(7):364-8. [pmid: 20688302].
197 Rodriguez R, Cizman Z, Hong K, Koliatsos A, Georgiades C. Prospective analysis of the safety and efficacy of percutaneous cryoablation for pT1NxMx biopsy-proven renal cell carcinoma. Cardiovasc Intervent Radiol. 2011;34(3):573-8. [pmid: 20628879].
198 Waldert M, Waalkes S, Klatte T, et al. External validation of the preoperative anatomical classification for prediction of complications related to nephron-sparing surgery. World J Urol. 2010;28(4):531-5. [pmid: 20607246].
199 Guazzoni G, Cestari A, Buffi N, et al. Oncologic results of laparoscopic renal cryoablation for clinical T1a tumors: 8 years of experience in a single institution. Urology. 2010;76(3):624-9. [pmid: 20579705].
200 Tracy CR, Raman JD, Donnally C, Trimmer CK, Cadeddu JA. Durable oncologic outcomes after radiofrequency ablation: experience from treating 243 small renal masses over 7.5 years. Cancer. 2010;116(13):3135-42. [pmid: 20564644].
201 Netsch C, Bruning R, Bach T, Gross AJ. Management of renal artery pseudoaneurysm after partial nephrectomy. World J Urol. 2010;28(4):519-24. [pmid: 20563584].
202 Colli J, Martin B, Purcell M, Kim YI, Busby EJ. Surgical factors affecting return of renal function after partial nephrectomy. Int Urol Nephrol. 2011;43(1):131-7. [pmid: 20526891].
203 Karellas ME, O'Brien MF, Jang TL, Bernstein M, Russo P. Partial nephrectomy for selected renal cortical tumours of >/= 7 cm. BJU Int. 2010;106(10):1484-7. [pmid: 20518765].
204 Forsberg AM, Uvelius B, Wullt B. Open partial nephrectomy for renal cell cancer in a medium patient volume centre: is high quality possible?. Scand J Urol Nephrol. 2010;44(4):204-11. [pmid: 20459372].
205 Beemster PW, Wijkstra H, de la Rosette JJ, Zwinderman AH, Pes MP. Quality of life and perceived pain after laparoscopic-assisted renal cryoablation. J Endourol. 2010;24(5):713-9. [pmid: 20443715].
206 Ko YH, Choi H, Kang SG, et al. Efficacy of laparoscopic renal cryoablation as an alternative treatment for small renal mass in patients with poor operability: experience from the Korean single center. J Laparoendosc Adv Surg Tech A. 2010;20(4):339-45. [pmid: 20438310].
207 Msezane L, Chang A, Shikanov S, et al. Laparoscopic nephron-sparing surgery in the management of angiomyolipoma: a single center experience. J Endourol. 2010;24(4):583-7. [pmid: 20423289].
208 Aguilera Bazan A, Perez Utrilla M, Giron de Francisco M, Reinoso Elbers J, Cisneros Ledo J, De la Pena Barthel J. Laparoscopic nephron-sparing surgery. 5 years' experience. Actas Urol Esp. 2010;34(3):238-41. [pmid: 20416240].
209 Ham BK, Kang SG, Choi H, Ko YH, Kang SH, Cheon J. The impact of renal tumor size on the efficacy of laparoscopic renal cryoablation. Korean J Urol. 2010;51(3):171-7. [pmid: 20414392].
210 Mottrie A, De Naeyer G, Schatteman P, Carpentier P, Sangalli M, Ficarra V. Impact of the learning curve on perioperative outcomes in patients who underwent robotic partial nephrectomy for parenchymal renal tumours. Eur Urol. 2010;58(1):127-32. [pmid: 20399002].
211 Schmit GD, Atwell TD, Callstrom MR, et al. Percutaneous cryoablation of renal masses >or=3 cm: efficacy and safety in treatment of 108 patients. J Endourol. 2010;24(8):1255-62. [pmid: 20380510].
212 Park SW, Jung SG, Lee W, Chung MK. Changes in renal function after nephron-sparing surgery in patients with a normal contralateral kidney. Int J Urol. 2010;17(5):457-61. [pmid: 20370846].
213 Huber J, Pahernik S, Hallscheidt P, et al. Risk factors and clinical management of haemorrhage after open nephron-sparing surgery. BJU Int. 2010;106(10):1488-93. [pmid: 20367634].
214 Jeon HG, Lee SR, Kim KH, et al. Benign lesions after partial nephrectomy for presumed renal cell carcinoma in masses 4 cm or less: prevalence and predictors in Korean patients. Urology. 2010;76(3):574-9. [pmid: 20303148].
215 Shikanov S, Lifshitz D, Chan AA, et al. Impact of ischemia on renal function after laparoscopic partial nephrectomy: a multicenter study. J Urol. 2010;183(5):1714-8. [pmid: 20299052].
216 Kundu SD, Thompson RH, Kallingal GJ, Cambareri G, Russo P. Urinary fistulae after partial nephrectomy. BJU Int. 2010;106(7):1042-4. [pmid: 20230384].
217 Porpiglia F, Fiori C, Piechaud T, et al. Laparoscopic partial nephrectomy for large renal masses: results of a European survey. World J Urol. 2010;28(4):525-9. [pmid: 20204379].
218 Kava BR, De Los Santos R, Ayyathurai R, et al. Contemporary open partial nephrectomy is associated with diminished procedure-specific morbidity despite increasing technical challenges: a single institutional experience. World J Urol. 2010;28(4):507-12. [pmid: 20119642].
219 Benway BM, Bhayani SB, Rogers CG, et al. Robot-assisted partial nephrectomy: an international experience. Eur Urol. 2010;57(5):815-20. [pmid: 20116163].
220 Roos FC, Pahernik S, Brenner W, Thuroff JW. Imperative and elective indications for nephron-sparing surgery for renal tumors: long-term oncological follow-up. Aktuelle Urol. Suppl 1. 2010;41:S70-6. [pmid: 20094960].
221 Aron M, Kamoi K, Remer E, Berger A, Desai M, Gill I. Laparoscopic renal cryoablation: 8-year, single surgeon outcomes. J Urol. 2010;183(3):889-95. [pmid: 20089263].
222 Scoll BJ, Uzzo RG, Chen DY, et al. Robot-assisted partial nephrectomy: a large single-institutional experience. Urology. 2010;75(6):1328-34. [pmid: 20080290].
223 Yoost TR, Clarke HS, Savage SJ. Laparoscopic cryoablation of renal masses: which lesions fail?. Urology. 2010;75(2):311-4. [pmid: 20018355].
224 Lifshitz DA, Shikanov SA, Deklaj T, et al. Laparoscopic partial nephrectomy: a single-center evolving experience. Urology. 2010;75(2):282-7. [pmid: 19962732].
225 Lifshitz DA, Shikanov SA, Deklaj T, Katz MH, Zorn KC, Shalhav AL. Laparoscopic partial nephrectomy for tumors larger than 4 cm: a comparative study. J Endourol. 2010;24(1):49-55. [pmid: 19958147].
226 Patel MN, Krane LS, Bhandari A, et al. Robotic partial nephrectomy for renal tumors larger than 4 cm. Eur Urol. 2010;57(2):310-6. [pmid: 19945213].
227 Tsivian M, Lyne JC, Mayes JM, Mouraviev V, Kimura M, Polascik TJ. Tumor size and endophytic growth pattern affect recurrence rates after laparoscopic renal cryoablation. Urology. 2010;75(2):307-10. [pmid: 19942265].
228 Zheng JH, Xu YF, Peng B, et al. Retroperitoneal laparoscopic partial nephrectomy for renal-cell carcinoma in a solitary kidney: report of 56 cases. J Endourol. 2009;23(12):1971-4. [pmid: 19916753].
229 Gill IS, Kamoi K, Aron M, Desai MM. 800 Laparoscopic partial nephrectomies: a single surgeon series. J Urol. 2010;183(1):34-41. [pmid: 19913256].
230 Lebed B, Jani SD, Kutikov A, Iffrig K, Uzzo RG. Renal masses herniating into the hilum: technical considerations of the “ball-valve phenomenon” during nephron-sparing surgery. Urology. 2010;75(3):707-10. [pmid: 19854478].
231 Malcolm JB, Logan JE, Given RW, et al. Renal functional outcomes after cryoablation of small renal masses. J Endourol. 2010;24(3):479-82. [pmid: 19839780].
232 Corcoran AT, Hayn MH, Gibbons EP, Mori R, Hrebinko R, Davies BJ. Partial nephrectomy without hilar control or cooling: longitudinal data over 5 years. Can J Urol. 2009;16(5):4820-5. [pmid: 19796457].
233 Hiraoka K, Kawauchi A, Nakamura T, Soh J, Mikami K, Miki T. Radiofrequency ablation for renal tumors: our experience. Int J Urol. 2009;16(11):869-73. [pmid: 19735313].
234 Thomas AA, Aron M, Hernandez AV, Lane BR, Gill IS. Laparoscopic partial nephrectomy in octogenarians. Urology. 2009;74(5):1042-6. [pmid: 19683799].
235 Rouach Y, Delongchamps N, Timsit MO, et al. Capsular involvement in patients undergoing partial nephrectomy for localized renal cell carcinoma: an adverse pathological finding?. BJU Int. 2010;105(5):616-9. [pmid: 19681891].
236 Ficarra V, Novara G, Secco S, et al. Preoperative aspects and dimensions used for an anatomical (PADUA) classification of renal tumours in patients who are candidates for nephron-sparing surgery. Eur Urol. 2009;56(5):786-93. [pmid: 19665284].
237 Gupta A, Raman JD, Leveillee RJ, et al. General anesthesia and contrast-enhanced computed tomography to optimize renal percutaneous radiofrequency ablation: multi-institutional intermediate-term results. J Endourol. 2009;23(7):1099-105. [pmid: 19530948].
238 Ku JH, Moon KC, Kwak C, Kim HH. External validation of an international multicenter study to predict survival in Korean patients with pT2N0M0 renal cell carcinoma. Urology. 2009;74(2):359-63. [pmid: 19501879].
239 Laguna MP, Beemster P, Kumar V, et al. Perioperative morbidity of laparoscopic cryoablation of small renal masses with ultrathin probes: a European multicentre experience. Eur Urol. 2009;56(2):355-61. [pmid: 19467771].
240 Srivastava A, Gupta M, Singh P, et al. Laparoscopic radical nephrectomy: a journey from T1 to very large T2 tumors. Urol Int. 2009;82(3):330-4. [pmid: 19440023].
241 Stern JM, Gupta A, Raman JD, et al. Radiofrequency ablation of small renal cortical tumours in healthy adults: renal function preservation and intermediate oncological outcome. BJU Int. 2009;104(6):786-9. [pmid: 19426196].
242 Godoy G, Ramanathan V, Kanofsky JA, et al. Effect of warm ischemia time during laparoscopic partial nephrectomy on early postoperative glomerular filtration rate. J Urol. 2009;181(6):2438-43. discussion 2443-5. [pmid: 19371905].
243 La Rochelle J, Shuch B, Riggs S, et al. Functional and oncological outcomes of partial nephrectomy of solitary kidneys. J Urol. 2009;181(5):2037-42. discussion 2043. [pmid: 19298974].
244 Badger WJ, de Araujo HA, Kuehn DM, Angresen KJ, Winfield HN. Laparoscopic renal tumor cryoablation: appropriate application of real-time ultrasonographic monitoring. J Endourol. 2009;23(3):427-30. [pmid: 19250024].
245 Carrafiello G, Lagana D, Ianniello A, et al. Percutaneous radiofrequency thermal ablation of renal cell carcinoma: is it possible a day-hospital treatment?. Int J Surg. Suppl 1. 2008;6:S31-5. [pmid: 19200792].
246 Joniau S, Vander Eeckt K, Srirangam SJ, Van Poppel H. Outcome of nephron-sparing surgery for T1b renal cell carcinoma. BJU Int. 2009;103(10):1344-8. [pmid: 19040528].
247 Li QL, Guan HW, Wang FP, Jiang T, Wu HC, Song XS. Significance of margin in nephron sparing surgery for renal cell carcinoma of 4 cm or less. Chin Med J (Engl). 2008;121(17):1662-5. [pmid: 19024095].
248 Peycelon M, Hupertan V, Comperat E, et al. Long-term outcomes after nephron sparing surgery for renal cell carcinoma larger than 4 cm. J Urol. 2009;181(1):35-41. [pmid: 19012929].
249 Nadu A, Kleinmann N, Laufer M, Dotan Z, Winkler H, Ramon J. Laparoscopic partial nephrectomy for central tumors: analysis of perioperative outcomes and complications. J Urol. 2009;181(1):42-7. discussion 47. [pmid: 19012908].
250 Celia A, Zeccolini G, Guazzoni G, et al. Laparoscopic nephron sparing surgery: a multi-institutional European survey of 592 cases. Arch Ital Urol Androl. 2008;80(3):85-91. [pmid: 19009862].
251 Kefer JC, Desai MM, Fergany A, Novick AC, Gill IS. Outcomes of partial nephrectomy in patients on chronic oral anticoagulant therapy. J Urol. 2008;180(6):2370-4. discussion 2734. [pmid: 18930273].
252 Lane BR, Babineau DC, Poggio ED, et al. Factors predicting renal functional outcome after partial nephrectomy. J Urol. 2008;180(6):2363-8. discussion 2368-9. [pmid: 18930264].
253 Stein AJ, Mayes JM, Mouraviev V, Chen VH, Nelson RC, Polascik TJ. Persistent contrast enhancement several months after laparoscopic cryoablation of the small renal mass may not indicate recurrent tumor. J Endourol. 2008;22(11):2433-9. [pmid: 18928388].
254 Iida S, Kondo T, Amano H, et al. Minimal effect of cold ischemia time on progression to late-stage chronic kidney disease observed long term after partial nephrectomy. Urology. 2008;72(5):1083-8. discussion 1088-9. [pmid: 18822449].
255 Crispen PL, Boorjian SA, Lohse CM, et al. Outcomes following partial nephrectomy by tumor size. J Urol. 2008;180(5):1912-7. [pmid: 18801543].
256 Okegawa T, Noda H, Horie S, Nutahara K, Higashihara E. Comparison of transperitoneal and retroperitoneal laparoscopic nephrectomy for renal cell carcinoma: a single-center experience of 100 cases. Int J Urol. 2008;15(11):957-60. [pmid: 18775034].
257 Georgiades CS, Hong K, Bizzell C, Geschwind JF, Rodriguez R. Safety and efficacy of CT-guided percutaneous cryoablation for renal cell carcinoma. J Vasc Interv Radiol. 2008;19(9):1302-10. [pmid: 18725093].
258 Veltri A, Garetto I, Pagano E, Tosetti I, Sacchetto P, Fava C. Percutaneous RF thermal ablation of renal tumors: is US guidance really less favorable than other imaging guidance techniques?. Cardiovasc Intervent Radiol. 2009;32(1):76-85. [pmid: 18709413].
259 Pyo P, Chen A, Grasso M. Retroperitoneal laparoscopic partial nephrectomy: surgical experience and outcomes. J Urol. 2008;180(4):1279-83. [pmid: 18707736].
260 Weizer AZ, Gilbert SM, Roberts WW, Hollenbeck BK, Wolf JS Jr. Tailoring technique of laparoscopic partial nephrectomy to tumor characteristics. J Urol. 2008;180(4):1273-8. [pmid: 18707711].
261 Simmons MN, Chung BI, Gill IS. Perioperative efficacy of laparoscopic partial nephrectomy for tumors larger than 4 cm. Eur Urol. 2009;55(1):199-207. [pmid: 18684555].
262 McClean JM, Kercher KW, Mah NA, et al. Strategies in the management of renal tumors amenable to partial nephrectomy. Surg Endosc. 2009;23(9):2161-6. [pmid: 18594916].
263 Lehman DS, Hruby GW, Phillips CK, McKiernan JM, Benson MC, Landman J. First Prize (tie): Laparoscopic renal cryoablation: efficacy and complications for larger renal masses. J Endourol. 2008;22(6):1123-7. [pmid: 18484888].
264 Yossepowitch O, Thompson RH, Leibovich BC, et al. Positive surgical margins at partial nephrectomy: predictors and oncological outcomes. J Urol. 2008;179(6):2158-63. [pmid: 18423758].
265 Desai PJ, Andrews PE, Ferrigni RG, Castle EP. Laparoscopic partial nephrectomy at the Mayo Clinic Arizona: follow-up surveillance of positive margin disease. Urology. 2008;71(2):283-6. [pmid: 18308104].
266 Turna B, Frota R, Kamoi K, et al. Risk factor analysis of postoperative complications in laparoscopic partial nephrectomy. J Urol. 2008;179(4):1289-94. discussion 1294-5. [pmid: 18289584].
267 Li QL, Cheng L, Guan HW, Zhang Y, Wang FP, Song XS. Safety and efficacy of mini-margin nephron-sparing surgery for renal cell carcinoma 4-cm or less. Urology. 2008;71(5):924-7. [pmid: 18267335].
268 Colombo JR Jr, Haber GP, Gill IS. Laparoscopic partial nephrectomy in patients with compromised renal function. Urology. 2008;71(6):1043-8. [pmid: 18267332].
269 Wright AD, Turk TM, Nagar MS, Phelan MW, Perry KT. Endophytic lesions: a predictor of failure in laparoscopic renal cryoablation. J Endourol. 2007;21(12):1493-6. [pmid: 18186689].
270 Nguyen MM, Gill IS. Halving ischemia time during laparoscopic partial nephrectomy. J Urol. 2008;179(2):627-32. discussion 632. [pmid: 18082215].
271 Pahernik S, Roos F, Rohrig B, Wiesner C, Thuroff JW. Elective nephron sparing surgery for renal cell carcinoma larger than 4 cm. J Urol. 2008;179(1):71-4. discussion 74. [pmid: 17997423].
272 Porpiglia F, Volpe A, Billia M, Renard J, Scarpa RM. Assessment of risk factors for complications of laparoscopic partial nephrectomy. Eur Urol. 2008;53(3):590-6. [pmid: 17997214].
273 Polascik TJ, Nosnik I, Mayes JM, Mouraviev V. Short Term Clinical Outcome after Laparoscopic Cryoablation of the Renal Tumor < or = 3.5 cm. Technol Cancer Res Treat. 2007;6(6):621-4. [pmid: 17994792].
274 Bandi G, Christian MW, Hedican SP, Moon TD, Nakada SY. Oncological outcomes of hand-assisted laparoscopic radical nephrectomy for clinically localized renal cell carcinoma: a single-institution study with >or=3 years of follow-up. BJU Int. 2008;101(4):459-62. [pmid: 17941924].
275 Carey RI, Leveillee RJ. First prize: direct real-time temperature monitoring for laparoscopic and CT-guided radiofrequency ablation of renal tumors between 3 and 5 cm. J Endourol. 2007;21(8):807-13. [pmid: 17867933].
276 Denzinger S, Ganzer R, Fink A, Wieland WF, Blana A. Open partial nephrectomy for imperative and elective indications comparison of peri-operative data and long-term follow-up. Scand J Urol Nephrol. 2007;41(6):496-500. [pmid: 17853016].
277 Hemal AK, Kumar A, Gupta NP, Kumar R. Oncologic outcome of 132 cases of laparoscopic radical nephrectomy with intact specimen removal for T1-2N0M0 renal cell carcinoma. World J Urol. 2007;25(6):619-26. [pmid: 17786453].
278 Zagoria RJ, Traver MA, Werle DM, Perini M, Hayasaka S, Clark PE. Oncologic efficacy of CT-guided percutaneous radiofrequency ablation of renal cell carcinomas. AJR Am J Roentgenol. 2007;189(2):429-36. [pmid: 17646471].
279 Pettus JA, Sharp DS, Yossepowitch O, et al. Tumor location does not affect long-term renal function after partial nephrectomy. Urology. 2007;69(6):1059-63. [pmid: 17572186].
280 Nadu A, Mor Y, Laufer M, et al. Laparoscopic partial nephrectomy: single center experience with 140 patients--evolution of the surgical technique and its impact on patient outcomes. J Urol. 2007;178(2):435-9. discussion 438-9. [pmid: 17561145].
281 Simmons MN, Gill IS. Decreased complications of contemporary laparoscopic partial nephrectomy: use of a standardized reporting system. J Urol. 2007;177(6):2067-73. discussion 2073. [pmid: 17509287].
282 Senga Y, Ozono S, Nakazawa H, et al. Surgical outcomes of partial nephrectomy for renal cell carcinoma: a joint study by the Japanese Society of Renal Cancer. Int J Urol. 2007;14(4):284-8. [pmid: 17470154].
283 Atwell TD, Farrell MA, Callstrom MR, et al. Percutaneous cryoablation of large renal masses: technical feasibility and short-term outcome. AJR Am J Roentgenol. 2007;188(5):1195-200. [pmid: 17449758].
284 Zorn KC, Gong EM, Orvieto MA, Gofrit ON, Mikhail AA, Shalhav AL. Impact of collecting-system repair during laparoscopic partial nephrectomy. J Endourol. 2007;21(3):315-20. [pmid: 17444778].
285 Weld KJ, Figenshau RS, Venkatesh R, et al. Laparoscopic cryoablation for small renal masses: three-year follow-up. Urology. 2007;69(3):448-51. [pmid: 17382142].
286 Littrup PJ, Ahmed A, Aoun HD, et al. CT-guided percutaneous cryotherapy of renal masses. J Vasc Interv Radiol. 2007;18(3):383-92. [pmid: 17377184].
287 Adamakis I, Koutalellis G, Mitropoulos D, Vourekas S, Constantinides C, Zervas A. Enucleoresection for the elective treatment of small renal cell carcinoma: can it be the treatment of choice?. Onkologie. 2007;30(3):97-102. [pmid: 17341895].
288 Brown GA, Matin SF. Laparoscopic partial nephrectomy: experience in 60 cases. J Endourol. 2007;21(1):71-4. [pmid: 17263612].
289 Patard JJ, Pantuck AJ, Crepel M, et al. Morbidity and clinical outcome of nephron-sparing surgery in relation to tumour size and indication. Eur Urol. 2007;52(1):148-54. [pmid: 17240036].
290 Pertia A, Managadze L. Long-term results of simple enucleation for the treatment of small renal cell carcinoma. Int Braz J Urol. 2006;32(6):640-5. discussion 646-7. [pmid: 17201941].
291 Gupta NP, Kumar A, Hemal AK, Dogra PN, Seth A, Kumar R. Open nephron-sparing surgery in renal tumors with normal contralateral kidney: A single centre experience of 8 years. Indian J Urol. 2007;23(1):18-22. [pmid: 19675755].
292 Lane BR, Gill IS. 5-Year outcomes of laparoscopic partial nephrectomy. J Urol. 2007;177(1):70-4. discussion 74. [pmid: 17162003].
293 Kwon EO, Carver BS, Snyder ME, Russo P. Impact of positive surgical margins in patients undergoing partial nephrectomy for renal cortical tumours. BJU Int. 2007;99(2):286-9. [pmid: 17155985].
294 Salagierski M, Salagierski M, Salagierska-Barwinska A, Sosnowski M. Percutaneous ultrasound-guided radiofrequency ablation for kidney tumors in patients with surgical risk. Int J Urol. 2006;13(11):1375-9. [pmid: 17083386].
295 Matin SF, Ahrar K, Cadeddu JA, et al. Residual and recurrent disease following renal energy ablative therapy: a multi-institutional study. J Urol. 2006;176(5):1973-7. [pmid: 17070224].
296 Yossepowitch O, Eggener SE, Serio A, et al. Temporary renal ischemia during nephron sparing surgery is associated with short-term but not long-term impairment in renal function. J Urol. 2006;176(4 Pt 1):1339-43. discussion 1343. [pmid: 16952626].
297 Schwartz BF, Rewcastle JC, Powell T, Whelan C, Manny T Jr, Vestal JC. Cryoablation of small peripheral renal masses: a retrospective analysis. Urology. 2006;68(1 Suppl):14-8. [pmid: 16857455].
298 Davol PE, Fulmer BR, Rukstalis DB. Long-term results of cryoablation for renal cancer and complex renal masses. Urology. 2006;68(1 Suppl):2-6. [pmid: 16857453].
299 Sorbellini M, Kattan MW, Snyder ME, Hakimi AA, Sarasohn DM, Russo P. Prognostic nomogram for renal insufficiency after radical or partial nephrectomy. J Urol. 2006;176(2):472-6. discussion 476. [pmid: 16813869].
300 Carini M, Minervini A, Masieri L, Lapini A, Serni S. Simple enucleation for the treatment of PT1a renal cell carcinoma: our 20-year experience. Eur Urol. 2006;50(6):1263-8. discussion 1269-71. [pmid: 16787695].
301 Venkatesh R, Weld K, Ames CD, et al. Laparoscopic partial nephrectomy for renal masses: effect of tumor location. Urology. 2006;67(6):1169-74. discussion 1174. [pmid: 16765174].
302 Pahernik S, Roos F, Hampel C, Gillitzer R, Melchior SW, Thuroff JW. Nephron sparing surgery for renal cell carcinoma with normal contralateral kidney: 25 years of experience. J Urol. 2006;175(6):2027-31. [pmid: 16697793].
303 Carini M, Minervini A, Lapini A, Masieri L, Serni S. Simple enucleation for the treatment of renal cell carcinoma between 4 and 7 cm in greatest dimension: progression and long-term survival. J Urol. 2006;175(6):2022-6. discussion 2026. [pmid: 16697790].
304 Berdjis N, Hakenberg OW, Zastrow S, Oehlschlager S, Novotny V, Wirth MP. Impact of resection margin status after nephron-sparing surgery for renal cell carcinoma. BJU Int. 2006;97(6):1208-10. [pmid: 16686712].
305 Becker F, Siemer S, Hack M, Humke U, Ziegler M, Stockle M. Excellent long-term cancer control with elective nephron-sparing surgery for selected renal cell carcinomas measuring more than 4 cm. Eur Urol. 2006;49(6):1058-63. discussion 1063-4. [pmid: 16630686].
306 Weld KJ, Venkatesh R, Huang J, Landman J. Evolution of surgical technique and patient outcomes for laparoscopic partial nephrectomy. Urology. 2006;67(3):502-6. discussion 506-7. [pmid: 16527568].
307 Frank I, Colombo JR Jr, Rubinstein M, Desai M, Kaouk J, Gill IS. Laparoscopic partial nephrectomy for centrally located renal tumors. J Urol. 2006;175(3 Pt 1):849-52. [pmid: 16469563].
308 Pasticier G, Timsit MO, Badet L, et al. Nephron-sparing surgery for renal cell carcinoma: detailed analysis of complications over a 15-year period. Eur Urol. 2006;49(3):485-90. [pmid: 16443321].
309 Wille AH, Tullmann M, Roigas J, Loening SA, Deger S. Laparoscopic partial nephrectomy in renal cell cancer--results and reproducibility by different surgeons in a high volume laparoscopic center. Eur Urol. 2006;49(2):337-42. discussion 342-3. [pmid: 16413957].
310 Moinzadeh A, Gill IS, Finelli A, Kaouk J, Desai M. Laparoscopic partial nephrectomy: 3-year followup. J Urol. 2006;175(2):459-62. [pmid: 16406971].
311 Orvieto MA, Chien GW, Tolhurst SR, et al. Simplifying laparoscopic partial nephrectomy: technical considerations for reproducible outcomes. Urology. 2005;66(5):976-80. [pmid: 16286106].
312 Permpongkosol S, Chan DY, Link RE, et al. Long-term survival analysis after laparoscopic radical nephrectomy. J Urol. 2005;174(4 Pt 1):1222-5. [pmid: 16145374].
313 Thompson RH, Leibovich BC, Lohse CM, Zincke H, Blute ML. Complications of contemporary open nephron sparing surgery: a single institution experience. J Urol. 2005;174(3):855-8. [pmid: 16093969].
314 Gill IS, Colombo JR Jr, Frank I, Moinzadeh A, Kaouk J, Desai M. Laparoscopic partial nephrectomy for hilar tumors. J Urol. 2005;174(3):850-3. discussion 853-4. [pmid: 16093968].
315 Ng CS, Gill IS, Ramani AP, et al. Transperitoneal versus retroperitoneal laparoscopic partial nephrectomy: patient selection and perioperative outcomes. J Urol. 2005;174(3):846-9. [pmid: 16093967].
316 Wright JL, Porter JR. Laparoscopic partial nephrectomy: comparison of transperitoneal and retroperitoneal approaches. J Urol. 2005;174(3):841-5. [pmid: 16093966].
317 Gervais DA, Arellano RS, McGovern FJ, McDougal WS, Mueller PR. Radiofrequency ablation of renal cell carcinoma: part 2, Lessons learned with ablation of 100 tumors. AJR Am J Roentgenol. 2005;185(1):72-80. [pmid: 15972401].
318 Gervais DA, McGovern FJ, Arellano RS, McDougal WS, Mueller PR. Radiofrequency ablation of renal cell carcinoma: part 1, Indications, results, and role in patient management over a 6-year period and ablation of 100 tumors. AJR Am J Roentgenol. 2005;185(1):64-71. [pmid: 15972400].
319 Cheung MC, Lee YM, Rindani R, Lau H. Oncological outcome of 100 laparoscopic radical nephrectomies for clinically localized renal cell carcinoma. ANZ J Surg. 2005;75(7):593-6. [pmid: 15972054].
320 Lapini A, Serni S, Minervini A, Masieri L, Carini M. Progression and long-term survival after simple enucleation for the elective treatment of renal cell carcinoma: experience in 107 patients. J Urol. 2005;174(1):57-60. discussion 60. [pmid: 15947577].
321 Gill IS, Remer EM, Hasan WA, et al. Renal cryoablation: outcome at 3 years. J Urol. 2005;173(6):1903-7. [pmid: 15879772].
322 Link RE, Bhayani SB, Allaf ME, et al. Exploring the learning curve, pathological outcomes and perioperative morbidity of laparoscopic partial nephrectomy performed for renal mass. J Urol. 2005;173(5):1690-4. [pmid: 15821559].
323 Salama ME, Guru K, Stricker H, et al. pT1 substaging in renal cell carcinoma: validation of the 2002 TNM staging modification of malignant renal epithelial tumors. J Urol. 2005;173(5):1492-5. [pmid: 15821466].
324 Mullerad M, Kastin A, Adusumilli PS, Moskovitz B, Sabo E, Nativ O. Comparison of nephron-sparing surgery in central versus peripheral renal tumors. Urology. 2005;65(3):467-72. [pmid: 15780357].
325 Desai MM, Gill IS, Ramani AP, Spaliviero M, Rybicki L, Kaouk JH. The impact of warm ischaemia on renal function after laparoscopic partial nephrectomy. BJU Int. 2005;95(3):377-83. [pmid: 15679798].
326 Seifman BD, Hollenbeck BK, Wolf JS Jr. Laparoscopic nephron-sparing surgery for a renal mass: 1-year minimum follow-up. J Endourol. 2004;18(8):783-6. [pmid: 15659903].
327 Lee YM, Cheung MC, Lau H. Laparoscopic radical nephrectomy: oncologic outcome in 100 cases. Ann Acad Med Singapore. 2004;33(5 Suppl):S86. [pmid: 15651228].
328 Ramani AP, Desai MM, Steinberg AP, et al. Complications of laparoscopic partial nephrectomy in 200 cases. J Urol. 2005;173(1):42-7. [pmid: 15592022].
329 Cestari A, Guazzoni G, dell'Acqua V, et al. Laparoscopic cryoablation of solid renal masses: intermediate term followup. J Urol. 2004;172(4 Pt 1):1267-70. [pmid: 15371821].
330 Bhayani SB, Rha KH, Pinto PA, et al. Laparoscopic partial nephrectomy: effect of warm ischemia on serum creatinine. J Urol. 2004;172(4 Pt 1):1264-6. [pmid: 15371820].
331 Allaf ME, Bhayani SB, Rogers C, et al. Laparoscopic partial nephrectomy: evaluation of long-term oncological outcome. J Urol. 2004;172(3):871-3. [pmid: 15310986].
332 Bove P, Bhayani SB, Rha KH, Allaf ME, Jarrett TW, Kavoussi LR. Necessity of ureteral catheter during laparoscopic partial nephrectomy. J Urol. 2004;172(2):458-60. [pmid: 15247702].
333 Matsumoto ED, Watumull L, Johnson DB, et al. The radiographic evolution of radio frequency ablated renal tumors. J Urol. 2004;172(1):45-8. [pmid: 15201734].
334 Kane CJ, Mitchell JA, Meng MV, Anast J, Carroll PR, Stoller ML. Laparoscopic partial nephrectomy with temporary arterial occlusion: description of technique and renal functional outcomes. Urology. 2004;63(2):241-6. [pmid: 14972462].
335 Diblasio CJ, Snyder ME, Kattan MW, Russo P. Ketorolac: safe and effective analgesia for the management of renal cortical tumors with partial nephrectomy. J Urol. 2004;171(3):1062-5. [pmid: 14767271].
336 Elmore JM, Kadesky KT, Koeneman KS, Sagalowsky AI. Reassessment of the 1997 TNM classification system for renal cell carcinoma. Cancer. 2003;98(11):2329-34. [pmid: 14635066].
337 Kuriki O, Ono Y, Kinukawa T, et al. Laparoscopic radical nephrectomy for renal cell carcinoma. Aktuelle Urol. 2003;34(4):244-6. [pmid: 14566674].
338 Zigeuner R, Quehenberger F, Pummer K, Petritsch P, Hubmer G. Long-term results of nephron-sparing surgery for renal cell carcinoma in 114 patients: risk factors for progressive disease. BJU Int. 2003;92(6):567-71. [pmid: 14511035].
339 Patel VR, Leveillee RJ. Hand-assisted laparoscopic nephrectomy for stage T1 and large stage T2 renal tumors. J Endourol. 2003;17(6):379-83. [pmid: 12965063].
340 Lundstam S, Jonsson O, Lyrdal D, Peeker R, Pettersson S. Nephron-sparing surgery for renal cell carcinoma--long-term results. Scand J Urol Nephrol. 2003;37(4):299-304. [pmid: 12944187].
341 Kural AR, Demirkesen O, Onal B, et al. Outcome of nephron-sparing surgery: elective versus imperative indications. Urol Int. 2003;71(2):190-6. [pmid: 12890959].
342 Franks ME, Hrebinko RL, Konety BR. Surgical enucleation for the treatment of renal tumors. Urol Int. 2003;71(2):184-9. [pmid: 12890958].
343 Mayo-Smith WW, Dupuy DE, Parikh PM, Pezzullo JA, Cronan JJ. Imaging-guided percutaneous radiofrequency ablation of solid renal masses: techniques and outcomes of 38 treatment sessions in 32 consecutive patients. AJR Am J Roentgenol. 2003;180(6):1503-8. [pmid: 12760909].
344 Zucchi A, Mearini L, Mearini E, Costantini E, Vivacqua C, Porena M. Renal cell carcinoma: histological findings on surgical margins after nephron sparing surgery. J Urol. 2003;169(3):905-8. [pmid: 12576810].
345 Desai MM, Gill IS, Kaouk JH, Matin SF, Novick AC. Laparoscopic partial nephrectomy with suture repair of the pelvicaliceal system. Urology. 2003;61(1):99-104. [pmid: 12559277].
346 McKiernan J, Yossepowitch O, Kattan MW, et al. Partial nephrectomy for renal cortical tumors: pathologic findings and impact on outcome. Urology. 2002;60(6):1003-9. [pmid: 12475658].
347 Castilla EA, Liou LS, Abrahams NA, et al. Prognostic importance of resection margin width after nephron-sparing surgery for renal cell carcinoma. Urology. 2002;60(6):993-7. [pmid: 12475656].
348 Minervini A, Lilas L, Minervini R, Selli C. Prognostic value of nuclear grading in patients with intracapsular (pT1-pT2) renal cell carcinoma. Long-term analysis in 213 patients. Cancer. 2002;94(10):2590-5. [pmid: 12173325].
349 Russo P, Goetzl M, Simmons R, Katz J, Motzer R, Reuter V. Partial nephrectomy: the rationale for expanding the indications. Ann Surg Oncol. 2002;9(7):680-7. [pmid: 12167583].
350 Fryczkowski M, Potyka A, Huk J. Evaluation of organ sparing operation results from planned indications in patients with kidney cancer. Int Urol Nephrol. 2001;32(4):621-7. [pmid: 11989552].
351 Lau WK, Cheville JC, Blute ML, Weaver AL, Zincke H. Prognostic features of pathologic stage T1 renal cell carcinoma after radical nephrectomy. Urology. 2002;59(4):532-7. [pmid: 11927308].
352 Gill IS, Desai MM, Kaouk JH, et al. Laparoscopic partial nephrectomy for renal tumor: duplicating open surgical techniques. J Urol. 2002;167(2 Pt 1):469-7. discussion 475-6. [pmid: 11792899].
353 Piper NY, Bishoff JT, Magee C, et al. Is a 1-CM margin necessary during nephron-sparing surgery for renal cell carcinoma?. Urology. 2001;58(6):849-52. [pmid: 11744443].
354 Sutherland SE, Resnick MI, Maclennan GT, Goldman HB. Does the size of the surgical margin in partial nephrectomy for renal cell cancer really matter?. J Urol. 2002;167(1):61-4. [pmid: 11743276].
355 Jeschke K, Peschel R, Wakonig J, Schellander L, Bartsch G, Henning K. Laparoscopic nephron-sparing surgery for renal tumors. Urology. 2001;58(5):688-92. [pmid: 11711341].
356 Igarashi T, Tobe T, Nakatsu HO, et al. The impact of a 4 cm. cutoff point for stratification of T1N0M0 renal cell carcinoma after radical nephrectomy. J Urol. 2001;165(4):1103-6. [pmid: 11257647].
357 Fryczkowski M, Potyka A, Huk J. Evaluation of organ sparing surgery results in patients with kidney cancer in scheduled operations. Med Sci Monit. 2000;6(6):1098-103. [pmid: 11208462].
358 Rukstalis DB, Khorsandi M, Garcia FU, Hoenig DM, Cohen JK. Clinical experience with open renal cryoablation. Urology. 2001;57(1):34-9. [pmid: 11164139].
359 Gill IS, Novick AC, Meraney AM, et al. Laparoscopic renal cryoablation in 32 patients. Urology. 2000;56(5):748-53. [pmid: 11068292].
360 Filipas D, Fichtner J, Spix C, et al. Nephron-sparing surgery of renal cell carcinoma with a normal opposite kidney: long-term outcome in 180 patients. Urology. 2000;56(3):387-92. [pmid: 10962300].
361 Black P, Filipas D, Fichtner J, Hohenfellner R, Thuroff JW. Nephron sparing surgery for central renal tumors: experience with 33 cases. J Urol. 2000;163(3):737-43. [pmid: 10687967].
362 Fergany AF, Hafez KS, Novick AC. Long-term results of nephron sparing surgery for localized renal cell carcinoma: 10-year followup. J Urol. 2000;163(2):442-5. [pmid: 10647650].
363 Abbou CC, Cicco A, Gasman D, et al. Retroperitoneal laparoscopic versus open radical nephrectomy. J Urol. 1999;161(6):1776-80. [pmid: 10332433].
364 Herr HW. Partial nephrectomy for unilateral renal carcinoma and a normal contralateral kidney: 10-year followup. J Urol. 1999;161(1):33-4. discussion 34-5. [pmid: 10037361].
365 Ono Y, Kinukawa T, Hattori R, et al. Laparoscopic radical nephrectomy for renal cell carcinoma: a five-year experience. Urology. 1999;53(2):280-6. [pmid: 9933040].
366 Cadeddu JA, Ono Y, Clayman RV, et al. Laparoscopic nephrectomy for renal cell cancer: evaluation of efficacy and safety: a multicenter experience. Urology. 1998;52(5):773-7. [pmid: 9801097].
367 Van Poppel H, Bamelis B, Oyen R, Baert L. Partial nephrectomy for renal cell carcinoma can achieve long-term tumor control. J Urol. 1998;160(3 Pt 1):674-8. [pmid: 9720519].
368 Ljungberg B, Alamdari FI, Holmberg G, Granfors T, Duchek M. Radical nephrectomy is still preferable in the treatment of localized renal cell carcinoma. A long-term follow-up study. Eur Urol. 1998;33(1):79-85. [pmid: 9471045].
369 Ono Y, Katoh N, Kinukawa T, Matsuura O, Ohshima S. Laparoscopic radical nephrectomy: the Nagoya experience. J Urol. 1997;158(3 Pt 1):719-23. [pmid: 9258067].
370 Hafez KS, Novick AC, Campbell SC. Patterns of tumor recurrence and guidelines for followup after nephron sparing surgery for sporadic renal cell carcinoma. J Urol. 1997;157(6):2067-70. [pmid: 9146581].
371 Hsi RS, Macleod LC, Gore JL, Wright JL, Harper JD. Comparison of selective parenchymal clamping to hilar clamping during robotic-assisted laparoscopic partial nephrectomy. Urology. 2014;83(2):339-44. [pmid: 24246321].
372 Fardoun T, Chaste D, Oger E, et al. Predictive factors of hemorrhagic complications after partial nephrectomy. Eur J Surg Oncol. 2014;40(1):85-9. [pmid: 24268762].
373 Tomaszewski JJ, Cung B, Smaldone MC, et al. Renal pelvic anatomy is associated with incidence, grade, and need for intervention for urine leak following partial nephrectomy. Eur Urol. 2014;66(5):949-55. [pmid: 24184023].
374 Alesawi A, Nadeau G, Bergeron A, Dujardin T, Lacombe L, Caumartin Y. Cystatin C for early detection of acute kidney injury after laparoscopic partial nephrectomy. Urol Ann. 2014;6(4):298-304. [pmid: 25371605].
375 Petros F, Sukumar S, Haber G-P, et al. Multi-institutional analysis of robot-assisted partial nephrectomy for renal tumors >4 cm versus (less-than or equal to)4 cm in 445 consecutive patients. J Endourol. 2012;26(6):642-6. [pmid: 22050488].
376 Best SL, Park SK, Yaacoub RF, et al. Long-term outcomes of renal tumor radio frequency ablation stratified by tumor diameter: Size matters. J Urol. 2012;187(4):1183-9. [pmid: 22335865].
377 Spana G, Haber G-P, Dulabon LM, et al. Complications after robotic partial nephrectomy at centers of excellence: Multi-institutional analysis of 450 cases. J Urol. 2011;186(2):417-21. [pmid: 21679980].
378 White MA, Haber G-P, Autorino R, et al. Outcomes of robotic partial nephrectomy for renal masses with nephrometry score of (greater-than or equal to)7. Urology. 2011;77(4):809-13. [pmid: 21333338].
379 Naeem N, Petros F, Sukumar S, et al. Robot-assisted partial nephrectomy in obese patients. J Endourol. 2011;25(1):101-5. [pmid: 21204675].
380 Schmit GD, Atwell TD, Callstrom MR, et al. Percutaneous cryoablation of renal masses (greater-than or equal to)3cm: Efficacy and safety in treatment of 108 patients. J Endourol. 2010;24(8):1255-62. [pmid: 20380510].
381 Park S-W, Jung S-G, Lee W, Chung M-K. Changes in renal function after nephron-sparing surgery in patients with a normal contralateral kidney: Original article: Clinical investigation. Int J Urol. 2010;17(5):457-61. [pmid: 20370846].
382 Jeon SH, Han K-S, Yoo KH, et al. How many cases are necessary to develop competence for laparoscopic radical nephrectomy?. J Endourol. 2009;23(12):1965-70. [pmid: 19916754].
383 Hiraoka K, Kawauchi A, Nakamura T, Soh J, Mikami K, Miki T. Radiofrequency ablation for renal tumors: Our experience: Original Article. Int J Urol. 2009;16(11):869-73. [pmid: 19735313].
384 Ritchie RW, Sullivan ME, Jones A. Laparoscopic radical nephrectomy for T2 renal cell carcinoma. Br J Med Surg Urol. 2009;2(3):117-23.
385 Bandi G, Christian MW, Hedican SP, Moon TD, Nakada SY. Oncological outcomes of hand-assisted laparoscopic radical nephrectomy for clinically localized renal cell carcinoma: A single-institution study with (greater-than or equal to)3 years of follow-up. BJU Int. 2008;101(4):459-62. [pmid: 17941924].
386 Polascik TJ, Nosnik I, Mayes JM, Mouraviev V. Short term clinical outcome after laparoscopic cryoablation of the renal tumor (less-than or equal to) 3.5 cm. Technol. Cancer Res Treat. 2007;6(6):621-4.
387 Wille AH, Deger S, Tullmann M, et al. Laparoscopic Partial Nephrectomy in Renal Cell Cancer-Indications, Technique, and Outcome in 80 Patients. Eur Urol. Suppl. 2007;6(10):635-40.
388 Salagierska-Barwinska A, Salagierski M, Salagierski M. 4-year experience with percutaneous US-guided radiofrequency ablation of kidney tumors. Pol J Radiol. 2007;72(2):32-5.
389 Lee D-G, Chang S-G, Jeon SH. Optimal size cutoff point for prognostic stratification of localized renal cell carcinoma. Korean J Urol. 2006;47(6):601-6.
390 Marszalek M, Ponholzer A, Brossner C, Wachter J, Maier U, Madersbacher S. Elective open nephron-sparing surgery for renal masses: Single-center experience with 129 consecutive patients. Urology. 2004;64(1):38-42. [pmid: 15245930].
391 Cooper CJ, Teleb M, Dwivedi A, et al. Comparative Outcome of Computed Tomography-guided Percutaneous Radiofrequency Ablation, Partial Nephrectomy or Radical Nephrectomy in the Treatment of Stage T1 Renal Cell Carcinoma. Rare Tumors. 2015;7(1):5583. [pmid: 25918603].
392 Caputo PA, Ramirez D, Zargar H, et al. Laparoscopic cryoablation for renal cell carcinoma: 100-month oncologic outcomes, a single institution's experience. J Urol. 2015. [pmid: 25912493].
393 Antic T, Taxy JB. Partial nephrectomy for renal tumors: lack of correlation between margin status and local recurrence. Am J Clin Pathol. 2015;143(5):645-51. [pmid: 25873497].
394 Carneiro A, Sivaraman A, Sanchez-Salas R, et al. Evolution from laparoscopic to robotic nephron sparing surgery: a high-volume laparoscopic center experience on achieving ‘trifecta’ outcomes. World J Urol. 2015. [pmid: 25869814].
395 Lay AH, Faddegon S, Olweny EO, et al. Oncologic efficacy of Radiofrequency Ablation for Small Renal Masses: Clear Cell versus Papillary Subtype. J Urol. 2015. [pmid: 25846416].
396 Lamoshi AY, Salkini MW. Off-clamp robotic partial nephrectomy: Technique and outcome. Urol Ann. 2015;7(2):226-30. [pmid: 25835489].
397 Abdeldaeim HM, Abou Youssif TM, Abdel Wahab MM, Kotb AF, El Gebaly OF, Mokhless IA. Prospective Randomized Comparison between Cold and Warm Ischemia in Patients With Renal Insufficiency Undergoing Partial Nephrectomy. Urology. 2015;85(4):862-8. [pmid: 25817108].
398 Kim EH, Larson JA, Potretzke AM, Hulsey NK, Bhayani S, Figenshau RS. Retroperitoneal Robot-Assisted Partial Nephrectomy for Posterior Renal Masses is Associated with Earlier Hospital Discharge: A Single-Institution Retrospective Comparison. J Endourol. 2015. [pmid: 25816694].
399 Chang X, Liu T, Zhang F, et al. The comparison of R.E.N.A.L., PADUA and Centrality Index score in predicting perioperative outcomes and complications following laparoscopic radiofrequency ablation of renal tumors. J Urol. 2015. [pmid: 25813450].
400 Mehrazin R, Smaldone MC, Egleston B, et al. Is anatomic complexity associated with renal tumor growth kinetics under active surveillance?. Urol Oncol. 2015;33(4):167.e7-167.e12. [pmid: 25778696].
401 Camacho JC, Kokabi N, Xing M, et al. R.e.N.a.L. (Radius, exophytic/endophytic, nearness to collecting system or sinus, anterior/posterior, and location relative to polar lines) nephrometry score predicts early tumor recurrence and complications after percutaneous ablative therapies for renal cell carcinoma: a 5-year experience. J Vasc Interv Radiol. 2015;26(5):686-93. [pmid: 25769213].
402 Patel NB, Monn MF, Bahler CD, Sundaram CP. Risk factors associated with 30 day hospital readmission following partial nephrectomy. Can J Urol. 2015;22(1):7640-6. [pmid: 25694012].
403 Satasivam P, Reeves F, Rao K, et al. Patients with medical risk factors for chronic kidney disease are at increased risk of renal impairment despite the use of nephron-sparing surgery. BJU Int. 2015. [pmid: 25676543].
404 Zargar H, Khalifeh A, Autorino R, et al. Urine leak in minimally invasive partial nephrectomy: analysis of risk factors and role of intraoperative ureteral catheterization. Int Braz J Urol. 2014;40(6):763-71. [pmid: 25615258].
405 Zeccolini G, de Concilio B, Del Biondo D, Gallo G, Silvestre P, Celia A. Robotic-assisted partial nephrectomy: experience on 60 cases. Urologia. 2014;0(0):0. [pmid: 25589026].
406 Kim JH, Park YH, Kim YJ, et al. Perioperative and long-term renal functional outcomes of robotic versus laparoscopic partial nephrectomy: a multicenter matched-pair comparison. World J Urol. 2015. [pmid: 25585500].
407 Jang HJ, Song W, Suh YS, et al. Comparison of perioperative outcomes of robotic versus laparoscopic partial nephrectomy for complex renal tumors (RENAL nephrometry score of 7 or higher). Korean J Urol. 2014;55(12):808-13. [pmid: 25512815].
408 Yang CM, Chung HJ, Huang YH, Lin TP, Lin AT, Chen KK. Standardized analysis of laparoscopic and robotic-assisted partial nephrectomy complications with Clavien classification. J Chin Med Assoc. 2014;77(12):637-41. [pmid: 25441770].
409 Miller AJ, Kurup AN, Schmit GD, et al. Percutaneous Clinical T Renal Mass Ablation in the Octogenarian and Nonagenarian: Oncologic Outcomes and Morbidity. J Endourol. 2014. [pmid: 25386995].
410 Han KS, Song GH, You D, et al. Comparison of Hand-Assisted Laparoscopic Versus Robot-Assisted Laparoscopic Versus Open Partial Nephrectomy in Patients with T1 Renal Masses. J Endourol. 2014. [pmid: 25353326].
411 Rodriguez-Faba O, Palou J, Rosales A, et al. Prospective study of ultrasound-guided percutaneous renal cryotherapy: case selection as an optimization factor for a technique. Actas Urol Esp. 2015;39(1):8-12. [pmid: 25124045].
412 Richards KA, Negron E, Cohn JA, Steinberg Z, Eggener SE, Shalhav AL. The impact of body mass index on renal functional outcomes following minimally invasive partial nephrectomy. J Endourol. 2014;28(11):1338-44. [pmid: 24935823].
413 Becker A, Pradel L, Kluth L, et al. Laparoscopic versus open partial nephrectomy for clinical T1 renal masses: no impact of surgical approach on perioperative complications and long-term postoperative quality of life. World J Urol. 2015;33(3):421-6. [pmid: 24879404].
414 Eggener SE, Clark MA, Shikanov S, et al. Impact of warm versus cold ischemia on renal function following partial nephrectomy. World J Urol. 2015;33(3):351-7. [pmid: 24817142].
415 Choo SH, Lee SY, Sung HH, et al. Transperitoneal versus retroperitoneal robotic partial nephrectomy: matched-pair comparisons by nephrometry scores. World J Urol. 2014;32(6):1523-9. [pmid: 24817141].
416 Bessede T, Bigot P, Bernhard JC, et al. Are warm ischemia and ischemia time still predictive factors of poor renal function after partial nephrectomy in the setting of elective indication?. World J Urol. 2015;33(1):11-5. [pmid: 24700310].
417 Pignot G, Mejean A, Bernhard JC, et al. The use of partial nephrectomy: results from a contemporary national prospective multicenter study. World J Urol. 2015;33(1):33-40. [pmid: 24663965].
418 Desai MM, de Castro Abreu AL, Leslie S, et al. Robotic partial nephrectomy with superselective versus main artery clamping: a retrospective comparison. Eur Urol. 2014;66(4):713-9. [pmid: 24486306].
419 Veltri A, Gazzera C, Busso M, et al. T1a as the sole selection criterion for RFA of renal masses: randomized controlled trials versus surgery should not be postponed. Cardiovasc Intervent Radiol. 2014;37(5):1292-8. [pmid: 24337348].
420 Li H-K, Chung H-J, Huang EY, Lin AT, Chen K-K. Impact of warm ischemia time on the change of split renal function after minimally invasive partial nephrectomy in Taiwanese patients. J Chin Med Assoc. 2015;78(1):62-6. [pmid: 25443801].
421 Boylu U, Basatac C, Yildirim U, Onol F, Gumus E. Comparison of surgical, functional, and oncological outcomes of open and robot-assisted partial nephrectomy. J Minimal Access Surg. 2015;11(1):72-7.
422 Gahan JC, Richter MD, Seideman CA, et al. The performance of a modified RENAL nephrometry score in predicting renal mass radiofrequency ablation success. Urology. 2015;85(1):125-9. [pmid: 25440815].
423 Zargar H, Akca O, Ramirez D, et al. The impact of extended warm ischemia time on late renal function after robotic partial nephrectomy. J Endourol. 2015;29(4):444-8. [pmid: 25203268].
424 Curtiss KM, Ball MW, Gorin MA, Harris KT, Pierorazio PM, Allaf ME. Perioperative outcomes of robotic partial nephrectomy for intrarenal tumors. J Endourol. 2015;29(3):293-6. [pmid: 24983384].
425 Larcher A, Fossati N, Mistretta F, et al. Long-term oncologic outcomes of laparoscopic renal cryoablation as primary treatment for small renal masses. Urol Oncol Semin Orig Invest. 2015;33(1):22.e1-22.e9.
426 Lista G, Buffi NM, Lughezzani G, et al. Margin, ischemia, and complications system to report perioperative outcomes of robotic partial nephrectomy: A European multicenter observational study (EMOS project). Urology. 2015;85(3):589-94. [pmid: 25733270].
427 Larson JA, Kaouk JH, Stifelman MD, et al. Nonmodifiable factors and complications contribute to length of stay in Robot-Assisted partial nephrectomy. J Endourol. 2015;29(4):422-9. [pmid: 25286232].
428 Salevitz DA, Patton MW, Tyson MD, et al. The impact of ischemia on long-term renal function after partial nephrectomy in the two kidney model. J Endourol. 2015;29(4):474-8. [pmid: 25265210].
429 Porpiglia F, Bertolo R, Amparore D, et al. Evaluation of functional outcomes after laparoscopic partial nephrectomy using renal scintigraphy: Clamped vs clampless technique. BJU Int. 2015;115(4):606-12. [pmid: 24913695].
430 Webb CM, Kamel M, Eltahawy E, et al. A comparative study of open, laparoscopic and robotic partial nephrectomy in obese patients. Urol Ann. 2015;7(2):231-4. [pmid: 25835601].
431 Wu Z, Li M, Song S, et al. Propensity-score matched analysis comparing robot-assisted with laparoscopic partial nephrectomy. BJU Int. 2015;115(3):437-45. [pmid: 24731125].
432 Ganpule A, Goti A, Mishra S, Sabnis R, Desai M, Desai M. Robotic-assisted laparoscopic partial nephrectomy: A single centre Indian experience. J Minimal Access Surg. 2015;11(1):78-82.
433 Komninos C, Tuliao P, Koo KC, Chang C-H, Han WK, Rha KH. Obesity is not associated with increased operative complications in single-site robotic partial nephrectomy. Yonsei Med J. 2015;56(2):382-7. [pmid: 25683985].
434 Tanaka K, Furukawa J, Shigemura K, et al. Surgery-related outcomes and postoperative split renal function by scintigraphy evaluation in robot-assisted partial nephrectomy in complex renal tumors: An initial case series. J Endourol. 2015;29(1):29-34. [pmid: 25087679].
435 Castaneda CV, Danzig MR, Finkelstein JB, et al. The natural history of renal functional decline in patients undergoing surveillance in the DISSRM registry. Urol Oncol Semin Orig Invest. 2015.
436 Atwell TD, Vlaminck JJ, Boorjian SA, et al. Percutaneous Cryoablation of Stage T1b Renal Cell Carcinoma: Technique Considerations, Safety, and Local Tumor Control. J Vasc Intervent Radiol. 2015.
437 Zargar H, Samarasekera D, Khalifeh A, et al. Laparoscopic vs Percutaneous Cryoablation for the Small Renal Mass: 15-Year Experience at a Single Center. Urology. 2015.
438 Tay MHW, Thamboo TP, Wu FMW, et al. High R.E.N.A.L. nephrometry scores are associated with pathologic upstaging of clinical T1 renal-cell carcinomas in radical nephrectomy specimens: Implications for nephron-sparing surgery. J Endourol. 2014;28(9):1138-42. [pmid: 24810993].
439 Maddox M, Mandava S, Liu J, Boonjindasup A, Lee BR. Robotic Partial Nephrectomy for Clinical Stage T1b Tumors: Intermediate Oncologic and Functional Outcomes. Clin Genitourin Cancer. 2014.
440 Park YH, Lee ES, Kim HH, et al. Long-term oncologic outcomes of hand-assisted laparoscopic radical nephrectomy for clinically localized renal cell carcinoma: A multi-institutional comparative study. J Laparoendosc Adv Surg Techn. 2014;24(8):556-62.
441 Hongo F, Kawauchi A, Ueda T, et al. Long-term outcome of hand-assisted laparoscopic radical nephrectomy for T1 renal cell carcinoma. Int J Urol. 2014.
442 Wiener S, Kiziloz H, Dorin RP, Finnegan K, Shichman SS, Meraney A. Predictors of postoperative decline in estimated glomerular filtration rate in patients undergoing robotic partial nephrectomy. J Endourol. 2014;28(7):807-13. [pmid: 24548077].
443 Harris KT, Ball MW, Gorin MA, Curtiss KM, Pierorazio PM, Allaf ME. Transperitoneal robot-assisted partial nephrectomy: A comparison of posterior and anterior renal masses. J Endourol. 2014;28(6):655-9. [pmid: 24422597].
444 Mukkamala A, He C, Weizer AZ, et al. Long-term oncologic outcomes of minimally invasive partial nephrectomy for renal-cell carcinoma. J Endourol. 2014;28(6):649-54. [pmid: 24405274].
445 Lai W-J, Chung H-J, Chen C-K, et al. Percutaneous computed tomography-guided cryoablation for renal tumor: Experience in 30 cases. J Chin Med Assoc. 2015.
446 Chang X, Ji C, Zhao X, et al. The application of R.E.N.A.L. nephrometry scoring system in predicting the complications after laparoscopic renal radiofrequency ablation. J Endourol. 2014;28(4):424-9. [pmid: 24364623].
447 Lee JW, Kim H, Choo M, et al. Different methods of hilar clamping during partial nephrectomy: Impact on renal function. Int J Urol. 2014;21(3):232-6. [pmid: 24033600].
448 Wah TM, Irving HC, Gregory W, Cartledge J, Joyce AD, Selby PJ. Radiofrequency ablation (RFA) of renal cell carcinoma (RCC): Experience in 200 tumours. BJU Int. 2014;113(3):416-28. [pmid: 24053769].
449 Yokoyama M, Fujii Y, Takeshita H, et al. Renal function after radical nephrectomy: Development and validation of predictive models in Japanese patients. Int J Urol. 2014;21(3):238-42. [pmid: 24118492].
450 Wang H, Zhou L, Guo J, et al. Mini-flank supra-12th rib incision for open partial nephrectomy compared with laparoscopic partial nephrectomy and traditional open partial nephrectomy. PLoS ONE. 2014;9(2).
451 Hsi RS, Macleod LC, Gore JL, Wright JL, Harper JD. Comparison of selective parenchymal clamping to hilar clamping during robotic-assisted laparoscopic partial nephrectomy. Urology. 2014;83(2):339-44. [pmid: 24246321].
452 Springer C, Greco F, Autorino R, et al. Analysis of oncological outcomes and renal function after laparoendoscopic single-site (LESS) partial nephrectomy: A multi-institutional outcome analysis. BJU Int. 2014;113(2):266-74. [pmid: 24053124].
453 Georgiades CS, Rodriguez R. Efficacy and Safety of Percutaneous Cryoablation for Stage 1A/B Renal Cell Carcinoma: Results of a Prospective, Single-Arm, 5-Year Study. Cardiovasc Intervent Radiol. 2014:1-6.
454 Maeda M, Funahashi Y, Sassa N, Fujita T, Majima T, Gotoh M. Prediction of partial nephrectomy outcomes by using the diameter-axis-polar nephrometry score. Int J Urol. 2014;21(5):442-6. [pmid: 24304131].
455 Yang R, Lian H, Zhang G, et al. Laparoscopic radiofrequency ablation with intraoperative contrast-enhanced ultrasonography for T1bN0M0 renal tumors: Initial functional and oncologic outcomes. J Endourol. 2014;28(1):4-9. [pmid: 23998802].
456 Tan H-J, Wolf JS Jr., Ye Z, Hafez KS, Miller DC. Population level assessment of hospital based outcomes following laparoscopic versus open partial nephrectomy during the adoption of minimally invasive surgery. J Urol. 2014;191(5):1231-7. [pmid: 24211600].
457 George AK, Herati AS, Rais-Bahrami S, Waingankar N, Kavoussi LR. Laparoscopic partial nephrectomy for hilar tumors: Oncologic and renal functional outcomes. Urology. 2014;83(1):111-5. [pmid: 24119677].
458 Sandberg JM, Krane LS, Hemal AK. A nonrandomized prospective comparison of robotic-assisted partial nephrectomy in the elderly to a younger cohort: An analysis of 339 patients with intermediate-term follow-up. Urology. 2014;84(4):838-43. [pmid: 25260445].
459 Yeon JS, Son SJ, Lee YJ, et al. The nephrometry score: Is it effective for predicting perioperative outcome during robot-assisted partial nephrectomy?. Korean J Urol. 2014;55(4):254-9. [pmid: 24741414].
460 Komninos C, Shin TY, Tuliao P, et al. Robotic partial nephrectomy for completely endophytic renal tumors: Complications and functional and oncologic outcomes during a 4-year median period of follow-up. Urology. 2014;84(6):1367-73. [pmid: 25440824].
461 Ma Y, Bedir S, Cadeddu JA, Gahan JC. Long-term outcomes in healthy adults after radiofrequency ablation of T1a renal tumours. BJU Int. 2014;113(1):51-5. [pmid: 24053553].
462 Verhoest G, Patard JJ, Oger E, et al. Predictive factors of chronic kidney disease stage V after partial nephrectomy in a solitary kidney: A multi-institutional study. Urol Oncol Semin Orig Invest. 2014;32(1):28.e21-28.e26.
463 Lorber G, Glamore M, Doshi M, Jorda M, Morillo-Burgos G, Leveillee RJ. Long-term oncologic outcomes following radiofrequency ablation with real-time temperature monitoring for T1a renal cell cancer. Urol Oncol Semin Orig Invest. 2014;32(7):1017-23.
464 Mukkamala A, He C, Weizer AZ, et al. Long-term renal functional outcomes of minimally invasive partial nephrectomy for renal cell carcinoma. Urol Oncol Semin Orig Invest. 2014;32(8):1247-51.
465 Hu JC, Treat E, Filson CP, et al. Technique and outcomes of robot-assisted retroperitoneoscopic partial nephrectomy: A multicenter study. Eur Urol. 2014;66(3):542-9. [pmid: 24857539].
466 Autorino R, Khalifeh A, Laydner H, et al. Robot-assisted partial nephrectomy (RAPN) for completely endophytic renal masses: A single institution experience. BJU Int. 2014;113(5):762-8. [pmid: 24053421].
467 Tan H-J, Wolf JS, Ye Z, Hafez KS, Miller DC. Population level assessment of hospital based outcomes following laparoscopic versus open partial nephrectomy durin. The adoption of minimally invasive surgery. J Urol. 2014;191(5):1231-7. [pmid: 24211600].
468 Johnson S, Pham KN, See W, Begun FP, Langenstroer P. Laparoscopic cryoablation for clinical stage T1 renal masses: Long-term oncologic outcomes at the medical college of wisconsin. Urology. 2014;84(3):613-7. [pmid: 25168540].
469 Kim EH, Tanagho YS, Saad NE, Bhayani SB, Figenshau RS. Comparison of laparoscopic and percutaneous cryoablation for treatment of renal masses. Urology. 2014;83(5):1081-7. [pmid: 24560975].
470 Zargar H, Bhayani S, Allaf ME, et al. Comparison of perioperative outcomes of robot-assisted partial nephrectomy and open partial nephrectomy in patients with a solitary kidney. J Endourol. 2014;28(10):1224-30. [pmid: 24959704].
471 Takagi T, Mir MC, Campbell RA, et al. Assessment of outcomes in partial nephrectomy incorporating detailed functional analysis. Urology. 2014;84(5):1128-33. [pmid: 25239254].
472 Fardoun T, Chaste D, Oger E, et al. Predictive factors of hemorrhagic complications after partial nephrectomy. Eur J Surg Oncol. 2014;40(1):85-9. [pmid: 24268762].
473 Ficarra V, Minervini A, Antonelli A, et al. A multicentre matched-pair analysis comparing robot-assisted versus open partial nephrectomy. BJU Int. 2014;113(6):936-41. [pmid: 24219227].
474 Jung S, Min GE, Chung BI, Jeon SH. Risk factors for postoperative hemorrhage after partial nephrectomy. Korean J Urol. 2014;55(1):17-22. [pmid: 24466392].
475 Ghani KR, Sukumar S, Sammon JD, Rogers CG, Trinh Q-D, Menon M. Practice patterns and outcomes of open and minimally invasive partial nephrectomy since the introduction of robotic partial nephrectomy: Results from the nationwide inpatient sample. J Urol. 2014;191(4):907-12. [pmid: 24184365].
476 Mobley JM, Kim EH, Larson JA, et al. Patients with pathologically proven renal disease have similar declines in renal function following robot-assisted partial nephrectomy. J Endourol. 2014;28(12):1429-34. [pmid: 25238210].
477 Volpe A, Garrou D, Amparore D, et al. Perioperative and renal functional outcomes of elective robot-assisted partial nephrectomy (RAPN) for renal tumours with high surgical complexity. BJU Int. 2014;114(6):903-9. [pmid: 24673750].
478 Youssef FR, Smith DJ, Oakley NE. Laparoscopic and open partial nephrectomy: A UK centre's experience. J Clini Urol. 2014;7(2):105-11.
479 Gin GE, Maschino AC, Spaliviero M, Vertosick EA, Bernstein ML, Coleman JA. Comparison of perioperative outcomes of retroperitoneal and transperitoneal minimally invasive partial nephrectomy after adjusting for tumor complexity. Urology. 2014;84(6):1355-60. [pmid: 25288573].
480 Liu J-J, Leppert JT, Maxwell BG, Panousis P, Chung BI. Trends and perioperative outcomes for laparoscopic and robotic nephrectomy using the National Surgical Quality Improvement Program (NSQIP) database. Urol Oncol Semin Orig Invest. 2014;32(4):473-9.
481 Wu Z-J, Ye H-M, Li M-M, et al. Application of R. E. N. A. L. scoring system in robotic laparoscopic partial nephrectomy. Acad J Second Mil Med Univ. 2014;35(4):383-7.
482 Oh JJ, Byun S-S, Lee SE, et al. Partial nephrectomy versus radical nephrectomy for non-metastatic pathological T3a renal cell carcinoma: A multi-institutional comparative analysis. Int J Urol. 2014;21(4):352-7. [pmid: 24118633].
483 Ye H-M, Wang R, Wu Z-J, et al. da Vinci robot-assisted laparoscopic partial nephrectomy for renal tumors with PADUA score (greater-than or equal to)10. Acad J Second Mil Med Univ. 2014;35(7):800-3.