# Evidence Tables

## Evidence Tables for KQs 1 and 2-Diagnostic KQs

Table D1 Study Characteristics Table for KQs 1 and 2

Table D2 Participant Characteristics Table for KQs 1 and 2

Table D3 Tumor Characteristics Table for KQs 1 and 2

Table D4 Tumor Scores Table for KQs 1 and 2

Table D5 Outcomes Table for KQs 1 and 2

Table D6 Accuracy Data Table for KQs 1 and 2

Table D7 Harms Table for KQs 1 and 2

## Evidence Tables for KQs 3a and 3b-Management KQs

Table D8 Study Characteristics Table for KQs 3a and 3b

Table D9 Participant Characteristics Table for KQs 3a and 3b

Table D10 Tumor Characteristics Table for KQs 3a and 3b

Table D11 Tumor Scores Table for KQs 3a and 3b

Table D12 Outcomes Table for KQs 3a and 3b

Table D13 Perioperative Outcomes Table for KQs 3a and 3b

### Reference List

1 Akdogan B, Gudeloglu A, Inci K, Gunay LM, Koni A, Ozen H. Prevalence and predictors of benign lesions in renal masses smaller than 7 cm presumed to be renal cell carcinoma. Clin Genitourin Cancer. 2012;10(2):121-5. [pmid: 22401753].
2 Antonelli A, Furlan M, Sandri M, et al. The R.e.N.a.L. Nephrometric nomogram cannot accurately predict malignancy or aggressiveness of small renal masses amenable to partial nephrectomy. Clin Genitourin Cancer. 2014;12(5):366-72. [pmid: 24637340].
3 Bazzi WM, Dejbakhsh SZ, Bernstein M, Russo P. The association of baseline health and gender with small renal mass pathology. Can J Urol. 2014;21(3):7271-6. [pmid: 24978356].
4 Campbell SC, Novick AC, Herts B, et al. Prospective evaluation of fine needle aspiration of small, solid renal masses: accuracy and morbidity. Urology. 1997;50(1):25-9. [pmid: 9218014].
5 Choi SK, Jeon SH, Chang SG. Characterization of small renal masses less than 4 cm with quadriphasic multidetector helical computed tomography: differentiation of benign and malignant lesions. Korean J Urol. 2012;53(3):159-64. [pmid: 22468210].
6 Chung MS, Choi HJ, Kim MH, Cho KS. Comparison of T2-weighted MRI with and without fat suppression for differentiating renal angiomyolipomas without visible fat from other renal tumors. AJR Am J Roentgenol. 2014;202(4):765-71. [pmid: 24660704].
7 Chyhrai A, Sanjmyatav J, Gajda M, et al. Multi-colour FISH on preoperative renal tumour biopsies to confirm the diagnosis of uncertain renal masses. World J Urol. 2010;28(3):269-74. [pmid: 20390284].
8 Fujita T, Iwamura M, Wakatabe Y, et al. Predictors of benign histology in clinical T1a renal cell carcinoma tumors undergoing partial nephrectomy. Int J Urol. 2014;21(1):100-2. [pmid: 23635425].
9 Halverson SJ, Kunju LP, Bhalla R, et al. Accuracy of determining small renal mass management with risk stratified biopsies: confirmation by final pathology. J Urol. 2013;189(2):441-6. [pmid: 23253955].
10 Harisinghani MG, Maher MM, Gervais DA, et al. Incidence of malignancy in complex cystic renal masses (Bosniak category III): should imaging-guided biopsy precede surgery?. AJR Am J Roentgenol. 2003;180(3):755-8. [pmid: 12591691].
11 Jeon HG, Lee SR, Kim KH, et al. Benign lesions after partial nephrectomy for presumed renal cell carcinoma in masses 4 cm or less: prevalence and predictors in Korean patients. Urology. 2010;76(3):574-9. [pmid: 20303148].
12 Kava BR, Eldefrawy A, Ayyathurai R, et al. Impact of body mass index and tumor location on the incidence of benign histology at the time of nephron-sparing surgery. Int Urol Nephrol. 2012;44(5):1319-24. [pmid: 22678516].
13 Keehn A, Srivastava A, Maiman R, et al. The Relationship Between Visceral Obesity and the Clinicopathologic Features of Patients with Small Renal Masses. J Endourol. 2014. [pmid: 25203393].
14 Koo KC, Yoo H, Shin TY, et al. External validation of the RENAL nephrometry score nomogram for predicting high-grade renal cell carcinoma in solid, enhancing, and small renal masses. World J Urol. 2014;32(1):249-55. [pmid: 24013182].
15 Lane BR, Babineau D, Kattan MW, et al. A preoperative prognostic nomogram for solid enhancing renal tumors 7 cm or less amenable to partial nephrectomy. J Urol. 2007;178(2):429-34. [pmid: 17561141].
16 Leveridge MJ, Finelli A, Kachura JR, et al. Outcomes of small renal mass needle core biopsy, nondiagnostic percutaneous biopsy, and the role of repeat biopsy. Eur Urol. 2011;60(3):578-84. [pmid: 21704449].
17 Londono DC, Wuerstle MC, Thomas AA, et al. Accuracy and implications of percutaneous renal biopsy in the management of renal masses. Perm J. 2013;17(3):4-7. [pmid: 24355883].
18 Menogue SR, O'Brien BA, Brown AL, Cohen RJ. Percutaneous core biopsy of small renal mass lesions: a diagnostic tool to better stratify patients for surgical intervention. BJU Int. 2013;111(4 Pt B):E146-51. [pmid: 22805186].
19 Millet I, Curros F, Serre I, Taourel P, Thuret R. Can renal biopsy accurately predict histological subtype and Fuhrman grade of renal cell carcinoma?. J Urol. 2012;188(5):1690-4. [pmid: 22998910].
20 Mullins JK, Kaouk JH, Bhayani S, et al. Tumor complexity predicts malignant disease for small renal masses. J Urol. 2012;188(6):2072-6. [pmid: 23083863].
21 Murphy AM, Buck AM, Benson MC, McKiernan JM. Increasing detection rate of benign renal tumors: evaluation of factors predicting for benign tumor histologic features during past two decades. Urology. 2009;73(6):1293-7. [pmid: 19371933].
22 Neuzillet Y, Lechevallier E, Andre M, Daniel L, Coulange C. Accuracy and clinical role of fine needle percutaneous biopsy with computerized tomography guidance of small (less than 4.0 cm) renal masses. J Urol. 2004;171(5):1802-5. [pmid: 15076280].
23 Nishikawa M, Miyake H, Kitajima K, Takahashi S, Sugimura K, Fujisawa M. Preoperative differentiation between benign and malignant renal masses smaller than 4 cm treated with partial nephrectomy. Int J Clin Oncol. 2014. [pmid: 24526391].
24 Park SY, Jeon SS, Lee SY, et al. Incidence and predictive factors of benign renal lesions in Korean patients with preoperative imaging diagnoses of renal cell carcinoma. J Korean Med Sci. 2011;26(3):360-4. [pmid: 21394303].
25 Park SY, Park BK, Kim CK, Kwon GY. Ultrasound-guided core biopsy of small renal masses: diagnostic rate and limitations. J Vasc Interv Radiol. 2013;24(1):90-6. [pmid: 23206333].
26 Rosenkrantz AB, Wehrli NE, Melamed J, Taneja SS, Shaikh MB. Renal masses measuring under 2 cm: Pathologic outcomes and associations with MRI features. Eur J Radiol. 2014;83(8):1311-6. [pmid: 24882784].
27 Salem S, Ponsky LE, Abouassaly R, et al. Image-guided biopsy of small renal masses in the era of ablative therapies. Int J Urol. 2013;20(6):580-4. [pmid: 23190309].
28 Shannon BA, Cohen RJ, de Bruto H, Davies RJ. The Value of Preoperative Needle Core Biopsy for Diagnosing Benign Lesions Among Small, Incidentally Detected Renal Masses. J Urol. 2008;180(4):1257-61. [pmid: 18707712].
29 Sofikerim M, Tatlisen A, Canoz O, Tokat F, Demirtas A, Mavili E. What is the role of percutaneous needle core biopsy in diagnosis of renal masses?. Urology. 2010;76(3):614-8. [pmid: 20110106].
30 Soga N, Nishikawa K, Takaki H, et al. Low incidence of benign lesions in resected suspicious renal masses greater than 2 cm: Single-center experience from Japan. Int J Urol. 2012;19(8):729-34. [pmid: 22515572].
31 Vasudevan A, Davies RJ, Shannon BA, Cohen RJ. Incidental renal tumours: the frequency of benign lesions and the role of preoperative core biopsy. BJU Int. 2006;97(5):946-9. [pmid: 16643475].
32 Volpe A, Mattar K, Finelli A, et al. Contemporary results of percutaneous biopsy of 100 small renal masses: a single center experience. J Urol. 2008;180(6):2333-7. [pmid: 18930274].
33 Wang R, Wolf JS Jr, Wood DP Jr, Higgins EJ, Hafez KS. Accuracy of percutaneous core biopsy in management of small renal masses. Urology. 2009;73(3):586-90. discussion 590-1. [pmid: 19118884].
34 Xiong YH, Zhang ZL, Li YH, et al. Benign pathological findings in 303 Chinese patients undergoing surgery for presumed localized renal cell carcinoma. Int J Urol. 2010;17(6):517-21. [pmid: 20370841].
35 Shin TY, Kim J, Koo KC, et al. Assessing the anatomical characteristics of renal masses has a limited effect on the prediction of pathological outcomes in solid, enhancing, small renal masses: Results using the PADUA classification system. BJU Int. 2014;113(5):754-61. [pmid: 24053790].
36 Ball MW, Gorin MA, Bhayani SB, et al. Preoperative predictors of malignancy and unfavorable pathology for clinical T1a tumors treated with partial nephrectomy: A multi-institutional analysis. Urol Oncol Semin Orig Invest. 2015;33(3):112.e9-112.e14.
37 Schmidbauer J, Remzi M, Memarsadeghi M, et al. Diagnostic accuracy of computed tomography-guided percutaneous biopsy of renal masses. Eur Urol. 2008;53(5):1003-11. [pmid: 18061339].
38 Reichelt O, Gajda M, Chyhrai A, Wunderlich H, Junker K, Schubert J. Ultrasound-guided biopsy of homogenous solid renal masses. Eur Urol. 2007;52(5):1421-6. [pmid: 17306920].
39 Prince J, Bultman E, Hinshaw L, et al. Patient and Tumor Characteristics can Predict Nondiagnostic Renal Mass Biopsy Findings. J Urol. 2014. [pmid: 25498574].
40 Richard PO, Jewett MA, Bhatt JR, et al. Renal Tumor Biopsy for Small Renal Masses: A Single-center 13-year Experience. Eur Urol. 2015. [pmid: 25900781].
41 Blumenfeld AJ, Guru K, Fuchs GJ, Kim HL. Percutaneous biopsy of renal cell carcinoma underestimates nuclear grade. Urology. 2010;76(3):610-3. [pmid: 20163843].
42 Leonard M, Tait CD, Gillan AS, Rai BP, Byrne DJ, Nabi G. Impact of multiple deprivations on detection, progression and interventions in small renal masses (less than 4 cm) in a population based study. Eur J Surg Oncol. 2013;39(10):1157-63. [pmid: 23886896].
43 Scanga LR, Maygarden SJ. Utility of fine-needle aspiration and core biopsy with touch preparation in the diagnosis of renal lesions. Cancer Cytopathol. 2014;122(3):182-90. [pmid: 24353131].
44 Schmit GD, Atwell TD, Callstrom MR, et al. Percutaneous cryoablation of renal masses (greater-than or equal to)3cm: Efficacy and safety in treatment of 108 patients. J Endourol. 2010;24(8):1255-62. [pmid: 20380510].
45 Barbalias GA, Liatsikos EN, Tsintavis A, Nikiforidis G. Adenocarcinoma of the kidney: nephron-sparing surgical approach vs. radical nephrectomy. J Surg Oncol. 1999;72(3):156-61. [pmid: 10562362].
46 Ficarra V, Novella G, Sarti A, et al. Psycho-social well-being and general health status after surgical treatment for localized renal cell carcinoma. Int Urol Nephrol. 2002-2003;34(4):441-6. [pmid: 14577481].
47 Indudhara R, Bueschen AJ, Urban DA, Burns JR, Lloyd LK. Nephron-sparing surgery compared with radical nephrectomy for renal tumors: current indications and results. South Med J. 1997;90(10):982-5. [pmid: 9347807].
48 Kim JM, Song PH, Kim HT, Park TC. Comparison of Partial and Radical Nephrectomy for pT1b Renal Cell Carcinoma. Korean J Urol. 2010;51(9):596-600. [pmid: 20856643].
49 Mariusdottir E, Jonsson E, Marteinsson VT, Sigurdsson MI, Gudbjartsson T. Kidney function following partial or radical nephrectomy for renal cell carcinoma: a population-based study. Scand J Urol. 2013;47(6):476-82. [pmid: 23597159].
50 Milonas D, Skulcius G, Baltrimavicius R, et al. Comparison of long-term results after nephron-sparing surgery and radical nephrectomy in treating 4- to 7-cm renal cell carcinoma. Medicina (Kaunas). 2013;49(5):223-8. [pmid: 24247918].
51 Roos FC, Brenner W, Thomas C, et al. Functional analysis of elective nephron-sparing surgery vs radical nephrectomy for renal tumors larger than 4 cm. Urology. 2012;79(3):607-13. [pmid: 22386408].
52 Shinohara N, Harabayashi T, Sato S, Hioka T, Tsuchiya K, Koyanagi T. Impact of nephron-sparing surgery on quality of life in patients with localized renal cell carcinoma. Eur Urol. 2001;39(1):114-9. [pmid: 11173949].
53 Xu H, Ding Q, Jiang H-W. Fewer complications after laparoscopic nephrectomy as compared to the open procedure with the modified Clavien classification system - a retrospective analysis from Southern China. World J Surg Oncol. 2014;12(1).
54 Antonelli A, Ficarra V, Bertini R, et al. Elective partial nephrectomy is equivalent to radical nephrectomy in patients with clinical T1 renal cell carcinoma: results of a retrospective, comparative, multi-institutional study. BJU Int. 2012;109(7):1013-8. [pmid: 21883829].
55 Antoniewicz AA, Poletajew S, Borowka A, Pasierski T, Rostek M, Pikto-Pietkiewicz W. Renal function and adaptive changes in patients after radical or partial nephrectomy. Int Urol Nephrol. 2012;44(3):745-51. [pmid: 21947980].
56 Badalato GM, Kates M, Wisnivesky JP, Choudhury AR, McKiernan JM. Survival after partial and radical nephrectomy for the treatment of stage T1bN0M0 renal cell carcinoma (RCC) in the USA: a propensity scoring approach. BJU Int. 2012;109(10):1457-62. [pmid: 21933334].
57 Bedke J, Pritsch M, Buse S, et al. Prognostic stratification of localized renal cell carcinoma by tumor size. J Urol. 2008;180(1):62-7. [pmid: 18485376].
58 Crepel M, Jeldres C, Sun M, et al. A population-based comparison of cancer-control rates between radical and partial nephrectomy for T1A renal cell carcinoma. Urology. 2010;76(4):883-8. [pmid: 20932408].
59 Crepel M, Jeldres C, Perrotte P, et al. Nephron-sparing surgery is equally effective to radical nephrectomy for T1BN0M0 renal cell carcinoma: a population-based assessment. Urology. 2010;75(2):271-5. [pmid: 19962740].
60 Dash A, Vickers AJ, Schachter LR, Bach AM, Snyder ME, Russo P. Comparison of outcomes in elective partial vs radical nephrectomy for clear cell renal cell carcinoma of 4-7 cm. BJU Int. 2006;97(5):939-45. [pmid: 16643474].
61 Daugherty M, Bratslavsky G. Compared with radical nephrectomy, nephron-sparing surgery offers a long-term survival advantage in patients between the ages of 20 and 44 years with renal cell carcinomas (</=4 cm): an analysis of the SEER database. Urol Oncol. 2014;32(5):549-54. [pmid: 24495447].
62 Thompson RH, Siddiqui S, Lohse CM, Leibovich BC, Russo P, Blute ML. Partial versus radical nephrectomy for 4 to 7 cm renal cortical tumors. J Urol. 2009;182(6):2601-6. [pmid: 19836797].
63 Huang WC, Levey AS, Serio AM, et al. Chronic kidney disease after nephrectomy in patients with renal cortical tumours: a retrospective cohort study. Lancet Oncol. 2006;7(9):735-40. [pmid: 16945768].
64 Huang WC, Elkin EB, Levey AS, Jang TL, Russo P. Partial nephrectomy versus radical nephrectomy in patients with small renal tumors--is there a difference in mortality and cardiovascular outcomes?. J Urol. 2009;181(1):55-61. discussion 61-2. [pmid: 19012918].
65 Kates M, Badalato GM, Pitman M, McKiernan JM. Increased risk of overall and cardiovascular mortality after radical nephrectomy for renal cell carcinoma 2 cm or less. J Urol. 2011;186(4):1247-53. [pmid: 21849201].
66 Kopp RP, Mehrazin R, Palazzi KL, et al. Survival outcomes after radical and partial nephrectomy for clinical T2 renal tumours categorised by R.E.N.A.L. nephrometry score. BJU Int. 2013. [pmid: 24274650].
67 Kyung YS, You D, Kwon T, et al. The type of nephrectomy has little effect on overall survival or cardiac events in patients of 70 years and older with localized clinical t1 stage renal masses. Korean J Urol. 2014;55(7):446-52. [pmid: 25045442].
68 Lane BR, Fergany AF, Weight CJ, Campbell SC. Renal functional outcomes after partial nephrectomy with extended ischemic intervals are better than after radical nephrectomy. J Urol. 2010;184(4):1286-90. [pmid: 20723936].
69 Li JR, Yang CR, Cheng CL, et al. Partial nephrectomy in the treatment of localized renal cell carcinoma: experience of Taichung Veterans General Hospital. J Chin Med Assoc. 2007;70(7):281-5. [pmid: 17631464].
70 Li Q, Guan H, Qin J, Jiang T. Mini-Margin nephron sparing surgery for renal cell carcinoma 4 cm or less. Adv Urol. 2010. [pmid: 20862196].
71 Lowrance WT, Yee DS, Savage C, et al. Complications after radical and partial nephrectomy as a function of age. J Urol. 2010;183(5):1725-30. [pmid: 20299040].
72 McKiernan J, Simmons R, Katz J, Russo P. Natural history of chronic renal insufficiency after partial and radical nephrectomy. Urology. 2002;59(6):816-20. [pmid: 12031359].
73 Medina-Polo J, Romero-Otero J, Rodriguez-Antolin A, et al. Can partial nephrectomy preserve renal function and modify survival in comparison with radical nephrectomy?. Scand J Urol Nephrol. 2011;45(2):143-50. [pmid: 21247272].
74 Meskawi M, Becker A, Bianchi M, et al. Partial and radical nephrectomy provide comparable long-term cancer control for T1b renal cell carcinoma. Int J Urol. 2014;21(2):122-8. [pmid: 23819700].
75 Mitchell RE, Gilbert SM, Murphy AM, Olsson CA, Benson MC, McKiernan JM. Partial nephrectomy and radical nephrectomy offer similar cancer outcomes in renal cortical tumors 4 cm or larger. Urology. 2006;67(2):260-4. [pmid: 16461075].
76 Miyamoto K, Inoue S, Kajiwara M, Teishima J, Matsubara A. Comparison of renal function after partial nephrectomy and radical nephrectomy for renal cell carcinoma. Urol Int. 2012;89(2):227-32. [pmid: 22846207].
77 Patard JJ, Shvarts O, Lam JS, et al. Safety and efficacy of partial nephrectomy for all T1 tumors based on an international multicenter experience. J Urol. 2004;171(6 Pt 1):2181-5. quiz 2435. [pmid: 15126781].
78 Scosyrev E, Messing EM, Sylvester R, Campbell S, Van Poppel H. Renal function after nephron-sparing surgery versus radical nephrectomy: results from EORTC randomized trial 30904. Eur Urol. 2014;65(2):372-7. [pmid: 23850254].
79 Smaldone MC, Egleston B, Uzzo RG, Kutikov A. Does partial nephrectomy result in a durable overall survival benefit in the Medicare population?. J Urol. 2012;188(6):2089-94. [pmid: 23083877].
80 Sun M, Bianchi M, Hansen J, et al. Chronic kidney disease after nephrectomy in patients with small renal masses: a retrospective observational analysis. Eur Urol. 2012;62(4):696-703. [pmid: 22483407].
81 Takagi T, Kondo T, Iizuka J, et al. Postoperative renal function after partial nephrectomy for renal cell carcinoma in patients with pre-existing chronic kidney disease: a comparison with radical nephrectomy. Int J Urol. 2011;18(6):472-6. [pmid: 21481013].
82 Tan HJ, Norton EC, Ye Z, Hafez KS, Gore JL, Miller DC. Long-term survival following partial vs radical nephrectomy among older patients with early-stage kidney cancer. JAMA. 2012;307(15):1629-35. [pmid: 22511691].
83 Thompson RH, Boorjian SA, Lohse CM, et al. Radical nephrectomy for pT1a renal masses may be associated with decreased overall survival compared with partial nephrectomy. J Urol. 2008;179(2):468-71. discussion 472-3. [pmid: 18076931].
84 Tomaszewski JJ, Uzzo RG, Kutikov A, et al. Assessing the burden of complications after surgery for clinically localized kidney cancer by age and comorbidity status. Urology. 2014;83(4):843-9. [pmid: 24680455].
85 Uchida K, Takahashi A, Masumori N, Yanase M, Itoh N, Tsukamoto T. Partial nephrectomy for small localized renal cell carcinoma. Hinyokika Kiyo. 2004;50(6):389-95. [pmid: 15293735].
86 Uzzo RG, Wei JT, Hafez K, Kay R, Novick AC. Comparison of direct hospital costs and length of stay for radical nephrectomy versus nephron-sparing surgery in the management of localized renal cell carcinoma. Urology. 1999;54(6):994-8. [pmid: 10604696].
87 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective, randomised EORTC intergroup phase 3 study comparing the oncologic outcome of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Eur Urol. 2011;59(4):543-52. [pmid: 21186077].
88 Weight CJ, Larson BT, Gao T, et al. Elective partial nephrectomy in patients with clinical T1b renal tumors is associated with improved overall survival. Urology. 2010;76(3):631-7. [pmid: 20451967].
89 Weight CJ, Lythgoe C, Unnikrishnan R, Lane BR, Campbell SC, Fergany AF. Partial nephrectomy does not compromise survival in patients with pathologic upstaging to pT2/pT3 or high-grade renal tumors compared with radical nephrectomy. Urology. 2011;77(5):1142-6. [pmid: 21420154].
90 Weight CJ, Larson BT, Fergany AF, et al. Nephrectomy induced chronic renal insufficiency is associated with increased risk of cardiovascular death and death from any cause in patients with localized cT1b renal masses. J Urol. 2010;183(4):1317-23. [pmid: 20171688].
91 Woldu SL, Weinberg AC, Korets R, et al. Who Really Benefits From Nephron-sparing Surgery?. Urology. 2014;84(4):860-8. [pmid: 25260447].
92 Yasuda Y, Yuasa T, Yamamoto S, et al. Evaluation of the RENAL nephrometry scoring system in adopting nephron-sparing surgery for cT1 renal cancer. Urol Int. 2013;90(2):179-83. [pmid: 23146865].
93 Zini L, Perrotte P, Capitanio U, et al. Radical versus partial nephrectomy: effect on overall and noncancer mortality. Cancer. 2009;115(7):1465-71. [pmid: 19195042].
94 Chung JS, Son NH, Lee SE, et al. Overall survival and renal function after partial and radical nephrectomy among older patients with localised renal cell carcinoma: A propensity-matched multicentre study. Eur J Cancer. 2015;51(4):489-97. [pmid: 25576517].
95 Kim CS, Bae EH, Ma SK, Kweon SS, Kim SW. Impact of partial nephrectomy on kidney function in patients with renal cell carcinoma. BMC Nephrol. 2014;15:181. [pmid: 25410757].
96 Van Poppel H, Da Pozzo L, Albrecht W, et al. A prospective randomized EORTC intergroup phase 3 study comparing the complications of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Eur Urol. 2007;51(6):1606-15. [pmid: 17140723].
97 O'Malley RL, Hayn MH, Brewer KA, et al. Cancer control of partial nephrectomy for high-risk localized renal cell carcinoma: population-based and single-institutional analysis. World J Urol. 2015. [pmid: 25805189].
98 Brewer K, O'Malley RL, Hayn M, et al. Perioperative and renal function outcomes of minimally invasive partial nephrectomy for T1b and T2a kidney tumors. J Endourol. 2012;26(3):244-8. [pmid: 22192099].
99 Deklaj T, Lifshitz DA, Shikanov SA, Katz MH, Zorn KC, Shalhav AL. Laparoscopic radical versus laparoscopic partial nephrectomy for clinical T1bN0M0 renal tumors: comparison of perioperative, pathological, and functional outcomes. J Endourol. 2010;24(10):1603-7. [pmid: 20932215].
100 Janetschek G, Jeschke K, Peschel R, Strohmeyer D, Henning K, Bartsch G. Laparoscopic surgery for stage T1 renal cell carcinoma: radical nephrectomy and wedge resection. Eur Urol. 2000;38(2):131-8. [pmid: 10895002].
101 Kim FJ, Rha KH, Hernandez F, Jarrett TW, Pinto PA, Kavoussi LR. Laparoscopic radical versus partial nephrectomy: assessment of complications. J Urol. 2003;170(2 Pt 1):408-11. [pmid: 12853787].
102 Snow DC, Bhayani SB. Rapid communication: chronic renal insufficiency after laparoscopic partial nephrectomy and radical nephrectomy for pathologic t1a lesions. J Endourol. 2008;22(2):337-41. [pmid: 18257672].
103 Zorn KC, Gong EM, Orvieto MA, et al. Comparison of laparoscopic radical and partial nephrectomy: effects on long-term serum creatinine. Urology. 2007;69(6):1035-40. [pmid: 17572181].
104 Becker A, Ravi P, Roghmann F, et al. Laparoscopic radical nephrectomy vs laparoscopic or open partial nephrectomy for T1 renal cell carcinoma: comparison of complication rates in elderly patients during the initial phase of adoption. Urology. 2014;83(6):1285-91. [pmid: 24862392].
105 Matin SF, Gill IS, Worley S, Novick AC. Outcome of laparoscopic radical and open partial nephrectomy for the sporadic 4 cm. or less renal tumor with a normal contralateral kidney. J Urol. 2002;168(4 Pt 1):1356-9. discussion 1359-60. [pmid: 12352392].
106 Roos FC, Brenner W, Jager W, et al. Perioperative morbidity and renal function in young and elderly patients undergoing elective nephron-sparing surgery or radical nephrectomy for renal tumours larger than 4 cm. BJU Int. 2011;107(4):554-61. [pmid: 20707798].
107 Iizuka J, Kondo T, Hashimoto Y, et al. Similar functional outcomes after partial nephrectomy for clinical T1b and T1a renal cell carcinoma. Int J Urol. 2012;19(11):980-6. [pmid: 22735049].
108 Minervini A, Serni S, Tuccio A, et al. Simple enucleation versus radical nephrectomy in the treatment of pT1a and pT1b renal cell carcinoma. Ann Surg Oncol. 2012;19(2):694-700. [pmid: 21861225].
109 Jeon HG, Jeong IG, Lee JW, Lee SE, Lee E. Prognostic factors for chronic kidney disease after curative surgery in patients with small renal tumors. Urology. 2009;74(5):1064-8. [pmid: 19758688].
110 Gratzke C, Seitz M, Bayrle F, et al. Quality of life and perioperative outcomes after retroperitoneoscopic radical nephrectomy (RN), open RN and nephron-sparing surgery in patients with renal cell carcinoma. BJU Int. 2009;104(4):470-5. [pmid: 19239445].
111 Bensalah K, Zeltser I, Tuncel A, Cadeddu J, Lotan Y. Evaluation of costs and morbidity associated with laparoscopic radiofrequency ablation and laparoscopic partial nephrectomy for treating small renal tumours. BJU Int. 2008;101(4):467-71. [pmid: 17922853].
112 Desai MM, Aron M, Gill IS. Laparoscopic partial nephrectomy versus laparoscopic cryoablation for the small renal tumor. Urology. 2005;66(5 Suppl):23-8. [pmid: 16194703].
113 Emara AM, Kommu SS, Hindley RG, Barber NJ. Robot-assisted partial nephrectomy vs laparoscopic cryoablation for the small renal mass: redefining the minimally invasive ‘gold standard’. BJU Int. 2014;113(1):92-9. [pmid: 24053473].
114 Guillotreau J, Haber GP, Autorino R, et al. Robotic partial nephrectomy versus laparoscopic cryoablation for the small renal mass. Eur Urol. 2012;61(5):899-904. [pmid: 22264680].
115 Haramis G, Graversen JA, Mues AC, et al. Retrospective comparison of laparoscopic partial nephrectomy versus laparoscopic renal cryoablation for small (<3.5 cm) cortical renal masses. J Laparoendosc Adv Surg Tech A. 2012;22(2):152-7. [pmid: 22145574].
116 Kiriluk KJ, Shikanov SA, Steinberg GD, Shalhav AL, Lifshitz DA. Laparoscopic partial nephrectomy versus laparoscopic ablative therapy: a comparison of surgical and functional outcomes in a matched control study. J Endourol. 2011;25(12):1867-72. [pmid: 21902540].
117 Haber GP, Lee MC, Crouzet S, Kamoi K, Gill IS. Tumour in solitary kidney: laparoscopic partial nephrectomy vs laparoscopic cryoablation. BJU Int. 2012;109(1):118-24. [pmid: 21895929].
118 Chang X, Zhang F, Liu T, et al. Radiofrequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: long-term clinical and oncologic outcomes. J Urol. 2014. [pmid: 25106899].
119 Faddegon S, Ju T, Olweny EO, et al. A comparison of long term renal functional outcomes following partial nephrectomy and radiofrequency ablation. Can J Urol. 2013;20(3):6785-9. [pmid: 23783048].
120 Mues AC, Korets R, Graversen JA, et al. Clinical, pathologic, and functional outcomes after nephron-sparing surgery in patients with a solitary kidney: a multicenter experience. J Endourol. 2012;26(10):1361-6. [pmid: 22667344].
121 Stern JM, Svatek R, Park S, et al. Intermediate comparison of partial nephrectomy and radiofrequency ablation for clinical T1a renal tumours. BJU Int. 2007;100(2):287-90. [pmid: 17617136].
122 Thompson RH, Atwell T, Schmit G, et al. Comparison of Partial Nephrectomy and Percutaneous Ablation for cT1 Renal Masses. Eur Urol. 2014. [pmid: 25108580].
123 Turna B, Kaouk JH, Frota R, et al. Minimally invasive nephron sparing management for renal tumors in solitary kidneys. J Urol. 2009;182(5):2150-7. [pmid: 19758655].
124 Whitson JM, Harris CR, Meng MV. Population-based comparative effectiveness of nephron-sparing surgery vs ablation for small renal masses. BJU Int. 2012;110(10):1438-43. discussion 1443. [pmid: 22639860].
125 Olweny EO, Park SK, Tan YK, Best SL, Trimmer C, Cadeddu JA. Radiofrequency ablation versus partial nephrectomy in patients with solitary clinical T1a renal cell carcinoma: comparable oncologic outcomes at a minimum of 5 years of follow-up. Eur Urol. 2012;61(6):1156-61. [pmid: 22257424].
126 Tanagho YS, Bhayani S, Kim EH, Figenshau RS. Renal Cryoablation versus Robot-Assisted Partial Nephrectomy: Washington University Long-Term Experience. J Endourol. 2013.
127 Chang X, Zhang F, Liu T, et al. Radio frequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: Long-term clinical and oncologic outcomes. J Urol. 2015;193(2):430-5. [pmid: 25106899].
128 Klatte T, Mauermann J, Heinz-Peer G, et al. Perioperative, oncologic, and functional outcomes of laparoscopic renal cryoablation and open partial nephrectomy: a matched pair analysis. J Endourol. 2011;25(6):991-7. [pmid: 21568698].
129 Mitchell CR, Atwell TD, Weisbrod AJ, et al. Renal function outcomes in patients treated with partial nephrectomy versus percutaneous ablation for renal tumors in a solitary kidney. J Urol. 2011;186(5):1786-90. [pmid: 21944103].
130 Youn CS, Park JM, Lee JY, et al. Comparison of laparoscopic radiofrequency ablation and open partial nephrectomy in patients with a small renal mass. Korean J Urol. 2013;54(9):603-8. [pmid: 24044094].
131 Patel HD, Kates M, Pierorazio PM, et al. Survival after diagnosis of localized T1a kidney cancer: current population-based practice of surgery and nonsurgical management. Urology. 2014;83(1):126-32. [pmid: 24246317].
132 Patel HD, Kates M, Pierorazio PM, Allaf ME. Balancing cardiovascular (CV) and cancer death among patients with small renal masses: modification by CV risk. BJU Int. 2014. [pmid: 24589376].
133 Sun M, Becker A, Tian Z, et al. Management of localized kidney cancer: calculating cancer-specific mortality and competing risks of death for surgery and nonsurgical management. Eur Urol. 2014;65(1):235-41. [pmid: 23567066].
134 Danzig MR, Chang P, Wagner AA, Pierorazio PM, Allaf ME, McKiernan JM. Active Surveillance is Superior to Radical Nephrectomy and Equivalent to Partial Nephrectomy in Preserving Renal Function Among Patients with Small Renal Masses; Results from the DISSRM Registry. J Urol. 2015. [pmid: 25813449].
135 Takaki H, Soga N, Kanda H, et al. Radiofrequency ablation versus radical nephrectomy: clinical outcomes for stage T1b renal cell carcinoma. Radiology. 2014;270(1):292-9. [pmid: 23925272].
136 Lane BR, Abouassaly R, Gao T, et al. Active treatment of localized renal tumors may not impact overall survival in patients aged 75 years or older. Cancer. 2010;116(13):3119-26. [pmid: 20564627].
137 Choueiri TK, Schutz FA, Hevelone ND, et al. Thermal ablation vs surgery for localized kidney cancer: a Surveillance, Epidemiology, and End Results (SEER) database analysis. Urology. 2011;78(1):93-8. [pmid: 21550636].
138 Lucas SM, Stern JM, Adibi M, Zeltser IS, Cadeddu JA, Raj GV. Renal function outcomes in patients treated for renal masses smaller than 4 cm by ablative and extirpative techniques. J Urol. 2008;179(1):75-9. discussion 79-80. [pmid: 17997440].
139 Permpongkosol S, Link RE, Su LM, et al. Complications of 2,775 urological laparoscopic procedures: 1993 to 2005. J Urol. 2007;177(2):580-5. [pmid: 17222637].
140 Takaki H, Yamakado K, Soga N, et al. Midterm results of radiofrequency ablation versus nephrectomy for T1a renal cell carcinoma. Jpn J Radiol. 2010;28(6):460-8. [pmid: 20661697].
141 Cooper CJ, Teleb M, Dwivedi A, et al. Comparative Outcome of Computed Tomography-guided Percutaneous Radiofrequency Ablation, Partial Nephrectomy or Radical Nephrectomy in the Treatment of Stage T1 Renal Cell Carcinoma. Rare Tumors. 2015;7(1):5583. [pmid: 25918603].
142 Deklaj T, Lifshitz DA, Shikanov SA, et al. Localized T1a renal lesions in the elderly: outcomes of laparoscopic renal surgery. J Endourol. 2010;24(3):397-401. [pmid: 20334557].
143 Foyil KV, Ames CD, Ferguson GG, et al. Longterm changes in creatinine clearance after laparoscopic renal surgery. J Am Coll Surg. 2008;206(3):511-5. [pmid: 18308223].
144 Kowalczyk KJ, Choueiri TK, Hevelone ND, et al. Comparative effectiveness, costs and trends in treatment of small renal masses from 2005 to 2007. BJU Int. 2013;112(4):E273-80. [pmid: 23452093].
145 Abouassaly R, Lane BR, Novick AC. Active surveillance of renal masses in elderly patients. J Urol. 2008;180(2):505-8. discussion 508-9. [pmid: 18550113].
146 Crispen PL, Wong YN, Greenberg RE, Chen DY, Uzzo RG. Predicting growth of solid renal masses under active surveillance. Urol Oncol. 2008;26(5):555-9. [pmid: 18774473].
147 Crispen PL, Viterbo R, Boorjian SA, Greenberg RE, Chen DY, Uzzo RG. Natural history, growth kinetics, and outcomes of untreated clinically localized renal tumors under active surveillance. Cancer. 2009;115(13):2844-52. [pmid: 19402168].
148 Jewett MA, Mattar K, Basiuk J, et al. Active surveillance of small renal masses: progression patterns of early stage kidney cancer. Eur Urol. 2011;60(1):39-44. [pmid: 21477920].
149 Kunkle DA, Crispen PL, Chen DY, Greenberg RE, Uzzo RG. Enhancing renal masses with zero net growth during active surveillance. J Urol. 2007;177(3):849-53. discussion 853-4. [pmid: 17296355].
150 Rosales JC, Haramis G, Moreno J, et al. Active surveillance for renal cortical neoplasms. J Urol. 2010;183(5):1698-702. [pmid: 20299038].
151 Parker PA, Swartz R, Fellman B, et al. Comprehensive assessment of quality of life and psychosocial adjustment in patients with renal tumors undergoing open, laparoscopic and nephron sparing surgery. J Urol. 2012;187(3):822-6. [pmid: 22245327].
152 Sun M, Bianchi M, Trinh QD, et al. Comparison of partial vs radical nephrectomy with regard to other-cause mortality in T1 renal cell carcinoma among patients aged >/=75 years with multiple comorbidities. BJU Int. 2013;111(1):67-73. [pmid: 22612472].
153 Yokoyama M, Fujii Y, Iimura Y, et al. Longitudinal change in renal function after radical nephrectomy in Japanese patients with renal cortical tumors. J Urol. 2011;185(6):2066-71. [pmid: 21496840].

## [Risk of Bias Assessments]

Table D14 Risk of bias assessment for studies addressing KQ1

Table D15 Risk of bias assessment for studies addressing KQ2

Table D16 Risk of bias assessment for studies addressing KQ3-oncology efficacy

Table D17 Risk of bias assessment for studies addressing KQ3-overall survival

Table D18 Risk of bias assessment for studies addressing KQ3-renal function

Table D19 Risk of bias assessment for studies addressing KQ3-perioperative

Table D20 Risk of bias assessment for studies addressing KQ3-harms

### Reference List

1 Akdogan B, Gudeloglu A, Inci K, Gunay LM, Koni A, Ozen H. Prevalence and predictors of benign lesions in renal masses smaller than 7 cm presumed to be renal cell carcinoma. Clin Genitourin Cancer. 2012;10(2):121-5. [pmid: 22401753].
2 Antonelli A, Furlan M, Sandri M, et al. The R.e.N.a.L. Nephrometric nomogram cannot accurately predict malignancy or aggressiveness of small renal masses amenable to partial nephrectomy. Clin Genitourin Cancer. 2014;12(5):366-72. [pmid: 24637340].
3 Bazzi WM, Dejbakhsh SZ, Bernstein M, Russo P. The association of baseline health and gender with small renal mass pathology. Can J Urol. 2014;21(3):7271-6. [pmid: 24978356].
4 Choi SK, Jeon SH, Chang SG. Characterization of small renal masses less than 4 cm with quadriphasic multidetector helical computed tomography: differentiation of benign and malignant lesions. Korean J Urol. 2012;53(3):159-64. [pmid: 22468210].
5 Chung MS, Choi HJ, Kim MH, Cho KS. Comparison of T2-weighted MRI with and without fat suppression for differentiating renal angiomyolipomas without visible fat from other renal tumors. AJR Am J Roentgenol. 2014;202(4):765-71. [pmid: 24660704].
6 Fujita T, Iwamura M, Wakatabe Y, et al. Predictors of benign histology in clinical T1a renal cell carcinoma tumors undergoing partial nephrectomy. Int J Urol. 2014;21(1):100-2. [pmid: 23635425].
7 Jeon HG, Lee SR, Kim KH, et al. Benign lesions after partial nephrectomy for presumed renal cell carcinoma in masses 4 cm or less: prevalence and predictors in Korean patients. Urology. 2010;76(3):574-9. [pmid: 20303148].
8 Kava BR, Eldefrawy A, Ayyathurai R, et al. Impact of body mass index and tumor location on the incidence of benign histology at the time of nephron-sparing surgery. Int Urol Nephrol. 2012;44(5):1319-24. [pmid: 22678516].
9 Keehn A, Srivastava A, Maiman R, et al. The Relationship Between Visceral Obesity and the Clinicopathologic Features of Patients with Small Renal Masses. J Endourol. 2014. [pmid: 25203393].
10 Koo KC, Yoo H, Shin TY, et al. External validation of the RENAL nephrometry score nomogram for predicting high-grade renal cell carcinoma in solid, enhancing, and small renal masses. World J Urol. 2014;32(1):249-55. [pmid: 24013182].
11 Lane BR, Babineau D, Kattan MW, et al. A preoperative prognostic nomogram for solid enhancing renal tumors 7 cm or less amenable to partial nephrectomy. J Urol. 2007;178(2):429-34. [pmid: 17561141].
12 Mullins JK, Kaouk JH, Bhayani S, et al. Tumor complexity predicts malignant disease for small renal masses. J Urol. 2012;188(6):2072-6. [pmid: 23083863].
13 Murphy AM, Buck AM, Benson MC, McKiernan JM. Increasing detection rate of benign renal tumors: evaluation of factors predicting for benign tumor histologic features during past two decades. Urology. 2009;73(6):1293-7. [pmid: 19371933].
14 Nishikawa M, Miyake H, Kitajima K, Takahashi S, Sugimura K, Fujisawa M. Preoperative differentiation between benign and malignant renal masses smaller than 4 cm treated with partial nephrectomy. Int J Clin Oncol. 2014. [pmid: 24526391].
15 Park SY, Jeon SS, Lee SY, et al. Incidence and predictive factors of benign renal lesions in Korean patients with preoperative imaging diagnoses of renal cell carcinoma. J Korean Med Sci. 2011;26(3):360-4. [pmid: 21394303].
16 Rosenkrantz AB, Wehrli NE, Melamed J, Taneja SS, Shaikh MB. Renal masses measuring under 2 cm: Pathologic outcomes and associations with MRI features. Eur J Radiol. 2014;83(8):1311-6. [pmid: 24882784].
17 Soga N, Nishikawa K, Takaki H, et al. Low incidence of benign lesions in resected suspicious renal masses greater than 2 cm: Single-center experience from Japan. Int J Urol. 2012;19(8):729-34. [pmid: 22515572].
18 Xiong YH, Zhang ZL, Li YH, et al. Benign pathological findings in 303 Chinese patients undergoing surgery for presumed localized renal cell carcinoma. Int J Urol. 2010;17(6):517-21. [pmid: 20370841].
19 Shin TY, Kim J, Koo KC, et al. Assessing the anatomical characteristics of renal masses has a limited effect on the prediction of pathological outcomes in solid, enhancing, small renal masses: Results using the PADUA classification system. BJU Int. 2014;113(5):754-61. [pmid: 24053790].
20 Ball MW, Gorin MA, Bhayani SB, et al. Preoperative predictors of malignancy and unfavorable pathology for clinical T1a tumors treated with partial nephrectomy: A multi-institutional analysis. Urol Oncol Semin Orig Invest. 2015;33(3):112.e9-112.e14.
21 Campbell SC, Novick AC, Herts B, et al. Prospective evaluation of fine needle aspiration of small, solid renal masses: accuracy and morbidity. Urology. 1997;50(1):25-9. [pmid: 9218014].
22 Chyhrai A, Sanjmyatav J, Gajda M, et al. Multi-colour FISH on preoperative renal tumour biopsies to confirm the diagnosis of uncertain renal masses. World J Urol. 2010;28(3):269-74. [pmid: 20390284].
23 Halverson SJ, Kunju LP, Bhalla R, et al. Accuracy of determining small renal mass management with risk stratified biopsies: confirmation by final pathology. J Urol. 2013;189(2):441-6. [pmid: 23253955].
24 Harisinghani MG, Maher MM, Gervais DA, et al. Incidence of malignancy in complex cystic renal masses (Bosniak category III): should imaging-guided biopsy precede surgery?. AJR Am J Roentgenol. 2003;180(3):755-8. [pmid: 12591691].
25 Leveridge MJ, Finelli A, Kachura JR, et al. Outcomes of small renal mass needle core biopsy, nondiagnostic percutaneous biopsy, and the role of repeat biopsy. Eur Urol. 2011;60(3):578-84. [pmid: 21704449].
26 Londono DC, Wuerstle MC, Thomas AA, et al. Accuracy and implications of percutaneous renal biopsy in the management of renal masses. Perm J. 2013;17(3):4-7. [pmid: 24355883].
27 Menogue SR, O'Brien BA, Brown AL, Cohen RJ. Percutaneous core biopsy of small renal mass lesions: a diagnostic tool to better stratify patients for surgical intervention. BJU Int. 2013;111(4 Pt B):E146-51. [pmid: 22805186].
28 Millet I, Curros F, Serre I, Taourel P, Thuret R. Can renal biopsy accurately predict histological subtype and Fuhrman grade of renal cell carcinoma?. J Urol. 2012;188(5):1690-4. [pmid: 22998910].
29 Neuzillet Y, Lechevallier E, Andre M, Daniel L, Coulange C. Accuracy and clinical role of fine needle percutaneous biopsy with computerized tomography guidance of small (less than 4.0 cm) renal masses. J Urol. 2004;171(5):1802-5. [pmid: 15076280].
30 Park SY, Park BK, Kim CK, Kwon GY. Ultrasound-guided core biopsy of small renal masses: diagnostic rate and limitations. J Vasc Interv Radiol. 2013;24(1):90-6. [pmid: 23206333].
31 Salem S, Ponsky LE, Abouassaly R, et al. Image-guided biopsy of small renal masses in the era of ablative therapies. Int J Urol. 2013;20(6):580-4. [pmid: 23190309].
32 Shannon BA, Cohen RJ, de Bruto H, Davies RJ. The Value of Preoperative Needle Core Biopsy for Diagnosing Benign Lesions Among Small, Incidentally Detected Renal Masses. J Urol. 2008;180(4):1257-61. [pmid: 18707712].
33 Sofikerim M, Tatlisen A, Canoz O, Tokat F, Demirtas A, Mavili E. What is the role of percutaneous needle core biopsy in diagnosis of renal masses?. Urology. 2010;76(3):614-8. [pmid: 20110106].
34 Vasudevan A, Davies RJ, Shannon BA, Cohen RJ. Incidental renal tumours: the frequency of benign lesions and the role of preoperative core biopsy. BJU Int. 2006;97(5):946-9. [pmid: 16643475].
35 Volpe A, Mattar K, Finelli A, et al. Contemporary results of percutaneous biopsy of 100 small renal masses: a single center experience. J Urol. 2008;180(6):2333-7. [pmid: 18930274].
36 Wang R, Wolf JS Jr, Wood DP Jr, Higgins EJ, Hafez KS. Accuracy of percutaneous core biopsy in management of small renal masses. Urology. 2009;73(3):586-90. discussion 590-1. [pmid: 19118884].
37 Reichelt O, Gajda M, Chyhrai A, Wunderlich H, Junker K, Schubert J. Ultrasound-guided biopsy of homogenous solid renal masses. Eur Urol. 2007;52(5):1421-6. [pmid: 17306920].
38 Schmidbauer J, Remzi M, Memarsadeghi M, et al. Diagnostic accuracy of computed tomography-guided percutaneous biopsy of renal masses. Eur Urol. 2008;53(5):1003-11. [pmid: 18061339].
39 Richard PO, Jewett MA, Bhatt JR, et al. Renal Tumor Biopsy for Small Renal Masses: A Single-center 13-year Experience. Eur Urol. 2015. [pmid: 25900781].
40 Prince J, Bultman E, Hinshaw L, et al. Patient and Tumor Characteristics can Predict Nondiagnostic Renal Mass Biopsy Findings. J Urol. 2014. [pmid: 25498574].
41 Antonelli A, Ficarra V, Bertini R, et al. Elective partial nephrectomy is equivalent to radical nephrectomy in patients with clinical T1 renal cell carcinoma: results of a retrospective, comparative, multi-institutional study. BJU Int. 2012;109(7):1013-8. [pmid: 21883829].
42 Badalato GM, Kates M, Wisnivesky JP, Choudhury AR, McKiernan JM. Survival after partial and radical nephrectomy for the treatment of stage T1bN0M0 renal cell carcinoma (RCC) in the USA: a propensity scoring approach. BJU Int. 2012;109(10):1457-62. [pmid: 21933334].
43 Barbalias GA, Liatsikos EN, Tsintavis A, Nikiforidis G. Adenocarcinoma of the kidney: nephron-sparing surgical approach vs. radical nephrectomy. J Surg Oncol. 1999;72(3):156-61. [pmid: 10562362].
44 Bedke J, Pritsch M, Buse S, et al. Prognostic stratification of localized renal cell carcinoma by tumor size. J Urol. 2008;180(1):62-7. [pmid: 18485376].
45 Bensalah K, Zeltser I, Tuncel A, Cadeddu J, Lotan Y. Evaluation of costs and morbidity associated with laparoscopic radiofrequency ablation and laparoscopic partial nephrectomy for treating small renal tumours. BJU Int. 2008;101(4):467-71. [pmid: 17922853].
46 Chang X, Zhang F, Liu T, et al. Radiofrequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: long-term clinical and oncologic outcomes. J Urol. 2014. [pmid: 25106899].
47 Choueiri TK, Schutz FA, Hevelone ND, et al. Thermal ablation vs surgery for localized kidney cancer: a Surveillance, Epidemiology, and End Results (SEER) database analysis. Urology. 2011;78(1):93-8. [pmid: 21550636].
48 Chung JS, Son NH, Lee SE, et al. Overall survival and renal function after partial and radical nephrectomy among older patients with localised renal cell carcinoma: A propensity-matched multicentre study. Eur J Cancer. 2015;51(4):489-97. [pmid: 25576517].
49 Crepel M, Jeldres C, Sun M, et al. A population-based comparison of cancer-control rates between radical and partial nephrectomy for T1A renal cell carcinoma. Urology. 2010;76(4):883-8. [pmid: 20932408].
50 Crepel M, Jeldres C, Perrotte P, et al. Nephron-sparing surgery is equally effective to radical nephrectomy for T1BN0M0 renal cell carcinoma: a population-based assessment. Urology. 2010;75(2):271-5. [pmid: 19962740].
51 Daugherty M, Bratslavsky G. Compared with radical nephrectomy, nephron-sparing surgery offers a long-term survival advantage in patients between the ages of 20 and 44 years with renal cell carcinomas (</=4 cm): an analysis of the SEER database. Urol Oncol. 2014;32(5):549-54. [pmid: 24495447].
52 Deklaj T, Lifshitz DA, Shikanov SA, Katz MH, Zorn KC, Shalhav AL. Laparoscopic radical versus laparoscopic partial nephrectomy for clinical T1bN0M0 renal tumors: comparison of perioperative, pathological, and functional outcomes. J Endourol. 2010;24(10):1603-7. [pmid: 20932215].
53 Desai MM, Aron M, Gill IS. Laparoscopic partial nephrectomy versus laparoscopic cryoablation for the small renal tumor. Urology. 2005;66(5 Suppl):23-8. [pmid: 16194703].
54 Emara AM, Kommu SS, Hindley RG, Barber NJ. Robot-assisted partial nephrectomy vs laparoscopic cryoablation for the small renal mass: redefining the minimally invasive ‘gold standard’. BJU Int. 2014;113(1):92-9. [pmid: 24053473].
55 Gratzke C, Seitz M, Bayrle F, et al. Quality of life and perioperative outcomes after retroperitoneoscopic radical nephrectomy (RN), open RN and nephron-sparing surgery in patients with renal cell carcinoma. BJU Int. 2009;104(4):470-5. [pmid: 19239445].
56 Guillotreau J, Haber GP, Autorino R, et al. Robotic partial nephrectomy versus laparoscopic cryoablation for the small renal mass. Eur Urol. 2012;61(5):899-904. [pmid: 22264680].
57 Haramis G, Graversen JA, Mues AC, et al. Retrospective comparison of laparoscopic partial nephrectomy versus laparoscopic renal cryoablation for small (<3.5 cm) cortical renal masses. J Laparoendosc Adv Surg Tech A. 2012;22(2):152-7. [pmid: 22145574].
58 Thompson RH, Siddiqui S, Lohse CM, Leibovich BC, Russo P, Blute ML. Partial versus radical nephrectomy for 4 to 7 cm renal cortical tumors. J Urol. 2009;182(6):2601-6. [pmid: 19836797].
59 Huang WC, Elkin EB, Levey AS, Jang TL, Russo P. Partial nephrectomy versus radical nephrectomy in patients with small renal tumors--is there a difference in mortality and cardiovascular outcomes?. J Urol. 2009;181(1):55-61. discussion 61-2. [pmid: 19012918].
60 Iizuka J, Kondo T, Hashimoto Y, et al. Similar functional outcomes after partial nephrectomy for clinical T1b and T1a renal cell carcinoma. Int J Urol. 2012;19(11):980-6. [pmid: 22735049].
61 Indudhara R, Bueschen AJ, Urban DA, Burns JR, Lloyd LK. Nephron-sparing surgery compared with radical nephrectomy for renal tumors: current indications and results. South Med J. 1997;90(10):982-5. [pmid: 9347807].
62 Janetschek G, Jeschke K, Peschel R, Strohmeyer D, Henning K, Bartsch G. Laparoscopic surgery for stage T1 renal cell carcinoma: radical nephrectomy and wedge resection. Eur Urol. 2000;38(2):131-8. [pmid: 10895002].
63 Kim FJ, Rha KH, Hernandez F, Jarrett TW, Pinto PA, Kavoussi LR. Laparoscopic radical versus partial nephrectomy: assessment of complications. J Urol. 2003;170(2 Pt 1):408-11. [pmid: 12853787].
64 Klatte T, Mauermann J, Heinz-Peer G, et al. Perioperative, oncologic, and functional outcomes of laparoscopic renal cryoablation and open partial nephrectomy: a matched pair analysis. J Endourol. 2011;25(6):991-7. [pmid: 21568698].
65 Kopp RP, Mehrazin R, Palazzi KL, et al. Survival outcomes after radical and partial nephrectomy for clinical T2 renal tumours categorised by R.E.N.A.L. nephrometry score. BJU Int. 2013. [pmid: 24274650].
66 Kyung YS, You D, Kwon T, et al. The type of nephrectomy has little effect on overall survival or cardiac events in patients of 70 years and older with localized clinical t1 stage renal masses. Korean J Urol. 2014;55(7):446-52. [pmid: 25045442].
67 Lane BR, Fergany AF, Weight CJ, Campbell SC. Renal functional outcomes after partial nephrectomy with extended ischemic intervals are better than after radical nephrectomy. J Urol. 2010;184(4):1286-90. [pmid: 20723936].
68 Lane BR, Abouassaly R, Gao T, et al. Active treatment of localized renal tumors may not impact overall survival in patients aged 75 years or older. Cancer. 2010;116(13):3119-26. [pmid: 20564627].
69 Li JR, Yang CR, Cheng CL, et al. Partial nephrectomy in the treatment of localized renal cell carcinoma: experience of Taichung Veterans General Hospital. J Chin Med Assoc. 2007;70(7):281-5. [pmid: 17631464].
70 Li Q, Guan H, Qin J, Jiang T. Mini-Margin nephron sparing surgery for renal cell carcinoma 4 cm or less. Adv Urol. 2010. [pmid: 20862196].
71 Lucas SM, Stern JM, Adibi M, Zeltser IS, Cadeddu JA, Raj GV. Renal function outcomes in patients treated for renal masses smaller than 4 cm by ablative and extirpative techniques. J Urol. 2008;179(1):75-9. discussion 79-80. [pmid: 17997440].
72 Mariusdottir E, Jonsson E, Marteinsson VT, Sigurdsson MI, Gudbjartsson T. Kidney function following partial or radical nephrectomy for renal cell carcinoma: a population-based study. Scand J Urol. 2013;47(6):476-82. [pmid: 23597159].
73 McKiernan J, Simmons R, Katz J, Russo P. Natural history of chronic renal insufficiency after partial and radical nephrectomy. Urology. 2002;59(6):816-20. [pmid: 12031359].
74 Medina-Polo J, Romero-Otero J, Rodriguez-Antolin A, et al. Can partial nephrectomy preserve renal function and modify survival in comparison with radical nephrectomy?. Scand J Urol Nephrol. 2011;45(2):143-50. [pmid: 21247272].
75 Meskawi M, Becker A, Bianchi M, et al. Partial and radical nephrectomy provide comparable long-term cancer control for T1b renal cell carcinoma. Int J Urol. 2014;21(2):122-8. [pmid: 23819700].
76 Milonas D, Skulcius G, Baltrimavicius R, et al. Comparison of long-term results after nephron-sparing surgery and radical nephrectomy in treating 4- to 7-cm renal cell carcinoma. Medicina (Kaunas). 2013;49(5):223-8. [pmid: 24247918].
77 Minervini A, Serni S, Tuccio A, et al. Simple enucleation versus radical nephrectomy in the treatment of pT1a and pT1b renal cell carcinoma. Ann Surg Oncol. 2012;19(2):694-700. [pmid: 21861225].
78 Mitchell RE, Gilbert SM, Murphy AM, Olsson CA, Benson MC, McKiernan JM. Partial nephrectomy and radical nephrectomy offer similar cancer outcomes in renal cortical tumors 4 cm or larger. Urology. 2006;67(2):260-4. [pmid: 16461075].
79 Mues AC, Korets R, Graversen JA, et al. Clinical, pathologic, and functional outcomes after nephron-sparing surgery in patients with a solitary kidney: a multicenter experience. J Endourol. 2012;26(10):1361-6. [pmid: 22667344].
80 Olweny EO, Park SK, Tan YK, Best SL, Trimmer C, Cadeddu JA. Radiofrequency ablation versus partial nephrectomy in patients with solitary clinical T1a renal cell carcinoma: comparable oncologic outcomes at a minimum of 5 years of follow-up. Eur Urol. 2012;61(6):1156-61. [pmid: 22257424].
81 Haber GP, Lee MC, Crouzet S, Kamoi K, Gill IS. Tumour in solitary kidney: laparoscopic partial nephrectomy vs laparoscopic cryoablation. BJU Int. 2012;109(1):118-24. [pmid: 21895929].
82 Patard JJ, Shvarts O, Lam JS, et al. Safety and efficacy of partial nephrectomy for all T1 tumors based on an international multicenter experience. J Urol. 2004;171(6 Pt 1):2181-5. quiz 2435. [pmid: 15126781].
83 Patel HD, Kates M, Pierorazio PM, et al. Survival after diagnosis of localized T1a kidney cancer: current population-based practice of surgery and nonsurgical management. Urology. 2014;83(1):126-32. [pmid: 24246317].
84 Patel HD, Kates M, Pierorazio PM, Allaf ME. Balancing cardiovascular (CV) and cancer death among patients with small renal masses: modification by CV risk. BJU Int. 2014. [pmid: 24589376].
85 Roos FC, Brenner W, Jager W, et al. Perioperative morbidity and renal function in young and elderly patients undergoing elective nephron-sparing surgery or radical nephrectomy for renal tumours larger than 4 cm. BJU Int. 2011;107(4):554-61. [pmid: 20707798].
86 Roos FC, Brenner W, Thomas C, et al. Functional analysis of elective nephron-sparing surgery vs radical nephrectomy for renal tumors larger than 4 cm. Urology. 2012;79(3):607-13. [pmid: 22386408].
87 Shinohara N, Harabayashi T, Sato S, Hioka T, Tsuchiya K, Koyanagi T. Impact of nephron-sparing surgery on quality of life in patients with localized renal cell carcinoma. Eur Urol. 2001;39(1):114-9. [pmid: 11173949].
88 Stern JM, Svatek R, Park S, et al. Intermediate comparison of partial nephrectomy and radiofrequency ablation for clinical T1a renal tumours. BJU Int. 2007;100(2):287-90. [pmid: 17617136].
89 Sun M, Becker A, Tian Z, et al. Management of localized kidney cancer: calculating cancer-specific mortality and competing risks of death for surgery and nonsurgical management. Eur Urol. 2014;65(1):235-41. [pmid: 23567066].
90 Takaki H, Soga N, Kanda H, et al. Radiofrequency ablation versus radical nephrectomy: clinical outcomes for stage T1b renal cell carcinoma. Radiology. 2014;270(1):292-9. [pmid: 23925272].
91 Tan HJ, Norton EC, Ye Z, Hafez KS, Gore JL, Miller DC. Long-term survival following partial vs radical nephrectomy among older patients with early-stage kidney cancer. JAMA. 2012;307(15):1629-35. [pmid: 22511691].
92 Tanagho YS, Bhayani S, Kim EH, Figenshau RS. Renal Cryoablation versus Robot-Assisted Partial Nephrectomy: Washington University Long-Term Experience. J Endourol. 2013.
93 Thompson RH, Atwell T, Schmit G, et al. Comparison of Partial Nephrectomy and Percutaneous Ablation for cT1 Renal Masses. Eur Urol. 2014. [pmid: 25108580].
94 Turna B, Kaouk JH, Frota R, et al. Minimally invasive nephron sparing management for renal tumors in solitary kidneys. J Urol. 2009;182(5):2150-7. [pmid: 19758655].
95 Uchida K, Takahashi A, Masumori N, Yanase M, Itoh N, Tsukamoto T. Partial nephrectomy for small localized renal cell carcinoma. Hinyokika Kiyo. 2004;50(6):389-95. [pmid: 15293735].
96 Uzzo RG, Wei JT, Hafez K, Kay R, Novick AC. Comparison of direct hospital costs and length of stay for radical nephrectomy versus nephron-sparing surgery in the management of localized renal cell carcinoma. Urology. 1999;54(6):994-8. [pmid: 10604696].
97 Weight CJ, Larson BT, Fergany AF, et al. Nephrectomy induced chronic renal insufficiency is associated with increased risk of cardiovascular death and death from any cause in patients with localized cT1b renal masses. J Urol. 2010;183(4):1317-23. [pmid: 20171688].
98 Weight CJ, Lythgoe C, Unnikrishnan R, Lane BR, Campbell SC, Fergany AF. Partial nephrectomy does not compromise survival in patients with pathologic upstaging to pT2/pT3 or high-grade renal tumors compared with radical nephrectomy. Urology. 2011;77(5):1142-6. [pmid: 21420154].
99 Whitson JM, Harris CR, Meng MV. Population-based comparative effectiveness of nephron-sparing surgery vs ablation for small renal masses. BJU Int. 2012;110(10):1438-43. discussion 1443. [pmid: 22639860].
100 Youn CS, Park JM, Lee JY, et al. Comparison of laparoscopic radiofrequency ablation and open partial nephrectomy in patients with a small renal mass. Korean J Urol. 2013;54(9):603-8. [pmid: 24044094].
101 Kim CS, Bae EH, Ma SK, Kweon SS, Kim SW. Impact of partial nephrectomy on kidney function in patients with renal cell carcinoma. BMC Nephrol. 2014;15:181. [pmid: 25410757].
102 Kates M, Badalato GM, Pitman M, McKiernan JM. Increased risk of overall and cardiovascular mortality after radical nephrectomy for renal cell carcinoma 2 cm or less. J Urol. 2011;186(4):1247-53. [pmid: 21849201].
103 Kim JM, Song PH, Kim HT, Park TC. Comparison of Partial and Radical Nephrectomy for pT1b Renal Cell Carcinoma. Korean J Urol. 2010;51(9):596-600. [pmid: 20856643].
104 Smaldone MC, Egleston B, Uzzo RG, Kutikov A. Does partial nephrectomy result in a durable overall survival benefit in the Medicare population?. J Urol. 2012;188(6):2089-94. [pmid: 23083877].
105 Takagi T, Kondo T, Iizuka J, et al. Postoperative renal function after partial nephrectomy for renal cell carcinoma in patients with pre-existing chronic kidney disease: a comparison with radical nephrectomy. Int J Urol. 2011;18(6):472-6. [pmid: 21481013].
106 Takaki H, Yamakado K, Soga N, et al. Midterm results of radiofrequency ablation versus nephrectomy for T1a renal cell carcinoma. Jpn J Radiol. 2010;28(6):460-8. [pmid: 20661697].
107 Thompson RH, Boorjian SA, Lohse CM, et al. Radical nephrectomy for pT1a renal masses may be associated with decreased overall survival compared with partial nephrectomy. J Urol. 2008;179(2):468-71. discussion 472-3. [pmid: 18076931].
108 Weight CJ, Larson BT, Gao T, et al. Elective partial nephrectomy in patients with clinical T1b renal tumors is associated with improved overall survival. Urology. 2010;76(3):631-7. [pmid: 20451967].
109 Zini L, Perrotte P, Capitanio U, et al. Radical versus partial nephrectomy: effect on overall and noncancer mortality. Cancer. 2009;115(7):1465-71. [pmid: 19195042].
110 Antoniewicz AA, Poletajew S, Borowka A, Pasierski T, Rostek M, Pikto-Pietkiewicz W. Renal function and adaptive changes in patients after radical or partial nephrectomy. Int Urol Nephrol. 2012;44(3):745-51. [pmid: 21947980].
111 Brewer K, O'Malley RL, Hayn M, et al. Perioperative and renal function outcomes of minimally invasive partial nephrectomy for T1b and T2a kidney tumors. J Endourol. 2012;26(3):244-8. [pmid: 22192099].
112 Chang X, Zhang F, Liu T, et al. Radio frequency ablation versus partial nephrectomy for clinical T1b renal cell carcinoma: Long-term clinical and oncologic outcomes. J Urol. 2015;193(2):430-5. [pmid: 25106899].
113 Cooper CJ, Teleb M, Dwivedi A, et al. Comparative Outcome of Computed Tomography-guided Percutaneous Radiofrequency Ablation, Partial Nephrectomy or Radical Nephrectomy in the Treatment of Stage T1 Renal Cell Carcinoma. Rare Tumors. 2015;7(1):5583. [pmid: 25918603].
114 Danzig MR, Chang P, Wagner AA, Pierorazio PM, Allaf ME, McKiernan JM. Active Surveillance is Superior to Radical Nephrectomy and Equivalent to Partial Nephrectomy in Preserving Renal Function Among Patients with Small Renal Masses; Results from the DISSRM Registry. J Urol. 2015. [pmid: 25813449].
115 Dash A, Vickers AJ, Schachter LR, Bach AM, Snyder ME, Russo P. Comparison of outcomes in elective partial vs radical nephrectomy for clear cell renal cell carcinoma of 4-7 cm. BJU Int. 2006;97(5):939-45. [pmid: 16643474].
116 Deklaj T, Lifshitz DA, Shikanov SA, et al. Localized T1a renal lesions in the elderly: outcomes of laparoscopic renal surgery. J Endourol. 2010;24(3):397-401. [pmid: 20334557].
117 Faddegon S, Ju T, Olweny EO, et al. A comparison of long term renal functional outcomes following partial nephrectomy and radiofrequency ablation. Can J Urol. 2013;20(3):6785-9. [pmid: 23783048].
118 Foyil KV, Ames CD, Ferguson GG, et al. Longterm changes in creatinine clearance after laparoscopic renal surgery. J Am Coll Surg. 2008;206(3):511-5. [pmid: 18308223].
119 Huang WC, Levey AS, Serio AM, et al. Chronic kidney disease after nephrectomy in patients with renal cortical tumours: a retrospective cohort study. Lancet Oncol. 2006;7(9):735-40. [pmid: 16945768].
120 Jeon HG, Jeong IG, Lee JW, Lee SE, Lee E. Prognostic factors for chronic kidney disease after curative surgery in patients with small renal tumors. Urology. 2009;74(5):1064-8. [pmid: 19758688].
121 Kiriluk KJ, Shikanov SA, Steinberg GD, Shalhav AL, Lifshitz DA. Laparoscopic partial nephrectomy versus laparoscopic ablative therapy: a comparison of surgical and functional outcomes in a matched control study. J Endourol. 2011;25(12):1867-72. [pmid: 21902540].
122 Kowalczyk KJ, Choueiri TK, Hevelone ND, et al. Comparative effectiveness, costs and trends in treatment of small renal masses from 2005 to 2007. BJU Int. 2013;112(4):E273-80. [pmid: 23452093].
123 Matin SF, Gill IS, Worley S, Novick AC. Outcome of laparoscopic radical and open partial nephrectomy for the sporadic 4 cm. or less renal tumor with a normal contralateral kidney. J Urol. 2002;168(4 Pt 1):1356-9. discussion 1359-60. [pmid: 12352392].
124 Mitchell CR, Atwell TD, Weisbrod AJ, et al. Renal function outcomes in patients treated with partial nephrectomy versus percutaneous ablation for renal tumors in a solitary kidney. J Urol. 2011;186(5):1786-90. [pmid: 21944103].
125 Miyamoto K, Inoue S, Kajiwara M, Teishima J, Matsubara A. Comparison of renal function after partial nephrectomy and radical nephrectomy for renal cell carcinoma. Urol Int. 2012;89(2):227-32. [pmid: 22846207].
126 Snow DC, Bhayani SB. Rapid communication: chronic renal insufficiency after laparoscopic partial nephrectomy and radical nephrectomy for pathologic t1a lesions. J Endourol. 2008;22(2):337-41. [pmid: 18257672].
127 Sun M, Bianchi M, Hansen J, et al. Chronic kidney disease after nephrectomy in patients with small renal masses: a retrospective observational analysis. Eur Urol. 2012;62(4):696-703. [pmid: 22483407].
128 Woldu SL, Weinberg AC, Korets R, et al. Who Really Benefits From Nephron-sparing Surgery?. Urology. 2014;84(4):860-8. [pmid: 25260447].
129 Yasuda Y, Yuasa T, Yamamoto S, et al. Evaluation of the RENAL nephrometry scoring system in adopting nephron-sparing surgery for cT1 renal cancer. Urol Int. 2013;90(2):179-83. [pmid: 23146865].
130 Zorn KC, Gong EM, Orvieto MA, et al. Comparison of laparoscopic radical and partial nephrectomy: effects on long-term serum creatinine. Urology. 2007;69(6):1035-40. [pmid: 17572181].
131 Permpongkosol S, Link RE, Su LM, et al. Complications of 2,775 urological laparoscopic procedures: 1993 to 2005. J Urol. 2007;177(2):580-5. [pmid: 17222637].
132 Tomaszewski JJ, Uzzo RG, Kutikov A, et al. Assessing the burden of complications after surgery for clinically localized kidney cancer by age and comorbidity status. Urology. 2014;83(4):843-9. [pmid: 24680455].
133 Xu H, Ding Q, Jiang H-W. Fewer complications after laparoscopic nephrectomy as compared to the open procedure with the modified Clavien classification system - a retrospective analysis from Southern China. World J Surg Oncol. 2014;12(1).
134 Becker A, Ravi P, Roghmann F, et al. Laparoscopic radical nephrectomy vs laparoscopic or open partial nephrectomy for T1 renal cell carcinoma: comparison of complication rates in elderly patients during the initial phase of adoption. Urology. 2014;83(6):1285-91. [pmid: 24862392].
135 Lowrance WT, Yee DS, Savage C, et al. Complications after radical and partial nephrectomy as a function of age. J Urol. 2010;183(5):1725-30. [pmid: 20299040].