# List of Excluded Studies

## Does not evaluate renal masses

Is the follow-up of small renal angiomyolipomas a necessary precaution?. Maclean DF, Sultana R, Radwan R, McKnight L, Khastgir J. Clin Radiol. 2014:822-6. [pmid: 24837696].
Clinical consequences of nephrectomy performed on medical grounds. Glazar W, Dobrowolska-Glazar B, Urbanowicz W, Sulowicz W. Przegl Lek. 2014:1-4. [pmid: 24712260].
Follow-up study of unilateral renal function after nephrectomy assessed by glomerular filtration rate per functional renal volume. Hosokawa Y, Tanaka N, Mibu H, Anai S, Torimoto K, Yoneda T, Hirayama A, Yoshida K, Hayashi Y, Hirao Y, Fujimoto K. World J Surg Oncol. 2014:59. [pmid: 24641796].
Trends of adult primary malignant renal tumors over 6 years. Khalil Ibrahim A. Pak J Med Sci. 2013:1385-8. [pmid: 24550959].
Overall survival and development of stage IV chronic kidney disease in patients undergoing partial and radical nephrectomy for benign renal tumors. Kaushik D, Kim SP, Childs MA, Lohse CM, Costello BA, Cheville JC, Boorjian SA, Leibovich BC, Thompson RH. Eur Urol. 2013:600-6. [pmid: 23280319].
Value of metastin receptor immunohistochemistry in predicting metastasis after radical nephrectomy for pT1 clear cell renal cell carcinoma. Shoji S, Nakano M, Tomonaga T, Kim H, Hanai K, Usui Y, Nagata Y, Miyazawa M, Sato H, Tang XY, Osamura YR, Uchida T, Terachi T, Takeya K. Clin Exp Metastasis. 2013:607-14. [pmid: 23277422].
The effect of gender on nephrectomy perioperative outcomes: a national survey. Sammon J, Trinh QD, Sun M, Bianchi M, Schmitges J, Shariat SF, Ghani KR, Sukumar S, Jeldres C, Briganti A, Perrotte P, Rogers CG, Peabody JO, Montorsi F, Menon M, Karakiewicz PI. Can J Urol. 2012:6337-44. [pmid: 22892256].
Incidence and long-term prognosis of papillary compared to clear cell renal cell carcinoma--a multicentre study. Steffens S, Janssen M, Roos FC, Becker F, Schumacher S, Seidel C, Wegener G, Thuroff JW, Hofmann R, Stockle M, Siemer S, Schrader M, Hartmann A, Kuczyk MA, Junker K, Schrader AJ. Eur J Cancer. 2012:2347-52. [pmid: 22698386].
Volume-outcome relationships in the treatment of renal tumors. Abouassaly R, Finelli A, Tomlinson GA, Urbach DR, Alibhai SM. J Urol. 2012:1984-8. [pmid: 22498222].
Urothelial carcinoma of the upper urinary tract: clinical and pathological criteria and their predictive implications after radical nephroureterectomy. Seitz C, Schramek P. Wien Med Wochenschr. 2011:366-70. [pmid: 21953425].
Iatrogenic splenectomy during left nephrectomy: a single-institution experience of eight years. Tan K, Lewis GR, Chahal R, Browning AJ, Sundaram SK, Weston PM, Harrison SC, Biyani CS. Urol Int. 2011:59-63. [pmid: 21701137].
The effect of hypertension and diabetes on the degree of renal function deterioration after unilateral nephrectomy. Satasivam P, Rao K, Guggenheimer K, Stanton R, Sowter S, Sengupta S, Bolton D. BJU Int. 2011:1508-12. [pmid: 21595821].
Radical renal surgery (laparoscopic and open) in octogenarians. Vasdev N, Hussein HK, Davidson A, Wood H, O'Riordan A, Soomro NA. Surgeon. 2011:135-41. [pmid: 21550518].
Laparoendoscopic single-site surgeries: a single-center experience of 171 consecutive cases. Choi KH, Ham WS, Rha KH, Lee JW, Jeon HG, Arkoncel FR, Yang SC, Han WK. Korean J Urol. 2011:31-8. [pmid: 21344028].
Renal impairment after laparoscopic radical nephrectomy affects hypoglycaemic therapy. Mizuno T, Ito K, Miyagawa Y, Kimura K, Suzuki Y, Mizuno M, Ito Y, Funahashi Y, Hattori R, Gotoh M, Noda Y, Yamada K. J Clin Pharm Ther. 2012:49-52. [pmid: 21332567].
Risk factors for conversion to hand assisted laparoscopy or open surgery during laparoscopic renal surgery. Rowley MW, Wolf JS Jr. J Urol. 2011:940-4. [pmid: 21247602].
Benefit of laparoscopic radical nephrectomy in patients with a high BMI. Hagiwara M, Miyajima A, Matsumoto K, Kikuchi E, Nakagawa K, Oya M. Jpn J Clin Oncol. 2011:400-4. [pmid: 20926414].
Kidney function following nephrectomy: similitude and discrepancies between kidney cancer and living donation. Timsit MO, Nguyen KN, Rouach Y, Elie C, Loupy A, Fournier C, Legendre C, Mejean A. Urol Oncol. 2012:482-6. [pmid: 20864365].
Retroperitoneoscopic nephrectomy with a modified hand-assisted approach. Capolicchio JP, Saemi A, Trotter S, Plante MK. Urology. 2011:607-11. [pmid: 20708224].
Laparoscopic nephrectomy: initial experience with 120 cases. Cheema IA, Manecksha RP, Murphy M, Flynn R. Ir Med J. 2010:49-51. [pmid: 20666056].
A collaborative approach reduces the learning curve and improves outcomes in laparoscopic nephrectomy. Schneider CL, Cobb WS, Carbonell AM, Hill LK, Flanagan WF. Surg Endosc. 2011:182-5. [pmid: 20549243].
Radical nephrectomy and nephroureterectomy in patients over 80 years old. Labanaris AP, Zugor V, Labanaris AP, Elias P, Kuhn R. Int Braz J Urol. 2010:141-8. discussion 149-50. [pmid: 20450498].
Minimum incision endoscopic surgery (MIES) in Japanese urology: results of adrenalectomy, radical nephrectomy and radical prostatectomy. Kihara K, Kobayashi T, Kawakami S, Fujii Y, Kageyama Y, Masuda H. Aktuelle Urol. 2010:S15-9. [pmid: 20094945].
Incidental angiomyolipoma resected during renal surgery for an enhancing renal mass. Berglund RK, Bernstein M, Manion MT, Touijer KA, Russo P. BJU Int. 2009:1650-4. [pmid: 19519761].
Angiomyolipomata: challenges, solutions, and future prospects based on over 100 cases treated. Sooriakumaran P, Gibbs P, Coughlin G, Attard V, Elmslie F, Kingswood C, Taylor J, Corbishley C, Patel U, Anderson C. BJU Int. 2010:101-6. [pmid: 19493268].
Oncological efficacy and safety of nephron-sparing surgery for selected patients with locally advanced renal cell carcinoma. Margulis V, Tamboli P, Jacobsohn KM, Swanson DA, Wood CG. BJU Int. 2007:1235-9. [pmid: 17979923].
Transabdominal radical nephrectomy for renal cell carcinoma: an experience on 155 patients. Chen XF, Zhou FJ, Han H, Qin ZK, Liu ZW, Yu SL, Li YH, Wang H, Hou GL. Ai Zheng. 2007:528-32. [pmid: 17672946].
Obesity as a risk factor for complications during laparoscopic surgery for renal cancer: multivariate analysis. Kurzer E, Leveillee R, Bird V. J Endourol. 2006:794-9. [pmid: 17094757].
Follow-up of renal oncocytoma diagnosed by percutaneous tumor biopsy. Neuzillet Y, Lechevallier E, Andre M, Daniel L, Nahon O, Coulange C. Urology. 2005:1181-5. [pmid: 16360437].
Prior abdominal surgery and radiation do not complicate the retroperitoneoscopic approach to the kidney or adrenal gland. Viterbo R, Greenberg RE, Al-Saleem T, Uzzo RG. J Urol. 2005:446-50. [pmid: 16006862].
A description of radical nephrectomy practice and outcomes in England: 1995-2002. Nuttall M, Cathcart P, van der Meulen J, Gillatt D, McIntosh G, Emberton M. BJU Int. 2005:58-61. [pmid: 15963121].
Laparoscopic nephrectomy: an early experience at Queen Mary Hospital. Cheung MC, Lee FC, Chu SM, Leung YL, Wong BB, Ho KL, Tam PC. Hong Kong Med J. 2005:7-11. [pmid: 15687510].
Learning curve of hand-assisted retroperitoneoscopic nephrectomy in less-experienced laparoscopic surgeons. Kawauchi A, Fujito A, Soh J, Yoneda K, Ukimura O, Mizutani Y, Miki T. Int J Urol. 2005:1-6. [pmid: 15661047].
A renal mass in the setting of a nonrenal malignancy: When is a renal tumor biopsy appropriate?. Sanchez-Ortiz RF, Madsen LT, Bermejo CE, Wen S, Shen Y, Swanson DA, Wood CG. Cancer. 2004:2195-201. [pmid: 15470708].
The British Association of Urological Surgeons Section of Endourology audit of laparoscopic nephrectomy. Keoghane SR, Keeley FX, Timoney AG, Tolley DA, Joyce A, Downey P. BJU Int. 2004:577-81. [pmid: 15329116].
Laparoscopic radical nephrectomy in the elderly. Varkarakis I, Neururer R, Harabayashi T, Bartsch G, Peschel R. BJU Int. 2004:517-20. [pmid: 15329103].
Hand-assisted retroperitoneoscopic radical nephrectomy and nephroureterectomy. Kawauchi A, Fujito A, Soh J, Ukimura O, Mizutani Y, Miki T. J Endourol. 2004:365-9. [pmid: 15253787].
Advanced age is not a prohibitive factor in laparoscopic nephrectomy for renal pathology. Cobb WS, Heniford BT, Matthews BD, Carbonell AM, Kercher KW. Am Surg. 2004:537-42. [pmid: 15212411].
Laparoscopic versus open nephrectomy in 210 consecutive patients: outcomes, cost, and changes in practice patterns. Kercher KW, Heniford BT, Matthews BD, Smith TI, Lincourt AE, Hayes DH, Eskind LB, Irby PB, Teigland CM. Surg Endosc. 2003:1889-95. [pmid: 14569452].
Coloepiploic mobilization during left radical nephrectomy for renal cell carcinoma is indicated to reduce the risk of iatrogenic splenectomy. Mejean A, Chretien Y, Vogt B, Cazin S, Balian C, Thiounn N, Dufour B. Urology. 2002:358-61. [pmid: 11880070].
Sonographically guided renal mass biopsy: indications and efficacy. Johnson PT, Nazarian LN, Feld RI, Needleman L, Lev-Toaff AS, Segal SR, Halpern EJ. J Ultrasound Med. 2001:749-53. quiz 755. [pmid: 11444733].
Carcinological risks and retroperitoneal laparoscopy. Cicco A, Salomon L, Hoznek H, Alame W, Saint F, Bralet MP, Antiphon P, Chopin DK, Abbou CC. Eur Urol. 2000:606-12. [pmid: 11096244].
Transperitoneal laparoscopic nephrectomy. Rozenberg H, Bruyere F, Abdelkader T, Husset A, Hamoura H. Prog Urol. 99:1034-8.
Fine-needle aspiration of renal masses in adults: analysis of results and diagnostic problems in 108 cases. Truong LD, Todd TD, Dhurandhar B, Ramzy I. Diagn Cytopathol. 99:339-49.
Laparoscopic nephrectomy: the experience of the laparoscopy working group of the German Urologic Association. Rassweiler J, Fornara P, Weber M, Janetschek G, Fahlenkamp D, Henkel T, Beer M, Stackl W, Boeckmann W, Recker F, Lampel A, Fischer C, Humke U, Miller K. J Urol. 98:18-21.
Splenectomy--a complication of left-sided nephrectomy. Mincik I, Petricko L. Rozhl Chir. 98:69-72.
Incisional hernia after laparoscopic nephrectomy with intact specimen removal: caveat emptor. Elashry OM, Giusti G, Nadler RB, McDougall EM, Clayman RV. J Urol. 97:363-9.
Utility of renal mass biopsy in a UK tertiary referral centre. Walton TJ, Amery C, Moore D, Mayer NJ, Rajesh A, Kockelbergh RC. Br J Med Surg Urol. 2012:216-223.
Laparoendoscopic single-site surgery in urology: Worldwide multi-institutional analysis of 1076 cases. Kaouk JH, Autorino R, Kim FJ, Han DH, Lee SW, Yinghao S, Cadeddu JA, Derweesh IH, Richstone L, Cindolo L, Branco A, Greco F, Allaf M, Sotelo R, Liatsikos E, Stolzenburg J-U, Rane A, White WM, Han WK, Haber G-P, White MA, Molina WR, Jeong BC, Lee JY, Linhui W, Best S, Stroup SP, Rais-Bahrami S, Schips L, Fornara P, Pierorazio P, Giedelman C, Lee JW, Stein RJ, Rha KH. Eur Urol. 2011:998-1005. [pmid: 21684069].
Young Age Is Independent Prognostic Factor for Cancer-Specific Survival of Low-Stage Clear Cell Renal Cell Carcinoma. Jung E-J, Lee HJ, Kwak C, Ku JH, Moon KC. Urology. 2009:137-141. [pmid: 18950844].
The relationship between the preoperative systemic inflammatory response and cancer-specific survival in patients undergoing potentially curative resection for renal clear cell cancer. Lamb GWA, McMillan DC, Ramsey S, Aitchison M. Br J Cancer. 2006:781-784. [pmid: 16523196].
Laparoscopic operations in urology - Results and complications in 150 patients. Laparoskopicke vykony v urologii - Vysledky a komplikacie u 150 pacientov. L'uptak J, Svihra J, Javorka K, Vrany M, Elias B, Sopilko I, Kliment J Jr. Endoskopie. 2005:66-72.
A review of our first 100 cases of laparoscopic nephrectomy: Defining risk factors for complications. Keeley FX, Tolley DA. Br J Urol. 98:615-618.
MDCT-based scoring system for differentiating angiomyolipoma with minimal fat from renal cell carcinoma. Kim MH, Lee J, Cho G, Cho KS, Kim J, Kim JK. Acta Radiol. 2013:1201-9. [pmid: 23864062].
Percutaneous US-guided needle biopsies of solid renal masses. Aribas BK, Arda K, Aktas E, Ciledag N, Yakut F, Sahin G, Cosar Y, Dogan K, Kaya G. Neoplasma. 2011:146-52. [pmid: 21275465].
Contrast enhanced ultrasonography prediction of cystic renal mass in comparison to histopathology. Xu Y, Zhang S, Wei X, Pan Y, Hao J. Clin Hemorheol Microcirc. 2013.
Radiologically guided percutaneous fine-needle aspiration biopsy of pelvic and retroperitoneal masses: a retrospective study of 68 cases. Guo Z, Kurtycz DF, De Las Casas LE, Hoerl HD. Diagn Cytopathol. 2001:43-9. [pmid: 11466812].
Fine-needle aspiration of cystic lesions of the kidney. Morphologic spectrum and diagnostic problems in 41 cases. Todd TD, Dhurandhar B, Mody D, Ramzy I, Truong LD. Am J Clin Pathol. 99:317-28.
Multi-quadrant biopsy technique improves diagnostic ability in large heterogeneous renal masses. Abel EJ, Heckman JE, Hinshaw L, Best S, Lubner M, Jarrard DF, Downs TM, Nakada SY, Lee FT Jr, Huang W, Ziemlewicz T. J Urol. 2015.
Predictors of 30-day acute kidney injury following radical and partial nephrectomy for renal cell carcinoma. Schmid M, Abd-El-Barr AE, Gandaglia G, Sood A, Olugbade K Jr, Ruhotina N, Sammon JD, Varda B, Chang SL, Kibel AS, Chun FK, Menon M, Fisch M, Trinh QD. Urol Oncol. 2014:1259-66. [pmid: 25129142].
Risk evaluation of selective renal arterial embolization in the treatment of delayed hemorrhage from renal artery pseudoaneurysm after partial nephrectomy. Zhu Y, Liu Y, Zhang J, Lin Z. Cell Biochem Biophys. 2014:1833-9. [pmid: 25048525].
Management, pathology and outcomes of Bosniak category IIF and III cystic renal lesions. Weibl P, Hora M, Kollarik B, Shariat SF, Klatte T. World J Urol. 2015:295-300. [pmid: 24744224].
Unenhanced CT for the diagnosis of minimal-fat renal angiomyolipoma. Schieda N, Hodgdon T, El-Khodary M, Flood TA, McInnes MD. AJR Am J Roentgenol. 2014:1236-41. [pmid: 25415700].
Contrast enhanced ultrasonography prediction of cystic renal mass in comparison to histopathology. Xu Y, Zhang S, Wei X, Pan Y, Hao J. Clin Hemorheol Microcirc. 2014:429-438. [pmid: 24165574].
The 1-year decline in estimated glomerular filtration rate (eGFR) after radical nephrectomy in patients with renal masses and matched living kidney donors is the same. Hew MN, Opondo D, Cordeiro ER, Van Donselaar-Van Der Pant KAMI, Bemelman FJ, Idu MM, De La Rosette JJMCH, Laguna MP. BJU Int. 2014:E49-E55. [pmid: 24053637].
Pathological characteristics and radiographic correlates of complex renal cysts. Reese AC, Johnson PT, Gorin MA, Pierorazio PM, Allaf ME, Fishman EK, Netto GJ, Pavlovich CP. Urol Oncol Semin Orig Invest. 2014:1010-1016.
Robotic partial nephrectomy for cystic renal masses: A comparative analysis of a matched-paired cohort. Akca O, Zargar H, Autorino R, Brandao LF, Laydner H, Krishnan J, Samarasekera D, Li J, Haber G-P, Stein R, Kaouk JH. Urology. 2014:93-98. [pmid: 24821467].
Fine needle aspiration biopsy of complex renal cystic tumors in the era of modern imaging modalities where shall we go?. Li G, Forest F, Feng G, Cuilleron M, Peoc'h M, Cottier M, Mottet N. Nicolas Anal Quant Cytol Histol. 2014:235-240.
Different presentations of renal cell cancer on ultrasound and computerized tomography. Markic D, Krpina K, Ahel J, Spanjol J, Grskovic A, Stifter S, Ethordevic G, Stemberger C, Pavlovic I, Maricic A. Urologia. 2014:0.
Overall mortality after radical nephrectomy in patients aged over 80 years with renal cancer: a retrospective study on preoperative prognostic factors. Brassart E, Lebdai S, Berger J, Traore S, Bernhard JC, Fardoun T, Muller G, Patard JJ, Azzouzi AR, Bigot P. Int J Urol. 2012:626-32. [pmid: 22458762].
Renal cell carcinoma stage migration in a single European centre over 25 years: effects on 5- and 10-year metastasis-free survival. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Pummer K, Zigeuner R. Int Urol Nephrol. 2012:997-1004. [pmid: 22456765].
Partial nephrectomy is associated with improved overall survival compared to radical nephrectomy in patients with unanticipated benign renal tumours. Weight CJ, Lieser G, Larson BT, Gao T, Lane BR, Campbell SC, Gill IS, Novick AC, Fergany AF. Eur Urol. 2010:293-8. [pmid: 20546991].
Laparoscopic radical nephrectomy for renal cell carcinoma: oncological outcomes at 10 years or more. Berger A, Brandina R, Atalla MA, Herati AS, Kamoi K, Aron M, Haber GP, Stein RJ, Desai MM, Kavoussi LR, Gill IS. J Urol. 2009:2172-6. [pmid: 19758651].
Benign lesions underwent radical nephrectomy for renal cancer. Bobrek tumoru on tanisi ile radikal nefrektomi yapilan benin lezyonlar. Sahin MO, Canda AE, Mungan MU, Kirkali Z, Sade M. Turk Urol Derg. 2004:405-409.

## Patients with recurrent renal cell carcinoma

Feasibility and outcomes of laparoscopic renal intervention after prior open ipsilateral retroperitoneal surgery. Boris RS, Gupta GN, Benson JS, Linehan WM, Pinto PA, Bratslavsky G. J Endourol. 2013:196-201. [pmid: 22963658].
Influence of visceral obesity on oncologic outcome in patients with renal cell carcinoma. Naya Y, Zenbutsu S, Araki K, Nakamura K, Kobayashi M, Kamijima S, Imamoto T, Nihei N, Suzuki H, Ichikawa T, Igarashi T. Urol Int. 2010:30-6. [pmid: 20693825].
Feasibility of laparoscopic partial nephrectomy after previous ipsilateral renal procedures. Turna B, Aron M, Frota R, Desai MM, Kaouk J, Gill IS. Urology. 2008:584-8. [pmid: 18579185].
Open partial nephrectomy for tumor in a solitary kidney: experience with 400 cases. Fergany AF, Saad IR, Woo L, Novick AC. J Urol. 2006:1630-3. discussion 1633. [pmid: 16600716].
Percutaneous radiofrequency ablation of renal tumors: technique, complications, and outcomes. Ahrar K, Matin S, Wood CG, Wallace MJ, Gupta S, Madoff DC, Rao S, Tannir NM, Jonasch E, Pisters LL, Rozner MA, Kennamer DL, Hicks ME. J Vasc Interv Radiol. 2005:679-88. [pmid: 15872323].
Percutaneous renal cryoablation: prospective experience treating 120 consecutive tumors. Buy X, Lang H, Garnon J, Sauleau E, Roy C, Gangi A. AJR Am J Roentgenol. 2013:1353-61. [pmid: 24261377].
CT-guided percutaneous cryoablation of renal masses in selected patients. Spreafico C, Nicolai N, Lanocita R, Morosi C, Catanzaro M, Civelli E, Torelli T, Stagni S, Piva L, Frigerio LF, Marchiano A, Salvioni R. Radiol Med. 2012:593-605. [pmid: 22020435].
Percutaneous cryoablation of masses in a solitary kidney. Weisbrod AJ, Atwell TD, Frank I, Callstrom MR, Farrell MA, Mandrekar JN, Charboneau JW. AJR Am J Roentgenol. 2010:1620-5. [pmid: 20489104].
Imaging guided biopsy of renal masses: indications, accuracy and impact on clinical management. Wood BJ, Khan MA, McGovern F, Harisinghani M, Hahn PF, Mueller PR. J Urol. 99:1470-4.
Changes in renal function after laparoscopic partial nephrectomy: Comparison with laparoscopic radical nephrectomy. Kang SH, Rhew HY, Kim TS. Korean J Urol. 2013:22-25. [pmid: 23362443].

## Clinically nonlocalized patients

Increased expression of Chitinase 3-like 1 and microvessel density predicts metastasis and poor prognosis in clear cell renal cell carcinoma. Zhang JP, Yuan HX, Kong WT, Liu Y, Lin ZM, Wangs WP, Guo JM. Tumour Biol. 2014.
Results of a comparative study analyzing octogenarians with renal cell carcinoma in a competing risk analysis with patients in the seventh decade of life. May M, Cindolo L, Zigeuner R, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Wolff I, Feciche B, Fenske F, Pichler M, Schips L, Figenshau RS, Madison K, Sanchez-Chapado M, Santiago Martin MD, Salzano L, Lotrecchiano G, Waidelich R, Stief C, Sountoulides P, Brookman-May S. Urol Oncol. 2014.
Pretherapeutic gamma-glutamyltransferase is an independent prognostic factor for patients with renal cell carcinoma. Hofbauer SL, Stangl KI, de Martino M, Lucca I, Haitel A, Shariat SF, Klatte T. Br J Cancer. 2014.
Oncologic outcomes after partial versus radical nephrectomy in renal cell carcinomas smaller than 7 cm with presumed renal sinus fat invasion on preoperative imaging. Koo KC, Kim JC, Cho KS, Choi YD, Hong SJ, Yang SC, Ham WS. BJU Int. 2014.
Serum level and immunohistochemical expression of vascular endothelial growth factor for the prediction of postoperative recurrence in renal cell carcinoma. Fujita N, Okegawa T, Terado Y, Tambo M, Higashihara E, Nutahara K. BMC Res Notes. 2014:369. [pmid: 24938498].
Extent of lymph node dissection at nephrectomy affects cancer-specific survival and metastatic progression in specific sub-categories of patients with renal cell carcinoma (RCC). Capitanio U, Suardi N, Matloob R, Roscigno M, Abdollah F, Di Trapani E, Moschini M, Gallina A, Salonia A, Briganti A, Montorsi F, Bertini R. BJU Int. 2014:210-5. [pmid: 24854206].
Clinical features and treatment of collecting duct carcinoma of the kidney from the korean cancer study group genitourinary and gynecology cancer committee. Kwon KA, Oh SY, Kim HY, Kim HS, Lee HY, Kim TM, Lim HY, Lee NR, Lee HJ, Hong SH, Rha SY. Cancer Res Treat. 2014:141-7. [pmid: 24851105].
Prognostic value of clinical and pathological factors for surgically treated localized clear cell renal cell carcinoma. Teng J, Gao Y, Chen M, Wang K, Cui X, Liu Y, Xu D. Chin Med J (Engl). 2014:1640-4. [pmid: 24791867].
Does robotic assistance confer an economic benefit during laparoscopic radical nephrectomy?. Yang DY, Monn MF, Bahler CD, Sundaram CP. J Urol. 2014:671-6. [pmid: 24747652].
Preoperative butyrylcholinesterase level as an independent predictor of overall survival in clear cell renal cell carcinoma patients treated with nephrectomy. Koie T, Ohyama C, Mikami J, Iwamura H, Fujita N, Sato T, Kojima Y, Fukushi K, Yamamoto H, Imai A, Hatakeyama S, Yoneyama T, Hashimoto Y, Kitayama M, Hirota K. ScientificWorldJournal. 2014:948305. [pmid: 24741368].
Lymph node dissection during cytoreductive nephrectomy: a retrospective analysis. Feuerstein MA, Kent M, Bernstein M, Russo P. Int J Urol. 2014:874-9. [pmid: 24712686].
Cytoreductive nephrectomy for metastatic renal cell carcinoma: a population-based analysis of perioperative outcomes according to clinical stage. Takagi T, Sugihara T, Yasunaga H, Horiguchi H, Fushimi K, Kondo T, Homma Y, Tanabe K. Int J Urol. 2014:770-5. [pmid: 24712555].
Diagnostic and prognostic role of preoperative circulating CA 15-3, CA 125, and beta-2 microglobulin in renal cell carcinoma. Lucarelli G, Ditonno P, Bettocchi C, Vavallo A, Rutigliano M, Galleggiante V, Larocca AM, Castellano G, Gesualdo L, Grandaliano G, Selvaggi FP, Battaglia M. Dis Markers. 2014:689795. [pmid: 24692843].
Tumour characteristics and surgical treatment of renal cell carcinoma in Sweden 2005-2010: a population-based study from the National Swedish Kidney Cancer Register. Thorstenson A, Bergman M, Scherman-Plogell AH, Hosseinnia S, Ljungberg B, Adolfsson J, Lundstam S. Scand J Urol. 2014:231-8. [pmid: 24666102].
Comparison of the Complications and the Cost of Open and Laparoscopic Radical Nephrectomy in Renal Tumors Larger than 7 centimeters. Bayrak O, Seckiner I, Erturhan S, Cil G, Erbagci A, Yagci F. Urol J. 2014:1222-7. [pmid: 24595928].
External validation of the modified Glasgow prognostic score for renal cancer. Tai CG, Johnson TV, Abbasi A, Herrell L, Harris WB, Kucuk O, Canter DJ, Ogan K, Pattaras JG, Nieh PT, Master VA. Indian J Urol. 2014:33-7. [pmid: 24497679].
Evolving epidemiologic trends in nonclear cell renal cell cancer: an analysis of the California Cancer Registry. Pai A, Brunson A, Brown M, Pan CX, Lara PN Jr. Urology. 2013:840-5. [pmid: 24074980].
Do young patients with renal cell carcinoma feature a distinct outcome after surgery? A comparative analysis of patient age based on the multinational CORONA database. Aziz A, May M, Zigeuner R, Pichler M, Chromecki T, Cindolo L, Schips L, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Hoschke B, Gilfrich C, Feciche B, Fenske F, Sountoulides P, Figenshau RS, Madison K, Sanchez-Chapado M, Del Carmen Santiago Martin M, Wieland WF, Salzano L, Lotrecchiano G, Waidelich R, Stief C, Brookman-May S. J Urol. 2014:310-5. [pmid: 23973516].
An analysis of patients with T2 renal cell carcinoma (RCC) according to tumour size: a population-based analysis. Bianchi M, Becker A, Trinh QD, Abdollah F, Tian Z, Shariat SF, Montorsi F, Perrotte P, Graefen M, Karakiewicz PI, Sun M. BJU Int. 2013:1184-90. [pmid: 23651446].
Renal lymph nodes for tumor staging: appraisal of 871 nephrectomies with examination of hilar fat. Mehta V, Mudaliar K, Ghai R, Quek ML, Milner J, Flanigan RC, Picken MM. Arch Pathol Lab Med. 2013:1584-90. [pmid: 23651149].
A generation of laparoscopic nephrectomy: stage-specific surgical and oncologic outcomes for laparoscopic nephrectomy in a single center. Laird A, Stewart GD, Zhong J, Ang WJ, Cutress ML, Riddick AC, McNeill SA, Tolley DA. J Endourol. 2013:1008-14. [pmid: 23634886].
Operative safety and oncologic outcome of laparoscopic radical nephrectomy for renal cell carcinoma >7 cm: a multicenter study of 222 patients. Luciani LG, Porpiglia F, Cai T, D'Elia C, Vattovani V, Giusti G, Tiscione D, Chiodini S, Peschechera R, Fiori C, Spina R, Parma P, Celia A, Malossini G. Urology. 2013:1239-44. [pmid: 23608667].
Gender differences in clinicopathological features and survival in surgically treated patients with renal cell carcinoma: an analysis of the multicenter CORONA database. May M, Aziz A, Zigeuner R, Chromecki T, Cindolo L, Schips L, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Hoschke B, Gilfrich C, Feciche B, Stoltze A, Fenske F, Fritsche HM, Figenshau RS, Madison K, Sanchez-Chapado M, Martin Mdel C, Salzano L, Lotrecchiano G, Joniau S, Waidelich R, Stief C, Brookman-May S. World J Urol. 2013:1073-80. [pmid: 23568445].
Validation of serum C-reactive protein (CRP) as an independent prognostic factor for disease-free survival in patients with localised renal cell carcinoma (RCC). de Martino M, Klatte T, Seemann C, Waldert M, Haitel A, Schatzl G, Remzi M, Weibl P. BJU Int. 2013:E348-53. [pmid: 23495750].
Assessing the accuracy and generalizability of the preoperative and postoperative Karakiewicz nomograms for renal cell carcinoma: results from a multicentre European and US study. Cindolo L, Chiodini P, Brookman-May S, De Cobelli O, May M, Squillacciotti S, De Nunzio C, Tubaro A, Coman I, Feciche B, Truss M, Wirth MP, Dalpiaz O, Chromecki TF, Shariat SF, Sanchez-Chapado M, Santiago Martin Mdel C, Rocco B, Salzano L, Lotrecchiano G, Berardinelli F, Schips L. BJU Int. 2013:578-84. [pmid: 23470199].
Predictive factors of chronic kidney disease stage V after partial nephrectomy in a solitary kidney: a multi-institutional study. Verhoest G, Patard JJ, Oger E, Rioux-Leclercq N, Peyronnet B, Bessede T, Laguna P, Barwari K, Rigaud J, Roupret M, Coffin G, Bernhard JC, Long JA, Zisman A, Berger J, Paparel P, Maurin C, Lechevallier E, Bertini R, Ouzaid I, Salomon L, Bex A, Farfara R, Ljungberg B, Rodriguez AR, Bensalah K. Urol Oncol. 2014:28.e21-6. [pmid: 23428536].
The effect of gender and age on kidney cancer survival: younger age is an independent prognostic factor in women with renal cell carcinoma. Rampersaud EN, Klatte T, Bass G, Patard JJ, Bensaleh K, Bohm M, Allhoff EP, Cindolo L, De La Taille A, Mejean A, Soulie M, Bellec L, Christophe Bernhard J, Pfister C, Colombel M, Belldegrun AS, Pantuck AJ, George D. Urol Oncol. 2014:30.e9-13. [pmid: 23422777].
Evaluation of long-term outcome for patients with renal cell carcinoma after surgery: analysis of cancer deaths occurring more than 10 years after initial treatment. Kyoda Y, Kobayashi K, Hirobe M, Shindo T, Fukuta F, Hashimoto K, Tanaka T, Tonooka A, Kitamura H, Takahashi S, Masumori N, Hasegawa T, Tsukamoto T. Int J Clin Oncol. 2014:146-51. [pmid: 23404486].
Association of microvascular and capillary-lymphatic invasion with outcome in patients with renal cell carcinoma. Eisenberg MS, Cheville JC, Thompson RH, Kaushik D, Lohse CM, Boorjian SA, Costello BA, Leibovich BC. J Urol. 2013:37-43. [pmid: 23353044].
Perioperative outcomes and mid-term results of radiofrequency ablation and partial nephrectomy in indications of renal tumor treatment and imperative nephron-sparing procedure. Arnoux V, Descotes JL, Sengel C, Terrier N, Rambeaud JJ, Long JA. Prog Urol. 2013:99-104. [pmid: 23352302].
Erythrocyte sedimentation rate and anaemia are independent predictors of survival in patients with clear cell renal cell carcinoma. Choi Y, Park B, Kim K, Jeong BC, Seo SI, Jeon SS, Choi HY, Lee JE, Lee HM. Br J Cancer. 2013:387-94. [pmid: 23299540].
Complications of radical nephrectomy for renal cell carcinoma: a retrospective study comparing transperitoneal and retroperitoneal approaches using a standardized reporting methodology in two Chinese centers. Zhang ZL, Li YH, Luo JH, Liu ZW, Yao K, Dong P, Han H, Qin ZK, Chen W, Zhou FJ. Chin J Cancer. 2013:461-8. [pmid: 23298461].
Does mechanical bowel preparation improve quality of laparoscopic nephrectomy? Propensity score-matched analysis in Japanese series. Sugihara T, Yasunaga H, Horiguchi H, Fujimura T, Nishimatsu H, Ohe K, Matsuda S, Fushimi K, Kattan MW, Homma Y. Urology. 2013:74-9. [pmid: 23273073].
Prognostic factors of overall survival in renal cancer patients - single oncological center study. Drewniak T, Sandheim M, Jakubowski J, Juszczak K, Stelmach AW. Cent European J Urol. 2013:283-91.
Down-regulation of human leukocyte antigen class I (HLA-I) is associated with poor prognosis in patients with clear cell renal cell carcinoma. Yuan J, Liu S, Yu Q, Lin Y, Bi Y, Wang Y, An R. Acta Histochem. 2013:470-4. [pmid: 23245688].
Wide range and variation in minimally invasive surgery for renal malignancy in Japan: a population-based analysis. Sugihara T, Yasunaga H, Horiguchi H, Tsuru N, Fujimura T, Nishimatsu H, Kume H, Ohe K, Matsuda S, Fushimi K, Homma Y. Int J Clin Oncol. 2013:1070-7. [pmid: 23179640].
Usefulness of R.E.N.A.L. nephrometry scoring system for predicting outcomes and complications of percutaneous ablation of 751 renal tumors. Schmit GD, Thompson RH, Kurup AN, Weisbrod AJ, Boorjian SA, Carter RE, Geske JR, Callstrom MR, Atwell TD. J Urol. 2013:30-5. [pmid: 23164375].
A preoperative prognostic model predicting recurrence-free survival for patients with kidney cancer. Yaycioglu O, Eskicorapci S, Karabulut E, Soyupak B, Gogus C, Divrik T, Turkeri L, Yazici S, Ozen H. Jpn J Clin Oncol. 2013:63-8. [pmid: 23159766].
Uric acid levels correlate with baseline renal function and high levels are a potent risk factor for postoperative chronic kidney disease in patients with renal cell carcinoma. Jeon HG, Choo SH, Jeong BC, Seo SI, Jeon SS, Choi HY, Lee HM. J Urol. 2013:1249-54. [pmid: 23159461].
Radical nephrectomy with transperitoneal subcostal incision for large and locally advanced tumors of the right kidney. Anastasiou J, Karatzas T, Felekouras E, Tokas T, Koutalellis G, Mitropoulos D, Constantinides C. Anticancer Res. 2012:5023-9. [pmid: 23155274].
Racial disparity in renal cell carcinoma patient survival according to demographic and clinical characteristics. Chow WH, Shuch B, Linehan WM, Devesa SS. Cancer. 2013:388-94. [pmid: 23147245].
Can we predict which patients will evolve to chronic kidney disease after nephrectomy for cortical renal tumors?. Torricelli FC, Danilovic A, Marchini GS, Sant'Anna AC, Dall'Oglio MF, Srougi M. Int Braz J Urol. 2012:637-43. discussion 644. [pmid: 23131505].
Cyclooxygenase-2 expression and its prognostic significance in clear cell renal cell carcinoma. Lee JW, Park JH, Suh JH, Nam KH, Choe JY, Jung HY, Chae JY, Moon KC. Korean J Pathol. 2012:237-45. [pmid: 23110009].
Predictive ability of the 2002 and 2010 versions of the Tumour-Node-Metastasis classification system regarding metastasis-free, cancer-specific and overall survival in a European renal cell carcinoma single-centre series. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Groselj-Strele A, Pummer K, Zigeuner R. BJU Int. 2013:E191-5. [pmid: 23107473].
Short-term functional and oncological outcomes of partial nephrectomy for renal cell carcinoma in patients with an anatomically or functionally solitary kidney: single-center experience. Maehana T, Tanaka T, Kitamura H, Masumori N, Tsukamoto T. Int J Clin Oncol. 2013:1049-53. [pmid: 23065115].
Nodal involvement at nephrectomy is associated with worse survival: a stage-for-stage and grade-for-grade analysis. Sun M, Bianchi M, Hansen J, Abdollah F, Trinh QD, Lughezzani G, Shariat SF, Montorsi F, Perrotte P, Karakiewicz PI. Int J Urol. 2013:372-80. [pmid: 23039208].
Comparison of the 2002 and 2010 TNM classification systems regarding outcome prediction in clear cell and papillary renal cell carcinoma. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Groselj-Strele A, Hoefler G, Pummer K, Zigeuner R. Histopathology. 2013:237-46. [pmid: 23020176].
ABO blood group is a predictor of survival in patients undergoing surgery for renal cell carcinoma. Kaffenberger SD, Morgan TM, Stratton KL, Boachie AM, Barocas DA, Chang SS, Cookson MS, Herrell SD, Smith JA, Clark PE. BJU Int. 2012:E641-6. [pmid: 22958439].
Validation of CRP as prognostic marker for renal cell carcinoma in a large series of patients. Steffens S, Kohler A, Rudolph R, Eggers H, Seidel C, Janssen M, Wegener G, Schrader M, Kuczyk MA, Schrader AJ. BMC Cancer. 2012:399. [pmid: 22958305].
Factors affecting renal function after open partial nephrectomy-a comparison of clampless and clamped warm ischemic technique. Kopp RP, Mehrazin R, Palazzi K, Bazzi WM, Patterson AL, Derweesh IH. Urology. 2012:865-70. [pmid: 22951008].
External validation of the preoperative Karakiewicz nomogram in a large multicentre series of patients with renal cell carcinoma. Gontero P, Sun M, Antonelli A, Bertini R, Carini M, Carmignani G, Longo N, Martorana G, Minervini A, Mirone V, Morgia G, Novara G, Oderda M, Simeone C, Simonato A, Siracusano S, Tizzani A, Volpe A, Karakiewicz P, Ficarra V. World J Urol. 2013:1285-90. [pmid: 22847452].
Port site metastasis after laparoscopic radical nephrectomy: a single-center experience. Kumar V, Mandhani A, Srivastava A, Ansari MS, Singh UP, Kapoor R. Indian J Cancer. 2012:102-6. [pmid: 22842176].
Detailed analysis of morbidity following nephrectomy for renal cell carcinoma in octogenarians. Berger J, Fardoun T, Brassart E, Capon G, Bigot P, Bernhard JC, Rigaud J, Patard JJ, Descazeaud A. J Urol. 2012:736-40. [pmid: 22818133].
Features associated with recurrence beyond 5 years after nephrectomy and nephron-sparing surgery for renal cell carcinoma: development and internal validation of a risk model (PRELANE score) to predict late recurrence based on a large multicenter database (CORONA/SATURN Project). Brookman-May S, May M, Shariat SF, Xylinas E, Stief C, Zigeuner R, Chromecki T, Burger M, Wieland WF, Cindolo L, Schips L, De Cobelli O, Rocco B, De Nunzio C, Feciche B, Truss M, Gilfrich C, Pahernik S, Hohenfellner M, Zastrow S, Wirth MP, Novara G, Carini M, Minervini A, Simeone C, Antonelli A, Mirone V, Longo N, Simonato A, Carmignani G, Ficarra V. Eur Urol. 2013:472-7. [pmid: 22748912].
Prognostic factors in renal cell carcinoma: analysis of 227 patients treated at the Brazilian National Cancer Institute. Ornellas AA, Andrade DM, Ornellas P, Wisnescky A, Schwindt AB. Int Braz J Urol. 2012:185-94. [pmid: 22555027].
The impact of delaying radical nephrectomy for stage II or higher renal cell carcinoma. Kim KH, You D, Jeong IG, Song C, Hong JH, Ahn H, Kim CS. J Cancer Res Clin Oncol. 2012:1561-7. [pmid: 22547152].
Obesity is associated with an improved cancer-specific survival, but an increased rate of postoperative complications after surgery for renal cell carcinoma. Rogde AJ, Gudbrandsdottir G, Hjelle KM, Sand KE, Bostad L, Beisland C. Scand J Urol Nephrol. 2012:348-57. [pmid: 22530756].
Renal function outcomes after nephrectomy for kidney cancer in elderly patients. Markic D, Valencic M, Spanjol J, Materljan M, Fuckar D. Coll Antropol. 2011:121-4. [pmid: 22220418].
Chromophobe renal cell carcinoma: analysis of 53 cases. Zhao PJ, Chen XP, Li XS, Yao L, Zhang CJ, Yu W, He Q, He ZS, Zhou LQ. J Cancer Res Clin Oncol. 2012:451-4. [pmid: 22179197].
Hospital volume is a determinant of postoperative complications, blood transfusion and length of stay after radical or partial nephrectomy. Sun M, Bianchi M, Trinh QD, Abdollah F, Schmitges J, Jeldres C, Shariat SF, Graefen M, Montorsi F, Perrotte P, Karakiewicz PI. J Urol. 2012:405-10. [pmid: 22177151].
Postoperative complications and long-term survival among patients treated surgically for renal cell carcinoma. Tan HJ, Hafez KS, Ye Z, Wei JT, Miller DC. J Urol. 2012:60-6. [pmid: 22114816].
Gender-specific clinicopathological features and survival in patients with renal cell carcinoma (RCC). Lee S, Jeon HG, Kwak C, Kim HH, Byun SS, Lee SE, Lee E. BJU Int. 2012:E28-33. [pmid: 22085161].
Randomized controlled study of natural interferon alpha as adjuvant treatment for stage II or III renal cell carcinoma. Hinotsu S, Kawai K, Ozono S, Tsushima T, Tokuda N, Nomata K, Naito S, Akaza H. Int J Clin Oncol. 2013:68-74. [pmid: 22068465].
Difference between clinical and pathologic renal tumor size, correlation with survival, and implications for patient counseling regarding nephron-sparing surgery. Brookman-May S, Johannsen M, May M, Hoschke B, Gunschera J, Wieland WF, Burger M. AJR Am J Roentgenol. 2011:1137-45. [pmid: 22021506].
Small renal cell carcinoma: oncological outcome with tumour size. Pahernik S, Huber J, Pfitzenmaier J, Haferkamp A, Hohenfellner M. Scand J Urol Nephrol. 2011:432-5. [pmid: 22017406].
External validation of the Leibovich prognosis score for nonmetastatic clear cell renal cell carcinoma at a single European center applying routine pathology. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Rehak P, Pummer K, Zigeuner R. J Urol. 2011:1773-7. [pmid: 21944989].
Prognostic significance of CD45RO+ memory T cells in renal cell carcinoma. Hotta K, Sho M, Fujimoto K, Shimada K, Yamato I, Anai S, Konishi N, Hirao Y, Nonomura K, Nakajima Y. Br J Cancer. 2011:1191-6. [pmid: 21934683].
Comparison of rates and risk factors for development of anaemia and erythropoiesis-stimulating agent utilization after radical or partial nephrectomy. Woldrich J, Mehrazin R, Bazzi WM, Bagrodia A, Kopp RP, Malcolm JB, Kane CJ, Patterson AL, Wan JY, Derweesh IH. BJU Int. 2012:1019-25. [pmid: 21933323].
Validation of the 2009 TNM Classification for Renal Cell Carcinoma: Comparison with the 2002 TNM Classification by Concordance Index. Lee C, You D, Park J, Jeong IG, Song C, Hong JH, Ahn H, Kim CS. Korean J Urol. 2011:524-30. [pmid: 21927698].
Outcomes and clinicopathologic variables associated with late recurrence after nephrectomy for localized renal cell carcinoma. Kim SP, Weight CJ, Leibovich BC, Thompson RH, Costello BA, Cheville JC, Lohse CM, Boorjian SA. Urology. 2011:1101-6. [pmid: 21903243].
Adult renal cancer in Senegal: Current epidemiological, clinical features, profile's evolution over the two past decades. Fall B, Diao B, Sow Y, Sarr A, Thiam A, Fall PA, Ndoye AK, Sylla C, Ba M, Mendes V, Diagne BA. Prog Urol. 2011:521-6. [pmid: 21872154].
A multidisciplinary evaluation of inter-reviewer agreement of the nephrometry score and the prediction of long-term outcomes. Weight CJ, Atwell TD, Fazzio RT, Kim SP, Kenny M, Lohse CM, Boorjian SA, Leibovich BC, Thompson RH. J Urol. 2011:1223-8. [pmid: 21849200].
The Karakiewicz nomogram is the most useful clinical predictor for survival outcomes in patients with localized renal cell carcinoma. Tan MH, Li H, Choong CV, Chia KS, Toh CK, Tang T, Tan PH, Wong CF, Lau W, Cheng C. Cancer. 2011:5314-24. [pmid: 21567386].
Chronic pulmonary diseases are independent risk factors for complications after radical nephrectomy. Tokgoz H, Akduman B, Unal I, Erol B, Akyurek E, Mungan NA. Int Urol Nephrol. 2011:1025-31. [pmid: 21516476].
Independent validation of the 2010 American Joint Committee on Cancer TNM classification for renal cell carcinoma: results from a large, single institution cohort. Kim SP, Alt AL, Weight CJ, Costello BA, Cheville JC, Lohse C, Allmer C, Leibovich BC. J Urol. 2011:2035-9. [pmid: 21496854].
Lymphadenectomy improves survival of patients with renal cell carcinoma and nodal metastases. Whitson JM, Harris CR, Reese AC, Meng MV. J Urol. 2011:1615-20. [pmid: 21419453].
Renal impairment after laparoscopic radical nephrectomy affects hypoglycaemic therapy. Mizuno T, Ito K, Miyagawa Y, Kimura K, Suzuki Y, Mizuno M, Ito Y, Funahashi Y, Hattori R, Gotoh M, Noda Y, Yamada K. J Clin Pharm Ther. 2012:49-52. [pmid: 21332567].
Oncological outcome of surgical treatment in 336 patients with renal cell carcinoma. Zhang ZL, Li YH, Xiong YH, Hou GL, Yao K, Dong P, Liu ZW, Han H, Qin ZK, Zhou FJ. Chin J Cancer. 2010:995-9. [pmid: 21114919].
Adverse renal outcomes in subjects undergoing nephrectomy for renal tumors: a population-based analysis. Klarenbach S, Moore RB, Chapman DW, Dong J, Braam B. Eur Urol. 2011:333-9. [pmid: 21109345].
Contemporary experience with laparoscopic radical nephrectomy. Mues AC, Haramis G, Rothberg MB, Okhunov Z, Casazza C, Landman J. J Laparoendosc Adv Surg Tech A. 2011:15-8. [pmid: 21091214].
Age-adjusted incidence, mortality, and survival rates of stage-specific renal cell carcinoma in North America: a trend analysis. Sun M, Thuret R, Abdollah F, Lughezzani G, Schmitges J, Tian Z, Shariat SF, Montorsi F, Patard JJ, Perrotte P, Karakiewicz PI. Eur Urol. 2011:135-41. [pmid: 21035250].
Comparison of laparoscopic versus open radical nephrectomy for large renal tumors: a retrospective analysis of multi-center results. Jeon SH, Kwon TG, Rha KH, Sung GT, Lee W, Lim JS, Jeong YB, Hong SH, Kim HH, Byun SS. BJU Int. 2011:817-21. [pmid: 21029315].
Late recurrence of renal cell carcinoma: retrospective and collaborative study of the Japanese Society of Renal Cancer. Miyao N, Naito S, Ozono S, Shinohara N, Masumori N, Igarashi T, Nakao M, Tsushima T, Senga Y, Horie S, Kanayama HO, Tokuda N, Kobayashi M. Urology. 2011:379-84. [pmid: 20970828].
Comparison of radical and partial nephrectomy in terms of renal function: a retrospective cohort study. Suer E, Burgu B, Gokce MI, Turkolmez K, Beduk Y, Baltaci S. Scand J Urol Nephrol. 2011:24-9. [pmid: 20923383].
Histopathological predictors of renal function decrease after laparoscopic radical nephrectomy. Gautam G, Lifshitz D, Shikanov S, Moore JM, Eggener SE, Shalhav AL, Chang A. J Urol. 2010:1872-6. [pmid: 20850146].
Clinico-radio-pathologic features of a solitary solid renal mass at MDCT examination. Kim EY, Park BK, Kim CK, Lee HM. Acta Radiol. 2010:1143-8. [pmid: 20849320].
Impact of body mass index and weight loss on cancer-specific and overall survival in patients with surgically resected renal cell carcinoma. Brookman-May S, Kendel F, Hoschke B, Wieland WF, Burger M, Rossler W, May M. Scand J Urol Nephrol. 2011:5-14. [pmid: 20846080].
Influence of visceral obesity on oncologic outcome in patients with renal cell carcinoma. Naya Y, Zenbutsu S, Araki K, Nakamura K, Kobayashi M, Kamijima S, Imamoto T, Nihei N, Suzuki H, Ichikawa T, Igarashi T. Urol Int. 2010:30-6. [pmid: 20693825].
Validation of the 2009 TNM version in a large multi-institutional cohort of patients treated for renal cell carcinoma: are further improvements needed?. Novara G, Ficarra V, Antonelli A, Artibani W, Bertini R, Carini M, Cosciani Cunico S, Imbimbo C, Longo N, Martignoni G, Martorana G, Minervini A, Mirone V, Montorsi F, Schiavina R, Simeone C, Serni S, Simonato A, Siracusano S, Volpe A, Carmignani G. Eur Urol. 2010:588-95. [pmid: 20674150].
Obesity is associated with improved survival in patients with organ-confined clear-cell kidney cancer. Waalkes S, Merseburger AS, Kramer MW, Herrmann TR, Wegener G, Rustemeier J, Hofmann R, Schrader M, Kuczyk MA, Schrader AJ. Cancer Causes Control. 2010:1905-10. [pmid: 20652393].
Experiences of open transperitoneal radical nephrectomy for large renal masses. Yao XD, Ye DW, Zhang SL, Dai B, Zhang HL, Shen YJ, Zhu Y, Zhu YP, Shi GH, Ma CG, Xiao WJ, Qin XJ, Lin GW. Zhonghua Yi Xue Za Zhi. 2010:1117-9. [pmid: 20646430].
Feasibility of differential diagnosis of kidney tumors by comparative genomic hybridization of fine needle aspiration biopsies. Vieira J, Henrique R, Ribeiro FR, Barros-Silva JD, Peixoto A, Santos C, Pinheiro M, Costa VL, Soares MJ, Oliveira J, Jeronimo C, Teixeira MR. Genes Chromosomes Cancer. 2010:935-47. [pmid: 20629095].
Impact of body mass index on perioperative outcomes of laparoscopic radical nephrectomy in Japanese patients with clinically localized renal cell carcinoma. Miyake H, Muramaki M, Tanaka K, Takenaka A, Fujisawa M. Int J Urol. 2010:522-6. [pmid: 20345492].
The prognostic value of erythrocyte polyamines in the preoperative evaluation of patients with renal cell carcinoma. Lughezzani G, Karakiewicz PI, Bigot P, Perrotte P, Crepel M, Rioux-Leclercq N, Catros-Quemener V, Moulinoux JP, Bouet F, Cipolla B, Patard JJ. Eur J Cancer. 2010:1927-35. [pmid: 20335019].
Pathological prognostic indicators in renal cell carcinoma. Rey Rey J, Leon Ramirez D, Lopez Garcia S, Fernandez Vazquez P, Benavente Delgado J, Ojea Calvo A. Actas Urol Esp. 2010:71-7. [pmid: 20223135].
The use of the American Society of Anesthesiology Classification as a prognostic factor in patients with renal cell carcinoma. de Cassio Zequi S, de Campos EC, Guimaraes GC, Bachega W Jr, da Fonseca FP, Lopes A. Urol Int. 2010:67-72. [pmid: 20173372].
Histological subtype is an independent predictor of outcome for patients with renal cell carcinoma. Leibovich BC, Lohse CM, Crispen PL, Boorjian SA, Thompson RH, Blute ML, Cheville JC. J Urol. 2010:1309-15. [pmid: 20171681].
The prognostic value of erythrocyte polyamine in the post-nephrectomy stratification of renal cell carcinoma specific mortality. Bigot P, Lughezzani G, Karakiewicz P, Perrotte P, Rioux-Leclercq N, Catros-Quemener V, Bouet F, Moulinoux JP, Cipolla B, Patard JJ. J Urol. 2010:486-91. [pmid: 20006872].
Preoperative erythrocyte sedimentation rate is an independent prognostic factor in Japanese patients with localized clear cell renal cell carcinoma. Kawai Y, Matsuyama H, Korenaga Y, Misumi T, Eguchi S, Hara T, Nagao K, Ohmi C, Sakano S, Naito K. Urol Int. 2009:306-10. [pmid: 19829031].
Limited prognostic value of tumor necrosis in patients with renal cell carcinoma. Isbarn H, Patard JJ, Lughezzani G, Rioux-Leclercq N, Crepel M, Cindolo L, de la Taille A, Zini L, Villers A, Shariat SF, Bertini R, Karakiewicz PI. Urology. 2010:1378-84. [pmid: 19781745].
Presence of intratumoral neutrophils is an independent prognostic factor in localized renal cell carcinoma. Jensen HK, Donskov F, Marcussen N, Nordsmark M, Lundbeck F, von der Maase H. J Clin Oncol. 2009:4709-17. [pmid: 19720929].
Impact of Charlson's comorbidity index on overall survival following tumor nephrectomy for renal cell carcinoma. Ather MH, Nazim SM. Int Urol Nephrol. 2010:299-303. [pmid: 19714477].
Laparoscopic radical nephrectomy for patients with T2 and T3 renal-cell carcinoma: evaluation of perioperative outcomes. Bird VG, Shields JM, Aziz M, Ayyathurai R, De Los Santos R, Roeter DH. J Endourol. 2009:1527-33. [pmid: 19698054].
Transperitoneal laparoscopic radical nephrectomy is an effective procedure for large (more than 7 cm) renal masses. Chertin B, Benjamin S, Reissman P, Kheifets A, Prat O, Shenfeld OZ, Sidi AA, Tsivian A. Surg Laparosc Endosc Percutan Tech. 2009:353-5. [pmid: 19692891].
Urinary collecting system invasion is an independent prognostic factor of organ confined renal cell carcinoma. Verhoest G, Avakian R, Bensalah K, Thuret R, Ficarra V, Artibani W, Tostain J, Guille F, Cindolo L, De La Taille A, Abbou CC, Salomon L, Rioux-Leclercq N, Patard JJ. J Urol. 2009:854-9. [pmid: 19616244].
Validation of a postoperative prognostic model consisting of tumor microvascular invasion, size, and grade to predict disease-free and cancer-specific survival of patients with surgically resected renal cell carcinoma. May M, Brookman-Amissah S, Kendel F, Knoll N, Roigas J, Hoschke B, Miller K, Gilfrich C, Pflanz S, Gralla O. Int J Urol. 2009:616-21. [pmid: 19456988].
Metastatic renal cell carcinoma risk according to tumor size. Thompson RH, Hill JR, Babayev Y, Cronin A, Kaag M, Kundu S, Bernstein M, Coleman J, Dalbagni G, Touijer K, Russo P. J Urol. 2009:41-5. [pmid: 19450840].
Factors predicting health-related quality of life recovery in patients undergoing surgical treatment for renal tumors: prospective evaluation using the RAND SF-36 Health Survey. Novara G, Secco S, Botteri M, De Marco V, Artibani W, Ficarra V. Eur Urol. 2010:112-20.
Postoperative surveillance for renal cell carcinoma: a multifactorial histological subtype specific protocol. Siddiqui SA, Frank I, Cheville JC, Lohse CM, Leibovich BC, Blute ML. BJU Int. 2009:778-85. [pmid: 19338559].
Radical nephrectomy surgical outcomes in the University HealthSystem Consortium Data Base: Impact of hospital case volume, hospital size, and geographic location on 40,000 patients. Mitchell RE, Lee BT, Cookson MS, Barocas DA, Duke Herrell S, Clark PE, Smith JA, Chang SS. Cancer. 2009:2447-52. [pmid: 19309750].
Preoperative prognostic nomogram (probability table) for renal cell carcinoma based on TNM classification. Kanao K, Mizuno R, Kikuchi E, Miyajima A, Nakagawa K, Ohigashi T, Nakashima J, Oya M. J Urol. 2009:480-5. discussion 485. [pmid: 19100568].
The prognostic relevance of interactions between venous invasion, lymph node involvement and distant metastases in renal cell carcinoma after radical nephrectomy. Zubac DP, Bostad L, Seidal T, Wentzel-Larsen T, Haukaas SA. BMC Urol. 2008:19. [pmid: 19099564].
Transperitoneal versus retroperitoneal laparoscopic radical nephrectomy: a comparative study. Taue R, Izaki H, Koizumi T, Kishimoto T, Oka N, Fukumori T, Takahashi M, Kanayama HO. Int J Urol. 2009:263-7. [pmid: 19087210].
Thirty-day mortality after nephrectomy: clinical implications for informed consent. Cloutier V, Capitanio U, Zini L, Perrotte P, Jeldres C, Shariat SF, Arjane P, Patard JJ, Montorsi F, Karakiewicz PI. Eur Urol. 2009:998-1003. [pmid: 19054604].
Race affects access to nephrectomy but not survival in renal cell carcinoma. Zini L, Perrotte P, Capitanio U, Jeldres C, Duclos A, Arjane P, Villers A, Montorsi F, Patard JJ, Karakiewicz PI. BJU Int. 2009:889-93. [pmid: 19021607].
Stage-specific effect of nodal metastases on survival in patients with non-metastatic renal cell carcinoma. Capitanio U, Jeldres C, Patard JJ, Perrotte P, Zini L, de La Taille A, Ficarra V, Cindolo L, Bensalah K, Artibani W, Tostain J, Valeri A, Zigeuner R, Mejean A, Descotes JL, Lechevallier E, Mulders PF, Lang H, Jacqmin D, Karakiewicz PI. BJU Int. 2009:33-7. [pmid: 18990161].
Radical nephrectomy with and without lymph-node dissection: final results of European Organization for Research and Treatment of Cancer (EORTC) randomized phase 3 trial 30881. Blom JH, van Poppel H, Marechal JM, Jacqmin D, Schroder FH, de Prijck L, Sylvester R. Eur Urol. 2009:28-34. [pmid: 18848382].
A preoperative prognostic model for patients treated with nephrectomy for renal cell carcinoma. Karakiewicz PI, Suardi N, Capitanio U, Jeldres C, Ficarra V, Cindolo L, de la Taille A, Tostain J, Mulders PF, Bensalah K, Artibani W, Salomon L, Zigeuner R, Valeri A, Descotes JL, Rambeaud JJ, Mejean A, Montorsi F, Bertini R, Patard JJ. Eur Urol. 2009:287-95. [pmid: 18715700].
Renal cell carcinoma in young and old patients--is there a difference?. Thompson RH, Ordonez MA, Iasonos A, Secin FP, Guillonneau B, Russo P, Touijer K. J Urol. 2008:1262-6. discussion 1266. [pmid: 18707708].
External validation of the Mayo Clinic cancer specific survival score in a Japanese series of clear cell renal cell carcinoma. Fujii Y, Saito K, Iimura Y, Sakai Y, Koga F, Kawakami S, Kumagai J, Kihara K. J Urol. 2008:1290-5. discussion 1295-6. [pmid: 18707704].
Radiofrequency ablation of renal tumors in the solitary kidney. Krambeck AE, Farrell MA, Callstrom MR, Atwell TD, Charboneau JW, Chow GK, Dimarco DS, Patterson DE. Can J Urol. 2008:4163-8. discussion 4168. [pmid: 18706143].
Robotic nephrectomy for the treatment of benign and malignant disease. Rogers C, Laungani R, Krane LS, Bhandari A, Bhandari M, Menon M. BJU Int. 2008:1660-5. [pmid: 18671787].
Retroperitoneal laparoscopic radical nephrectomy: intermediate oncological results. Larre S, Kanso C, De La Taille A, Hoznek A, Vordos D, Yiou R, Abbou CC, Salomon L. World J Urol. 2008:611-5. [pmid: 18629504].
Nephron-sparing surgery: a call for greater application of established techniques. Young JG, Luscombe CJ, Lynch C, Wallace DM. BJU Int. 2008:1389-93. [pmid: 18565170].
Renal surgery in the elderly: morbidity in patients aged >75 years in a contemporary series. Staehler M, Haseke N, Stadler T, Bader M, Karl A, Becker A, Stief CG. BJU Int. 2008:684-7. [pmid: 18510657].
Comparison of open and laparoscopic nephrectomy in obese and nonobese patients: outcomes stratified by body mass index. Feder MT, Patel MB, Melman A, Ghavamian R, Hoenig DM. J Urol. 2008:79-83. [pmid: 18485408].
The efficacy of laparoscopic radical nephrectomy for renal cell cancer in the elderly: an oncological outcome analysis. Harano M, Eto M, Yokomizo A, Tatsugami K, Hamaguchi M, Naito S. Int J Urol. 2008:577-81. [pmid: 18462356].
Percutaneous renal cryoablation: experience treating 115 tumors. Atwell TD, Farrell MA, Leibovich BC, Callstrom MR, Chow GK, Blute ML, Charboneau JW. J Urol. 2008:2136-40. discussion 2140-1. [pmid: 18423719].
Renal tumour surgery in elderly patients. Roos FC, Pahernik S, Melchior SW, Thuroff JW. BJU Int. 2008:680-3. [pmid: 18410435].
How long is too long? The effect of the duration of anaesthesia on the incidence of non-urological complications after surgery. Routh JC, Bacon DR, Leibovich BC, Zincke H, Blute ML, Frank I. BJU Int. 2008:301-4. [pmid: 18410433].
Evaluation of the association of current cigarette smoking and outcome for patients with clear cell renal cell carcinoma. Parker A, Lohse C, Cheville J, Leibovich B, Igel T, Blute M. Int J Urol. 2008:304-8. [pmid: 18380816].
Incidence of local and port site recurrence of urologic cancer after laparoscopic surgery. Tanaka K, Hara I, Takenaka A, Kawabata G, Fujisawa M. Urology. 2008:728-34. [pmid: 18279936].
Analysis of clinicopathologic predictors of oncologic outcome provides insight into the natural history of surgically managed papillary renal cell carcinoma. Margulis V, Tamboli P, Matin SF, Swanson DA, Wood CG. Cancer. 2008:1480-8. [pmid: 18240184].
Renal and cardiovascular morbidity after partial or radical nephrectomy. Miller DC, Schonlau M, Litwin MS, Lai J, Saigal CS. Cancer. 2008:511-20. [pmid: 18072263].
En bloc stapler ligation of the renal vascular pedicle during laparoscopic nephrectomy. Buse S, Gilfrich C, Pfitzenmaier J, Bedke J, Haferkamp A, Hohenfellner M. BJU Int. 2008:878-82. [pmid: 18070189].
Nephron-sparing surgery versus radical nephrectomy in the treatment of intracapsular renal cell carcinoma up to 7cm. Antonelli A, Cozzoli A, Nicolai M, Zani D, Zanotelli T, Perucchini L, Cunico SC, Simeone C. Eur Urol. 2008:803-9. [pmid: 18036730].
Oncological efficacy and safety of nephron-sparing surgery for selected patients with locally advanced renal cell carcinoma. Margulis V, Tamboli P, Jacobsohn KM, Swanson DA, Wood CG. BJU Int. 2007:1235-9. [pmid: 17979923].
Disparities in treatment and outcome for renal cell cancer among older black and white patients. Berndt SI, Carter HB, Schoenberg MP, Newschaffer CJ. J Clin Oncol. 2007:3589-95. [pmid: 17704406].
Microvascular tumor invasion, tumor size and Fuhrman grade: a pathological triad for prognostic evaluation of renal cell carcinoma. Dall'Oglio MF, Ribeiro-Filho LA, Antunes AA, Crippa A, Nesrallah L, Goncalves PD, Leite KR, Srougi M. J Urol. 2007:425-8. discussion 428. [pmid: 17561167].
Multi-institutional validation of a new renal cancer-specific survival nomogram. Karakiewicz PI, Briganti A, Chun FK, Trinh QD, Perrotte P, Ficarra V, Cindolo L, De la Taille A, Tostain J, Mulders PF, Salomon L, Zigeuner R, Prayer-Galetti T, Chautard D, Valeri A, Lechevallier E, Descotes JL, Lang H, Mejean A, Patard JJ. J Clin Oncol. 2007:1316-22. [pmid: 17416852].
Does tumor size or microvascular invasion affect prognosis in patients with renal cell carcinoma?. Miyagawa T, Shimazui T, Hinotsu S, Oikawa T, Sekido N, Miyanaga N, Kawai K, Akaza H. Jpn J Clin Oncol. 2007:197-200. [pmid: 17360737].
The follow-up management of non-metastatic renal cell carcinoma: definition of a surveillance protocol. Antonelli A, Cozzoli A, Zani D, Zanotelli T, Nicolai M, Cunico SC, Simeone C. BJU Int. 2007:296-300. [pmid: 17326263].
Survival analysis of 130 patients with papillary renal cell carcinoma: prognostic utility of type 1 and type 2 subclassification. Pignot G, Elie C, Conquy S, Vieillefond A, Flam T, Zerbib M, Debre B, Amsellem-Ouazana D. Urology. 2007:230-5. [pmid: 17275070].
Nephron sparing surgery: A single institution experience. Agrawal S, Jha MS, Khurana N, Ansari MS, Dubey D, Srivastava A, Kapoor R, Kumar A, Jain M, Mandhani A. Indian J Urol. 2007:23-7. [pmid: 19675756].
Laparoscopic radical nephrectomy: comparison of clinical Stage T1 and T2 renal tumors. Gong EM, Lyon MB, Orvieto MA, Lucioni A, Gerber GS, Shalhav AL. Urology. 2006:1183-7. [pmid: 17169642].
Laparoscopic partial nephrectomy for incidental stage pT2 or worse tumors. Ukimura O, Haber GP, Remer EM, Gill IS. Urology. 2006:976-82. [pmid: 17095068].
Gender discrepancies in the diagnosis of renal cortical tumors. Pierorazio PM, Murphy AM, Benson MC, McKiernan JM. World J Urol. 2007:81-5. [pmid: 17066264].
Prognostic significance of common preoperative laboratory variables in clear cell renal cell carcinoma. Lee SE, Byun SS, Han JH, Han BK, Hong SK. BJU Int. 2006:1228-32. [pmid: 17034508].
The influence of clinical and pathological stage discrepancy on cancer specific survival in patients treated for renal cell carcinoma. Svatek RS, Lotan Y, Herman MP, Duchene DA, Sagalowsky AI, Cadeddu JA. J Urol. 2006:1321-5. discussion 125. [pmid: 16952621].
Intraoperative conversion of laparoscopic partial nephrectomy. Rais-Bahrami S, Lima GC, Varkarakis IM, Romero FR, Trock B, Jarrett TW, Kavoussi LR. J Endourol. 2006:205-8. [pmid: 16548731].
Treating renal cell cancer in the elderly. Berdjis N, Hakenberg OW, Novotny V, Froehner M, Wirth MP. BJU Int. 2006:703-5. [pmid: 16536757].
Intermediate results of laparoscopic cryoablation in 59 patients at the Medical College of Wisconsin. Lawatsch EJ, Langenstroer P, Byrd GF, See WA, Quiroz FA, Begun FP. J Urol. 2006:1225-9. discussion 1229. [pmid: 16515964].
Impact of body mass index on survival of patients with surgically treated renal cell carcinoma. Donat SM, Salzhauer EW, Mitra N, Yanke BV, Snyder ME, Russo P. J Urol. 2006:46-52. [pmid: 16406867].
Reassessing the current TNM lymph node staging for renal cell carcinoma. Terrone C, Cracco C, Porpiglia F, Bollito E, Scoffone C, Poggio M, Berruti A, Ragni F, Cossu M, Scarpa RM, Rossetti SR. Eur Urol. 2006:324-31. [pmid: 16386352].
Retroperitoneoscopic versus open surgical radical nephrectomy for large renal cell carcinoma in clinical stage cT2 or cT3a: quality of life, pain and reconvalescence. Dillenburg W, Poulakis V, Skriapas K, de Vries R, Ferakis N, Witzsch U, Melekos M, Becht E. Eur Urol. 2006:314-22. discussion 322-3. [pmid: 16377073].
Elective nephron sparing surgery should become standard treatment for small unilateral renal cell carcinoma: Long-term survival data of 216 patients. Becker F, Siemer S, Humke U, Hack M, Ziegler M, Stockle M. Eur Urol. 2006:308-13. [pmid: 16359779].
Mini-flank supra-11th rib incision for open partial or radical nephrectomy. Diblasio CJ, Snyder ME, Russo P. BJU Int. 2006:149-56. [pmid: 16336347].
Laparoscopic nephrectomy: new standard of care?. Sim HG, Yip SK, Ng CY, Teo YS, Tan YH, Siow WY, Cheng WS. Asian J Surg. 2005:277-81. [pmid: 16234079].
Comparison of predictive accuracy of four prognostic models for nonmetastatic renal cell carcinoma after nephrectomy: a multicenter European study. Cindolo L, Patard JJ, Chiodini P, Schips L, Ficarra V, Tostain J, de La Taille A, Altieri V, Lobel B, Zigeuner RE, Artibani W, Guille F, Abbou CC, Salzano L, Gallo C. Cancer. 2005:1362-71. [pmid: 16116599].
Partial nephrectomy with perfusion cooling for imperative indications: a 24-year experience. Steffens J, Humke U, Ziegler M, Siemer S. BJU Int. 2005:608-11. [pmid: 16104919].
Miniinvasive laparoscopic or retroperitoneoscopic radical nephrectomy for the parenchymal tumor. Hora M, Klecka J Jr, Hes O, Ferda J, Urge T. Rozhl Chir. 2005:246-52. [pmid: 16045121].
Incisional hernia following hand-assisted laparoscopic surgery for renal cell cancer. Troxel SA, Das S. JSLS. 2005:196-8. [pmid: 15984709].
Survival prognostic factors valuation on a series of 202 patients with surgical treatment of renal cell carcinoma. Ortiz Gorraiz M, Vicente Prados FJ, Rosales Leal JL, Honrubia Vilchez B, Martinez Morcillo A, Cozar Olmo JM, Espejo Maldonado E, Tallada Bunuel M. Actas Urol Esp. 2005:179-89. [pmid: 15881917].
Independent validation of the 2002 American Joint Committee on cancer primary tumor classification for renal cell carcinoma using a large, single institution cohort. Frank I, Blute ML, Leibovich BC, Cheville JC, Lohse CM, Zincke H. J Urol. 2005:1889-92. [pmid: 15879769].
Results of open radical nephrectomy in a series of 230 patients. Peyromaure M, Barry Delongchamps N, Roffi F, Debre B, Zerbib M. Prog Urol. 2005:18-22. [pmid: 15822386].
Retrospective study of laparoscopic retroperitoneal radical nephrectomy. Hetet JF, Rigaud J, Renaudin K, Battisti S, Braud G, Bouchot O, Karam G. Prog Urol. 2005:10-7. discussion 16. [pmid: 15822385].
Impact of tumor size on the long-term survival of patients with early stage renal cell cancer. Kuczyk M, Wegener G, Merseburger AS, Anastasiadis A, Machtens S, Zumbragel A, Hartmann JT, Bokemeyer C, Jonas U, Stenzl A. World J Urol. 2005:50-4. [pmid: 15729558].
Prospective randomized trial comparing high lumbotomic with laparotomic access in renal cell carcinoma surgery. Battaglia M, Ditonno P, Martino P, Palazzo S, Annunziata G, Selvaggi FP. Scand J Urol Nephrol. 2004:306-14. [pmid: 15669590].
Associations with contralateral recurrence following nephrectomy for renal cell carcinoma using a cohort of 2,352 patients. Bani-Hani AH, Leibovich BC, Lohse CM, Cheville JC, Zincke H, Blute ML. J Urol. 2005:391-4. [pmid: 15643178].
Re-evaluation of the Tumour-Node-Metastasis staging of locally advanced renal cortical tumours: absolute size (T2) is more significant than renal capsular invasion (T3a). Murphy AM, Gilbert SM, Katz AE, Goluboff ET, Sawczuk IS, Olsson CA, Benson MC, McKiernan JM. BJU Int. 2005:27-30. [pmid: 15638890].
Partial nephrectomy for patients with a solitary kidney: the Memorial Sloan-Kettering experience. Saranchuk JW, Touijer AK, Hakimian P, Snyder ME, Russo P. BJU Int. 2004:1323-8. [pmid: 15610114].
Prospective randomized comparison of transperitoneal versus retroperitoneal laparoscopic radical nephrectomy. Desai MM, Strzempkowski B, Matin SF, Steinberg AP, Ng C, Meraney AM, Kaouk JH, Gill IS. J Urol. 2005:38-41. [pmid: 15592021].
Clinicopathological features of recurrence after radical surgery for nonmetastatic renal cell carcinoma. Ishimura T, Sakai I, Harada K, Hara I, Eto H, Miyake H. Int J Clin Oncol. 2004:369-72. [pmid: 15549586].
Laparoscopic radical nephrectomy for large (greater than 7 cm, T2) renal tumors. Steinberg AP, Finelli A, Desai MM, Abreu SC, Ramani AP, Spaliviero M, Rybicki L, Kaouk J, Novick AC, Gill IS. J Urol. 2004:2172-6. [pmid: 15538225].
Management of renal masses in patients medically unsuitable for nephrectomy--natural history, complications, and outcome. Lamb GW, Bromwich EJ, Vasey P, Aitchison M. Urology. 2004:909-13. [pmid: 15533476].
Prediction of postoperative renal function by preoperative serum creatinine level and three-dimensional diagnostic image reconstruction in patients with renal cell carcinoma. Tanaka N, Fujimoto K, Tani M, Yoshii M, Yoshida K, Hirao Y, Ozono S. Urology. 2004:904-8. [pmid: 15533475].
Prognosticfactors in patients with renal cell carcinoma: is TNM (1997) staging relevant in Indian subpopulation?. Srivastava A, Mandhani A, Kapoor R, Jain M, Dubey D, Srivastava A, Raghavendra M, Kumar A. Indian J Cancer. 2004:99-103. [pmid: 15472406].
Portless endoscopic radical nephrectomy via a single minimum incision in 80 patients. Kihara K, Kageyama Y, Yano M, Kobayashi T, Kawakami S, Fujii Y, Masuda H, Hyochi N. Int J Urol. 2004:714-20. [pmid: 15379934].
Long-term consequence of renal function following nephrectomy for renal cell cancer. Shirasaki Y, Tsushima T, Nasu Y, Kumon H. Int J Urol. 2004:704-8. [pmid: 15379932].
Prognostic value of the involvement of the urinary collecting system in renal cell carcinoma. Terrone C, Cracco C, Guercio S, Bollito E, Poggio M, Scoffone C, Tarabuzzi R, Porpiglia F, Scarpa RM, Fontana D, Rocca Rossetti S. Eur Urol. 2004:472-6. [pmid: 15363563].
Prognostic value of microscopic venous invasion in renal cell carcinoma: long-term follow-up. Lang H, Lindner V, Letourneux H, Martin M, Saussine C, Jacqmin D. Eur Urol. 2004:331-5. [pmid: 15306103].
Prognostic significance of tumour size in patients after tumour nephrectomy for localised renal cell carcinoma. Steiner T, Knels R, Schubert J. Eur Urol. 2004:327-30. [pmid: 15306102].
Role of nephron sparing surgery in the treatment of centrally located renal tumors. Martorana G, Lupo S, Brunocilla E, Concetti S, Malizia M, Vece E. Arch Ital Urol Androl. 2004:51-5. [pmid: 15270413].
Incidental and symptomatic kidney cancer: pathological features and survival. Dall'Oglio M, Srougi M, Ortiz V, Nesrallah L, Goncalves PD, Leite KM, Hering F. Rev Assoc Med Bras. 2004:27-31. [pmid: 15253022].
Kidney function after nephrectomy for renal cell carcinoma. Shirasaki Y, Tsushima T, Saika T, Nasu Y, Kumon H. Urology. 2004:43-7. discussion 48. [pmid: 15245931].
Microscopic venous invasion in renal cell carcinoma as a predictor of recurrence after radical surgery. Ishimura T, Sakai I, Hara I, Eto H, Miyake H. Int J Urol. 2004:264-8. [pmid: 15147540].
Impact of surgical volume on mortality and length of stay after nephrectomy. Taub DA, Miller DC, Cowan JA, Dimick JB, Montie JE, Wei JT. Urology. 2004:862-7. [pmid: 15134966].
Use of American Society of Anesthesiologists physical status classification to assess perioperative risk in patients undergoing radical nephrectomy for renal cell carcinoma. Han KR, Kim HL, Pantuck AJ, Dorey FJ, Figlin RA, Belldegrun AS. Urology. 2004:841-6. discussion 846-7. [pmid: 15134960].
Laparoscopic radical nephrectomy: techniques, results and oncological outcome in 125 consecutive cases. Wille AH, Roigas J, Deger S, Tullmann M, Turk I, Loening SA. Eur Urol. 2004:483-8. discussion 488-9. [pmid: 15041113].
Permanent flank bulge is a consequence of flank incision for radical nephrectomy in one half of patients. Chatterjee S, Nam R, Fleshner N, Klotz L. Urol Oncol. 2004:36-9. [pmid: 14969802].
Effect of papillary and chromophobe cell type on disease-free survival after nephrectomy for renal cell carcinoma. Beck SD, Patel MI, Snyder ME, Kattan MW, Motzer RJ, Reuter VE, Russo P. Ann Surg Oncol. 2004:71-7. [pmid: 14699037].
Operative mortality after nephrectomy for renal cell carcinoma. Thoroddsen A, Gudbjartsson T, Jonsson E, Gislason T, Einarsson GV. Scand J Urol Nephrol. 2003:507-11. [pmid: 14675926].
The prediction of renal function 6 years after unilateral nephrectomy using preoperative risk factors. Ito K, Nakashima J, Hanawa Y, Oya M, Ohigashi T, Marumo K, Murai M. J Urol. 2004:120-5. [pmid: 14665858].
Renal tumors in young adults. Eggener SE, Rubenstein JN, Smith ND, Nadler RB, Kontak J, Flanigan RC, Waters WB, Picken M, Campbell SC. J Urol. 2004:106-10. [pmid: 14665855].
Racial disparity in incidence patterns and outcome of kidney cancer. Vaishampayan UN, Do H, Hussain M, Schwartz K. Urology. 2003:1012-7. [pmid: 14665346].
Extended total nephrectomy with laparoscopy in localized renal carcinoma Report of 25 cases compared with 32 conventional surgical cases. Lang H, Gimel P, Martin M, Nguyen Ngoc T, Saussine C, Jacqmin D. Prog Urol. 2003:569-76. [pmid: 14650284].
A preoperative clinical prognostic model for non-metastatic renal cell carcinoma. Cindolo L, de la Taille A, Messina G, Romis L, Abbou CC, Altieri V, Rodriguez A, Patard JJ. BJU Int. 2003:901-5. [pmid: 14632843].
Hand assisted laparoscopic radical nephrectomy: comparison with open radical nephrectomy. Lee SE, Ku JH, Kwak C, Kim HH, Paick SH. J Urol. 2003:756-9. [pmid: 12913691].
Renal cell carcinoma as a cause of end-stage renal disease in the United States: patient characteristics and survival. Stiles KP, Moffatt MJ, Agodoa LY, Swanson SJ, Abbott KC. Kidney Int. 2003:247-53. [pmid: 12787416].
Loss of expression of transforming growth factor-beta receptor as a prognostic factor in patients with renal cell carcinoma. Miyajima A, Asano T, Seta K, Asano T, Kakoi N, Hayakawa M. Urology. 2003:1072-7. [pmid: 12736050].
Comparisons of outcome and prognostic features among histologic subtypes of renal cell carcinoma. Cheville JC, Lohse CM, Zincke H, Weaver AL, Blute ML. Am J Surg Pathol. 2003:612-24. [pmid: 12717246].
Benefits of laparoscopic renal surgery are more pronounced in patients with a high body mass index. Klingler HC, Remzi M, Janetschek G, Marberger M. Eur Urol. 2003:522-7. [pmid: 12705997].
Correlation between the mode of presentation of renal tumors and patient survival. Patard JJ, Bensalah K, Vincendeau S, Rioux-Leclerq N, Guille F, Lobel B. Prog Urol. 2003:23-8. [pmid: 12703350].
Outcome and survival with nonsurgical management of renal cell carcinoma. Baird AD, Woolfenden KA, Desmond AD, Fordham MV, Parsons KF. BJU Int. 2003:600-2. [pmid: 12699467].
Clinicopathological study of renal cell carcinoma. Nakatani T, Yoshida N, Iwata H, Kuratsukuri K, Uchida J, Kawashima H, Ikemoto S, Sugimura K. Oncol Rep. 2003:679-85. [pmid: 12684643].
Prediction of progression after radical nephrectomy for patients with clear cell renal cell carcinoma: a stratification tool for prospective clinical trials. Leibovich BC, Blute ML, Cheville JC, Lohse CM, Frank I, Kwon ED, Weaver AL, Parker AS, Zincke H. Cancer. 2003:1663-71. [pmid: 12655523].
Renal cell carcinoma: gender difference in incidental detection and cancer-specific survival. Beisland C, Medby PC, Beisland HO. Scand J Urol Nephrol. 2002:414-8. [pmid: 12623504].
Laparoscopic radical nephrectomy: indications, techniques, and oncological outcome. Wille AH, Roigas J, Deger S, Turk I, Tullmann M, Dubbke A, Schnorr D. Urologe A. 2003:205-10. [pmid: 12607088].
Hand-assisted laparoscopic vs the open (flank incision) approach to radical nephrectomy. Busby E, Das S, Rao Tunuguntla HS, Evans CP. BJU Int. 2003:341-4. [pmid: 12603411].
Influence of age on the prognosis of patients with renal cell carcinoma (RCC). Yusim I, Mermershtain W, Neulander E, Eidelberg I, Gusakova I, Kaneti J. Onkologie. 2002:548-50. [pmid: 12566900].
Incidental and symptomatic renal tumors: impact on patient survival. Dall'Oglio MF, Srougi M, Goncalves PD, Leite K, Nesrallah L, Hering F. Sao Paulo Med J. 2002:165-9. [pmid: 12563422].
Hand-assisted laparoscopy for large renal specimens: a multi-institutional study. Stifelman MD, Handler T, Nieder AM, Del Pizzo J, Taneja S, Sosa RE, Shichman SJ. Urology. 2003:78-82. [pmid: 12559271].
Partial nephrectomy safely preserves renal function in patients with a solitary kidney. Adkins KL, Chang SS, Cookson MS, Smith JA Jr. J Urol. 2003:79-81. [pmid: 12478108].
Mode of presentation of renal cell carcinoma provides prognostic information. Lee CT, Katz J, Fearn PA, Russo P. Urol Oncol. 2002:135-40. [pmid: 12474528].
An outcome prediction model for patients with clear cell renal cell carcinoma treated with radical nephrectomy based on tumor stage, size, grade and necrosis: the SSIGN score. Frank I, Blute ML, Cheville JC, Lohse CM, Weaver AL, Zincke H. J Urol. 2002:2395-400. [pmid: 12441925].
Sporadic renal cell carcinoma in young adults: presentation, treatment, and outcome. Abou El Fettouh HI, Cherullo EE, El-Jack M, Al Maslamani Y, Novick AC. Urology. 2002:806-10. [pmid: 12429303].
Thrombocytosis is associated with a significant increase in the cancer specific death rate after radical nephrectomy. O'Keefe SC, Marshall FF, Issa MM, Harmon MP, Petros JA. J Urol. 2002:1378-80. [pmid: 12352397].
Prognostic significance of primary-tumor extension, stage and grade of nuclear differentiation in patients with renal cell carcinoma. Fiori E, De Cesare A, Galati G, Bononi M, D'Andrea N, Barbarosos A, Izzo L, Bolognese A. J Exp Clin Cancer Res. 2002:229-32. [pmid: 12148583].
Prognostic factors in patients with renal cell carcinoma: retrospective analysis of 675 cases. Ficarra V, Righetti R, Pilloni S, D'amico A, Maffei N, Novella G, Zanolla L, Malossini G, Mobilio G. Eur Urol. 2002:190-8. [pmid: 12074408].
Recurrence of renal cell carcinoma more than 5 years after nephrectomy. Uchida K, Miyao N, Masumori N, Takahashi A, Oda T, Yanase M, Kitamura H, Itoh N, Sato M, Tsukamoto T. Int J Urol. 2002:19-23. [pmid: 11972645].
Comparison of costs and complications of radical and partial nephrectomy for treatment of localized renal cell carcinoma. Shekarriz B, Upadhyay J, Shekarriz H, de Assis Mendes Goes F Jr, Bianco FJ, Tiguert R, Gheiler E, Wood DP Jr. Urology. 2002:211-5. [pmid: 11834387].
Laparoscopic radical nephrectomy in 100 patients: a single center experience from the United States. Gill IS, Meraney AM, Schweizer DK, Savage SS, Hobart MG, Sung GT, Nelson D, Novick AC. Cancer. 2001:1843-55. [pmid: 11745257].
Renal cancer: descriptive analysis of a series of 267 intervened cases. Medina Lopez RA, Congregado Ruiz CB, Campoy Martinez P, Morales Lopez A, Sanchez Gomez E, pascual del Pobil Moreno JL. Arch Esp Urol. 2001:423-8. [pmid: 11494714].
Results of retroperitoneal laparoscopic radical nephrectomy. Cicco A, Salomon L, Hoznek A, Saint F, Alame W, Gasman D, Antiphon P, Chopin DK, Abbou CC. J Endourol. 2001:355-9. discussion 375-6. [pmid: 11394446].
Laparoscopic versus open radical nephrectomy: a 9-year experience. Dunn MD, Portis AJ, Shalhav AL, Elbahnasy AM, Heidorn C, McDougall EM, Clayman RV. J Urol. 2000:1153-9. [pmid: 10992356].
Prognostic indicators for renal cell carcinoma: a multivariate analysis of 643 patients using the revised 1997 TNM staging criteria. Tsui KH, Shvarts O, Smith RB, Figlin RA, deKernion JB, Belldegrun A. J Urol. 2000:1090-5. quiz 1295. [pmid: 10737472].
Laparoscopic radical nephrectomy: a single-center experience of 51 cases. Jeschke K, Wakonig J, Pitzler C, Henning K. Tech Urol. 2000:9-11. [pmid: 10708140].
Surgical management of renal tumors 4 cm. or less in a contemporary cohort. Lee CT, Katz J, Shi W, Thaler HT, Reuter VE, Russo P. J Urol. 2000:730-6. [pmid: 10687966].
Comparison of preoperative embolization followed by radical nephrectomy with radical nephrectomy alone for renal cell carcinoma. Zielinski H, Szmigielski S, Petrovich Z. Am J Clin Oncol. 2000:6-12. [pmid: 10683065].
Renal cell carcinoma: prognostic significance of incidentally detected tumors. Tsui KH, Shvarts O, Smith RB, Figlin R, de Kernion JB, Belldegrun A. J Urol. 2000:426-30. [pmid: 10647646].
Nephron-sparing surgery for renal cell carcinoma--is tumor size a suitable parameter for indication?. Miller J, Fischer C, Freese R, Altmannsberger M, Weidner W. Urology. 99:988-93.
Mortality and morbidity after nephrectomy for renal cell carcinoma using a transperitoneal anterior subcostal incision. Mejean A, Vogt B, Quazza JE, Chretien Y, Dufour B. Eur Urol. 99:298-302.
The surgical therapy of renal carcinomas. The prognostic factors and long-term results. Scilletta B, Di Carlo I, Lombardo R, Aronica G, Di Stefano F, Racalbuto A, Puleo S. Minerva Chir. 99:157-62.
Significant prognostic factors for 5-year survival after curative resection of renal cell carcinoma. Masuda H, Kurita Y, Fukuta K, Mugiya S, Suzuki K, Fujita K. Int J Urol. 98:418-22.
Outcome of renal function in 114 patients who underwent uninephrectomy for renal cancer. el Khader K, Ziade J, Bansard JY, Mhidia A, Patard JJ, Guille F, Lobel B. Prog Urol. 98:341-6.
Stage specific guidelines for surveillance after radical nephrectomy for local renal cell carcinoma. Levy DA, Slaton JW, Swanson DA, Dinney CP. J Urol. 98:1163-7.
Complications of radical nephrectomy in the treatment of kidney adenocarcinoma. Herranz Amo F, Verdu Tartajo F, Diez Cordero JM, Rodriguez Fernandez E, Lledo Garcia E, Moncada Iribarren I, Jara Rascon J, Gonzalez Chamorro F, de Palacio Espana A. Actas Urol Esp. 97:15-21.
Evaluation of patients who underwent radical nephrectomy due to renal tumor. Gunes M, Gecit I, Princci N, Taken K, Ceylan K, Resit Oncu M. East J Med. 2013:108-112.
Prognostic Impact of Histological Subtype on Surgically Treated Localized Renal Cell Carcinoma. Teloken PE, Thompson RH, Tickoo SK, Cronin A, Savage C, Reuter VE, Russo P. J Urol. 2009:2132-2136. [pmid: 19758615].
Is computerized tomography reliable for detecting tumor number and adrenal gland involvement in patients with renal cell cancer? A multicenter study. Bobrek Hucreli Kanser Hastalarinda Tumor Sayisi ve Adrenal Bez Tutulumunu Belirlemede Bilgisayarli Tomografi Guvenilir Midir? Cok Merkezli Bir Calisma. Atan A, Tuncel A, Aslan Y, Caskurlu T, Eroglu M, Albayrak S, Karaman I, Ergenekon E. Turk Urol Derg. 2005:329-334.
Laparoscopic radical nephrectomy for renal cell carcinoma: Oncologically safe?. Laparoscopische behandeling van niercelcarcinoom: Oncologisch verantwoord?. Schatteman P, Tuytten T, Carpentier P, Fonteyne E, Mottrie A. Tijdschr Geneeskd. 2005:179-184.
The symptoms of renal cell carcinoma related to patients' survival. Ou Y-C, Yang C-R, Ho H-C, Cheng C-L, Kao Y-L, Su C-K, Chiu K-Y, Chen W-M. J Chin Med Assoc. 2003:537-543. [pmid: 14649678].
Renal cell carcinoma: Clinical experience and technical success with radio-frequency ablation of 42 tumors. Gervais DA, McGovern FJ, Arellano RS, Scott McDougal W, Mueller PR. Radiology. 2003:417-424. [pmid: 12563135].
A retrospective analysis of serum CA 15-3 concentrations in patients with localised or metastatic renal cancer and its impact on prognosis and follow-up. A single-centre experience. Briasoulis E, Pentheroudakis G, Letsa I, Pavlidis N. UroOncology. 2002:179-184.
Renal cancer in adults. Report of a series of 60 cases. Le cancer du rein de l'adulte. A propos de 60 cas. Benchekroun A, Lachkar A, Bensliman L, Soumana A, Farih MH, Belahnech Z, Marzouk M, Faik M. Ann Urol. 98:119-127.
Laparoscopic radical nephrectomy with morcellation for renal cell carcinoma: The Saskatoon experience. Barrett PH, Fentie DD, Taranger LA. Urology. 98:23-28.
Prognosis in the cases with renal cell carcinoma according to clinical parameters. Fukuda M, Satomi Y, Asakura T, Hosaka M, Noguchi S, Kishida T, Kondou I, Ida T, Hirokawa M, Kumagai H, Shiozaki H, Ishizuka E, Miyai K, Fukuoka H, Sasaki K, Oogo Y, Koudaira T, Ogawa K, Nakahashi M, Matsuura K, Moriyama M, Udagawa K, Senga Y, Ishibashi Y, Shimura H. Jpn J Urol. 98:647-656.
Prognostic factors of renal cell carcinoma: A multivariate analysis. Yasunaga Y, Shin M, Miki T, Okuyama A, Aozasa K. J Surg Oncol. 98:11-18.
Is there a role of the enhancement degree of the lesion on computerized tomography for the characterization of renal tumors?. Kutman K, Suer E, Beduk Y, Ozturk E, Gulpinar O, Gokce I, Baltaci S. J Urol. 2013:436-40. [pmid: 22982427].
Evaluation of malignant and benign renal lesions using diffusion-weighted MRI with multiple b values. Erbay G, Koc Z, Karadeli E, Kuzgunbay B, Goren MR, Bal N. Acta Radiol. 2012:359-65. [pmid: 22334870].
Contrast-enhanced ultrasonography in the diagnosis of solid renal tumors. Tamai H, Takiguchi Y, Oka M, Shingaki N, Enomoto S, Shiraki T, Furuta M, Inoue I, Iguchi M, Yanaoka K, Arii K, Shimizu Y, Nakata H, Shinka T, Sanke T, Ichinose M. J Ultrasound Med. 2005:1635-40. [pmid: 16301719].
Evaluation of imaging-guided fine-needle percutaneous biopsy of renal masses. Jaff A, Molinie V, Mellot F, Guth A, Lebret T, Scherrer A. Eur Radiol. 2005:1721-6. [pmid: 15627185].
Evaluation of sonographically guided percutaneous core biopsy of renal masses. Caoili EM, Bude RO, Higgins EJ, Hoff DL, Nghiem HV. AJR Am J Roentgenol. 2002:373-8. [pmid: 12130435].
Color Duplex sonography vs computed tomography: accuracy in the preoperative evaluation of renal cell carcinoma. Spahn M, Portillo FJ, Michel MS, Siegsmund M, Gaa J, Alken P, Junemann KP. Eur Urol. 2001:337-42. [pmid: 11684852].
Visceral obesity is associated with better recurrence-free survival after curative surgery for Japanese patients with localized clear cell renal cell carcinoma. Kaneko G, Miyajima A, Yuge K, Yazawa S, Mizuno R, Kikuchi E, Jinzaki M, Oya M. Jpn J Clin Oncol. 2014.
Imaging of renal lesions: evaluation of fast MRI and helical CT. Walter C, Kruessell M, Gindele A, Brochhagen HG, Gossmann A, Landwehr P. Br J Radiol. 2003:696-703. [pmid: 14512329].
Renal masses--evaluation by amplitude coded colour Doppler sonography and multiphasic contrast-enhanced CT. Riccabona M, Szolar D, Preidler K, Uggowitzer M, Kugler C, Dorfler O, Schreyer HH. Acta Radiol. 99:457-61.
Characterization and staging of renal tumors: significance of MRI diagnostics. Kalinka A, Gerlach A, Arlart IP, Gunes N, Hauser TK, Wurstlin S, Bosse A. Rofo. 2006:298-305. [pmid: 16508837].
Dynamic computed tomography and color Doppler ultrasound of renal parenchymal neoplasms: correlations with histopathological findings. Kitamura H, Fujimoto H, Tobisu K, Mizuguchi Y, Maeda T, Matsuoka N, Komiyama M, Nakagawa T, Kakizoe T. Jpn J Clin Oncol. 2004:78-81. [pmid: 15067100].
Renal cancer. Fernandez Mena FJ, Moreno Torres C. Arch Esp Urol. 2001:541-54. [pmid: 11512398].
Renal cell carcinoma: clinical experience and technical success with radio-frequency ablation of 42 tumors. Gervais DA, McGovern FJ, Arellano RS, McDougal WS, Mueller PR. Radiology. 2003:417-24. [pmid: 12563135].
Small incidental renal tumors. Evaluation and biological parameters. Remzi M, Memarsadeghi M. Urologe A. 480. 2007:478-4. [pmid: 17447049].
Renal cell carcinoma: incidental detection and pathological staging. Siow WY, Yip SK, Ng LG, Tan PH, Cheng WS, Foo KT. J R Coll Surg Edinb. 2000:291-5. [pmid: 11077776].
Characterization and staging of renal tumors: Significance of MRI diagnostics. Charakterisierung und staging von nierentumoren: Bedeutung der MRT-diagnostik. Kalinka A, Gerlach A, Arlart IP, Gunes N, Hauser T-K, Wurstlin S, Bosse A. RoFo Fortschr Geb Rontgenstr Bildgebenden Verfahren. 2006:298-305.
Incidental detection of preclinical renal tumors with electron beam computed tomography: Report of 26 consecutive operated patients. Mitchell TL, Pippin JJ, Devers SM, Kimball TE, Gibbons LW, Cooper LL, Gonzalez-Dunn V, Cooper KH. J Comput Assisted Tomogr. 2000:843-845.
Identification of the MN/CA9 protein as a reliable diagnostic biomarker of clear cell carcinoma of the kidney. Liao S-Y, Aurelio ON, Jan K, Zavada J, Stanbridge EJ. CANCER RES. 97:2827-2831.
Surgical treatment of kidney cancer in elderly. Maricic A, Sotosek S, Markic D, Spanjol J, Krpina K, Rahelic D, Materljan M. Coll Antropol. 2014:1225-7. [pmid: 25842764].
Multi-quadrant biopsy technique improves diagnostic ability in large heterogeneous renal masses. Abel EJ, Heckman JE, Hinshaw L, Best S, Lubner M, Jarrard DF, Downs TM, Nakada SY, Lee FT Jr, Huang W, Ziemlewicz T. J Urol. 2015.
A propensity-matched comparison of perioperative complications and of chronic kidney disease between robot-assisted laparoscopic partial nephrectomy and radiofrequency ablative therapy. Kim SH, Lee ES, Kim HH, Kwak C, Ku JH, Lee SE, Hong SK, Jeong CW, Kim SH, Cho JY, Hwang SI, Lee HJ, Byun SS. Asian J Surg. 2014.
Quality of life survey following laparoscopic and open radical nephrectomy. Acar C, Bilen C, Bayazit Y, Aslan G, Koni A, Basok E, Kaplan M. Urol J. 2014:1944-50. [pmid: 25433472].
The diagnostic accuracy of percutaneous renal needle core biopsy and its potential impact on the clinical management of renal cortical neoplasms. Gellert LL, Mehra R, Chen YB, Gopalan A, Fine SW, Al-Ahmadie H, Reuter VE, Tickoo SK. Arch Pathol Lab Med. 2014:1673-9. [pmid: 25427045].
Improved outcome with combined US/CT guidance as compared to US guidance in percutaneous radiofrequency ablation of small renal masses. Andersson M, Hashimi F, Lyrdal D, Lundstam S, Hellstrom M. Acta Radiol. 2014.
Perioperative outcomes for laparoscopic radical nephrectomies performed on &gt;/= 10 cm tumors. Ouellet S, Carmel M, Martel A, Sabbagh R. Can J Urol. 2014:7487-95. [pmid: 25347376].
Cell-free RNA content in urine as a possible molecular diagnostic tool for clear cell renal cell carcinoma. Zhao A, Peoc'h M, Cottier M, Genin C, Mottet N, Li G. Int J Cancer. 2015:2610-5. [pmid: 25379634].
Qualitative and quantitative MDCT features for differentiating clear cell renal cell carcinoma from other solid renal cortical masses. Lee-Felker SA, Felker ER, Tan N, Margolis DJ, Young JR, Sayre J, Raman SS. AJR Am J Roentgenol. 2014:W516-24. [pmid: 25341166].
Discovery and validation of urinary biomarkers for detection of renal cell carcinoma. Frantzi M, Metzger J, Banks RE, Husi H, Klein J, Dakna M, Mullen W, Cartledge JJ, Schanstra JP, Brand K, Kuczyk MA, Mischak H, Vlahou A, Theodorescu D, Merseburger AS. J Proteomics. 2014:44-58. [pmid: 24374379].
Visceral fat accumulation is associated with different pathological subtypes of renal cell carcinoma (RCC): A multicentre study in China. Wang H-K, Song X-S, Cheng Y, Qu Y-Y, Zhang S-L, Dai B, Zhang H-L, Shen Y-J, Zhu Y-P, Shi G-H, Qin X-J, Ma C-G, Lin G-W, Xiao W-J, Zhu Y, Ye D-W. BJU Int. 2014:496-502. [pmid: 25383400].
Utility of fine-needle aspiration and core biopsy with touch preparation in the diagnosis of renal lesions. Scanga LR, Maygarden SJ. Cancer Cytho. 2014:182-190.
Comparison of prognosis between patients with renal cell carcinoma on hemodialysis and those with renal cell carcinoma in the general population. Hashimoto Y, Takagi T, Kondo T, Iizuka J, Kobayashi H, Omae K, Yoshida K, Tanabe K. Int J Clin Oncol. 2015.
Expression pattern of autophagy-related markers in non-metastatic clear cell renal cell carcinoma: association with disease recurrence following radical nephrectomy. Nishikawa M, Miyake H, Liu B, Fujisawa M. J Cancer Res Clin Oncol. 2015.
Preoperative serum cholesterol is an independent prognostic factor for patients with renal cell carcinoma (RCC). De Martino M, Leitner CV, Seemann C, Hofbauer SL, Lucca I, Haitel A, Shariat SF, Klatte T. BJU Int. 2015:397-404. [pmid: 24698164].
Notch1 predicts recurrence and survival of patients with clear-cell renal cell carcinoma after surgical resection. An H, Zhu Y, Xu L, Chen L, Lin Z, Xu J. Urology. 2015:483.e9-483.e14. [pmid: 25559729].
Snail predicts recurrence and survival of patients with localized clear cell renal cell carcinoma after surgical resection. Liu W, Liu Y, Liu H, Zhang W, An H, Xu J. Urol Oncol Semin Orig Invest. 2015:69e1-69e10.
Nomograms incorporating serum C-reactive protein effectively predict mortality before and after surgical treatment of renal cell carcinoma. Hsiao W, Herrel LA, Yu C, Kattan MW, Canter DJ, Carthon BC, Ogan K, Master VA. Int J Urol. 2015:264-270. [pmid: 25428139].
Survival in patients with clear cell renal cell carcinoma is predicted by HIF-1(alpha) expression. Minardi D, Lucarini G, Santoni M, Mazzucchelli R, Burattini L, Conti A, Principi E, Bianconi M, Scartozzi M, Milanese G, Di Primio R, Montironi R, Cascinu S, Muzzonigro G. Anticancer Res. 2015:433-438. [pmid: 25550584].
Partial and Radical Nephrectomy for Unilateral Synchronous Multifocal Renal Cortical Tumors. Mano R, Kent M, Larish Y, Winer AG, Chevinsky MS, Hakimi AA, Sternberg IA, Sjoberg DD, Russo P. Urology. 2015.
Survival advantage of partial over radical nephrectomy in patients presenting with localized renal cell carcinoma. Roos FC, Steffens S, Junker K, Janssen M, Becker F, Wegener G, Brenner W, Steinestel J, Schnoeller TJ, Schrader M, Hofmann R, Thuroff JW, Kuczyk MA, Wunderlich H, Siemer S, Hartmann A, Stockle M, Schrader AJ. BMC Cancer. 2014.
Predictive factors for the development of chronic renal insufficiency after renal surgery: A multicenter study. Choi YS, Park YH, Kim Y-J, Kang SH, Byun S-S, Hong S-H. Int Urol Nephrol. 2014:681-686. [pmid: 24072453].
Small tumour size is associated with new-onset chronic kidney disease after radical nephrectomy in patients with renal cell carcinoma. Jeon HG, Choo SH, Sung HH, Jeong BC, Seo SI, Jeon SS, Choi H-Y, Lee HM. Eur J Cancer. 2014:64-69. [pmid: 24060356].
Predictive factors for postoperative complications in radical nephrectomy for renal cell carcinoma. Wongvittavas N, Panumatrassamee K, Opanuraks J, Usawachintachit M, Ratchanon S, Tantiwongse K, Bunyaratavej C, Santingamkun A, Prasopsanti K. Asian Biomed. 2014:763-769.
Outcome of nephrectomies in Malta since 2000. Busuttil G, Bugeja S, Zammit P, Mattocks S, German K. Malta Med J. 2014:9-14.
Clinicopathological characteristics and outcomes of surgically excised renal masses in African Americans. Qi P, Tsivian M, Abern MR, Passoni NM, McGinley KF, Polascik TJ. Urol Oncol Semin Orig Invest. 2014:555-560.
Pre-existing type 2 diabetes mellitus is an independent risk factor for mortality and progression in patients with renal cell carcinoma. Vavallo A, Simone S, Lucarelli G, Rutigliano M, Galleggiante V, Grandaliano G, Gesualdo L, Campagna M, Cariello M, Ranieri E, Pertosa G, Lastilla G, Selvaggi FP, Ditonno P, Battaglia M. Medicine. 2014.
A population-based competing-risks analysis of survival after nephrectomy for renal cell carcinoma. Bianchi M, Gandaglia G, Trinh Q-D, Hansen J, Becker A, Abdollah F, Tian Z, Lughezzani G, Roghmann F, Briganti A, Montorsi F, Karakiewicz PI, Sun M. Urol Oncol Semin Orig Invest. 2014:46.e1-46.e7.
The effect of gender and age on kidney cancer survival: Younger age is an independent prognostic factor in women with renal cell carcinoma. Rampersaud EN, Klatte T, Bass G, Patard J-J, Bensaleh K, Bohm M, Allhoff EP, Cindolo L, De La Taille A, Mejean A, Soulie M, Bellec L, Christophe Bernhard J, Pfister C, Colombel M, Belldegrun AS, Pantuck AJ, George D. Urol Oncol Semin Orig Invest. 2014:30.e9-30.e13.
Nephron-sparing surgery is superior to radical nephrectomy in preserving renal function benefit even when expanding indications beyond the traditional 4-cm cutoff. Pignot G, Bigot P, Bernhard J-C, Bouliere F, Bessede T, Bensalah K, Salomon L, Mottet N, Bellec L, Soulie M, Ferriere J-M, Pfister C, Drai J, Colombel M, Villers A, Rigaud J, Bouchot O, Montorsi F, Bertini R, Belldegrun AS, Pantuck AJ, Patard J-J. Urol Oncol Semin Orig Invest. 2014:1024-1030.
Renal surgery for kidney cancer in Germany 2005-2006: length of stay, risk of postoperative complications and in-hospital death. Stang A, Buchel C. BMC Urol. 2014:74. [pmid: 25217295].
CT perfusion in the characterisation of renal lesions: an added value to multiphasic CT. Mazzei FG, Mazzei MA, Cioffi Squitieri N, Pozzessere C, Righi L, Cirigliano A, Guerrini S, D'Elia D, Ambrosio MR, Barone A, del Vecchio MT, Volterrani L. Biomed Res Int. 2014:135013. [pmid: 25184133].
Cancer-free survival and local tumor control after impendence-based radiofrequency ablation of biopsy-proven renal cell carcinomas with a minimum of 1-year follow-up. Forauer AR, Dewey BJ, Seigne JD. Urol Oncol. 2014:869-76. [pmid: 24946958].
Does gender influence morbidity or mortality in the surgical treatment of renal masses?. Minnillo BJ, Horowitz A, Finelli A, Alibhai SM, Ponsky LE, Abouassaly R. Can Urol Assoc J. 2014:E311-6. [pmid: 24940456].
Predictive factors for benign lesions in partially or radically resected kidneys in a single independent cancer center. Soga N, Ogura Y, Hayashi N. Curr Urol. 2013:70-4. [pmid: 24917762].
The 1-year decline in estimated glomerular filtration rate (eGFR) after radical nephrectomy in patients with renal masses and matched living kidney donors is the same. Hew MN, Opondo D, Cordeiro ER, van Donselaar-van der Pant KA, Bemelman FJ, Idu MM, de la Rosette JJ, Laguna MP. BJU Int. 2014:E49-55. [pmid: 24053637].
Trends in renal function after radical nephrectomy: a multicentre analysis. Chung JS, Son NH, Byun SS, Lee SE, Hong SK, Jeong CW, Lee SC, Chae DW, Choi WS, Park YH, Hong SH, Kim YJ, Kang SH. BJU Int. 2014:408-15. [pmid: 23937424].
Perioperative mortality and associated factors in patients undergoing radical nephrectomy. Diaz-Hung AM, Garcia-Perdomo HA, Carbonell-Gonzalez J, Castillo-Cobaleda DF, Garcia-Angel AF. Actas Urol Esp. 2013:608-12. [pmid: 23602503].
Iatrogenic splenectomy during nephrectomy for renal tumors. Wang JK, Tollefson MK, Kim SP, Boorjian SA, Leibovich BC, Lohse CM, Cheville JC, Thompson RH. Int J Urol. 2013:896-902. [pmid: 23379901].
MR imaging of renal cortical tumours: qualitative and quantitative chemical shift imaging parameters. Karlo CA, Donati OF, Burger IA, Zheng J, Moskowitz CS, Hricak H, Akin O. Eur Radiol. 2013:1738-44. [pmid: 23300041].
Overall mortality after radical nephrectomy in patients aged over 80 years with renal cancer: a retrospective study on preoperative prognostic factors. Brassart E, Lebdai S, Berger J, Traore S, Bernhard JC, Fardoun T, Muller G, Patard JJ, Azzouzi AR, Bigot P. Int J Urol. 2012:626-32. [pmid: 22458762].
Partial nephrectomy for renal masses &gt;/= 7 cm: technical, oncological and functional outcomes. Long CJ, Canter DJ, Kutikov A, Li T, Simhan J, Smaldone M, Teper E, Viterbo R, Boorjian SA, Chen DY, Greenberg RE, Uzzo RG. BJU Int. 2012:1450-6. [pmid: 22221502].
Prospective study comparing two techniques of renal clamping in laparoscopic partial nephrectomy: impact on perioperative parameters. Imbeault A, Pouliot F, Finley DS, Shuch B, Dujardin T. J Endourol. 2012:509-14. [pmid: 21823983].
Comparison of rates and risk factors for development of osteoporosis and fractures after radical or partial nephrectomy. Bagrodia A, Mehrazin R, Bazzi WM, Silberstein J, Malcolm JB, Stroup SP, Raheem O, Wake RW, Kane CJ, Patterson AL, Wan JY, Derweesh IH. Urology. 2011:614-9. [pmid: 21777959].
Oncologic long-term outcome of elective nephron-sparing surgery versus radical nephrectomy in patients with renal cell carcinoma stage pT1b or greater in a matched-pair cohort. Roos FC, Brenner W, Muller M, Schubert C, Jager WJ, Thuroff JW, Hampel C. Urology. 2011:803-8. [pmid: 21145093].
Renal function and oncologic outcomes in nephron sparing surgery for renal masses in solitary kidneys. Lee DJ, Hruby G, Benson MC, McKiernan JM. World J Urol. 2011:343-8. [pmid: 20623290].
The role of percutaneous needle biopsy in differentiation of renal tumors. Izumi K, Narimoto K, Sugimoto K, Kobori Y, Maeda Y, Mizokami A, Koh E, Yamada T, Yano S, Namiki M. Jpn J Clin Oncol. 2010:1081-6. [pmid: 20601495].
Predictive factors for ipsilateral recurrence after nephron-sparing surgery in renal cell carcinoma. Bernhard JC, Pantuck AJ, Wallerand H, Crepel M, Ferriere JM, Bellec L, Maurice-Tison S, Robert G, Albouy B, Pasticier G, Soulie M, Lopes D, Lacroix B, Bensalah K, Pfister C, Thuret R, Tostain J, De La Taille A, Salomon L, Abbou C, Colombel M, Belldegrun AS, Patard JJ. Eur Urol. 2010:1080-6. [pmid: 20188458].
Laparoscopic radical nephrectomy for renal cell carcinoma: oncological outcomes at 10 years or more. Berger A, Brandina R, Atalla MA, Herati AS, Kamoi K, Aron M, Haber GP, Stein RJ, Desai MM, Kavoussi LR, Gill IS. J Urol. 2009:2172-6. [pmid: 19758651].
Partial versus radical nephrectomy in patients with adverse clinical or pathologic characteristics. Jeldres C, Patard JJ, Capitanio U, Perrotte P, Suardi N, Crepel M, Ficarra V, Cindolo L, de La Taille A, Tostain J, Pfister C, Albouy B, Colombel M, Mejean A, Lang H, Jacqmin D, Bernhard JC, Ferriere JM, Bensalah K, Karakiewicz PI. Urology. 2009:1300-5. [pmid: 19376568].
Preservation of renal function following partial or radical nephrectomy using 24-hour creatinine clearance. Clark AT, Breau RH, Morash C, Fergusson D, Doucette S, Cagiannos I. Eur Urol. 2008:143-49. [pmid: 18407401].
Nephron-sparing surgery versus radical nephrectomy in the treatment of renal cell carcinoma up to 7 cm. Antonelli A, Zani D, Cozzoli A, Nicolai M, Zanotelli T, Perucchini L, Cosciano Cunico S, Simeone C. Urologia. 2007:173-179. [pmid: 21086397].
Management of renal tumors by image-guided radiofrequency ablation: experience in 105 tumors. Breen DJ, Rutherford EE, Stedman B, Roy-Choudhury SH, Cast JE, Hayes MC, Smart CJ. Cardiovasc Intervent Radiol. 2007:936-42. [pmid: 17573550].
Renal cell carcinoma of 4 cm or less: an appraisal of its clinical presentation and contemporary surgical management. Lee VT, Yip SK, Tan PH, Siow WY, Lau WK, Cheng CW. Asian J Surg. 2006:40-3. [pmid: 16428098].
Prognostic significance of morphologic parameters in renal cell carcinoma. Erdogan F, Demirel A, Polat O. Int J Clin Pract. 2004:333-6. [pmid: 15161115].
Clinicopathological factors predicting recurrence of N0M0 renal cell carcinoma: a case series analysis of one facility. Masuda A, Aoki M, Tokunaga M, Usui Y, Abe T, Miyakita H, Kinoshita H, Kawamura N, Terachi T. Int J Urol. 2003:511-7. [pmid: 14516397].
Renal cell carcinoma in the solitary kidney: an analysis of complications and outcome after nephron sparing surgery. Ghavamian R, Cheville JC, Lohse CM, Weaver AL, Zincke H, Blute ML. J Urol. 2002:454-9. [pmid: 12131287].
Nephron sparing surgery for localized renal cell carcinoma: impact of tumor size on patient survival, tumor recurrence and TNM staging. Hafez KS, Fergany AF, Novick AC. J Urol. 99:1930-3.
CT-guided bipolar and multipolar radiofrequency ablation (RF Ablation) of renal cell carcinoma: Specific technical aspects and clinical results. Sommer CM, Lemm G, Hohenstein E, Bellemann N, Stampfl U, Goezen AS, Rassweiler J, Kauczor HU, Radeleff BA, Pereira PL. Cardiovasc Intervent Radiol. 2013:731-737. [pmid: 22926302].
Changes in renal function after laparoscopic partial nephrectomy: Comparison with laparoscopic radical nephrectomy. Kang SH, Rhew HY, Kim TS. Korean J Urol. 2013:22-25. [pmid: 23362443].
Partial nephrectomy for selected renal cortical tumours of (greater-than or equal to)7 cm. Karellas ME, Obrien MF, Jang TL, Bernstein M, Russo P. BJU Int. 2010:1484-1487. [pmid: 20518765].
The significance of serum ferritin level in renal cell carcinoma. Bobrek Hucrelikanserde serum ferritin duzeyinin onemi. Erdemir F, Parlaktas BS, Uluocak N, Ozcan F, Celik M, Gokce O. Turk Urol Derg. 2005:479-484.
Our initial experiences with laparoscopic nephrectomy. Laparoskopik nefrektomide baslangic deneyimlerimiz. Kural AR, Demirkesen O, Akpinar H, Tufek I, Yalcin V, Ozkan B. Turk Urol Derg. 2004:414-421.
Carcinoma of the kidney: About 47 cases: Cancer du rein: A propos de 47 cas. Janane A, Hachi H, Tijami F, Jalil A, Othmani M, Boughtab A, Benjelloun S, Ahyoud F, Souadka A. Ann Urol. 2003:57-60.
Renal cell carcinoma - A retrospective study of 368 patients. Nyrekreft - En retrospektiv undersokelse av 368 pasienter. Beisland C, Medby PC, Beisland HO. Tidsskr Nor Laegeforen. 2002:2431-2435. [pmid: 12448109].
Renal cell carcinoma. Experience in the treatment and follow-up in 118 patients. Experiencia en el tr tratamiento y seguimiento de 118 pacientes con diagnostico de adenocarcinoma de celulas claras de rinon. Meza BO, Castillo GDO, Ochoa JM. Med Interna Mex. 2002:214-219.
The cancer of kidney. A report of 170 cases. Le cancer du rein. A propos de 170 cas. Fekak H, Bennani S, Taha A, Rabii R, Joual A, Sarf S, Hafiani M, El Mrini M, Benjelloun S. Ann Urol. 2001:249-256.
Retrospective epidemiological study of renal cancer. Cancer renal: Estudio epidemiologico retrospectivo. Ale R, Sivori F, Corbetta JP, Attar J, Petrone J, Casal JM, Grippo L, Deparci A, Gonzalez G, Garcik A, Krenz R, Verdinelli J. Prensa Med Argent. 2000:806-813.
Lumbar radical nephrectomy. Lumbale radikale nephrektomie: Eine retrospektive analyse von 186 fallen. Wiedemann A, Holtmann G, Diekmann W-P, Zumbe J. Urologe Ausg A. 2000:154-159.
Renal cancer in adults based on a series of 68 cases. Cancer du rein de l'adulte. A propos de 68 cas. Moudouni SM, Tazi Mokha K, Nouri M, Lrhorfi MH, Koutani A, Iben Attya Andaloussi A, Hachimi M, Lakrissa A. Ann Urol. 99:395-401.
Trends in renal function after radical nephrectomy: A multicentre analysis. Chung JS, Son NH, Byun S-S, Lee SE, Hong SK, Jeong CW, Lee SC, Chae D-W, Choi WS, Park YH, Hong SH, Kim YJ, Kang SH. BJU Int. 2014:408-415. [pmid: 23937424].
Local recurrence after radical nephrectomy for kidney cancer: Management and prediction of outcomes. A multi-institutional study. Paparel P, Bigot P, Matillon X, Bensalah K, Salomon L, Baumert H, Bastide C, Thuret R, Karsenty G, Long JA, Ammi M, Bessede T, Bin S, Roux A, Escudier B, Rioux Leclercq N, Pignot G, Soulie M, Patard J-J. J Surg Oncol. 2014:126-131. [pmid: 24174430].

## Patients on Hemodialysis

De novo renal carcinoma in renal transplant recipients: effect of early treatment. Tillou X, Demailly M, Hakami F, Westeel PF, Saint F, Petit J. Transplant Proc. 2009:3314-6. [pmid: 19857739].
Renal cell carcinoma in patients with end-stage renal disease: relationship between histological type and duration of dialysis. Nouh MA, Kuroda N, Yamashita M, Hayashida Y, Yano T, Minakuchi J, Taniguchi S, Nomura I, Inui M, Sugimoto M, Kakehi Y. BJU Int. 2010:620-7. [pmid: 19747356].
Prevalence of renal cell carcinoma in patients with autosomal dominant polycystic kidney disease and chronic renal failure. Hajj P, Ferlicot S, Massoud W, Awad A, Hammoudi Y, Charpentier B, Durrbach A, Droupy S, Benoit G. Urology. 2009:631-4. [pmid: 19616833].
Comparison of prognosis between patients with renal cell carcinoma on hemodialysis and those with renal cell carcinoma in the general population. Hashimoto Y, Takagi T, Kondo T, Iizuka J, Kobayashi H, Omae K, Yoshida K, Tanabe K. Int J Clin Oncol. 2015.
Renal cell carcinoma in patients with end-stage renal disease has favorable overall prognosis. Shrewsberry AB, Osunkoya AO, Jiang K, Westby R, Canter D, Pattaras J, Turgeon N, Master VA, Ogan K. Clin Transplant. 2014:211-216. [pmid: 24494735].

## Patients with familial conditions

Image guided percutaneous probe ablation for renal tumors in 65 solitary kidneys: functional and oncological outcomes. Altunrende F, Autorino R, Hillyer S, Yang B, Laydner H, White MA, Khanna R, Isac W, Spana G, Stein RJ, Haber GP, O'Malley CM, Remer EM, Kaouk JH. J Urol. 2011:35-41. [pmid: 21571336].
Is it safe and effective to treat complex renal cysts by the laparoscopic approach?. Pinheiro T, Sepulveda F, Natalin RH, Metrebian E, Medina R, Goldman SM, Ortiz V, Andreoni C. J Endourol. 2011:471-6. [pmid: 21361825].
Percutaneous cryoablation of renal masses: impact of patient selection and treatment parameters on outcomes. Vricella GJ, Haaga JR, Adler BL, Dean Nakamoto, Cherullo EE, Flick S, Ponsky LE. Urology. 2011:649-54. [pmid: 21185065].
The prognostic value of the width of the surgical margin in the enucleoresection of small renal cell carcinoma: an intermediate-term follow-up. Jeong SJ, Kim KT, Chung MS, Hong SK, Byun SS, Lee SE. Urology. 2010:587-92. [pmid: 20346491].
Partial nephrectomy for renal tumours: the Singapore General Hospital experience. Yip SK, Cheng WS, Tan BS, Li MK, Foo KT. J R Coll Surg Edinb. 99:156-60.

## No Original Data

Controversies of partial nephrectomy for renal cell carcinoma : survey in the German-speaking countries. Tietze S, Herms M, Behrendt W, Krause J, Hamza A. Urologe A. 2014:1181-5. [pmid: 24824467].
The challenges of managing urological malignancy in the elderly. Abu-Ghanem Y, Dhesi JK, Challacombe BJ. BJU Int. 2014:12-5. [pmid: 24417883].
Radiofrequency ablation of kidney tumors. Souteyrand P, Chagnaud C, Lechevallier E, Andre M. Prog Urol. 2013:1163-7. [pmid: 24176403].
Initial experience with arterial spin-labeling MR imaging to assess histology of renal masses. Masarapu V, Kim HL. Quant Imaging Med Surg. 2013:130-1. [pmid: 23833725].
Cost-utility analysis of radical nephrectomy versus partial nephrectomy in the management of small renal masses: Adjusting for the burden of ensuing chronic kidney disease. Klinghoffer Z, Tarride JE, Novara G, Ficarra V, Kapoor A, Shayegan B, Braga LH. Can Urol Assoc J. 2013:108-13. [pmid: 23671525].
The management of a clinical t1b renal tumor in the presence of a normal contralateral kidney. Weight CJ, Miller DC, Campbell SC, Derweesh IH, Lane BR, Messing EM. J Urol. 2013:1198-202. [pmid: 23337186].
Nephron-sparing treatments for kidney cancer. Casuscelli J, Fischereder M, Gratzke C, Staehler M, Stief CG. MMW Fortschr Med. 2012:45-6. 48. [pmid: 23297539].
Re: Features associated with recurrence beyond 5 years after nephrectomy and nephron-sparing surgery for renal cell carcinoma: development and internal validation of a risk model (PRELANE score) to predict late recurrence based on a large multicenter database (CORONA/SATURN project). Taneja SS. J Urol. 2013:67-8.
Lymph node excision for renal cancer. Montgomery JS, Leibovich BC. J Urol. 2013:419-21. [pmid: 23159583].
A novel technique to limit renal warm ischaemia time during laparoscopic partial nephrectomy. Sapre N, Corcoran NM, Costello AJ, Agarwal D. BJU Int. 2012:1216-9. [pmid: 23020701].
Laparoscopic cryotherapy for renal tumours. Grange P, Rouse P, Kouriefs C, Rao A, Karamanolakis D, Roy A, Arya M. BJU Int. 2012:808-17. [pmid: 22339994].
Focal therapy for renal mass lesions: where do we stand in 2012?. Rane A, Stein R, Cadeddu J. BJU Int. 2012:491-2. [pmid: 22233234].
Application of gasless laparoendoscopic single port surgery, GasLESS, to partial nephrectomy for renal cell carcinoma: GasLESS-clampless partial nephrectomy as a multiply satisfactory method. Kihara K. Int J Urol. 2012:3-4. [pmid: 22168271].
Zero-ischaemia robotic and laparoscopic partial nephrectomy (PN). Patil MB, Gill IS. BJU Int. 2011:780-92. [pmid: 21854529].
Preferred management option for small renal masses: laparoscopic partial nephrectomy. Kapoor A. Can Urol Assoc J. 2010:139-41. [pmid: 20368900].
Active surveillance as the preferred management option for small renal masses. Rendon RA. Can Urol Assoc J. 2010:136-8. [pmid: 20368899].
Determining failure after renal ablative therapy for renal cell carcinoma: false-negative and false-positive imaging findings. Matin SF. Urology. 2010:1254-7. [pmid: 20299082].
Open to debate. The motion: Cryotherapy is an efficient alternative for kidney cancer. Guazzoni G, Nava L, Lazzeri M, Cestari A, Volpe A, Kirkali Z. Eur Urol. 2010:168-70. [pmid: 19854568].
Current role of robotic assisted partial nephrectomy. Cestari A, Guazzoni G, Buffi NM, Scapaticci E, Zanoni M, Fabbri F, Gadda G, Rigatti P. Arch Ital Urol Androl. 2009:76-9. [pmid: 19760860].
Reporting standards for percutaneous thermal ablation of renal cell carcinoma. Clark TW, Millward SF, Gervais DA, Goldberg SN, Grassi CJ, Kinney TB, Phillips DA, Sacks D, Cardella JF. J Vasc Interv Radiol. 2009:S409-16. [pmid: 19560028].
Robotic-assisted partial nephrectomy: surgical technique using a 3-arm approach and sliding-clip renorrhaphy. Cabello JM, Benway BM, Bhayani SB. Int Braz J Urol. 2009:199-203. discussion 203-4. [pmid: 19409124].
Robotic-assisted partial nephrectomy. Patel MN, Bhandari M, Menon M, Rogers CG. BJU Int. 2009:1296-311. [pmid: 19402830].
Robot-assisted partial nephrectomy. Sairam K, Dasgupta P. BJU Int. 2008:266-7. [pmid: 18485045].
Evolution to nephron-sparing surgery for renal cell carcinoma. O'Malley PJ, Bruyere F, Costello AJ. ANZ J Surg. 2007:2-3. [pmid: 17295809].
Organ-preserving endoscopic kidney cancer resection. Heinrich E, Egner T, Noe M, Schiefelbein F, Schoen G. Eur Urol. 2006:732-7. [pmid: 16930815].
Laparoscopic partial nephrectomy: contemporary technique and outcomes. Haber GP, Gill IS. Eur Urol. 2006:660-5. [pmid: 16504373].
Percutaneous CT-guided radiofrequency ablation of renal neoplasms: factors influencing success. Marshall FF. J Urol. 2005:1782.
Laparoscopic tumor nephrectomy. Janetschek G, al-Zachrani H, Vrabec G, Leeb K. Urologe A. 2002:101-6. [pmid: 11993086].
Matched comparison of radical nephrectomy vs nephron-sparing surgery in patients with unilateral renal cell carcinoma and a normal contralateral kidney. Lau WK, Blute ML, Weaver AL, Torres VE, Zincke H. Mayo Clin Proc. 2000:1236-42. [pmid: 11126830].
Impact of kidney cancer surgery on oncologic and kidney functional outcomes. Han JS, Huang WC. Am J Kidney Dis. 2011:846-854. [pmid: 21956016].
Renal artery pseudoaneurysm after partial nephrectomy: Three case reports and a literature review. Albani JM, Novick AC. Urology. 2003:227-231. [pmid: 12893324].
A tumor of the kidney which should not be misdiagnosed. Une tumeur du rein a ne pas meconnaitre. Ismail O, Tissier F, Colin D, Flam T, Vieillefond A, De Pinieux G. Ann Pathol. 2002:489-490. [pmid: 12594397].
A prospective, randomised EORTC intergroup phase 3 study comparing the oncologic outcome of elective nephron-sparing surgery and radical nephrectomy for low-stage renal cell carcinoma. Taneja SS. Journal of urology. 2011:1637-8. [pmid: 22088685].
Management of small indeterminate renal tumours: is there a case for needle biopsy?. Khan AA, Shergill IS, Gujral SS, Timoney AG. BJU Int. 2007:1-3. [pmid: 17433032].
To biopsy or not to biopsy: Results of 1000 renal mass biopsies at a single institution. Deshmukh SM, Dhyani M, McGovern FJ, McDougal WS, Olumi AF, Dahl DM, Arellano R, Samir A, Blute ML, Feldman AS. J Urol. 2013:e437.
Treatment of Exophytic Renal Cancer Smaller than 3 cm: Surgery versus Active Surveillance. Lallas CD, Trabulsi EJ, Kaffenberger SD, Touijer KA. J Urol. 2015.

## Study address KQ1 but does not include imaging or one element from at least 2 of the categories - Demographic characteristics, Clinical, Blood/urine test

Comparative Studies of the Proteome, Glycoproteome, and N-Glycome of Clear Cell Renal Cell Carcinoma Plasma before and after Curative Nephrectomy. Gbormittah FO, Lee LY, Taylor K, Hancock WS, Iliopoulos O. J Proteome Res. 2014.
The impact of tumour size on the probability of synchronous metastasis and survival in renal cell carcinoma patients: a population-based study. Ingimarsson JP, Sigurdsson MI, Hardarson S, Petursdottir V, Jonsson E, Einarsson GV, Gudbjartsson T. BMC Urol. 2014:72. [pmid: 25174263].
Diabetes mellitus as a risk factor for high grade renal cell carcinoma. Otunctemur A, Ozbek E, Sahin S, Dursun M, Besiroglu H, Koklu I, Erkoc M, Danis E, Bozkurt M, Gurbuz A. Asian Pac J Cancer Prev. 2014:3993-6. [pmid: 24935606].
Diagnostic and prognostic role of preoperative circulating CA 15-3, CA 125, and beta-2 microglobulin in renal cell carcinoma. Lucarelli G, Ditonno P, Bettocchi C, Vavallo A, Rutigliano M, Galleggiante V, Larocca AM, Castellano G, Gesualdo L, Grandaliano G, Selvaggi FP, Battaglia M. Dis Markers. 2014:689795. [pmid: 24692843].
Elevated serum-circulating RNA in patients with conventional renal cell cancer. Feng G, Li G, Gentil-Perret A, Tostain J, Genin C. Anticancer Res. 2008:321-6. [pmid: 18383864].
Cell-free RNA content in urine as a possible molecular diagnostic tool for clear cell renal cell carcinoma. Zhao A, Peoc'h M, Cottier M, Genin C, Mottet N, Li G. Int J Cancer. 2015:2610-5. [pmid: 25379634].

## Study does not give an adequate description of how complications and peri-operative outcomes were assessed

Enhanced computed tomography after partial nephrectomy in early postoperative period to detect asymptomatic renal artery pseudoaneurysm. Takagi T, Kondo T, Tajima T, Campbell SC, Tanabe K. Int J Urol. 2014:880-5. [pmid: 24712736].
Incidence of hypercoagulable events after image-guided percutaneous cryoablation of renal tumors: a single-center experience. Hartman JB, Bhojwani N, Corn DJ, Cooney MM, Haaga J, Ponsky L, Abouassaly R, Paspulati A, Prologo JD. J Vasc Interv Radiol. 2014:776-9. [pmid: 24656177].
Renal function outcomes following selective angioembolization for iatrogenic vascular lesions after partial nephrectomy. Gahan JC, Gaitonde M, Wadskier L, Cadeddu JA, Trimmer C. J Endourol. 2013:1516-9. [pmid: 24199730].
Sutureless hemostatic control during laparoscopic NSS for the treatment of small renal masses. Minervini A, Siena G, Tuccio A, Lapini A, Serni S, Carini M. Surg Innov. 2014:32-8. [pmid: 23575917].
Robot-assisted partial nephrectomy: a comparison of the transperitoneal and retroperitoneal approaches. Hughes-Hallett A, Patki P, Patel N, Barber NJ, Sullivan M, Thilagarajah R. J Endourol. 2013:869-74. [pmid: 23461381].
Rates of open versus laparoscopic and partial versus radical nephrectomy for T1a renal cell carcinoma: a population-based evaluation. Bianchi M, Becker A, Abdollah F, Trinh QD, Hansen J, Tian Z, Shariat SF, Perrotte P, Karakiewicz PI, Sun M. Int J Urol. 2013:1064-71. [pmid: 23418921].
Fast access and early ligation of the renal pedicle significantly facilitates retroperitoneal laparoscopic radical nephrectomy procedures: modified laparoscopic radical nephrectomy. Yang Q, Du J, Zhao ZH, Chen XS, Zhou L, Yao X. World J Surg Oncol. 2013:27. [pmid: 23363489].
Bipolar versus multipolar radiofrequency (RF) ablation for the treatment of renal cell carcinoma: differences in technical and clinical parameters. Sommer CM, Lemm G, Hohenstein E, Stampfl U, Bellemann N, Teber D, Rassweiler J, Kauczor HU, Radeleff BA, Pereira PL. Int J Hyperthermia. 2013:21-9. [pmid: 23311376].
Antimicrobial prophylaxis is not necessary in clean category minimally invasive surgery for renal and adrenal tumors: a prospective study of 373 consecutive patients. Kijima T, Masuda H, Yoshida S, Tatokoro M, Yokoyama M, Numao N, Saito K, Koga F, Fujii Y, Kihara K. Urology. 2012:570-5. [pmid: 22743261].
Clinical comparison between microporous polysaccharide hemispheres (MPH) and fibrin glue. Sakata R, Makiyama K, Noguchi G, Sano F, Nakaigawa N, Yao M, Kubota Y. Nihon Hinyokika Gakkai Zasshi. 2012:8-13. [pmid: 22568163].
Correlation of the RENAL nephrometry score with warm ischemia time after robotic partial nephrectomy. Altunrende F, Laydner H, Hernandez AV, Autorino R, Khanna R, White MA, Isac W, Spana G, Hillyer S, Yang B, Yakoubi R, Haber GP, Kaouk JH, Stein RJ. World J Urol. 2013:1165-9. [pmid: 22527672].
Integrating robotic partial nephrectomy to an existing robotic surgery program. Yuh B, Muldrew S, Menchaca A, Yip W, Lau C, Wilson T, Josephson D. Can J Urol. 2012:6193-200. [pmid: 22512965].
Multiple factor analysis of urine leaks after retroperitoneal laparoscopic partial nephrectomy. Wang P, Xia D, Wang S. Urol Int. 2011:411-5. [pmid: 22004840].
Implementation and external validation of Preoperative Aspects and Dimensions Used for an Anatomical (PADUA) score for predicting complications in 74 consecutive partial nephrectomies. Tyritzis SI, Papadoukakis S, Katafigiotis I, Adamakis I, Anastasiou I, Stravodimos KG, Alamanis C, Mitropoulos D, Constantinides CA. BJU Int. 2012:1813-8. [pmid: 21981696].
The comparison of three renal tumor scoring systems: C-Index, P.A.D.U.A., and R.E.N.A.L. nephrometry scores. Okhunov Z, Rais-Bahrami S, George AK, Waingankar N, Duty B, Montag S, Rosen L, Sunday S, Vira MA, Kavoussi LR. J Endourol. 2011:1921-4. [pmid: 21905850].
Does partial nephrectomy at an academic institution result in better outcomes?. Trinh QD, Schmitges J, Sun M, Sammon J, Shariat SF, Sukumar S, Zorn K, Bianchi M, Jeldres C, Perrotte P, Graefen M, Rogers CG, Peabody JO, Menon M, Karakiewicz PI. World J Urol. 2012:505-10. [pmid: 21904920].
The effect of insurance status on outcomes after partial nephrectomy. Abdo A, Trinh QD, Sun M, Schmitges J, Bianchi M, Sammon J, Shariat SF, Sukumar S, Zorn K, Jeldres C, Perrotte P, Rogers CG, Peabody JO, Menon M, Karakiewicz PI. Int Urol Nephrol. 2012:343-51. [pmid: 21894468].
Two-port robot-assisted vs standard robot-assisted laparoscopic partial nephrectomy: a matched-pair comparison. Arkoncel FR, Lee JW, Rha KH, Han WK, Jeoung HB, Oh CK. Urology. 2011:581-5. [pmid: 21783230].
Critical appraisal of the PADUA classification and assessment of the R.E.N.A.L. nephrometry score in patients undergoing partial nephrectomy. Hew MN, Baseskioglu B, Barwari K, Axwijk PH, Can C, Horenblas S, Bex A, Rosette JJ, Pes MP. J Urol. 2011:42-6. [pmid: 21571340].
Robot-assisted partial nephrectomy: evaluation of learning curve for an experienced renal surgeon. Haseebuddin M, Benway BM, Cabello JM, Bhayani SB. J Endourol. 2010:57-61. [pmid: 19958156].
Current role of robotic assisted partial nephrectomy. Cestari A, Guazzoni G, Buffi NM, Scapaticci E, Zanoni M, Fabbri F, Gadda G, Rigatti P. Arch Ital Urol Androl. 2009:76-9. [pmid: 19760860].
Retroperitoneal laparoscopic and open radical nephrectomy for T1 renal cell carcinoma. Wang L, Wang L, Yang Q, Xiao C, Sun Y. J Endourol. 2009:1509-12. [pmid: 19673654].
Outcomes of laparoscopic partial nephrectomy after fellowship training. Shah SK, Matin SF, Singer EA, Eichel L, Kim HL. JSLS. 2009:154-9. [pmid: 19660208].
Prospective comparative study between retroperitoneoscopic and hand-assisted laparoscopic approach for radical nephrectomy. Tobias-Machado M, Ravizzini PI, Pertusier LO, Pedroso E, Wroclawski ER. Int Braz J Urol. 2009:284-91. discussion 291-2. [pmid: 19538763].
Decision tree for laparoscopic partial nephrectomy versus laparoscopic renal cryoablation for small renal masses. Nisbet AA, Rieder JM, Tran VQ, Williams SG, Chien GW. J Endourol. 2009:431-7. [pmid: 19265467].
Impact of renal lesion size on perioperative and pathologic outcomes in patients undergoing laparoscopic partial nephrectomy. Eng MK, Bernstein AJ, Katz MH, Shikanov S, Zorn KC, Shalhav AL. J Endourol. 2009:439-43. [pmid: 19250023].
Comparison of different extraction sites used during laparoscopic radical nephrectomy. Bird VG, Au JK, Sandman Y, De Los Santos R, Ayyathurai R, Shields JM. J Urol. 2009:1565-70. [pmid: 19233420].
Management of renal masses with laparoscopic-guided radiofrequency ablation versus laparoscopic partial nephrectomy. Bird VG, Carey RI, Ayyathurai R, Bird VY. J Endourol. 2009:81-8. [pmid: 19118475].
Retroperitoneoscopic nephrectomy in overweight and obese Japanese patients: complications and outcomes. Makiyama K, Nakaigawa N, Miyoshi Y, Murakami T, Yao M, Kubota Y. Urol Int. 2008:427-30. [pmid: 19077404].
Clinical experience with laparoscopic radical nephrectomy for renal cell carcinoma. Tsujihata M, Nonomura N, Momohara C, Nishimura K, Tsujimura A, Okuyama A. Urol Int. 2008:301-5. [pmid: 18931547].
Laparoscopic radical nephrectomy--the cohort of 150 patients. Eret V, Hora M, Klecka J, Stransky P, Ferda J, Hes O, Urge T. Cas Lek Cesk. 2007:758-62. [pmid: 18020007].
Technical difficulties in retro-peritoneoscopic radical nephrectomy. Is tumor location important?. Lucan M, Lucan V, Ghervan L, Elec F, Iacob G, Barbos A. Chirurgia (Bucur). 2007:185-90. [pmid: 17615920].
Analysis of complications following partial and total nephrectomy for renal cancer in a population based sample. Joudi FN, Allareddy V, Kane CJ, Konety BR. J Urol. 2007:1709-14. [pmid: 17437791].
Analysis of impact of body mass index on outcomes of laparoscopic renal surgery. Gong EM, Orvieto MA, Lyon MB, Lucioni A, Gerber GS, Shalhav AL. Urology. 2007:38-43. [pmid: 17270610].
A prospective comparison of transperitoneal and retroperitoneal laparoscopic nephrectomy in the extremely obese patient. Berglund RK, Gill IS, Babineau D, Desai M, Kaouk JH. BJU Int. 2007:871-4. [pmid: 17233808].
The efficacy and safety of laparoscopic nephrectomy in patients with three or more comorbidities. Naya Y, Tobe T, Suyama T, Araki K, Komiya A, Suzuki H, Igarashi T, Ichikawa T. Int J Urol. 2007:17-20. [pmid: 17199854].
Perioperative clinical thromboembolic events after radical or partial nephrectomy. Pettus JA, Eggener SE, Shabsigh A, Yanke B, Snyder ME, Serio A, Vickers A, Russo P, Donat SM. Urology. 2006:988-92. [pmid: 17113889].
Obesity as a risk factor for complications during laparoscopic surgery for renal cancer: multivariate analysis. Kurzer E, Leveillee R, Bird V. J Endourol. 2006:794-9. [pmid: 17094757].
Minimizing knot tying during reconstructive laparoscopic urology. Shalhav AL, Orvieto MA, Chien GW, Mikhail AA, Zagaja GP, Zorn KC. Urology. 2006:508-13. [pmid: 16979736].
Organ-preserving endoscopic kidney cancer resection. Heinrich E, Egner T, Noe M, Schiefelbein F, Schoen G. Eur Urol. 2006:732-7. [pmid: 16930815].
Sutureless nephron-sparing surgery: use of albumin glutaraldehyde tissue adhesive (BioGlue). Hidas G, Kastin A, Mullerad M, Shental J, Moskovitz B, Nativ O. Urology. 2006:697-700. discussion 700. [pmid: 16566976].
Incidence and treatment of complications in nephron sparing surgery. Seveso M, Maugeri O, Taverna G, Giusti G, Piccinelli A, Benetti A, Pasini L, Graziotti P. Arch Ital Urol Androl. 2005:206-10. [pmid: 16444934].
Renal artery pseudoaneurysm following laparoscopic partial nephrectomy. Singh D, Gill IS. J Urol. 2005:2256-9. [pmid: 16280793].
Laparoscopic partial nephrectomy: is it advantageous and safe to clamp the renal artery?. Nadu A, Kitrey N, Mor Y, Golomb J, Ramon J. Urology. 2005:279-82. [pmid: 16098356].
Urological retroperitoneoscopic surgery for patients with prior intra-abdominal surgery. Mita K, Shigeta M, Mutaguchi K, Matsubara A, Yoshino T, Seki M, Mochizuki H, Kato M, Teishima J, Kadonishi Y, Yasumoto H, Usui T. Eur Urol. 2005:97-101. [pmid: 15967258].
Retroperitoneal laparoscopic nephron-sparing surgery for renal tumors: report of 32 cases. Zhang X, Li HZ, Ma X, Zheng T, Li LC, Ye ZQ. Urology. 2005:1080-4. discussion 1084-5. [pmid: 15913730].
Laparoscopic partial nephrectomy: hand-assisted technique. Strup S, Garrett J, Gomella L, Rowland R. J Endourol. 2005:456-9. discussion 459-60. [pmid: 15910255].
Hemorrhagic complications after nephron-sparing surgery: angiographic diagnosis and management by transcatheter embolization. Heye S, Maleux G, Van Poppel H, Oyen R, Wilms G. AJR Am J Roentgenol. 2005:1661-4. [pmid: 15855135].
Closed suction or penrose drainage after partial nephrectomy: does it matter?. Sanchez-Ortiz R, Madsen LT, Swanson DA, Canfield SE, Wood CG. J Urol. 2004:244-6. [pmid: 14665885].
Benefits of laparoscopic renal surgery are more pronounced in patients with a high body mass index. Klingler HC, Remzi M, Janetschek G, Marberger M. Eur Urol. 2003:522-7. [pmid: 12705997].
Perioperative antibiotic prophylaxis in transperitoneal tumor nephrectomy: does it lower the rate of clinically significant postoperative infections?. Steiner T, Traue C, Schubert J. Urologe A. 2003:34-7. [pmid: 12574881].
Improvement of hemostasis in open and laparoscopically performed partial nephrectomy using a gelatin matrix-thrombin tissue sealant (FloSeal). Richter F, Schnorr D, Deger S, Trk I, Roigas J, Wille A, Loening SA. Urology. 2003:73-7. [pmid: 12559270].
Blood loss and the need for transfusion in patients who undergo partial or radical nephrectomy for renal cell carcinoma. Shvarts O, Tsui KH, Smith RB, Kernion JB, Belldegrun A. J Urol. 2000:1160-3. [pmid: 10992357].
Incisional hernia after laparoscopic nephrectomy with intact specimen removal: caveat emptor. Elashry OM, Giusti G, Nadler RB, McDougall EM, Clayman RV. J Urol. 97:363-9.
Risk factors for postoperative hemorrhage after partial nephrectomy. Jung S, Min GE, Chung BI, Jeon SH, Korean J. Urol. 2014:17-22.
Robotic assisted Laparoscopic partial Nephrectomy for suspected Renal Cell Carcinoma: Retrospective review of surgical outcomes of 35 Cases. Bhayani SB, Das N. BMC Surg. 2008.
Use of Haemostatic Agents and Glues during Laparoscopic Partial Nephrectomy: A Multi-Institutional Survey from the United States and Europe of 1347 Cases{A figure is presented}. Breda A, Stepanian SV, Lam JS, Liao JC, Gill IS, Colombo JR, Guazzoni G, Stifelman MD, Perry KT, Celia A, Breda G, Fornara P, Jackman SV, Rosales A, Palou J, Grasso M, Pansadoro V, Disanto V, Porpiglia F, Milani C, Abbou CC, Gaston R, Janetschek G, Soomro NA, De la Rosette JJ, Laguna PM, Schulam PG. Eur Urol. 2007:798-803. [pmid: 17329015].
Direct real-time temperature monitoring for laparoscopic and CT-guided radiofrequency ablation of renal tumors between 3 and 5 cm. Carey RI, Leveillee RJ. J Endourol. 2007:807-813. [pmid: 17867933].
Percutaneous renal cryoablation: Feasibility under local anesthesia. De Kerviler E, Coffin A, De Bazelaire C, Meria P, Mongiat-Artus P, Desgrandchamps F. Cardiovasc Intervent Radiol. 2014:S234.
Percutaneous renal cryoablation: Feasibility under local anesthesia. De Kerviler E, Coffin A, De Bazelaire C, Meria P, Mongiat-Artus P, Desgrandchamps F. Cardiovasc Intervent Radiol. 2014:S234.
The impact of hospital volume on postoperative complications following robot-assisted partial nephrectomy. Monn MF, Bahler CD, Flack CK, Dube HT, Sundaram CP. J Endourol. 2014:1231-6. [pmid: 25019495].
Laparoscopic partial nephrectomy for multilocular cystic renal cell carcinoma: a potential gold standard treatment with excellent perioperative outcomes. Xu B, Mi Y, Zhou LQ, Jin J, Zhang Q, Chen GF. World J Surg Oncol. 2014:111. [pmid: 24754899].
Growth kinetics and short-term outcomes of cT1b and cT2 renal masses under active surveillance. Mehrazin R, Smaldone MC, Kutikov A, Li T, Tomaszewski JJ, Canter DJ, Viterbo R, Greenberg RE, Chen DY, Uzzo RG. J Urol. 2014:659-64. [pmid: 24641909].
A single overnight stay is possible for most patients undergoing robotic partial nephrectomy. Abaza R, Shah K. Urology. 2013:301-6. [pmid: 23374787].
Near-infrared fluorescence imaging to facilitate super-selective arterial clamping during zero-ischaemia robotic partial nephrectomy. Borofsky MS, Gill IS, Hemal AK, Marien TP, Jayaratna I, Krane LS, Stifelman MD. BJU Int. 2013:604-10. [pmid: 23253629].
Application of retroperitoneal laparoscopic partial nephrectomy for renal cell carcinoma of the early stage. Wang J, Qi L, Zu X, Chen M. Zhong Nan Da Xue Xue Bao Yi Xue Ban. 2012:485-90. [pmid: 22659661].
Comparison of total, selective, and nonarterial clamping techniques during laparoscopic and robot-assisted partial nephrectomy. Martin GL, Warner JN, Nateras RN, Andrews PE, Humphreys MR, Castle EP. J Endourol. 2012:152-6. [pmid: 22192110].
Complications of renal cryoablation: a single center experience. Sidana A, Aggarwal P, Feng Z, Georgiades CS, Trock BJ, Rodriguez R. J Urol. 2010:42-7. [pmid: 20478601].
Laparoscopic and open partial nephrectomy: frequency and long-term follow-up of postoperative collections. Hecht EM, Bennett GL, Brown KW, Robbins D, Hyams ES, Taneja SS, Stifelman MA. Radiology. 2010:476-84. [pmid: 20413760].
Laparoscopic partial nephrectomy for technically challenging tumours. Shikanov S, Lifshitz DA, Deklaj T, Katz MH, Shalhav AL. BJU Int. 2010:91-4. [pmid: 19888971].
Robotic partial nephrectomy versus laparoscopic partial nephrectomy for renal cell carcinoma: single-surgeon analysis of >100 consecutive procedures. Wang AJ, Bhayani SB. Urology. 2009:306-10. [pmid: 19038419].
The impact of minimally invasive techniques on open partial nephrectomy: a 10-year single institutional experience. Weight CJ, Fergany AF, Gunn PW, Lane BR, Novick AC. J Urol. 2008:84-8. [pmid: 18485409].
Laparoscopic partial nephrectomy: fifty cases. Bhayani SB. J Endourol. 2008:313-6. [pmid: 18294039].
Comparison of transperitoneal versus retroperitoneal approach in laparoscopic radical nephrectomy for renal cell carcinoma: a single-center experience of 63 cases. Berdjis N, Hakenberg OW, Leike S, Zastrow S, Manseck A, Oehlschlager S, Wirth MP. Urol Int. 2006:166-9. [pmid: 16888424].
Retroperitoneoscopic radical nephrectomy in obese patients: outcomes and considerations. Inoue S, Mita K, Shigeta M, Mochizuki H, Tanabe T, Moriyama H, Usui T. Urol Int. 2006:252-5. [pmid: 16601389].
Laparoscopic versus open partial nephrectomy. Beasley KA, Al Omar M, Shaikh A, Bochinski D, Khakhar A, Izawa JI, Welch RO, Chin JL, Kapoor A, Luke PP. Urology. 2004:458-61. [pmid: 15351570].
Renal artery occlusion during nephron-sparing surgery: Retrospective review of 301 cases. Duvdevani M, Mor Y, Kastin A, Laufer M, Nadu A, Golomb J, Zilberman D, Nativ O, Ramon J. Urology. 2006:960-963. [pmid: 17113887].
Renal sinus exposure as an independent factor predicting asymptomatic unruptured pseudoaneurysm formation detected in the early postoperative period after minimally invasive partial nephrectomy. Omae K, Kondo T, Takagi T, Morita S, Hashimoto Y, Kobayashi H, Iizuka J, Nozaki T, Yoshida K, Tanabe K. Int J Urol. 2015:356-361. [pmid: 25581594].

## Not relevant to key questions

The preoperative prognostic nutritional index is an independent predictor of survival in patients with renal cell carcinoma. Hofbauer SL, Pantuck AJ, de Martino M, Lucca I, Haitel A, Shariat SF, Belldegrun AS, Klatte T. Urol Oncol. 2014.
Validation of mammalian target of rapamycin biomarker panel in patients with clear cell renal cell carcinoma. Haddad AQ, Kapur P, Singla N, Raman JD, Then MT, Nuhn P, Buchner A, Bastian P, Seitz C, Shariat SF, Bensalah K, Rioux-Leclercq N, Sagalowsky A, Lotan Y, Margulis V. Cancer. 2014.
Comparative Studies of the Proteome, Glycoproteome, and N-Glycome of Clear Cell Renal Cell Carcinoma Plasma before and after Curative Nephrectomy. Gbormittah FO, Lee LY, Taylor K, Hancock WS, Iliopoulos O. J Proteome Res. 2014.
Tumor miR-125b predicts recurrence and survival of patients with clear-cell renal cell carcinoma after surgical resection. Fu Q, Liu Z, Pan D, Zhang W, Xu L, Zhu Y, Liu H, Xu J. Cancer Sci. 2014.
Increased expression of Chitinase 3-like 1 and microvessel density predicts metastasis and poor prognosis in clear cell renal cell carcinoma. Zhang JP, Yuan HX, Kong WT, Liu Y, Lin ZM, Wangs WP, Guo JM. Tumour Biol. 2014.
Clinical Symptoms Predict Poor Overall Survival in Chronic-dialysis Patients with Renal Cell Carcinoma Associated with End-stage Renal Disease. Ikezawa E, Kondo T, Hashimoto Y, Kobayashi H, Iizuka J, Takagi T, Omae K, Tanabe K. Jpn J Clin Oncol. 2014.
High preoperative C-reactive protein values predict poor survival in patients on chronic hemodialysis undergoing nephrectomy for renal cancer. Omae K, Kondo T, Tanabe K. Urol Oncol. 2014.
Pretherapeutic gamma-glutamyltransferase is an independent prognostic factor for patients with renal cell carcinoma. Hofbauer SL, Stangl KI, de Martino M, Lucca I, Haitel A, Shariat SF, Klatte T. Br J Cancer. 2014.
Expression of Neural Wiskott-Aldrich Syndrome Protein in Clear Cell Renal Cell Carcinoma and Its Correlation with Clinicopathological Features. Liu GH, Chen J, Ji ZG, Zhou L. Urol Int. 2014.
Factors Associated With Diagnostic Accuracy When Performing a Pre-Ablation Renal Biopsy. Lorber G, Jorda M, Leveillee RJ. J Endourol. 2014.
Clinicopathologic Outcomes of Cystic Renal Cell Carcinoma. Donin NM, Mohan S, Pham H, Chandarana H, Doshi A, Deng FM, Stifelman MD, Taneja SS, Huang WC. Clin Genitourin Cancer. 2014.
Low preoperative lymphocyte-monocyte ratio (LMR) represents a potentially poor prognostic factor in nonmetastatic clear cell renal cell carcinoma. Hutterer GC, Stoeckigt C, Stojakovic T, Jesche J, Eberhard K, Pummer K, Zigeuner R, Pichler M. Urol Oncol. 2014.
Surgeon-specific factors affecting treatment decisions among Canadian urologists in the management of pT1a renal tumours. Millman AL, Pace KT, Ordon M, Lee JY. Can Urol Assoc J. 2014:183-9. [pmid: 25024788].
Neutrophil-lymphocyte ratio in small renal masses. Bazzi WM, Dejbakhsh SZ, Bernstein M, Russo P. ISRN Urol. 2014:759253. [pmid: 25006517].
Comparison of diameter-axial-polar nephrometry and RENAL nephrometry score for treatment decision-making in patients with small renal mass. Naya Y, Kawauchi A, Oishi M, Ueda T, Fujihara A, Naito Y, Nakamura T, Hongo F, Kamoi K, Okihara K, Miki T. Int J Clin Oncol. 2014.
Diabetes Mellitus Is Independently Associated with an Increased Risk of Mortality in Patients with Clear Cell Renal Cell Carcinoma. Psutka SP, Stewart SB, Boorjian SA, Lohse CM, Tollefson MK, Cheville JC, Leibovich BC, Thompson RH. J Urol. 2014.
Tumor signatures of PTHLH overexpression, high serum calcium, and poor prognosis were observed exclusively in clear cell but not non clear cell renal carcinomas. Yao M, Murakami T, Shioi K, Mizuno N, Ito H, Kondo K, Hasumi H, Sano F, Makiyama K, Nakaigawa N, Kishida T, Nagashima Y, Yamanaka S, Kubota Y. Cancer Med. 2014:845-54. [pmid: 24861371].
Extent of lymph node dissection at nephrectomy affects cancer-specific survival and metastatic progression in specific sub-categories of patients with renal cell carcinoma (RCC). Capitanio U, Suardi N, Matloob R, Roscigno M, Abdollah F, Di Trapani E, Moschini M, Gallina A, Salonia A, Briganti A, Montorsi F, Bertini R. BJU Int. 2014:210-5. [pmid: 24854206].
Is the follow-up of small renal angiomyolipomas a necessary precaution?. Maclean DF, Sultana R, Radwan R, McKnight L, Khastgir J. Clin Radiol. 2014:822-6. [pmid: 24837696].
Significance of the R.E.N.A.L. nephrometry scoring system in renal tumour of T1 stage. Liu Y, Wang H, Mao X, Jing T, Jiang D, Ji J, Liu S, Song S. Zhonghua Wai Ke Za Zhi. 2014:139-42. [pmid: 24809525].
Prognostic value of clinical and pathological factors for surgically treated localized clear cell renal cell carcinoma. Teng J, Gao Y, Chen M, Wang K, Cui X, Liu Y, Xu D. Chin Med J (Engl). 2014:1640-4. [pmid: 24791867].
GALNT4 Predicts Clinical Outcome in Patients with Clear Cell Renal Cell Carcinoma. Liu Y, Liu W, Xu L, Liu H, Zhang W, Zhu Y, Xu J, Gu J. J Urol. 2014.
Analysis and validation of tissue biomarkers for renal cell carcinoma using automated high-throughput evaluation of protein expression. Abel EJ, Bauman TM, Weiker M, Shi F, Downs TM, Jarrard DF, Huang W. Hum Pathol. 2014:1092-9. [pmid: 24746216].
Preoperative butyrylcholinesterase level as an independent predictor of overall survival in clear cell renal cell carcinoma patients treated with nephrectomy. Koie T, Ohyama C, Mikami J, Iwamura H, Fujita N, Sato T, Kojima Y, Fukushi K, Yamamoto H, Imai A, Hatakeyama S, Yoneyama T, Hashimoto Y, Kitayama M, Hirota K. ScientificWorldJournal. 2014:948305. [pmid: 24741368].
Novel prognostic model for patients with sarcomatoid renal cell carcinoma. Zhang BY, Thompson RH, Lohse CM, Leibovich BC, Boorjian SA, Cheville JC, Costello BA. BJU Int. 2014.
Prognostic Significance of p21-activated Kinase 6 Expression in Patients with Clear Cell Renal Cell Carcinoma. Liu W, Liu H, Liu Y, Xu L, Zhang W, Zhu Y, Xu J, Gu J. Ann Surg Oncol. 2014.
Enhanced computed tomography after partial nephrectomy in early postoperative period to detect asymptomatic renal artery pseudoaneurysm. Takagi T, Kondo T, Tajima T, Campbell SC, Tanabe K. Int J Urol. 2014:880-5. [pmid: 24712736].
Approach via a small retroperitoneal anterior subcostal incision in the supine position for gasless laparoendoscopic single-port radical nephrectomy: initial experience of 42 patients. Morita T, Fujisaki A, Kubo T, Kurokawa S. BMC Urol. 2014:29. [pmid: 24708621].
Preoperative serum cholesterol is an independent prognostic factor for patients with renal cell carcinoma (RCC). de Martino M, Leitner CV, Seemann C, Hofbauer SL, Lucca I, Haitel A, Shariat SF, Klatte T. BJU Int. 2014.
Chromosome 9p deletions are an independent predictor of tumor progression following nephrectomy in patients with localized clear cell renal cell carcinoma. de Oliveira D, Dall'Oglio MF, Reis ST, Zerati M, Souza IC, Leite KR, Srougi M. Urol Oncol. 2014:601-6. [pmid: 24629495].
Use and outcomes of extended antibiotic prophylaxis in urological cancer surgery. Calvert JK, Holt SK, Mossanen M, James AC, Wright JL, Porter MP, Gore JL. J Urol. 2014:425-9. [pmid: 24603103].
Delay in nephrectomy and cancer control outcomes in elderly patients with small renal masses. Becker A, Roghmann F, Ravi P, Tian Z, Kluth LA, Gandaglia G, Noldus J, Dahlem R, Schlomm T, Graefen M, Karakiewicz PI, Trinh QD, Sun M. Urol Int. 2014:455-61. [pmid: 24602994].
Factors Influencing the Operative Approach to Renal Tumors: Analyses According to RENAL Nephrometry Scores. Oh JH, Rhew HY, Kim TS. Korean J Urol. 2014:97-101. [pmid: 24578804].
Growth kinetics of small renal masses: A prospective analysis from the Renal Cell Carcinoma Consortium of Canada. Organ M, Jewett M, Basiuk J, Morash C, Pautler S, Siemens DR, Tanguay S, Gleave M, Drachenberg D, Chow R, Chin J, Evans A, Fleshner N, Gallie B, Haider M, Kachura J, Finelli A, Rendon RA. Can Urol Assoc J. 2014:24-7. [pmid: 24578738].
Association of type of renal surgery and access to robotic technology for kidney cancer: results from a population-based cohort. Kardos SV, Gross CP, Shah ND, Schulam PG, Trinh QD, Smaldone MC, Sun M, Weight CJ, Sammon J, Han LC, Kim SP. BJU Int. 2014:549-54. [pmid: 24571281].
Current patterns of presentation and treatment of renal masses: a clinical research office of the endourological society prospective study. Laguna MP, Algaba F, Cadeddu J, Clayman R, Gill I, Gueglio G, Hohenfellner M, Joyce A, Landman J, Lee B, van Poppel H. J Endourol. 2014:861-70. [pmid: 24555480].
Simple enucleation versus standard partial nephrectomy for clinical T1 renal masses: perioperative outcomes based on a matched-pair comparison of 396 patients (RECORd project). Longo N, Minervini A, Antonelli A, Bianchi G, Bocciardi AM, Cunico SC, Fiori C, Fusco F, Giancane S, Mari A, Martorana G, Mirone V, Morgia G, Novara G, Porpiglia F, Raspollini MR, Rocco F, Rovereto B, Schiavina R, Serni S, Simeone C, Verze P, Volpe A, Ficarra V, Carini M. Eur J Surg Oncol. 2014:762-8. [pmid: 24529794].
Utilization of renal mass biopsy in patients with renal cell carcinoma. Leppert JT, Hanley J, Wagner TH, Chung BI, Srinivas S, Chertow GM, Brooks JD, Saigal CS. Urology. 2014:774-9. [pmid: 24529579].
Impact of Recurrent Copy Number Alterations and Cancer Gene Mutations on the Predictive Accuracy of Prognostic Models in Clear Cell Renal Cell Carcinoma. Hakimi AA, Mano R, Ciriello G, Gonen M, Mikkilineni N, Sfakianos JP, Kim PH, Motzer RJ, Russo P, Reuter VE, Hsieh JJ, Ostrovnaya I. J Urol. 2014.
Quantitative proteomic analysis reveals potential diagnostic markers and pathways involved in pathogenesis of renal cell carcinoma. White NM, Masui O, Desouza LV, Krakovska O, Metias S, Romaschin AD, Honey RJ, Stewart R, Pace K, Lee J, Jewett MA, Bjarnason GA, Siu KW, Yousef GM. Oncotarget. 2014:506-18. [pmid: 24504108].
MALDI imaging mass spectrometry profiling of proteins and lipids in clear cell renal cell carcinoma. Jones EE, Powers TW, Neely BA, Cazares LH, Troyer DA, Parker AS, Drake RR. Proteomics. 2014:924-35. [pmid: 24497498].
The impact of perioperative blood transfusion on survival after nephrectomy for non-metastatic renal cell carcinoma (RCC). Linder BJ, Thompson RH, Leibovich BC, Cheville JC, Lohse CM, Gastineau DA, Boorjian SA. BJU Int. 2014:368-74. [pmid: 24471825].
A novel 3-dimensional image analysis system for case-specific kidney anatomy and surgical simulation to facilitate clampless partial nephrectomy. Komai Y, Sakai Y, Gotohda N, Kobayashi T, Kawakami S, Saito N. Urology. 2014:500-6. [pmid: 24468517].
Subtyping of renal cortical neoplasms in fine needle aspiration biopsies using a decision tree based on genomic alterations detected by fluorescence in situ hybridization. Gowrishankar B, Cahill L, Arndt AE, Al-Ahmadie H, Lin O, Chadalavada K, Chaganti S, Nanjangud GJ, Murty VV, Chaganti RS, Reuter VE, Houldsworth J. BJU Int. 2014.
Renal cell carcinoma is more aggressive in Turkish patients with the metabolic syndrome. Ozbek E, Otunctemur A, Sahin S, Dursun M, Besiroglu H, Koklu I, Polat EC, Erkoc M, Danis E, Bozkurt M. Asian Pac J Cancer Prev. 2013:7351-4. [pmid: 24460301].
Interleukin-6 (IL-6) and C-reactive protein (CRP) concentration prior to total nephrectomy are prognostic factors in localized renal cell carcinoma (RCC). Hrab M, Olek-Hrab K, Antczak A, Kwias Z, Milecki T. Rep Pract Oncol Radiother. 2013:304-9. [pmid: 24416568].
Loss of BAP1 protein expression is an independent marker of poor prognosis in patients with low-risk clear cell renal cell carcinoma. Joseph RW, Kapur P, Serie DJ, Eckel-Passow JE, Parasramka M, Ho T, Cheville JC, Frenkel E, Rakheja D, Brugarolas J, Parker A. Cancer. 2014:1059-67. [pmid: 24382589].
Gender disparity in kidney cancer treatment: women are more likely to undergo radical excision of a localized renal mass. O'Malley RL, Underwood W 3rd, Brewer KA, Hayn MH, Kim HL, Mehedint DC, Safwat MW, Huang WC, Schwaab T. Urology. 2013:1065-9. [pmid: 24358483].
Costs analysis of laparoendoscopic, single-site laparoscopic and open surgery for cT1 renal masses in a European high-volume centre. Pini G, Ascalone L, Greco F, Mohammed N, Fornara P. World J Urol. 2013.
The impact of metformin use on recurrence and cancer-specific survival in clinically localized high-risk renal cell carcinoma. Hakimi AA, Chen L, Kim PH, Sjoberg D, Glickman L, Walker MR, Russo P. Can Urol Assoc J. 2013:E687-91. [pmid: 24282458].
Age distribution for partial and radical nephrectomy: whose nephrons are being spared?. von Klot C, Herrmann TR, Wegener G, Kuczyk MA, Hupe MC, Akkoyun M, Peters I, Kramer MW, Merseburger AS. Adv Ther. 2013:924-32. [pmid: 24155056].
Comparison of baseline quality of life measures between renal cell carcinoma patients undergoing partial versus radical nephrectomy. Arnold ML, Thiel DD, Diehl N, Wu KJ, Ames S, Parker AS. BMC Urol. 2013:52. [pmid: 24148752].
Evolving epidemiologic trends in nonclear cell renal cell cancer: an analysis of the California Cancer Registry. Pai A, Brunson A, Brown M, Pan CX, Lara PN Jr. Urology. 2013:840-5. [pmid: 24074980].
Role of CT in the assessment of muscular venous branch invasion in patients with renal cell carcinoma. Karlo CA, Donati OF, Marigliano C, Tickoo SK, Hricak H, Russo P, Akin O. AJR Am J Roentgenol. 2013:847-52. [pmid: 24059374].
Can the Leibovich score for clear cell renal cell carcinoma (ccRCC) be accurately reported by a general pathologist?. Vasdev N, Altal Y, Mafeld S, Wong K, Chadwick D, Gowda BD, Mutton A, Nagarajan S, Bhatti A. BJU Int. 2014:581-5. [pmid: 24053353].
Do young patients with renal cell carcinoma feature a distinct outcome after surgery? A comparative analysis of patient age based on the multinational CORONA database. Aziz A, May M, Zigeuner R, Pichler M, Chromecki T, Cindolo L, Schips L, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Hoschke B, Gilfrich C, Feciche B, Fenske F, Sountoulides P, Figenshau RS, Madison K, Sanchez-Chapado M, Del Carmen Santiago Martin M, Wieland WF, Salzano L, Lotrecchiano G, Waidelich R, Stief C, Brookman-May S. J Urol. 2014:310-5. [pmid: 23973516].
Multi-institutional analysis of localized renal cell carcinoma that demonstrates the impact of diabetic status on prognosis after nephrectomy. Ha YS, Kim WT, Yun SJ, Lee SC, Kim WJ, Park YH, Kang SH, Hong SH, Byun SS, Kim YJ. Ann Surg Oncol. 2013:3662-8. [pmid: 23907313].
Time to recurrence is a significant predictor of cancer-specific survival after recurrence in patients with recurrent renal cell carcinoma--results from a comprehensive multicentre database (CORONA/SATURN-Project). Brookman-May SD, May M, Shariat SF, Novara G, Zigeuner R, Cindolo L, De Cobelli O, De Nunzio C, Pahernik S, Wirth MP, Longo N, Simonato A, Serni S, Siracusano S, Volpe A, Morgia G, Bertini R, Dalpiaz O, Stief C, Ficarra V. BJU Int. 2013:909-16. [pmid: 23890378].
Clear cell renal cell carcinoma and papillary renal cell carcinoma: differentiation of distinct histological types with multiphase CT. Bata P, Gyebnar J, Tarnoki DL, Tarnoki AD, Kekesi D, Szendroi A, Fejer B, Szasz AM, Nyirady P, Karlinger K, Berczi V. Diagn Interv Radiol. 2013:387-92. [pmid: 23864331].
Use of surveillance imaging following treatment of small renal masses. Kowalczyk KJ, Harbin AC, Choueiri TK, Hevelone ND, Lipsitz SR, Trinh QD, Tina Shih YC, Hu JC. J Urol. 2013:1680-5. [pmid: 23764074].
Active surveillance, radiofrequency ablation, or cryoablation for the nonsurgical management of a small renal mass: a cost-utility analysis. Bhan SN, Pautler SE, Shayegan B, Voss MD, Goeree RA, You JJ. Ann Surg Oncol. 2013:3675-84. [pmid: 23720071].
Overall survival advantage with partial nephrectomy: a bias of observational data?. Shuch B, Hanley J, Lai J, Vourganti S, Kim SP, Setodji CM, Dick AW, Chow WH, Saigal C. Cancer. 2013:2981-9. [pmid: 23674264].
Cost-utility analysis of radical nephrectomy versus partial nephrectomy in the management of small renal masses: Adjusting for the burden of ensuing chronic kidney disease. Klinghoffer Z, Tarride JE, Novara G, Ficarra V, Kapoor A, Shayegan B, Braga LH. Can Urol Assoc J. 2013:108-13. [pmid: 23671525].
Patient and caregiver knowledge and utilization of partial versus radical nephrectomy: results of a national kidney foundation survey to assess educational needs of kidney cancer patients and caregivers. Russo P, Szczech LA, Torres GS, Swartz MD. Am J Kidney Dis. 2013:939-46. [pmid: 23523238].
Validation of serum C-reactive protein (CRP) as an independent prognostic factor for disease-free survival in patients with localised renal cell carcinoma (RCC). de Martino M, Klatte T, Seemann C, Waldert M, Haitel A, Schatzl G, Remzi M, Weibl P. BJU Int. 2013:E348-53. [pmid: 23495750].
Trends in the surgical management of localized renal masses: thermal ablation, partial and radical nephrectomy in the USA, 1998-2008. Woldrich JM, Palazzi K, Stroup SP, Sur RL, Parsons JK, Chang D, Derweesh IH. BJU Int. 2013:1261-8. [pmid: 23470140].
Trends in partial and radical nephrectomy: an analysis of case logs from certifying urologists. Poon SA, Silberstein JL, Chen LY, Ehdaie B, Kim PH, Russo P. J Urol. 2013:464-9. [pmid: 23454156].
Impact of clinical and histopathological parameters on disease specific survival in patients with collecting duct renal cell carcinoma: development of a disease specific risk model. May M, Ficarra V, Shariat SF, Zigeuner R, Chromecki T, Cindolo L, Burger M, Gunia S, Feciche B, Wenzl V, Aziz A, Chun F, Becker A, Pahernik S, Simeone C, Longo N, Zucchi A, Antonelli A, Mirone V, Stief C, Novara G, Brookman-May S. J Urol. 2013:458-63. [pmid: 23434943].
Use of nephron-sparing surgery among renal cell carcinoma patients with diabetes and hypertension. Filson CP, Schwartz K, Colt JS, Ruterbusch J, Linehan WM, Chow WH, Miller DC. Urol Oncol. 2014:27.e15-21. [pmid: 23419677].
Rates of open versus laparoscopic and partial versus radical nephrectomy for T1a renal cell carcinoma: a population-based evaluation. Bianchi M, Becker A, Abdollah F, Trinh QD, Hansen J, Tian Z, Shariat SF, Perrotte P, Karakiewicz PI, Sun M. Int J Urol. 2013:1064-71. [pmid: 23418921].
Fenoldopam and renal function after partial nephrectomy in a solitary kidney: a randomized, blinded trial. O'Hara JF Jr, Mahboobi R, Novak SM, Bonilla AM, Mascha EJ, Fergany AF, Campbell SC, Kaouk JH, Kaple KM, Gill IS, Ziegman SA, Sessler DI. Urology. 2013:340-5. [pmid: 23374797].
Clinical characteristics associated with treatment type for localized renal tumors: implications for practice pattern assessment. Smaldone MC, Churukanti G, Simhan J, Kim SP, Reyes J, Zhu F, Kutikov A, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Urology. 2013:269-75. [pmid: 23374778].
Differential use of partial nephrectomy for intermediate and high complexity tumors may explain variability in reported utilization rates. Lane BR, Golan S, Eggener S, Tobert CM, Kahnoski RJ, Kutikov A, Smaldone M, Whelan CM, Shalhav A, Uzzo RG. J Urol. 2013:2047-53. [pmid: 23313207].
Does mechanical bowel preparation improve quality of laparoscopic nephrectomy? Propensity score-matched analysis in Japanese series. Sugihara T, Yasunaga H, Horiguchi H, Fujimura T, Nishimatsu H, Ohe K, Matsuda S, Fushimi K, Kattan MW, Homma Y. Urology. 2013:74-9. [pmid: 23273073].
Radiofrequency ablation of small renal masses as an alternative to nephron-sparing surgery: preliminary results. Jasinski M, Siekiera J, Chlosta P, Mikolajczak W, Drewa T. Wideochir Inne Tech Malo Inwazyjne. 2011:242-5. [pmid: 23255987].
Pre-operative imaging may overestimate the kidney tumor size. Nasseh HR, Falahatkar S, Ghanbari A, Bagheri Chenari H. Urol J. 2012:662-6. [pmid: 23235970].
Single nucleotide polymorphisms and risk of recurrence of renal-cell carcinoma: a cohort study. Schutz FA, Pomerantz MM, Gray KP, Atkins MB, Rosenberg JE, Hirsch MS, McDermott DF, Lampron ME, Lee GS, Signoretti S, Kantoff PW, Freedman ML, Choueiri TK. Lancet Oncol. 2013:81-7. [pmid: 23219378].
Wide range and variation in minimally invasive surgery for renal malignancy in Japan: a population-based analysis. Sugihara T, Yasunaga H, Horiguchi H, Tsuru N, Fujimura T, Nishimatsu H, Kume H, Ohe K, Matsuda S, Fushimi K, Homma Y. Int J Clin Oncol. 2013:1070-7. [pmid: 23179640].
The use of Surgisis(R) optimizes and simplifies partial nephrectomy for large renal tumors. Schnoeller TJ, de Petriconi R, Hefty R, Jentzmik F, Al Ghazal A, Steinestel J, Mueller J, Zengerling F, Schrader M, Schrader AJ. Urologe A. 2013:246-51. [pmid: 23178845].
Nature of lesions undergoing radical nephrectomy for renal cancer. Mustafa G, Ilhan G, Necip P, Kerem T, Kadir C. Asian Pac J Cancer Prev. 2012:4431-3. [pmid: 23167356].
A preoperative prognostic model predicting recurrence-free survival for patients with kidney cancer. Yaycioglu O, Eskicorapci S, Karabulut E, Soyupak B, Gogus C, Divrik T, Turkeri L, Yazici S, Ozen H. Jpn J Clin Oncol. 2013:63-8. [pmid: 23159766].
Uric acid levels correlate with baseline renal function and high levels are a potent risk factor for postoperative chronic kidney disease in patients with renal cell carcinoma. Jeon HG, Choo SH, Jeong BC, Seo SI, Jeon SS, Choi HY, Lee HM. J Urol. 2013:1249-54. [pmid: 23159461].
Cyclooxygenase-2 expression and its prognostic significance in clear cell renal cell carcinoma. Lee JW, Park JH, Suh JH, Nam KH, Choe JY, Jung HY, Chae JY, Moon KC. Korean J Pathol. 2012:237-45. [pmid: 23110009].
Predictive ability of the 2002 and 2010 versions of the Tumour-Node-Metastasis classification system regarding metastasis-free, cancer-specific and overall survival in a European renal cell carcinoma single-centre series. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Groselj-Strele A, Pummer K, Zigeuner R. BJU Int. 2013:E191-5. [pmid: 23107473].
Competing risks of death in patients with localized renal cell carcinoma: a comorbidity based model. Kutikov A, Egleston BL, Canter D, Smaldone MC, Wong YN, Uzzo RG. J Urol. 2012:2077-83. [pmid: 23083850].
A novel technique to limit renal warm ischaemia time during laparoscopic partial nephrectomy. Sapre N, Corcoran NM, Costello AJ, Agarwal D. BJU Int. 2012:1216-9. [pmid: 23020701].
CD44 is associated with tumor recurrence and is an independent poor prognostic factor for patients with localized clear cell renal cell carcinoma after nephrectomy. Jeong BJ, Liang ZL, Huang SM, Lim JS, Kim JM, Lee HJ. Exp Ther Med. 2012:811-817. [pmid: 22969974].
Analysis of clinicopathological features and prognosis in 68 patients with chromophobe renal cell carcinoma. Huang JW, Zhang J, Dong BJ, Kong W, Niu SX, Chen YH, Xue W, Liu DM, Huang YR. Zhonghua Zhong Liu Za Zhi. 2012:510-3. [pmid: 22967469].
Renal volumetric analysis: a new paradigm in renal mass treatment assessment. Gorbatiy V, Iremashvili V, Castro A, Mure A, Ortiz N, Castle SM, Leveillee RJ. J Endourol. 2013:361-5. [pmid: 22967235].
Association of clinical and radiographic features with perinephric &quot;sticky&quot; fat. Bylund JR, Qiong H, Crispen PL, Venkatesh R, Strup SE. J Endourol. 2013:370-3. [pmid: 22966767].
Validation of CRP as prognostic marker for renal cell carcinoma in a large series of patients. Steffens S, Kohler A, Rudolph R, Eggers H, Seidel C, Janssen M, Wegener G, Schrader M, Kuczyk MA, Schrader AJ. BMC Cancer. 2012:399. [pmid: 22958305].
Partial nephrectomy: is there an advantage of the self-retaining barbed suture in the perioperative period? A matched case-control comparison. Zondervan PJ, Gozen AS, Opondo D, Rassweiler JJ, de la Rosette JJ, Laguna MP. World J Urol. 2012:659-64. [pmid: 22956042].
Assessment of the pathologic inclusion criteria from contemporary adjuvant clinical trials for predicting disease progression after nephrectomy for renal cell carcinoma. Kim SP, Crispen PL, Thompson RH, Weight CJ, Boorjian SA, Costello BA, Lohse CM, Leibovich BC. Cancer. 2012:4412-20. [pmid: 22952032].
Carcinoma of the collecting ducts of Bellini and renal medullary carcinoma: clinicopathologic analysis of 52 cases of rare aggressive subtypes of renal cell carcinoma with a focus on their interrelationship. Gupta R, Billis A, Shah RB, Moch H, Osunkoya AO, Jochum W, Hes O, Bacchi CE, de Castro MG, Hansel DE, Zhou M, Vankalakunti M, Salles PG, Cabrera RA, Gown AM, Amin MB. Am J Surg Pathol. 2012:1265-78. [pmid: 22895263].
Prognostic significance of high nuclear grade in patients with pathologic T1a renal cell carcinoma. Suzuki K, Mizuno R, Mikami S, Tanaka N, Kanao K, Kikuchi E, Miyajima A, Nakagawa K, Oya M. Jpn J Clin Oncol. 2012:831-5. [pmid: 22811408].
Tumour-related imaging parameters predicting the percentage of preserved normal renal parenchyma following nephron sparing surgery: a retrospective study. Aertsen M, De Keyzer F, Van Poppel H, Joniau S, De Wever L, Lerut E, Oyen R, Claus F. Eur Radiol. 2013:280-6. [pmid: 22797982].
Kidney size and cancer-specific survival for patients undergoing nephrectomy for pT1 clear cell renal cell carcinoma. Jorns JJ, Thiel DD, Lohse C, Williams A, Arnold M, Cheville J, Leibovich B, Parker AS. Urology. 2012:147-50. [pmid: 22748870].
Antimicrobial prophylaxis is not necessary in clean category minimally invasive surgery for renal and adrenal tumors: a prospective study of 373 consecutive patients. Kijima T, Masuda H, Yoshida S, Tatokoro M, Yokoyama M, Numao N, Saito K, Koga F, Fujii Y, Kihara K. Urology. 2012:570-5. [pmid: 22743261].
Analysis of the evolution of surgery for the treatment of primary renal tumors during the period 2006-2010: report of 458 consecutive surgeries. Bellec L, Thoulouzan M, Soler P, Khedis M, Walschaerts M, Delaunay B, Crenn G, Salloum A, Rouvellat P, Malavaud B, Rischmann P, Plante P, Soulie M, Huyghe E. Prog Urol. 2012:520-8. [pmid: 22732643].
Assessing performance trends in laparoscopic nephrectomy and nephron-sparing surgery for localized renal tumors. Smaldone MC, Kutikov A, Egleston B, Simhan J, Canter DJ, Teper E, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Urology. 2012:286-91. [pmid: 22704174].
Staging lymphadenectomy in renal cell carcinoma must be extended: a sensitivity curve analysis. Capitanio U, Suardi N, Matloob R, Abdollah F, Castiglione F, Briganti A, Carenzi C, Roscigno M, Montorsi F, Bertini R. BJU Int. 2013:412-8. [pmid: 22703190].
Histopathology of surgically treated renal cell carcinoma: survival differences by subtype and stage. Keegan KA, Schupp CW, Chamie K, Hellenthal NJ, Evans CP, Koppie TM. J Urol. 2012:391-7. [pmid: 22698625].
The effect of race and gender on the surgical management of the small renal mass. Kates M, Whalen MJ, Badalato GM, McKiernan JM. Urol Oncol. 2013:1794-9. [pmid: 22687567].
Comparison of two core biopsy techniques before and after laparoscopic cryoablation of small renal cortical neoplasms. Truesdale MD, Mues AC, Sartori S, Casazza CN, Hruby GW, Harik LR, O'Toole KM, Badani KK, Perez-Lanzac A, Landman J. JSLS. 2011:509-16. [pmid: 22643507].
RENAL nephrometry score predicts surgery type independent of individual surgeon's use of nephron-sparing surgery. Tobert CM, Kahnoski RJ, Thompson DE, Anema JG, Kuntzman RS, Lane BR. Urology. 2012:157-61. [pmid: 22626579].
Characteristics and outcomes of tumors arising from the distal nephron. Abern MR, Tsivian M, Polascik TJ, Coogan CL. Urology. 2012:140-6. [pmid: 22626576].
Perioperative outcomes of laparoscopic radical nephrectomy for renal cell carcinoma in patients with dialysis-dependent end-stage renal disease. Yamashita K, Ito F, Nakazawa H. Ther Apher Dial. 2012:254-9. [pmid: 22607569].
Integrating robotic partial nephrectomy to an existing robotic surgery program. Yuh B, Muldrew S, Menchaca A, Yip W, Lau C, Wilson T, Josephson D. Can J Urol. 2012:6193-200. [pmid: 22512965].
Simplified hemostatic technique during laparoscopic partial nephrectomy. Tsivian A, Tsivian M, Benjamin S, Sidi AA. Int Braz J Urol. 2012:84-8. [pmid: 22397789].
The fate of small renal masses, less then 1 cm size: outcome study. Lang EK, Hanano A, Rudman E, Thomas R, Myers L, Nguyen Q, Macchia RJ. Int Braz J Urol. 2012:40-8. discussion 48. [pmid: 22397785].
Prognostic nomogram for disease-free survival in patients with renal adenocarcinoma. Di Capua Sacoto C, Budia A, Garcia-Fadrique G, Lujan S, Ruiz-Cerda JL, Jimenez-Cruz JF. Urol Int. 2012:271-6. [pmid: 22378354].
Evolving practice patterns for the management of small renal masses in the USA. Yang G, Villalta JD, Meng MV, Whitson JM. BJU Int. 2012:1156-61. [pmid: 22372984].
Relevance of the clinical-pathological predictive factors in force in chromophobe renal cell cancer. Pardo P, Rodriguez-Faba O, Palou J, Algaba F, Breda A, Esquena S, Villavicencio H. Actas Urol Esp. 2012:527-31. [pmid: 22365081].
Treatment management of small renal masses in the 21st century: a paradigm shift. Sun M, Abdollah F, Bianchi M, Trinh QD, Jeldres C, Thuret R, Tian Z, Shariat SF, Montorsi F, Perrotte P, Karakiewicz PI. Ann Surg Oncol. 2012:2380-7. [pmid: 22322956].
Safety and outcomes of surgical treatment of renal cell carcinoma in the elderly. O'Malley RL, Hayn MH, Hellenthal NJ, Kim HL, Underwood W 3rd, Schwaab T. Can J Urol. 2012:6111-7. [pmid: 22316513].
Radiofrequency ablation of incidental benign small renal mass: outcomes and follow-up protocol. Tan YK, Best SL, Olweny E, Park S, Trimmer C, Cadeddu JA. Urology. 2012:827-30. [pmid: 22309782].
Prediction of growth rate of solid renal masses: utility of MR imaging features--preliminary experience. Dodelzon K, Mussi TC, Babb JS, Taneja SS, Rosenkrantz AB. Radiology. 2012:884-93. [pmid: 22267588].
Histologic tumor necrosis is an independent prognostic indicator for clear cell and papillary renal cell carcinoma. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Rehak P, Pummer K, Zigeuner R. Am J Clin Pathol. 2012:283-9. [pmid: 22261455].
National trends in the use of partial nephrectomy: a rising tide that has not lifted all boats. Patel SG, Penson DF, Pabla B, Clark PE, Cookson MS, Chang SS, Herrell SD, Smith JA Jr, Barocas DA. J Urol. 2012:816-21. [pmid: 22248514].
NDRG2 is involved in the oncogenic properties of renal cell carcinoma and its loss is a novel independent poor prognostic factor after nephrectomy. Liang ZL, Kang K, Yoon S, Huang SM, Lim JS, Kim JM, Lim JS, Lee HJ. Ann Surg Oncol. 2012:2763-72. [pmid: 22246425].
Low local metastatic rate may widen indication of nephron-sparing surgery for renal cell carcinoma. Xiong ZQ, Zheng J, Feng CC, Bao Y, Ding Q, Fang ZJ. Ann Diagn Pathol. 2012:190-5. [pmid: 22209503].
Chromophobe renal cell carcinoma: analysis of 53 cases. Zhao PJ, Chen XP, Li XS, Yao L, Zhang CJ, Yu W, He Q, He ZS, Zhou LQ. J Cancer Res Clin Oncol. 2012:451-4. [pmid: 22179197].
Do we continue to unnecessarily perform ipsilateral adrenalectomy at the time of radical nephrectomy? A population based study. Yap SA, Alibhai SM, Abouassaly R, Timilshina N, Finelli A. J Urol. 2012:398-404. [pmid: 22177155].
Direct upper kidney pole access and early ligation of renal pedicle significantly facilitates transperitoneal laparoscopic nephrectomy procedures: Tunc technique. Tunc L, Canda AE, Polat F, Onaran M, Atkin S, Biri H, Bozkirli I. Surg Laparosc Endosc Percutan Tech. 2011:453-7. [pmid: 22146171].
Trends in the use of of nephron-sparing surgery (NSS) at an Australian tertiary referral centre: an analysis of surgical decision-making using the R.E.N.A.L. nephrometry scoring system. Satasivam P, Rajarubendra N, Chia PH, Munshey A, Sengupta S, Bolton D. BJU Int. 2012:1341-4. [pmid: 21951826].
Contemporary trends in nephrectomy for renal cell carcinoma in the United States: results from a population based cohort. Kim SP, Shah ND, Weight CJ, Thompson RH, Moriarty JP, Shippee ND, Costello BA, Boorjian SA, Leibovich BC. J Urol. 2011:1779-85. [pmid: 21944105].
Tumour size, tumour complexity, and surgical approach are associated with nephrectomy type in small renal cortical tumours treated electively. Broughton GJ, Clark PE, Barocas DA, Cookson MS, Smith JA Jr, Herrell SD, Chang SS. BJU Int. 2012:1607-13. [pmid: 21939493].
Bilateral synchronous sporadic renal tumors: pathologic concordance and clinical implications. Patel AR, Lee BH, Campbell SC, Zhou M, Fergany AF. Urology. 2011:1095-9. [pmid: 21937095].
Prognostic significance of CD45RO+ memory T cells in renal cell carcinoma. Hotta K, Sho M, Fujimoto K, Shimada K, Yamato I, Anai S, Konishi N, Hirao Y, Nonomura K, Nakajima Y. Br J Cancer. 2011:1191-6. [pmid: 21934683].
Absent Toll-like receptor-9 expression predicts poor prognosis in renal cell carcinoma. Ronkainen H, Hirvikoski P, Kauppila S, Vuopala KS, Paavonen TK, Selander KS, Vaarala MH. J Exp Clin Cancer Res. 2011:84. [pmid: 21929816].
Prognostic factors in a large multi-institutional series of papillary renal cell carcinoma. Zucchi A, Novara G, Costantini E, Antonelli A, Carini M, Carmignani G, Cosciani Cunico S, Fontana D, Longo N, Martignoni G, Minervini A, Mirone V, Porena M, Roscigno M, Schiavina R, Simeone C, Simonato A, Siracusano S, Terrone C, Ficarra V. BJU Int. 2012:1140-6. [pmid: 21871053].
Incidence of multiple sporadic renal cell carcinomas in patients referred for renal radiofrequency ablation: implications for imaging follow-up. Beland MD, Wolf FJ, Grand DJ, Dupuy DE, Mayo-Smith WW. AJR Am J Roentgenol. 2011:671-5. [pmid: 21862810].
Zero-ischaemia robotic and laparoscopic partial nephrectomy (PN). Patil MB, Gill IS. BJU Int. 2011:780-92. [pmid: 21854529].
Iatrogenic splenectomy during left nephrectomy: a single-institution experience of eight years. Tan K, Lewis GR, Chahal R, Browning AJ, Sundaram SK, Weston PM, Harrison SC, Biyani CS. Urol Int. 2011:59-63. [pmid: 21701137].
Metastatic potential of a renal mass according to original tumour size at presentation. Umbreit EC, Shimko MS, Childs MA, Lohse CM, Cheville JC, Leibovich BC, Blute ML, Thompson RH. BJU Int. 2012:190-4. discussion 194. [pmid: 21557795].
Lymphadenectomy improves survival of patients with renal cell carcinoma and nodal metastases. Whitson JM, Harris CR, Reese AC, Meng MV. J Urol. 2011:1615-20. [pmid: 21419453].
Robot-assisted retroperitoneal partial nephrectomy: technique and perioperative results. Weizer AZ, Palella GV, Montgomery JS, Miller DC, Hafez KS. J Endourol. 2011:553-7. [pmid: 21381954].
Laparoendoscopic single-site surgeries: a single-center experience of 171 consecutive cases. Choi KH, Ham WS, Rha KH, Lee JW, Jeon HG, Arkoncel FR, Yang SC, Han WK. Korean J Urol. 2011:31-8. [pmid: 21344028].
Clinicopathological outcomes of clinical T1a renal cell carcinoma by tumor size. Kitagawa Y, Nakashima K, Shima T, Izumi K, Narimoto K, Miwa S, Miyagi T, Maeda Y, Kadono Y, Konaka H, Mizokami A, Namiki M. Jpn J Clin Oncol. 2011:637-41. [pmid: 21297120].
Preoperative nutritional status is an important predictor of survival in patients undergoing surgery for renal cell carcinoma. Morgan TM, Tang D, Stratton KL, Barocas DA, Anderson CB, Gregg JR, Chang SS, Cookson MS, Herrell SD, Smith JA Jr, Clark PE. Eur Urol. 2011:923-8. [pmid: 21295907].
Is there a need to further subclassify pT2 renal cell cancers as implemented by the revised 7th TNM version?. Waalkes S, Becker F, Schrader AJ, Janssen M, Wegener G, Merseburger AS, Schrader M, Hofmann R, Stockle M, Kuczyk MA. Eur Urol. 2011:258-63. [pmid: 21030143].
Late recurrence of renal cell carcinoma: retrospective and collaborative study of the Japanese Society of Renal Cancer. Miyao N, Naito S, Ozono S, Shinohara N, Masumori N, Igarashi T, Nakao M, Tsushima T, Senga Y, Horie S, Kanayama HO, Tokuda N, Kobayashi M. Urology. 2011:379-84. [pmid: 20970828].
Validation of the 2009 TNM version in a large multi-institutional cohort of patients treated for renal cell carcinoma: are further improvements needed?. Novara G, Ficarra V, Antonelli A, Artibani W, Bertini R, Carini M, Cosciani Cunico S, Imbimbo C, Longo N, Martignoni G, Martorana G, Minervini A, Mirone V, Montorsi F, Schiavina R, Simeone C, Serni S, Simonato A, Siracusano S, Volpe A, Carmignani G. Eur Urol. 2010:588-95. [pmid: 20674150].
Feasibility of differential diagnosis of kidney tumors by comparative genomic hybridization of fine needle aspiration biopsies. Vieira J, Henrique R, Ribeiro FR, Barros-Silva JD, Peixoto A, Santos C, Pinheiro M, Costa VL, Soares MJ, Oliveira J, Jeronimo C, Teixeira MR. Genes Chromosomes Cancer. 2010:935-47. [pmid: 20629095].
A collaborative approach reduces the learning curve and improves outcomes in laparoscopic nephrectomy. Schneider CL, Cobb WS, Carbonell AM, Hill LK, Flanagan WF. Surg Endosc. 2011:182-5. [pmid: 20549243].
Comparison of accuracy of 14-, 18- and 20-G needles in ex-vivo renal mass biopsy: a prospective, blinded study. Breda A, Treat EG, Haft-Candell L, Leppert JT, Harper JD, Said J, Raman S, Smith RB, Belldegrun AS, Schulam PG. BJU Int. 2010:940-5. [pmid: 19888984].
Primary treatment of renal cell carcinoma. Yesterday, today, tomorrow. Dufour B. Bull Acad Natl Med. 2009:691-707. discussion 707-8. [pmid: 19883019].
Laparoscopic radical nephrectomy in big surgical specimens. Alonso y, Gregorio S, Sanchez S, Soler C, Rando A, Giron M, Tabernero Gomez AJ, Aguilera A, Cisneros Ledo J, de la Pena Barthel J. Actas Urol Esp. 2009:755-8. [pmid: 19757660].
Predicting collecting system transection at laparoscopic partial nephrectomy: analysis of tumor parameters. Shikanov S, Lifshitz DA, Deklaj T, Katz MH, Shalhav AL. J Endourol. 2009:1863-6. [pmid: 19619066].
Incidental angiomyolipoma resected during renal surgery for an enhancing renal mass. Berglund RK, Bernstein M, Manion MT, Touijer KA, Russo P. BJU Int. 2009:1650-4. [pmid: 19519761].
Angiomyolipomata: challenges, solutions, and future prospects based on over 100 cases treated. Sooriakumaran P, Gibbs P, Coughlin G, Attard V, Elmslie F, Kingswood C, Taylor J, Corbishley C, Patel U, Anderson C. BJU Int. 2010:101-6. [pmid: 19493268].
Hybrid renal cell carcinomas containing histopathologic features of chromophobe renal cell carcinomas and oncocytomas have excellent oncologic outcomes. Waldert M, Klatte T, Haitel A, Ozsoy M, Schmidbauer J, Marberger M, Remzi M. Eur Urol. 2010:661-5. [pmid: 19477583].
A novel and ergonomic patient position for laparoscopic kidney surgery. Martin GL, Nunez RN, Martin AD, Andrews PE, Castle EP. Can J Urol. 2009:4580-3. [pmid: 19364431].
Increasing the number of biopsy cores before renal cryoablation increases the diagnostic yield. Kramer BA, Whelan CM, Vestal JC, Schwartz BF. J Endourol. 2009:283-6. [pmid: 19220086].
Organ-confined clear cell renal cell carcinoma: the prognostic impact of microvascular invasion, nuclear grade and tumour size. Zubac DP, Bostad L, Kihl B, Eide J, Wentzel-Larsen T, Haukaas SA. APMIS. 2008:1027-33. [pmid: 19133004].
Diagnostic yield of renal biopsy immediately prior to laparoscopic radiofrequency ablation: a multicenter study. Kyle CC, Wingo MS, Carey RI, Leveillee RJ, Bird VG. J Endourol. 2008:2291-3. [pmid: 18937593].
A preoperative prognostic model for patients treated with nephrectomy for renal cell carcinoma. Karakiewicz PI, Suardi N, Capitanio U, Jeldres C, Ficarra V, Cindolo L, de la Taille A, Tostain J, Mulders PF, Bensalah K, Artibani W, Salomon L, Zigeuner R, Valeri A, Descotes JL, Rambeaud JJ, Mejean A, Montorsi F, Bertini R, Patard JJ. Eur Urol. 2009:287-95. [pmid: 18715700].
External validation of the Mayo Clinic cancer specific survival score in a Japanese series of clear cell renal cell carcinoma. Fujii Y, Saito K, Iimura Y, Sakai Y, Koga F, Kawakami S, Kumagai J, Kihara K. J Urol. 2008:1290-5. discussion 1295-6. [pmid: 18707704].
Renal surgery in the elderly: morbidity in patients aged >75 years in a contemporary series. Staehler M, Haseke N, Stadler T, Bader M, Karl A, Becker A, Stief CG. BJU Int. 2008:684-7. [pmid: 18510657].
Renal cell carcinoma radiofrequency ablation: evaluation of efficacy based on histological correlation. Mylona S, Ntai S, Stroumpouli E, Glentzes V, Martinis S, Thanos L. Br J Radiol. 2008:479-84. [pmid: 18487388].
Tumor size does not predict risk of metastatic disease or prognosis of small renal cell carcinomas. Klatte T, Patard JJ, de Martino M, Bensalah K, Verhoest G, de la Taille A, Abbou CC, Allhoff EP, Carrieri G, Riggs SB, Kabbinavar FF, Belldegrun AS, Pantuck AJ. J Urol. 2008:1719-26. [pmid: 18343437].
Analysis of clinicopathologic predictors of oncologic outcome provides insight into the natural history of surgically managed papillary renal cell carcinoma. Margulis V, Tamboli P, Matin SF, Swanson DA, Wood CG. Cancer. 2008:1480-8. [pmid: 18240184].
Impact of gender in renal cell carcinoma: an analysis of the SEER database. Aron M, Nguyen MM, Stein RJ, Gill IS. Eur Urol. 2008:133-40. [pmid: 18160207].
Laparoscopic renal oncological surgery in the presence of abdominal aortic and vena caval pathology: 8-year experience. Lin YC, Haber GP, Turna B, Frota R, Koenig P, Desai M, Kaouk J, Gill IS. J Urol. 2008:455-60. discussion 460. [pmid: 18076915].
Disparities in treatment and outcome for renal cell cancer among older black and white patients. Berndt SI, Carter HB, Schoenberg MP, Newschaffer CJ. J Clin Oncol. 2007:3589-95. [pmid: 17704406].
Nephrectomy: indications, complications and mortality in 154 consecutive patients. Rafique M. J Pak Med Assoc. 2007:308-11. [pmid: 17629234].
Renal cell carcinoma: a clinicopathological follow-up study after radical nephrectomy. Zubac DP, Bostad L, Gestblom C, Kihl B, Seidal T, Wentzel-Larsen T, Bakke AM. Scand J Urol Nephrol. 2007:191-7. [pmid: 17469026].
Does tumor size or microvascular invasion affect prognosis in patients with renal cell carcinoma?. Miyagawa T, Shimazui T, Hinotsu S, Oikawa T, Sekido N, Miyanaga N, Kawai K, Akaza H. Jpn J Clin Oncol. 2007:197-200. [pmid: 17360737].
Survival analysis of 130 patients with papillary renal cell carcinoma: prognostic utility of type 1 and type 2 subclassification. Pignot G, Elie C, Conquy S, Vieillefond A, Flam T, Zerbib M, Debre B, Amsellem-Ouazana D. Urology. 2007:230-5. [pmid: 17275070].
Prognostic relevance of capsular involvement and collecting system invasion in stage I and II renal cell carcinoma. Klatte T, Chung J, Leppert JT, Lam JS, Pantuck AJ, Figlin RA, Belldegrun AS. BJU Int. 2007:821-4. [pmid: 17244281].
Dynamic outcome prediction in patients with clear cell renal cell carcinoma treated with radical nephrectomy: the D-SSIGN score. Thompson RH, Leibovich BC, Lohse CM, Cheville JC, Zincke H, Blute ML, Frank I. J Urol. 2007:477-80. [pmid: 17222614].
Opened vs laparoscopic radical nephrectomy in renal adenocarcinoma cost comparison. Herranz Amo F, Subira Rios D, Hernandez Fernandez C, Martinez Salamanca JI, Monzo JI, Cabello Benavente R. Actas Urol Esp. 2006:921-5. [pmid: 17175932].
Results of computerized tomography guided percutaneous ablation of renal masses with nondiagnostic pre-ablation pathological findings. Permpongkosol S, Link RE, Solomon SB, Kavoussi LR. J Urol. 2006:463-7. discussion 467. [pmid: 16813865].
Mini-flank supra-11th rib incision for open partial or radical nephrectomy. Diblasio CJ, Snyder ME, Russo P. BJU Int. 2006:149-56. [pmid: 16336347].
Laparoscopic nephrectomy: new standard of care?. Sim HG, Yip SK, Ng CY, Teo YS, Tan YH, Siow WY, Cheng WS. Asian J Surg. 2005:277-81. [pmid: 16234079].
Comparison of predictive accuracy of four prognostic models for nonmetastatic renal cell carcinoma after nephrectomy: a multicenter European study. Cindolo L, Patard JJ, Chiodini P, Schips L, Ficarra V, Tostain J, de La Taille A, Altieri V, Lobel B, Zigeuner RE, Artibani W, Guille F, Abbou CC, Salzano L, Gallo C. Cancer. 2005:1362-71. [pmid: 16116599].
Prior abdominal surgery and radiation do not complicate the retroperitoneoscopic approach to the kidney or adrenal gland. Viterbo R, Greenberg RE, Al-Saleem T, Uzzo RG. J Urol. 2005:446-50. [pmid: 16006862].
Urological retroperitoneoscopic surgery for patients with prior intra-abdominal surgery. Mita K, Shigeta M, Mutaguchi K, Matsubara A, Yoshino T, Seki M, Mochizuki H, Kato M, Teishima J, Kadonishi Y, Yasumoto H, Usui T. Eur Urol. 2005:97-101. [pmid: 15967258].
The accuracy of 250 fine needle biopsies of renal tumors. Wunderlich H, Hindermann W, Al Mustafa AM, Reichelt O, Junker K, Schubert J. J Urol. 2005:44-6. [pmid: 15947574].
Comparison of presentation and outcome for patients 18 to 40 and 60 to 70 years old with solid renal masses. Gillett MD, Cheville JC, Karnes RJ, Lohse CM, Kwon ED, Leibovich BC, Zincke H, Blute ML. J Urol. 2005:1893-6. [pmid: 15879770].
Laparoscopic heminephrectomy for tumor. Finelli A, Gill IS, Desai MM, Tan YH, Moinzadeh A, Singh D, Kaouk JH. Urology. 2005:473-8. [pmid: 15780358].
Laparoscopic specimen extraction: morcellation. Varkarakis I, Rha K, Hernandez F, Kavoussi LR, Jarrett TW. BJU Int. 2005:27-31. [pmid: 15759350].
Hand-assisted retroperitoneoscopic radical nephrectomy and nephroureterectomy. Kawauchi A, Fujito A, Soh J, Ukimura O, Mizutani Y, Miki T. J Endourol. 2004:365-9. [pmid: 15253787].
Effect of papillary and chromophobe cell type on disease-free survival after nephrectomy for renal cell carcinoma. Beck SD, Patel MI, Snyder ME, Kattan MW, Motzer RJ, Reuter VE, Russo P. Ann Surg Oncol. 2004:71-7. [pmid: 14699037].
Closed suction or penrose drainage after partial nephrectomy: does it matter?. Sanchez-Ortiz R, Madsen LT, Swanson DA, Canfield SE, Wood CG. J Urol. 2004:244-6. [pmid: 14665885].
Racial disparity in incidence patterns and outcome of kidney cancer. Vaishampayan UN, Do H, Hussain M, Schwartz K. Urology. 2003:1012-7. [pmid: 14665346].
Renal cell carcinoma as a cause of end-stage renal disease in the United States: patient characteristics and survival. Stiles KP, Moffatt MJ, Agodoa LY, Swanson SJ, Abbott KC. Kidney Int. 2003:247-53. [pmid: 12787416].
Loss of expression of transforming growth factor-beta receptor as a prognostic factor in patients with renal cell carcinoma. Miyajima A, Asano T, Seta K, Asano T, Kakoi N, Hayakawa M. Urology. 2003:1072-7. [pmid: 12736050].
Comparisons of outcome and prognostic features among histologic subtypes of renal cell carcinoma. Cheville JC, Lohse CM, Zincke H, Weaver AL, Blute ML. Am J Surg Pathol. 2003:612-24. [pmid: 12717246].
Influence of age on the prognosis of patients with renal cell carcinoma (RCC). Yusim I, Mermershtain W, Neulander E, Eidelberg I, Gusakova I, Kaneti J. Onkologie. 2002:548-50. [pmid: 12566900].
Prospective analysis of computerized tomography and needle biopsy with permanent sectioning to determine the nature of solid renal masses in adults. Dechet CB, Zincke H, Sebo TJ, King BF, LeRoy AJ, Farrow GM, Blute ML. J Urol. 2003:71-4. [pmid: 12478106].
Transcatheter renal arterial embolization in malignant renal neoplasms: clinical results and indications for use of the method in multi-profile hospitals. Vaicekavicius E, Pranculis A. Medicina (Kaunas). 2002:888-91. [pmid: 12474771].
Prediction of post-operative glomerular filtration rate after nephrectomy for renal malignancy. Johansson M, Moonen M. Clin Physiol. 2001:688-92. [pmid: 11722476].
Renal cell carcinoma: evaluation of the 1997 TNM system and recommendations for follow-up after surgery. Gofrit ON, Shapiro A, Kovalski N, Landau EH, Shenfeld OZ, Pode D. Eur Urol. 2001:669-74. discussion 675. [pmid: 11464056].
Carcinological risks and retroperitoneal laparoscopy. Cicco A, Salomon L, Hoznek H, Alame W, Saint F, Bralet MP, Antiphon P, Chopin DK, Abbou CC. Eur Urol. 2000:606-12. [pmid: 11096244].
Stage specific guidelines for surveillance after radical nephrectomy for local renal cell carcinoma. Levy DA, Slaton JW, Swanson DA, Dinney CP. J Urol. 98:1163-7.
RENAL nephrometry score is a predictive factor for the annual growth rate of renal mass. Matsumoto R, Abe T, Shinohara N, Murai S, Maruyama S, Tsuchiya K, Nonomura K. Int J Urol. 2014:549-552. [pmid: 24405437].
Clinical outcome of small renal cell carcinoma after delayed surgery versus immediate surgery. Sugimoto K, Shimizu N, Nose K, Tahara H, Imanishi M, Nishioka T, Esa A, Kajikawa H, Uemura H. J Cancer. 2013:514-518. [pmid: 23901351].
Laparoendoscopic single-site surgery in urology: Worldwide multi-institutional analysis of 1076 cases. Kaouk JH, Autorino R, Kim FJ, Han DH, Lee SW, Yinghao S, Cadeddu JA, Derweesh IH, Richstone L, Cindolo L, Branco A, Greco F, Allaf M, Sotelo R, Liatsikos E, Stolzenburg J-U, Rane A, White WM, Han WK, Haber G-P, White MA, Molina WR, Jeong BC, Lee JY, Linhui W, Best S, Stroup SP, Rais-Bahrami S, Schips L, Fornara P, Pierorazio P, Giedelman C, Lee JW, Stein RJ, Rha KH. Eur Urol. 2011:998-1005. [pmid: 21684069].
Role of Intraarterial Embolization before Cryoablation of Large Renal Tumors: A Pilot Study. Woodrum DA, Atwell TD, Farrell MA, Andrews JC, Charboneau JW, Callstrom MR. J Vasc Intervent Radiol. 2010:930-936.
A Comparative Study of Quality of Life Issues Relating to Open Versus Laparoscopic Nephrectomy: A Prospective Pragmatic Study. Harryman OA, Davenport K, Keoghane S, Keeley FX, Timoney AG. J Urol. 2009:998-1003. [pmid: 19150558].
Extensively cystic renal neoplasms in adults (Bosniak Classification II or III) - Possible &quot;common&quot; histological diagnoses: Multilocular cystic renal cell carcinoma, cystic nephroma, and mixed epithelial and stromal tumor of the kidney. Hora M, Hes O, Michal M, Boudova L, Chudacek Z, Kreuzberg B, Klecka J. Int Urol Nephrol. 2005:743-750. [pmid: 16362592].
Complications of transperitoneal laparoscopic surgery in urology: Review of 1,311 procedures at a single center. Vallancien G, Cathelineau X, Baumert H, Doublet JD, Guillonneau B. J Urol. 2002:23-26. [pmid: 12050484].
Renal cell carcinoma: Clinical and therapeutic considerations about 301 cases. Destito A, Servello C, Pisanti F, Lacquaniti S, Candidi MO, Racioppi M, Alcini E. Acta Med Rom. 99:498-503.
Original report Three-dimensional CT stereoscopic visualization of renal masses: Impact on diagnosis and patient treatment. Smith PA, Marshall FF, Urban BA, Heath DG, Fishman EK. AM J ROENTGENOL. 97:1331-1334.
Diagnosis of renal angiomyolipoma with hounsfield unit thresholds: effect of size of region of interest and nephrographic phase imaging. Davenport MS, Neville AM, Ellis JH, Cohan RH, Chaudhry HS, Leder RA. Radiology. 2011:158-65. [pmid: 21555349].
Differentiation of clear from non-clear cell renal cell carcinoma using CT washout formula. Kopp RP, Aganovic L, Palazzi KL, Cassidy FH, Sakamoto K, Derweesh IH. Can J Urol. 2013:6790-7. [pmid: 23783049].
3D cone-beam CT guidance, a novel technique in renal biopsy--results in 41 patients with suspected renal masses. Braak SJ, van Melick HH, Onaca MG, van Heesewijk JP, van Strijen MJ. Eur Radiol. 2012:2547-52. [pmid: 22660984].
Diagnostic accuracy of segmental enhancement inversion for the diagnosis of renal oncocytoma using biphasic computed tomography (CT) and multiphase contrast-enhanced magnetic resonance imaging (MRI). Schieda N, Al-Subhi M, Flood TA, El-Khodary M, McInnes MD. Eur Radiol. 2014:2787-94. [pmid: 25027841].
Unenhanced CT for the Diagnosis of Minimal-Fat Renal Angiomyolipoma. Schieda N, Hodgdon T, El-Khodary M, Flood TA, McInnes MD. AJR Am J Roentgenol. 2014:1236-41. [pmid: 25415700].
Use of electron microscopy in core biopsy diagnosis of oncocytic renal tumors. Johnson NB, Johnson MM, Selig MK, Nielsen GP. Ultrastruct Pathol. 2010:189-94. [pmid: 20594037].
Unenhanced CT for the detection of renal cell carcinoma: effect of tumor size and contour type. Jung SI, Park HS, Kim YJ, Jeon HJ. Abdom Imaging. 2014:348-57. [pmid: 24407727].
Computed tomography-guided renal tumor biopsies: tumor imaging features affecting sample adequacy. Davis IC, Heilbrun ME, Tangtiang K, Childs DD, Zagoria RJ. J Comput Assist Tomogr. 2013:171-5. [pmid: 23493205].
Histogram analysis of small solid renal masses: differentiating minimal fat angiomyolipoma from renal cell carcinoma. Chaudhry HS, Davenport MS, Nieman CM, Ho LM, Neville AM. AJR Am J Roentgenol. 2012:377-83. [pmid: 22268181].
Predicting the histology of small renal masses using preoperative dynamic contrast-enhanced magnetic resonance imaging. Kim JH, Bae JH, Lee KW, Kim ME, Park SJ, Park JY. Urology. 2012:872-6. [pmid: 22854134].
Analysis of surgical complications of renal tumor enucleation with standardized instruments and external validation of PADUA classification. Minervini A, Vittori G, Salvi M, Sebastianelli A, Tuccio A, Siena G, Masieri L, Gacci M, Lapini A, Serni S, Carini M. Ann Surg Oncol. 2013:1729-36. [pmid: 23263701].
Indications for renal fine needle aspiration biopsy in the era of modern imaging modalities. Dragoescu EA, Liu L. Cytojournal. 2013:15. [pmid: 23976896].
Comparison of Cox regression with other methods for determining prediction models and nomograms. Kattan MW. J Urol. 2003:S6-9. discussion S10. [pmid: 14610404].
Role of ultrasonography in screening for urological malignancies in patients presenting with painless haematuria. Yip SK, Peh WC, Tam PC, Li JH, Lam CH. Ann Acad Med Singapore. 99:174-7.
FDG PET characterization of renal masses: preliminary experience. Goldberg MA, Mayo-Smith WW, Papanicolaou N, Fischman AJ, Lee MJ. Clin Radiol. 97:510-5.
Screening for renal cell carcinoma using ultrasonography: a feasibility study. Filipas D, Spix C, Schulz-Lampel D, Michaelis J, Hohenfellner R, Roth S, Thuroff JW. BJU Int. 2003:595-9. [pmid: 12699466].
Comparison of 16-MDCT and MRI for characterization of kidney lesions. Beer AJ, Dobritz M, Zantl N, Weirich G, Stollfuss J, Rummeny EJ. AJR Am J Roentgenol. 2006:1639-50. [pmid: 16714654].
Computer-aided detection of kidney tumor on abdominal computed tomography scans. Kim DY, Park JW. Acta Radiol. 2004:791-5. [pmid: 15624525].
Multiphasic helical CT of the kidney: increased conspicuity for detection and characterization of small (< 3-cm) renal masses. Szolar DH, Kammerhuber F, Altziebler S, Tillich M, Breinl E, Fotter R, Schreyer HH. Radiology. 97:211-7.
Effectiveness of contrast enhanced ultrasonography in the assesment of renal masses. Alvarez Rodriguez S, Sanz Mayayo E, Lopez- Fando Lavalle L, Rodriguez-Patron Rodriguez R, Arias Funez F, Hevia Palacios V, Burgos Revilla FJ. Eur Urol Suppl. 2014:e393-e393a.
Growth kinetics of small renal masses: A prospective analysis from the renal cell carcinoma consortium of Canada. Organ M, Jewett M, Abdolell M, Basiuka J, Fleshner N, Finelli A, Morash C, Pautler S, Chin J, Siemens R, Tanguay S, Gleave M, Drachenberg D, Chow R, Evans A, Gallie B, Haider M, Kachura J, Rendon R. J Urol. 2013:e482.
Can we predict malignancy in bosniak III renal lesions identified on multiphasic CT?. Goenka A, Remer E, Smith A, Obuchowski N, Klink J, Campbell S. Am J Roentgenol. 2012.
Evaluation of renal tumors by Image Guided biopsies with an empahasis on oncocytic neoplasms: A retrospective four year study from a large academic institution. Bhalla R, Wu A, Kunju L. J Urol. 2011:e282.
Evaluation of renal tumors by image guided biopsies with an emphasis on oncocytic neoplasms: A retrospective four year study from a large academic institution. Bhalla R, Wu A, Kunju LP. Lab Invest. 2011:180A.
Incidental detection of preclinical renal tumors with electron beam computed tomography: Report of 26 consecutive operated patients. Mitchell TL, Pippin JJ, Devers SM, Kimball TE, Gibbons LW, Cooper LL, Gonzalez-Dunn V, Cooper KH. J Comput Assisted Tomogr. 2000:843-845.
Identification of the MN/CA9 protein as a reliable diagnostic biomarker of clear cell carcinoma of the kidney. Liao S-Y, Aurelio ON, Jan K, Zavada J, Stanbridge EJ. CANCER RES. 97:2827-2831.
Readmissions after major urologic cancer surgery. Leow JJ, Gandaglia G, Sood A, Ruhotina N, Klett DE, Sammon JD, Schmid M, Sun M, Chang SL, Kibel AS, Trinh QD. Can J Urol. 2014:7537-46. [pmid: 25483761].
The diagnostic accuracy of percutaneous renal needle core biopsy and its potential impact on the clinical management of renal cortical neoplasms. Gellert LL, Mehra R, Chen YB, Gopalan A, Fine SW, Al-Ahmadie H, Reuter VE, Tickoo SK. Arch Pathol Lab Med. 2014:1673-9. [pmid: 25427045].
High rate of benign histology in radiologically suspect renal lesions. Lindkvist Pedersen C, Winck-Flyvholm L, Dahl C, Azawi NH. Dan Med J. 2014:A4932. [pmid: 25283622].
Predictors of 30-day acute kidney injury following radical and partial nephrectomy for renal cell carcinoma. Schmid M, Abd-El-Barr AE, Gandaglia G, Sood A, Olugbade K Jr, Ruhotina N, Sammon JD, Varda B, Chang SL, Kibel AS, Chun FK, Menon M, Fisch M, Trinh QD. Urol Oncol. 2014:1259-66. [pmid: 25129142].
Risk evaluation of selective renal arterial embolization in the treatment of delayed hemorrhage from renal artery pseudoaneurysm after partial nephrectomy. Zhu Y, Liu Y, Zhang J, Lin Z. Cell Biochem Biophys. 2014:1833-9. [pmid: 25048525].
Management, pathology and outcomes of Bosniak category IIF and III cystic renal lesions. Weibl P, Hora M, Kollarik B, Shariat SF, Klatte T. World J Urol. 2015:295-300. [pmid: 24744224].
Evaluation of percutaneous biopsies of renal masses under MRI-guidance: a retrospective study about 26 cases. Garnon J, Schlier A, Buy X, Tsoumakidou G, de Mathelin M, Breton E, Gangi A. Eur Radiol. 2015:617-23. [pmid: 25312553].
Visceral fat accumulation is associated with different pathological subtypes of renal cell carcinoma (RCC): A multicentre study in China. Wang H-K, Song X-S, Cheng Y, Qu Y-Y, Zhang S-L, Dai B, Zhang H-L, Shen Y-J, Zhu Y-P, Shi G-H, Qin X-J, Ma C-G, Lin G-W, Xiao W-J, Zhu Y, Ye D-W. BJU Int. 2014:496-502. [pmid: 25383400].
Visceral obesity in predicting oncologic outcomes of localized renal cell carcinoma. Park YH, Lee JK, Kim KM, Kook HR, Lee H, Kim KB, Lee S, Byun S-S, Lee SE. J Urol. 2014:1043-1049. [pmid: 24704011].
MR imaging in the characterization of small renal masses. Willatt JM, Hussain HK, Chong S, Kappil M, Azar SF, Liu PS, Ruma JA, Elsayes KM. Abdom Imaging. 2014:761-769. [pmid: 24615511].
Routinely performed multiparametric magnetic resonance imaging helps to differentiate common subtypes of renal tumours. Cornelis F, Tricaud E, Lasserre AS, Petitpierre F, Bernhard JC, Le Bras Y, Yacoub M, Bouzgarrou M, Ravaud A, Grenier N. Eur Radiol. 2014:1068-1080. [pmid: 24557052].
Small renal masses managed with active surveillance: Predictors of tumor growth rate after long-term follow-up. Schiavina R, Borghesi M, Dababneh H, Bianchi L, Longhi B, Diazzi D, Monti C, La Manna G, Martorana G, Brunocilla E. Clin Genitourin Cancer. 2015:e87-e92. [pmid: 25450030].
A prospective, multicenter evaluation of predictive factors for positive surgical margins after nephron-sparing surgery for renal cell carcinoma: The record1 italian project. Schiavina R, Serni S, Mari A, Antonelli A, Bertolo R, Bianchi G, Brunocilla E, Borghesi M, Carini M, Longo N, Martorana G, Mirone V, Morgia G, Porpiglia F, Rocco B, Rovereto B, Simeone C, Sodano M, Terrone C, Ficarra V, Minervini A. Clin Genitourin Cancer. 2015:165-170. [pmid: 25450033].
Preoperative serum cholesterol is an independent prognostic factor for patients with renal cell carcinoma (RCC). De Martino M, Leitner CV, Seemann C, Hofbauer SL, Lucca I, Haitel A, Shariat SF, Klatte T. BJU Int. 2015:397-404. [pmid: 24698164].
Notch1 predicts recurrence and survival of patients with clear-cell renal cell carcinoma after surgical resection. An H, Zhu Y, Xu L, Chen L, Lin Z, Xu J. Urology. 2015:483.e9-483.e14. [pmid: 25559729].
Snail predicts recurrence and survival of patients with localized clear cell renal cell carcinoma after surgical resection. Liu W, Liu Y, Liu H, Zhang W, An H, Xu J. Urol Oncol Semin Orig Invest. 2015:69e1-69e10.
Survival in patients with clear cell renal cell carcinoma is predicted by HIF-1(alpha) expression. Minardi D, Lucarini G, Santoni M, Mazzucchelli R, Burattini L, Conti A, Principi E, Bianconi M, Scartozzi M, Milanese G, Di Primio R, Montironi R, Cascinu S, Muzzonigro G. Anticancer Res. 2015:433-438. [pmid: 25550584].
A novel mathematical model to predict the severity of postoperative functional reduction before partial nephrectomy: The importance of calculating resected and ischemic volume. Shin TY, Komninos C, Kim DW, So KS, Bang KS, Jeong H-J, Han WK, Hong SJ, Jung BH, Lim SK, Lee SK, Lee WK, Rha KH. J Urol. 2015:423-429. [pmid: 25063491].
Diagnostic accuracy of preoperative computed tomography used alone to detect lymph-node involvement at radical nephrectomy. Connolly SS, Raja A, Stunell H, Parashar D, Upponi S, Warren AY, Gnanapragasam VJ, Eisen T. Scand J Urol. 2015:142-148. [pmid: 25623950].
TriMatch comparison of the efficacy of FloSeal versus TachoSil versus no hemostatic agents for partial nephrectomy: Results from a large multicenter dataset. Antonelli A, Minervini A, Mari A, Bertolo R, Bianchi G, Lapini A, Longo N, Martorana G, Mirone V, Morgia G, Novara G, Porpiglia F, Rocco B, Rovereto B, Schiavina R, Simeone C, Sodano M, Terrone C, Ficarra V, Carini M, Serni S. Int J Urol. 2015:47-52. [pmid: 25139104].
Current patterns of presentation and treatment of renal masses: A clinical research office of the endourological society prospective study. Laguna MP, Algaba F, Cadeddu J, Clayman R, Gill I, Gueglio G, Hohenfellner M, Joyce A, Landman J, Lee B, Van Poppel H. J Endourol. 2014:861-870. [pmid: 24555480].
Diagnosis of complex renal cystic masses and solid renal lesions using PET imaging: Comparison of 11C-acetate and 18F-FDG PET imaging. Oyama N, Ito H, Takahara N, Miwa Y, Akino H, Kudo T, Okazawa H, Fujibayashi Y, Komatsu K, Tsukahara K, Yokoyama O. Clin Nucl Med. 2014:e208-e214. [pmid: 24217534].
Evaluation of long-term outcome for patients with renal cell carcinoma after surgery: Analysis of cancer deaths occurring more than 10 years after initial treatment. Kyoda Y, Kobayashi K, Hirobe M, Shindo T, Fukuta F, Hashimoto K, Tanaka T, Tonooka A, Kitamura H, Takahashi S, Masumori N, Hasegawa T, Tsukamoto T. Int J Clin Oncol. 2014:146-151. [pmid: 23404486].
Hilar Location is an Independent Prognostic Factor for Recurrence in T1 Renal Cell Carcinoma After Nephrectomy. Shim M, Song C, Park S, Kim A, Choi S-K, Kim C-S, Ahn H. Ann Surg Oncol. 2014:344-350. [pmid: 25323469].
Results of a prospective study comparing the clinical efficacy of cryoablation of renal cell cancer followed by immediate partial nephrectomy. Khoder WY, Siegert S, Stief CG, Becker AJ, Waidelich R. Eur J Surg Oncol. 2014:96-102. [pmid: 24139636].
Clinicopathological characteristics and outcomes of surgically excised renal masses in African Americans. Qi P, Tsivian M, Abern MR, Passoni NM, McGinley KF, Polascik TJ. Urol Oncol Semin Orig Invest. 2014:555-560.
Anatomic complexity quantitated by nephrometry score is associated with prolonged warm ischemia time during robotic partial nephrectomy. Tomaszewski JJ, Smaldone MC, Mehrazin R, Kocher N, Ito T, Abbosh P, Baber J, Kutikov A, Viterbo R, Chen DYT, Canter DJ, Uzzo RG. Urology. 2014:340-344. [pmid: 24925833].
Adverse health outcomes associated with surgical management of the small renal mass. Shuch B, Hanley JM, Lai JC, Vourganti S, Setodji CM, Dick AW, Chow W-H, Saigal CS. J Urol. 2014:301-308. [pmid: 24012580].
Pathologic validation of renal cell carcinoma histology in the Surveillance, Epidemiology, and End Results program. Shuch B, Hofmann JN, Merino MJ, Nix JW, Vourganti S, Linehan WM, Schwartz K, Ruterbusch JJ, Colt JS, Purdue MP, Chow W-H. Urol Oncol Semin Orig Invest. 2014:23.e9-23.e13.
Delay in nephrectomy and cancer control outcomes in elderly patients with small renal masses. Becker A, Roghmann F, Ravi P, Tian Z, Kluth LA, Gandaglia G, Noldus J, Dahlem R, Schlomm T, Graefen M, Karakiewicz PI, Trinh Q-D, Sun M. Urol Int. 2014:455-461. [pmid: 24602994].
The key role of time in predicting progression-free survival in patients with renal cell carcinoma treated with partial or radical nephrectomy: Conditional survival analysis. Abdollah F, Suardi N, Capitanio U, Matloob R, Fossati N, Castiglione F, Di Trapani E, Di Trapani D, Russo A, Carenzi C, Montorsi F, Rigatti P, Bertini R. Urol Oncol Semin Orig Invest. 2014:43.e9-43.e16.
Patients with anatomically &quot;simple&quot; renal masses are more likely to be placed on active surveillance than those with anatomically &quot;complex&quot; lesions. Tomaszewski JJ, Uzzo RG, Kocher N, Li T, Manley B, Mehrazin R, Ito T, Abbosh P, Viterbo R, Chen DYT, Greenberg RE, Canter D, Smaldone MC, Kutikov A. Urol Oncol Semin Orig Invest. 2014:1267-1271.
Can selective arterial clamping with fluorescence imaging preserve kidney function during robotic partial nephrectomy?. McClintock TR, Bjurlin MA, Wysock JS, Borofsky MS, Marien TP, Okoro C, Stifelman MD. Urology. 2014:327-332. [pmid: 24909960].
Race and sex disparities in the treatment of older patients with T1a renal cell carcinoma: A comorbidity-controlled competing-risks model. Patel HD, Kates M, Pierorazio PM, Allaf ME. Urol Oncol Semin Orig Invest. 2014:576-583.
Clinical behavior of chromophobe renal cell carcinoma is less aggressive than that of clear cell renal cell carcinoma, independent of Fuhrman grade or tumor size. Steffens S, Roos FC, Janssen M, Becker F, Steinestel J, Abbas M, Steinestel K, Wegener G, Siemer S, Thuroff JW, Hofmann R, Stockle M, Schrader M, Hartmann A, Junker K, Kuczyk MA, Schrader AJ. Virchows Arch. 2014:439-444. [pmid: 25178561].
The impact of perioperative blood transfusion on survival after nephrectomy for non-metastatic renal cell carcinoma (RCC). Linder BJ, Thompson RH, Leibovich BC, Cheville JC, Lohse CM, Gastineau DA, Boorjian SA. BJU Int. 2014:368-374. [pmid: 24471825].
Outcomes in patients undergoing nephrectomy for renal cancer on chronic anticoagulation therapy. Sfakianos JP, Hakimi AA, Kim PH, Zabor EC, Mano R, Bernstein M, Karellas M, Russo P. Eur J Surg Oncol. 2014:1700-1705. [pmid: 24813810].
Evaluation of renal mass biopsy risk stratification algorithm for robotic partial nephrectomy - Could a biopsy have guided management?. Rahbar H, Bhayani S, Stifelman M, Kaouk J, Allaf M, Marshall S, Zargar H, Ball MW, Larson J, Rogers C. J Urol. 2014:1337-1342. [pmid: 24936720].
Hand-assisted partial nephrectomy with early arterial clamp removal: Impact of the learning curve. Azawi NH, Norus TP, Wittendorff H-E, Dahl C. Scand J Urol. 2014:538-543. [pmid: 24930565].
Renal masses measuring under 2 cm: Pathologic outcomes and associations with MRI features. Rosenkrantz AB, Wehrli NE, Melamed J, Taneja SS, Shaikh MB. Eur J Radiol. 2014:1311-1316. [pmid: 24882784].
Tumor enucleation vs sharp excision in minimally invasive partial nephrectomy: Technical benefit without impact on functional or oncologic outcomes. Mukkamala A, Allam CL, Ellison JS, Hafez KS, Miller DC, Montgomery JS, Weizer AZ, Wolf JS Jr. Urology. 2014:1294-1299. [pmid: 24713137].
Race and sex disparities in the treatment of older patients with T1a renal cell carcinoma: a comorbidity-controlled competing-risks model. Patel HD, Kates M, Pierorazio PM, Allaf ME. Urol Oncol. 2014:576-83. [pmid: 24629500].
Cystic renal cell carcinomas: do they grow, metastasize, or recur?. Jhaveri K, Gupta P, Elmi A, Flor L, Moshonov H, Evans A, Jewett M. AJR Am J Roentgenol. 2013:W292-6. [pmid: 23883243].
Safety of en bloc ligation of the renal hilum during laparoscopic radical nephrectomy for renal cell carcinoma: a randomized controlled trial. Chung JH, Lee SW, Lee KS, Cho WY, Kim TH. J Laparoendosc Adv Surg Tech A. 2013:489-94. [pmid: 23621831].
Evaluation of perirenal fat as a predictor of cT1a renal cortical neoplasm histopathology and surgical outcomes. Okhunov Z, Mues AC, Kline M, Haramis G, Xu B, Mirabile G, Vira M, Landman J. J Endourol. 2012:911-916. [pmid: 22380739].
Bilateral renal cell carcinoma. Therapy management and histopathological results in long-term follow-up of 66 patients. Der bilaterale nierentumor. Therapiemanagement und histopathologische ergebnisse mit langzeitverlauf bei 66 patienten. Siemer S, Uder M, Zell A, Ponicke C, Humke U, Ziegler M, Stockle M. Urologe Ausg A. 2001:114-120.
Laparoscopic procedures in urology. Laparoskopische operationen in der urologie. Turk I, Deger S, Schonberger B, Loening SA. J Urol Urogynakol. 99:69-72.
Characterization of small solid renal lesions: can benign and malignant tumors be differentiated with CT?. Millet I, Doyon FC, Hoa D, Thuret R, Merigeaud S, Serre I, Taourel P. AJR Am J Roentgenol. 2011:887-96. [pmid: 21940576].
The accuracy of renal tumor biopsy: analysis from a national prospective study. Bernhard JC, Bigot P, Pignot G, Baumert H, Zini L, Lang H, Crepel M, Monod P, Salomon L, Bellec L, Roupret M, Schneider M, Xylinas E, Paparel P, Bruyere F, Berger J, Ansieau JP, Gimel P, Salome F, Castagnola C, Pfister C, Legraverend JM, Timsit MO, Le Pellec L, Auberget JL, Rolland E, Mallet R, Mejean A, Patard JJ. World J Urol. 2014.
Can Quantitative CT Texture Analysis be Used to Differentiate Fat-poor Renal Angiomyolipoma from Renal Cell Carcinoma on Unenhanced CT Images?. Hodgdon T, McInnes MD, Schieda N, Flood TA, Lamb L, Thornhill RE. Radiology. 2015:142215.
Value of the diffusion-weighted MRI in the differential diagnostics of malignant and benign kidney neoplasms - Our clinical experience. Mytsyk Y, Borys Y, Komnatska I, Dutka I, Shatynska-Mytsyk I. Pol J Radiol. 2014:290-295. [pmid: 25202435].
Renal sinus exposure as an independent factor predicting asymptomatic unruptured pseudoaneurysm formation detected in the early postoperative period after minimally invasive partial nephrectomy. Omae K, Kondo T, Takagi T, Morita S, Hashimoto Y, Kobayashi H, Iizuka J, Nozaki T, Yoshida K, Tanabe K. Int J Urol. 2015:356-361. [pmid: 25581594].
Differentiation of renal oncocytoma and renal clear cell carcinoma using relative CT enhancement ratio. Ren A, Cai F, Shang Y-N, Ma E-S, Huang Z-G, Wang W, Lu Y, Zhang X-Z. Chin Med J. 2015:175-179. [pmid: 25591558].
Do we need to clamp the renal hilum liberally during the initial phase of the learning curve of robot-assisted nephron-sparing surgery?. Acar O, Esen T, Musaoglu A, Vural M. Sci World J. 2014.

## Does not provide any OUTCOME of interest

Clinicopathologic Outcomes of Cystic Renal Cell Carcinoma. Donin NM, Mohan S, Pham H, Chandarana H, Doshi A, Deng FM, Stifelman MD, Taneja SS, Huang WC. Clin Genitourin Cancer. 2014.
Surgeon-specific factors affecting treatment decisions among Canadian urologists in the management of pT1a renal tumours. Millman AL, Pace KT, Ordon M, Lee JY. Can Urol Assoc J. 2014:183-9. [pmid: 25024788].
Patients with anatomically &quot;simple&quot; renal masses are more likely to be placed on active surveillance than those with anatomically &quot;complex&quot; lesions. Tomaszewski JJ, Uzzo RG, Kocher N, Li T, Manley B, Mehrazin R, Ito T, Abbosh P, Viterbo R, Chen DY, Greenberg RE, Canter D, Smaldone MC, Kutikov A. Urol Oncol. 2014.
Flank muscle volume changes after open and laparoscopic partial nephrectomy. Crouzet S, Chopra S, Tsai S, Kamoi K, Haber GP, Remer EM, Berger AK, Gill IS, Aron M. J Endourol. 2014:1202-7. [pmid: 24894128].
R.E.N.A.L. Nephrometry scoring: how well correlated are urologist, radiologist, and collaborator scores?. Monn MF, Gellhaus PT, Masterson TA, Patel AA, Tann M, Cregar DM, Boris RS. J Endourol. 2014:1006-10. [pmid: 24708445].
Practice patterns for the surgical treatment of T1 renal cell carcinoma: A nationwide population-based register study. Ljungberg B, Gudmundsson E, Christensen S, Lundstam S. Scand J Urol. 2014:445-52. [pmid: 24666103].
Incidence of hypercoagulable events after image-guided percutaneous cryoablation of renal tumors: a single-center experience. Hartman JB, Bhojwani N, Corn DJ, Cooney MM, Haaga J, Ponsky L, Abouassaly R, Paspulati A, Prologo JD. J Vasc Interv Radiol. 2014:776-9. [pmid: 24656177].
Practical and intuitive surgical approach renal ranking to predict outcomes in the management of renal tumors: a novel score tool. Tannus M, Goldman SM, Andreoni C. J Endourol. 2014:487-92. [pmid: 24437510].
Histopathologic findings of small renal tumor biopsies performed immediately after cryoablation therapy: a retrospective study of 50 cases. Tayal S, Kim FJ, Sehrt D, Miano R, Pompeo A, Molina W. Am J Clin Pathol. 2014:35-42. [pmid: 24343735].
Pathological characteristics and prognostic effect of peritumoral capsule penetration in renal cell carcinoma after tumor enucleation. Minervini A, Rosaria Raspollini M, Tuccio A, Di Cristofano C, Siena G, Salvi M, Vittori G, Sebastianelli A, Lapini A, Serni S, Carini M. Urol Oncol. 2014:50.e15-22. [pmid: 24239462].
Adverse health outcomes associated with surgical management of the small renal mass. Shuch B, Hanley JM, Lai JC, Vourganti S, Setodji CM, Dick AW, Chow WH, Saigal CS. J Urol. 2014:301-8. [pmid: 24012580].
Overall survival advantage with partial nephrectomy: a bias of observational data?. Shuch B, Hanley J, Lai J, Vourganti S, Kim SP, Setodji CM, Dick AW, Chow WH, Saigal C. Cancer. 2013:2981-9. [pmid: 23674264].
Is diameter-axial-polar scoring predictive of renal functional damage in patients undergoing partial nephrectomy? An evaluation using technetium Tc 99m ((9)(9)Tcm) diethylene-triamine-penta-acetic acid (DTPA) glomerular filtration rate. Wang L, Li M, Chen W, Wu Z, Cai C, Xiang C, Sheng J, Liu B, Yang Q, Sun Y. BJU Int. 2013:1191-8. [pmid: 23651467].
Renal lymph nodes for tumor staging: appraisal of 871 nephrectomies with examination of hilar fat. Mehta V, Mudaliar K, Ghai R, Quek ML, Milner J, Flanigan RC, Picken MM. Arch Pathol Lab Med. 2013:1584-90. [pmid: 23651149].
Evaluation of anatomic and morphologic nomogram to predict malignant and high-grade disease in a cohort of patients with small renal masses. Bagrodia A, Harrow B, Liu ZW, Olweny EO, Faddegon S, Yin G, Tan YK, Han WK, Lotan Y, Margulis V, Cadeddu JA. Urol Oncol. 2014:37.e17-23. [pmid: 23628308].
Trends in partial and radical nephrectomy: an analysis of case logs from certifying urologists. Poon SA, Silberstein JL, Chen LY, Ehdaie B, Kim PH, Russo P. J Urol. 2013:464-9. [pmid: 23454156].
Use of nephron-sparing surgery among renal cell carcinoma patients with diabetes and hypertension. Filson CP, Schwartz K, Colt JS, Ruterbusch J, Linehan WM, Chow WH, Miller DC. Urol Oncol. 2014:27.e15-21. [pmid: 23419677].
A comparison of pathologic outcomes of matched robotic and open partial nephrectomies. Mellon MJ, Lucas SM, Kum JB, Cheng L, Sundaram C. Int Urol Nephrol. 2013:381-5. [pmid: 23386247].
Clinical characteristics associated with treatment type for localized renal tumors: implications for practice pattern assessment. Smaldone MC, Churukanti G, Simhan J, Kim SP, Reyes J, Zhu F, Kutikov A, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Urology. 2013:269-75. [pmid: 23374778].
Long-term outcome of small, organ-confined renal cell carcinoma (RCC) is not always favourable. Shindo T, Masumori N, Kobayashi K, Fukuta F, Hirobe M, Tonooka A, Hasegawa T, Kitamura H, Tsukamoto T. BJU Int. 2013:941-5. [pmid: 23350965].
Value of metastin receptor immunohistochemistry in predicting metastasis after radical nephrectomy for pT1 clear cell renal cell carcinoma. Shoji S, Nakano M, Tomonaga T, Kim H, Hanai K, Usui Y, Nagata Y, Miyazawa M, Sato H, Tang XY, Osamura YR, Uchida T, Terachi T, Takeya K. Clin Exp Metastasis. 2013:607-14. [pmid: 23277422].
Patient safety and the diffusion of surgical innovations: a national analysis of laparoscopic partial nephrectomy. Parsons JK, Palazzi K, Chang D, Stroup SP. Surg Endosc. 2013:1674-80. [pmid: 23239306].
Comparison of the 2002 and 2010 TNM classification systems regarding outcome prediction in clear cell and papillary renal cell carcinoma. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Groselj-Strele A, Hoefler G, Pummer K, Zigeuner R. Histopathology. 2013:237-46. [pmid: 23020176].
Renal volumetric analysis: a new paradigm in renal mass treatment assessment. Gorbatiy V, Iremashvili V, Castro A, Mure A, Ortiz N, Castle SM, Leveillee RJ. J Endourol. 2013:361-5. [pmid: 22967235].
Association of clinical and radiographic features with perinephric &quot;sticky&quot; fat. Bylund JR, Qiong H, Crispen PL, Venkatesh R, Strup SE. J Endourol. 2013:370-3. [pmid: 22966767].
Tumour-related imaging parameters predicting the percentage of preserved normal renal parenchyma following nephron sparing surgery: a retrospective study. Aertsen M, De Keyzer F, Van Poppel H, Joniau S, De Wever L, Lerut E, Oyen R, Claus F. Eur Radiol. 2013:280-6. [pmid: 22797982].
Overexpression of IL-32 is a novel prognostic factor in patients with localized clear cell renal cell carcinoma. Lee HJ, Liang ZL, Huang SM, Lim JS, Yoon DY, Lee HJ, Kim JM. Oncol Lett. 2012:490-496. [pmid: 22740938].
Analysis of the evolution of surgery for the treatment of primary renal tumors during the period 2006-2010: report of 458 consecutive surgeries. Bellec L, Thoulouzan M, Soler P, Khedis M, Walschaerts M, Delaunay B, Crenn G, Salloum A, Rouvellat P, Malavaud B, Rischmann P, Plante P, Soulie M, Huyghe E. Prog Urol. 2012:520-8. [pmid: 22732643].
Assessing performance trends in laparoscopic nephrectomy and nephron-sparing surgery for localized renal tumors. Smaldone MC, Kutikov A, Egleston B, Simhan J, Canter DJ, Teper E, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Urology. 2012:286-91. [pmid: 22704174].
Staging lymphadenectomy in renal cell carcinoma must be extended: a sensitivity curve analysis. Capitanio U, Suardi N, Matloob R, Abdollah F, Castiglione F, Briganti A, Carenzi C, Roscigno M, Montorsi F, Bertini R. BJU Int. 2013:412-8. [pmid: 22703190].
Assessment of cancer control outcomes in patients with high-risk renal cell carcinoma treated with partial nephrectomy. Hansen J, Sun M, Bianchi M, Rink M, Tian Z, Hanna N, Meskawi M, Schmitges J, Shariat SF, Chun FK, Perrotte P, Graefen M, Karakiewicz PI. Urology. 2012:347-53. [pmid: 22698478].
The effect of race and gender on the surgical management of the small renal mass. Kates M, Whalen MJ, Badalato GM, McKiernan JM. Urol Oncol. 2013:1794-9. [pmid: 22687567].
Pathological implications of areas of lower enhancement on contrast-enhanced computed tomography in renal-cell carcinoma: additional information for selecting candidates for surveillance protocols. Villalobos-Gollas M, Aguilar-Davidov B, Culebro-Garcia C, Gomez-Alvarado MO, Rojas-Garcia P, Ibarra-Fombona R, Uribe-Uribe N, Feria-Bernal G, Castillejos-Molina R, Sotomayor M, Gabilondo F, Rodriguez-Covarrubias F. Int Urol Nephrol. 2012:1369-74. [pmid: 22648292].
Comparison of two core biopsy techniques before and after laparoscopic cryoablation of small renal cortical neoplasms. Truesdale MD, Mues AC, Sartori S, Casazza CN, Hruby GW, Harik LR, O'Toole KM, Badani KK, Perez-Lanzac A, Landman J. JSLS. 2011:509-16. [pmid: 22643507].
RENAL nephrometry score predicts surgery type independent of individual surgeon's use of nephron-sparing surgery. Tobert CM, Kahnoski RJ, Thompson DE, Anema JG, Kuntzman RS, Lane BR. Urology. 2012:157-61. [pmid: 22626579].
Characteristics and outcomes of tumors arising from the distal nephron. Abern MR, Tsivian M, Polascik TJ, Coogan CL. Urology. 2012:140-6. [pmid: 22626576].
Nephron-sparing surgery: our experience. Crestani A, Guttilla A, Dal Moro F, Valotto C, Zattoni F. Urologia. 2012:97-101. [pmid: 22610838].
Understanding criteria for surveillance of patients with a small renal mass. Jacobs BL, Tan HJ, Montgomery JS, Weizer AZ, Wood DP, Miller DC, Wolf JS Jr, Hafez KS. Urology. 2012:1027-32. [pmid: 22546379].
The role of pathology in small renal mass laparoscopic cryoablation. Lagerveld BW, van Dekken H, van Leenders GJ, van der Zee JA. Adv Urol. 2012:539648. [pmid: 22518116].
Volume-outcome relationships in the treatment of renal tumors. Abouassaly R, Finelli A, Tomlinson GA, Urbach DR, Alibhai SM. J Urol. 2012:1984-8. [pmid: 22498222].
Perioperative outcomes of robotic and open partial nephrectomy for moderately and highly complex renal lesions. Simhan J, Smaldone MC, Tsai KJ, Li T, Reyes JM, Canter D, Kutikov A, Chen DY, Greenberg RE, Uzzo RG, Viterbo R. J Urol. 2012:2000-4. [pmid: 22498208].
Inpatient safety trends in laparoscopic and open nephrectomy for renal tumours. Stroup SP, Palazzi KL, Chang DC, Ward NT, Parsons JK. BJU Int. 2012:1808-13. [pmid: 22471427].
Intraoperative ultrasonography: a useful tool in retrolaparoscopic nephron-sparing surgery. Kang N, Niu Y, Zhang J, Wang J, Tian X, Yan Y, Yu Z, Xing N. Urol Int. 2012:338-42. [pmid: 22441243].
Impact of comorbidity on complications after nephrectomy: use of the Clavien Classification of Surgical Complications. Hennus PM, Kroeze SG, Bosch JL, Jans JJ. BJU Int. 2012:682-7. [pmid: 22432906].
Functional recovery after partial nephrectomy: effects of volume loss and ischemic injury. Simmons MN, Hillyer SP, Lee BH, Fergany AF, Kaouk J, Campbell SC. J Urol. 2012:1667-73. [pmid: 22425124].
Under-grading of &lt;4 cm renal masses on renal biopsy. Harris CR, Whitson JM, Meng MV. BJU Int. 2012:794-7. [pmid: 22404857].
Simplified hemostatic technique during laparoscopic partial nephrectomy. Tsivian A, Tsivian M, Benjamin S, Sidi AA. Int Braz J Urol. 2012:84-8. [pmid: 22397789].
Prognostic nomogram for disease-free survival in patients with renal adenocarcinoma. Di Capua Sacoto C, Budia A, Garcia-Fadrique G, Lujan S, Ruiz-Cerda JL, Jimenez-Cruz JF. Urol Int. 2012:271-6. [pmid: 22378354].
Evolving practice patterns for the management of small renal masses in the USA. Yang G, Villalta JD, Meng MV, Whitson JM. BJU Int. 2012:1156-61. [pmid: 22372984].
Relevance of the clinical-pathological predictive factors in force in chromophobe renal cell cancer. Pardo P, Rodriguez-Faba O, Palou J, Algaba F, Breda A, Esquena S, Villavicencio H. Actas Urol Esp. 2012:527-31. [pmid: 22365081].
Laparoscopic cryotherapy for renal tumours. Grange P, Rouse P, Kouriefs C, Rao A, Karamanolakis D, Roy A, Arya M. BJU Int. 2012:808-17. [pmid: 22339994].
Treatment management of small renal masses in the 21st century: a paradigm shift. Sun M, Abdollah F, Bianchi M, Trinh QD, Jeldres C, Thuret R, Tian Z, Shariat SF, Montorsi F, Perrotte P, Karakiewicz PI. Ann Surg Oncol. 2012:2380-7. [pmid: 22322956].
Higher perioperative morbidity and in-hospital mortality in patients with end-stage renal disease undergoing nephrectomy for non-metastatic kidney cancer: a population-based analysis. Schmitges J, Trinh QD, Sun M, Hansen J, Bianchi M, Jeldres C, Perrotte P, Dahlem R, Shariat SF, Chun FK, Montorsi F, Menon M, Fisch M, Graefen M, Karakiewicz PI. BJU Int. 2012:E183-90. [pmid: 22321256].
Optimal surgical margin in nephron-sparing surgery for T1b renal cell carcinoma. Chen XS, Zhang ZT, Du J, Bi XC, Sun G, Yao X. Urology. 2012:836-9. [pmid: 22305422].
NDRG2 is involved in the oncogenic properties of renal cell carcinoma and its loss is a novel independent poor prognostic factor after nephrectomy. Liang ZL, Kang K, Yoon S, Huang SM, Lim JS, Kim JM, Lim JS, Lee HJ. Ann Surg Oncol. 2012:2763-72. [pmid: 22246425].
Low local metastatic rate may widen indication of nephron-sparing surgery for renal cell carcinoma. Xiong ZQ, Zheng J, Feng CC, Bao Y, Ding Q, Fang ZJ. Ann Diagn Pathol. 2012:190-5. [pmid: 22209503].
A non-cancer-related survival benefit is associated with partial nephrectomy. Sun M, Trinh QD, Bianchi M, Hansen J, Hanna N, Abdollah F, Shariat SF, Briganti A, Montorsi F, Perrotte P, Karakiewicz PI. Eur Urol. 2012:725-31. [pmid: 22172373].
Growth pattern of renal cell carcinoma (RCC) in patients with delayed surgical intervention. Li XS, Yao L, Gong K, Yu W, He Q, Zhou LQ, He ZS. J Cancer Res Clin Oncol. 2012:269-74. [pmid: 22105897].
Partial elective nephrectomy. Zungri E, Martinez L, Leal D, Lorenzo L. Actas Urol Esp. 2012:160-4. [pmid: 21955560].
Trends in the use of of nephron-sparing surgery (NSS) at an Australian tertiary referral centre: an analysis of surgical decision-making using the R.E.N.A.L nephrometry scoring system. Satasivam P, Rajarubendra N, Chia PH, Munshey A, Sengupta S, Bolton D. BJU Int. 2012:1341-4. [pmid: 21951826].
Contemporary trends in nephrectomy for renal cell carcinoma in the United States: results from a population based cohort. Kim SP, Shah ND, Weight CJ, Thompson RH, Moriarty JP, Shippee ND, Costello BA, Boorjian SA, Leibovich BC. J Urol. 2011:1779-85. [pmid: 21944105].
Validation of the 2009 TNM Classification for Renal Cell Carcinoma: Comparison with the 2002 TNM Classification by Concordance Index. Lee C, You D, Park J, Jeong IG, Song C, Hong JH, Ahn H, Kim CS. Korean J Urol. 2011:524-30. [pmid: 21927698].
Incidence of multiple sporadic renal cell carcinomas in patients referred for renal radiofrequency ablation: implications for imaging follow-up. Beland MD, Wolf FJ, Grand DJ, Dupuy DE, Mayo-Smith WW. AJR Am J Roentgenol. 2011:671-5. [pmid: 21862810].
Tumour diameter and decreased preoperative estimated glomerular filtration rate are independently correlated in patients with renal cell carcinoma. Donin NM, Suh LK, Barlow L, Hruby GW, Newhouse J, McKiernan J. BJU Int. 2012:379-83. [pmid: 21851533].
Increasing use of kidney sparing approaches for localized renal tumors in a community based health system: impact on renal functional outcomes. Lane BR, Chen H, Morrow M, Anema JG, Kahnoski RJ. J Urol. 2011:1229-35. [pmid: 21849192].
Degree and Predictors of Functional Loss of the Operated Kidney following Nephron-Sparing Surgery: Assessment by Quantitative SPECT of 99m Tc-Dimercaptosuccinic Acid Scintigraphy. Nativ O, Levi A, Farfara R, Halachmi S, Moskovitz B. Adv Urol. 2011:961525. [pmid: 21845188].
The Karakiewicz nomogram is the most useful clinical predictor for survival outcomes in patients with localized renal cell carcinoma. Tan MH, Li H, Choong CV, Chia KS, Toh CK, Tang T, Tan PH, Wong CF, Lau W, Cheng C. Cancer. 2011:5314-24. [pmid: 21567386].
Benefits of a combined approach to sampling of renal neoplasms as demonstrated in a series of 351 cases. Parks GE, Perkins LA, Zagoria RJ, Garvin AJ, Sirintrapun SJ, Geisinger KR. Am J Surg Pathol. 2011:827-35. [pmid: 21552112].
Chyluria after radiofrequency ablation of renal tumors. Kaur H, Matin SF, Javadi S, Johnson VE, Choi H, Sandler C, Ahrar K. J Vasc Interv Radiol. 2011:924-7. [pmid: 21507680].
Independent validation of the 2010 American Joint Committee on Cancer TNM classification for renal cell carcinoma: results from a large, single institution cohort. Kim SP, Alt AL, Weight CJ, Costello BA, Cheville JC, Lohse C, Allmer C, Leibovich BC. J Urol. 2011:2035-9. [pmid: 21496854].
Post-operative acute kidney injury in patients with renal cell carcinoma is a potent risk factor for new-onset chronic kidney disease after radical nephrectomy. Cho A, Lee JE, Kwon GY, Huh W, Lee HM, Kim YG, Kim DJ, Oh HY, Choi HY. Nephrol Dial Transplant. 2011:3496-501. [pmid: 21406544].
Risk factors for conversion to hand assisted laparoscopy or open surgery during laparoscopic renal surgery. Rowley MW, Wolf JS Jr. J Urol. 2011:940-4. [pmid: 21247602].
Clinical characteristics and outcomes of patients with recurrence 5 years after nephrectomy for localized renal cell carcinoma. Adamy A, Chong KT, Chade D, Costaras J, Russo G, Kaag MG, Bernstein M, Motzer RJ, Russo P. J Urol. 2011:433-8. [pmid: 21167521].
Clinical predictors of renal mass pathological features. Tsivian M, Mouraviev V, Albala DM, Caso JR, Robertson CN, Madden JF, Polascik TJ. BJU Int. 2011:735-40. [pmid: 21054752].
Age-adjusted incidence, mortality, and survival rates of stage-specific renal cell carcinoma in North America: a trend analysis. Sun M, Thuret R, Abdollah F, Lughezzani G, Schmitges J, Tian Z, Shariat SF, Montorsi F, Patard JJ, Perrotte P, Karakiewicz PI. Eur Urol. 2011:135-41. [pmid: 21035250].
Diagnostic value of processing cytologic aspirates of renal tumors in agar cell (tissue) blocks. Smedts F, Schrik M, Horn T, Hopman AH. Acta Cytol. 2010:587-94. [pmid: 20715661].
The Prognostic Factors for Patients with pT1a Renal Cell Carcinoma. Kim JM, Song PH, Kim HT, Park TC. Korean J Urol. 2010:233-8. [pmid: 20428424].
Predicting occult multifocality of renal cell carcinoma. Tsivian M, Moreira DM, Caso JR, Mouraviev V, Madden JF, Bratslavsky G, Robertson CN, Albala DM, Polascik TJ. Eur Urol. 2010:118-26. [pmid: 20346577].
The prognostic value of erythrocyte polyamines in the preoperative evaluation of patients with renal cell carcinoma. Lughezzani G, Karakiewicz PI, Bigot P, Perrotte P, Crepel M, Rioux-Leclercq N, Catros-Quemener V, Moulinoux JP, Bouet F, Cipolla B, Patard JJ. Eur J Cancer. 2010:1927-35. [pmid: 20335019].
Characterization of contrast enhancement in the ablation zone immediately after radiofrequency ablation of renal tumors. Javadi S, Ahrar JU, Ninan E, Gupta S, Matin SF, Ahrar K. J Vasc Interv Radiol. 2010:690-5. [pmid: 20227295].
Radiofrequency ablation of renal tumours: diagnostic accuracy of contrast-enhanced ultrasound for early detection of residual tumour. Hoeffel C, Pousset M, Timsit MO, Elie C, Mejean A, Merran S, Tranquart F, Khairoune A, Joly D, Richard S, Helenon O, Correas JM. Eur Radiol. 2010:1812-21. [pmid: 20204642].
Variation in the incidence of and risk factors for the development of nephrolithiasis after radical or partial nephrectomy. Bagrodia A, Malcolm JB, Diblasio CJ, Mehrazin R, Patterson AL, Wake RW, Wan JY, Derweesh IH. BJU Int. 2010:1200-4. [pmid: 20156212].
Predicting collecting system transection at laparoscopic partial nephrectomy: analysis of tumor parameters. Shikanov S, Lifshitz DA, Deklaj T, Katz MH, Shalhav AL. J Endourol. 2009:1863-6. [pmid: 19619066].
Laparoscopic partial nephrectomy: predictors of prolonged warm ischemia. Lifshitz DA, Shikanov S, Jeldres C, Deklaj T, Karakiewicz PI, Zorn KC, Eggener SE, Shalhav AL. J Urol. 2009:860-5. [pmid: 19616257].
Bowel displacement for CT-guided tumor radiofrequency ablation: techniques and anatomic considerations. Ginat DT, Saad W, Davies M, Walman D, Erturk E. J Endourol. 2009:1259-64. [pmid: 19594374].
MRI and CT characteristics of successfully ablated renal masses: Imaging surveillance after radiofrequency ablation. Davenport MS, Caoili EM, Cohan RH, Ellis JH, Higgins EJ, Willatt J, Fox GA. AJR Am J Roentgenol. 2009:1571-8. [pmid: 19457820].
Estimation and prediction of renal function in patients with renal tumor. Kim HL, Shah SK, Tan W, Shikanov SA, Zorn KC, Shalhav AL, Wilding GE. J Urol. 2009:2451-60. discussion 2460-1. [pmid: 19371883].
Nephron-sparing surgery: the effect of surface cooling and temporary renal artery occlusion on renal function. Bakirtas H, Eroglu M, Naldoken S, Akbulut Z, Tekdogan UY. Urol Int. 2009:24-7. [pmid: 19172092].
Age at diagnosis is a determinant factor of renal cell carcinoma-specific survival in patients treated with nephrectomy. Karakiewicz PI, Jeldres C, Suardi N, Hutterer GC, Perrotte P, Capitanio U, Ficarra V, Cindolo L, de La Taille A, Tostain J, Mulders PF, Salomon L, Zigeuner R, Schips L, Chautard D, Valeri A, Lechevallier E, Descots JL, Lang H, Mejean A, Verhoest G, Patard JJ. Can Urol Assoc J. 2008:610-7. [pmid: 19066680].
Diagnostic yield of renal biopsy immediately prior to laparoscopic radiofrequency ablation: a multicenter study. Kyle CC, Wingo MS, Carey RI, Leveillee RJ, Bird VG. J Endourol. 2008:2291-3. [pmid: 18937593].
Obesity and morbid obesity are associated with a greater conversion rate to open surgery for standard but not hand assisted laparoscopic radical nephrectomy. Gabr AH, Elsayed ER, Gdor Y, Roberts WW, Wolf JS Jr. J Urol. 2008:2357-62. discussion 2362. [pmid: 18930284].
Effect of baseline glomerular filtration rate on survival in patients undergoing partial or radical nephrectomy for renal cortical tumors. Pettus JA, Jang TL, Thompson RH, Yossepowitch O, Kagiwada M, Russo P. Mayo Clin Proc. 2008:1101-6. [pmid: 18828969].
Splenic injury during left nephrectomy for renal cell cancer. Zielinski H, Pawlicki B, Bortnowski L, Jedynak R, Piotrowicz G, Galka M. Pol Merkur Lekarski. 2008:502-5. [pmid: 18702330].
Incidence of benign pathologic lesions at partial nephrectomy for presumed RCC renal masses: Japanese dual-center experience with 176 consecutive patients. Fujii Y, Komai Y, Saito K, Iimura Y, Yonese J, Kawakami S, Ishikawa Y, Kumagai J, Kihara K, Fukui I. Urology. 2008:598-602. [pmid: 18649929].
Elective laparoscopic partial nephrectomy in patients with tumors &gt;4 cm. Rais-Bahrami S, Romero FR, Lima GC, Kohanim S, Permpongkosol S, Trock BJ, Jarrett TW, Kavoussi LR. Urology. 2008:580-3. [pmid: 18632142].
Renal cell carcinoma radiofrequency ablation: evaluation of efficacy based on histological correlation. Mylona S, Ntai S, Stroumpouli E, Glentzes V, Martinis S, Thanos L. Br J Radiol. 2008:479-84. [pmid: 18487388].
Elevated serum-circulating RNA in patients with conventional renal cell cancer. Feng G, Li G, Gentil-Perret A, Tostain J, Genin C. Anticancer Res. 2008:321-6. [pmid: 18383864].
Transperitoneal laparoscopic radical nephrectomy for large (more than 7 cm) renal masses. Berger AD, Kanofsky JA, O'Malley RL, Hyams ES, Chang C, Taneja SS, Stifelman MD. Urology. 2008:421-4. [pmid: 18342177].
Immediate renal tumor involution after radiofrequency thermal ablation. Ganguli S, Brennan DD, Faintuch S, Rayan ME, Goldberg SN. J Vasc Interv Radiol. 2008:412-8. [pmid: 18295702].
Comparison of standard and hand-assisted laparoscopic radical nephrectomy for renal cell carcinoma. Harano M, Eto M, Yokomizo A, Tatsugami K, Hamaguchi M, Naito S. Fukuoka Igaku Zasshi. 2007:389-96. [pmid: 18186294].
Impact of gender in renal cell carcinoma: an analysis of the SEER database. Aron M, Nguyen MM, Stein RJ, Gill IS. Eur Urol. 2008:133-40. [pmid: 18160207].
CT-guided biopsy for the diagnosis of renal tumors before treatment with percutaneous ablation. Heilbrun ME, Zagoria RJ, Garvin AJ, Hall MC, Krehbiel K, Southwick A, Clark PE. AJR Am J Roentgenol. 2007:1500-5. [pmid: 17515368].
Opened vs laparoscopic radical nephrectomy in renal adenocarcinoma cost comparison. Herranz Amo F, Subira Rios D, Hernandez Fernandez C, Martinez Salamanca JI, Monzo JI, Cabello Benavente R. Actas Urol Esp. 2006:921-5. [pmid: 17175932].
Positive surgical parenchymal margin after laparoscopic partial nephrectomy for renal cell carcinoma: oncological outcomes. Permpongkosol S, Colombo JR Jr, Gill IS, Kavoussi LR. J Urol. 2006:2401-4. [pmid: 17085113].
Incidence of benign lesions for clinically localized renal masses smaller than 7 cm in radiological diameter: influence of sex. Snyder ME, Bach A, Kattan MW, Raj GV, Reuter VE, Russo P. J Urol. 2006:2391-5. discussion 2395-6. [pmid: 17085108].
The influence of clinical and pathological stage discrepancy on cancer specific survival in patients treated for renal cell carcinoma. Svatek RS, Lotan Y, Herman MP, Duchene DA, Sagalowsky AI, Cadeddu JA. J Urol. 2006:1321-5. discussion 125. [pmid: 16952621].
Are small renal tumors harmless? Analysis of histopathological features according to tumors 4 cm or less in diameter. Remzi M, Ozsoy M, Klingler HC, Susani M, Waldert M, Seitz C, Schmidbauer J, Marberger M. J Urol. 2006:896-9. [pmid: 16890647].
Efficacy and safety of fast-track recovery strategy for patients undergoing laparoscopic nephrectomy. Recart A, Duchene D, White PF, Thomas T, Johnson DB, Cadeddu JA. J Endourol. 2005:1165-9. [pmid: 16359206].
Hand-assisted laparoscopic radical nephrectomy: comparison of the transperitoneal and retroperitoneal approaches. Shiraishi K, Eguchi S, Mohri J, Kamiryo Y. Surg Laparosc Endosc Percutan Tech. 2005:216-9. [pmid: 16082309].
Independent validation of the 2002 American Joint Committee on cancer primary tumor classification for renal cell carcinoma using a large, single institution cohort. Frank I, Blute ML, Leibovich BC, Cheville JC, Lohse CM, Zincke H. J Urol. 2005:1889-92. [pmid: 15879769].
Ureteropelvic junction obstruction after partial nephrectomy. Singh D, Desai M, Novick AC, Streem SB. J Endourol. 2005:416-8. [pmid: 15865539].
Hemorrhagic complications after nephron-sparing surgery: angiographic diagnosis and management by transcatheter embolization. Heye S, Maleux G, Van Poppel H, Oyen R, Wilms G. AJR Am J Roentgenol. 2005:1661-4. [pmid: 15855135].
Renal neoplasms in younger adults: analysis of 112 tumors from a single institution according to the new 2004 World Health Organization classification and 2002 American Joint Committee on Cancer Staging System. Cao Y, Paner GP, Perry KT, Flanigan RC, Campbell SC, Picken MM. Arch Pathol Lab Med. 2005:487-91. [pmid: 15794671].
Laparoscopic specimen extraction: morcellation. Varkarakis I, Rha K, Hernandez F, Kavoussi LR, Jarrett TW. BJU Int. 2005:27-31. [pmid: 15759350].
Pathological stage does not alter the prognosis for renal lesions determined to be stage T1 by computerized tomography. Roberts WW, Bhayani SB, Allaf ME, Chan TY, Kavoussi LR, Jarrett TW. J Urol. 2005:713-5. [pmid: 15711249].
Associations with contralateral recurrence following nephrectomy for renal cell carcinoma using a cohort of 2,352 patients. Bani-Hani AH, Leibovich BC, Lohse CM, Cheville JC, Zincke H, Blute ML. J Urol. 2005:391-4. [pmid: 15643178].
Prediction of postoperative renal function by preoperative serum creatinine level and three-dimensional diagnostic image reconstruction in patients with renal cell carcinoma. Tanaka N, Fujimoto K, Tani M, Yoshii M, Yoshida K, Hirao Y, Ozono S. Urology. 2004:904-8. [pmid: 15533475].
A renal mass in the setting of a nonrenal malignancy: When is a renal tumor biopsy appropriate?. Sanchez-Ortiz RF, Madsen LT, Bermejo CE, Wen S, Shen Y, Swanson DA, Wood CG. Cancer. 2004:2195-201. [pmid: 15470708].
Evaluation of patients referred for percutaneous ablation of renal tumors: importance of a preprocedural diagnosis. Tuncali K, vanSonnenberg E, Shankar S, Mortele KJ, Cibas ES, Silverman SG. AJR Am J Roentgenol. 2004:575-82. [pmid: 15333338].
Guidelines for the surveillance of localized renal cell carcinoma based on the patterns of relapse after nephrectomy. Stephenson AJ, Chetner MP, Rourke K, Gleave ME, Signaevsky M, Palmer B, Kuan J, Brock GB, Tanguay S. J Urol. 2004:58-62. [pmid: 15201737].
Radical retroperitoneal nephrectomy. Heidenreich A. Aktuelle Urol. 2004:65-76. [pmid: 14997419].
Impact of arterial occlusion during partial nephrectomy on residual renal function: an evaluation with (99m)technetium-dimercaptosuccinic acid scintigraphy. Kondo T, Nakazawa H, Ito F, Onitsuka S, Ryoji O, Yago R, Hashimoto Y, Toma H. Int J Urol. 2002:435-40. [pmid: 12225340].
Prognostic importance of tumor size for localized conventional (clear cell) renal cell carcinoma: assessment of TNM T1 and T2 tumor categories and comparison with other prognostic parameters. Delahunt B, Kittelson JM, McCredie MR, Reeve AE, Stewart JH, Bilous AM. Cancer. 2002:658-64. [pmid: 11857297].
Can renal oncocytomas be distinguished from renal cell carcinoma on fine-needle aspiration specimens? A study of conventional smears in conjunction with ancillary studies. Liu J, Fanning CV. Cancer. 2001:390-7. [pmid: 11748579].
Prediction of post-operative glomerular filtration rate after nephrectomy for renal malignancy. Johansson M, Moonen M. Clin Physiol. 2001:688-92. [pmid: 11722476].
Cystic renal cell carcinoma: pathological features, survival and implications for treatment. Bielsa O, Lloreta J, Gelabert-Mas A. Br J Urol. 98:16-20.
Renal function after radical nephrectomy: Development and validation of predictive models in Japanese patients. Yokoyama M, Fujii Y, Takeshita H, Kawamura N, Nakayama T, Iimura Y, Sakura M, Ishioka J, Saito K, Koga F, Masuda H, Noro A, Arisawa C, Kitahara S, Kihara K. Int J Urol. 2014:238-242. [pmid: 24118492].
RENAL nephrometry score is a predictive factor for the annual growth rate of renal mass. Matsumoto R, Abe T, Shinohara N, Murai S, Maruyama S, Tsuchiya K, Nonomura K. Int J Urol. 2014:549-552. [pmid: 24405437].
Clinico-pathological prognostic factors of renal cell carcinoma: A 15-year review from a single center in Greece. Grivas N, Kafarakis V, Tsimaris I, Raptis P, Hastazeris K, Stavropoulos NE. Urol Ann. 2014:116-121. [pmid: 24833821].
Stage T1NOMO renal cell carcinoma: The prognosid in Asian patients. Zhang Z-L, Chen W, Li Y-H, Liu Z-W, Luo J-H, Lau W, Tan M-H, Zhou F-J. Chin J Cancer. 2011:772-778. [pmid: 22035858].
Robotics applied in laparoscopic kidney surgery: The Yonsei University experience of 127 cases. Lorenzo EIS, Jeong W, Oh CK, Chung BH, Choi YD, Rha KH. Urology. 2011:114-118. [pmid: 20434761].
Thermal protection during percutaneous thermal ablation procedures: Interest of carbon dioxide dissection and temperature monitoring. Buy X, Tok C-H, Szwarc D, Bierry G, Gangi A. Cardiovasc Intervent Radiol. 2009:529-534. [pmid: 19219496].
A Comparative Study of Quality of Life Issues Relating to Open Versus Laparoscopic Nephrectomy: A Prospective Pragmatic Study. Harryman OA, Davenport K, Keoghane S, Keeley FX, Timoney AG. J Urol. 2009:998-1003. [pmid: 19150558].
Clinicopathological features and survival rates of patients with renal cell carcinoma under 50 years of age. Atmaca AF, Bayrak O, Kandemir O, Serefoglu EC, Culha IE, Canda AE, Balbay MD. Cent Eur J Med. 2008:453-458.
Robotic assisted Laparoscopic partial Nephrectomy for suspected Renal Cell Carcinoma: Retrospective review of surgical outcomes of 35 Cases. Bhayani SB, Das N. BMC Surg. 2008.
Use of Haemostatic Agents and Glues during Laparoscopic Partial Nephrectomy: A Multi-Institutional Survey from the United States and Europe of 1347 Cases{A figure is presented}. Breda A, Stepanian SV, Lam JS, Liao JC, Gill IS, Colombo JR, Guazzoni G, Stifelman MD, Perry KT, Celia A, Breda G, Fornara P, Jackman SV, Rosales A, Palou J, Grasso M, Pansadoro V, Disanto V, Porpiglia F, Milani C, Abbou CC, Gaston R, Janetschek G, Soomro NA, De la Rosette JJ, Laguna PM, Schulam PG. Eur Urol. 2007:798-803. [pmid: 17329015].
Pathological Features of Renal Neoplasms Classified by Size and Symptomatology. Schlomer B, Figenshau RS, Yan Y, Venkatesh R, Bhayani SB. J Urol. 2006:1317-1320. [pmid: 16952619].
Extensively cystic renal neoplasms in adults (Bosniak Classification II or III) - Possible &quot;common&quot; histological diagnoses: Multilocular cystic renal cell carcinoma, cystic nephroma, and mixed epithelial and stromal tumor of the kidney. Hora M, Hes O, Michal M, Boudova L, Chudacek Z, Kreuzberg B, Klecka J. Int Urol Nephrol. 2005:743-750. [pmid: 16362592].
Neuromuscular complications after percutaneous radiofrequency ablation of renal tumors. Bhayani SB, Allaf ME, Su L-M, Solomon SB. Urology. 2005:592.e24-592.e25. [pmid: 15780392].
Clinicopathological Features of Incidentally Detected Renal Cell Carcinoma in Japan. Miyake H, Ishimura T, Sakai I, Hara I, Eto H. UroOncology. 2003:95-98.
The symptoms of renal cell carcinoma related to patients' survival. Ou Y-C, Yang C-R, Ho H-C, Cheng C-L, Kao Y-L, Su C-K, Chiu K-Y, Chen W-M. J Chin Med Assoc. 2003:537-543. [pmid: 14649678].
Complications of transperitoneal laparoscopic surgery in urology: Review of 1,311 procedures at a single center. Vallancien G, Cathelineau X, Baumert H, Doublet JD, Guillonneau B. J Urol. 2002:23-26. [pmid: 12050484].
Significance of intratumoral microscopic vascular invasion in patients with renal cell carcinoma. Dall'Oglio MF, Srougi M, Goncalves PD, Leitte K, Scortegagna E Jr., Hering F. Braz J Urol. 2002:20-24.
Radiologic, pathologic and molecular attributes of two types of papillary renal adenocarcinomas. Mydlo JH, Weinstein R, Misseri R, Axiotis C, Thelmo W. Scand J Urol Nephrol. 2001:262-269. [pmid: 11676349].
Original report Three-dimensional CT stereoscopic visualization of renal masses: Impact on diagnosis and patient treatment. Smith PA, Marshall FF, Urban BA, Heath DG, Fishman EK. AM J ROENTGENOL. 97:1331-1334.
Assessing the anatomical characteristics of renal masses has a limited effect on the prediction of pathological outcomes in solid, enhancing, small renal masses: results using the PADUA classification system. Shin TY, Kim J, Koo KC, Lim SK, Kim DW, Kang MW, Rha KH, Choi YD, Ham WS. BJU Int. 2014:754-61. [pmid: 24053790].
Differentiation of clear from non-clear cell renal cell carcinoma using CT washout formula. Kopp RP, Aganovic L, Palazzi KL, Cassidy FH, Sakamoto K, Derweesh IH. Can J Urol. 2013:6790-7. [pmid: 23783049].
Results of fine-needle aspiration cytology (FNAC) in the diagnosis of indeterminate solid renal tumours. Li G, Cuilleron M, Cottier M, Rambaud B, Tostain J, Gigante M. Prog Urol. 2010:30-4. [pmid: 20123525].
Histogram analysis of small solid renal masses: differentiating minimal fat angiomyolipoma from renal cell carcinoma. Chaudhry HS, Davenport MS, Nieman CM, Ho LM, Neville AM. AJR Am J Roentgenol. 2012:377-83. [pmid: 22268181].
Combination of core biopsy and fine-needle aspiration increases diagnostic rate for small solid renal tumors. Li G, Cuilleron M, Zhao A, Obadia F, Mouracade P, Tostain J, Cottier M, Peoc'h M, Gigante M. Anticancer Res. 2012:3463-6. [pmid: 22843931].
EUS-guided FNA aspiration of kidney masses: a multicenter U.S. experience. DeWitt J, Gress FG, Levy MJ, Hernandez LV, Eloubeidi MA, Mishra G, Sherman S, Al-Haddad MA, LeBlanc JK. Gastrointest Endosc. 2009:573-8. [pmid: 19560139].
Contrast-enhanced ultrasound using a time-intensity curve for the diagnosis of renal cell carcinoma. Aoki S, Hattori R, Yamamoto T, Funahashi Y, Matsukawa Y, Gotoh M, Yamada Y, Honda N. BJU Int. 2011:349-54. [pmid: 21044245].
Real-time 3D fluoroscopy-guided large core needle biopsy of renal masses: a critical early evaluation according to the IDEAL recommendations. Kroeze SG, Huisman M, Verkooijen HM, van Diest PJ, Ruud Bosch JL, van den Bosch MA. Cardiovasc Intervent Radiol. 2012:680-5. [pmid: 21822769].
Diagnostic efficacy of contrast-enhanced ultrasound for small renal masses. Oh TH, Lee YH, Seo IY. Korean J Urol. 2014:587-92. [pmid: 25237460].
Characterization of solid renal masses using 64-slice multidetector CT scanner. El-Esawy SS, Abou El-Ghar ME, Gaballa GM, Zahra SA. ScientificWorldJournal. 2009:441-8. [pmid: 19526183].
Detection of renal lesion enhancement with dual-energy multidetector CT. Neville AM, Gupta RT, Miller CM, Merkle EM, Paulson EK, Boll DT. Radiology. 2011:173-83. [pmid: 21292866].
MR imaging in the characterization of small renal masses. Willatt JM, Hussain HK, Chong S, Kappil M, Azar SF, Liu PS, Ruma JA, Elsayes KM. Abdom Imaging. 2014:761-9. [pmid: 24615511].
MR imaging of renal masses interpreted on CT to be suspicious. Tello R, Davison BD, O'Malley M, Fenlon H, Thomson KR, Witte DJ, Harewood L. AJR Am J Roentgenol. 2000:1017-22. [pmid: 10749242].
Characterization and outcome of renal cancers &lt;/= 4cm treated by surgery. Gigante M, Li G, Gentil-Perret A, Chamba C, Tostain J. Prog Urol. 2010:572-7. [pmid: 20832034].
Management of small indeterminate renal tumours: is there a case for needle biopsy?. Khan AA, Shergill IS, Gujral SS, Timoney AG. BJU Int. 2007:1-3. [pmid: 17433032].
Multislice computed tomography versus contrast-enhanced ultrasound in evaluation of complex cystic renal masses using the Bosniak classification system. Clevert DA, Minaifar N, Weckbach S, Jung EM, Stock K, Reiser M, Staehler M. Clin Hemorheol Microcirc. 2008:171-8. [pmid: 18503122].
Cystic renal masses: accurate Bosniak classification requires adequate renal CT. Curry NS, Cochran ST, Bissada NK. AJR Am J Roentgenol. 2000:339-42. [pmid: 10915671].
Multiphasic enhancement patterns of small renal masses ((less-than or equal to)4 cm) on preoperative computed tomography: Utility for distinguishing subtypes of renal cell carcinoma, angiomyolipoma, and oncocytoma. Pierorazio PM, Hyams ES, Tsai S, Feng Z, Trock BJ, Mullins JK, Johnson PT, Fishman EK, Allaf ME. Urology. 2013:1265-1271. [pmid: 23601445].
Growth kinetics of small renal masses: A prospective analysis from the renal cell carcinoma consortium of Canada. Organ M, Jewett M, Abdolell M, Basiuka J, Fleshner N, Finelli A, Morash C, Pautler S, Chin J, Siemens R, Tanguay S, Gleave M, Drachenberg D, Chow R, Evans A, Gallie B, Haider M, Kachura J, Rendon R. J Urol. 2013:e482.
Differential diagnosis of renal oncocytoma and carcinoma by spiral CT. Zhang J, Ma D-Q, He W, Zhang Z-J, Hu Y-M, Xu Y. Chin J Med Imaging Technol. 2007:718-720.
Study on diagnosis of renal tumors by real-time contrast-enhanced ultrasonography. Li J, Zhou X-D, Luo E-P, Han Z-H, Zheng M, Zheng M-J, Wang L. Chin J Med Imaging Technol. 2006:591-593.
Small renal masses: Assessment of lesion characterization and vascularity on dynamic contrast-enhanced MR imaging with fat suppression. Scialpi M, Di Maggio A, Midiri M, Loperfido A, Angelelli G, Rotondo A. Am J Roentgenol. 2000:751-757. [pmid: 10954462].
Readmissions after major urologic cancer surgery. Leow JJ, Gandaglia G, Sood A, Ruhotina N, Klett DE, Sammon JD, Schmid M, Sun M, Chang SL, Kibel AS, Trinh QD. Can J Urol. 2014:7537-46. [pmid: 25483761].
Small renal masses managed with active surveillance: Predictors of tumor growth rate after long-term follow-up. Schiavina R, Borghesi M, Dababneh H, Bianchi L, Longhi B, Diazzi D, Monti C, La Manna G, Martorana G, Brunocilla E. Clin Genitourin Cancer. 2015:e87-e92. [pmid: 25450030].
A prospective, multicenter evaluation of predictive factors for positive surgical margins after nephron-sparing surgery for renal cell carcinoma: The record1 italian project. Schiavina R, Serni S, Mari A, Antonelli A, Bertolo R, Bianchi G, Brunocilla E, Borghesi M, Carini M, Longo N, Martorana G, Mirone V, Morgia G, Porpiglia F, Rocco B, Rovereto B, Simeone C, Sodano M, Terrone C, Ficarra V, Minervini A. Clin Genitourin Cancer. 2015:165-170. [pmid: 25450033].
R.E.N.A.L nephrometry score in clinical stage T1 renal mass: Ramathibodi hospital experience. Prasit S, Sirisreetreerux P, Sangkum P, Kijvikai K, Viseshsindh W, Kongchareonsombat W, Leenanupunth C, Kochakarn W. J Med Assoc Thailand. 2015:181-187.
Anatomic complexity quantitated by nephrometry score is associated with prolonged warm ischemia time during robotic partial nephrectomy. Tomaszewski JJ, Smaldone MC, Mehrazin R, Kocher N, Ito T, Abbosh P, Baber J, Kutikov A, Viterbo R, Chen DYT, Canter DJ, Uzzo RG. Urology. 2014:340-344. [pmid: 24925833].
Renal masses measuring under 2 cm: Pathologic outcomes and associations with MRI features. Rosenkrantz AB, Wehrli NE, Melamed J, Taneja SS, Shaikh MB. Eur J Radiol. 2014:1311-1316. [pmid: 24882784].
Bosniak category III cysts are more likely to be malignant than we expected in the era of multidetector computed tomography technology. Bata P, Tarnoki AD, Tarnoki DL, Szasz AM, Poloskei G, Fejer B, Gyebnar J, Nyirady P, Berczi V, Karlinger K, Szendroi A. J Res Med Sci. 2014:634-638. [pmid: 25364363].
Factors Associated with Diagnostic Accuracy When Performing a Preablation Renal Biopsy. Lorber G, Jorda M, Leveillee R. J Endourol. 2014.
Nephron-sparing Techniques Independently Decrease the Risk of Cardiovascular Events Relative to Radical Nephrectomy in Patients with a T1a-T1b Renal Mass and Normal Preoperative Renal Function. Capitanio U, Terrone C, Antonelli A, Minervini A, Volpe A, Furlan M, Matloob R, Regis F, Fiori C, Porpiglia F, Di Trapani E, Zacchero M, Serni S, Salonia A, Carini M, Simeone C, Montorsi F, Bertini R. Eur Urol. 2014.
Renal surgery for kidney cancer in Germany 2005-2006: length of stay, risk of postoperative complications and in-hospital death. Stang A, Buchel C. BMC Urol. 2014;74.
Evaluation of Renal Mass Biopsy Risk Stratification Algorithm for Robotic Partial Nephrectomy-Could a Biopsy Have Guided Management?. Rahbar H, Bhayani S, Stifelman M, Kaouk J, Allaf M, Marshall S, Zargar H, Ball M, Larson J, Rogers C. J Urol. 2014.
Survival advantage of partial over radical nephrectomy in patients presenting with localized renal cell carcinoma. Roos FC, Steffens S, Junker K, Janssen M, Becker F, Wegener G, Brenner W, Steinestel J, Schnoeller TJ, Schrader M, Hofmann R, Thuroff JW, Kuczyk MA, Wunderlich H, Siemer S, Hartmann A, Stockle M, Schrader AJ. BMC Cancer. 2014:372. [pmid: 24885955].
Outcomes in patients undergoing nephrectomy for renal cancer on chronic anticoagulation therapy. Sfakianos JP, Hakimi AA, Kim PH, Zabor EC, Mano R, Bernstein M, Karellas M, Russo P. Eur J Surg Oncol. 2014.
An obese body habitus does not preclude a minimally invasive partial nephrectomy. Reynolds C, Hannon M, Lehman K, Harpster LE, Raman JD. Can J Urol. 2014:7145-9. [pmid: 24529018].
The impact of type 2 diabetes on the outcome of localized renal cell carcinoma. Hofner T, Zeier M, Hatiboglu G, Eisen C, Schonberg G, Hadaschik B, Teber D, Duensing S, Trumpp A, Hohenfellner M, Pahernik S. World J Urol. 2013.
Renal function following curative surgery for renal cell carcinoma: who is at risk for renal insufficiency?. Kong HJ, Park JS, Kim DY, Shin HS, Jung HJ. Korean J Urol. 2013:830-3. [pmid: 24363863].
Estimating the risk of chronic kidney disease after nephrectomy. Ngo TC, Hurley MP, Thong AE, Jeon SH, Leppert JT, Chung BI. Can J Urol. 2013:7035-41. [pmid: 24331345].
Is there a volume-outcome relationship for partial nephrectomy?. Couapel JP, Bensalah K, Bernhard JC, Pignot G, Zini L, Lang H, Rigaud J, Salomon L, Bellec L, Soulie M, Vaessen C, Roupret M, Jung JL, Mourey E, Bigot P, Bruyere F, Berger J, Ansieau JP, Gimel P, Salome F, Hubert J, Pfister C, Baumert H, Timsit MO, Mejean A, Patard JJ. World J Urol. 2014:1323-9. [pmid: 24270969].
Population level assessment of hospital based outcomes following laparoscopic versus open partial nephrectomy during the adoption of minimally invasive surgery. Tan HJ, Wolf JS Jr, Ye Z, Hafez KS, Miller DC. J Urol. 2014:1231-7. [pmid: 24211600].
Factors that affect proportional glomerular filtration rate after minimally invasive partial nephrectomy. Hakimi AA, Ghavamian R, Williams SK, Kim PH, Chen L, Sfakianos JP, Keren-Paz GE, Sankin A, Ginzburg N, Coleman JA. J Endourol. 2013:1371-5. [pmid: 23560653].
Renal function outcomes for multifocal renal neoplasms managed by radiofrequency ablation. Gupta P, Allen BC, Chen MY, Childs DD, Kota G, Zagoria RJ. Cardiovasc Intervent Radiol. 2013:1329-35. [pmid: 23361116].
Angiomyolipoma with minimal fat: differentiation from papillary renal cell carcinoma by helical CT. Zhang YY, Luo S, Liu Y, Xu RT. Clin Radiol. 2013:365-70. [pmid: 23321146].
Urinary NGAL and KIM-1: biomarkers for assessment of acute ischemic kidney injury following nephron sparing surgery. Abassi Z, Shalabi A, Sohotnik R, Nativ O, Awad H, Bishara B, Frajewicki V, Sukhotnik I, Abbasi A, Nativ O. J Urol. 2013:1559-66. [pmid: 23085062].
Single-center comparative oncologic outcomes of surgical and percutaneous cryoablation for treatment of renal tumors. Goyal J, Verma P, Sidana A, Georgiades CS, Rodriguez R. J Endourol. 2012:1413-9. [pmid: 22642574].
Is near infrared fluorescence imaging using indocyanine green dye useful in robotic partial nephrectomy: a prospective comparative study of 94 patients. Krane LS, Manny TB, Hemal AK. Urology. 2012:110-6. [pmid: 22607949].
Nephrometry score is associated with volume loss and functional recovery after partial nephrectomy. Simmons MN, Hillyer SP, Lee BH, Fergany AF, Kaouk J, Campbell SC. J Urol. 2012:39-44. [pmid: 22578726].
Renal cell carcinoma stage migration in a single European centre over 25 years: effects on 5- and 10-year metastasis-free survival. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Pummer K, Zigeuner R. Int Urol Nephrol. 2012:997-1004. [pmid: 22456765].
Understanding the role of percutaneous biopsy in the management of patients with a small renal mass. Tan HJ, Jacobs BL, Hafez KS, Montgomery JS, Weizer AZ, Wood DP Jr, Miller DC, Wolf JS Jr. Urology. 2012:372-7. [pmid: 22310755].
Significant impact of age at diagnosis on the prognosis of Japanese patients with pT1 renal cell carcinoma following surgical resection. Sakai I, Miyake H, Muramaki M, Kondo Y, Kusuda Y, Yamada Y, Fujisawa M. BJU Int. 2012:695-9. [pmid: 21854532].
Laparoscopic and open partial nephrectomy: frequency and long-term follow-up of postoperative collections. Hecht EM, Bennett GL, Brown KW, Robbins D, Hyams ES, Taneja SS, Stifelman MA. Radiology. 2010:476-84. [pmid: 20413760].
Identifying the risk of disease progression after surgery for localized renal cell carcinoma. Abel EJ, Culp SH, Meissner M, Matin SF, Tamboli P, Wood CG. BJU Int. 2010:1277-83. [pmid: 20394619].
Hydrodisplacement in the percutaneous cryoablation of 50 renal tumors. Bodily KD, Atwell TD, Mandrekar JN, Farrell MA, Callstrom MR, Schmit GD, Charboneau JW. AJR Am J Roentgenol. 2010:779-83. [pmid: 20173159].
Central and deep renal tumors can be effectively ablated: radiofrequency ablation outcomes with fiberoptic peripheral temperature monitoring. Wingo MS, Leveillee RJ. J Endourol. 2008:1261-7. [pmid: 18484892].
Preservation of renal function following partial or radical nephrectomy using 24-hour creatinine clearance. Clark AT, Breau RH, Morash C, Fergusson D, Doucette S, Cagiannos I. Eur Urol. 2008:143-49. [pmid: 18407401].
Enucleation of renal cell carcinoma with ablation of the tumour base. Kutikov A, Vanarsdalen KN, Gershman B, Fossett LK, Guzzo TJ, Wein AJ, Malkowicz SB. BJU Int. 2008:688-91. [pmid: 18384627].
Follow-up of renal masses after cryosurgery using computed tomography; enhancement patterns and cryolesion size. Beemster P, Phoa S, Wijkstra H, de la Rosette J, Laguna P. BJU Int. 2008:1237-42. [pmid: 18218056].
Intermediate-term prospective results of radiofrequency-assisted laparoscopic partial nephrectomy: a non-ischaemic coagulative technique. Zeltser IS, Moonat S, Park S, Anderson JK, Cadeddu JA. BJU Int. 2008:36-8. [pmid: 17850367].
Image-guided biopsy in the evaluation of renal mass lesions in contemporary urological practice: indications, adequacy, clinical impact, and limitations of the pathological diagnosis. Shah RB, Bakshi N, Hafez KS, Wood DP Jr, Kunju LP. Hum Pathol. 2005:1309-15. [pmid: 16311125].
Prognostic role of Fuhrman grade and vascular endothelial growth factor in pT1a clear cell carcinoma in partial nephrectomy specimens. Minardi D, Lucarini G, Mazzucchelli R, Milanese G, Natali D, Galosi AB, Montironi R, Biagini G, Muzzonigro G. J Urol. 2005:1208-12. [pmid: 16145371].
Does the distance to normal renal parenchyma (DTNRP) in nephron-sparing surgery for renal cell carcinoma have an effect on survival?. Akcetin Z, Zugor V, Elsasser D, Krause FS, Lausen B, Schrott KM, Engehausen DG. Anticancer Res. 2005:1629-32. [pmid: 16033072].
Application of TNM, 2002 version, in localized renal cell carcinoma: is it able to predict different cancer-specific survival probability?. Ficarra V, Novara G, Galfano A, Novella G, Schiavone D, Artibani W. Urology. 2004:1050-4. [pmid: 15183948].
Prognostic significance of morphologic parameters in renal cell carcinoma. Erdogan F, Demirel A, Polat O. Int J Clin Pract. 2004:333-6. [pmid: 15161115].
The impact of tumor size on clinical outcome in patients with localized renal cell carcinoma treated by radical nephrectomy. Nativ O, Sabo E, Raviv G, Madjar S, Halachmi S, Moskovitz B. J Urol. 97:729-32.
Evaluation of perirenal fat as a predictor of cT1a renal cortical neoplasm histopathology and surgical outcomes. Okhunov Z, Mues AC, Kline M, Haramis G, Xu B, Mirabile G, Vira M, Landman J. J Endourol. 2012:911-916. [pmid: 22380739].
The significance of serum ferritin level in renal cell carcinoma: Bobrek Hucrelikanserde serum ferritin duzeyinin onemi. Erdemir F, Parlaktas BS, Uluocak N, Ozcan F, Celik M, Gokce O. Turk Urol Derg. 2005:479-484.
Benign lesions underwent radical nephrectomy for renal cancer: Bobrek tumoru on tanisi ile radikal nefrektomi yapilan benin lezyonlar. Sahin MO, Canda AE, Mungan MU, Kirkali Z, Sade M. Turk Urol Derg. 2004:405-409.
RENAL nephrometry score is a predictive factor for the annual growth rate of renal mass. Matsumoto R, Abe T, Shinohara N, Murai S, Maruyama S, Tsuchiya K, Nonomura K. Int J Urol. 2014:549-52. [pmid: 24405437].
Partial nephrectomy for T2 renal masses: contemporary trends and oncologic efficacy. Alanee S, Nutt M, Moore A, Holland B, Dynda D, Wilber A, El-Zawahry A. Int Urol Nephrol. 2015.
Learning curves for robot-Assisted and laparoscopic partial nephrectomy. Hanzly M, Frederick A, Creighton T, Atwood K, Mehedint D, Kauffman EC, Kim HL, Schwaab T. J Endourol. 2015:297-303. [pmid: 25111313].
Prospective Evaluation of the Association of Adherent Perinephric Fat With Perioperative Outcomes of Robotic-assisted Partial Nephrectomy. Davidiuk AJ, Parker AS, Thomas CS, Heckman MG, Custer K, Thiel DD. Urology. 2015.
Perinephric fat thickness is an independent predictor of operative complexity during robot-assisted partial nephrectomy. Macleod LC, Hsi RS, Gore JL, Wright JL, Harper JD. J Endourol. 2014:587-591. [pmid: 24377723].
Do we need to clamp the renal hilum liberally during the initial phase of the learning curve of robot-assisted nephron-sparing surgery?. Acar O, Esen T, Musaoglu A, Vural M. Sci World J. 2014.
Comparison of warm and cold ischemia on renal function after partial nephrectomy. Funahashi Y, Yoshino Y, Sassa N, Matsukawa Y, Takai S, Gotoh M. Urology. 2014:1408-1413. [pmid: 25432829].

## Other

Intraoperative sonography during open partial nephrectomy for renal cell cancer: does it alter surgical management?. Bhosale PR, Wei W, Ernst RD, Bathala TK, Reading RM, Wood CG, Bedi DG. AJR Am J Roentgenol. 2014:822-7. [pmid: 25247947].
Validation of mammalian target of rapamycin biomarker panel in patients with clear cell renal cell carcinoma. Haddad AQ, Kapur P, Singla N, Raman JD, Then MT, Nuhn P, Buchner A, Bastian P, Seitz C, Shariat SF, Bensalah K, Rioux-Leclercq N, Sagalowsky A, Lotan Y, Margulis V. Cancer. 2014.
The impact of tumour size on the probability of synchronous metastasis and survival in renal cell carcinoma patients: a population-based study. Ingimarsson JP, Sigurdsson MI, Hardarson S, Petursdottir V, Jonsson E, Einarsson GV, Gudbjartsson T. BMC Urol. 2014;72.
Tumor miR-125b predicts recurrence and survival of patients with clear-cell renal cell carcinoma after surgical resection. Fu Q, Liu Z, Pan D, Zhang W, Xu L, Zhu Y, Liu H, Xu J. Cancer Sci. 2014.
Low enhancement on multiphase contrast-enhanced CT images: an independent predictor of the presence of high tumor grade of clear cell renal cell carcinoma. Zhu YH, Wang X, Zhang J, Chen YH, Kong W, Huang YR. AJR Am J Roentgenol. 2014:W295-300. [pmid: 25148187].
Results of a comparative study analyzing octogenarians with renal cell carcinoma in a competing risk analysis with patients in the seventh decade of life. May M, Cindolo L, Zigeuner R, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Wolff I, Feciche B, Fenske F, Pichler M, Schips L, Figenshau RS, Madison K, Sanchez-Chapado M, Santiago Martin MD, Salzano L, Lotrecchiano G, Waidelich R, Stief C, Sountoulides P, Brookman-May S. Urol Oncol. 2014.
Factors Associated With Diagnostic Accuracy When Performing a Pre-Ablation Renal Biopsy. Lorber G, Jorda M, Leveillee RJ. J Endourol. 2014.
Low preoperative lymphocyte-monocyte ratio (LMR) represents a potentially poor prognostic factor in nonmetastatic clear cell renal cell carcinoma. Hutterer GC, Stoeckigt C, Stojakovic T, Jesche J, Eberhard K, Pummer K, Zigeuner R, Pichler M. Urol Oncol. 2014.
Pathological characteristics and radiographic correlates of complex renal cysts. Reese AC, Johnson PT, Gorin MA, Pierorazio PM, Allaf ME, Fishman EK, Netto GJ, Pavlovich CP. Urol Oncol. 2014.
Controversies of partial nephrectomy for renal cell carcinoma : survey in the German-speaking countries. Tietze S, Herms M, Behrendt W, Krause J, Hamza A. Urologe A. 2014:1181-5. [pmid: 24824467].
Analysis and validation of tissue biomarkers for renal cell carcinoma using automated high-throughput evaluation of protein expression. Abel EJ, Bauman TM, Weiker M, Shi F, Downs TM, Jarrard DF, Huang W. Hum Pathol. 2014:1092-9. [pmid: 24746216].
Clinical consequences of nephrectomy performed on medical grounds. Glazar W, Dobrowolska-Glazar B, Urbanowicz W, Sulowicz W. Przegl Lek. 2014:1-4. [pmid: 24712260].
Tumour characteristics and surgical treatment of renal cell carcinoma in Sweden 2005-2010: a population-based study from the National Swedish Kidney Cancer Register. Thorstenson A, Bergman M, Scherman-Plogell AH, Hosseinnia S, Ljungberg B, Adolfsson J, Lundstam S. Scand J Urol. 2014:231-8. [pmid: 24666102].
Hydro-Jet-assisted laparoscopic partial nephrectomy with no renal arterial clamping: a preliminary study in a single center. Gao Y, Chen L, Ning Y, Cui X, Yin L, Chen J, Wang J, Shao B, Xu D. Int Urol Nephrol. 2014:1289-93. [pmid: 24638210].
Chromosome 9p deletions are an independent predictor of tumor progression following nephrectomy in patients with localized clear cell renal cell carcinoma. de Oliveira D, Dall'Oglio MF, Reis ST, Zerati M, Souza IC, Leite KR, Srougi M. Urol Oncol. 2014:601-6. [pmid: 24629495].
The initial experience with RENAL Nephrometry in children, adolescents, and young adults with renal tumors. Cost NG, DeFoor WR Jr, Crotty EJ, Geller JI. Pediatr Blood Cancer. 2014:1434-9. [pmid: 24610879].
Use and outcomes of extended antibiotic prophylaxis in urological cancer surgery. Calvert JK, Holt SK, Mossanen M, James AC, Wright JL, Porter MP, Gore JL. J Urol. 2014:425-9. [pmid: 24603103].
Delay in nephrectomy and cancer control outcomes in elderly patients with small renal masses. Becker A, Roghmann F, Ravi P, Tian Z, Kluth LA, Gandaglia G, Noldus J, Dahlem R, Schlomm T, Graefen M, Karakiewicz PI, Trinh QD, Sun M. Urol Int. 2014:455-61. [pmid: 24602994].
Comparison of the Complications and the Cost of Open and Laparoscopic Radical Nephrectomy in Renal Tumors Larger than 7 centimeters. Bayrak O, Seckiner I, Erturhan S, Cil G, Erbagci A, Yagci F. Urol J. 2014:1222-7. [pmid: 24595928].
Trends of adult primary malignant renal tumors over 6 years. Khalil Ibrahim A. Pak J Med Sci. 2013:1385-8. [pmid: 24550959].
Simple enucleation versus standard partial nephrectomy for clinical T1 renal masses: perioperative outcomes based on a matched-pair comparison of 396 patients (RECORd project). Longo N, Minervini A, Antonelli A, Bianchi G, Bocciardi AM, Cunico SC, Fiori C, Fusco F, Giancane S, Mari A, Martorana G, Mirone V, Morgia G, Novara G, Porpiglia F, Raspollini MR, Rocco F, Rovereto B, Schiavina R, Serni S, Simeone C, Verze P, Volpe A, Ficarra V, Carini M. Eur J Surg Oncol. 2014:762-8. [pmid: 24529794].
Impact of Recurrent Copy Number Alterations and Cancer Gene Mutations on the Predictive Accuracy of Prognostic Models in Clear Cell Renal Cell Carcinoma. Hakimi AA, Mano R, Ciriello G, Gonen M, Mikkilineni N, Sfakianos JP, Kim PH, Motzer RJ, Russo P, Reuter VE, Hsieh JJ, Ostrovnaya I. J Urol. 2014.
Benefit in regionalization of care for patients treated with nephrectomy: a Nationwide Inpatient Sample. Becker A, Bianchi M, Hansen J, Tian Z, Shariat SF, Popa I, Perrotte P, Trinh QD, Karakiewicz PI, Sun M. World J Urol. 2014.
External validation of TNM-C score in three community hospital cohorts for clear cell renal cell carcinoma. Nakayama T, Saito K, Ishioka J, Kawano K, Morimoto S, Matsuoka Y, Okuno T, Moriyama S, Takeshita H, Noro A, Fujii Y, Kihara K. Anticancer Res. 2014:921-6. [pmid: 24511033].
Quantitative proteomic analysis reveals potential diagnostic markers and pathways involved in pathogenesis of renal cell carcinoma. White NM, Masui O, Desouza LV, Krakovska O, Metias S, Romaschin AD, Honey RJ, Stewart R, Pace K, Lee J, Jewett MA, Bjarnason GA, Siu KW, Yousef GM. Oncotarget. 2014:506-18. [pmid: 24504108].
External validation of the modified Glasgow prognostic score for renal cancer. Tai CG, Johnson TV, Abbasi A, Herrell L, Harris WB, Kucuk O, Canter DJ, Ogan K, Pattaras JG, Nieh PT, Master VA. Indian J Urol. 2014:33-7. [pmid: 24497679].
Clinicopathological characteristics and outcomes of surgically excised renal masses in African Americans. Qi P, Tsivian M, Abern MR, Passoni NM, McGinley KF, Polascik TJ. Urol Oncol. 2014:555-60. [pmid: 24495445].
The impact of perioperative blood transfusion on survival after nephrectomy for non-metastatic renal cell carcinoma (RCC). Linder BJ, Thompson RH, Leibovich BC, Cheville JC, Lohse CM, Gastineau DA, Boorjian SA. BJU Int. 2014:368-74. [pmid: 24471825].
Practical and intuitive surgical approach renal ranking to predict outcomes in the management of renal tumors: a novel score tool. Tannus M, Goldman SM, Andreoni C. J Endourol. 2014:487-92. [pmid: 24437510].
Loss of BAP1 protein expression is an independent marker of poor prognosis in patients with low-risk clear cell renal cell carcinoma. Joseph RW, Kapur P, Serie DJ, Eckel-Passow JE, Parasramka M, Ho T, Cheville JC, Frenkel E, Rakheja D, Brugarolas J, Parker A. Cancer. 2014:1059-67. [pmid: 24382589].
Histopathologic findings of small renal tumor biopsies performed immediately after cryoablation therapy: a retrospective study of 50 cases. Tayal S, Kim FJ, Sehrt D, Miano R, Pompeo A, Molina W. Am J Clin Pathol. 2014:35-42. [pmid: 24343735].
Trends and perioperative outcomes for laparoscopic and robotic nephrectomy using the National Surgical Quality Improvement Program (NSQIP) database. Liu JJ, Leppert JT, Maxwell BG, Panousis P, Chung BI. Urol Oncol. 2014:473-9. [pmid: 24332644].
Small renal cell carcinomas--how dangerous are they really? Results of a large multicenter study. Steffens S, Junker K, Roos FC, Janssen M, Becker F, Henn D, Wegener G, Siemer S, Hofmann R, Schrader M, Stockle M, Thuroff JW, Hartmann A, Kuczyk MA, Schrader AJ. Eur J Cancer. 2014:739-45. [pmid: 24321262].
The impact of metformin use on recurrence and cancer-specific survival in clinically localized high-risk renal cell carcinoma. Hakimi AA, Chen L, Kim PH, Sjoberg D, Glickman L, Walker MR, Russo P. Can Urol Assoc J. 2013:E687-91. [pmid: 24282458].
Pathological characteristics and prognostic effect of peritumoral capsule penetration in renal cell carcinoma after tumor enucleation. Minervini A, Rosaria Raspollini M, Tuccio A, Di Cristofano C, Siena G, Salvi M, Vittori G, Sebastianelli A, Lapini A, Serni S, Carini M. Urol Oncol. 2014:50.e15-22. [pmid: 24239462].
Renal Pelvic Anatomy Is Associated with Incidence Grade, and Need for Intervention for Urine Leak Following Partial Nephrectomy. Tomaszewski JJ, Cung B, Smaldone MC, Mehrazin R, Kutikov A, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Eur Urol. 2013.
Comparison of baseline quality of life measures between renal cell carcinoma patients undergoing partial versus radical nephrectomy. Arnold ML, Thiel DD, Diehl N, Wu KJ, Ames S, Parker AS. BMC Urol. 2013;52.
Soft coagulation in partial nephrectomy without renorrhaphy: feasibility of a new technique and early outcomes. Ota T, Komori H, Rii J, Ochi A, Suzuki K, Shiga N, Nishiyama H. Int J Urol. 2014:244-7. [pmid: 24102735].
Multi-institutional analysis of localized renal cell carcinoma that demonstrates the impact of diabetic status on prognosis after nephrectomy. Ha YS, Kim WT, Yun SJ, Lee SC, Kim WJ, Park YH, Kang SH, Hong SH, Byun SS, Kim YJ. Ann Surg Oncol. 2013:3662-8. [pmid: 23907313].
Time to recurrence is a significant predictor of cancer-specific survival after recurrence in patients with recurrent renal cell carcinoma--results from a comprehensive multi-centre database (CORONA/SATURN-Project). Brookman-May SD, May M, Shariat SF, Novara G, Zigeuner R, Cindolo L, De Cobelli O, De Nunzio C, Pahernik S, Wirth MP, Longo N, Simonato A, Serni S, Siracusano S, Volpe A, Morgia G, Bertini R, Dalpiaz O, Stief C, Ficarra V. BJU Int. 2013:909-16. [pmid: 23890378].
Active surveillance, radiofrequency ablation, or cryoablation for the nonsurgical management of a small renal mass: a cost-utility analysis. Bhan SN, Pautler SE, Shayegan B, Voss MD, Goeree RA, You JJ. Ann Surg Oncol. 2013:3675-84. [pmid: 23720071].
Conditional survival after nephrectomy for renal cell carcinoma (RCC): changes in future survival probability over time. Bianchi M, Becker A, Hansen J, Trinh QD, Tian Z, Abdollah F, Briganti A, Shariat SF, Perrotte P, Montorsi F, Karakiewicz PI, Sun M. BJU Int. 2013:E283-9. [pmid: 23714646].
Sutureless hemostatic control during laparoscopic NSS for the treatment of small renal masses. Minervini A, Siena G, Tuccio A, Lapini A, Serni S, Carini M. Surg Innov. 2014:32-8. [pmid: 23575917].
Gender differences in clinicopathological features and survival in surgically treated patients with renal cell carcinoma: an analysis of the multicenter CORONA database. May M, Aziz A, Zigeuner R, Chromecki T, Cindolo L, Schips L, De Cobelli O, Rocco B, De Nunzio C, Tubaro A, Coman I, Truss M, Dalpiaz O, Hoschke B, Gilfrich C, Feciche B, Stoltze A, Fenske F, Fritsche HM, Figenshau RS, Madison K, Sanchez-Chapado M, Martin Mdel C, Salzano L, Lotrecchiano G, Joniau S, Waidelich R, Stief C, Brookman-May S. World J Urol. 2013:1073-80. [pmid: 23568445].
Carbonic anhydrase IX (CAIX) is not an independent predictor of outcome in patients with clear cell renal cell carcinoma (ccRCC) after long-term follow-up. Zhang BY, Thompson RH, Lohse CM, Dronca RS, Cheville JC, Kwon ED, Leibovich BC. BJU Int. 2013:1046-53. [pmid: 23551810].
Treatment and overall survival in renal cell carcinoma: a Swedish population-based study (2000-2008). Wahlgren T, Harmenberg U, Sandstrom P, Lundstam S, Kowalski J, Jakobsson M, Sandin R, Ljungberg B. Br J Cancer. 2013:1541-9. [pmid: 23531701].
Bilateral synchronous sporadic renal masses: intermediate functional and oncological outcomes at a single institution. Woodson B, Fernandez R, Stewart C, Mandava S, Wang L, Lee BR. Int Urol Nephrol. 2013:619-25. [pmid: 23529271].
Assessing the accuracy and generalizability of the preoperative and postoperative Karakiewicz nomograms for renal cell carcinoma: results from a multicentre European and US study. Cindolo L, Chiodini P, Brookman-May S, De Cobelli O, May M, Squillacciotti S, De Nunzio C, Tubaro A, Coman I, Feciche B, Truss M, Wirth MP, Dalpiaz O, Chromecki TF, Shariat SF, Sanchez-Chapado M, Santiago Martin Mdel C, Rocco B, Salzano L, Lotrecchiano G, Berardinelli F, Schips L. BJU Int. 2013:578-84. [pmid: 23470199].
Trends in the surgical management of localized renal masses: thermal ablation, partial and radical nephrectomy in the USA, 1998-2008. Woldrich JM, Palazzi K, Stroup SP, Sur RL, Parsons JK, Chang D, Derweesh IH. BJU Int. 2013:1261-8. [pmid: 23470140].
Impact of clinical and histopathological parameters on disease specific survival in patients with collecting duct renal cell carcinoma: development of a disease specific risk model. May M, Ficarra V, Shariat SF, Zigeuner R, Chromecki T, Cindolo L, Burger M, Gunia S, Feciche B, Wenzl V, Aziz A, Chun F, Becker A, Pahernik S, Simeone C, Longo N, Zucchi A, Antonelli A, Mirone V, Stief C, Novara G, Brookman-May S. J Urol. 2013:458-63. [pmid: 23434943].
Predictive factors of chronic kidney disease stage V after partial nephrectomy in a solitary kidney: a multi-institutional study. Verhoest G, Patard JJ, Oger E, Rioux-Leclercq N, Peyronnet B, Bessede T, Laguna P, Barwari K, Rigaud J, Roupret M, Coffin G, Bernhard JC, Long JA, Zisman A, Berger J, Paparel P, Maurin C, Lechevallier E, Bertini R, Ouzaid I, Salomon L, Bex A, Farfara R, Ljungberg B, Rodriguez AR, Bensalah K. Urol Oncol. 2014:28.e21-6. [pmid: 23428536].
The effect of gender and age on kidney cancer survival: younger age is an independent prognostic factor in women with renal cell carcinoma. Rampersaud EN, Klatte T, Bass G, Patard JJ, Bensaleh K, Bohm M, Allhoff EP, Cindolo L, De La Taille A, Mejean A, Soulie M, Bellec L, Christophe Bernhard J, Pfister C, Colombel M, Belldegrun AS, Pantuck AJ, George D. Urol Oncol. 2014:30.e9-13. [pmid: 23422777].
Influence of body mass index, smoking, and blood pressure on survival of patients with surgically-treated, low stage renal cell carcinoma: a 14-year retrospective cohort study. Park B, Jeong BC, Seo SI, Jeon SS, Choi HY, Lee HM. J Korean Med Sci. 2013:227-36. [pmid: 23400428].
The true risk of blood transfusion after nephrectomy for renal masses: a population-based study. Vricella GJ, Finelli A, Alibhai SM, Ponsky LE, Abouassaly R. BJU Int. 2013:1294-300. [pmid: 23368715].
Association of microvascular and capillary-lymphatic invasion with outcome in patients with renal cell carcinoma. Eisenberg MS, Cheville JC, Thompson RH, Kaushik D, Lohse CM, Boorjian SA, Costello BA, Leibovich BC. J Urol. 2013:37-43. [pmid: 23353044].
Long-term outcome of small, organ-confined renal cell carcinoma (RCC) is not always favourable. Shindo T, Masumori N, Kobayashi K, Fukuta F, Hirobe M, Tonooka A, Hasegawa T, Kitamura H, Tsukamoto T. BJU Int. 2013:941-5. [pmid: 23350965].
Differential use of partial nephrectomy for intermediate and high complexity tumors may explain variability in reported utilization rates. Lane BR, Golan S, Eggener S, Tobert CM, Kahnoski RJ, Kutikov A, Smaldone M, Whelan CM, Shalhav A, Uzzo RG. J Urol. 2013:2047-53. [pmid: 23313207].
Renal cell carcinoma: A 12-year retrospective study of epidemiologic, therapeutic and follow-up data. Arnoux V, Long JA, Jund J, Fiard G, Terrier N, Thuillier C, Boillot B, Rambeaud JJ, Descotes JL. Prog Urol. 2013:15-21. [pmid: 23287479].
Overall survival and development of stage IV chronic kidney disease in patients undergoing partial and radical nephrectomy for benign renal tumors. Kaushik D, Kim SP, Childs MA, Lohse CM, Costello BA, Cheville JC, Boorjian SA, Leibovich BC, Thompson RH. Eur Urol. 2013:600-6. [pmid: 23280319].
Comparison of the loss of renal function after cold ischemia open partial nephrectomy, warm ischemia laparoscopic partial nephrectomy and laparoscopic partial nephrectomy using microwave coagulation. Kawahara T, Sakata R, Kawahara K, Ito H, Miyoshi Y, Sano F, Nakaigawa N, Uemura H, Yao M, Kubota Y, Makiyama K. Curr Urol. 2013:118-23. [pmid: 24917728].
Patient safety and the diffusion of surgical innovations: a national analysis of laparoscopic partial nephrectomy. Parsons JK, Palazzi K, Chang D, Stroup SP. Surg Endosc. 2013:1674-80. [pmid: 23239306].
Surgically induced chronic kidney disease may be associated with a lower risk of progression and mortality than medical chronic kidney disease. Lane BR, Campbell SC, Demirjian S, Fergany AF. J Urol. 2013:1649-55. [pmid: 23201493].
Racial disparity in renal cell carcinoma patient survival according to demographic and clinical characteristics. Chow WH, Shuch B, Linehan WM, Devesa SS. Cancer. 2013:388-94. [pmid: 23147245].
Can we predict which patients will evolve to chronic kidney disease after nephrectomy for cortical renal tumors?. Torricelli FC, Danilovic A, Marchini GS, Sant'Anna AC, Dall'Oglio MF, Srougi M. Int Braz J Urol. 2012:637-43. discussion 644. [pmid: 23131505].
Competing risks of death in patients with localized renal cell carcinoma: a comorbidity based model. Kutikov A, Egleston BL, Canter D, Smaldone MC, Wong YN, Uzzo RG. J Urol. 2012:2077-83. [pmid: 23083850].
Predictive factors for late recurrence in patients with stage T1 clear cell renal cell carcinoma: a multiinstitutional study. Ha YS, Park YH, Kang SH, Hong SH, Hwang TK, Byun SS, Kim YJ. Clin Genitourin Cancer. 2013:51-5. [pmid: 23017336].
Feasibility and outcomes of laparoscopic renal intervention after prior open ipsilateral retroperitoneal surgery. Boris RS, Gupta GN, Benson JS, Linehan WM, Pinto PA, Bratslavsky G. J Endourol. 2013:196-201. [pmid: 22963658].
The effect of gender on nephrectomy perioperative outcomes: a national survey. Sammon J, Trinh QD, Sun M, Bianchi M, Schmitges J, Shariat SF, Ghani KR, Sukumar S, Jeldres C, Briganti A, Perrotte P, Rogers CG, Peabody JO, Montorsi F, Menon M, Karakiewicz PI. Can J Urol. 2012:6337-44. [pmid: 22892256].
External validation of the preoperative Karakiewicz nomogram in a large multicentre series of patients with renal cell carcinoma. Gontero P, Sun M, Antonelli A, Bertini R, Carini M, Carmignani G, Longo N, Martorana G, Minervini A, Mirone V, Morgia G, Novara G, Oderda M, Simeone C, Simonato A, Siracusano S, Tizzani A, Volpe A, Karakiewicz P, Ficarra V. World J Urol. 2013:1285-90. [pmid: 22847452].
Histopathology of surgically treated renal cell carcinoma: survival differences by subtype and stage. Keegan KA, Schupp CW, Chamie K, Hellenthal NJ, Evans CP, Koppie TM. J Urol. 2012:391-7. [pmid: 22698625].
Assessment of cancer control outcomes in patients with high-risk renal cell carcinoma treated with partial nephrectomy. Hansen J, Sun M, Bianchi M, Rink M, Tian Z, Hanna N, Meskawi M, Schmitges J, Shariat SF, Chun FK, Perrotte P, Graefen M, Karakiewicz PI. Urology. 2012:347-53. [pmid: 22698478].
Incidence and long-term prognosis of papillary compared to clear cell renal cell carcinoma--a multicentre study. Steffens S, Janssen M, Roos FC, Becker F, Schumacher S, Seidel C, Wegener G, Thuroff JW, Hofmann R, Stockle M, Siemer S, Schrader M, Hartmann A, Kuczyk MA, Junker K, Schrader AJ. Eur J Cancer. 2012:2347-52. [pmid: 22698386].
Pathological implications of areas of lower enhancement on contrast-enhanced computed tomography in renal-cell carcinoma: additional information for selecting candidates for surveillance protocols. Villalobos-Gollas M, Aguilar-Davidov B, Culebro-Garcia C, Gomez-Alvarado MO, Rojas-Garcia P, Ibarra-Fombona R, Uribe-Uribe N, Feria-Bernal G, Castillejos-Molina R, Sotomayor M, Gabilondo F, Rodriguez-Covarrubias F. Int Urol Nephrol. 2012:1369-74. [pmid: 22648292].
Perioperative outcomes of laparoscopic radical nephrectomy for renal cell carcinoma in patients with dialysis-dependent end-stage renal disease. Yamashita K, Ito F, Nakazawa H. Ther Apher Dial. 2012:254-9. [pmid: 22607569].
Prognostic factors in renal cell carcinoma: analysis of 227 patients treated at the Brazilian National Cancer Institute. Ornellas AA, Andrade DM, Ornellas P, Wisnescky A, Schwindt AB. Int Braz J Urol. 2012:185-94. [pmid: 22555027].
The impact of delaying radical nephrectomy for stage II or higher renal cell carcinoma. Kim KH, You D, Jeong IG, Song C, Hong JH, Ahn H, Kim CS. J Cancer Res Clin Oncol. 2012:1561-7. [pmid: 22547152].
Perioperative outcomes of robotic and open partial nephrectomy for moderately and highly complex renal lesions. Simhan J, Smaldone MC, Tsai KJ, Li T, Reyes JM, Canter D, Kutikov A, Chen DY, Greenberg RE, Uzzo RG, Viterbo R. J Urol. 2012:2000-4. [pmid: 22498208].
Impact of renal function on cardiovascular events in patients undergoing radical nephrectomy for renal cancer. Takeshita H, Yokoyama M, Fujii Y, Chiba K, Ishioka J, Noro A, Kihara K. Int J Urol. 2012:722-8. [pmid: 22487379].
Inpatient safety trends in laparoscopic and open nephrectomy for renal tumours. Stroup SP, Palazzi KL, Chang DC, Ward NT, Parsons JK. BJU Int. 2012:1808-13. [pmid: 22471427].
Intraoperative ultrasonography: a useful tool in retrolaparoscopic nephron-sparing surgery. Kang N, Niu Y, Zhang J, Wang J, Tian X, Yan Y, Yu Z, Xing N. Urol Int. 2012:338-42. [pmid: 22441243].
Impact of comorbidity on complications after nephrectomy: use of the Clavien Classification of Surgical Complications. Hennus PM, Kroeze SG, Bosch JL, Jans JJ. BJU Int. 2012:682-7. [pmid: 22432906].
Functional recovery after partial nephrectomy: effects of volume loss and ischemic injury. Simmons MN, Hillyer SP, Lee BH, Fergany AF, Kaouk J, Campbell SC. J Urol. 2012:1667-73. [pmid: 22425124].
Under-grading of &lt;4 cm renal masses on renal biopsy. Harris CR, Whitson JM, Meng MV. BJU Int. 2012:794-7. [pmid: 22404857].
Laparoscopic and robotic partial nephrectomy with controlled hypotensive anesthesia to avoid hilar clamping: feasibility, safety and perioperative functional outcomes. Papalia R, Simone G, Ferriero M, Costantini M, Guaglianone S, Forastiere E, Gallucci M. J Urol. 2012:1190-4. [pmid: 22335869].
Higher perioperative morbidity and in-hospital mortality in patients with end-stage renal disease undergoing nephrectomy for non-metastatic kidney cancer: a population-based analysis. Schmitges J, Trinh QD, Sun M, Hansen J, Bianchi M, Jeldres C, Perrotte P, Dahlem R, Shariat SF, Chun FK, Montorsi F, Menon M, Fisch M, Graefen M, Karakiewicz PI. BJU Int. 2012:E183-90. [pmid: 22321256].
Three-dimensional tumour volume and cancer-specific survival for patients undergoing nephrectomy to treat pT1 clear-cell renal cell carcinoma. Jorns J, Thiel DD, Lohse CM, Williams A, Arnold ML, Cheville JC, Leibovich BC, Parker AS. BJU Int. 2012:956-60. [pmid: 22300498].
Pre-existing type-2 diabetes is not an adverse prognostic factor in patients with renal cell carcinoma: a single-center retrospective study. Antonelli A, Arrighi N, Corti S, Zanotelli T, Cozzoli A, Cosciani Cunico S, Simeone C. Urol Oncol. 2013:1310-5. [pmid: 22281433].
Histologic tumor necrosis is an independent prognostic indicator for clear cell and papillary renal cell carcinoma. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Rehak P, Pummer K, Zigeuner R. Am J Clin Pathol. 2012:283-9. [pmid: 22261455].
Does prolonged warm ischemia after partial nephrectomy under pneumoperitoneum cause irreversible damage to the affected kidney?. Choi JD, Park JW, Lee SY, Jeong BC, Jeon SS, Lee HM, Choi HY, Seo SI. J Urol. 2012:802-6. [pmid: 22245321].
Renal function outcomes after nephrectomy for kidney cancer in elderly patients. Markic D, Valencic M, Spanjol J, Materljan M, Fuckar D. Coll Antropol. 2011:121-4. [pmid: 22220418].
Hospital volume is a determinant of postoperative complications, blood transfusion and length of stay after radical or partial nephrectomy. Sun M, Bianchi M, Trinh QD, Abdollah F, Schmitges J, Jeldres C, Shariat SF, Graefen M, Montorsi F, Perrotte P, Karakiewicz PI. J Urol. 2012:405-10. [pmid: 22177151].
Clinical utility of the Glasgow Prognostic Score in patients undergoing curative nephrectomy for renal clear cell cancer: basis of new prognostic scoring systems. Lamb GW, Aitchison M, Ramsey S, Housley SL, McMillan DC. Br J Cancer. 2012:279-83. [pmid: 22166802].
Direct upper kidney pole access and early ligation of renal pedicle significantly facilitates transperitoneal laparoscopic nephrectomy procedures: Tunc technique. Tunc L, Canda AE, Polat F, Onaran M, Atkin S, Biri H, Bozkirli I. Surg Laparosc Endosc Percutan Tech. 2011:453-7. [pmid: 22146171].
Postoperative complications and long-term survival among patients treated surgically for renal cell carcinoma. Tan HJ, Hafez KS, Ye Z, Wei JT, Miller DC. J Urol. 2012:60-6. [pmid: 22114816].
Randomized controlled study of natural interferon alpha as adjuvant treatment for stage II or III renal cell carcinoma. Hinotsu S, Kawai K, Ozono S, Tsushima T, Tokuda N, Nomata K, Naito S, Akaza H. Int J Clin Oncol. 2013:68-74. [pmid: 22068465].
Renal cell carcinoma in young patients is associated with poorer prognosis. Lee LS, Yuen JS, Sim HG. Ann Acad Med Singapore. 2011:401-6. [pmid: 22065033].
Quality of life of patients undergoing surgical treatment for newly-diagnosed, clinically localized renal cell carcinoma. Ames SC, Parker AS, Crook JE, Diehl NN, Tan WW, Williams CR, Ames GE. J Psychosoc Oncol. 2011:593-605. [pmid: 22035533].
Partial elective nephrectomy. Zungri E, Martinez L, Leal D, Lorenzo L. Actas Urol Esp. 2012:160-4. [pmid: 21955560].
External validation of the Leibovich prognosis score for nonmetastatic clear cell renal cell carcinoma at a single European center applying routine pathology. Pichler M, Hutterer GC, Chromecki TF, Jesche J, Kampel-Kettner K, Rehak P, Pummer K, Zigeuner R. J Urol. 2011:1773-7. [pmid: 21944989].
Comparison of rates and risk factors for development of anaemia and erythropoiesis-stimulating agent utilization after radical or partial nephrectomy. Woldrich J, Mehrazin R, Bazzi WM, Bagrodia A, Kopp RP, Malcolm JB, Kane CJ, Patterson AL, Wan JY, Derweesh IH. BJU Int. 2012:1019-25. [pmid: 21933323].
Prognosis and characteristics of renal cell carcinoma in hemodialysis patients: bilateral occurrence does not influence cancer-specific survival. Takagi T, Kondo T, Izuka J, Kobayashi H, Tomita E, Hashimoto Y, Tanabe K. Int J Urol. 2011:806-12. [pmid: 21917022].
Outcomes and clinicopathologic variables associated with late recurrence after nephrectomy for localized renal cell carcinoma. Kim SP, Weight CJ, Leibovich BC, Thompson RH, Costello BA, Cheville JC, Lohse CM, Boorjian SA. Urology. 2011:1101-6. [pmid: 21903243].
Prognostic factors in a large multi-institutional series of papillary renal cell carcinoma. Zucchi A, Novara G, Costantini E, Antonelli A, Carini M, Carmignani G, Cosciani Cunico S, Fontana D, Longo N, Martignoni G, Minervini A, Mirone V, Porena M, Roscigno M, Schiavina R, Simeone C, Simonato A, Siracusano S, Terrone C, Ficarra V. BJU Int. 2012:1140-6. [pmid: 21871053].
Tumour diameter and decreased preoperative estimated glomerular filtration rate are independently correlated in patients with renal cell carcinoma. Donin NM, Suh LK, Barlow L, Hruby GW, Newhouse J, McKiernan J. BJU Int. 2012:379-83. [pmid: 21851533].
A multidisciplinary evaluation of inter-reviewer agreement of the nephrometry score and the prediction of long-term outcomes. Weight CJ, Atwell TD, Fazzio RT, Kim SP, Kenny M, Lohse CM, Boorjian SA, Leibovich BC, Thompson RH. J Urol. 2011:1223-8. [pmid: 21849200].
Increasing use of kidney sparing approaches for localized renal tumors in a community based health system: impact on renal functional outcomes. Lane BR, Chen H, Morrow M, Anema JG, Kahnoski RJ. J Urol. 2011:1229-35. [pmid: 21849192].
Impact of tumor size on renal function and prediction of renal insufficiency after radical nephrectomy in patients with renal cell carcinoma. Ohno Y, Nakashima J, Ohori M, Hashimoto T, Iseki R, Hatano T, Tachibana M. J Urol. 2011:1242-6. [pmid: 21849191].
The effect of hypertension and diabetes on the degree of renal function deterioration after unilateral nephrectomy. Satasivam P, Rao K, Guggenheimer K, Stanton R, Sowter S, Sengupta S, Bolton D. BJU Int. 2011:1508-12. [pmid: 21595821].
Critical appraisal of the PADUA classification and assessment of the R.E.N.A.L nephrometry score in patients undergoing partial nephrectomy. Hew MN, Baseskioglu B, Barwari K, Axwijk PH, Can C, Horenblas S, Bex A, Rosette JJ, Pes MP. J Urol. 2011:42-6. [pmid: 21571340].
Image guided percutaneous probe ablation for renal tumors in 65 solitary kidneys: functional and oncological outcomes. Altunrende F, Autorino R, Hillyer S, Yang B, Laydner H, White MA, Khanna R, Isac W, Spana G, Stein RJ, Haber GP, O'Malley CM, Remer EM, Kaouk JH. J Urol. 2011:35-41. [pmid: 21571336].
Benefits of a combined approach to sampling of renal neoplasms as demonstrated in a series of 351 cases. Parks GE, Perkins LA, Zagoria RJ, Garvin AJ, Sirintrapun SJ, Geisinger KR. Am J Surg Pathol. 2011:827-35. [pmid: 21552112].
Chronic pulmonary diseases are independent risk factors for complications after radical nephrectomy. Tokgoz H, Akduman B, Unal I, Erol B, Akyurek E, Mungan NA. Int Urol Nephrol. 2011:1025-31. [pmid: 21516476].
Post-operative acute kidney injury in patients with renal cell carcinoma is a potent risk factor for new-onset chronic kidney disease after radical nephrectomy. Cho A, Lee JE, Kwon GY, Huh W, Lee HM, Kim YG, Kim DJ, Oh HY, Choi HY. Nephrol Dial Transplant. 2011:3496-501. [pmid: 21406544].
Is it safe and effective to treat complex renal cysts by the laparoscopic approach?. Pinheiro T, Sepulveda F, Natalin RH, Metrebian E, Medina R, Goldman SM, Ortiz V, Andreoni C. J Endourol. 2011:471-6. [pmid: 21361825].
Percutaneous cryoablation of renal masses: impact of patient selection and treatment parameters on outcomes. Vricella GJ, Haaga JR, Adler BL, Dean Nakamoto Cherullo EE, Flick S, Ponsky LE. Urology. 2011:649-54. [pmid: 21185065].
Prognostic factors for renal dysfunction after nephrectomy in renal cell carcinomas. Xu Y, Wu B. J Surg Res. 2011:e53-7. [pmid: 21176917].
Adverse renal outcomes in subjects undergoing nephrectomy for renal tumors: a population-based analysis. Klarenbach S, Moore RB, Chapman DW, Dong J, Braam B. Eur Urol. 2011:333-9. [pmid: 21109345].
Contemporary experience with laparoscopic radical nephrectomy. Mues AC, Haramis G, Rothberg MB, Okhunov Z, Casazza C, Landman J. J Laparoendosc Adv Surg Tech A. 2011:15-8. [pmid: 21091214].
Clinical predictors of renal mass pathological features. Tsivian M, Mouraviev V, Albala DM, Caso JR, Robertson CN, Madden JF, Polascik TJ. BJU Int. 2011:735-40. [pmid: 21054752].
Comparison of laparoscopic versus open radical nephrectomy for large renal tumors: a retrospective analysis of multi-center results. Jeon SH, Kwon TG, Rha KH, Sung GT, Lee W, Lim JS, Jeong YB, Hong SH, Kim HH, Byun SS. BJU Int. 2011:817-21. [pmid: 21029315].
Benefit of laparoscopic radical nephrectomy in patients with a high BMI. Hagiwara M, Miyajima A, Matsumoto K, Kikuchi E, Nakagawa K, Oya M. Jpn J Clin Oncol. 2011:400-4. [pmid: 20926414].
Comparison of radical and partial nephrectomy in terms of renal function: a retrospective cohort study. Suer E, Burgu B, Gokce MI, Turkolmez K, Beduk Y, Baltaci S. Scand J Urol Nephrol. 2011:24-9. [pmid: 20923383].
Kidney function following nephrectomy: similitude and discrepancies between kidney cancer and living donation. Timsit MO, Nguyen KN, Rouach Y, Elie C, Loupy A, Fournier C, Legendre C, Mejean A. Urol Oncol. 2012:482-6. [pmid: 20864365].
Histopathological predictors of renal function decrease after laparoscopic radical nephrectomy. Gautam G, Lifshitz D, Shikanov S, Moore JM, Eggener SE, Shalhav AL, Chang A. J Urol. 2010:1872-6. [pmid: 20850146].
Clinico-radio-pathologic features of a solitary solid renal mass at MDCT examination. Kim EY, Park BK, Kim CK, Lee HM. Acta Radiol. 2010:1143-8. [pmid: 20849320].
Impact of body mass index and weight loss on cancer-specific and overall survival in patients with surgically resected renal cell carcinoma. Brookman-May S, Kendel F, Hoschke B, Wieland WF, Burger M, Rossler W, May M. Scand J Urol Nephrol. 2011:5-14. [pmid: 20846080].
Retroperitoneoscopic nephrectomy with a modified hand-assisted approach. Capolicchio JP, Saemi A, Trotter S, Plante MK. Urology. 2011:607-11. [pmid: 20708224].
Laparoscopic nephrectomy: initial experience with 120 cases. Cheema IA, Manecksha RP, Murphy M, Flynn R. Ir Med J. 2010:49-51. [pmid: 20666056].
Experiences of open transperitoneal radical nephrectomy for large renal masses. Yao XD, Ye DW, Zhang SL, Dai B, Zhang HL, Shen YJ, Zhu Y, Zhu YP, Shi GH, Ma CG, Xiao WJ, Qin XJ, Lin GW. Zhonghua Yi Xue Za Zhi. 2010:1117-9. [pmid: 20646430].
The Prognostic Factors for Patients with pT1a Renal Cell Carcinoma. Kim JM, Song PH, Kim HT, Park TC. Korean J Urol. 2010:233-8. [pmid: 20428424].
Single minimum incision endoscopic radical nephrectomy for renal tumors with preoperative virtual navigation using 3D-CT volume-rendering. Kamai T, Furuya N, Kambara T, Abe H, Honda M, Shioyama Y, Kaji Y, Yoshida K. BMC Urol. 2010:7. [pmid: 20398251].
The prognostic value of the width of the surgical margin in the enucleoresection of small renal cell carcinoma: an intermediate-term follow-up. Jeong SJ, Kim KT, Chung MS, Hong SK, Byun SS, Lee SE. Urology. 2010:587-92. [pmid: 20346491].
Impact of body mass index on perioperative outcomes of laparoscopic radical nephrectomy in Japanese patients with clinically localized renal cell carcinoma. Miyake H, Muramaki M, Tanaka K, Takenaka A, Fujisawa M. Int J Urol. 2010:522-6. [pmid: 20345492].
Radiofrequency ablation of renal tumours: diagnostic accuracy of contrast-enhanced ultrasound for early detection of residual tumour. Hoeffel C, Pousset M, Timsit MO, Elie C, Mejean A, Merran S, Tranquart F, Khairoune A, Joly D, Richard S, Helenon O, Correas JM. Eur Radiol. 2010:1812-21. [pmid: 20204642].
The use of the American Society of Anesthesiology Classification as a prognostic factor in patients with renal cell carcinoma. de Cassio Zequi S, de Campos EC, Guimaraes GC, Bachega W Jr, da Fonseca FP, Lopes A. Urol Int. 2010:67-72. [pmid: 20173372].
Histological subtype is an independent predictor of outcome for patients with renal cell carcinoma. Leibovich BC, Lohse CM, Crispen PL, Boorjian SA, Thompson RH, Blute ML, Cheville JC. J Urol. 2010:1309-15. [pmid: 20171681].
Minimum incision endoscopic surgery (MIES) in Japanese urology: results of adrenalectomy, radical nephrectomy and radical prostatectomy. Kihara K, Kobayashi T, Kawakami S, Fujii Y, Kageyama Y, Masuda H. Aktuelle Urol. 2010:S15-9. [pmid: 20094945].
Transperitoneal laparoscopic radical nephrectomy for patients with dialysis-dependent end-stage renal disease: an analysis and comparison of perioperative outcome. Bird VG, Shields JM, Aziz M, De Los Santos R, Ayyathurai R, Ciancio G. Urology. 2010:1335-42. [pmid: 20035985].
Prognostic factors influencing long-term survival of patients undergoing nephron-sparing surgery for nonmetastatic renal-cell carcinoma (RCC) with imperative indications. Haferkamp A, Kurosch M, Pritsch M, Hatiboglu G, Macher-Goeppinger S, Pfitzenmaier J, Pahernik S, Wagener N, Hohenfellner M. Ann Surg Oncol. 2010:544-51. [pmid: 19953334].
Functional results of partial nephrectomy for kidney tumors. Petrov SB, Shpilenia ES, Shkarupa DD. Vestn Khir Im I I Grek. 2009:85-7. [pmid: 19947426].
Evaluating overall survival and competing risks of death in patients with localized renal cell carcinoma using a comprehensive nomogram. Kutikov A, Egleston BL, Wong YN, Uzzo RG. J Clin Oncol. 2010:311-7. [pmid: 19933918].
Primary treatment of renal cell carcinoma. Yesterday, today, tomorrow. Dufour B. Bull Acad Natl Med. 2009:691-707. discussion 707-8. [pmid: 19883019].
De novo renal carcinoma in renal transplant recipients: effect of early treatment. Tillou X, Demailly M, Hakami F, Westeel PF, Saint F, Petit J. Transplant Proc. 2009:3314-6. [pmid: 19857739].
Laparoscopic radical nephrectomy in big surgical specimens. Alonso y, Gregorio S, Sanchez S, Soler C, Rando A, Giron M, Tabernero Gomez AJ, Aguilera A, Cisneros Ledo J, de la Pena Barthel J. Actas Urol Esp. 2009:755-8. [pmid: 19757660].
Renal cell carcinoma in patients with end-stage renal disease: relationship between histological type and duration of dialysis. Nouh MA, Kuroda N, Yamashita M, Hayashida Y, Yano T, Minakuchi J, Taniguchi S, Nomura I, Inui M, Sugimoto M, Kakehi Y. BJU Int. 2010:620-7. [pmid: 19747356].
Impact of Charlson's comorbidity index on overall survival following tumor nephrectomy for renal cell carcinoma. Ather MH, Nazim SM. Int Urol Nephrol. 2010:299-303. [pmid: 19714477].
Laparoscopic radical nephrectomy for patients with T2 and T3 renal-cell carcinoma: evaluation of perioperative outcomes. Bird VG, Shields JM, Aziz M, Ayyathurai R, De Los Santos R, Roeter DH. J Endourol. 2009:1527-33. [pmid: 19698054].
Laparoscopic radical nephrectomy for large renal-cell carcinomas. Hattori R, Osamu K, Yoshino Y, Tsuchiya F, Fujita T, Yamada S, Funahashi Y, Ono Y, Gotoh M. J Endourol. 2009:1523-6. [pmid: 19698022].
A multi-institutional study on the safety and efficacy of specimen morcellation after laparoscopic radical nephrectomy for clinical stage T1 or T2 renal cell carcinoma. Wu SD, Lesani OA, Zhao LC, Johnston WK, Wolf JS Jr, Clayman RV, Nadler RB. J Endourol. 2009:1513-8. [pmid: 19694517].
Laparoscopic radical nephrectomy for renal masses 7 centimeters or larger. Rosoff JS, Raman JD, Sosa RE, Del Pizzo JJ. JSLS. 2009:148-53. [pmid: 19660207].
Does histologic subtype affect oncologic outcomes after nephron-sparing surgery?. Crepel M, Isbarn H, Capitanio U, Liberman D, Jeldres C, Sun M, Shariat SF, Widmer H, Arjane P, Graefen M, Montorsi F, Patard JJ, Perrotte P, Karakiewicz PI. Urology. 2009:842-5. [pmid: 19628262].
Prevalence of renal cell carcinoma in patients with autosomal dominant polycystic kidney disease and chronic renal failure. Hajj P, Ferlicot S, Massoud W, Awad A, Hammoudi Y, Charpentier B, Durrbach A, Droupy S, Benoit G. Urology. 2009:631-4. [pmid: 19616833].
Patient and pathologic correlates with perioperative and long-term outcomes of laparoscopic radical nephrectomy. Gabr AH, Gdor Y, Strope SA, Roberts WW, Wolf JS Jr. Urology. 2009:635-40. [pmid: 19616826].
Urinary collecting system invasion is an independent prognostic factor of organ confined renal cell carcinoma. Verhoest G, Avakian R, Bensalah K, Thuret R, Ficarra V, Artibani W, Tostain J, Guille F, Cindolo L, De La Taille A, Abbou CC, Salomon L, Rioux-Leclercq N, Patard JJ. J Urol. 2009:854-9. [pmid: 19616244].
Approach and specimen handling do not influence oncological perioperative and long-term outcomes after laparoscopic radical nephrectomy. Gabr AH, Gdor Y, Strope SA, Roberts WW, Wolf JS Jr. J Urol. 2009:874-80. [pmid: 19616234].
Baseline renal function, ischaemia time and blood loss predict the rate of renal failure after partial nephrectomy. Jeldres C, Bensalah K, Capitanio U, Zini L, Perrotte P, Suardi N, Tostain J, Valeri A, Descotes JL, Rambeaud JJ, de La Taille A, Salomon L, Abbou C, Patard JJ, Karakiewicz PI. BJU Int. 2009:1632-5. [pmid: 19545272].
Overweight is associated with improved cancer-specific survival in patients with organ-confined renal cell carcinoma. Schrader AJ, Rustemeier J, Rustemeier JC, Timmesfeld N, Varga Z, Hegele A, Olbert PJ, Hofmann R. J Cancer Res Clin Oncol. 2009:1693-9. [pmid: 19543914].
Four-arm robotic partial nephrectomy for complex renal cell carcinoma. Gong Y, Du C, Josephson DY, Wilson TG, Nelson R. World J Urol. 2010:111-5. [pmid: 19499225].
Renal Tumor Quantification and Classification in Contrast-Enhanced Abdominal CT. Linguraru MG, Yao J, Gautam R, Peterson J, Li Z, Linehan WM, Summers RM. Pattern Recognit. 2009:1149-1161. [pmid: 19492069].
Hybrid renal cell carcinomas containing histopathologic features of chromophobe renal cell carcinomas and oncocytomas have excellent oncologic outcomes. Waldert M, Klatte T, Haitel A, Ozsoy M, Schmidbauer J, Marberger M, Remzi M. Eur Urol. 2010:661-5. [pmid: 19477583].
MRI and CT characteristics of successfully ablated renal masses: Imaging surveillance after radiofrequency ablation. Davenport MS, Caoili EM, Cohan RH, Ellis JH, Higgins EJ, Willatt J, Fox GA. AJR Am J Roentgenol. 2009:1571-8. [pmid: 19457820].
Validation of a postoperative prognostic model consisting of tumor microvascular invasion, size, and grade to predict disease-free and cancer-specific survival of patients with surgically resected renal cell carcinoma. May M, Brookman-Amissah S, Kendel F, Knoll N, Roigas J, Hoschke B, Miller K, Gilfrich C, Pflanz S, Gralla O. Int J Urol. 2009:616-21. [pmid: 19456988].
Single center experience with percutaneous and laparoscopic cryoablation of small renal masses. Malcolm JB, Berry TT, Williams MB, Logan JE, Given RW, Lance RS, Barone B, Shaves S, Vingan H, Fabrizio MD. J Endourol. 2009:907-11. [pmid: 19456244].
Metastatic renal cell carcinoma risk according to tumor size. Thompson RH, Hill JR, Babayev Y, Cronin A, Kaag M, Kundu S, Bernstein M, Coleman J, Dalbagni G, Touijer K, Russo P. J Urol. 2009:41-5. [pmid: 19450840].
Factors predicting health-related quality of life recovery in patients undergoing surgical treatment for renal tumors: prospective evaluation using the RAND SF-36 Health Survey. Novara G, Secco S, Botteri M, De Marco V, Artibani W, Ficarra V. Eur Urol. 2010:112-20.
Laparoscopic radical versus partial nephrectomy for tumors &gt;4 cm: intermediate-term oncologic and functional outcomes. Simmons MN, Weight CJ, Gill IS. Urology. 2009:1077-82. [pmid: 19394509].
Limitation for performing ultrasound-guided radiofrequency ablation of small renal masses. Park BK, Kim CK, Choi HY, Lee HM, Jeon SS, Seo SI, Han DH. Eur J Radiol. 2010:248-52. [pmid: 19394181].
Postoperative surveillance for renal cell carcinoma: a multifactorial histological subtype specific protocol. Siddiqui SA, Frank I, Cheville JC, Lohse CM, Leibovich BC, Blute ML. BJU Int. 2009:778-85. [pmid: 19338559].
Radical nephrectomy surgical outcomes in the University HealthSystem Consortium Data Base: Impact of hospital case volume, hospital size, and geographic location on 40,000 patients. Mitchell RE, Lee BT, Cookson MS, Barocas DA, Duke Herrell S, Clark PE, Smith JA, Chang SS. Cancer. 2009:2447-52. [pmid: 19309750].
A single institution experience of 141 cases of laparoscopic radical nephrectomy with cost-reductive measures. Kumar A, Gupta NP, Hemal AK. J Endourol. 2009:445-9. [pmid: 19265470].
Decision tree for laparoscopic partial nephrectomy versus laparoscopic renal cryoablation for small renal masses. Nisbet AA, Rieder JM, Tran VQ, Williams SG, Chien GW. J Endourol. 2009:431-7. [pmid: 19265467].
Pre-operative renal arterial embolisation does not provide survival benefit in patients with radical nephrectomy for renal cell carcinoma. May M, Brookman-Amissah S, Pflanz S, Roigas J, Hoschke B, Kendel F. Br J Radiol. 2009:724-31. [pmid: 19255117].
Comparison of rates and risk factors for developing chronic renal insufficiency, proteinuria and metabolic acidosis after radical or partial nephrectomy. Malcolm JB, Bagrodia A, Derweesh IH, Mehrazin R, Diblasio CJ, Wake RW, Wan JY, Patterson AL. BJU Int. 2009:476-81. [pmid: 19220252].
A population-based comparison of survival after nephrectomy vs nonsurgical management for small renal masses. Zini L, Perrotte P, Jeldres C, Capitanio U, Duclos A, Jolivet-Tremblay M, Arjane P, Peloquin F, Pharand D, Villers A, Montorsi F, Patard JJ, Karakiewicz PI. BJU Int. 2009:899-904. discussion 904. [pmid: 19154499].
Prognostic value of capsular invasion for localized clear-cell renal cell carcinoma. Cho HJ, Kim SJ, Ha US, Hong SH, Kim JC, Choi YJ, Hwang TK. Eur Urol. 2009:1006-12. [pmid: 19135776].
Organ-confined clear cell renal cell carcinoma: the prognostic impact of microvascular invasion, nuclear grade and tumour size. Zubac DP, Bostad L, Kihl B, Eide J, Wentzel-Larsen T, Haukaas SA. APMIS. 2008:1027-33. [pmid: 19133004].
The prognostic relevance of interactions between venous invasion, lymph node involvement and distant metastases in renal cell carcinoma after radical nephrectomy. Zubac DP, Bostad L, Seidal T, Wentzel-Larsen T, Haukaas SA. BMC Urol. 2008:19. [pmid: 19099564].
Transperitoneal versus retroperitoneal laparoscopic radical nephrectomy: a comparative study. Taue R, Izaki H, Koizumi T, Kishimoto T, Oka N, Fukumori T, Takahashi M, Kanayama HO. Int J Urol. 2009:263-7. [pmid: 19087210].
Retroperitoneoscopic nephrectomy in overweight and obese Japanese patients: complications and outcomes. Makiyama K, Nakaigawa N, Miyoshi Y, Murakami T, Yao M, Kubota Y. Urol Int. 2008:427-30. [pmid: 19077404].
Cancer-specific and non-cancer-related mortality rates in European patients with T1a and T1b renal cell carcinoma. Zini L, Patard JJ, Capitanio U, Crepel M, de La Taille A, Tostain J, Ficarra V, Bernhard JC, Ferriere JM, Pfister C, Villers A, Montorsi F, Karakiewicz PI. BJU Int. 2009:894-8. [pmid: 19076131].
Age at diagnosis is a determinant factor of renal cell carcinoma-specific survival in patients treated with nephrectomy. Karakiewicz PI, Jeldres C, Suardi N, Hutterer GC, Perrotte P, Capitanio U, Ficarra V, Cindolo L, de La Taille A, Tostain J, Mulders PF, Salomon L, Zigeuner R, Schips L, Chautard D, Valeri A, Lechevallier E, Descots JL, Lang H, Mejean A, Verhoest G, Patard JJ. Can Urol Assoc J. 2008:610-7. [pmid: 19066680].
Stage-specific effect of nodal metastases on survival in patients with non-metastatic renal cell carcinoma. Capitanio U, Jeldres C, Patard JJ, Perrotte P, Zini L, de La Taille A, Ficarra V, Cindolo L, Bensalah K, Artibani W, Tostain J, Valeri A, Zigeuner R, Mejean A, Descotes JL, Lechevallier E, Mulders PF, Lang H, Jacqmin D, Karakiewicz PI. BJU Int. 2009:33-7. [pmid: 18990161].
Number of needle passes does not correlate with the diagnostic yield of renal fine needle aspiration cytology. Andonian S, Okeke Z, Okeke DA, Sugrue C, Wasserman PG, Lee BR. J Endourol. 2008:2377-80. [pmid: 18937600].
Obesity and morbid obesity are associated with a greater conversion rate to open surgery for standard but not hand assisted laparoscopic radical nephrectomy. Gabr AH, Elsayed ER, Gdor Y, Roberts WW, Wolf JS Jr. J Urol. 2008:2357-62. discussion 2362. [pmid: 18930284].
Effect of baseline glomerular filtration rate on survival in patients undergoing partial or radical nephrectomy for renal cortical tumors. Pettus JA, Jang TL, Thompson RH, Yossepowitch O, Kagiwada M, Russo P. Mayo Clin Proc. 2008:1101-6. [pmid: 18828969].
Evaluation of renicapsular involvement in Stages I and II renal cell carcinoma from the morphological and prognostic point of view. May M, Brookman-Amissah S, Roigas J, Gilfrich CP, Pflanz S, Hoschke B, Gunia S. Urol Oncol. 2010:274-9. [pmid: 18805709].
Radiofrequency ablation of renal tumors in the solitary kidney. Krambeck AE, Farrell MA, Callstrom MR, Atwell TD, Charboneau JW, Chow GK, Dimarco DS, Patterson DE. Can J Urol. 2008:4163-8. discussion 4168. [pmid: 18706143].
Robotic nephrectomy for the treatment of benign and malignant disease. Rogers C, Laungani R, Krane LS, Bhandari A, Bhandari M, Menon M. BJU Int. 2008:1660-5. [pmid: 18671787].
Incidence of benign pathologic lesions at partial nephrectomy for presumed RCC renal masses: Japanese dual-center experience with 176 consecutive patients. Fujii Y, Komai Y, Saito K, Iimura Y, Yonese J, Kawakami S, Ishikawa Y, Kumagai J, Kihara K, Fukui I. Urology. 2008:598-602. [pmid: 18649929].
Elective laparoscopic partial nephrectomy in patients with tumors >4 cm. Rais-Bahrami S, Romero FR, Lima GC, Kohanim S, Permpongkosol S, Trock BJ, Jarrett TW, Kavoussi LR. Urology. 2008:580-3. [pmid: 18632142].
Retroperitoneal laparoscopic radical nephrectomy: intermediate oncological results. Larre S, Kanso C, De La Taille A, Hoznek A, Vordos D, Yiou R, Abbou CC, Salomon L. World J Urol. 2008:611-5. [pmid: 18629504].
Nephron-sparing surgery: a call for greater application of established techniques. Young JG, Luscombe CJ, Lynch C, Wallace DM. BJU Int. 2008:1389-93. [pmid: 18565170].
Impact of comorbidity on overall survival in patients surgically treated for renal cell carcinoma. Berger DA, Megwalu II, Vlahiotis A, Radwan MH, Serrano MF, Humphrey PA, Piccirillo JF, Kibel AS. Urology. 2008:359-63. [pmid: 18468663].
The efficacy of laparoscopic radical nephrectomy for renal cell cancer in the elderly: an oncological outcome analysis. Harano M, Eto M, Yokomizo A, Tatsugami K, Hamaguchi M, Naito S. Int J Urol. 2008:577-81. [pmid: 18462356].
Transperitoneal approach for radical nephrectomy: five years experience at Pakistan Institute of Medical Sciences, Islamabad Pakistan. Ghaffar F, Sajid MA, Anwar K. J Ayub Med Coll Abbottabad. 2007:15-8. [pmid: 18444583].
Preoperative nomogram predicting 12-year probability of metastatic renal cancer. Raj GV, Thompson RH, Leibovich BC, Blute ML, Russo P, Kattan MW. J Urol. 2008:2146-51. discussion 2151. [pmid: 18423735].
Percutaneous renal cryoablation: experience treating 115 tumors. Atwell TD, Farrell MA, Leibovich BC, Callstrom MR, Chow GK, Blute ML, Charboneau JW. J Urol. 2008:2136-40. 2140-1. [pmid: 18423719].
How long is too long? The effect of the duration of anaesthesia on the incidence of non-urological complications after surgery. Routh JC, Bacon DR, Leibovich BC, Zincke H, Blute ML, Frank I. BJU Int. 2008:301-4. [pmid: 18410433].
Evaluation of the association of current cigarette smoking and outcome for patients with clear cell renal cell carcinoma. Parker A, Lohse C, Cheville J, Leibovich B, Igel T, Blute M. Int J Urol. 2008:304-8. [pmid: 18380816].
Tumor size does not predict risk of metastatic disease or prognosis of small renal cell carcinomas. Klatte T, Patard JJ, de Martino M, Bensalah K, Verhoest G, de la Taille A, Abbou CC, Allhoff EP, Carrieri G, Riggs SB, Kabbinavar FF, Belldegrun AS, Pantuck AJ. J Urol. 2008:1719-26. [pmid: 18343437].
Transperitoneal laparoscopic radical nephrectomy for large (more than 7 cm) renal masses. Berger AD, Kanofsky JA, O'Malley RL, Hyams ES, Chang C, Taneja SS, Stifelman MD. Urology. 2008:421-4. [pmid: 18342177].
Association of abnormal preoperative laboratory values with survival after radical nephrectomy for clinically confined clear cell renal cell carcinoma. Magera JS Jr, Leibovich BC, Lohse CM, Sengupta S, Cheville JC, Kwon ED, Blute ML. Urology. 2008:278-82. [pmid: 18308103].
Immediate renal tumor involution after radiofrequency thermal ablation. Ganguli S, Brennan DD, Faintuch S, Rayan ME, Goldberg SN. J Vasc Interv Radiol. 2008:412-8. [pmid: 18295702].
Evaluation of the impact of body mass index on outcome among renal mass patients treated with hand-assisted laparoscopic radical nephrectomy. Parker AS, Lewis R, Heckman MG, Diehl NH, Brisson T, Pak R, Wehle MJ. J Endourol. 2008:301-6. [pmid: 18294037].
Incidence of local and port site recurrence of urologic cancer after laparoscopic surgery. Tanaka K, Hara I, Takenaka A, Kawabata G, Fujisawa M. Urology. 2008:728-34. [pmid: 18279936].
The influence of body mass index on the long-term survival of patients with renal cell carcinoma after tumour nephrectomy. Haferkamp A, Pritsch M, Bedke J, Wagener N, Pfitzenmaier J, Buse S, Hohenfellner M. BJU Int. 2008:1243-6. [pmid: 18261150].
Comparison of standard and hand-assisted laparoscopic radical nephrectomy for renal cell carcinoma. Harano M, Eto M, Yokomizo A, Tatsugami K, Hamaguchi M, Naito S. Fukuoka Igaku Zasshi. 2007:389-96. [pmid: 18186294].
Laparoscopic radical nephrectomy versus open radical nephrectomy in T1-T3 renal tumors: An outcome analysis. Ganpule AP, Sharma R, Thimmegowda M, Veeramani M, Desai MR. Indian J Urol. 2008:39-43. [pmid: 19468357].
Core biopsies of renal tumors: a study on diagnostic accuracy, interobserver, and intraobserver variability. Kummerlin I, ten Kate F, Smedts F, Horn T, Algaba F, Trias I, de la Rosette J, Laguna MP. Eur Urol. 2008:1219-25. [pmid: 18082317].
En bloc stapler ligation of the renal vascular pedicle during laparoscopic nephrectomy. Buse S, Gilfrich C, Pfitzenmaier J, Bedke J, Haferkamp A, Hohenfellner M. BJU Int. 2008:878-82. [pmid: 18070189].
Surgical resection provides excellent outcomes for patients with cystic clear cell renal cell carcinoma. Webster WS, Thompson RH, Cheville JC, Lohse CM, Blute ML, Leibovich BC. Urology. 2007:900-4. discussion 904. [pmid: 18068445].
Nephron-sparing surgery versus radical nephrectomy in the treatment of intracapsular renal cell carcinoma up to 7cm. Antonelli A, Cozzoli A, Nicolai M, Zani D, Zanotelli T, Perucchini L, Cunico SC, Simeone C. Eur Urol. 2008:803-9. [pmid: 18036730].
Transabdominal radical nephrectomy for renal cell carcinoma: an experience on 155 patients. Chen XF, Zhou FJ, Han H, Qin ZK, Liu ZW, Yu SL, Li YH, Wang H, Hou GL. Ai Zheng. 2007:528-32. [pmid: 17672946].
Nephrectomy: indications, complications and mortality in 154 consecutive patients. Rafique M. J Pak Med Assoc. 2007:308-11. [pmid: 17629234].
Microvascular tumor invasion, tumor size and Fuhrman grade: a pathological triad for prognostic evaluation of renal cell carcinoma. Dall'Oglio MF, Ribeiro-Filho LA, Antunes AA, Crippa A, Nesrallah L, Goncalves PD, Leite KR, Srougi M. J Urol. 2007:425-8. discussion 428. [pmid: 17561167].
Prognostic impact of tumor size on pT2 renal cell carcinoma: an international multicenter experience. Klatte T, Patard JJ, Goel RH, Kleid MD, Guille F, Lobel B, Abbou CC, De La Taille A, Tostain J, Cindolo L, Altieri V, Ficarra V, Artibani W, Prayer-Galetti T, Allhoff EP, Schips L, Zigeuner R, Figlin RA, Kabbinavar FF, Pantuck AJ, Belldegrun AS, Lam JS. J Urol. 2007:35-40. discussion 40. [pmid: 17521678].
CT-guided biopsy for the diagnosis of renal tumors before treatment with percutaneous ablation. Heilbrun ME, Zagoria RJ, Garvin AJ, Hall MC, Krehbiel K, Southwick A, Clark PE. AJR Am J Roentgenol. 2007:1500-5. [pmid: 17515368].
Renal cell carcinoma: a clinicopathological follow-up study after radical nephrectomy. Zubac DP, Bostad L, Gestblom C, Kihl B, Seidal T, Wentzel-Larsen T, Bakke AM. Scand J Urol Nephrol. 2007:191-7. [pmid: 17469026].
Impact of clinicopathological parameters in patients treated for renal cell carcinoma. Dall'Oglio MF, Arap MA, Antunes AA, Cury J, Leite KR, Srougi M. J Urol. 2007:1687-91. [pmid: 17437783].
Five-year survival after surgical treatment for kidney cancer: a population-based competing risk analysis. Hollingsworth JM, Miller DC, Daignault S, Hollenbeck BK. Cancer. 2007:1763-8. [pmid: 17351954].
ECOG performance status 0 or 1 and symptom classification do not improve the ability to predict renal cell carcinoma-specific survival. Karakiewicz PI, Trinh QD, de la Taille A, Abbou CC, Salomon L, Tostain J, Cindolo L, Artibani W, Ficarra V, Patard JJ. Eur J Cancer. 2007:1023-9. [pmid: 17349784].
The follow-up management of non-metastatic renal cell carcinoma: definition of a surveillance protocol. Antonelli A, Cozzoli A, Zani D, Zanotelli T, Nicolai M, Cunico SC, Simeone C. BJU Int. 2007:296-300. [pmid: 17326263].
Diagnostic yield of 58 consecutive imaging-guided biopsies of solid renal masses: should we biopsy all that are indeterminate?. Beland MD, Mayo-Smith WW, Dupuy DE, Cronan JJ, DeLellis RA. AJR Am J Roentgenol. 2007:792-7. [pmid: 17312070].
Outcome of open and laparoscopic nephrectomies in a county hospital--centralization. Lund L, Jonler M, Bisballe S. Ugeskr Laeger. 2007:602-4. [pmid: 17311755].
Sporadic renal cell carcinoma in young and elderly patients: are there different clinicopathological features and disease specific survival rates?. Denzinger S, Otto W, Burger M, Hammerschmied C, Junker K, Hartmann A, Wieland WF, Walter B. World J Surg Oncol. 2007;16.
Prognostic relevance of capsular involvement and collecting system invasion in stage I and II renal cell carcinoma. Klatte T, Chung J, Leppert JT, Lam JS, Pantuck AJ, Figlin RA, Belldegrun AS. BJU Int. 2007:821-4. [pmid: 17244281].
Dynamic outcome prediction in patients with clear cell renal cell carcinoma treated with radical nephrectomy: the D-SSIGN score. Thompson RH, Leibovich BC, Lohse CM, Cheville JC, Zincke H, Blute ML, Frank I. J Urol. 2007:477-80. [pmid: 17222614].
Nephron sparing surgery: A single institution experience. Agrawal S, Jha MS, Khurana N, Ansari MS, Dubey D, Srivastava A, Kapoor R, Kumar A, Jain M, Mandhani A. Indian J Urol. 2007:23-7. [pmid: 19675756].
Laparoscopic radical nephrectomy: comparison of clinical Stage T1 and T2 renal tumors. Gong EM, Lyon MB, Orvieto MA, Lucioni A, Gerber GS, Shalhav AL. Urology. 2006:1183-7. [pmid: 17169642].
Conventional and hand-assisted laparoscopic radical nephrectomy: Comparative analysis of 271 cases. Matin SF, Dhanani N, Acosta M, Wood CG. J Endourol. 2006:891-4. [pmid: 17144857].
Perioperative clinical thromboembolic events after radical or partial nephrectomy. Pettus JA, Eggener SE, Shabsigh A, Yanke B, Snyder ME, Serio A, Vickers A, Russo P, Donat SM. Urology. 2006:988-92. [pmid: 17113889].
Incidence of benign lesions for clinically localized renal masses smaller than 7 cm in radiological diameter: influence of sex. Snyder ME, Bach A, Kattan MW, Raj GV, Reuter VE, Russo P. J Urol. 2006:2391-5. discussion 2395-6. [pmid: 17085108].
Greater body mass index is associated with better pathologic features and improved outcome among patients treated surgically for clear cell renal cell carcinoma. Parker AS, Lohse CM, Cheville JC, Thiel DD, Leibovich BC, Blute ML. Urology. 2006:741-6. [pmid: 17070345].
Gender discrepancies in the diagnosis of renal cortical tumors. Pierorazio PM, Murphy AM, Benson MC, McKiernan JM. World J Urol. 2007:81-5. [pmid: 17066264].
Prognostic significance of common preoperative laboratory variables in clear cell renal cell carcinoma. Lee SE, Byun SS, Han JH, Han BK, Hong SK. BJU Int. 2006:1228-32. [pmid: 17034508].
Risk of renal insufficiency in African-Americans after radical nephrectomy for kidney cancer. Hepps D, Chernoff A. Urol Oncol. 2006:391-5. [pmid: 16962487].
Increased preoperative serum C-reactive protein level predicts a poor prognosis in patients with localized renal cell carcinoma. Komai Y, Saito K, Sakai K, Morimoto S. BJU Int. 2007:77-80. [pmid: 16956357].
Are small renal tumors harmless? Analysis of histopathological features according to tumors 4 cm or less in diameter. Remzi M, Ozsoy M, Klingler HC, Susani M, Waldert M, Seitz C, Schmidbauer J, Marberger M. J Urol. 2006:896-9. [pmid: 16890647].
Experiences in US-guided percutaneous radiofrequency ablation of 44 renal tumors in 31 patients: analysis of predictors for complications and technical success. Veltri A, Calvo A, Tosetti I, Pagano E, Genovesio A, Virzi V, Ferrando U, Fontana D, Gandini G. Cardiovasc Intervent Radiol. 2006:811-8. [pmid: 16832595].
Renal cell carcinoma recurrence after nephrectomy for localized disease: predicting survival from time of recurrence. Eggener SE, Yossepowitch O, Pettus JA, Snyder ME, Motzer RJ, Russo P. J Clin Oncol. 2006:3101-6. [pmid: 16809736].
Open partial nephrectomy: outcomes from two UK centres. Ray ER, Turney BW, Singh R, Chandra A, Cranston DW, O'Brien TS. BJU Int. 2006:1211-5. [pmid: 16686713].
Open partial nephrectomy for tumor in a solitary kidney: experience with 400 cases. Fergany AF, Saad IR, Woo L, Novick AC. J Urol. 2006:1630-3. discussion 1633. [pmid: 16600716].
Intraoperative conversion of laparoscopic partial nephrectomy. Rais-Bahrami S, Lima GC, Varkarakis IM, Romero FR, Trock B, Jarrett TW, Kavoussi LR. J Endourol. 2006:205-8. [pmid: 16548731].
Radical nephrectomy performed by open, laparoscopy with or without hand-assistance or robotic methods by the same surgeon produces comparable perioperative results. Nazemi T, Galich A, Sterrett S, Klingler D, Smith L, Balaji KC. Int Braz J Urol. 2006:15-22. [pmid: 16519823].
Impact of body mass index on survival of patients with surgically treated renal cell carcinoma. Donat SM, Salzhauer EW, Mitra N, Yanke BV, Snyder ME, Russo P. J Urol. 2006:46-52. [pmid: 16406867].
Retroperitoneoscopic versus open surgical radical nephrectomy for large renal cell carcinoma in clinical stage cT2 or cT3a: quality of life, pain and reconvalescence. Dillenburg W, Poulakis V, Skriapas K, de Vries R, Ferakis N, Witzsch U, Melekos M, Becht E. Eur Urol. 2006:314-22. discussion 322-3. [pmid: 16377073].
Follow-up of renal oncocytoma diagnosed by percutaneous tumor biopsy. Neuzillet Y, Lechevallier E, Andre M, Daniel L, Nahon O, Coulange C. Urology. 2005:1181-5. [pmid: 16360437].
Proposal for revision of the TNM classification system for renal cell carcinoma. Ficarra V, Guille F, Schips L, de la Taille A, Prayer Galetti T, Tostain J, Cindolo L, Novara G, Zigeuner R, Bratti E, Li G, Altieri V, Abbou CC, Zanolla L, Artibani W, Patard JJ. Cancer. 2005:2116-23. [pmid: 16208703].
The laparoscopic nephrectomy learning curve: a single centre's development of a de novo practice. Phillips J, Catto JW, Lavin V, Doyle D, Smith DJ, Hastie KJ, Oakley NE. Postgrad Med J. 2005:599-603. [pmid: 16143692].
Early ligature of renal artery during radical laparoscopic transperitoneal nephrectomy: description of standard technique and direct access. Porpiglia F, Terrone C, Cracco C, Cossu M, Grande S, Musso F, Renard J, Scarpa RM. J Endourol. 2005:623-6. discussion 626-7. [pmid: 16053349].
Miniinvasive laparoscopic or retroperitoneoscopic radical nephrectomy for the parenchymal tumor. Hora M, Klecka J Jr, Hes O, Ferda J, Urge T. Rozhl Chir. 2005:246-52. [pmid: 16045121].
Laparoscopic nephrectomy. Poulsen EU, Eddy B, Poulsen J. Scand J Urol Nephrol. 2005:138-42. [pmid: 16019768].
Laparoscopic nephrectomy: initial experience in Israel with 110 cases. Nadu A, Mor Y, Chen J, Sofer M, Golomb J, Ramon J. Isr Med Assoc J. 2005:431-4. [pmid: 16011057].
Multiinstitutional European validation of the 2002 TNM staging system in conventional and papillary localized renal cell carcinoma. Ficarra V, Schips L, Guille F, Li G, De La Taille A, Prayer Galetti T, Cindolo L, Novara G, Zigeuner RE, Bratti E, Tostain J, Altieri V, Abbou CC, Artibani W, Patard JJ. Cancer. 2005:968-74. [pmid: 16007683].
Incisional hernia following hand-assisted laparoscopic surgery for renal cell cancer. Troxel SA, Das S. JSLS. 2005:196-8. [pmid: 15984709].
A description of radical nephrectomy practice and outcomes in England: 1995-2002. Nuttall M, Cathcart P, van der Meulen J, Gillatt D, McIntosh G, Emberton M. BJU Int. 2005:58-61. [pmid: 15963121].
Direct access to the renal artery at the level of treitz ligament during left radical laparoscopic transperitoneal nephrectomy. Porpiglia F, Terrone C, Cracco C, Renard J, Musso F, Grande S, Scarpa RM. Eur Urol. 2005:291-5. [pmid: 15939529].
Laparoscopic partial nephrectomy: hand-assisted technique. Strup S, Garrett J, Gomella L, Rowland R. J Endourol. 2005:456-9. discussion 459-60. [pmid: 15910255].
Comparison of presentation and outcome for patients 18 to 40 and 60 to 70 years old with solid renal masses. Gillett MD, Cheville JC, Karnes RJ, Lohse CM, Kwon ED, Leibovich BC, Zincke H, Blute ML. J Urol. 2005:1893-6. [pmid: 15879770].
Percutaneous radiofrequency ablation of renal tumors: technique, complications, and outcomes. Ahrar K, Matin S, Wood CG, Wallace MJ, Gupta S, Madoff DC, Rao S, Tannir NM, Jonasch E, Pisters LL, Rozner MA, Kennamer DL, Hicks ME. J Vasc Interv Radiol. 2005:679-88. [pmid: 15872323].
Results of open radical nephrectomy in a series of 230 patients. Peyromaure M, Barry Delongchamps N, Roffi F, Debre B, Zerbib M. Prog Urol. 2005:18-22. [pmid: 15822386].
Renal neoplasms in younger adults: analysis of 112 tumors from a single institution according to the new 2004 World Health Organization classification and 2002 American Joint Committee on Cancer Staging System. Cao Y, Paner GP, Perry KT, Flanigan RC, Campbell SC, Picken MM. Arch Pathol Lab Med. 2005:487-91. [pmid: 15794671].
Laparoscopic heminephrectomy for tumor. Finelli A, Gill IS, Desai MM, Tan YH, Moinzadeh A, Singh D, Kaouk JH. Urology. 2005:473-8. [pmid: 15780358].
Impact of tumor size on the long-term survival of patients with early stage renal cell cancer. Kuczyk M, Wegener G, Merseburger AS, Anastasiadis A, Machtens S, Zumbragel A, Hartmann JT, Bokemeyer C, Jonas U, Stenzl A. World J Urol. 2005:50-4. [pmid: 15729558].
Pathological stage does not alter the prognosis for renal lesions determined to be stage T1 by computerized tomography. Roberts WW, Bhayani SB, Allaf ME, Chan TY, Kavoussi LR, Jarrett TW. J Urol. 2005:713-5. [pmid: 15711249].
Learning curve of hand-assisted retroperitoneoscopic nephrectomy in less-experienced laparoscopic surgeons. Kawauchi A, Fujito A, Soh J, Yoneda K, Ukimura O, Mizutani Y, Miki T. Int J Urol. 2005:1-6. [pmid: 15661047].
Predicting postoperative renal insufficiency in patients undergoing nephrectomy for renal malignancy: assessment by renal scintigraphy using 99mtechnetium-mercaptoacetyltriglycine. Shirasaki Y, Saika T, Tsushima T, Nasu Y, Arata R, Kumon H. J Urol. 2005:388-90. [pmid: 15643177].
pT2 classification for renal cell carcinoma.Can its accuracy be improved?. Frank I, Blute ML, Leibovich BC, Cheville JC, Lohse CM, Kwon ED, Zincke H. J Urol. 2005:380-4. [pmid: 15643175].
Re-evaluation of the Tumour-Node-Metastasis staging of locally advanced renal cortical tumours: absolute size (T2) is more significant than renal capsular invasion (T3a). Murphy AM, Gilbert SM, Katz AE, Goluboff ET, Sawczuk IS, Olsson CA, Benson MC, McKiernan JM. BJU Int. 2005:27-30. [pmid: 15638890].
Prospective randomized comparison of transperitoneal versus retroperitoneal laparoscopic radical nephrectomy. Desai MM, Strzempkowski B, Matin SF, Steinberg AP, Ng C, Meraney AM, Kaouk JH, Gill IS. J Urol. 2005:38-41. [pmid: 15592021].
Clinicopathological features of recurrence after radical surgery for nonmetastatic renal cell carcinoma. Ishimura T, Sakai I, Harada K, Hara I, Eto H, Miyake H. Int J Clin Oncol. 2004:369-72. [pmid: 15549586].
Laparoscopic radical nephrectomy for large (greater than 7 cm, T2) renal tumors. Steinberg AP, Finelli A, Desai MM, Abreu SC, Ramani AP, Spaliviero M, Rybicki L, Kaouk J, Novick AC, Gill IS. J Urol. 2004:2172-6. [pmid: 15538225].
Management of renal masses in patients medically unsuitable for nephrectomy--natural history, complications, and outcome. Lamb GW, Bromwich EJ, Vasey P, Aitchison M. Urology. 2004:909-13. [pmid: 15533476].
Prognosticfactors in patients with renal cell carcinoma: is TNM (1997) staging relevant in Indian subpopulation?. Srivastava A, Mandhani A, Kapoor R, Jain M, Dubey D, Srivastava A, Raghavendra M, Kumar A. Indian J Cancer. 2004:99-103. [pmid: 15472406].
Portless endoscopic radical nephrectomy via a single minimum incision in 80 patients. Kihara K, Kageyama Y, Yano M, Kobayashi T, Kawakami S, Fujii Y, Masuda H, Hyochi N. Int J Urol. 2004:714-20. [pmid: 15379934].
Long-term consequence of renal function following nephrectomy for renal cell cancer. Shirasaki Y, Tsushima T, Nasu Y, Kumon H. Int J Urol. 2004:704-8. [pmid: 15379932].
The British Association of Urological Surgeons Section of Endourology audit of laparoscopic nephrectomy. Keoghane SR, Keeley FX, Timoney AG, Tolley DA, Joyce A, Downey P. BJU Int. 2004:577-81. [pmid: 15329116].
Laparoscopic radical nephrectomy in the elderly. Varkarakis I, Neururer R, Harabayashi T, Bartsch G, Peschel R. BJU Int. 2004:517-20. [pmid: 15329103].
Kidney function after nephrectomy for renal cell carcinoma. Shirasaki Y, Tsushima T, Saika T, Nasu Y, Kumon H. Urology. 2004:43-7. discussion 48. [pmid: 15245931].
Guidelines for the surveillance of localized renal cell carcinoma based on the patterns of relapse after nephrectomy. Stephenson AJ, Chetner MP, Rourke K, Gleave ME, Signaevsky M, Palmer B, Kuan J, Brock GB, Tanguay S. J Urol. 2004:58-62. [pmid: 15201737].
Microscopic venous invasion in renal cell carcinoma as a predictor of recurrence after radical surgery. Ishimura T, Sakai I, Hara I, Eto H, Miyake H. Int J Urol. 2004:264-8. [pmid: 15147540].
Impact of surgical volume on mortality and length of stay after nephrectomy. Taub DA, Miller DC, Cowan JA, Dimick JB, Montie JE, Wei JT. Urology. 2004:862-7. [pmid: 15134966].
Use of American Society of Anesthesiologists physical status classification to assess perioperative risk in patients undergoing radical nephrectomy for renal cell carcinoma. Han KR, Kim HL, Pantuck AJ, Dorey FJ, Figlin RA, Belldegrun AS. Urology. 2004:841-6. discussion 846-7. [pmid: 15134960].
Laparoscopic radical nephrectomy: techniques, results and oncological outcome in 125 consecutive cases. Wille AH, Roigas J, Deger S, Tullmann M, Turk I, Loening SA. Eur Urol. 2004:483-8. discussion 488-9. [pmid: 15041113].
Permanent flank bulge is a consequence of flank incision for radical nephrectomy in one half of patients. Chatterjee S, Nam R, Fleshner N, Klotz L. Urol Oncol. 2004:36-9. [pmid: 14969802].
Hand assisted laparoscopic radical nephrectomy: comparison with open radical nephrectomy. Lee SE, Ku JH, Kwak C, Kim HH, Paick SH. J Urol. 2003:756-9. [pmid: 12913691].
Single-center comparison of purely laparoscopic, hand-assisted laparoscopic, and open radical nephrectomy in patients at high anesthetic risk. Baldwin DD, Dunbar JA, Parekh DJ, Wells N, Shuford MD, Cookson MS, Smith JA Jr, Herrell SD, Chang SS, McDougall EM. J Endourol. 2003:161-7. [pmid: 12803988].
Outcome and survival with nonsurgical management of renal cell carcinoma. Baird AD, Woolfenden KA, Desmond AD, Fordham MV, Parsons KF. BJU Int. 2003:600-2. [pmid: 12699467].
Clinicopathological study of renal cell carcinoma. Nakatani T, Yoshida N, Iwata H, Kuratsukuri K, Uchida J, Kawashima H, Ikemoto S, Sugimura K. Oncol Rep. 2003:679-85. [pmid: 12684643].
Renal cell carcinoma: gender difference in incidental detection and cancer-specific survival. Beisland C, Medby PC, Beisland HO. Scand J Urol Nephrol. 2002:414-8. [pmid: 12623504].
Laparoscopic radical nephrectomy: indications, techniques, and oncological outcome. Wille AH, Roigas J, Deger S, Turk I, Tullmann M, Dubbke A, Schnorr D. Urologe A. 2003:205-10. [pmid: 12607088].
Incidental and symptomatic renal tumors: impact on patient survival. Dall'Oglio MF, Srougi M, Goncalves PD, Leite K, Nesrallah L, Hering F. Sao Paulo Med J. 2002:165-9. [pmid: 12563422].
Hand-assisted laparoscopy for large renal specimens: a multi-institutional study. Stifelman MD, Handler T, Nieder AM, Del Pizzo J, Taneja S, Sosa RE, Shichman SJ. Urology. 2003:78-82. [pmid: 12559271].
Prospective analysis of computerized tomography and needle biopsy with permanent sectioning to determine the nature of solid renal masses in adults. Dechet CB, Zincke H, Sebo TJ, King BF, LeRoy AJ, Farrow GM, Blute ML. J Urol. 2003:71-4. [pmid: 12478106].
Mode of presentation of renal cell carcinoma provides prognostic information. Lee CT, Katz J, Fearn PA, Russo P. Urol Oncol. 2002:135-40. [pmid: 12474528].
An outcome prediction model for patients with clear cell renal cell carcinoma treated with radical nephrectomy based on tumor stage, size, grade and necrosis: the SSIGN score. Frank I, Blute ML, Cheville JC, Lohse CM, Weaver AL, Zincke H. J Urol. 2002:2395-400. [pmid: 12441925].
Sporadic renal cell carcinoma in young adults: presentation, treatment, and outcome. Abou El Fettouh HI, Cherullo EE, El-Jack M, Al Maslamani Y, Novick AC. Urology. 2002:806-10. [pmid: 12429303].
Thrombocytosis is associated with a significant increase in the cancer specific death rate after radical nephrectomy. O'Keefe SC, Marshall FF, Issa MM, Harmon MP, Petros JA. J Urol. 2002:1378-80. [pmid: 12352397].
Prognostic significance of primary-tumor extension, stage and grade of nuclear differentiation in patients with renal cell carcinoma. Fiori E, De Cesare A, Galati G, Bononi M, D'Andrea N, Barbarosos A, Izzo L, Bolognese A. J Exp Clin Cancer Res. 2002:229-32. [pmid: 12148583].
Prognostic factors in patients with renal cell carcinoma: retrospective analysis of 675 cases. Ficarra V, Righetti R, Pilloni S, D'amico A, Maffei N, Novella G, Zanolla L, Malossini G, Mobilio G. Eur Urol. 2002:190-8. [pmid: 12074408].
Recurrence of renal cell carcinoma more than 5 years after nephrectomy. Uchida K, Miyao N, Masumori N, Takahashi A, Oda T, Yanase M, Kitamura H, Itoh N, Sato M, Tsukamoto T. Int J Urol. 2002:19-23. [pmid: 11972645].
Coloepiploic mobilization during left radical nephrectomy for renal cell carcinoma is indicated to reduce the risk of iatrogenic splenectomy. Mejean A, Chretien Y, Vogt B, Cazin S, Balian C, Thiounn N, Dufour B. Urology. 2002:358-61. [pmid: 11880070].
Laparoscopic radical nephrectomy in 100 patients: a single center experience from the United States. Gill IS, Meraney AM, Schweizer DK, Savage SS, Hobart MG, Sung GT, Nelson D, Novick A. Cancer. 2001:1843-55. [pmid: 11745257].
Renal cell carcinoma: evaluation of the 1997 TNM system and recommendations for follow-up after surgery. Gofrit ON, Shapiro A, Kovalski N, Landau EH, Shenfeld OZ, Pode D. Eur Urol. 2001:669-74. discussion 675. [pmid: 11464056].
Matched comparison of radical nephrectomy vs nephron-sparing surgery in patients with unilateral renal cell carcinoma and a normal contralateral kidney. Lau WK, Blute ML, Weaver AL, Torres VE, Zincke H. Mayo Clin Proc. 2000:1236-42. [pmid: 11126830].
Laparoscopic versus open radical nephrectomy: a 9-year experience. Dunn MD, Portis AJ, Shalhav AL, Elbahnasy AM, Heidorn C, McDougall EM, Clayman RV. J Urol. 2000:1153-9. [pmid: 10992356].
Comparison of preoperative embolization followed by radical nephrectomy with radical nephrectomy alone for renal cell carcinoma. Zielinski H, Szmigielski S, Petrovich Z. Am J Clin Oncol. 2000:6-12. [pmid: 10683065].
Renal cell carcinoma: prognostic significance of incidentally detected tumors. Tsui KH, Shvarts O, Smith RB, Figlin R, de Kernion JB, Belldegrun A. J Urol. 2000:426-30. [pmid: 10647646].
Mortality and morbidity after nephrectomy for renal cell carcinoma using a transperitoneal anterior subcostal incision. Mejean A, Vogt B, Quazza JE, Chretien Y, Dufour B. Eur Urol. 99:298-302.
Fine-needle aspiration of renal masses in adults: analysis of results and diagnostic problems in 108 cases. Truong LD, Todd TD, Dhurandhar B, Ramzy I. Diagn Cytopathol. 99:339-49.
Significant prognostic factors for 5-year survival after curative resection of renal cell carcinoma. Masuda H, Kurita Y, Fukuta K, Mugiya S, Suzuki K, Fujita K. Int J Urol. 98:418-22.
Cystic renal cell carcinoma: pathological features, survival and implications for treatment. Bielsa O, Lloreta J, Gelabert-Mas A. Br J Urol. 98:16-20.
Laparoscopic nephrectomy: the experience of the laparoscopy working group of the German Urologic Association. Rassweiler J, Fornara P, Weber M, Janetschek G, Fahlenkamp D, Henkel T, Beer M, Stackl W, Boeckmann W, Recker F, Lampel A, Fischer C, Humke U, Miller K. J Urol. 98:18-21.
Radical nephrectomy for renal cell carcinoma: long-term results and prognostic factors on a series of 328 cases. Giberti C, Oneto F, Martorana G, Rovida S, Carmignani G. Eur Urol. 97:40-8.
Risk factors for postoperative hemorrhage after partial nephrectomy. Jung S, Min GE, Chung BI, Jeon SH. Korean J Urol. 2014:17-22. [pmid: 24466392].
Clinico-pathological prognostic factors of renal cell carcinoma: A 15-year review from a single center in Greece. Grivas N, Kafarakis V, Tsimaris I, Raptis P, Hastazeris K, Stavropoulos NE. Urol Ann. 2014:116-121. [pmid: 24833821].
Clinical outcome of small renal cell carcinoma after delayed surgery versus immediate surgery. Sugimoto K, Shimizu N, Nose K, Tahara H, Imanishi M, Nishioka T, Esa A, Kajikawa H, Uemura H. J Cancer. 2013:514-518. [pmid: 23901351].
Percutaneous image-guided radiofrequency ablation of renal neoplasms: Seven-year local experience. Tsang KWK, Lee SF, Cheung HY, Lui PY, Tam KY. Hong Kong. 2013:17-26.
Visceral obesity and risk of high grade disease in clinical T1a renal cell carcinoma. Zhu Y, Wang H-K, Zhang H-L, Yao X-D, Zhang S-L, Dai B, Shen Y-J, Liu X-H, Zhou L-P, Ye D-W. J Urol. 2013:447-453. [pmid: 23253956].
Body mass index and survival in patients with renal cell carcinoma: A clinical-based cohort and meta-analysis. Choi Y, Park B, Jeong BC, Seo SI, Jeon SS, Choi HY, Adami H-O, Lee JE, Lee HM. Int J Cancer. 2013:625-634. [pmid: 22610826].
Importance of local data on occurrence and outcomes of renal cell cancer. Veeratterapillay R, Rakhra S, El-Sherif A, Robson C, Johnson MI, Pickard RS, Soomro N, Heer R. J Clini Urol. 2013:158-163.
Robotic laparoendoscopic single site urological surgery: Analysis of 50 consecutive cases. White MA, Autorino R, Spana G, Hillyer S, Stein RJ, Kaouk JH. J Urol. 2012:1696-1701. [pmid: 22425120].
Stage T1NOMO renal cell carcinoma: The prognosid in Asian patients. Zhang Z-L, Chen W, Li Y-H, Liu Z-W, Luo J-H, Lau W, Tan M-H, Zhou F-J. Chin J Cancer. 2011:772-778. [pmid: 22035858].
Robotics applied in laparoscopic kidney surgery: The Yonsei University experience of 127 cases. Lorenzo EIS, Jeong W, Oh CK, Chung BH, Choi YD, Rha KH. Urology. 2011:114-118. [pmid: 20434761].
Fine needle aspiration of renal cortical lesions in adults. Adeniran AJ, Al-Ahmadie H, Iyengar P, Reuter VE, Lin O. Diagn Cytopathol. 2010:710-715. [pmid: 19950394].
Prognostic Impact of Histological Subtype on Surgically Treated Localized Renal Cell Carcinoma. Teloken PE, Thompson RH, Tickoo SK, Cronin A, Savage C, Reuter VE, Russo P. J Urol. 2009:2132-2136. [pmid: 19758615].
Nephron-sparing surgery for small renal cell carcinoma. Li Y, Zhu S, Cai W, Chen S, Li Q. J Nanjing Med Univ. 2009:207-211.
Young Age Is Independent Prognostic Factor for Cancer-Specific Survival of Low-Stage Clear Cell Renal Cell Carcinoma. Jung E-J, Lee HJ, Kwak C, Ku JH, Moon KC. Urology. 2009:137-141. [pmid: 18950844].
Clinicopathological features and survival rates of patients with renal cell carcinoma under 50 years of age. Atmaca AF, Bayrak O, Kandemir O, Serefoglu EC, Culha IE, Canda AE, Balbay MD. Cent Eur J Med. 2008:453-458.
Direct real-time temperature monitoring for laparoscopic and CT-guided radiofrequency ablation of renal tumors between 3 and 5 cm. Carey RI, Leveillee RJ. J Endourol. 2007:807-813. [pmid: 17867933].
Randomized trial of laparoscopic (nu) open nephrectomy. Burgess NA, Koo BC, Calvert RC, Hindmarsh A, Donaldson PJ, Rhodes M. J Endourol. 2007:610-613. [pmid: 17638555].
Laparoscopic Cryoablation of Small Renal Masses: Technique and Results after 6-Year Experience. Cestari A, Guazzoni G, Buffi NM, Riva M, Rigatti P. Eur Urol Suppl. 2007:646-652.
Pathological Features of Renal Neoplasms Classified by Size and Symptomatology. Schlomer B, Figenshau RS, Yan Y, Venkatesh R, Bhayani SB. J Urol. 2006:1317-1320. [pmid: 16952619].
Laparoscopic radical nephrectomy for renal cell carcinoma: Oncologically safe?. Laparoscopische behandeling van niercelcarcinoom: Oncologisch verantwoord?. Schatteman P, Tuytten T, Carpentier P, Fonteyne E, Mottrie A. Tijdschr Geneeskd. 2005:179-184.
Renal artery pseudoaneurysm after partial nephrectomy: Three case reports and a literature review. Albani JM, Novick AC. Urology. 2003:227-231. [pmid: 12893324].
Incidental detection beyond pathological factors as prognostic predictor of renal cell carcinoma. Ficarra V, Prayer-Galetti T, Novella G, Bratti E, Maffei N, Dal Bianco M, Artibani W, Pagano F. Eur Urol. 2003:663-669. [pmid: 12767368].
Perioperative homologous blood transfusion and survival in patients with surgically treated renal cell carcinoma. Mermershtain W, Eidelberg I, Yusim I, Ariad S, Kaneti J. UroOncology. 2003:23-25.
Stage pT1 renal cell carcinoma: Review of the prognostic significance of size. Zucchi A, Mearini L, Mearini E, Costantini E. Urol Int. 2003:47-50. [pmid: 12566815].
Renal cell carcinoma: Clinical experience and technical success with radio-frequency ablation of 42 tumors. Gervais DA, McGovern FJ, Arellano RS, Scott McDougal W, Mueller PR. Radiology. 2003:417-424. [pmid: 12563135].
A retrospective analysis of serum CA 15-3 concentrations in patients with localised or metastatic renal cancer and its impact on prognosis and follow-up.A single-centre experience. Briasoulis E, Pentheroudakis G, Letsa I, Pavlidis N. UroOncology. 2002:179-184.
Radiologic, pathologic and molecular attributes of two types of papillary renal adenocarcinomas. Mydlo JH, Weinstein R, Misseri R, Axiotis C, Thelmo W. Scand J Urol Nephrol. 2001:262-269. [pmid: 11676349].
Importance of early detection of renal carcinoma with regard to the prognosis: Vyznam vcasneho zachytu karcinomu ledviny - Vzhledem k prognoze. Fiala A, Urban M. Prakt Lek. 2001:197-199.
Renal cell carcinoma: Clinical and therapeutic considerations about 301 cases. Destito A, Servello C, Pisanti F, Lacquaniti S, Candidi MO, Racioppi M, Alcini E. Acta Med Rom. 99:498-503.
Impact of tumor size on the clinical outcomes of patients with Robson Stage I renal cell carcinoma. Kinouchi T, Saiki S, Meguro N, Maeda O, Kuroda M, Usami M, Kotake T. Cancer. 99:689-695.
A review of our first 100 cases of laparoscopic nephrectomy: Defining risk factors for complications. Keeley FX, Tolley DA. Br J Urol. 98:615-618.
Partial nephrectomy: Alternative treatment for selected patients with renal cell carcinoma. Duque JLF, Loughlin KR, O'Leary MP, Kumar S, Richie JP. Urology. 98:584-590.
Laparoscopic radical nephrectomy with morcellation for renal cell carcinoma: The Saskatoon experience. Barrett PH, Fentie DD, Taranger LA. Urology. 98:23-28.
Prognosis in the cases with renal cell carcinoma according to clinical parameters. Fukuda M, Satomi Y, Asakura T, Hosaka M, Noguchi S, Kishida T, Kondou I, Ida T, Hirokawa M, Kumagai H, Shiozaki H, Ishizuka E, Miyai K, Fukuoka H, Sasaki K, Oogo Y, Koudaira T, Ogawa K, Nakahashi M, Matsuura K, Moriyama M, Udagawa K, Senga Y, Ishibashi Y, Shimura H. Jpn J Urol. 98:647-656.
Assessment of renal lesions with blood oxygenation level-dependent MRI at 3 T: Preliminary experience. Min JH, Kim CK, Park BK, Kim E, Kim B. American Journal of Roentgenology. 2011:W489-W494. [pmid: 21862777].
Assessing the anatomical characteristics of renal masses has a limited effect on the prediction of pathological outcomes in solid, enhancing, small renal masses: results using the PADUA classification system. Shin TY, Kim J, Koo KC, Lim SK, Kim DW, Kang MW, Rha KH, Choi YD, Ham WS. BJU Int. 2014:754-61. [pmid: 24053790].
Individualized renal mass biopsy strategy for Chinese patients with different subtypes and necrosis area. Shi GH, Chen Y, Yao XD, Zhang SL, Dai B, Feng LQ, Zhang HL, Shen YJ, Zhu Y, Zhu YP, Xiao WJ, Ma CG, Wen LG, Qin XJ, Yang LF, Ye DW. Urol Oncol. 2013:920-3. [pmid: 23886035].
Diagnosis of renal angiomyolipoma with hounsfield unit thresholds: effect of size of region of interest and nephrographic phase imaging. Davenport MS, Neville AM, Ellis JH, Cohan RH, Chaudhry HS, Leder RA. Radiology. 2011:158-65. [pmid: 21555349].
Diagnostic accuracy of segmental enhancement inversion for the diagnosis of renal oncocytoma using biphasic computed tomography (CT) and multiphase contrast-enhanced magnetic resonance imaging (MRI). Schieda N, Al-Subhi M, Flood TA, El-Khodary M, McInnes MD. Eur Radiol. 2014:2787-94. [pmid: 25027841].
Unenhanced CT for the detection of renal cell carcinoma: effect of tumor size and contour type. Jung SI, Park HS, Kim YJ, Jeon HJ. Abdom Imaging. 2014:348-57. [pmid: 24407727].
Computed tomography-guided renal tumor biopsies: tumor imaging features affecting sample adequacy. Davis IC, Heilbrun ME, Tangtiang K, Childs DD, Zagoria RJ. J Comput Assist Tomogr. 2013:171-5. [pmid: 23493205].
What is the added value of combined core biopsy and fine needle aspiration in the diagnostic process of renal tumours?. Barwari K, Kummerlin IP, ten Kate FJ, Algaba F, Trias I, Wijkstra H, De la Rosette JJ, Laguna P. World J Urol. 2013:823-7. [pmid: 21626116].
Typing of renal tumors by morphological and immunocytochemical evaluation of fine needle aspirates. Strojan Flezar M, Gutnik H, Jeruc J, Kirbis IS. Virchows Arch. 2011:607-14. [pmid: 22052200].
Angiomyolipoma with minimal fat: can it be differentiated from clear cell renal cell carcinoma by using standard MR techniques?. Hindman N, Ngo L, Genega EM, Melamed J, Wei J, Braza JM, Rofsky NM, Pedrosa I. Radiology. 2012:468-77. [pmid: 23012463].
Role of diffusion-weighted magnetic resonance imaging in characterization of renal tumors. Razek AA, Farouk A, Mousa A, Nabil N. J Comput Assist Tomogr. 2011:332-6. [pmid: 21586925].
Combination of core biopsy and fine-needle aspiration increases diagnostic rate for small solid renal tumors. Li G, Cuilleron M, Zhao A, Obadia F, Mouracade P, Tostain J, Cottier M, Peoc'h M, Gigante M. Anticancer Res. 2012:3463-6. [pmid: 22843931].
EUS-guided FNA aspiration of kidney masses: a multicenter U.S. experience. DeWitt J, Gress FG, Levy MJ, Hernandez LV, Eloubeidi MA, Mishra G, Sherman S, Al-Haddad MA, LeBlanc JK. Gastrointest Endosc. 2009:573-8. [pmid: 19560139].
Contrast-enhanced ultrasound using a time-intensity curve for the diagnosis of renal cell carcinoma. Aoki S, Hattori R, Yamamoto T, Funahashi Y, Matsukawa Y, Gotoh M, Yamada Y, Honda N. BJU Int. 2011:349-54. [pmid: 21044245].
The value of contrast enhanced ultrasound (CEUS) in the characterisation of patients with renal masses. Ignee A, Straub B, Brix D, Schuessler G, Ott M, Dietrich CF. Clin Hemorheol Microcirc. 2010:275-90. [pmid: 21187576].
Exophytic renal masses: angular interface with renal parenchyma for distinguishing benign from malignant lesions at MR imaging. Verma SK, Mitchell DG, Yang R, Roth CG, O'Kane P, Verma M, Parker L. Radiology. 2010:501-7. [pmid: 20160001].
Minimal fat renal angiomyolipoma: the initial study with contrast-enhanced ultrasonography. Lu Q, Wang W, Huang B, Li C, Li C. Ultrasound Med Biol. 2012:1896-901. [pmid: 22906749].
Cytological punctures in the diagnosis of renal tumours: a study on accuracy and reproducibility. Kummerlin IP, Smedts F, ten Kate FJ, Horn T, Algaba F, Trias I, Wijkstra H, de la Rosette JJ, Laguna MP. Eur Urol. 2009:187-95. [pmid: 18486314].
Diffusion-weighted MRI in inflammatory renal lesions: all that glitters is not RCC!. Goyal A, Sharma R, Bhalla AS, Gamanagatti S, Seth A. Eur Radiol. 2013:272-9. [pmid: 22797980].
Clear cell renal cell carcinoma: discrimination from other renal cell carcinoma subtypes and oncocytoma at multiphasic multidetector CT. Young JR, Margolis D, Sauk S, Pantuck AJ, Sayre J, Raman SS. Radiology. 2013:444-53. [pmid: 23382290].
Accuracy of multiphase helical tomography in detection and characterisation of suspected renal masses using histopathological findings as gold standard. Siddiqui TS, Tariq A, Rehman B, Siddiqui TS, Asim A. J Ayub Med Coll Abbottabad. 2010:170-3. [pmid: 22338448].
Single-phase dual-energy CT allows for characterization of renal masses as benign or malignant. Graser A, Becker CR, Staehler M, Clevert DA, Macari M, Arndt N, Nikolaou K, Sommer W, Stief C, Reiser MF, Johnson TR. Invest Radiol. 2010:399-405. [pmid: 20498609].
Value of T2-weighted MR imaging in differentiating low-fat renal angiomyolipomas from other renal tumors. Choi HJ, Kim JK, Ahn H, Kim CS, Kim MH, Cho KS. Acta Radiol. 2011:349-53. [pmid: 21498374].
Real-time 3D fluoroscopy-guided large core needle biopsy of renal masses: a critical early evaluation according to the IDEAL recommendations. Kroeze SG, Huisman M, Verkooijen HM, van Diest PJ, Ruud Bosch JL, van den Bosch MA. Cardiovasc Intervent Radiol. 2012:680-5. [pmid: 21822769].
High temporal resolution 3D gadolinium-enhanced dynamic MR imaging of renal tumors with pharmacokinetic modeling: preliminary observations. Chandarana H, Amarosa A, Huang WC, Kang SK, Taneja S, Melamed J, Kim S. J Magn Reson Imaging. 2013:802-8. [pmid: 23389833].
Diagnostic efficacy of contrast-enhanced ultrasound for small renal masses. Oh TH, Lee YH, Seo IY. Korean J Urol. 2014:587-92. [pmid: 25237460].
Percutaneous US-guided needle biopsies of solid renal masses. Aribas BK, Arda K, Aktas E, Ciledag N, Yakut F, Sahin G, Cosar Y, Dogan K, Kaya G. Neoplasma. 2011:146-52. [pmid: 21275465].
Evaluation of percutaneous biopsies of renal masses under MRI-guidance: a retrospective study about 26 cases. Garnon J, Schlier A, Buy X, Tsoumakidou G, de Mathelin M, Breton E, Gangi A. Eur Radiol. 2014.
Is there a role of the enhancement degree of the lesion on computerized tomography for the characterization of renal tumors?. Kutman K, Suer E, Beduk Y, Ozturk E, Gulpinar O, Gokce I, Baltaci S. J Urol. 2013:436-40. [pmid: 22982427].
Evaluation of malignant and benign renal lesions using diffusion-weighted MRI with multiple b values. Erbay G, Koc Z, Karadeli E, Kuzgunbay B, Goren MR, Bal N. Acta Radiol. 2012:359-65. [pmid: 22334870].
Contrast-enhanced ultrasonography in the diagnosis of solid renal tumors. Tamai H, Takiguchi Y, Oka M, Shingaki N, Enomoto S, Shiraki T, Furuta M, Inoue I, Iguchi M, Yanaoka K, Arii K, Shimizu Y, Nakata H, Shinka T, Sanke T, Ichinose M. J Ultrasound Med. 2005:1635-40. [pmid: 16301719].
Indications for renal fine needle aspiration biopsy in the era of modern imaging modalities. Dragoescu EA, Liu L. Cytojournal. 2013;15.
Detection of renal lesion enhancement with dual-energy multidetector CT. Neville AM, Gupta RT, Miller CM, Merkle EM, Paulson EK, Boll DT. Radiology. 2011:173-83. [pmid: 21292866].
Evaluation of imaging-guided fine-needle percutaneous biopsy of renal masses. Jaff A, Molinie V, Mellot F, Guth A, Lebret T, Scherrer A. Eur Radiol. 2005:1721-6. [pmid: 15627185].
Renal mass core biopsy: accuracy and impact on clinical management. Maturen KE, Nghiem HV, Caoili EM, Higgins EG, Wolf JS Jr, Wood DP Jr. AJR Am J Roentgenol. 2007:563-70. [pmid: 17242269].
Diagnostic value of CT-guided biopsy of indeterminate renal masses. Eshed I, Elias S, Sidi AA. Clin Radiol. 2004:262-7. [pmid: 15037139].
Renal lesions: characterization with diffusion-weighted imaging versus contrast-enhanced MR imaging. Taouli B, Thakur RK, Mannelli L, Babb JS, Kim S, Hecht EM, Lee VS, Israel GM. Radiology. 2009:398-407. [pmid: 19276322].
Visceral obesity is associated with better recurrence-free survival after curative surgery for Japanese patients with localized clear cell renal cell carcinoma. Kaneko G, Miyajima A, Yuge K, Yazawa S, Mizuno R, Kikuchi E, Jinzaki M, Oya M. Jpn J Clin Oncol. 2014.
Role of percutaneous image-guided biopsy in the evaluation of renal masses. Hara I, Miyake H, Hara S, Arakawa S, Hanioka K, Kamidono S. Urol Int. 2001:199-202. [pmid: 11598445].
Characterization and outcome of renal cancers </= 4cm treated by surgery. Gigante M, Li G, Gentil-Perret A, Chamba C, Tostain J. Prog Urol. 2010:572-7. [pmid: 20832034].
Can high-attenuation renal cysts be differentiated from renal cell carcinoma at unenhanced CT?. Jonisch AI, Rubinowitz AN, Mutalik PG, Israel GM. Radiology. 2007:445-50. [pmid: 17456870].
Renal masses--evaluation by amplitude coded colour Doppler sonography and multiphasic contrast-enhanced CT. Riccabona M, Szolar D, Preidler K, Uggowitzer M, Kugler C, Dorfler O, Schreyer HH. Acta Radiol. 99:457-61.
Role of ultrasonography in screening for urological malignancies in patients presenting with painless haematuria. Yip SK, Peh WC, Tam PC, Li JH, Lam CH. Ann Acad Med Singapore. 99:174-7.
FDG PET characterization of renal masses: preliminary experience. Goldberg MA, Mayo-Smith WW, Papanicolaou N, Fischman AJ, Lee MJ. Clin Radiol. 97:510-5.
Dynamic computed tomography and color Doppler ultrasound of renal parenchymal neoplasms: correlations with histopathological findings. Kitamura H, Fujimoto H, Tobisu K, Mizuguchi Y, Maeda T, Matsuoka N, Komiyama M, Nakagawa T, Kakizoe T. Jpn J Clin Oncol. 2004:78-81. [pmid: 15067100].
Comparison of 16-MDCT and MRI for characterization of kidney lesions. Beer AJ, Dobritz M, Zantl N, Weirich G, Stollfuss J, Rummeny EJ. AJR Am J Roentgenol. 2006:1639-50. [pmid: 16714654].
Utility of iodine overlay technique and virtual unenhanced images for the characterization of renal masses by dual-energy CT. Song KD, Kim CK, Park BK, Kim B. AJR Am J Roentgenol. 2011:W1076-82. [pmid: 22109322].
Computer-aided detection of kidney tumor on abdominal computed tomography scans. Kim DY, Park JW. Acta Radiol. 2004:791-5. [pmid: 15624525].
Small incidental renal tumors.Evaluation and biological parameters. Remzi M, Memarsadeghi M. Urologe A. 480. 2007:478-4. [pmid: 17447049].
Multiphasic helical CT of the kidney: increased conspicuity for detection and characterization of small (&lt; 3-cm) renal masses. Szolar DH, Kammerhuber F, Altziebler S, Tillich M, Breinl E, Fotter R, Schreyer HH. Radiology. 97:211-7.
Radiologically guided percutaneous fine-needle aspiration biopsy of pelvic and retroperitoneal masses: a retrospective study of 68 cases. Guo Z, Kurtycz DF, De Las Casas LE, Hoerl HD. Diagn Cytopathol. 2001:43-9. [pmid: 11466812].
Value of the diffusion-weighted MRI in the differential diagnostics of malignant and benign kidney neoplasms - our clinical experience. Mytsyk Y, Borys Y, Komnatska I, Dutka I, Shatynska-Mytsyk I. Pol J Radiol. 2014:290-5. [pmid: 25202435].
Fine-needle aspiration of cystic lesions of the kidney.Morphologic spectrum and diagnostic problems in 41 cases. Todd TD, Dhurandhar B, Mody D, Ramzy I, Truong LD. Am J Clin Pathol. 99:317-28.
Fast sequences with fat suppression in breath-hold mode: new standard in contrast-enhanced T1-weighted MR imaging of renal tumors?. Walter C, Heindel W, Kruessell M, Kugel H, Jung G, Gindele A. Eur Radiol. 2001:2092-8. [pmid: 11702145].
Role of active surveillance in the management of small renal masses in elderly and co-morbid patients: A retrospective study with long-term follow-up. Brunocilla E, Borghesi M, Schiavina R, Della Mora L, Cevenini M, Pultrone C, Del Prete C, Gentile G, Monti C, Martorana G. Eur Urol Suppl. 2014:e89.
To biopsy or not to biopsy: Results of 1000 renal mass biopsies at a single institution. Deshmukh SM, Dhyani M, McGovern FJ, McDougal WS, Olumi AF, Dahl DM, Arellano R, Samir A, Blute ML, Feldman AS. J Urol. 2013:e437.
Active surveillance of small renal masses: First Italian prospective study. Volpe A, Munegato S, Zegna L, Di Domenico A, De Angelis P, Mondino P, Terrone C. Eur Urol Suppl. 2013:e174.
Renal biopsy: Simple, safe and reliable. Fazakas Zs, Nagy V, Fekete Z, Boszormenyi-Nagy G. Eur Urol Suppl. 2012:114-115.
Percutaneous image-guided needle biopsy of renal masses with core biopsy technique: From exception to rule. Veltri A, Sardo D, Basso E, Binello F, Gazzera C, Garetto I. Cardiovasc Intervent Radiol. 2012:S204.
Role of percutaneous biopsy in the diagnosis of the small renal masses: Our experience. Cova G, Beniamin F, Dugo M, Maccatrozzo L. Anticancer Res. 2012:1868-1869.
Minimally invasive open tumor enucleation vs percutaneous radiofrequency ablation vs. active surveillance of small renal masses &lt; 3 cm in elderly patients: Long-term results of a prospective follow-up study. Brausi M, De Luca G, Gavioli M, Verrini G, Peracchia G, Romano A, Viola M, Giliberto GL. Anticancer Res. 2011:1819.
Quantification of competing risks of death in patients with localized renal cell carcinoma (RCC): A comprehensive nomogram incorporating co-morbidities. Kutikov A, Egleston BL, Smaldone MC, Canter D, Wong Y-N, Uzzo RG. J Urol. 2011:e666.
Evaluation of renal tumors by Image Guided biopsies with an empahasis on oncocytic neoplasms: A retrospective four year study from a large academic institution. Bhalla R, Wu A, Kunju L. J Urol. 2011:e282.
Evaluation of renal tumors by image guided biopsies with an emphasis on oncocytic neoplasms: A retrospective four year study from a large academic institution. Bhalla R, Wu A, Kunju LP. Lab Invest. 2011:180A.
Mini-invasive open tumour enucleation vs percutaneous radiofrequency ablation (PRA) of small renal masses &lt; 3 cm in elderly patients: Long-term results of a prospective follow-up study. Brausi M, De Luca G, Gavioli M, Verrini G, Simonini G, Romano A, Peracchia G, Viola M, Giliberto GL. Anticancer Res. 2010:1401.
Correlation between Fuhrman grading in percutaneous needle biopsy and surgical resection specimens in clear cell renal carcinoma (less-than or equal to) 4 cm in size. Fahim L, Finelli A, Ryan P, Jewett M, Kachura J, Evans AJ. Lab Invest. 2010:190A. [pmid: 20921951].
Radiofrequency ablation of small renal masses: Prognostic implications of a history of RCC and solitary kidney. Tailly T, Oyen R, Van Poppel H, Joniau S. J Endourol. 2009:A10.
Results of RFA in patients with small renal masses, a single-centre experience with median follow-up of 48 months. Joniau S, Tailly T, Goeman L, Oyen R, Van Poppel H. J Endourol. 2009:A9.
Helical CT evaluation of renal mass lesions: A prospective study. Bajwa RPS, Sandhu P, Aulakh BS, Sandhu JS, Saggar K, Ahluwalia A. J Indian Acad Clin Med. 2007:262-264.
Differential diagnosis of renal oncocytoma and carcinoma by spiral CT. Zhang J, Ma D-Q, He W, Zhang Z-J, Hu Y-M, Xu Y. Chin J Med Imaging Technol. 2007:718-720.
Characterization and staging of renal tumors: Significance of MRI diagnostics. Charakterisierung und staging von nierentumoren: Bedeutung der MRT-diagnostik. Kalinka A, Gerlach A, Arlart IP, Gunes N, Hauser T-K, Wurstlin S, Bosse A. RoFo Fortschr Geb Rontgenstr Bildgebenden Verfahren. 2006:298-305.
Subtyping of renal cortical neoplasms in fine needle aspiration biopsies using a decision tree based on genomic alterations detected by fluorescence in situ hybridization. Gowrishankar B, Cahill L, Arndt AE, Al-Ahmadie H, Lin O, Chadalavada K, Chaganti S, Nanjangud GJ, Murty VV, Chaganti RS, Reuter VE, Houldsworth J. BJU Int. 2014:881-90. [pmid: 24467611].
Accuracy of Contrast-enhanced US for Differentiating Benign from Malignant Solid Small Renal Masses. Atri M, Tabatabaeifar L, Jang HJ, Finelli A, Moshonov H, Jewett M. Radiology. 2015. 140907.
Unenhanced CT for the diagnosis of minimal-fat renal angiomyolipoma. Schieda N, Hodgdon T, El-Khodary M, Flood TA, McInnes MD. AJR Am J Roentgenol. 2014:1236-41. [pmid: 25415700].
Contrast-enhanced ultrasonography for evaluation of cystic renal mass: in comparison to contrast-enhanced CT and conventional ultrasound. Xue LY, Lu Q, Huang BJ, Ma JJ, Yan LX, Wen JX, Wang WP. Abdom Imaging. 2014:1274-83. [pmid: 24929667].
Lessons learned from the comparative study between renal mass biopsy and the analysis of the surgical specimen. Dominguez-Esteban M, Villacampa-Auba F, Garcia-Munoz H, Tejido Sanchez A, Romero Otero J, de la Rosa Kehrmann F. Actas Urol Esp. 2014:655-61. [pmid: 24704129].
Surgical and conservative management of small renal tumors. Starolis E, Silinis D, Bakavicius A, Karvelis Z. Eur Urol Suppl. 2014:e1205.
Role of active surveillance in the management of small renal masses in elderly and co-morbid patients: A retrospective study with long-term follow-up. Brunocilla E, Borghesi M, Schiavina R, Della Mora L, Cevenini M, Pultrone C, Del Prete C, Gentile G, Monti C, Martorana G. Eur Urol Suppl. 2014:e89.
Effectiveness of contrast enhanced ultrasonography in the assesment of renal masses. Alvarez Rodriguez S, Sanz Mayayo E, Lopez- Fando Lavalle L, Rodriguez-Patron Rodriguez R, Arias Funez F, Hevia Palacios V, Burgos Revilla FJ. Eur Urol Suppl. 2014:e393-e393a.
Visceral obesity in predicting oncologic outcomes of localized renal cell carcinoma. Park YH, Lee JK, Kim KM, Kook HR, Lee H, Kim KB, Lee S, Byun S-S, Lee SE. J Urol. 2014:1043-1049. [pmid: 24704011].
Routinely performed multiparametric magnetic resonance imaging helps to differentiate common subtypes of renal tumours. Cornelis F, Tricaud E, Lasserre AS, Petitpierre F, Bernhard JC, Le Bras Y, Yacoub M, Bouzgarrou M, Ravaud A, Grenier N. Eur Radiol. 2014:1068-1080. [pmid: 24557052].
Evaluation of indeterminate renal masses with contrast-enhanced US: A diagnostic performance study. Barr RG, Peterson C, Hindi A. Radiology. 2014:133-142. [pmid: 24475802].
Comparison of T2-weighted MRI with and without fat suppression for differentiating renal angiomyolipomas without visible fat from other renal tumors. Chung MS, Choi HJ, Kim M-H, Cho K-S. Am J Roentgenol. 2014:765-771. [pmid: 24660704].
CT texture analysis of renal masses: Pilot study using random forest classification for prediction of pathology. Raman SP, Chen Y, Schroeder JL, Huang P, Fishman EK. Acad Radiol. 2014:1587-1596. [pmid: 25239842].
Diagnostic efficacy of contrast-enhanced ultrasound for small renal masses. Oh TH, Lee YH, Seo IY. Korean J Urol. 2014:587-592. [pmid: 25237460].
Renal Function is Associated with Nephrometry Score After Partial Nephrectomy: A Study Using Diethylene Triamine Penta-Acetic Acid (DTPA) Renal Scanning. Kwon T, Jeong IG, Ryu J, Lee C, Lee C, You D, Kim C-S. Ann Surg Oncol. 2015.
The application of PADUA scoring system for predicting complications of laparoscopic renal cryoablation. Zhuang J, Lian H, Zhao X, Zhang G, Gan W, Li X, Guo H. Int Urol Nephrol. 2015.
Partial nephrectomy for the treatment of renal cell carcinoma (RCC) and the risk of end-stage renal disease (ESRD). Yap SA, Finelli A, Urbach DR, Tomlinson GA, Alibhai SM. BJU Int. 2015.
Nomograms incorporating serum C-reactive protein effectively predict mortality before and after surgical treatment of renal cell carcinoma. Hsiao W, Herrel LA, Yu C, Kattan MW, Canter DJ, Carthon BC, Ogan K, Master VA. Int J Urol. 2015:264-270. [pmid: 25428139].
Clinicopathologic outcomes of cystic renal cell carcinoma. Donin NM, Mohan S, Pham H, Chandarana H, Doshi A, Deng F-M, Stifelman MD, Taneja SS, Huang WC. Clin Genitourin Cancer. 2015:67-70. [pmid: 25088469].
Visceral obesity is associated with better recurrence-free survival after curative surgery for Japanese patients with localized clear cell renal cell carcinoma. Kaneko G, Miyajima A, Yuge K, Yazawa S, Mizuno R, Kikuchi E, Jinzaki M, Oya M. Jpn J Clin Oncol. 2015:210-216. [pmid: 25420691].
Clinical outcomes of patients with nondiagnostic biopsy during cryoablation of small renal masses. Babaian KN, Okhunov Z, Juncal S, Ordon M, Lusch A, Zand T, Andreoni C, Landman J. Urology. 2015:605-609. [pmid: 25733273].
Diagnostic accuracy of preoperative computed tomography used alone to detect lymph-node involvement at radical nephrectomy. Connolly SS, Raja A, Stunell H, Parashar D, Upponi S, Warren AY, Gnanapragasam VJ, Eisen T. Scand J Urol. 2015:142-148. [pmid: 25623950].
Different clinicopathological features between patients who developed early and late recurrence following surgery for renal cell carcinoma. Fujii Y, Ikeda M, Kurosawa K, Tabata M, Kamigaito T, Hosoda C, Okaneya T. Int J Clin Oncol. 2014.
Partial and Radical Nephrectomy for Unilateral Synchronous Multifocal Renal Cortical Tumors. Mano R, Kent M, Larish Y, Winer AG, Chevinsky MS, Hakimi AA, Sternberg IA, Sjoberg DD, Russo P. Urology. 2015.
Racial Disparities in Postoperative Complications After Radical Nephrectomy: A Population-based Analysis. Chung BI, Leow JJ, Gelpi-Hammerschmidt F, Wang Y, Del Giudice F, De S, Chou EP, Song KH, Almario L, Chang SL. Urology. 2015.
Role of percutaneous needle core biopsy in diagnosis and clinical management of renal masses. Hu R, Montemayor-Garcia C, Das K. Hum Pathol. 2015.
Survival advantage of partial over radical nephrectomy in patients presenting with localized renal cell carcinoma. Roos FC, Steffens S, Junker K, Janssen M, Becker F, Wegener G, Brenner W, Steinestel J, Schnoeller TJ, Schrader M, Hofmann R, Thuroff JW, Kuczyk MA, Wunderlich H, Siemer S, Hartmann A, Stockle M, Schrader AJ. BMC Cancer. 2014.
Diagnosis of complex renal cystic masses and solid renal lesions using PET imaging: Comparison of 11C-acetate and 18F-FDG PET imaging. Oyama N, Ito H, Takahara N, Miwa Y, Akino H, Kudo T, Okazawa H, Fujibayashi Y, Komatsu K, Tsukahara K, Yokoyama O. Clin Nucl Med. 2014:e208-e214. [pmid: 24217534].
Evaluation of long-term outcome for patients with renal cell carcinoma after surgery: Analysis of cancer deaths occurring more than 10 years after initial treatment. Kyoda Y, Kobayashi K, Hirobe M, Shindo T, Fukuta F, Hashimoto K, Tanaka T, Tonooka A, Kitamura H, Takahashi S, Masumori N, Hasegawa T, Tsukamoto T. Int J Clin Oncol. 2014:146-151. [pmid: 23404486].
Renal cell carcinoma in patients with end-stage renal disease has favorable overall prognosis. Shrewsberry AB, Osunkoya AO, Jiang K, Westby R, Canter D, Pattaras J, Turgeon N, Master VA, Ogan K. Clin Transplant. 2014:211-216. [pmid: 24494735].
Diabetes mellitus is independently associated with an increased risk of mortality in patients with clear cell renal cell carcinoma. Psutka SP, Stewart SB, Boorjian SA, Lohse CM, Tollefson MK, Cheville JC, Leibovich BC, Thompson RH. J Urol. 2014:1620-1627. [pmid: 24931804].
Pathological characteristics and radiographic correlates of complex renal cysts. Reese AC, Johnson PT, Gorin MA, Pierorazio PM, Allaf ME, Fishman EK, Netto GJ, Pavlovich CP. Urol Oncol Semin Orig Invest. 2014:1010-1016.
Predictive factors for postoperative complications in radical nephrectomy for renal cell carcinoma. Wongvittavas N, Panumatrassamee K, Opanuraks J, Usawachintachit M, Ratchanon S, Tantiwongse K, Bunyaratavej C, Santingamkun A, Prasopsanti K. Asian Biomed. 2014:763-769.
Outcome of nephrectomies in Malta since 2000. Busuttil G, Bugeja S, Zammit P, Mattocks S, German K. Malta Med J. 2014:9-14.
Results of a prospective study comparing the clinical efficacy of cryoablation of renal cell cancer followed by immediate partial nephrectomy. Khoder WY, Siegert S, Stief CG, Becker AJ, Waidelich R. Eur J Surg Oncol. 2014:96-102. [pmid: 24139636].
Pathologic validation of renal cell carcinoma histology in the Surveillance, Epidemiology, and End Results program. Shuch B, Hofmann JN, Merino MJ, Nix JW, Vourganti S, Linehan WM, Schwartz K, Ruterbusch JJ, Colt JS, Purdue MP, Chow W-H. Urol Oncol Semin Orig Invest. 2014:23.e9-23.e13.
Pre-existing type 2 diabetes mellitus is an independent risk factor for mortality and progression in patients with renal cell carcinoma. Vavallo A, Simone S, Lucarelli G, Rutigliano M, Galleggiante V, Grandaliano G, Gesualdo L, Campagna M, Cariello M, Ranieri E, Pertosa G, Lastilla G, Selvaggi FP, Ditonno P, Battaglia M. Medicine. 2014.
A population-based competing-risks analysis of survival after nephrectomy for renal cell carcinoma. Bianchi M, Gandaglia G, Trinh Q-D, Hansen J, Becker A, Abdollah F, Tian Z, Lughezzani G, Roghmann F, Briganti A, Montorsi F, Karakiewicz PI, Sun M. Urol Oncol Semin Orig Invest. 2014:46.e1-46.e7.
Delay in nephrectomy and cancer control outcomes in elderly patients with small renal masses. Becker A, Roghmann F, Ravi P, Tian Z, Kluth LA, Gandaglia G, Noldus J, Dahlem R, Schlomm T, Graefen M, Karakiewicz PI, Trinh Q-D, Sun M. Urol Int. 2014:455-461. [pmid: 24602994].
The effect of gender and age on kidney cancer survival: Younger age is an independent prognostic factor in women with renal cell carcinoma. Rampersaud EN, Klatte T, Bass G, Patard J-J, Bensaleh K, Bohm M, Allhoff EP, Cindolo L, De La Taille A, Mejean A, Soulie M, Bellec L, Christophe Bernhard J, Pfister C, Colombel M, Belldegrun AS, Pantuck AJ, George D. Urol Oncol Semin Orig Invest. 2014:30.e9-30.e13.
The key role of time in predicting progression-free survival in patients with renal cell carcinoma treated with partial or radical nephrectomy: Conditional survival analysis. Abdollah F, Suardi N, Capitanio U, Matloob R, Fossati N, Castiglione F, Di Trapani E, Di Trapani D, Russo A, Carenzi C, Montorsi F, Rigatti P, Bertini R. Urol Oncol Semin Orig Invest. 2014:43.e9-43.e16.
Evaluation of anatomic and morphologic nomogram to predict malignant and high-grade disease in a cohort of patients with small renal masses. Bagrodia A, Harrow B, Liu Z-W, Olweny EO, Faddegon S, Yin G, Tan YK, Han WK, Lotan Y, Margulis V, Cadeddu JA. Urol Oncol Semin Orig Invest. 2014:37.e17-37.e23.
Race and sex disparities in the treatment of older patients with T1a renal cell carcinoma: A comorbidity-controlled competing-risks model. Patel HD, Kates M, Pierorazio PM, Allaf ME. Urol Oncol Semin Orig Invest. 2014:576-583.
The impact of perioperative blood transfusion on survival after nephrectomy for non-metastatic renal cell carcinoma (RCC). Linder BJ, Thompson RH, Leibovich BC, Cheville JC, Lohse CM, Gastineau DA, Boorjian SA. BJU Int. 2014:368-374. [pmid: 24471825].
Bosniak category III cysts are more likely to be malignant than we expected in the era of multidetector computed tomography technology. Bata P, Tarnoki AD, Tarnoki DL, Szasz AM, Poloskei G, Fejer B, Gyebnar J, Nyirady P, Berczi V, Karlinger K, Szendroi A. J Res Med Sci. 2014:634-638. [pmid: 25364363].
Factors Associated with Diagnostic Accuracy When Performing a Preablation Renal Biopsy. Lorber G, Jorda M, Leveillee R. J Endourol. 2014.
CT perfusion in the characterisation of renal lesions: an added value to multiphasic CT. Mazzei FG, Mazzei MA, Cioffi Squitieri N, Pozzessere C, Righi L, Cirigliano A, Guerrini S, D'Elia D, Ambrosio MR, Barone A, del Vecchio MT, Volterrani L. Biomed Res Int. 2014:135013. [pmid: 25184133].
Predictors of 30-day acute kidney injury following radical and partial nephrectomy for renal cell carcinoma. Schmid M, Abd-El-Barr AE, Gandaglia G, Sood A, Olugbade K Jr, Ruhotina N, Sammon JD, Varda B, Chang SL, Kibel AS, Chun FK, Menon M, Fisch M, Trinh QD. Urol Oncol. 2014.
The impact of hospital volume on postoperative complications following robot-assisted partial nephrectomy. Monn MF, Bahler CD, Flack CK, Dube HT, Sundaram CP. J Endourol. 2014:1231-6. [pmid: 25019495].
The association of baseline health and gender with small renal mass pathology. Bazzi WM, Dejbakhsh SZ, Bernstein M, Russo P. Can J Urol. 2014:7271-6. [pmid: 24978356].
Cancer-free survival and local tumor control after impendence-based radiofrequency ablation of biopsy-proven renal cell carcinomas with a minimum of 1-year follow-up. Forauer AR, Dewey BJ, Seigne JD. Urol Oncol. 2014:869-76. [pmid: 24946958].
Does gender influence morbidity or mortality in the surgical treatment of renal masses?. Minnillo BJ, Horowitz A, Finelli A, Alibhai SM, Ponsky LE, Abouassaly R. Can Urol Assoc J. 2014:E311-6. [pmid: 24940456].
Predictive factors for benign lesions in partially or radically resected kidneys in a single independent cancer center. Soga N, Ogura Y, Hayashi N. Curr Urol. 2013:70-4. [pmid: 24917762].
Outcomes in patients undergoing nephrectomy for renal cancer on chronic anticoagulation therapy. Sfakianos JP, Hakimi AA, Kim PH, Zabor EC, Mano R, Bernstein M, Karellas M, Russo P. Eur J Surg Oncol. 2014.
Laparoscopic partial nephrectomy for multilocular cystic renal cell carcinoma: a potential gold standard treatment with excellent perioperative outcomes. Xu B, Mi Y, Zhou LQ, Jin J, Zhang Q, Chen GF. World J Surg Oncol. 2014:111. [pmid: 24754899].
Race and sex disparities in the treatment of older patients with T1a renal cell carcinoma: a comorbidity-controlled competing-risks model. Patel HD, Kates M, Pierorazio PM, Allaf ME. Urol Oncol. 2014:576-83. [pmid: 24629500].
The impact of type 2 diabetes on the outcome of localized renal cell carcinoma. Hofner T, Zeier M, Hatiboglu G, Eisen C, Schonberg G, Hadaschik B, Teber D, Duensing S, Trumpp A, Hohenfellner M, Pahernik S. World J Urol. 2013.
Renal function following curative surgery for renal cell carcinoma: who is at risk for renal insufficiency?. Kong HJ, Park JS, Kim DY, Shin HS, Jung HJ. Korean J Urol. 2013:830-3. [pmid: 24363863].
Estimating the risk of chronic kidney disease after nephrectomy. Ngo TC, Hurley MP, Thong AE, Jeon SH, Leppert JT, Chung BI. Can J Urol. 2013:7035-41. [pmid: 24331345].
Is there a volume-outcome relationship for partial nephrectomy?. Couapel JP, Bensalah K, Bernhard JC, Pignot G, Zini L, Lang H, Rigaud J, Salomon L, Bellec L, Soulie M, Vaessen C, Roupret M, Jung JL, Mourey E, Bigot P, Bruyere F, Berger J, Ansieau JP, Gimel P, Salome F, Hubert J, Pfister C, Baumert H, Timsit MO, Mejean A, Patard JJ. World J Urol. 2014:1323-9. [pmid: 24270969].
Percutaneous renal cryoablation: prospective experience treating 120 consecutive tumors. Buy X, Lang H, Garnon J, Sauleau E, Roy C, Gangi A. AJR Am J Roentgenol. 2013:1353-61. [pmid: 24261377].
Incidence and risk factors of chronic kidney disease in korean patients with t1a renal cell carcinoma before and after radical or partial nephrectomy. Kim SH, Lee SE, Hong SK, Jeong CW, Park YH, Kim YJ, Kang SH, Hong SH, Choi WS, Byun SS. Jpn J Clin Oncol. 2013:1243-8. [pmid: 24198287].
Small tumour size is associated with new-onset chronic kidney disease after radical nephrectomy in patients with renal cell carcinoma. Jeon HG, Choo SH, Sung HH, Jeong BC, Seo SI, Jeon SS, Choi HY, Lee HM. Eur J Cancer. 2014:64-9. [pmid: 24060356].
A population-based competing-risks analysis of survival after nephrectomy for renal cell carcinoma. Bianchi M, Gandaglia G, Trinh QD, Hansen J, Becker A, Abdollah F, Tian Z, Lughezzani G, Roghmann F, Briganti A, Montorsi F, Karakiewicz PI, Sun M. Urol Oncol. 2014:46.e1-7. [pmid: 24054864].
The 1-year decline in estimated glomerular filtration rate (eGFR) after radical nephrectomy in patients with renal masses and matched living kidney donors is the same. Hew MN, Opondo D, Cordeiro ER, van Donselaar-van der Pant KA, Bemelman FJ, Idu MM, de la Rosette JJ, Laguna MP. BJU Int. 2014:E49-55. [pmid: 24053637].
Trends in renal function after radical nephrectomy: a multicentre analysis. Chung JS, Son NH, Byun SS, Lee SE, Hong SK, Jeong CW, Lee SC, Chae DW, Choi WS, Park YH, Hong SH, Kim YJ, Kang SH. BJU Int. 2014:408-15. [pmid: 23937424].
Health-related quality of life in long-term survivors after renal cancer treatment. Beisland C, Beisland E, Hjelle KM, Bostad L, Hjermstad MJ, Aarstad AK, Aarstad HJ. Scand J Urol. 2014:52-64. [pmid: 23883326].
Cystic renal cell carcinomas: do they grow, metastasize, or recur?. Jhaveri K, Gupta P, Elmi A, Flor L, Moshonov H, Evans A, Jewett M. AJR Am J Roentgenol. 2013:W292-6. [pmid: 23883243].
How can the R.E.N.A.L nephrometry scoring system aid management of a solid renal mass?. Wong MH, Cho KY, Ho KL, Wong KW, Lai CT, Man CM, Yiu MK. Hong Kong Med J. 2014:37-44.
Charlson score as a single pertinent criterion to select candidates for active surveillance among patients with small renal masses. Audenet F, Audouin M, Drouin SJ, Comperat E, Mozer P, Chartier-Kastler E, Mejean A, Cussenot O, Shariat SF, Roupret M. World J Urol. 2014:513-8. [pmid: 23873357].
Predictive preoperative factors for renal insufficiency in patients followed for more than 5 years after radical nephrectomy. Ahn JS, Kim HJ, Jeon HG, Jeong BC, Seo SI, Lee HM, Choi HY, Jeon SS. Korean J Urol. 2013:303-10. [pmid: 23700495].
Laparoendoscopic single-site nephrectomy compared with conventional laparoscopic nephrectomy: a 5-year, single-surgeon experience. Antonelli JA, Bagrodia A, Odom C, Olweny EO, Faddegon S, Cadeddu JA. Eur Urol. 2013:412-8. [pmid: 23623478].
Robotic-assisted transperitoneal nephron-sparing surgery for small renal masses with associated surgical procedures: surgical technique and preliminary experience. Ceccarelli G, Codacci-Pisanelli M, Patriti A, Ceribelli C, Biancafarina A, Casciola L. Updates Surg. 2013:183-90. [pmid: 23619828].
Perioperative mortality and associated factors in patients undergoing radical nephrectomy. Diaz-Hung AM, Garcia-Perdomo HA, Carbonell-Gonzalez J, Castillo-Cobaleda DF, Garcia-Angel AF. Actas Urol Esp. 2013:608-12. [pmid: 23602503].
Factors that affect proportional glomerular filtration rate after minimally invasive partial nephrectomy. Hakimi AA, Ghavamian R, Williams SK, Kim PH, Chen L, Sfakianos JP, Keren-Paz GE, Sankin A, Ginzburg N, Coleman JA. J Endourol. 2013:1371-5. [pmid: 23560653].
Diagnostic radiation exposure during surveillance in patients with pT1a renal cell carcinoma. Lipsky MJ, Shapiro EY, Hruby GW, McKiernan JM. Urology. 2013:1190-5. [pmid: 23540857].
Laparoendoscopic single-site partial nephrectomy: a multi-institutional outcome analysis. Greco F, Autorino R, Rha KH, Derweesh I, Cindolo L, Richstone L, Herrmann TR, Liatsikos E, Sun Y, Fanizza C, Nagele U, Stolzenburg JU, Rais-Bahrami S, Liss MA, Schips L, Kassab A, Wang L, Kallidonis P, Wu Z, Young ST, Mohammed N, Haber GP, Springer C, Fornara P, Kaouk JH. Eur Urol. 2013:314-22. [pmid: 23415378].
Iatrogenic splenectomy during nephrectomy for renal tumors. Wang JK, Tollefson MK, Kim SP, Boorjian SA, Leibovich BC, Lohse CM, Cheville JC, Thompson RH. Int J Urol. 2013:896-902. [pmid: 23379901].
A single overnight stay is possible for most patients undergoing robotic partial nephrectomy. Abaza R, Shah K. Urology. 2013:301-6. [pmid: 23374787].
Renal function outcomes for multifocal renal neoplasms managed by radiofrequency ablation. Gupta P, Allen BC, Chen MY, Childs DD, Kota G, Zagoria RJ. Cardiovasc Intervent Radiol. 2013:1329-35. [pmid: 23361116].
Renal cell carcinoma: radiofrequency ablation with a multiple-electrode switching system--a phase II clinical study. Takaki H, Nakatsuka A, Uraki J, Yamanaka T, Fujimori M, Hasegawa T, Arima K, Sugimura Y, Yamakado K. Radiology. 2013:285-92. [pmid: 23315660].
Prevalence and impact on survival of positive surgical margins in partial nephrectomy for renal cell carcinoma: a population-based study. Ani I, Finelli A, Alibhai SM, Timilshina N, Fleshner N, Abouassaly R. BJU Int. 2013:E300-5. [pmid: 23305148].
Comparison of laparoendoscopic single-site and multiport laparoscopic radical and partial nephrectomy: a prospective, nonrandomized study. Bazzi WM, Stroup SP, Kopp RP, Cohen SA, Sakamoto K, Derweesh IH. Urology. 2012:1039-45. [pmid: 22990064].
Haemostasis control during laparoscopic partial nephrectomy without parenchymal renorrhaphy: the VIVOSTAT((R)) experience. Hevia M, Abascal-Junquera JM, Sacristan R, Suarez J, Lobo B, Mendez S, Pellejero P, Abascal-Garcia R. Actas Urol Esp. 2013:47-53. [pmid: 22819491].
Evaluation of patient-reported quality-of-life outcomes after renal surgery. Kim SB, Williams SB, Cheng SC, Sanda MG, Wagner AA. Urology. 2012:1268-73. [pmid: 22542421].
Comparison of total, selective, and nonarterial clamping techniques during laparoscopic and robot-assisted partial nephrectomy. Martin GL, Warner JN, Nateras RN, Andrews PE, Humphreys MR, Castle EP. J Endourol. 2012:152-6. [pmid: 22192110].
Significant impact of age at diagnosis on the prognosis of Japanese patients with pT1 renal cell carcinoma following surgical resection. Sakai I, Miyake H, Muramaki M, Kondo Y, Kusuda Y, Yamada Y, Fujisawa M. BJU Int. 2012:695-9. [pmid: 21854532].
The effect of age on the morbidity of kidney surgery. Abouassaly R, Alibhai SM, Tomlinson GA, Urbach DR, Finelli A. J Urol. 2011:811-6. [pmid: 21788042].
Comparison of rates and risk factors for development of osteoporosis and fractures after radical or partial nephrectomy. Bagrodia A, Mehrazin R, Bazzi WM, Silberstein J, Malcolm JB, Stroup SP, Raheem O, Wake RW, Kane CJ, Patterson AL, Wan JY, Derweesh IH. Urology. 2011:614-9. [pmid: 21777959].
Anatomic features of enhancing renal masses predict malignant and high-grade pathology: a preoperative nomogram using the RENAL Nephrometry score. Kutikov A, Smaldone MC, Egleston BL, Manley BJ, Canter DJ, Simhan J, Boorjian SA, Viterbo R, Chen DY, Greenberg RE, Uzzo RG. Eur Urol. 2011:241-8. [pmid: 21458155].
Population-level comparative effectiveness of laparoscopic versus open radical nephrectomy for patients with kidney cancer. Tan HJ, Wolf JS Jr, Ye Z, Wei JT, Miller DC. Cancer. 2011:4184-93. [pmid: 21365632].
Young age as favorable prognostic factor for cancer-specific survival in localized renal cell carcinoma. Komai Y, Fujii Y, Iimura Y, Tatokoro M, Saito K, Otsuka Y, Koga F, Arisawa C, Kawakami S, Okuno T, Tsujii T, Kageyama Y, Morimoto S, Toma T, Higashi Y, Fukui I, Kihara K. Urology. 2011:842-7. [pmid: 21256565].
Renal cell carcinoma in octogenarians: nephron sparing surgery should remain the standard of care. Hellenthal NJ, Mansour AM, Hayn MH, Schwaab T. J Urol. 2011:415-20. [pmid: 21167523].
Oncologic long-term outcome of elective nephron-sparing surgery versus radical nephrectomy in patients with renal cell carcinoma stage pT1b or greater in a matched-pair cohort. Roos FC, Brenner W, Muller M, Schubert C, Jager WJ, Thuroff JW, Hampel C. Urology. 2011:803-8. [pmid: 21145093].
The role of percutaneous needle biopsy in differentiation of renal tumors. Izumi K, Narimoto K, Sugimoto K, Kobori Y, Maeda Y, Mizokami A, Koh E, Yamada T, Yano S, Namiki M. Jpn J Clin Oncol. 2010:1081-6. [pmid: 20601495].
Identifying the risk of disease progression after surgery for localized renal cell carcinoma. Abel EJ, Culp SH, Meissner M, Matin SF, Tamboli P, Wood CG. BJU Int. 2010:1277-83. [pmid: 20394619].
Predictive factors for ipsilateral recurrence after nephron-sparing surgery in renal cell carcinoma. Bernhard JC, Pantuck AJ, Wallerand H, Crepel M, Ferriere JM, Bellec L, Maurice-Tison S, Robert G, Albouy B, Pasticier G, Soulie M, Lopes D, Lacroix B, Bensalah K, Pfister C, Thuret R, Tostain J, De La Taille A, Salomon L, Abbou C, Colombel M, Belldegrun AS, Patard JJ. Eur Urol. 2010:1080-6. [pmid: 20188458].
Predicting renal functional outcomes after surgery for renal cortical tumours: a multifactorial analysis. Barlow LJ, Korets R, Laudano M, Benson M, McKiernan J. BJU Int. 2010:489-92. [pmid: 20039869].
Renal functional outcomes for tumours in a solitary kidney managed by ablative or extirpative techniques. Raman JD, Raj GV, Lucas SM, Williams SK, Lauer EM, Ahrar K, Matin SF, Leveillee RJ, Cadeddu JA. BJU Int. 2010:496-500. [pmid: 19681900].
Robotic partial nephrectomy with sliding-clip renorrhaphy: technique and outcomes. Benway BM, Wang AJ, Cabello JM, Bhayani SB. Eur Urol. 2009:592-9. [pmid: 19144457].
Pathological tumour diameter predicts risk of conventional subtype in small renal cortical tumours. Laudano MA, Klafter FE, Katz M, McCann TR, Desai M, Benson MC, McKiernan JM. BJU Int. 2008:1385-8. [pmid: 18710458].
Survival rates after resection for localized kidney cancer: 1989 to 2004. Russo P, Jang TL, Pettus JA, Huang WC, Eggener SE, O'Brien MF, Karellas ME, Karanikolas NT, Kagiwada MA. Cancer. 2008:84-96. [pmid: 18470927].
Management of renal tumors by image-guided radiofrequency ablation: experience in 105 tumors. Breen DJ, Rutherford EE, Stedman B, Roy-Choudhury SH, Cast JE, Hayes MC, Smart CJ. Cardiovasc Intervent Radiol. 2007:936-42. [pmid: 17573550].
Retroperitoneoscopic radical nephrectomy in obese patients: outcomes and considerations. Inoue S, Mita K, Shigeta M, Mochizuki H, Tanabe T, Moriyama H, Usui T. Urol Int. 2006:252-5. [pmid: 16601389].
Image-guided biopsy in the evaluation of renal mass lesions in contemporary urological practice: indications, adequacy, clinical impact, and limitations of the pathological diagnosis. Shah RB, Bakshi N, Hafez KS, Wood DP Jr, Kunju LP. Hum Pathol. 2005:1309-15. [pmid: 16311125].
Application of TNM, 2002 version, in localized renal cell carcinoma: is it able to predict different cancer-specific survival probability?. Ficarra V, Novara G, Galfano A, Novella G, Schiavone D, Artibani W. Urology. 2004:1050-4. [pmid: 15183948].
Laparoscopic radical nephrectomy in obese patients: outcomes and technical considerations. Fugita OE, Chan DY, Roberts WW, Kavoussi LR, Jarrett TW. Urology. 2004:247-52. discussion 252. [pmid: 14972463].
Clinicopathological factors predicting recurrence of N0M0 renal cell carcinoma: a case series analysis of one facility. Masuda A, Aoki M, Tokunaga M, Usui Y, Abe T, Miyakita H, Kinoshita H, Kawamura N, Terachi T. Int J Urol. 2003:511-7. [pmid: 14516397].
Percutaneous computed tomography-guided radiofrequency ablation of renal masses in high surgical risk patients: preliminary results. Su Li, Jarrett TW, Chan DY, Kavoussi LR, Solomon SB. Urology. 2003:26-33. [pmid: 12657358].
Renal cell carcinoma in patients with prior spinal cord injury. Brandes SB, Smith JB, Longo WE, Virgo KS, Johnson FE. J Spinal Cord Med. 2001:251-6. [pmid: 11944783].
Comparison of complications after radical and partial nephrectomy: results from the National Veterans Administration Surgical Quality Improvement Program. Corman JM, Penson DF, Hur K, Khuri SF, Daley J, Henderson W, Krieger JN. BJU Int. 2000:782-9. [pmid: 11069401].
Partial nephrectomy for renal tumours: the Singapore General Hospital experience. Yip SK, Cheng WS, Tan BS, Li MK, Foo KT. J R Coll Surg Edinb. 99:156-60.
Imaging guided biopsy of renal masses: indications, accuracy and impact on clinical management. Wood BJ, Khan MA, McGovern F, Harisinghani M, Hahn PF, Mueller PR. J Urol. 99:1470-4.
Partial nephrectomy for selected renal cortical tumours of (greater-than or equal to)7 cm. Karellas ME, Obrien MF, Jang TL, Bernstein M, Russo P. BJU Int. 2010:1484-1487. [pmid: 20518765].
Bilateral renal cell carcinoma. Therapy management and histopathological results in long-term follow-up of 66 patients. Der bilaterale nierentumor. Therapiemanagement und histopathologische ergebnisse mit langzeitverlauf bei 66 patienten. Siemer S, Uder M, Zell A, Ponicke C, Humke U, Ziegler M, Stockle M. Urologe Ausg A. 2001:114-120.
Laparoscopic procedures in urology. Laparoskopische operationen in der urologie. Turk I, Deger S, Schonberger B, Loening SA. J Urol Urogynakol. 99:69-72.
Characterization of small solid renal lesions: can benign and malignant tumors be differentiated with CT?. Millet I, Doyon FC, Hoa D, Thuret R, Merigeaud S, Serre I, Taourel P. AJR Am J Roentgenol. 2011:887-96. [pmid: 21940576].
RENAL nephrometry score is a predictive factor for the annual growth rate of renal mass. Matsumoto R, Abe T, Shinohara N, Murai S, Maruyama S, Tsuchiya K, Nonomura K. Int J Urol. 2014:549-52. [pmid: 24405437].
The accuracy of renal tumor biopsy: analysis from a national prospective study. Bernhard JC, Bigot P, Pignot G, Baumert H, Zini L, Lang H, Crepel M, Monod P, Salomon L, Bellec L, Roupret M, Schneider M, Xylinas E, Paparel P, Bruyere F, Berger J, Ansieau JP, Gimel P, Salome F, Castagnola C, Pfister C, Legraverend JM, Timsit MO, Le Pellec L, Auberget JL, Rolland E, Mallet R, Mejean A, Patard JJ. World J Urol. 2014.
Role of MRI in indeterminate renal mass: diagnostic accuracy and impact on clinical decision making. Kwon T, Jeong IG, Yoo S, Lee J, Hong S, You D, Hong JH, Ahn H, Kim CS. Int Urol Nephrol. 2015:585-93. [pmid: 25681121].
Can radiologists and urologists reliably determine renal mass histology using standard preoperative computed tomography imaging?. Monn MF, Gellhaus PT, Patel AA, Masterson TA, Tann M, Boris RS. J Endourol. 2015:391-6. [pmid: 25222030].
Value of the diffusion-weighted MRI in the differential diagnostics of malignant and benign kidney neoplasms - Our clinical experience. Mytsyk Y, Borys Y, Komnatska I, Dutka I, Shatynska-Mytsyk I. Pol J Radiol. 2014:290-295. [pmid: 25202435].
Renal cryoablation of small renal masses: A Korea university experience. Kim HK, Pyun JH, Kim JY, Kim SB, Cho S, Kang SG, Lee JG, Kim JJ, Cheon J, Kang SH. Korean J Urol. 2015:117-124. [pmid: 25685298].
Differentiation of renal oncocytoma and renal clear cell carcinoma using relative CT enhancement ratio. Ren A, Cai F, Shang Y-N, Ma E-S, Huang Z-G, Wang W, Lu Y, Zhang X-Z. Chin Med J. 2015:175-179. [pmid: 25591558].
Trends in renal function after radical nephrectomy: A multicentre analysis. Chung JS, Son NH, Byun S-S, Lee SE, Hong SK, Jeong CW, Lee SC, Chae D-W, Choi WS, Park YH, Hong SH, Kim YJ, Kang SH. BJU Int. 2014:408-415. [pmid: 23937424].
Health-related quality of life in long-term survivors after renal cancer treatment. Beisland C, Beisland E, Hjelle KM, Bostad L, Hjermstad MJ, Aarstad AKH, Aarstad HJ. Scand J Urol. 2014:52-64. [pmid: 23883326].
Local recurrence after radical nephrectomy for kidney cancer: Management and prediction of outcomes. A multi-institutional study. Paparel P, Bigot P, Matillon X, Bensalah K, Salomon L, Baumert H, Bastide C, Thuret R, Karsenty G, Long JA, Ammi M, Bessede T, Bin S, Roux A, Escudier B, Rioux Leclercq N, Pignot G, Soulie M, Patard J-J. J Surg Oncol. 2014:126-131. [pmid: 24174430].
Serum level and immunohistochemical expression of vascular endothelial growth factor for the prediction of postoperative recurrence in renal cell carcinoma. Fujita N, Okegawa T, Terado Y, Tambo M, Higashihara E, Nutahara K. BMC Res Notes. 2014:369. [pmid: 24938498].
Clinical features and treatment of collecting duct carcinoma of the kidney from the korean cancer study group genitourinary and gynecology cancer committee. Kwon KA, Oh SY, Kim HY, Kim HS, Lee HY, Kim TM, Lim HY, Lee NR, Lee HJ, Hong SH, Rha SY. Cancer Res Treat. 2014:141-7. [pmid: 24851105].
Prospective randomized controlled trial of conventional laparoscopic versus laparoendoscopic single-site radical nephrectomy for localized renal cell carcinoma: a preliminary report regarding quality of life. Park YH, Kim KT, Ko K, Kim HH. World J Urol. 2014.
Do we need to clamp the renal hilum liberally during the initial phase of the learning curve of robot-assisted nephron-sparing surgery?. Acar O, Esen T, Musaoglu A, Vural M. ScientificWorldJournal. 2014:498917. [pmid: 24688393].
Laparoscopic partial nephrectomy for endophytic hilar tumors: feasibility and outcomes. Di Pierro GB, Tartaglia N, Aresu L, Polara A, Cielo A, Cristini C, Grande P, Gentile V, Grosso G. Eur J Surg Oncol. 2014:769-74. [pmid: 24370283].
Nephron-Sparing Surgery for Renal Masses Measuring Larger Than 7 cm on Preoperative Imaging: A Single Surgeon Single Center Experience. Esen T, Acar O, Musaoglu A, Vural M, Akpek S. ISRN Surg. 2013:691080. [pmid: 23691366].
Robotic retroperitoneal partial nephrectomy: a four-arm approach. Feliciano J, Stifelman M. JSLS. 2012:208-11. [pmid: 23477167].
Bipolar versus multipolar radiofrequency (RF) ablation for the treatment of renal cell carcinoma: differences in technical and clinical parameters. Sommer CM, Lemm G, Hohenstein E, Stampfl U, Bellemann N, Teber D, Rassweiler J, Kauczor HU, Radeleff BA, Pereira PL. Int J Hyperthermia. 2013:21-9. [pmid: 23311376].
Comparison of the loss of renal function after cold ischemia open partial nephrectomy, warm ischemia laparoscopic partial nephrectomy and laparoscopic partial nephrectomy using microwave coagulation. Kawahara T, Sakata R, Kawahara K, Ito H, Miyoshi Y, Sano F, Nakaigawa N, Uemura H, Yao M, Kubota Y, Makiyama K. Curr Urol. 2013:118-23. [pmid: 24917728].
Radiofrequency ablation of small renal masses as an alternative to nephron-sparing surgery: preliminary results. Jasinski M, Siekiera J, Chlosta P, Mikolajczak W, Drewa T. Wideochir Inne Tech Malo Inwazyjne. 2011:242-5. [pmid: 23255987].
Application of gasless laparoendoscopic single port surgery, GasLESS, to partial nephrectomy for renal cell carcinoma: GasLESS-clampless partial nephrectomy as a multiply satisfactory method. Kihara K. Int J Urol. 2012:3-4. [pmid: 22168271].
Outcome of laser-assisted laparoscopic partial nephrectomy without ischaemia for peripheral renal tumours. Khoder WY, Sroka R, Siegert S, Stief CG, Becker AJ. World J Urol. 2012:633-8. [pmid: 22160275].
Transition from laparoscopic to robotic partial nephrectomy: the learning curve for an experienced laparoscopic surgeon. Lavery HJ, Small AC, Samadi DB, Palese MA. JSLS. 2011:291-7. [pmid: 21985712].
Delayed proximal ureteric stricture formation after complex partial nephrectomy. Reyes JM, Canter DJ, Sirohi M, Simhan J, Smaldone MC, Teper E, Kutikov A, Chen DY, Uzzo RG. BJU Int. 2012:539-43. [pmid: 21733077].
Robot-assisted retroperitoneal partial nephrectomy: technique and perioperative results. Weizer AZ, Palella GV, Montgomery JS, Miller DC, Hafez KS. J Endourol. 2011:553-7. [pmid: 21381954].
Cryoablation for endophytic renal cell carcinoma: intermediate-term oncologic efficacy and safety. Park SH, Kang SH, Ko YH, Kang SG, Park HS, Moon du G, Lee JG, Kim JJ, Cheon J. Korean J Urol. 2010:518-24. [pmid: 20733956].
Radical nephrectomy and nephroureterectomy in patients over 80 years old. Labanaris AP, Zugor V, Labanaris AP, Elias P, Kuhn R. Int Braz J Urol. 2010:141-8. discussion 149-50. [pmid: 20450498].
Radiofrequency ablation of kidney tumours in patients with a solitary kidney. Prevoo W, van den Munckhof MP, Meinhardt W, Horenblas S, van den Bosch MA. Clin Radiol. 2010:230-6. [pmid: 20152280].
Robot-assisted partial nephrectomy: evaluation of learning curve for an experienced renal surgeon. Haseebuddin M, Benway BM, Cabello JM, Bhayani SB. J Endourol. 2010:57-61. [pmid: 19958156].
Bowel displacement for CT-guided tumor radiofrequency ablation: techniques and anatomic considerations. Ginat DT, Saad W, Davies M, Walman D, Erturk E. J Endourol. 2009:1259-64. [pmid: 19594374].
Renal insufficiency is not a contraindication for cryoablation of small renal masses. Bourne AE, Kramer BA, Steiner HL, Schwartz BF. J Endourol. 2009:1195-8. [pmid: 19530949].
Four-arm robotic partial nephrectomy for complex renal cell carcinoma. Gong Y, Du C, Josephson DY, Wilson TG, Nelson R. World J Urol. 2010:111-5. [pmid: 19499225].
Single center experience with percutaneous and laparoscopic cryoablation of small renal masses. Malcolm JB, Berry TT, Williams MB, Logan JE, Given RW, Lance RS, Barone B, Shaves S, Vingan H, Fabrizio MD. J Endourol. 2009:907-11. [pmid: 19456244].
Laparoscopic partial nephrectomy without hilar control. Jeon SS, Kim IY. J Endourol. 2008:1937-9. discussion 1941-2. [pmid: 18811497].
A prospective comparison of laparoscopic and robotic radical nephrectomy for T1-2N0M0 renal cell carcinoma. Hemal AK, Kumar A. World J Urol. 2009:89-94. [pmid: 18704439].
Feasibility of laparoscopic partial nephrectomy after previous ipsilateral renal procedures. Turna B, Aron M, Frota R, Desai MM, Kaouk J, Gill IS. Urology. 2008:584-8. [pmid: 18579185].
Simultaneous &quot;cut and suture&quot;: a novel technique for laparoscopic partial nephrectomy without vascular clamping. Schatloff O, Ramon J, Nadu A. Urology. 2008:1203-4. discussion 1204-5. [pmid: 18384851].
Comparative study of laparoscopic partial nephrectomy and traditional open procedure: analysis of 26 cases. Ou TW, Zhang Y, Cui X, Zhang B. Zhonghua Yi Xue Za Zhi. 2007:2549-51. [pmid: 18067831].
Effect of radiofrequency ablation of renal tumors on renal function in patients with a solitary kidney. Syvanthong C, Wile GE, Zagoria RJ. AJR Am J Roentgenol. 2007:1619-21. [pmid: 17515385].
The efficacy and safety of laparoscopic nephrectomy in patients with three or more comorbidities. Naya Y, Tobe T, Suyama T, Araki K, Komiya A, Suzuki H, Igarashi T, Ichikawa T. Int J Urol. 2007:17-20. [pmid: 17199854].
Laparoscopic partial nephrectomy for incidental stage pT2 or worse tumors. Ukimura O, Haber GP, Remer EM, Gill IS. Urology. 2006:976-82. [pmid: 17095068].
Positive surgical parenchymal margin after laparoscopic partial nephrectomy for renal cell carcinoma: oncological outcomes. Permpongkosol S, Colombo JR Jr, Gill IS, Kavoussi LR. J Urol. 2006:2401-4. [pmid: 17085113].
Results of computerized tomography guided percutaneous ablation of renal masses with nondiagnostic pre-ablation pathological findings. Permpongkosol S, Link RE, Solomon SB, Kavoussi LR. J Urol. 2006:463-7. discussion 467. [pmid: 16813865].
Radical nephrectomy performed by open, laparoscopy with or without hand-assistance or robotic methods by the same surgeon produces comparable perioperative results. Nazemi T, Galich A, Sterrett S, Klingler D, Smith L, Balaji KC. Int Braz J Urol. 2006:15-22. [pmid: 16519823].
A prospective study of laparoscopic radical nephrectomy for T1 tumors--is transperitoneal, retroperitoneal or hand assisted the best approach?. Nadler RB, Loeb S, Clemens JQ, Batler RA, Gonzalez CM, Vardi IY. J Urol. 2006:1230-3. discussion 1234. [pmid: 16515966].
An original modification of wedge resection of the kidney in renal cell carcinoma. Alferov SM, Grishin MA. Urologiia. 2005:23-6. [pmid: 16419476].
The use of acellular porcine collagen matrix to facilitate renal parenchymal closure during partial nephrectomy. Douglas DA, Cross WR, Prescott S. BJU Int. 2005:1142-3. [pmid: 16225545].
Hand-assisted laparoscopic radical nephrectomy: comparison of the transperitoneal and retroperitoneal approaches. Shiraishi K, Eguchi S, Mohri J, Kamiryo Y. Surg Laparosc Endosc Percutan Tech. 2005:216-9. [pmid: 16082309].
Direct access to the renal artery at the level of treitz ligament during left radical laparoscopic transperitoneal nephrectomy. Porpiglia F, Terrone C, Cracco C, Renard J, Musso F, Grande S, Scarpa RM. Eur Urol. 2005:291-5. [pmid: 15939529].
Retroperitoneal laparoscopic nephron-sparing surgery for renal tumors: report of 32 cases. Zhang X, Li HZ, Ma X, Zheng T, Li LC, Ye ZQ. Urology. 2005:1080-4. discussion 1084-5. [pmid: 15913730].
Laparoscopic nephrectomy: an early experience at Queen Mary Hospital. Cheung MC, Lee FC, Chu SM, Leung YL, Wong BB, Ho KL, Tam PC. Hong Kong Med J. 2005:7-11. [pmid: 15687510].
Evaluation of patients referred for percutaneous ablation of renal tumors: importance of a preprocedural diagnosis. Tuncali K, vanSonnenberg E, Shankar S, Mortele KJ, Cibas ES, Silverman SG. AJR Am J Roentgenol. 2004:575-82. [pmid: 15333338].
Natural history of renal masses followed expectantly. Kassouf W, Aprikian AG, Laplante M, Tanguay S. J Urol. 2004:111-3. discussion 113. [pmid: 14665856].
Single-center comparison of purely laparoscopic, hand-assisted laparoscopic, and open radical nephrectomy in patients at high anesthetic risk. Baldwin DD, Dunbar JA, Parekh DJ, Wells N, Shuford MD, Cookson MS, Smith JA Jr, Herrell SD, Chang SS, McDougall EM. J Endourol. 2003:161-7. [pmid: 12803988].
Imaging-guided radiofrequency ablation of solid renal tumors. Farrell MA, Charboneau WJ, DiMarco DS, Chow GK, Zincke H, Callstrom MR, Lewis BD, Lee RA, Reading CC. AJR Am J Roentgenol. 2003:1509-13. [pmid: 12760910].
Improvement of hemostasis in laparoscopic and open partial nephrectomy with gelatin thrombin matrix (FloSeal). Richter F, Tullmann ME, Turk I, Deger S, Roigas J, Wille A, Schnorr D. Urologe A. 2003:338-46. [pmid: 12671767].
Hand-assisted laparoscopic vs the open (flank incision) approach to radical nephrectomy. Busby E, Das S, Rao Tunuguntla HS, Evans CP. BJU Int. 2003:341-4. [pmid: 12603411].
Laparoscopic partial nephrectomy for renal tumor: single center experience comparing clamping and no clamping techniques of the renal vasculature. Guillonneau B, Bermudez H, Gholami S, El Fettouh H, Gupta R, Adorno Rosa J, Baumert H, Cathelineau X, Fromont G, Vallancien G. J Urol. 2003:483-6. [pmid: 12544293].
Surgical outcomes of nephron-sparing surgery for renal tumors. Minowada S, Homma Y, Takeuchi T, Tomita K, Kameyama S, Ohta N, Kitamura T. Nihon Hinyokika Gakkai Zasshi. 2002:555-61. [pmid: 12056040].
Percutaneous image-guided radiofrequency ablation of renal neoplasms: Seven-year local experience. Tsang KWK, Lee SF, Cheung HY, Lui PY, Tam KY. Hong Kong. 2013:17-26.
Role of Intraarterial Embolization before Cryoablation of Large Renal Tumors: A Pilot Study. Woodrum DA, Atwell TD, Farrell MA, Andrews JC, Charboneau JW, Callstrom MR. J Vasc Intervent Radiol. 2010:930-936.
Laparoscopic partial nephrectomy in a solitary kidney. Jea WL, Lim T, Ill YS, Joung SR. Korean J Urol. 2009:463-467.
Thermal protection during percutaneous thermal ablation procedures: Interest of carbon dioxide dissection and temperature monitoring. Buy X, Tok C-H, Szwarc D, Bierry G, Gangi A. Cardiovasc Intervent Radiol. 2009:529-534. [pmid: 19219496].
Magnetic resonance imaging findings after laparoscopic renal cryoablation. Bolte SL, Ankem MK, Moon TD, Hedican SP, Lee FT, Sadowski EA, Nakada SY. Urology. 2006:485-489. [pmid: 16504260].
Laparoscopic operations in urology - Results and complications in 150 patients. Laparoskopicke vykony v urologii - Vysledky a komplikacie u 150 pacientov. L'uptak J, Svihra J, Javorka K, Vrany M, Elias B, Sopilko I, Kliment J Jr. Endoskopie. 2005:66-72.
Radiofrequency ablation in the treatment of renal tumors; early experience. Iguchi T, Mimura H, Mukai T, Dendo S, Hyodo T, Fujiwara H, Hara T, Yasui K, Kanazawa S, Hiraki Y, Tsushima T, Kumon H. Jpn J Clin Radiol. 2004:542-546.
Results of RFA in patients with small renal masses, a single-centre experience with median follow-up of 48 months. Joniau S, Tailly T, Goeman L, Oyen R, Van Poppel H. J Endourol. 2009:A9.
Different presentations of renal cell cancer on ultrasound and computerized tomography. Markic D, Krpina K, Ahel J, Spanjol J, Grskovic A, Stifter S, Ethordevic G, Stemberger C, Pavlovic I, Maricic A. Urologia. 2014:228-32. [pmid: 25198941].
Retroperitoneal laparoscopic partial nephrectomy for moderately complex renal hilar tumors. Xu B, Zhang Q, Jin J. Urol Int. 2014:400-406. [pmid: 24296329].
Renal function and oncologic outcomes after cryoablation or partial nephrectomy for tumors in solitary kidneys. Goyal J, Sidana A, Georgiades CS, Rodriguez R. Korean J Urol. 2011:384-9. [pmid: 21750748].
Haemostatics in surgery and our experience in the enucleoresection of renal cell carcinoma. Pace G, Saldutto P, Vicentini C, Miano L. World J Surg Oncol. 2010;37.
Ischemic renal damage after nephron-sparing surgery in patients with normal contralateral kidney. Funahashi Y, Hattori R, Yamamoto T, Kamihira O, Kato K, Gotoh M. Eur Urol. 2009:209-15. [pmid: 18706758].
Renal cell carcinoma in patients with prior spinal cord injury. Brandes SB, Smith JB, Longo WE, Virgo KS, Johnson FE. J Spinal Cord Med. 2001:251-6. [pmid: 11944783].
A comparison of early results of laparoscopic radical nephrectomy with open radical nephrectomy. Laparoskopik radikal nefrektominin erken sonuclarinin acik radikal nefrektomi ile karsilastirilmasi. Oktay B, Yavascaoglu I, Vuruskan H, Kordan Y, Caliskan Z, Ozturk M. Turk Urol Derg. 2005:178-181.
Experience with retroperitoneoscopic nephrectomy. Moriyama H, Inoue S, Tanabe T, Hayashi T, Nishinihon J. Urol. 2005:119-123. [pmid: 15992909].
Our initial experiences with laparoscopic nephrectomy. Laparoskopik nefrektomide baslangic deneyimlerimiz. Kural AR, Demirkesen O, Akpinar H, Tufek I, Yalcin V, Ozkan B. Turk Urol Derg. 2004:414-421.
Evaluation of percutaneous biopsies of renal masses under MRI-guidance: a retrospective study about 26 cases. Garnon J, Schlier A, Buy X, Tsoumakidou G, de Mathelin M, Breton E, Gangi A. Eur Radiol. 2014.
MR imaging in the characterization of small renal masses. Willatt JM, Hussain HK, Chong S, Kappil M, Azar SF, Liu PS, Ruma JA, Elsayes KM. Abdom Imaging. 2014:761-9. [pmid: 24615511].
Different presentations of renal cell cancer on ultrasound and computerized tomography. Markic D, Krpina K, Ahel J, Spanjol J, Grskovic A, Stifter S, Ethordevic G, Stemberger C, Pavlovic I, Maricic A. Urologia. 2014:228-32. [pmid: 25198941].
Different presentations of renal cell cancer on ultrasound and computerized tomography. Markic D, Krpina K, Ahel J, Spanjol J, Grskovic A, Stifter S, Ethordevic G, Stemberger C, Pavlovic I, Maricic A. Urologia. 2014:0.
A non-cancer-related survival benefit is associated with partial nephrectomy. Sun M, Trinh QD, Bianchi M, Hansen J, Hanna N, Abdollah F, Shariat SF, Briganti A, Montorsi F, Perrotte P, Karakiewicz PI. Eur Urol. 2012:725-31. [pmid: 22172373].
Two-port robot-assisted vs standard robot-assisted laparoscopic partial nephrectomy: a matched-pair comparison. Arkoncel FR, Lee JW, Rha KH, Han WK, Jeoung HB, Oh CK. Urology. 2011:581-5. [pmid: 21783230].
Clinical characteristics and outcomes of patients with recurrence 5 years after nephrectomy for localized renal cell carcinoma. Adamy A, Chong KT, Chade D, Costaras J, Russo G, Kaag MG, Bernstein M, Motzer RJ, Russo P. J Urol. 2011:433-8. [pmid: 21167521].
Prognostic importance of tumor size for localized conventional (clear cell) renal cell carcinoma: assessment of TNM T1 and T2 tumor categories and comparison with other prognostic parameters. Delahunt B, Kittelson JM, McCredie MR, Reeve AE, Stewart JH, Bilous AM. Cancer. 2002:658-64. [pmid: 11857297].
Iatrogenic splenectomy during nephrectomy for renal tumors. Wang JK, Tollefson MK, Kim SP, Boorjian SA, Leibovich BC, Lohse CM, Cheville JC, Thompson RH. Int J Urol. 2013:896-902. [pmid: 23379901].
Renal nephrometry score is associated with urine leak after partial nephrectomy. Bruner B, Breau RH, Lohse CM, Leibovich BC, Blute ML. BJU Int. 2011:67-72. [pmid: 21087391].
A giant clot. Gupta R, Jindal A, Cranston-D'Amato H. Am J Respir Crit Care Med. 2014:e68. [pmid: 24881950].
Radiofrequency ablation of kidney tumors. Souteyrand P, Chagnaud C, Lechevallier E, Andre M. Prog Urol. 2013:1163-7. [pmid: 24176403].
Impact of kidney cancer surgery on oncologic and kidney functional outcomes. Han JS, Huang WC. Am J Kidney Dis. 2011:846-854. [pmid: 21956016].
Recurrent renal cell carcinoma after laparoscopic resection. Lang EK, Gupta N, Thomas R. J Urol. 2006:315. [pmid: 16406935].
Neuromuscular complications after percutaneous radiofrequency ablation of renal tumors. Bhayani SB, Allaf ME, Su L-M, Solomon SB. Urology. 2005:592.e24-592.e25. [pmid: 15780392].
Papillary renal cell carcinoma containing fat without calcification mimicking angiomyolipoma on CT. Schuster TG, Ferguson MR, Baker DE, Schaldenbrand JD, Solomon MH. Am J Roentgenol. 2004:1402-1404. [pmid: 15505311].
A rare complication of radical nephrectomy: A pancreatic pseudocyst. Lekili M, Coskun T, Gunduz I, Temeltas G, Buyuksu C. BJU Int. 2002:e30-e31.
Desmopressin induced hyponatremia and seizures after laparoscopic radical nephrectomy. Pruthi RS, Kang J, Vick R. J Urol. 2002;187.