# Screening and Data Abstraction Forms

Figure B1 Abstract Review Form

Figure B1 Title/abstract screen: This image is a screen shot of the title/abstract screen form used by the systematic review team to screen articles for applicability and categorization.

Figure B2 Article Review Form

Figure B2 Article screen: This image is a screen shot of the article screen form used by the systematic review team to screen articles for applicability and categorization.

## Data Abstraction Forms

Figure B3 Study characteristics

Figure B3-Study Characteristics form: This image is a screenshot of the study characteristics data abstraction form used by the systematic review team to record and organize data.

Figure B4 Intervention

Figure B4-Intervention characteristics form: This image is a screenshot of the intervention characteristics data abstraction form used by the systematic review team to record and organize data.

Figure B5 Participants characteristics

Figure B5-Patient characteristics form: This image is a screenshot of the patient characteristics data abstraction form used by the systematic review team to record and organize data.

Figure B6 Tumor characteristics

Figure B6-Tumor characteristics form: This image is a screenshot of the tumor characteristics data abstraction form used by the systematic review team to record and organize data.

Figure B7 Oncologic Outcomes

Figure B7- Oncologic outcomes form: This image is a screenshot of the oncology outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B8 Categorical Renal Outcomes

Figure B8- Categorical Renal Outcomes form: This image is a screenshot of the categorical renal outcomes) data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B9 Continuous Renal Outcomes

Figure B9- Continuous Renal Outcomes form: This image is a screenshot of the continuous renal outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B10 Quality of Life Outcome

Figure B10-Quality of Life Outcome: This image is a screenshot of the quality of life outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B11 Overall Survival Outcome

Figure B11: Overall Survival Outcome: This image is a screenshot of the overall survival outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B12 Harms

Figure B12: Harms: This image is a screenshot of the harms outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure B13 Perioperative Outcomes

Figure B13: Perioperative Outcomes: This image is a screenshot of the perioperative outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.

Figure 14 Key Question 3B

Figure B14: Key Question 3B: This image is a screenshot of the key questions 3b outcomes data abstraction form used by the systematic review team to record and organize data for baseline, within arm comparison, and between arm comparisons.