# Detailed Electronic Database Search Strategies

## Diagnostic Key Questions (KQ1 and 2)

### PubMed Strategy

((((((((((“Kidney Neoplasms”[Mesh] OR ((Kidney [tiab] or renal[tiab]) AND (cancer [tiab] or carcinoma [tiab] or neoplasm [tiab] or tumor [tiab] or malignancy [tiab] or adenocarcinoma [tiab])) OR “RCC” [tiab] OR “renal mass”[tiab] OR “renal masses”[tiab]OR “Hypernephromas”[tiab] OR “grawitz tumor”[tiab] OR ((Carcinoma[tiab]) AND (Renal Collecting Duct[tiab] OR Hypernephroid[tiab] OR nephroid[tiab]))))

AND (Biopsy, Fine-Needle [mh] OR ((percutaneous[tiab] OR needle[tiab] OR aspiration[tiab] OR core [tiab] OR tru-cut[tiab]) AND (biopsy [tiab] OR sampling[tiab])) OR “FNA”[tiab] OR nomograms[mh] OR nomograms[tiab] OR nomogram[tiab] OR Urinalysis [mh] OR Urinalyses [tiab] OR urine[tiab] OR Blood Cell Count [mh] OR “Blood Cell Count” [tiab] OR WBC [tiab] OR leukocyte[tiab] OR leukocytes[tiab] OR RBC[tiab] OR erythrocyte[tiab] OR thrombocyte[tiab] OR platelet[tiab] OR Blood Coagulation Tests [mh] OR blood coagulation [tiab] OR Thromboplastin Time [tiab] OR Coagulation Time [tiab] OR Prothrombin Time [tiab] OR Thrombotest [tiab] OR quick test [tiab] OR Russell Viper Venom Time [tiab] OR Blood Sedimentation [mh] OR blood Sedimentation[tiab] OR “Sedimentation rate*”[tiab] OR “Diagnostic Imaging”[Mh] OR “Computerized tomography”[tiab] OR “Computed tomography”[tiab] OR “CT”[tiab] OR Ultrasonography[tiab] OR Sonography[tiab] OR ultrasound [tiab] OR “magnetic resonance” [tiab])) AND (Accura*[tiab] OR diagnosis [ti] OR Sensitivity and specificity[mh] OR Sensitivity[tiab] OR Specificity[tiab] OR False positive reactions[mh] OR false positive*[tiab] OR False negative reactions[mh] OR False negative*[tiab] OR Predict*[tiab] OR predictive value of tests[mh] OR score[tiab] OR scores[tiab]))) NOT (((animals[mh] NOT humans[mh]))

## Management Key Questions (KQ3a and 3b)

### PubMed Strategy

kidney neoplasms [mh] OR ((Kidney [tiab] or renal[tiab]) AND (cancer [tiab] or carcinoma [tiab] or neoplasm [tiab] or tumor [tiab] or malignancy [tiab] or adenocarcinoma [tiab])) OR “RCC” [tiab] OR “renal mass”[tiab] OR “renal masses”[tiab]OR “Hypernephromas”[tiab] OR “grawitz tumor”[tiab] OR ((Carcinoma[tiab]) AND (Renal Collecting Duct[tiab] OR Hypernephroid[tiab] OR nephroid[tiab]))

AND

Nephrectomy [mh] OR Nephrectomy [tiab] OR “Nephron sparing surgery”[tiab] OR Peritoneoscopy[tiab] OR Celioscopy[tiab] OR ((cryoablation [tiab] OR radiofrequency [tiab]) AND (renal[tiab] OR kidney [tiab])) OR Cryosurgery [mh] OR Cryosurgery [tiab] OR cryotherapy [tiab] OR “thermal ablation” [tiab] OR surveillance [tiab] OR Watchful Waiting [mh]

NOT

(animals[mh] NOT humans[mh])