# Results

## Introduction

We begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). For each KQ, we provide a detailed description of the studies, key summary points, a detailed analysis of the results, and a table that presents the strength of evidence.

## Literature Searches

The literature searches identified 120 articles describing 105 studies (see Figure 2). Eleven studies (including 1 RCT) addressed KQ 1, and six studies (including 2 RCTs) examined KQ 2. The remaining 103 articles included 88 unique RCTs that addressed KQ 3. Among the 88 trials that addressed KQ 3, 32 examined reduced dosing of a calcineurin inhibitor (CNI), 22 evaluated converting from a CNI regimen to another immunosuppressive regimen, 13 assessed withdrawal of a CNI, 8 explored CNI avoidance through de novo use of non-CNI therapy, and 4 studies had more than 2 arms, which included a standard-dose CNI control group, a CNI minimization group, and either a conversion arm,22 a withdrawal arm,23,24 or an avoidance arm.4 For these four multi-arm trials, data from each intervention group were analyzed with their respective regimens. Additionally, nine studies compared a low-dose CNI regimen with another type of alternative regimen without a standard-dose CNI arm to serve as a control group.

Figure 2 Study flow diagram

KQ = Key Question; RCT=randomized controlled trial

Figure 2 shows a study flow diagram. The large number of citations identified by the literature searches enters the flow diagram at the top. Abstract screening then occurs, and those citations excluded during abstract screening exit the flow diagram to the right, listed in a large box with reasons for exclusion. Continuing down the flow diagram, the number of articles retrieved (630) for full-article screening are shown in a box, and then they are screened against the full inclusion criteria. Excluded articles exit the diagram to the right, and are listed in a large box with reasons for exclusion. Continuing down the flow diagram, at the bottom the number of included studies (116 studies) are shown.

## Methods for Monitoring CNI Drug Levels

### Key Question 1a How do liquid chromatographic and mass spectrometric analytical techniques compare with immunoassay analysis for therapeutic monitoring of full dosing regimens of CNIs?

### Key Question 1b How do liquid chromatographic and mass spectrometric analytical techniques compare with immunoassay analysis for therapeutic monitoring of lower dosing regimens of CNIs?

#### Description of Included Studies

We categorized studies that addressed this KQ according to the “ACCE” framework, which identifies four important dimensions for evaluating a medical test: (1) analytical validity; (2) clinical validity; (3) clinical utility; and (4) ethical, legal, and social implications. The first three of these criteria are meaningful for this KQ. Analytical validity refers to how well a test measures the properties or characteristics it is intended to measure, in a laboratory setting. Clinical validity (or diagnostic accuracy) refers to the accuracy with which a test predicts the presence or absence of a clinical condition. Clinical utility refers to the usefulness of the test and the value of information to medical practice. Outcomes measured in support of clinical utility may range from impact on clinical thinking to impact on therapeutic decisions to patient health outcomes.

Our literature searches identified 11 studies that compared the use of chromatographic techniques to immunoassay techniques to measure CNI (TAC and CsA) levels. None of the studies evaluated clinical validity, but one of the studies assessed clinical utility. Table 4 presents an overview of the studies addressing KQ 1.

Table 4 Methods used to measure calcineurin inhibitors

Reference | Type of Study | Monitoring Methods | Outcomes
Leung et al. 2014^26^ | Prospective comparison of analytical performance of tests | LC-MS/MS vs. QMS™ TAC immunoassay (QMS) | Analytic bias
Shipkova et al. 2014^27^ | Prospective comparison of analytical performance of tests | LC-MS/MS vs. Elecsys TAC assay (ELCIA) | Analytic bias
Westley et al. 2007^28^ | Retrospective comparison of analytical performance of tests | HPLC-MS vs. CEDIA and MEIA | Analytic bias
Borrows et al. 2006^25^ | Randomized controlled trial | HPLC-MS vs. MEIA | Patient and graft survival, kidney function, biopsy proven acute rejection, TAC associated adverse events (e.g., TAC nephrotoxicity and CMV infection), and test precision.
Chan et al. 2005^29^ | Prospective comparison of analytical performance | HPLC-MS vs. MEIA | Analytic accuracy
Butch et al. 2004^30^ | Prospective comparison of analytical performance of tests | HPLC vs. CEDIA Plus | Analytic accuracy and bias
Staatz et al. 2002^31^ | Retrospective comparison of analytical performance | LC-MS/MS vs. ELISA | Analytic accuracy and bias
Hamwi et al. 1999^32^ | Prospective comparison of analytical performance of tests | HPLC-MS vs. FPIA/AxSYM, CEDIA, and modified EMIT | Analytic accuracy and bias
Schutz et al. 1998^33^ | Prospective comparison of analytical performance of tests | HPLC-MS vs. FPIA/AxSYM, CEDIA, and modified EMIT | Analytic accuracy and bias
Salm et al. 1997^34^ | Prospective comparison of analytical performance | HPLC-MS vs. ELISA and MEIA | Analytic accuracy
Roberts et al. 1995^35^ | Prospective comparison of analytical performance of tests | HPLC-MS vs. FPIA/TDx mono and polyclonal immunoassay | Analytic accuracy and bias

CEDIA = cloned enzyme donor immunoassay; CMV = cytomegalovirus; ELCIA = electrochemiluminescence immunoassay; ELISA = enzyme-linked immunosorbent assay; EMIT = enzyme multiplied immunoassay; FPIA = fluorescence polarization immunoassay; HPLC-MS = high performance liquid chromatography; LC/MS/MS = liquid chromatography-tandem mass spectrometry; MEIA = microparticle enzyme immunoassay; TAC = tacrolimus

The one study assessing clinical utility compared clinical outcomes among patients monitored with a chromatographic technique (i.e., HPLC-MS) versus an immunoassay.25 The following clinical outcomes were evaluated: patient and graft survival, biopsy proven acute rejection (BPAR), cytomegalovirus (CMV) infection, TAC nephrotoxicity, and delayed graft function. The remaining studies focused solely on the analytical validity of the different monitoring methods. The primary outcomes reported in these studies were analytic accuracy, bias, and precision. These outcomes and other measures of analytic performance reported in the studies are defined in Table 5. Due to the limited number of studies reporting on patient-level data and heterogeneity of the data on analytic performance, we did not attempt to pool data quantitatively. Instead, we narratively summarize key findings from the studies. Detailed information on study and patient-level characteristics, outcome data, and reported adverse events are presented in evidence tables in Appendix C.

Table 5 Measures of analytical performance

Term | Definition
Analytic accuracy | The analytic accuracy expresses the closeness of agreement between the true value (e.g., drug concentration) or an accepted reference value and the value found.
Precision | The degree to which the same method produces the same results on repeated measurements (repeatability and reproducibility); the degree to which values cluster around the mean of the distribution of values (i.e., the confidence limit).
Limits of Quantification | The highest or lowest concentration at which the drug can be reliably detected.
Linearity | The linearity of an analytical procedure is its ability (within a given range) to obtain test results, which are directly proportional to the concentration (amount) of drug or analyte in the sample.
Analytic Bias | The mean (overall) difference in values obtained with 2 different methods of measurement.
Confidence Limit | Range within which 95% of the differences from the bias are expected to be.
Limits of Agreement | Confidence limits for the bias. Upper LOA is computed as bias +1.96 SD. The lower LOA is computed as bias −1.96 SD. The range between the upper LOA and lower LOA is the confidence limit.

LOA = limits of agreement; SD = standard deviation

Source: www.fda.gov/downloads/animalveterinary/guidancecomplianceenforcement/guidanceforindustry/ucm052377.pdf.

The risk of bias of the one RCT assessing clinical utility was rated as high due to the authors not reporting on the methods used to carry out the randomization procedure and if the outcome assessors were blinded to patient assignment.

Findings for the risk-of-bias assessment of the analytic validity studies are presented in Table C-7. Most of the studies assessing analytic validity adequately described the tests under evaluation. However, the methods used to calibrate the tests and specifics about how the blood samples were collected and handled varied across studies. Only four studies reported the limit of quantification of each test26,28,29,33 and five reported on the linearity range.26-28,30,32 Similarly, only two studies reported that reproducibility was established before comparing the tests' analytical performance.26,27 One of these studies was a multicenter study in which reproducibility of the tests was established over time and across participating laboratories.27 None of the studies reported whether the test interpreters were blinded to the testing methods used to monitor CNI levels.

#### Key Points

- One small study with high risk of bias reported on clinical validity outcomes. The evidence from this study was considered insufficient to permit conclusions about the comparative performance of HPLC versus immunoassay for clinical outcomes due to limitations in methodologic quality of the study and imprecision of the findings.
- The findings of the studies assessing analytical performance suggest that chromatographic methods are more analytically accurate and precise than commonly used immunoassays at measuring CNI drug levels, but it was unclear whether differences identified in these studies were clinically relevant such that they would change clinical management or affect patient outcomes.

#### Summary of Clinical Utility Outcomes

Borrows et al. conducted a RCT comparing the clinical outcomes of renal transplant recipients in whom TAC trough concentration levels were monitored using HPLC versus MEIA.25 Table 6 below presents the findings and strength-of-evidence ratings for the outcomes this study assessed. Overall, the findings are insufficient to permit conclusions about the comparative performance of HPLC versus immunoassay for clinical outcomes.

Table 6 Strength of evidence for clinical utility outcomes of studies of monitoring technologies

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
HPLC vs. MEIA | Biopsy-proven acute rejection | Inconclusive (RR: 0.25; 95% CI: 0.02–2.14) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | Patient death | Inconclusive (too few events) (0/40 vs. 0/40) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | Graft loss | Inconclusive (RR: 0.33; 95% CI: 0.01–7.94) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | Serum creatinine levels (as measured using the Cockcroft Gault formula) | Inconclusive (SMD: 0.024; 95% CI: -0.41–0.43) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | Biopsy proven acute TAC nephrotoxicity | Inconclusive (RR: 0.85; 95% CI: 0.32–2.33) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | CMV infection | Inconclusive (RR: 1.0; 95% CI: 0.49–2.04) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient
HPLC vs. MEIA | Delayed graft function | Inconclusive (RR: 1.16; 95% CI: 0.62–2.20) | 1 RCT25 N=80 | Study Limitations Imprecision | Insufficient

CI = confidence interval; CMV = cytomegalovirus; HPLC-MS = high-performance liquid chromatography; MEIA = microparticle enzyme immunoassay; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, and Directness. Consistency was not assessed because the evidence base included only one study. Publication and reporting bias were not assessed due to insufficient number of studies.

#### Summary of Analytical Performance Outcomes

All 11 studies addressing KQ 1 compared the analytical performance of chromatographic techniques to an immunoassay. Among studies monitoring CsA levels, two compared HPLC to FPIA/AxSYM, CEDIA and modified EMIT,32,33 one compared HPLC to the FPIA/TDx35 and one compared HPLC to CEDIA plus.30 Among studies monitoring TAC levels, three compared HPLC to either MEIA or CEDIA,21-23 two compared LC-MS/MS to either ELISA or MEIA,24,25 and two compared LC-MS/MS to TAC-specific immunoassays.26,27 Most of the studies had an adequate number of participants and blood samples (30 or more participants with about 100 blood samples). The overall agreement between the chromatographic and immunoassay tests across all the studies was good (Pearson's correlation estimate: r^2^ range 0.90–0.98). The most commonly reported outcomes among these studies were analytic accuracy, bias, and precision. The key findings from these studies are summarized in Table 7.

Table 7 Key findings of studies comparing analytic performance of chromatographic techniques versus immunoassays

Outcome | CNI Regimen | Quantity and Type of Evidence | Key Findings
Analytic accuracy | CsA | 4 prospective comparative studies30,32,33,35 | Immunoassays show good correlation with HPLC-MS; - HPLC vs CEDIA plus immunosassay: r^2^=0.98; slope 0.90 (95% CI 0.87 to 0.93); intercept -18 (-26.6, -9.5), Sy/x=32.9; - HPLC vs FPIA/TDx monoclonal immunoassay: r^2^=0.91; - HPLC vs FPIA/TDx polyclonal: r^2^=0.98; - HPLC vs CEDIA: r^2^=0.97; slope 1.31 (95% CI 1.29 to 1.47); - HPLC vs EMIT: r^2^=0.97; slope 1.17 (95 CI 1.02 to 1.28); - HPLC vs FPIA/AxSYM r^2^=0.98; slope 1.03 (95% CI 0.97 to 1.12); - HPLC vs FPIA/TDx r^2^= 0.97 slope 1.29 (95% CI 1.19 to 1.42); - HPLC vs FPIA/AxSYM: slope=1.17 (1.04 to 1.32), intercept 13.2, Sx/y=19.2; - HPLC vs CEDIA: slope=1.19 (1.00 to 1.39), intercept -3.5, Sx/y=24.0; - HPLC vs EMIT: slope 1.07 (0.97 to 1.19), intercept 16.2, Sx/y=16.1
Analytic bias | CsA | 4 prospective comparative studies30,32,33,35 | Immunoassays measured significantly higher CsA levels than HPLC; - HPLC results were 17.5% lower than CEDIA plus; - HPLC values were always lower than the FPIA/TDx monoclonal with a mean difference of -109 µg/L (standard deviations [SD] 99); - Immunoassay was higher than HPLC: 14.1 % higher with CEDIA, 18.8% with EMIT, 10% with FPIA/AxSYM, 50% with FPIA/TDx; - Immunoassay was higher than HPLC: 32% higher with FPIA/AxSYM, 22.5% higher with CEDIA, 23.9% higher with EMIT
Precision | CsA | 4 prospective comparative studies30,32,33,35 | HPLC demonstrated greater precision than immunoassays; - For the CEDIA plus, the within assay coefficient of variance (CV) was between 2.7% and 8.7% for CsA levels ranging from 48-1,502 µg/L.; - The within assay CV ranged between 2% and 5% for both the monoclonal and polyclonal FPIA/TDx; - The within assay CV at the lowest CsA concentration ranged from 3.07% for the FPIA/TDx to 10.6% for the CEDIA. At the highest concentration, the CV ranged from 1.73% for FPIA/TDx to 6.45% for FPIA/AxSYM. The between assay CV ranged from 4.25% (FPIA/TDx) to 8.90% (EMIT) at the lowest CSA and from 3.12% (FPIA/TDx) to 6.77% (FPIA/AxSYM) at the highest CSA.; - The within assay coefficient of variation are provided for low and high range controls: HPLC 6.8%, 7.6%; FPIA/AxSym 5.8%, 1.7%; CEDIA 11%, 5.5%; EMIT 6.5%, 4.8%
Analytic accuracy | TAC | 2 prospective and 1 retrospective comparative studies29,31,34 | HPLC and LC-MS/MS more accurate than immunoassay at measuring TAC at lower concentration levels.; - TAC concentration levels measured by HPLC-MS were statistically lower than levels measured by MEIA (median difference -0.40 (2.03) µg/L; p<0.001).; - Concentration measurements of TAC at 5 µg/L ng/mL, 10 µg/L ng/mL, and 20 µg/L ng/mL had corresponding relative difference in values between LC-MS/MS and immunoassay (as expressed by 95% confidence intervals) of between -50% and 60%, -24% to 31%, and -11% to 17%.; - Measurement of TAC samples at various concentrations (1.0, 4.0, 15.0 and 50.0 µg/l), indicated acceptable accuracy of HPLC-MC at all levels tested (<10% deviation), and for ELISA at 1.0 and 4.0. Analytic accuracy was not acceptable for ELISA at 15.0 and 50.0 µg/L or for MEIA at all concentrations.^*^
Analytic bias | TAC | 2 prospective and 2 retrospective comparative studies26-28,31 | Compared to chromatographic techniques, bias for immunoassays ranged from 2% to 37%.
Precision | TAC | 1 RCT25 | Inter-assay variability using Abbott Diagnostic control samples of 5, 11, and 22 ng/ml TAC was 8.0%, 6.5%, and 5.7% for HPLC-MS, respectively, compared to 13.7%, 8.3%, and 10.9% for MEIA, respectively.

CEDIA = cloned enzyme donor immunoassay; CsA = cyclosporine; CV = coefficient of variation; ELCIA = electrochemiluminescence immunoassay; ELISA = enzyme-linked immunosorbent assay; EMIT = enzyme multiplied immunoassay; FPIA = fluorescence polarization immunoassay; HPLC-MS = high performance liquid chromatography; LC/MS/MS = liquid chromatography-tandem mass spectrometry; MEIA = microparticle enzyme immunoassay; RCT = randomized controlled trial; Sy/x = dispersion of residuals;TAC = tacrolimus

* Accuracy was measured 3 times per day for 5 days, each of the weighed-in controls was assayed in triplicate by all 3 methods (HPLC-MS, ELISA, MEIA). Accuracy was calculated for each measurement as mean concentration/weight in concentration.

In brief, three studies compared the analytic accuracy of chromatographic techniques to immunoassay to measure TAC at various concentration levels.29,31,34 Only two of these studies adequately reported sufficient details about the methods used to calibrate the tests or how blood samples were obtained and managed.29,34 Only one study reported on the limit of quantification.29 None of these studies were multicenter studies, and none of them reported on whether reproducibility of the tests was established either within blood samples or across test operators or over time. In general, the findings of these studies suggest that HPLC and LC-MS/MS were more accurate than an immunoassay in measuring TAC at lower concentration levels. However, it is unclear whether these differences are clinically relevant such that they would change clinical management or affect patient outcomes. We did not grade the strength of evidence for these nonclinical outcomes.

Four studies reported on analytic bias between immunoassays compared to chromatographic techniques to measure TAC.26-28,31 Three of the studies sufficiently reported details about the tests and reported on other important aspects of conducting analytical validity studies, such as the linearity and reproducibility of the tests.26-28 The remaining study did not provide any details about how tests were calibrated or samples were obtained or handled and did not report on other details such as linearity and reproducibility.31 The results of these studies suggest that immunoassays overestimate TAC levels compared to measurements from chromatographic techniques.

One RCT compared the precision of chromatographic techniques to immunoassays to measure TAC.25 The findings suggest that assay precision was better for HPLC-MS than MEIA. We did not grade the strength of evidence for this nonclinical outcome. Again, it is unclear whether the differences found in these studies would change clinical management.

Finally, four studies compared the analytic accuracy and bias of chromatographic techniques to immunoassays to measure CsA levels.30,32,33,35 In general, the tests under evaluation in these studies were sufficiently described, and all four of the studies evaluated the issue of cross-reactivity. Cross-reactivity of antibody-based CsA immunoassays with metabolites is a concern especially in situations where metabolite levels are expected to accumulate. The evaluation of cross-reactivity among these studies consistently showed that FPIA had the greatest cross-reactivity, followed by CEDIA, and EMIT showing the least cross-reactivity. The overall findings of the studies suggest that chromatographic methods are more analytically accurate and precise than commonly used immunoassays. However, it was again unclear if differences identified in these studies were clinically relevant.

#### Applicability

The majority of the studies addressing KQ 1 were laboratory studies comparing the analytical performance of immunoassays to chromatographic techniques. These studies varied in terms of the quality controls used to prepare and handle blood samples, methods of calibrating equipment, and analytical methods used to process data. Such differences may limit the generalizability of the studies. Further, most of these studies took place in academic medical centers in which there was access to chromatographic technologies. Access to these technologies may be limited in smaller clinical settings.

#### Summary

Only one study at high risk of bias assessed clinical outcomes of renal recipients in whom TAC levels were measured with either a commonly used commercial immunoassay (e.g., MEIA) or HPLC. The evidence from this study was considered insufficient to permit conclusions about the comparative performance of HPLC versus immunoassay for clinical outcomes due to limitations in methodological quality of the study and imprecision of the findings.

The findings assessing analytical performance suggest that chromatographic methods are more analytically accurate and precise than commonly used immunoassays at measuring CNI drug levels. Selection of assay methodology for measurement of calcineurin inhibitors did not have an impact on clinical outcomes after renal transplantation. This is partially due to the bias between assay methodologies. However additional factors such as the lack of standardization in laboratory procedures also impacts the wide inter-laboratory variability reported in therapeutic drug monitoring of immunosuppressive drugs.36 However, the methodologic quality of some of the studies is questionable due to not reporting information about baseline test characteristics such as limit of detection, linearity, and reproducibility, and it was unclear whether differences identified in these studies were clinically relevant such that they would change clinical management or affect patient outcomes.

## Timing for Monitoring CNI Drug Levels

### Key Question 2 How does 2-hour post-administration CsA monitoring (C2) compare with trough monitoring (C0)?

#### Description of Included Studies

Six comparative trials addressed this question. All but one study compared C0 monitoring of CsA to C2 among new renal transplant recipients. The remaining study compared C0 monitoring to C2 monitoring of CsA among stable renal transplant recipients (>3 months post-transplant).37 Due to the heterogeneity of the studies, we did not attempt to combine data from the studies quantitatively. Instead, we provide a narrative synthesis of the studies' general findings. Detailed evidence tables presenting information on the design of the studies, study populations, findings, and risk-of-bias assessment are located in Appendix C.

Two of the included studies were RCTs. Both studies were rated as having high risk of bias. In one study, withdrawal was higher among patients in the C2 group (6 vs. 0 in C0 group) primarily due to discomfort of giving repeated blood samples. The other RCT was rated as having high risk of bias due to not reporting on randomization procedures, blinding of outcome assessors, or completion rates.

The remaining four studies were nonrandomized comparative trials. In general, these studies were rated as high risk of bias primarily due to not using methods to ensure group comparability, not reporting whether outcome assessors were blinded, and retrospective designs.

#### Key Points

- Among new renal transplant recipients, risk of BPAR is similar between patients monitored at C0 and those monitored at C2. (Strength of Evidence: Low)
- Among new renal transplant recipients (within 20 days after transplant), evidence from one RCT indicated that C2 monitoring led to a significantly higher CsA mean cumulative dose increase compared to C0 monitoring. (Strength of Evidence: Low)
- Among new renal transplant recipients, evidence from one RCT demonstrated that significantly more patients in the C2 group experienced tremors than patients in the C0 group. (Strength of Evidence: Low)
- Among new renal transplant recipients, there was insufficient evidence available to draw conclusions about the association of C0 versus C2 monitoring for the outcomes of patient and graft loss, renal function, and other adverse events. This was due to the study limitations and imprecision of findings in the non-randomized trials available.
- Among stable renal transplant recipients at 3 or more months after transplant, C2 monitoring led to significantly more CsA dose reductions than C0 monitoring. (Strength of Evidence: Low)

#### Detailed Synthesis

##### Studies of New Renal Transplant Recipients

One RCT compared CsA C2 monitoring to C0 monitoring among new renal transplant patients. Kyllonen and colleagues randomly assigned 160 patients before transplantation to C0 monitoring or C2 monitoring for 20-days post-transplantation.38 After transplantation, CsA levels in both study groups were monitored at both C0 and C2 timepoints. However, depending on the randomization, the values of one method were blinded until the end of the 20-day study period. After 20 days, all patients were continued with C0 monitoring only. Patients at higher immunologic risk (i.e., panel reactive antibodies [PRA] >30% and/or previous graft loss within 1 year for immunologic reasons) were excluded from the study. The target C0 level was 200 to 300 µg/L, and the target C2 level was 1,500 to 2,000 µg/L. However, despite dose adjustments, 72 percent of C2 monitored patients did not reach the C2 target range by day-3 post-transplant, and 45 percent did not reach the target range by day-5 post-transplant. In contrast, 5 percent of patients did not reach the C0 target range by day-5 post-transplant.

The difficulty in reaching C2 target levels in this study likely explains the highly significant differences observed in the mean CsA doses and blood levels between the two monitoring groups. Low strength of evidence from this study indicated that C2 monitoring led to a significantly higher overall increase in CsA dose compared to C0 monitoring. The mean CsA dose in the group randomly assigned to management based on C2 monitoring was 56 percent higher than in the group randomly assigned to management based on C0 monitoring (11,409 mg vs. 7,256 mg, respectively), and the mean C0 and C2 blood levels were 98 percent and 55 percent higher in the C2 group than the C0 group. In the C0 group, the mean cumulative CsA dose increased by 7,175 mg compared to a cumulative increase of 8,460 mg in the C2 group (p<0.01). Such differences, however, did not lead to differences in overall acute rejection rate between the groups.

The remainder of the evidence for new renal transplant patients comes from four nonrandomized studies.39-42 Overall, low strength of evidence from these studies and the RCT suggests no difference in the risk of acute rejection between patients monitored at C2 and those at C0 (RR 0.95, 95% CI: 0.61 to 1.45). One small non-RCT did demonstrate a significant decline in renal function among patients in the C0 group compared to those in the C2 group over the course of the study.39 The serum creatinine level at 36 months was significantly higher among patients in the C0 group (1.46±0.52) than in patients in the C2 group (0.99±0.13, p=0.04). Similarly, creatinine clearance levels were significantly lower in the C0 group (55.15±19.21) than the in the C2 group (84.65±14.97, p<0.001). Patients in this study were followed for 36 months compared to 6 or fewer months in the other studies. For the most part, the evidence for patient and graft loss and adverse events among studies comparing C0 to C2 monitoring in new renal transplants was inconclusive due to study limitations of nonrandomized trials and imprecision of findings. However, low strength evidence from one RCT did indicate that significantly more patients in the C2 group (n=9) than in the C0 group (n=2) experienced tremors (RR 4.82, 95% CI: 1.09 to 21.78).

##### Studies of Stable Renal Transplant Recipients

Jirasiritham and colleagues conducted an RCT comparing CsA C0 monitoring to C2 monitoring among patients who had more than 3 months of successful renal transplantation with well-functioning renal grafts.37 The authors randomly assigned 35 patients to convert from C0 monitoring to C2 monitoring and 35 to remain on C0 monitoring. All patients were followed for 3 months. The target C2 level among patients converted to C2 monitoring was 800 ng/mL with 10 percent variation, and the target C0 level among patients who remained on C0 monitoring was 100 to 150 ng/mL. Lack of precision due to the study's small sample size and small number of events occurring in each group prevented conclusions for the primary outcomes of interest: acute rejection, patient and graft loss, and nephrotoxicity. The findings of the study did, however, provide low strength of evidence indicating that C2 monitoring led to more dosage reductions than C0 monitoring (34.3% vs. 14.3%, p=0.02). The discrepancy of the findings related to CsA dose between this study and the study by Kyllonen may be due to differences between the studies in the time period examined post-transplant. In the Kyllonen study, the patients were 20 days post-transplant, whereas in this study they were 3 or more months post-transplant. CsA levels tend to fluctuate more shortly after transplantation, and reaching target levels is often difficult.

#### Applicability

The applicability of the studies addressing this KQ is limited due primarily to the exclusion of patients at high risk of rejection. Overall, 71 percent of the studies excluded patients considered high risk. This includes patients over the age of 65 and patients with previous renal transplants. The average age range of patients enrolled in the studies was between 32 to 51 years. Few studies reported on race. Among the three studies that did, the majority of patients were Caucasian.

#### Summary

Table 8 presents the strength of evidence ratings for the studies addressing this KQ. Overall, low strength of evidence suggests that risk of BPAR is similar between new renal transplants monitored at C0 compared to those monitored at C2. For the most part, the evidence for patient and graft loss and adverse events among studies comparing C0 to C2 monitoring in new renal transplants was inconclusive due to study limitations of nonrandomized trials and imprecision of findings. However, low strength of evidence from one RCT indicated that C2 monitoring led to a significantly higher CsA mean cumulative dose increase compared to C0 monitoring. Low strength of evidence from this same study also indicated that significantly more patients in the C2 group than in the C0 group experienced tremors. In contrast, low strength of evidence from one small RCT indicated that C2 monitoring led to significantly more CsA dose reductions than C0 monitoring among stable renal recipients. The discrepancy of the findings related to CsA dose could be due to the difference in time post-transplant of patients in the studies. In one study, the patients were only 20-days post-transplant; in the other study, they were 3 or more months post-transplant. The difference may also reflect the fact that these conclusions come from single studies and that additional studies could overturn their conclusions.

Table 8 Strength of evidence of studies comparing C0 to C2 monitoring of CsA

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
C2 vs. C0 among new renal transplant recipients | BPAR | No difference (RR: 0.95; 95% CI: 0.61–1.45) | 1 RCT, 3 non-RCTs40-42 N=851 | Study Limitations Imprecision | Low
C2 vs. C0 among new renal transplant recipients | Patient death | Inconclusive (RR: 1.71; 95% CI: 0.41–7.05) | 1 RCT, 2 non-RCTs38,41,42 N=431 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among new renal transplant recipients | Graft loss | Inconclusive (RR: 0.84; 95% CI: 0.33–2.14 | 1 RCT, 2 non-RCTs40-42 N=635 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among new renal transplant recipients | Serum creatinine levels | The findings from 1 non-RCT indicated serum creatinine level at 36 months was significantly higher among patients in the C0 group (1.46±0.52) than the C2 group (0.99±0.13, p=0.04), and creatinine clearance levels were significantly lower in the C0 group (55.15±19.21) than the C2 group (84.65±14.97, p<0.001). | 1 non-RCT39 N=37 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among new renal transplant recipients | CsA dosage | Findings from 1 RCT indicated significantly higher CsA mean cumulative dose increase among patients in the C2 group compared to the C0 group (8460 mg vs. 7175 mg, p<0.01) | 1 RCT38 N=154 | Study Limitations Imprecision | Low
C2 vs. C0 among new renal transplant recipients | Chronic allograft nephrotoxicity (CAN) | Inconclusive (RR: 0.16; 95% CI: 0.02–1.09) | 1 non-RCT39 N=37 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among new renal transplant recipients | Tremors | Findings from 1 RCT indicated significantly more patients in the C2 group (n=9) had tremors than the C0 group (n=2); (RR 4.82, 95% CI: 1.09–21.78) | 1 RCT38 N=154 | Study Limitations Imprecision | Low
C2 vs. C0 among new renal transplant recipients | Other Adverse Events | Inconclusive for other AEs (infections, cardiac symptoms, new onset diabetes) | 1 RCTs, 2 non-RCTs40-42 N=635 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among stable renal transplant recipients | BPAR | Inconclusive (RR: 0.33: 95% CI: 0.01–7.90) | 1 RCT37 N=70 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among stable renal transplant recipients | Patient death | Inconclusive (no events) | 1 RCT37 N=70 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among stable renal transplant recipients | Graft loss | Inconclusive (no events) | 1 RCT37 N=70 | Study Limitations Imprecision | Insufficient
C2 vs. C0 among stable renal transplant recipients | CsA dosage | C2 monitoring led to more dosage reductions compared to C0 monitoring (34.3% vs. 14.3%, p=0.02). | 1 RCT37 N=70 | Study Limitations Imprecision | Low
C2 vs. C0 among stable renal transplant recipients | Nephrotoxicity | Inconclusive (no events) | 1 RCT37 N=70 | Study Limitations Imprecision | Insufficient

AE = adverse event; BPAR = biopsy proven acute rejection; C2 = 2-hour CsA monitoring; CI = confidence interval; C0 = trough monitoring; CsA = cyclosporine A; RCT = randomized controlled trial; RR = relative risk

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, and Directness. Publication and reporting bias not assessed due to insufficient number of studies.

## Alternative CNI Regimens

### Key Question 3a In adult renal transplants, how do immunosuppressive regimens designed to reduce or eliminate exposure to CNI toxicity compare with each other and with full-dose CNI regimens for health outcomes?

### Key Question 3b How do the type of induction agent (including when no induction is used) and the use of concurrent immunosuppressive agents affect outcomes of regimens that reduce or eliminate CNI exposure?

Regimens designed to reduce or eliminate CNI exposure after renal transplant were grouped into four types of strategies, as described in Table 1: minimization, conversion, withdrawal, and avoidance. Each regimen was analyzed separately, and the head-to-head studies were assessed as a separate category.

The average age of renal transplant recipients enrolled in the studies was between 30 and 55 years. Thirty-seven studies (42%) excluded patients over 75 years old, including 20 (23%) that excluded patients older than 65. Among studies reporting on patient race, the majority of enrolled patients were Caucasian males. Measures of patient socioeconomic status were not reported. In most studies, the majority of patients received their renal transplant from a deceased donor, although 11 studies (13%) enrolled only patients whose renal transplant was from a living donor. Seventy studies (80%) were conducted in the United States or Europe, while others took place in Australia, Brazil, China, Egypt, India, Iran, Japan, Korea, Mexico, and New Zealand.

In general, the studies we reviewed excluded patients at high risk for graft failure or other adverse outcomes. Clinical indications commonly used to exclude participants included active infections, history of malignancies, prior renal transplant, and/or severe metabolic or hematologic abnormalities. In thirty-five studies (40%), patients with PRA greater than 50 percent were excluded, and retransplants were not eligible for participation in 21 studies (24%). Additionally, we excluded studies conducted in multi-organ transplant populations from our analysis.

## Minimization

### Description of Included Studies: Minimization

The most widely studied strategy reported in the RCTs we identified in the literature search is minimization of CNI dosage. Minimization is most frequently implemented by reducing the target blood levels that are used to adjust dosing. CNI minimization has been evaluated for both CsA and TAC. CNI minimization has been supplemented with many combinations of other immunosuppressive drugs and induction agents. Thirty-six RCTs examining dose minimization met the inclusion criteria for this review (Table 9). Twenty-two studies used reduced dosing of CsA, seven studies examined TAC minimization, and seven RCTs combined populations that received CsA or TAC. Mycophenolic acid formulations (MMF or enteric-coated mycophenolic sodium) were used as the primary additional immunosuppressive drug in 19 studies, and 14 studies used mammalian target of rapamycin (mTOR) inhibitors in addition to CNI. Two studies incorporated multiple adjunct therapies, including mycophenolic acid formulations, mTOR inhibitors, and azathioprine (AZA). Vathsala et al.43 did not use any additional maintenance immunosuppressive therapy. Steroid therapy, usually prednisone, was administered in the intervention and control groups in nearly every study.

Table 9 Minimization studies

Reference | CNI | Other Immunosuppression | N, Intervention | N, Control
Xu 2011^44^ | CsA, TAC | MMF | 20 | 18
Gaston 2009^45^ | CsA, TAC | MMF | 243 | 477
Spagnoletti 2009^46^ | CsA, TAC | MMF | 30 | 30
Ekberg 2007b4 | CsA, TAC | MMF | 800 | 390
Hernandez 2007^47^ | CsA, TAC | MMF | 160 | 80
Tang 2006^48^ | CsA, TAC | MMF, AZA | 18 | 16
Cai 2014^49^ | CsA | MPS | 90 | 90
Chadban 2013^50^ | CsA | MPS | 42 | 33
Etienne 2010^51^ | CsA | MMF | 106 | 102
Fangmann 2010^52^ | CsA | MMF | 75 | 73
Budde 2007^53^ | CsA | MPS | 44 | 45
Cibrik 2007^54^ | CsA | MPS | 75 | 66
Ekberg 2007a24 | CsA | MMF | 183 | 173
Ghafari 2007^55^ | CsA | MMF | 42 | 48
Frimat 2006^56,57^ | CsA | MMF | 70 | 31
Stoves 2004^58^ | CsA | MMF | 13 | 16
Pascual 2003^59^ | CsA | MMF | 32 | 32
de Sevaux 2001^60^ | CsA | MMF | 152 | 161
Chan 2012^61^ | TAC | MPS | 151 | 141
Kamar 2012^62^ | TAC | MPS | 45 | 47
Bolin 2008^63^ | TAC | MMF, SRL, AZA | 100 | 223
Holdaas 2011^22^ | CsA, TAC | EVR | 144 | 123
Chadban 2014^23^ | CsA | EVR | 30 | 47
Muhlbacher 2014^64^ | CsA | SRL | 178 | 179
Cibrik 2013^65^ | CsA | EVR | 556 | 277
Takahashi 2013^66^ | CsA | EVR | 61 | 61
Oh 2014^67^ | CsA | EVR | 67 | 72
Paoletti 2012^68^ | CsA | EVR | 10 | 20
Bertoni 2011^69^ | CsA | EVR | 56 | 50
Salvadori 2009^70^ | CsA | EVR | 143 | 142
Nashan 2004^71^ | CsA | EVR | 58 | 53
Bechstein 2013^72^ | TAC | SRL | 63 | 65
Langer 2012^73^ | TAC | EVR | 107 | 117
Chan 2008^74^ | TAC | EVR | 49 | 43
Lo 2004^75^ | TAC | SRL | 23 | 16
Vathsala 2005^43^ | CsA | None | 20 | 10

AZA = azathioprine; CsA = cyclosporine; EVR = everolimus; MMF = mycophenolate mofetil; MPS = mycophenolate sodium; N = number of patients; SRL = sirolimus; TAC = tacrolimus

These trials widely used induction therapy. Sixteen studies included basiliximab induction, three used daclizumab, one used alemtuzumab, two included rabbit antithymocyte globulin (rATG), and one indicated that induction therapy was not standardized and varied according to the local practice of study sites. Two studies indicated that induction therapy was not used, while the remaining 11 studies did not report on induction. Subgroup analysis of regimens with induction agents was performed separately for studies using mycophenolic acid formulations and mTOR inhibitors.

CNI exposure was usually minimized immediately or shortly after transplant. Twenty-nine studies initiated minimization within the first 6 months following transplant, three trials waited at least 6 months, and four adopted this strategy 1 year or more after transplant. Subgroup analysis was conducted comparing early (i.e., first 6 months after transplant) and late (i.e., 6 months or later after transplant) minimization for patients receiving MMF or mycophenolate sodium (MPS). We did not examine timing of minimization for patients receiving mTOR inhibitors because minimization was initiated early in all but two studies.

Risk of bias was determined to be high for 17 of the 36 minimization studies (47%). The detailed assessments of risk of bias are presented in Table E-21 in the Appendix. Sixteen studies were categorized as moderate risk, and three studies were assessed as low risk of bias. Incomplete descriptions of randomization and allocation concealment practices were common, and many studies did not sufficiently describe whether all eligible patients were enrolled. Additionally, data on patient adherence with drug therapy were rarely included in published results. Twenty-seven trials (75%) were funded by sources that could benefit financially from the study results, such as pharmaceutical manufacturers. Five studies were funded by sources that did not appear to have a financial interest in the outcomes, and four studies did not report source of funding.

### Key Points

- Early minimization of CNI exposure through low-dose regimens is associated with improved renal function and lower risk of acute rejection and graft loss (Strength of Evidence: High).
- Regimens using mycophenolic acid formulations and low-dose CsA are associated with better renal function, lower risk of acute rejection (Strength of Evidence: Moderate), and lower risk of graft loss (Strength of Evidence: High) compared with regimens based on standard-dose CsA. The evidence for minimization regimens using mycophenolic acid formulations and TAC suggests improvement in renal function (Strength of Evidence: High) but is insufficient to draw conclusions for the other outcomes.
- Regimens that include mTOR inhibitors and low-dose CsA are associated with improved renal function and no difference in acute rejection (Strength of Evidence: Moderate) compared with standard-dose regimens, but the evidence for mTOR inhibitors with TAC is insufficient.
- Induction with basiliximab, when used with mTOR inhibitors and low-dose CNIs, is associated with better renal function (Strength of Evidence: High), lower risk of graft loss, and no difference in risk of acute rejection (Strength of Evidence: Moderate), but the evidence is insufficient to draw conclusions when basiliximab is used with mycophenolic acid formulations.
- Minimization with low-dose CNIs and mycophenolic acid formulations, when initiated within the first 6 months after renal transplant, is associated with improved renal function (Strength of Evidence: Low), lower risk of graft loss (Strength of Evidence: Moderate), and lower risk of acute rejection and infection (Strength of Evidence: High) compared with standard-dose regimens.
- Minimization initiated 6 months after transplant or later is associated with increased risk of acute rejection (Strength of Evidence: Low). The evidence is insufficient to draw conclusions for other clinical outcomes.

### Detailed Synthesis—Minimization Studies

Analysis combining results from all 36 trials (see Table 10) found that CNI minimization was associated with improved renal function, reduced risk of acute rejection and graft loss, and lower incidence of CMV and other opportunistic infections (with the exception of BK virus infection, for which the evidence was inconclusive) compared with standard-dose regimens. No difference was observed for patient death.

Table 10 Strength of evidence for all minimization studies

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
All reduced CNI vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.32; 95% CI: 0.22–0.41; I^2^=60%^a^) | 24 RCTs4,22,24,44,47-50,52,53,56,59-62,64,66,67,69-74 N=5,043 | None | High
All reduced CNI vs. Standard | BPAR | Minimization associated with reduced rejection (RR: 0.84; 95% CI: 0.75–0.95; I^2^=19%) | 35 RCTs4,22-24,43-45,47-56,58-75 N=7,563 | None | High
All reduced CNI vs. Standard | Graft loss | Minimization associated with reduced graft loss (RR: 0.76; 95% CI: 0.61–0.94; I^2^=12%) | 36 RCTs4,22-24,43-56,58-75 N=7,623 | None | High
All reduced CNI vs. Standard | Patient death | No difference (RR: 0.91; 95% CI: 0.72–1.14; I^2^=0) | 32 RCTs4,22-24,43-45,47,49,50,52-56,58-68,70-75 N=7,215 | Imprecision | Moderate
All reduced CNI vs. Standard | CMV infection | Minimization associated with lower incidence of CMV (RR: 0.71; 95% CI: 0.55–0.92; I^2^=57%^a^) | 19 RCTs4,23,24,43,45,47,52,59,60,63-66,69-73,75 N=5,666 | Study Limitations | Moderate
All reduced CNI vs. Standard | BK infection | Inconclusive (RR: 0.68; 95% CI: 0.06–7.55; I^2^=65%) | 4 RCTs45,59,65,73 N=1,841 | Study Limitations Imprecision Inconsistency | Insufficient
All reduced CNI vs. Standard | Other opportunistic infections | Minimization associated with lower incidence of other infections (RR: 0.76; 95% CI: 0.64–0.91; I^2^=0) | 13 RCTs4,24,43,48,52,54,56,59,60,62,64,71,72 N=3,065 | None | High

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

a Based on subgroup analyses, the high level of heterogeneity observed in this outcome appears to be attributable primarily to the use of multiple, diverse immunosuppressive regimens and/or the presence of high- and low-risk patients, in the included studies. Therefore, we did not decrease the strength of evidence for Inconsistency.

The strength of evidence for these findings was high for renal function, acute rejection, graft loss, and other opportunistic infections and moderate for patient death and CMV infection. The evidence for BK virus infection was insufficient based on the four studies that reported this outcome due to the small number of reported infections and substantial imprecision and inconsistency in the results. A moderate amount of heterogeneity was identified for the outcomes of eGFR and CMV infection, but this was due to the inclusion of diverse immunosuppressive regimens and the inclusion of high- and low-risk patients in these comprehensive comparisons. The effect estimate for patient death was imprecise, and the outcome of other infections was subject to reporting bias. Further analyses were conducted to separate studies according to type of adjunctive immunosuppressive therapy and choice of CNI.

#### Mycophenolic Acid-Based Adjunctive Therapy

Similar results were found for the 19 studies that used CNI minimization with mycophenolic acid formulations. In general, renal function improved, as measured by eGFR, and risk of acute rejection, graft loss, CMV infection, and other infections were reduced (Table 11). No difference was observed for patient death, and the two studies that reported BK infection did not yield sufficient evidence to support a conclusion. Of these 19 studies, 14 minimized CsA and 5 minimized TAC. Examination of these studies separately found high- or moderate-strength evidence that low-dose CsA was associated with improved renal function, reduced risk of acute rejection and graft loss, and lower incidence of opportunistic infections compared with standard-dose CsA (Table 12). The evidence was inconclusive for patient death, CMV infection, and BK virus infection. Low-dose TAC was also associated with improved renal function, based on high-strength evidence, compared to standard-dose regimens, but the evidence for the other important clinical outcomes we analyzed was insufficient to support conclusions.

Table 11 Strength of evidence for minimization studies with adjunctive use of mycophenolic acid formulations

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.32; 95% CI: 0.20–0.45; I^2^=55%^a^) | 13 RCTs4,24,44,47,49,50,52,53,56,59-62 N=3,178 | None | High
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | BPAR | Minimization associated with reduced rejection (RR: 0.80; 95% CI: 0.68–0.95; I^2^=27% | 18 RCTs4,24,44,45,47,49-56,58-62 N=4,366 | None | High
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | Graft loss | Minimization associated with reduced graft loss (RR: 0.71; 95% CI: 0.56–0.90; I^2^=5%) | 19 RCTs4,24,44-47,49-56,58-62 N=4,426 | None | High
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | Patient death | No difference (RR: 0.87; 95% CI: 0.66–1.15; I^2^=0) | 17 RCTs4,24,44,45,47,49,50,52-56,58-62 N=4,158 | Imprecision | Low
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | CMV infection | Minimization associated with lower incidence of CMV (RR: 0.77; 95% CI: 0.62–0.95; I^2^=36%) | 7 RCTs4,24,45,47,52,59,60 N=3,031 | None | High
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | BK infection | Inconclusive (RR: 0.55; 95% CI: 0.07–4.57; I^2^=0) | 2 RCTs45,59 N=784 | Study Limitations Imprecision | Insufficient
Reduced CNI (cyclosporine or tacrolimus) + mycophenolic acid formulations vs. Standard | Other opportunistic infections | Minimization associated with lower incidence of other infections (RR: 0.77; 95% CI: 0.61–0.98; I^2^=7%) | 8 RCTs4,24,52,54,56,59,60,62 N=2,405 | Reporting Bias | Moderate
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.28; 95% CI: 0.10–0.46; I^2^=58%) | 10 RCTs4,24,47,49,50,52,53,56,59,60 N=2,756 | Inconsistency | Moderate
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | BPAR | Minimization associated with reduced risk of acute rejection (RR: 0.88; 95% CI: 0.76–1.02); I^2^=0) | 14 RCTs4,24,47,49-56,58-60 N=3,224 | Imprecision | Moderate
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | Graft loss | Minimization associated with reduced graft loss (RR: 0.70; 95% CI: 0.55–0.88; I^2^=0) | 14 RCTs4,24,47,49-56,58-60 N=3,224 | None | High
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | Patient death | Inconclusive (RR: 0.80; 95% CI: 0.54–1.20; I^2^=0) | 13 RCTs4,24,47,49,50,52-56,58-60 N=3,016 | Imprecision | Insufficient
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | CMV infection | Inconclusive (RR: 0.86; 95% CI: 0.62–1.18; I^2^=47%) | 6 RCTs4,24,47,52,59,60 N=2,311 | Imprecision | Insufficient
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | BK infection | Inconclusive, no events observed | 1 RCT59 N=64 | Study Limitations Imprecision | Insufficient
Reduced cyclosporine + mycophenolic acid formulations vs. Standard | Other opportunistic infections | Minimization associated with lower incidence of other infections (RR: 0.83; 95% CI: 0.64–1.07; I^2^=0) | 7 RCTs4,24,52,54,56,59,60 N=2,313 | Imprecision | Moderate
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.42; 95% CI: 0.22–0.62; I^2^=29%) | 4 RCTs4,47,61,62 N=1,814 | None | High
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | BPAR | Inconclusive (RR: 0.76; 95% CI: 0.40–1.43; I^2^=56%) | 4 RCTs4,47,61,62 N=1,814 | Imprecision Inconsistency | Insufficient
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | Graft loss | Inconclusive (RR: 0.88; 95% CI: 0.32–2.46; I^2^=47%) | 5 RCTs4,46,47,61,62 N=1,874 | Imprecision | Insufficient
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | Patient death | Inconclusive (RR: 1.00; 95% CI: 0.45–2.24; I^2^=0) | 4 RCTs4,47,61,62 N=1,814 | Imprecision | Insufficient
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | CMV infection | Inconclusive (RR: 0.64; 95% CI: 0.27–1.52; I^2^=0) | 2 RCTs4,47 N=1,430 | Imprecision | Insufficient
Reduced tacrolimus + mycophenolic acid formulations vs. Standard | Other opportunistic infections | Inconclusive (RR: 0.63; 95% CI: 0.01–49.02; I^2^=5%) | 2 RCTs4,62 N=1,282 | Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

a Based on subgroup analyses, the high level of heterogeneity observed in this outcome appears to be attributable primarily to the use of multiple, diverse immunosuppressive regimens and/or the presence of high- and low-risk patients in the included studies. Therefore, we did not decrease the strength of evidence for Inconsistency.

Table 12 Strength of evidence for subgroup analyses of minimization studies with adjunctive use of mycophenolic acid formulations

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Induction subgroup: Basiliximab + reduced CNI + mycophenolic acid formulations | Renal function | Inconclusive (SMD: 0.42; 95% CI: -0.78–1.62; I^2^=84%) | 3 RCTs50,53,61 N=456 | Imprecision Inconsistency | Insufficient
Induction subgroup: Basiliximab + reduced CNI + mycophenolic acid formulations | BPAR | Inconclusive (RR: 0.86; 95% CI: 0.57–1.30; I^2^=0) | 4 RCTs50,53,54,61 N=597 | Imprecision | Insufficient
Induction subgroup: Basiliximab + reduced CNI + mycophenolic acid formulations | Graft loss | Inconclusive (RR: 1.57; 95% CI: 0.61–4.07; I^2^=0) | 5 RCTs46,50,53,54,61 N=657 | Imprecision | Insufficient
Induction subgroup: Basiliximab + reduced CNI + mycophenolic acid formulations | Patient death | Inconclusive (RR: 1.10; 95% CI: 0.16–7.43; I^2^=0) | 4 RCTs50,53,54,61 N=597 | Imprecision | Insufficient
Induction subgroup: Basiliximab + reduced CNI + mycophenolic acid formulations | Other opportunistic infections | Inconclusive (RR: 1.14; 95% CI: 0.66–1.95; p=0.64) | 1 RCT54 N=141 | Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | Renal function | Minimization with no induction or not reported associated with improved eGFR (SMD: 0.25; 95% CI: 0.05–0.45; I^2^=9%) | 6 RCTs44,49,56,59,60,62 N=788 | Study Limitations | Moderate
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | BPAR | Minimization with no induction or not reported associated with lower risk of rejection (RR: 0.83; 95% CI: 0.74–0.95; I^2^=0) | 9 RCTs44,45,49,55,56,58-60,62 N=1,627 | Study Limitations | Moderate
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | Graft loss | Minimization with no induction or not reported associated with lower risk of graft loss (RR: 0.79; 95% CI: 0.60–1.04; I^2^=0) | 9 RCTs44,45,49,55,56,58-60,62 N=1,627 | Study Limitations Imprecision | Low
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | Patient death | Minimization with no induction or not reported associated with lower risk of death (RR: 0.81; 95% CI: 0.61–1.08; I^2^=0) | 9 RCTs44,45,49,55,56,58-60,62 N=1,627 | Study Limitations Imprecision | Low
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | CMV infection | Inconclusive (RR: 1.01; 95% CI: 0.50–2.01; I^2^=17%) | 3 RCTs45,59,60 N=1,097 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | BK infection | Inconclusive (RR: 0.55; 95% CI: 0.07–4.57; I^2^=0) | 2 RCTs59,76 N=784 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mycophenolic acid formulations | Other opportunistic infections | Inconclusive (RR: 1.08; 95% CI: 0.52–2.24; I^2^=0) | 4 RCTs56,59,60,62 N=570 | Study Limitations Imprecision | Insufficient
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | Renal function | Minimization with daclizumab induction associated with improved eGFR (SMD: 0.25; 95% CI: 0.05–0.44; I^2^=54%) | 3 RCTs4,24,52 N=1,694 | Inconsistency | Moderate
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | BPAR | Inconclusive (RR: 0.58; 95% CI: 0.16 to 2.15; I^2^=93%) | 3 RCTs4,24,52 N=1,694 | Imprecision Inconsistency | Insufficient
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | Graft loss | Minimization with daclizumab induction associated with lower risk of graft loss (RR: 0.53; 95% CI: 0.31–0.91; I^2^=8%) | 3 RCTs4,24,52 N=1,694 | None | High
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | Patient death | Minimization with daclizumab induction associated with lower risk of death (RR: 0.65; 95% CI: 0.40–1.05; I^2^=0) | 3 RCTs4,24,52 N=1,694 | Imprecision | Low
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | CMV infection | Minimization with daclizumab induction associated with lower incident of CMV infection (RR: 0.81; 95% CI: 0.58–1.13; I^2^=0) | 3 RCTs4,24,52 N=1,694 | Imprecision | Low
Induction subgroup: daclizumab only in minimization group + reduced CNI + mycophenolic acid formulations | Other opportunistic infections | Minimization with daclizumab induction associated with lower risk of other infections (RR: 0.68; 95% CI: 0.50–0.94; I^2^=0%) | 3 RCTs4,24,52 N=1,694 | None | High
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | Renal function | Early minimization associated with improved eGFR (SMD: 0.33; 95% CI: 0.16–0.45; I^2^=61%) | 10 RCTs4,24,44,47,49,50,52,53,60,61 N=2,921 | Study Limitations Inconsistency | Low
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | BPAR | Early minimization associated with lower risk of rejection (RR: 0.79; 95% CI: 0.66–0.96; I^2^=33%) | 13 RCTs4,24,44,45,47,49,50,52-55,60,61 N=3,872 | None | High
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | Graft loss | Early minimization associated with lower risk of graft loss (RR: 0.72; 95% CI: 0.54–0.95; I^2^=9%) | 14 RCTs4,24,44-47,49,50,52-55,60,61 N=3,932 | Study Limitations | Moderate
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | Patient death | Inconclusive (RR: 0.87; 95% CI: 0.63–1.20; I^2^=0) | 13 RCTs4,24,44,45,47,49,50,52-55,60,61 N=3,872 | Study Limitations Imprecision | Insufficient
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | CMV infection | Early minimization associated with lower risk of CMV (RR: 0.77; 95% CI: 0.61–0.96; I^2^=39%) | 6 RCTs4,24,45,47,52,60 N=2,967 | None | High
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | BK infection | Inconclusive (RR: 0.53; 95% CI: 0.18–1.57; p=0.25) | 1 RCT45 N=720 | Study Limitations Imprecision | Insufficient
Early minimization subgroup: reduced CNI + mycophenolic acid formulations | Other opportunistic infections | Early minimization associated with lower risk of other infections (RR: 0.76; 95% CI: 0.57 of 1.00; I^2^=9%) | 5 RCTs4,24,52,54,60 N=2,148 | Imprecision | Moderate
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | Renal function | Inconclusive (SMD: 0.42; 95% CI: -0.17–1.02; I^2^=6%) | 3 RCTs56,59,62 N=257 | Imprecision | Insufficient
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | BPAR | Late minimization associated with increased risk of acute rejection (RR: 1.48; 95% CI: 0.81–2.71; I^2^=0) | 5 RCTs51,56,58,59,62 N=494 | Imprecision | Low
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | Graft loss | Inconclusive (RR: 0.62; 95% CI: 0.30–1.30; I^2^=0) | 5 RCTs51,56,58,59,62 N=494 | Imprecision | Insufficient
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | Patient death | Inconclusive (RR: 0.87; 95% CI: 0.43–1.77; I^2^=0) | 4 RCTs56,58,59,62 N=286 | Imprecision | Insufficient
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | CMV infection | Inconclusive, no events observed | 1 RCT59 N=64 | Study Limitations Imprecision | Insufficient
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | BK infection | Inconclusive, no events observed | 1 RCT59 N=64 | Study Limitations Imprecision | Insufficient
Late minimization subgroup: reduced CNI + mycophenolic acid formulations | Other opportunistic infections | Inconclusive (RR: 2.35; 95% CI: 0.72–7.66; I^2^=0) | 3 RCTs56,59,62 N=257 | Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

Subgroup analyses were performed to evaluate the effect of induction therapy and timing of minimization on outcomes. Five studies used basiliximab induction in addition to CNI minimization and mycophenolic acid formulations. The evidence for each outcome was insufficient to support a conclusion due mainly to substantial imprecision in the effect size estimates. Three studies used daclizumab in the minimization arm and no induction in the control group. These studies were associated with an improvement in eGFR and lower risk of graft loss, death, and infection. However, only reduced risk of graft loss and other opportunistic infections were supported by high-strength evidence, while the other outcomes were supported by moderate- or low-strength evidence. Additionally, the results for acute rejection were inconclusive due to insufficient evidence.

Nine studies did not use induction or did not report whether induction was used. Meta-analysis of these trials found that minimization without induction, or when no induction was reported, was associated with improved renal function and reduced risk for acute rejection, graft loss, and death. The evidence base was moderate strength for eGFR and acute rejection and low strength for graft loss and death. Analyses of infection outcomes were inconclusive.

Overall, regimens that included mycophenolic acid formulations and low-dose CNI resulted in better outcomes than standard-dose CNI regimens when induction therapy was not used, not reported, or incorporated daclizumab. Unfortunately, none of the RCTs that examined low-dose CNI regimens used different induction strategies across the minimization arm, so direct within-study comparisons of the effects of different induction agents were not possible. Further research is necessary to clarify the effect of induction therapy in CNI minimization.

Fourteen studies initiated minimization within 6 months after transplant. These trials were associated with improvement in all outcomes, except death and BK virus infection, for which the data were insufficient to support a conclusion. Interestingly, early minimization was associated with lower risk of acute rejection, as this finding may call into question conventional wisdom about the risks of low-dose strategies.

In five studies that reduced CNI dose 6 months after transplant or later, low-strength evidence indicated a higher risk of acute rejection. For the other outcomes, the evidence base was insufficient. Although we identified no studies that directly compared early with late minimization, the evidence indicates that early initiation is associated with improved outcomes while later initiation may not confer benefit and may be associated with harm. Importantly, these studies used minimization as a planned strategy in randomized populations and did not initiate lower-dose regimens in response to specific patient needs. This evidence base cannot address the potential benefits or harms of later-stage minimization in transplant recipients who experience CNI toxicity or other adverse events.

#### MTOR Inhibitor-Based Adjunctive Therapy

Fourteen RCTs studied SRL or EVR and reduced-dose CNI compared to standard-dose regimens. Analysis of these studies found moderate-strength evidence for improvement in renal function, and low-strength evidence suggesting no difference for risk of acute rejection and lower incidence of CMV infection (Table 13). The evidence was insufficient for the other outcomes.

Table 13 Strength of evidence for minimization studies with adjunctive use of mTOR inhibitors

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.31; 95% CI: 0.12–0.50; I^2^=68%^a^) | 10 RCTs22,64,66,67,69-74 N=1,831 | Study Limitations | Moderate
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | BPAR | No difference (RR: 0.95; 95% CI: 0.77–1.17; I^2^=0) | 14 RCTs22,23,64-75 N=2,810 | Study Limitations Imprecision | Low
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | Graft loss | Inconclusive (RR: 0.79; 95% CI: 0.47–1.33; I^2^=24%) | 14 RCTs22,23,64-75 N=2,810 | Study Limitations Imprecision | Insufficient
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | Patient death | Inconclusive (RR: 0.97; 95% CI: 0.59–1.60; I^2^=0) | 13 RCTs22,23,64-68,70-75 N=2,704 | Imprecision | Insufficient
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | CMV infection | Minimization associated with lower incidence of CMV (RR: 0.52; 95% CI: 0.29–0.93; I^2^=55%) | 10 RCTs23,64-66,69-73,75 N=2,282 | Study Limitations Inconsistency | Low
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | BK infection | Inconclusive (RR: 0.84; 95% CI: 0.03–27.74; I^2^=86%) | 2 RCTs65,73 N=1,057 | Imprecision Inconsistency | Insufficient
Reduced CNI (cyclosporine or tacrolimus) + mTOR inhibitors vs. Standard | Other opportunistic infections | Inconclusive (RR: 0.75; 95% CI: 0.29–1.91; I^2^=0) | 3 RCTs64,71,72 N=596 | Study Limitations Imprecision | Insufficient
Reduced cyclosporine + mTOR inhibitors vs. Standard | Renal function | Minimization associated with improved eGFR (SMD: 0.36; 95% CI: 0.08–0.64; I^2^=69%^a^) | 6 RCTs64,66,67,69-71 N=1,120 | Study Limitations | Moderate
Reduced cyclosporine + mTOR inhibitors vs. Standard | BPAR | No difference (RR: 0.88; 95% CI: 0.70–1.10; I^2^=0) | 9 RCTs23,64-71 N=2,060 | Imprecision | Moderate
Reduced cyclosporine + mTOR inhibitors vs. Standard | Graft loss | Minimization associated with reduced risk of graft loss (RR: 0.56; 95% CI: 0.26–1.18; I^2^=31%) | 9 RCTs23,64-71 N=2,060 | Imprecision | Low
Reduced cyclosporine + mTOR inhibitors vs. Standard | Patient death | Inconclusive (RR: 0.86; 95% CI: 0.42–1.77; I^2^=0) | 8 RCTs23,64-68,70,71 N=1,954 | Imprecision | Insufficient
Reduced cyclosporine + mTOR inhibitors vs. Standard | CMV infection | Minimization associated with reduced risk for CMV infection (RR: 0.51; 95% CI: 0.25–1.06; I^2^=69%) | 7 RCTs23,64-66,69-71 N=1,891 | Imprecision Inconsistency | Low
Reduced cyclosporine + mTOR inhibitors vs. Standard | BK infection | Minimization associated with reduced incidence of BK infection (RR: 0.15; 95% CI: 0.03–0.67; p=0.01) | 1 RCT65 N=833 | Imprecision | Low
Reduced cyclosporine + mTOR inhibitors vs. Standard | Other opportunistic infections | Inconclusive (RR: 0.59; 95% CI: 0.15–2.30; I^2^=30%) | 2 RCTs64,71 N=468 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | Renal function | Inconclusive (SMD: 0.37; 95% CI: -0.12–0.85; I^2^=23%) | 3 RCTs72-74 N=444 | Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | BPAR | Inconclusive (RR: 1.50; 95% CI: 0.78–2.91; I^2^=0) | 4 RCTs72-75 N=483 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | Graft loss | Inconclusive (RR: 1.88; 95% CI: 0.56–6.39; I^2^=0) | 4 RCTs72-75 N=483 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | Patient death | Inconclusive (RR: 1.02; 95% CI: 0.31–3.35; I^2^=0) | 4 RCTs72-75 N=483 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | CMV infection | Inconclusive (RR: 0.59; 95% CI: 0.21–1.65; I^2^=0) | 3 RCTs72,73,75 N=391 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | BK infection | Inconclusive (RR: 5.46; 95% CI: 0.65–45.99; p=0.12) | 1 RCT73 N=224 | Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Standard | Other opportunistic infections | Inconclusive (RR: 0.52; 95% CI: 0.10 to 2.72; p=0.43 for candida; RR: 1.03; 95% CI: 0.07–16.15; p=0.98 for herpes) | 1 RCT72 N=128 | Study Limitations Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

a Based on subgroup analyses, the high level of heterogeneity observed in this outcome appears to be attributable primarily to the use of multiple, diverse immunosuppressive regimens and/or the presence of high- and low-risk patients in the included studies. Therefore, we did not decrease the strength of evidence for Inconsistency.

Meta-analysis of the trials that specifically used low-dose CsA with an mTOR inhibitor resulted in moderate-strength evidence that suggested improved renal function and no difference for risk of acute rejection. Low-strength evidence suggested a reduced risk for graft loss and CMV infection, while the evidence was insufficient to draw conclusions about risk of death or other opportunistic infections. Only one of these studies reported on BK infection, but the authors found significantly fewer cases in the minimization group. Four studies used low-dose TAC with an mTOR inhibitor, but the evidence was insufficient for all outcomes due to substantial imprecision in the effect size estimates. The overall improvement in outcomes associated with low-dose CNI and mTOR inhibitors appears to be influenced by the studies that used CsA but not regimens based on TAC.

Induction therapy with basiliximab was employed in 10 of the trials that lowered CNI dosing and used SRL or EVR. Improved renal function and lower risk of graft loss were found in these studies, supported by moderate-strength evidence, and low-strength evidence suggested lower risk of CMV infection. No differences were observed for the risk of graft loss and death, and the evidence was insufficient to support conclusions for the outcomes of BK virus and other infections. In the three studies that did not use or did not report induction therapy in conjunction with mTOR inhibitors, the evidence base was insufficient for all outcomes.

### Applicability

The patient populations included in these studies were generally at lower risk of adverse outcomes, based on clinical and demographic characteristics, and the findings may thus be less applicable to higher-risk patients. The average age of included patients was between 40 and 50, 60 and 70 percent in most studies were men. Most of the studies excluded patients with PRA that exceeded a defined threshold (typically 50%), and patients over age 65 or 70 as well retransplant recipients were frequently excluded.

Another important consideration is that 22 of the studies used CsA, 7 used TAC, and 7 combined patients that received CsA and those that received TAC. Our overall results were generally similar to the results of subgroup analyses of studies that administered CsA. Subgroup analysis also suggested that the heterogeneity observed in several of our results might be attributed in part to the studies that used TAC. The overall findings may therefore be more representative of CsA minimization than TAC minimization.

Other features of these studies also limit the applicability of our findings. “Minimization” is not a uniform approach based on a single strategy for reducing CNI dosing, and studies varied in their selection of target levels. For example, CsA low-dose targets ranged from 25 to 50 ng/mL in some studies and 80 to 120 ng/mL in other trials. Similarly, low-dose TAC was defined as a trough target of 1.5 to 3.0 ng/mL in one study, and 5 to 10 ng/mL in another, while other studies varied within these ranges. Therefore, the target levels compared in this analysis do not represent the effect of a particular low-dose regimen. Rather, the results indicate that reduced CNI dosage is associated with improved outcomes compared with nonreduced dosing. This review cannot identify a specific target range for minimization that is associated with better clinical outcomes.

Moreover, management of immunosuppressive therapy has evolved over the past 20 years, as utilization of CNIs and adjunctive agents has increased, and as other elements of transplant medicine have changed. One important result is that current management of CNI therapy typically uses dosing and target levels that are lower than those employed in many of the studies we reviewed. In some studies, therefore, the minimization arm used dosing that would currently be viewed as a standard-dose, rather than a low-dose regimen. Another important consideration is that target ranges for therapeutic drug levels are goals that may not be achieved for every patient or even a majority of patients in a study. The appendix (Table E-3) presents data on the extent to which target levels were achieved in intervention and control groups. Wide variation existed in how this information was reported and in the achievement of targets. In many of the studies we reviewed, many patients did not, or may not, have reached a designated target level. We considered the impact of this variation on heterogeneity when we assessed the strength of evidence. However, due to incomplete and inconsistent reporting of data on achievement of target levels, it was not possible to conduct subgroup analyses based on these factors.

### Summary

Overall, high- and moderate-strength evidence suggests that early CNI minimization, through low-dose regimens, improves patient outcomes and does not increase adverse event rates. The benefits associated with minimization were observed for CsA and TAC, although the evidence for TAC was frequently insufficient, and for regimens that included mycophenolic acid formulations or mTOR inhibitors as adjunct immunosuppressive therapy. Induction agents did not clearly correlate with improved outcomes, and results for subgroup analyses of induction therapy varied by adjunct immunosuppression treatment. Timing of initiating minimization may be an important factor affecting outcomes. High strength of evidence indicated improved clinical outcomes were associated with early minimization but not late minimization. It is important to note that all these findings may be less applicable to patients at higher risk for poor clinical outcomes and may represent effects associated with CsA to a greater degree than TAC. Nevertheless, these results demonstrate that CNI minimization appears to be an effective approach to immunosuppression therapy in renal transplant recipients.

Table 14 Strength of evidence for subgroup analyses of minimization studies with adjunctive use of mTOR inhibitors

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | Renal function | Induction with basiliximab associated with improved eGFR (SMD: 0.34; 95% CI: 0.10 to 0.58; I^2^=61%^a^) | 7 RCTs66,67,69-71,73,74 N=1,079 | None | High
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | BPAR | No difference (RR: 0.94; 95% CI: 0.77–1.14; I^2^=0) | 10 RCTs23,65-71,73,74 N=2,019 | Imprecision | Moderate
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | Graft loss | Induction with basiliximab associated with reduced risk of graft loss (RR: 0.57; 95% CI: 0.32–1.03; I^2^=28%) | 10 RCTs23,65-71,73,74 N=2,019 | Imprecision | Moderate
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | Patient death | No difference (RR: 0.97; 95% CI: 0.62–1.54; I^2^=0) | 9 RCTs23,65-68,70,71,73,74 N=1,913 | Imprecision | Low
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | CMV infection | Induction with basiliximab associated with lower incidence of CMV infection (RR: 0.47; 95% CI: 0.20–1.09; I^2^=62%) | 7 RCTs23,65,66,69-71,73 N=1,758 | Imprecision Inconsistency | Low
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | BK infection | Inconclusive (RR: 0.84; 95% CI: 0.03–27.74; I^2^=86%) | 2 RCTs65,73 N=1,057 | Imprecision Inconsistency | Insufficient
Induction subgroup: basiliximab + reduced CNI + mTOR inhibitors | Other opportunistic infections | Inconclusive for herpes simplex infections (RR: 0.13; 95% CI: 0.01–2.47; p=0.18) | 1 RCT71 N=111 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | Renal function | Inconclusive (SMD: 0.26; 95% CI: -0.58–1.10; I^2^=84%) | 3 RCTs22,64,72 N=752 | Study Limitations Imprecision Inconsistency | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | BPAR | Inconclusive (RR: 1.34; 95% CI: 0.22–8.08; I^2^=64%) | 3 RCTs22,64,72 N=752 | Study Limitations Imprecision Inconsistency | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | Graft loss | Inconclusive (RR: 1.26; 95% CI: 0.21–7.50; I^2^=0) | 3 RCTs22,64,72 N=752 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | Patient death | Inconclusive (RR: 1.20; 95% CI: 0.02–71.29; I^2^=29%) | 3 RCTs22,64,72 N=752 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | CMV infection | Inconclusive (RR: 0.85; 95% CI: 0.10–7.30; I^2^=0) | 2 RCTs64,72 N=485 | Study Limitations Imprecision | Insufficient
Induction subgroup: no induction or not reported + reduced CNI + mTOR inhibitors | Other opportunistic infections | Inconclusive (RR: 0.78; 95% CI: 0.25–2.50; I^2^=0) | 2 RCTs64,72 N=485 | Study Limitations Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

a Based on subgroup analyses, the high level of heterogeneity observed in this outcome appears to be attributable primarily to the use of multiple, diverse immunosuppressive regimens and/or the presence of high- and low-risk patients in the included studies. Therefore, we did not decrease the strength of evidence for Inconsistency.

## Conversion

### Description of Conversion Studies

Overall, 23 studies assessed the benefits and harms of converting from a CNI to another maintenance immunosuppressive regimen. The majority of the studies (n=18) evaluated conversion from a CNI to an mTOR-based inhibitor (SRL or EVR). The other studies assessed conversion from CNI to AZA, MMF, MPS, or belatacept. Table 15 presents the immunosuppressive regimens assessed in the studies. In most of the studies, conversion took place within 3- to 6-months post-transplantation. Additional information about the dosing of the regimens is provided in Table E-5.

Table 15 Conversion studies

Reference | Type of Intervention | N, Intervention | N, Control
Budde 2015^80^ | CNI to EVR | 46 | 47
Bensal 2013^77^ | CNI to SRL | 31 | 29
Holdaas 2011^22^ | CNI to EVR | 127 | 123
Weir 2011^81^ | CNI to SRL | 148 | 151
Schena 2009^82^ | CNI to SRL | 555 | 275
Watson 2005^79^ | CNI to SRL | 19 | 19
Chhabra 2013^83^ | TAC to SRL | 123 | 64
Silva 2013^84^ | TAC to SRL | 97 | 107
Heilman 2011^85^ | TAC to SRL | 62 | 60
Rostaing 2015^86^ | CsA to EVR | 96 | 98
Mjornstedt 2012^87^ | CsA to EVR | 102 | 100
Nafar 2012^88^ | CsA to SRL | 50 | 50
Guba 2010^89^ | CsA to SRL | 69 | 71
Bemelman 2009^90^ | CsA to EVR or MPS | 74 | 39
Lebranchu 2009^91^ | CsA to SRL | 95 | 97
Durrbach 2008^92^ | CsA to SRL | 33 | 36
Barsoum 2007^93^ | CsA to SRL | 76 | 37
Budde 2012^78^ | CsA to EVR | 155 | 146
Bakker 2003^94^ | CsA to AZA | 60 | 68
MacPhee 1998^95^ | CsA to AZA | 102 | 114
Hilbrands 1996^96^ | CsA to AZA | 60 | 60
Dudley 2005^97^ | CsA to MMF | 73 | 70
Rostaing 2011^98^ | CNI to belatacept | 84 | 89

AZA = azathioprine; CNI = calcineurin inhibitor; CsA = cyclosporine; EVR = everolimus; MMF = mycophenolate mofetil; MPS = mycophenolate sodium; SRL = sirolimus; TAC = tacrolimus

All the studies evaluating the impact of conversion were RCTs in which all patients were initially on a CNI regimen and then randomly assigned to either remain on the CNI regimen or convert to another immunosuppressive agent. The majority of the studies were rated as having high (53%) or moderate (30%) risk of bias. In most cases, the sources of potential bias were due to not reporting if there was allocation concealment or if outcome assessors were blinded, differential loss to followup, and potential conflict of interest of the funding source. The majority of studies (96%) were either industry funded or did not report the funding source. Four studies were rated as having a low risk of bias.77-79 These studies clearly reported allocation concealment and did not have differential loss to followup. See Table E-21 for risk-of-bias ratings.

### Key Points

- Patients converted to an mTOR inhibitor demonstrated modest improvement in renal function compared to patients who remained on a CNI regimen. (Strength of Evidence: Moderate)
- Patients converted to an mTOR inhibitor experienced lower incidence of cytomegalovirus infection than patients remaining on a CNI regimen. (Strength of Evidence: High)
- Graft loss was similar among patients remaining on a CNI and those converting to an mTOR inhibitor or AZA. (Strength of Evidence: Low)
- The overall risk of BPAR was higher among patients converted to MPS than those who remained on a CNI regimen. (Strength of Evidence: Moderate)
- The evidence was insufficient due to lack of precision to permit conclusions for the outcomes from studies that evaluated conversion from CsA to MMF.

### Detailed Synthesis: Conversion Studies

Table 16 shows the findings and the strength-of-evidence ratings for all the outcomes analyzed. Seventeen studies contributed data to a pooled analysis comparing renal function as measured by glomerular filtration rate among patients converted to an mTOR inhibitor to renal function among those remaining on a CNI. Moderate-strength evidence suggested modest improvement in renal function among those converted to an mTOR inhibitor (SMD: 0.37; 95% CI: 0.14–0.60). When the analysis was stratified based on type of CNI, high-strength evidence suggested improved renal function among those converted to an mTOR compared to patients remaining on CsA (SMD: 0.62; 95% CI: 0.23–1.01). However, low-strength evidence indicated no difference in renal function between patients converted to an mTOR inhibitor and those remaining on TAC (SMD: -0.11; 95% CI: -0.47–0.25).

Table 16 Strength of evidence for conversion studies

Comparison | Outcome | Conclusions | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | BPAR | Inconclusive (RR: 1.38; 95% CI: 0.96–1.99; I^2^=49%) | 18 RCTs22,77,79,81-85,87-93,99 N=3,442 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | Graft loss | Inconclusive (RR: 1.11; 95% CI: 0.73–1.69; I^2^=2%) | 14 RCTs22,81-85,87,89,91-93,99 N=3,165 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | Patient death | Inconclusive (RR: 1.19; 95% CI: 0.66–2.15; I^2^=0) | 14 RCTs22,81-85,87,89,91-93,99 N=3,165 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | Renal function | Conversion to mTOR associated with improved renal function (SMD: 0.37; 95% CI: 0.14–0.60; I^2^=87%) | 17 RCTs22,77,79,81-85,87,89,91-93,99 N=3,254 | Inconsistency | Moderate
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | CMV Infection | Conversion to mTOR associated with lower incidence of CMV (RR: 0.61; 95% CI: 0.38–0.98; I^2^=37%) | 10 RCTs77,81,83-85,87,89,90,92,99 N=1,660 | None | High
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | BK infection | Inconclusive (RR: 0.59; 95% CI: 0.20–1.79; I^2^=40%) | 7 RCTs77,81,83-85,87,91,99 N=1,332 | Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to mTOR inhibitors | Other infection | Inconclusive (RR: 1.28; 95% CI: 0.84–1.97; I^2^=28%) | 10 RCTs77,79,81-85,87,93,99 N=1,660 | Imprecision | Insufficient
Tacrolimus to mTOR inhibitors | BPAR | Inconclusive (RR: 1.75; 95% CI: 0.35–8.08; I^2^=0%) | 3 RCTs83-85 N=513 | Imprecision | Insufficient
Tacrolimus to mTOR inhibitors | Graft loss | No difference (RR: 0.88; 95% CI: 0.55–1.39; I^2^=0%) | 3 RCTs83-85 N=513 | Imprecision | Low
Tacrolimus to mTOR inhibitors | Patient death | Inconclusive (RR: 1.46; 95% CI: 0.24–8.83; I^2^=0%) | 3 RCTs83-85 N=513 | Imprecision | Insufficient
Tacrolimus to mTOR inhibitors | Renal function | No difference (SMD: -0.11; 95% CI: -0.47–0.25; I^2^=0% | 3 RCTs83-85 N=513 | Imprecision | Low
Tacrolimus to mTOR inhibitors | CMV Infection | Inconclusive (RR: 0.70; 95% CI: 0.07–6.91; I^2^=56%) | 3 RCTs83-85 N=513 | Imprecision | Insufficient
Tacrolimus to mTOR inhibitors | BK infection | Inconclusive (RR: 0.35; 95% CI: 0.11–1.14; I^2^=0%) | 2 RCTs83,85 N=309 | Study Limitations Imprecision | Insufficient
Tacrolimus to mTOR inhibitors | Other infection | Inconclusive (RR: 0.58; 95% CI: 0.05–6.47; I^2^=0%) | 3 RCTs83-85 N=513 | Imprecision | Insufficient
Cyclosporine to mTOR inhibitors | BPAR | Inconclusive (RR: 1.37; 95% CI: 0.76–2.46; I^2^=64%) | 9 RCTs87-93,99 N=1,357 | Imprecision Inconsistency | Insufficient
Cyclosporine to mTOR inhibitors | Graft loss | Inconclusive (RR: 1.27; 95% CI: 0.42–3.81; I^2^=25%) | 7 RCTs87,89,91-93,99 N=1,180 | Imprecision | Insufficient
Cyclosporine to mTOR inhibitors | Patient death | Inconclusive (RR: 0.78; 95% CI: 0.43–1.42; I^2^=0%) | 7 RCTs87,89,91-93,99 N=1,180 | Imprecision | Insufficient
Cyclosporine to mTOR inhibitors | Renal function | Conversion to mTOR associated with improved renal function (SMD: 0.62; 95% CI: 0.23–1.01; I^2^=86%; with 1 outlier study removed SMD: 0.48; 95% CI: 0.32–0.65; I^2^=14%)^a^ | 8 RCTs87-91,93,99 N=1,288 | None | High
Cyclosporine to mTOR inhibitors | CMV infection | Inconclusive (RR: 0.56; 95% CI: 0.23–1.38; I^2^=54%) | 5 RCTs87,89,90,92,99 N=788 | Imprecision | Insufficient
Cyclosporine to mTOR inhibitors | BK infection | Inconclusive (RR: 1.59; 95% CI: 0.33–7.61; I^2^=0%) | 3 RCTs87,91,99 N=534 | Imprecision | Insufficient
Cyclosporine to mTOR inhibitors | Other infection | Inconclusive (RR: 1.30; 95% CI: 0.28–6.11; I^2^=57%) | 3 RCTs87,91,99 N=534 | Imprecision | Insufficient
Cyclosporine to azathioprine | BPAR | Inconclusive (RR: 0.93; 95% CI: 0.52–1.68; I^2^=0%) | 3 RCTs94-96 N=464 | Study Limitations Imprecision | Insufficient
Cyclosporine to azathioprine | Graft loss | No difference (RR: 0.84; 95% CI: 0.55–1.28; I^2^=0%) | 3 RCTs94-96 N=464 | Study Limitations Imprecision | Low
Cyclosporine to azathioprine | Patient death | Inconclusive (RR: 0.92; 95% CI: 0.41–2.04; I^2^=14%) | 3 RCTs94-96 N=465 | Study Limitations Imprecision | Insufficient
Cyclosporine to azathioprine | CMV infection | Inconclusive (RR: 3.35; 95% CI: 0.13–82.5) | 1 RCT96 N=120 | Study Limitations Imprecision | Insufficient
Cyclosporine to mycophenolic acid formulations | BPAR | Conversion to MPS associated with higher incidence of acute rejection (RR: 8.67; 95% CI: 1.14–65.9) | 1 RCTs90 N=103 | Imprecision | Moderate
Cyclosporine to mycophenolic acid formulations | Graft loss | Inconclusive (RR: 0.473, 95% CI: 0.09–2.50) | 1 RCT97 N=143 | Imprecision | Insufficient
Cyclosporine to mycophenolic acid formulations | Patient death | Inconclusive (too few events) (RR: 7.0, 95% CI: 0.36 to 133) | 1 RCT97 N=143 | Imprecision | Insufficient
Cyclosporine to mycophenolic acid formulations | CMV infection | Inconclusive (RR: 1.62; 95% CI: 0.20–12.9; I^2^=0%) | 2 RCTs90,97 N=256 | Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | BPAR | Inconclusive (RR: 13.76, 95% CI: 0.78–240) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | Graft loss | Inconclusive (no events) (0/84 vs. 0/89) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | Patient death | Inconclusive (RR: 0.35, 95% CI: 0.01–8.54) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | Renal function | Inconclusive (SMD: 0.31; 95% CI: -0.02–0.64) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | CMV infection | Inconclusive (too few events) (RR: 1.06, 95% CI: 0.15–7.35) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | BK infection | Inconclusive (too few events) (RR: 7.41, 95% CI: 0.39–141) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient
CNI (cyclosporine or tacrolimus) to Belatacept | Other infection | Inconclusive (RR: 1.06, 95% CI: 0.22–5.10) | 1 RCT98 N=173 | Study Limitations Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

a The primary difference between the outlier study and the other studies in this analysis was a delay in the addition of MMF among patients converted to SRL from CsA. The addition of MMF in the outlier study occurred 3-months postconversion and 6-months post-transplant. In the other studies, MMF or MPS were initiated immediately or shortly after renal transplantation.

Pooled analyses revealed substantial heterogeneity for renal function for both the overall CNI versus mTOR analysis (I^2^= 89%) and the CsA versus mTOR subanalysis (I^2^= 88%). When we removed the Barsoum et al. study from the analysis, the I^2^ for the overall CNI analysis dropped to 74 percent and to 14 percent in the CsA subanalysis.93 One primary difference between this study and the other studies in the analyses was a delay in the addition of MMF among patients converted to SRL from CsA. The addition of MMF among these patients occurred 3-months postconversion and 6-months post-transplant. In the other studies, MMF or MPS were initiated immediately or shortly after renal transplantation. This might explain why the between-group difference in eGFR was substantially higher in this study than the others.

The only other difference observed between patients converted to an mTOR inhibitor and those remaining on a CNI regimen was in the reported incidence of cytomegalovirus (CMV). High-strength evidence suggested that conversion to an mTOR inhibitor was associated with lower reported incidence of CMV (RR: 0.61; 95% CI: 0.38 to 0.98; I^2^=37%). This difference, however, was no longer present when the analysis was stratified by type of CNI (CsA vs. TAC). Finally, low-strength evidence indicated no difference between groups in the TAC subanalysis for graft loss. The evidence was insufficient for this outcome for the overall CNI analysis and for the CsA subanalysis. The evidence was also insufficient to draw any conclusions for incidence of BPAR, patient death, or other infection-related adverse events among patients converted to an mTOR and those remaining on a CNI regimen.

Similarly, evidence from three studies that evaluated conversion from CsA to AZA was insufficient to support conclusions for the outcomes of acute rejection, patient death, and incidence of infection.94-96 However, low-strength evidence from these studies did suggest that graft loss was similar among patients who converted to AZA and those who remained on CsA (RR: 0.84; 95% CI: 0.55–1.28, I^2^=0).

Moderate-strength evidence from one study in which patients were converted from CsA to MPS indicated a significantly higher risk of BPAR among patients converted to MPS.90 In this study, eight patients in the MPS group experienced an episode of acute rejection compared to only one patient in the CsA group (RR: 8.61; 95% CI: 1.14–65.9; p=0.04). The evidence was insufficient to permit conclusions for patient death, graft loss, or risk of infection among patients converted to MMF or MPS and those who remained on CsA.

Finally, the findings of one study in which patients were converted from CsA to belatacept showed a modest improvement in GFR among patients who converted to belatacept (60.5±11.01 mL/min/MDRD vs. 56.5±14.42 mL/min/MDRD; mean change from baseline 2.1±10.34, p<0.01). The evidence from this study was inconclusive for patient death, graft loss, or infection risk.

We did not conduct subgroup analyses of these studies to identify effects associated with induction agents. Induction therapy is expected to affect patient outcomes immediately after transplantation and shortly thereafter but is less likely to have an impact during the later timeframes when most studies initiated CNI conversion. Moreover, subgroups were too small for analysis due to heterogeneity and frequent nonreporting of induction therapy.

### Applicability

The applicability of the findings of the studies assessing conversion from a CNI to another immunosuppression regimen is limited due to lack of reporting about key patient characteristics such as race and exclusion of high-risk patients. Overall, 38 percent of the studies evaluating conversion did not report on race. Among those that did, the majority of the enrolled patients were male Caucasians. Thirteen studies (62%) excluded high-risk patients. This includes older patients (≥65 years of age) and patients who had a previous renal transplant. Overall, eight studies (38%) excluded patients aged 65 years or older, and six (28%) excluded patients who had a previous renal transplant.

### Summary

Overall, moderate-strength evidence indicated that conversion to an mTOR inhibitor was associated with modest improvement in renal function. The strength of evidence was high for the finding that conversion to an mTOR was associated with a decreased risk in the incidence of CMV infection. Finally, low-strength evidence suggests no difference in graft loss between patients remaining on TAC and those converting to an mTOR inhibitor or AZA. For BPAR, patient death, or incidence of other infection-related adverse events, the findings of our analyses were inconclusive due to study limitations and/or lack of precision. In general, the followup period in the majority of studies addressing conversion was relatively short (12 months) and limited primarily to low-risk patients.

## Withdrawal

### Description of Withdrawal Studies

Renal transplant patients on a CNI-based regimen may benefit from having CNI withdrawn while continuing alternative immunosuppression therapies. Withdrawal is different from conversion because the non-CNI immunosuppressive agent is included in the regimen before withdrawal, while conversion strategies do not introduce the alternative drug until discontinuation of the CNI.

Fifteen RCTs examined CNI withdrawal (Table 17). Nine studies included MMF as the primary alternative to CNI, and six studies used mTOR inhibitors. CsA was withdrawn in 10 studies (6 with MMF and 4 with SRL or EVR). TAC was withdrawn in two studies that used SRL. Three studies that used MMF combined data on patients receiving CsA or TAC. Seven studies included fewer than 100 patients, while the largest study enrolled 430 transplant recipients. Nine studies initiated withdrawal within 6 months following transplant, five studies withdrew CNI 6 months or more post-transplant, and one study began withdrawal between 2 and 16 months after renal transplant.

Table 17 Withdrawal studies

Reference | Withdrawn | Maintained | N, Intervention | N, Control
Mourer 2012^104^ | CNI | MMF | 79 | 79
Pascual 2008^100^ | CNI | MMF | 20 | 20
Suwelack 2004^105^ | CNI | MMF | 18 | 20
Asberg 2012^106^ | CsA | MMF | 20 | 19
Ekberg 2007a24 | CsA | MMF | 179 | 173
Hazzan 2006^101^ | CsA | MMF | 54 | 54
Abramowicz 2002^107^ | CsA | MMF | 85 | 85
Schnuelle 2002^103^ | CsA | MMF | 44 | 40
Smak Gregoor 2002^108^ | CsA | MMF | 63 | 149
Chadban 2014^23^ | CsA | EVR | 49 | 47
Stallone 2003^102^ | CsA | SRL | 20 | 20
Gonwa 2002^109^ | CsA | SRL | 100 | 97
Johnson 2001^110^ | CsA | SRL | 215 | 215
Flechner 2011^111^ | TAC | SRL | 152 | 139
Freitas 2011^112^ | TAC | SRL | 23 | 24

CNI = calcineurin inhibitor; CsA = cyclosporine; EVR = everolimus; MMF = mycophenolate mofetil; SRL = sirolimus; TAC = tacrolimus

Overall risk of bias was assessed as high for 10 of the withdrawal studies, moderate for 4 studies, and 1 study was at low risk of bias.100 Only 1 study declared funding support from a noncommercial source,101 2 studies did not disclose any funding information,102,103 and 12 of the 15 studies received funding from sources that could benefit financially from favorable study results.

### Key Points

- Withdrawal was associated with increased risk of acute rejection for patients maintained on mycophenolate acid formulations (Strength of Evidence: High) or mTOR inhibitors (Strength of Evidence: Moderate) compared to patients who remained on both a CNI and other adjunctive therapy.
- Risk of graft loss was higher when CNI was withdrawn from patients remaining on MMF (Strength of Evidence: Low) compared to patients maintained on both CNIs and MMF. The evidence for the outcome of graft loss was insufficient to support conclusions for studies that maintained patients on mTOR inhibitors after CNI withdrawal (Strength of Evidence: Insufficient) compared to patients who continued to receive both CNIs and mTOR inhibitors.
- Maintenance of MMF after CNI withdrawal was associated with improvement in renal function (Strength of Evidence: High) compared to continuation of both therapies.
- The evidence base is insufficient to support conclusions for the risk of infections in patients withdrawn from CNIs.

### Detailed Synthesis of Withdrawal Studies

Withdrawal of CNI therapy was associated with increased risk of BPAR, regardless of whether patients received MMF or mTOR inhibitors as the primary alternative immunosuppressive agent. High-strength evidence demonstrated a large magnitude of effect, with risk of rejection more than three times greater in patients maintained on MMF after CNI withdrawal compared with recipients continued on both MMF and CNI. A smaller but still significant effect was observed in regimens using mTOR inhibitors, with a relative risk of rejection greater than 1.7. Risk of graft loss was also higher when CNI was withdrawn from patients remaining on MMF based on low-strength evidence, but the evidence base was inconclusive for this outcome in studies that maintained patients on mTOR inhibitors after CNI withdrawal.

High-strength evidence also supported the finding that maintenance of MMF after CNI withdrawal was associated with improvement in renal function, but the evidence for eGFR was inconclusive for the subset of studies using CsA. Evidence for other outcomes, including infections and death, was insufficient to support conclusions.

Timing of withdrawal with respect to renal transplant was assessed in subgroup analyses of the nine studies that included MMF, since all six studies that used mTOR inhibitors used early withdrawal. Three studies initiated CNI withdrawal during the first 6-months post-transplant (designated “early withdrawal”), and five studies initiated withdrawal 6 months or later after transplant (“late withdrawal”). One study included both early and late withdrawal.100 Low-strength evidence was found for improved renal function in the late withdrawal subgroups. Early withdrawal was associated with higher risk of graft loss and death, and the evidence was insufficient to make conclusions for acute rejection and renal function. For studies of late withdrawal, maintenance of MMF after CNI withdrawal was associated with greater risk of acute rejection based on moderate-strength evidence. The evidence was insufficient to support any conclusions regarding infection outcomes in these subgroups.

We did not conduct subgroup analyses of these studies to identify effects associated with induction agents. As with conversion strategies, induction therapy is not expected to have a clinically significant impact during the later timeframes when most studies initiated CNI withdrawal. Moreover, subgroups were too small for analysis due to heterogeneity and frequent nonreporting of induction therapy.

### Applicability

The studies of CNI withdrawal have similar limits on applicability as described elsewhere. Nine of the 15 studies excluded patients who exceeded a defined PRA threshold. In 10 studies that reported patient race, at least 75 percent of participants were Caucasian. These studies are therefore most applicable to average- or low-risk patients. However, only one study excluded patients over 65 years old, and just one study excluded retransplants. Moreover, seven studies reported the proportion of patients who experienced DGF, which was present in at least 13 percent of intervention group patients in each study. Finally, 10 studies enrolled patients receiving CsA, three studies combined patients on either CsA or TAC, and only two studies focused exclusively on the use of TAC. Our findings may thus be more relevant to withdrawal of CsA than to withdrawal of TAC.

### Summary

High-strength evidence based on 15 RCTs indicates that CNI withdrawal is associated with greater risk of acute rejection for renal transplant recipients (Table 18). Moderate-strength evidence suggests that withdrawal may be associated with increased graft loss in patients maintained on MMF. Renal function may improve after withdrawal in some patients, and the evidence base is inconclusive for death and infection outcomes.

Table 18 Strength of evidence for withdrawal studies

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
CNI withdrawal + mycophenolate | Renal function | Withdrawal associated with improved renal function (SMD: 0.49; 95% CI: 0.26–0.72; I^2^=21%) | 5 RCTs24,100,103,104,113 N=742 | None | High
CNI withdrawal + mycophenolate | BPAR | Withdrawal associated with higher risk of rejection (RR: 3.17; 95% CI: 1.78–5.66; I^2^=46%) | 9 RCTs24,100,103-108,113 N=1,201 | None | High
CNI withdrawal + mycophenolate | Graft loss | Withdrawal associated with higher risk of graft loss (RR: 1.35; 95% CI: 0.80–2.26; I^2^=0) | 9 RCTs24,100,103-108,113 N=1,201 | Imprecision | Low
CNI withdrawal + mycophenolate | Patient death | No difference (RR: 0.99; 95% CI: 0.67 to 1.48; I^2^=0) | 8 RCTs24,100,103,104,106-108,113 N=1,163 | Imprecision | Low
CNI withdrawal + mycophenolate | CMV infection | Inconclusive (RR: 1.12; 95% CI: 0.39 to 3.21; I^2^=22%) | 5 RCTs24,100,103,105,108 N=726 | Imprecision | Insufficient
CNI withdrawal + mycophenolate | Other opportunistic infections | Inconclusive (RR: 0.73; 95% CI: 0.47–1.12; I^2^=35%) | 5 RCTs24,100,103,105,108 N=726 | Imprecision | Insufficient
Cyclosporine withdrawal + mycophenolate | Renal function | Inconclusive (SMD: 0.54; 95% CI: -0.07–1.15; I^2^=54%) | 3 RCTs24,103,113 N=544 | Study Limitations Imprecision Inconsistency | Insufficient
Cyclosporine withdrawal + mycophenolate | BPAR | Withdrawal associated with higher risk of rejection (RR: 3.23; 95% CI: 1.39–7.47; I^2^=60%) | 6 RCTs24,103,106-108,113 N=965 | Study Limitations Inconsistency | Low
Cyclosporine withdrawal + mycophenolate | Graft loss | Withdrawal associated with higher risk of graft loss (RR: 1.56; 95% CI: 0.95–2.54; I^2^=0) | 6 RCTs24,103,106-108,113 N=965 | Study Limitations Imprecision | Low
Cyclosporine withdrawal + mycophenolate | Patient death | Inconclusive (RR: 1.11; 95% CI: 0.66–1.87; I^2^=0) | 6 RCTs24,103,106-108,113 N=965 | Study Limitations Imprecision | Insufficient
Cyclosporine withdrawal + mycophenolate | CMV infection | Inconclusive (RR: 1.49; 95% CI: 0.26–8.62; I^2^=41%) | 3 RCTs24,103,108 N=648 | Imprecision | Insufficient
Cyclosporine withdrawal + mycophenolate | Other opportunistic infections | Inconclusive (RR: 0.73; 95% CI: 0.31–1.69; I^2^=54%) | 3 RCTs24,103,108 N=648 | Imprecision Inconsistency | Insufficient
Early withdrawal subgroup: CNI + mycophenolate | Renal function | Inconclusive (SMD: 0.54; 95% CI: -0.07–1.15; I^2^=54%) | 3 RCTs24,103,113 N=544 | Study Limitations Imprecision Inconsistency | Insufficient
Early withdrawal subgroup: CNI + mycophenolate | BPAR | Inconclusive (RR: 1.69; 95% CI: 0.59–4.85; I^2^=26%) | 3 RCTs24,103,113 N=544 | Study Limitations Imprecision | Insufficient
Early withdrawal subgroup: CNI + mycophenolate | Graft loss | Early withdrawal associated with higher risk of graft loss (RR: 1.34; 95% CI: 0.75–2.39; I^2^=0) | 3 RCTs24,103,113 N=544 | Study Limitations Imprecision | Low
Early withdrawal subgroup: CNI + mycophenolate | Patient death | Early withdrawal associated with higher risk of death (RR: 1.45; 95% CI: 0.87–2.40; I^2^=0) | 3 RCTs24,103,113 N=544 | Study Limitations Imprecision | Low
Early withdrawal subgroup: CNI + mycophenolate | CMV infection | Inconclusive (RR: 0.98; 95% CI: 0.04–21.99; I^2^=0) | 2 RCTs24,103 N=436 | Study Limitations Imprecision | Insufficient
Early withdrawal subgroup: CNI + mycophenolate | Other opportunistic infections | Inconclusive (RR: 0.60; 95% CI: 0.11–3.22; I^2^=0) | 2 RCTs24,103 N=436 | Study Limitations Imprecision | Insufficient
Late withdrawal subgroup: CNI + mycophenolate | Renal function | Late withdrawal associated with improved eGFR (61.1 vs. 52.9, p<0.01;^104^ 66 vs. 63, p=NS;107 increase of 4.5 mL/min, p=0.16^108^) | 3 RCTs104,107,108 N=540 | Imprecision | Low
Late withdrawal subgroup: CNI + mycophenolate | BPAR | Late withdrawal associated with higher risk of rejection (RR: 6.16; 95% CI: 3.11–12.21; I^2^=0) | 5 RCTs104-108 N=617 | Imprecision | Moderate
Late withdrawal subgroup: CNI + mycophenolate | Graft loss | Inconclusive (RR: 1.40; 95% CI: 0.33–5.95; I^2^=0) | 5 RCTs104-108 N=617 | Imprecision | Insufficient
Late withdrawal subgroup: CNI + mycophenolate | Patient death | Inconclusive (RR: 0.83; 95% CI: 0.37–1.83; I^2^=0) | 4 RCTs104,106-108 N=579 | Imprecision | Insufficient
Late withdrawal subgroup: CNI + mycophenolate | CMV infection | Inconclusive (RR: 0.83; 95% CI: 0.05–13.36; I^2^=80%) | 2 RCTs105,108 N=250 | Study Limitations Imprecision Inconsistency | Insufficient
Late withdrawal subgroup: CNI + mycophenolate | Other opportunistic infections | Inconclusive (RR: 0.98; 95% CI: 0.08–11.73; I^2^=0) | 2 RCTs105,108 N=250 | Study Limitations Imprecision | Insufficient
CNI withdrawal + mTOR inhibitors | Renal function | Inconclusive (SMD: 0.16; 95% CI: -0.25–0.57; I^2^=69%) | 5 RCTs23,102,110-112 N=904 | Study Limitations Imprecision Inconsistency | Insufficient
CNI withdrawal + mTOR inhibitors | BPAR | Withdrawal associated with higher risk of rejection (RR: 1.71; 95% CI: 1.19–2.45; I^2^=5%) | 6 RCTs23,102,109-112 N=1,101 | Study Limitations | Moderate
CNI withdrawal + mTOR inhibitors | Graft loss | Inconclusive (RR: 0.97; 95% CI: 0.45–2.09; I^2^=30%) | 6 RCTs23,102,109-112 N=1,101 | Study Limitations Imprecision | Insufficient
CNI withdrawal + mTOR inhibitors | Patient death | No difference (RR: 1.03; 95% CI: 0.64–1.66; I^2^=0) | 6 RCTs23,102,109-112 N=1,101 | Study Limitations Imprecision | Low
CNI withdrawal + mTOR inhibitors | CMV infection | Inconclusive (RR: 0.91; 95% CI: 0.01–119.68; I^2^=0) | 2 RCTs23,110 N=526 | Study Limitations Imprecision | Insufficient
CNI withdrawal + mTOR inhibitors | Other opportunistic infections | Inconclusive (RR: 0.68; 95% CI: 0.39–1.18; p=0.17) | 1 RCT110 N=430 | Study Limitations Imprecision | Insufficient
Cyclosporine withdrawal + mTOR inhibitors | Renal function | Inconclusive (SMD: 0.26; 95% CI: -0.71–1.23; I^2^=71%) | 3 RCTs23,102,110 N=566 | Study Limitations Imprecision Inconsistency | Insufficient
Cyclosporine withdrawal + mTOR inhibitors | BPAR | Withdrawal associated with higher risk of acute rejection (RR: 1.67; 95% CI: 0.87–3.22; I^2^=22%) | 4 RCTs23,102,109,110 N=763 | Study Limitations Imprecision | Low
Cyclosporine withdrawal + mTOR inhibitors | Graft loss | Withdrawal associated with lower risk of graft loss (RR: 0.64; 95% CI: 0.37–1.12; I^2^=0) | 4 RCTs23,102,109,110 N=763 | Study Limitations Imprecision | Low
Cyclosporine withdrawal + mTOR inhibitors | Patient death | Inconclusive (RR: 0.82; 95% CI: 0.39–1.74; I^2^=0) | 4 RCTs23,102,109,110 N=763 | Study Limitations Imprecision | Insufficient
Cyclosporine withdrawal + mTOR inhibitors | CMV infection | Inconclusive (RR: 0.91; 95% CI: 0.01–119.68; I^2^=0) | 2 RCTs23,110 N=526 | Study Limitations Imprecision | Insufficient
Cyclosporine withdrawal + mTOR inhibitors | Other opportunistic infections | Inconclusive (RR: 0.68; 95% CI: 0.39–1.18; p=0.17) | 1 RCT110 N=430 | Study Limitations Imprecision | Insufficient
Tacrolimus withdrawal + mTOR inhibitors | Renal function | Inconclusive (SMD: 0.00; 95% CI: -2.48–2.48; I^2^=43%) | 2 RCTs111,112 N=338 | Study Limitations Imprecision | Insufficient
Tacrolimus withdrawal + mTOR inhibitors | BPAR | Withdrawal associated with higher risk of rejection (RR: 1.93; 95% CI: 1.43–2.60; I^2^=0) | 2 RCTs111,112 N=338 | Study Limitations | Moderate
Tacrolimus withdrawal + mTOR inhibitors | Graft loss | Inconclusive (RR: 2.15; 95% CI: 0.29–16.01; I^2^=0) | 2 RCTs111,112 N=338 | Study Limitations Imprecision | Insufficient
Tacrolimus withdrawal + mTOR inhibitors | Patient death | Inconclusive (RR: 1.40; 95% CI: 0.31–6.19; I^2^=0) | 2 RCTs111,112 N=338 | Study Limitations Imprecision | Insufficient

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

BPAR=biopsy proven acute rejection; CI=confidence interval; CMV=cytomegalovirus; CNI=calcineurin inhibitor; eGFR=estimated glomerular filtration rate; mTOR=mammalian target of rapamycin; NS=not significant; RCT=randomized controlled trial; RR=relative risk; SMD=standardized mean difference

## Avoidance

### Description of Avoidance Studies

Another strategy to prevent CNI-associated toxicity is complete avoidance of CNI regimens. Immunosuppressive treatment based on SRL or belatacept has been studied in nine RCTs (Table 19). Sirolimus was used with MMF in five studies, with AZA in one study, and alone in one study. Six of the SRL studies were small and included fewer than 150 patients each, while 1 study included nearly 800 patients.4 Two large multinational trials, BENEFIT114 and BENEFIT-EXT,115 compared belatacept and MMF to CsA and MMF, with basiliximab induction in both groups. BENEFIT-EXT enrolled only extended criteria donors, who are typically associated with poorer clinical outcomes. Both BENEFIT studies included and compared more and less intensive schedules for administration of belatacept. We attempted to combine the BENEFIT studies for meta-analysis, but the results masked individual study effects and exhibited high heterogeneity, probably due to the differences in patient populations. Therefore, we report these two studies separately in the synthesis of results and the assessment of strength of evidence.

Table 19 Avoidance studies

Reference | Intervention | Control | Induction | N, Intervention | N, Control
Vincenti 2010^114^ | Belatacept, MMF | CsA, MMF | Basiliximab | 445 | 221
Durrbach 2010^115^ | Belatacept, MMF | CsA, MMF | Basiliximab | 359 | 184
Flechner 2002^116^ | SRL, MMF | CsA, MMF | Basiliximab | 31 | 30
Ekberg 2007b4 | SRL, MMF | CsA, MMF | Daclizumab (non-CNI arm) | 399 | 390
Asher 2013^117^ | SRL, MMF | TAC, MMF | Daclizumab | 19 | 19
Glotz 2010^118^ | SRL, MMF | TAC, MMF | rATG (non-CNI arm) | 71 | 70
Schaefer 2006^119^ | SRL, MMF | TAC, MMF | ATG | 41 | 78
Groth 1999^120^ | SRL, AZA | CsA, AZA | None used | 41 | 42
Refaie 2011^121^ | SRL | TAC | Alemtuzumab | 10 | 11

ATG = anti-thymocyte globulin; AZA = azathioprine; CNI = calcineurin inhibitor; CsA = cyclosporine; MMF = mycophenolate mofetil; r-ATG = rabbit anti-thymocyte globulin; SRL = sirolimus; TAC = tacrolimus

The seven remaining studies used SRL, but one did not use an induction agent while the others varied widely in choice of induction, including basiliximab, alemtuzumab, daclizumab, and ATG. The studies also differed in whether induction was used solely in the intervention arm or in the control arm as well.

Five of the avoidance studies were assessed to have moderate risk of bias, while four were categorized as high risk of bias. Adherence with treatment regimen was of particular concern as a threat to validity in these studies, as five of nine studies did not achieve at least 85-percent adherence. Six studies were funded by sources with a commercial interest in the outcome, while three studies did not report a funding source.

### Key Points

- The evidence base for these CNI avoidance regimens was small and mainly inconclusive.
- The studies were heterogeneous in their use of immunosuppressive therapies and induction agents.
- Belatacept was associated with improved renal function (Strength of Evidence: Moderate) and no difference in risk of graft loss or death (Strength of Evidence: Low) compared to use of CsA.
- Studies that used mTOR inhibitors and MMF instead of CNI were associated with improved renal function but higher risk of graft loss compared with tacrolimus regimens (Strength of Evidence: Low) and no difference in risk of graft loss compared with cyclosporine regimens (Strength of Evidence: Low). Results for the other outcomes were generally inconclusive.

### Detailed Synthesis of Avoidance Studies

Each BENEFIT study found that belatacept was associated with improved renal function based on moderate-strength evidence, and low-strength evidence suggested it was noninferior to CsA for the outcomes of graft loss and death (Table 20). The study that used standard-criteria donors also found that belatacept was associated with increased risk for acute rejection, while the study conducted with extended-criteria donors found that belatacept was noninferior to CsA for this outcome. These studies did not provide sufficient evidence to draw conclusions for the infection outcomes.

Table 20 Strength of evidence for avoidance studies

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | Renal function | Associated with improved eGFR (Less intensive belatacept regimen: SMD: 0.55; 95% CI: 0.36–0.74; p<0.001); more intensive belatacept regimen: SMD: 0.58; 95% CI: 0.39–0.77; p<0.001) | 1 RCT114,115 N=666 | Imprecision | Moderate
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | BPAR | Associated with increased risk of acute rejection (RR: 2.73; 95% CI: 1.64–4.54; p<0.001) | 1 RCT114,115 N=666 | Imprecision | Moderate
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | Graft loss | Belatacept noninferior to CsA (RR: 0.56; 95% CI: 0.22–1.43; p=0.22) | 1 RCT114,115 N=666 | Imprecision | Low
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | Patient death | Belatacept noninferior to CsA (RR: 0.71; 95% CI: 0.27–1.84; p=0.48) | 1 RCT114,115 N=666 | Imprecision | Low
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | CMV infection | Inconclusive (RR: 0.78; 95% CI: 0.45–1.36; p=0.39) | 1 RCT114,115 N=666 | Imprecision | Insufficient
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | BK infection | Inconclusive (RR: 0.72; 95% CI: 0.31–1.65; p=0.44) | 1 RCT114 N=666 | Imprecision | Insufficient
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with standard-criteria donors | Other opportunistic infections | Inconclusive (RR: 0.61; 95% CI: 0.33–1.14; p=0.12) | 1RCT114,115 N=666 | Imprecision | Insufficient
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | Renal function | More intensive belatacept regimen associated with improved eGFR (SMD: 0.32; 95% CI: 0.11 to 0.53; p<0.01); inconclusive for less intensive belatacept regimen (SMD: 0.18; 95% CI: -0.02–0.39; p=0.08) | 1 RCT115 N=543 | Imprecision | Moderate
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | BPAR | Belatacept noninferior to CsA (RR: 1.26; 95% CI: 0.83–1.92; p=0.28) | 1 RCT115 N=543 | Imprecision | Moderate
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | Graft loss | Belatacept noninferior to CsA (RR: 0.85; 95% CI: 0.50–1.43; p=0.53) | 1 RCT115 N=543 | Imprecision | Low
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | Patient death | Belatacept noninferior to CsA (RR: 0.77; 95% CI: 0.32–1.85; p=0.56) | 1 RCT115 N=543 | Imprecision | Low
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | CMV infection | Inconclusive (RR: 0.96; 95% CI: 0.61–1.53; p=0.87) | 1 RCT115 N=543 | Imprecision | Insufficient
Belatacept + MMF vs. CsA + MMF, with basiliximab induction in both groups, with extended-criteria donors | Other opportunistic infections | Inconclusive (RR: 0.51; 95% CI: 0.23–1.12; p=0.09) | 1 RCT115 N=543 | Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | Renal function | Inconclusive (SMD: 0.46; 95% CI: -0.53–1.45; I^2^=92%) | 2 RCT4,116 N=850 | Imprecision Inconsistency | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | BPAR | Inconclusive (RR: 0.93; 95% CI: 0.31–2.81; I^2^=58%) | 2 RCT4,116 N=850 | Imprecision Inconsistency | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | Graft loss | No difference (RR: 1.01; 95% CI: 0.64–1.59; I^2^=0) | 2 RCT4,116 N=850 | Imprecision | Low
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | Patient death | Inconclusive (RR: 0.96; 95% CI: 0.46–2.04; I^2^=0) | 2 RCT4,116 N=850 | Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | CMV infection | Inconclusive (RR: 0.58; 95% CI: 0.19–1.77; I^2^=49%) | 2 RCT4,116 N=850 | Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Cyclosporine + mycophenolate mofetil | Other opportunistic infections | Inconclusive (RR: 0.82; 95% CI: 0.56–1.21; p=0.32) | 1 RCT4 N=789 | Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | Renal function | Regimen associated with improved eGFR at 12 months (68 mL/min vs. 62 mL/min; p=0.06)118 and improved serum creatinine at 3 months (1.3 vs. 1.5, p=0.01)119 | 2 RCT118,119 N=260 | Study Limitations Imprecision | Low
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | BPAR | Inconclusive (RR: 1.61; 95% CI: 0.75–3.43; I^2^=0) | 3 RCT117-119 N=298 | Study Limitations Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | Graft loss | Regimen associated with higher risk of graft loss (RR: 3.40; 95% CI: 0.97-11.92; I^2^=0) | 3 RCT117-119 N=298 | Study Limitations Imprecision | Low
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | Patient death | Inconclusive (RR: 2.48; 95% CI: 0.27–22.87; I2=0) | 3 RCT117-119 N=298 | Study Limitations Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | CMV infection | Regimen associated with lower incidence of CMV (RR: 0.07; 95% CI: 0.01–0.52; p=0.009) | 1 RCT118 N=141 | Study Limitations Imprecision | Low
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | BK infection | Inconclusive (RR: 4.93; 95% CI: 0.24–100.89; p=0.30) | 1 RCT118 N=141 | Study Limitations Imprecision | Insufficient
mTOR inhibitors + mycophenolate mofetil vs. Tacrolimus + mycophenolate mofetil | Other opportunistic infections | Inconclusive (RR: 1.77; 95% CI: 0.63–5.03; p=0.28) | 1 RCT118 N=141 | Study Limitations Imprecision | Insufficient
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | Renal function | No difference (69.5±4.1 mL/min vs. 58.7±3.6 mL/min, p=NS) | 1 RCT120 N=83 | Imprecision | Moderate
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | BPAR | Inconclusive (RR: 1.09; 95% CI: 0.64–1.85; p=0.75) | 1 RCT120 N=83 | Imprecision | Insufficient
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | Graft loss | Inconclusive (RR: 0.26; 95% CI: 0.03–2.20; p=0.21) | 1 RCT120 N=83 | Imprecision | Insufficient
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | Patient death | Inconclusive (RR: 0.34; 95% CI: 0.01–8.14; p=0.51) | 1 RCT120 N=83 | Imprecision | Insufficient
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | CMV infection | Inconclusive (RR: 1.23; 95% CI: 0.41–3.72; p=0.71) | 1 RCT120 N=83 | Imprecision | Insufficient
mTOR inhibitors + azathioprine vs. Cyclosporine + azathioprine | Other opportunistic Infections | Associated with higher incidence of other infections (RR: 2.22; 95% CI: 0.93–5.28; p=0.07) | 1 RCT120 N=83 | Imprecision | Low
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | Renal function | SRL associated with improved renal function (1.83±0.88 mL/second vs. 1.38±0.48 mL/second, p<0.05) | 1 RCT121 N=21 | Study Limitations Imprecision | Low
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | BPAR | Inconclusive (RR: 0.44; 95% CI: 0.11–1.78; p=0.25) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | Graft loss | Inconclusive (RR: 2.20; 95% CI: 0.23–20.72; p=0.49) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | Patient death | Inconclusive (RR: 0.36; 95% CI: 0.02–8.03; p=0.52) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | BPAR | Inconclusive (RR: 0.44; 95% CI: 0.11–1.78; p=0.25) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | Graft loss | Inconclusive (RR: 2.20; 95% CI: 0.23–20.72; p=0.49) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient
mTOR inhibitors vs. Tacrolimus, with alemtuzumab induction in both groups | Patient death | Inconclusive (RR: 0.36; 95% CI: 0.02–8.03; p=0.52) | 1 RCT121 N=21 | Study Limitations Imprecision | Insufficient

AZA = azathioprine; BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; CsA = cyclosporine; eGFR = estimated glomerular filtration rate; MMF = mycophenolate mofetil; mTOR = mammalian target of rapamycin; NS = not significant; rATG = rabbit anti-thymocyte globulin; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference; SRL = sirolimus; TAC = tacrolimus

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

Two studies compared SRL to CSA, with MMF in both arms.4,116 SRL was associated with no difference in risk of graft loss, based on low-strength evidence. The evidence was insufficient to support conclusions for the other outcomes.

Three studies compared SRL to TAC, with MMF in both arms.117-119 SRL was associated with improved renal function and lower risk of CMV infection but a higher risk of graft loss, based on low-strength evidence. The evidence was insufficient to support conclusions for other outcomes.

Groth studied a regimen of SRL and AZA compared with CsA and AZA in 83 patients. Moderate- to low-strength evidence showed no difference in renal function or acute rejection and an increased risk of other opportunistic infections. The evidence was inconclusive for the outcomes of graft loss, death, and CMV infection.

Finally, a small study121 of 21 kidney recipients compared SRL to TAC, with alemtuzumab induction in both groups but no additional immunosuppressive therapy. Renal function as measured by creatinine clearance was observed to improve in the SRL group; the evidence base for other outcomes was insufficient to draw conclusions.

We did not conduct subgroup analyses of these studies to identify effects associated with induction agents. Although induction therapy could be important in explaining differences in patient outcomes in these studies, subgroups were too small for analysis.

### Applicability

The BENEFIT-EXT study is one of few studies included in this report that specifically enrolled patients at higher risk for poor clinical outcomes. The other eight studies were similar to those described in the sections on CNI minimization, conversion, and withdrawal. Four studies excluded patients based on a PRA threshold, four excluded older patients, and two excluded retransplants. These studies are generally applicable to average or low-risk renal transplant recipients but may be limited in their generalizability to other populations. As is the case in other sections of this report, the majority of studies (five of nine) used CsA rather than TAC as the CNI.

### Summary

Moderate- or low-strength evidence, based on a small number of heterogeneous studies, indicates that regimens that use belatacept or SRL from the time of transplantation are associated with few differences in clinical outcomes compared with standard-dose CNI regimens. Belatacept, however, was associated with increased risk of acute rejection compared to CsA, when used in recipients of standard-criteria donors.

## Head-to-Head Studies

### Description of Head-to-Head Studies

Nine studies directly compared a CNI minimization regimen to CNI conversion, withdrawal, or avoidance strategies (Table 21). These studies did not have a standard-dose CNI arm to serve as a conventional control group. Five studies compared minimization to conversion: two converted patients from low-dose CsA to SRL,122,123 one converted patients from low-dose TAC to SRL,124 and two converted subjects from low-dose CNI (CsA or TAC) to EVR125 or unspecified “rapamycin.”126 In addition to the studies comparing minimization to conversion, two studies compared low-dose TAC to withdrawal of TAC.127,128 Finally, two studies compared low-dose TAC to avoidance strategies based on SRL.129,130

Table 21 Head-to-head studies

Reference | Minimization | Other Intervention | N, Intervention | N, Control
Stallone 2005^126^ | CNI, MMF | Conversion to SRL | 50 | 34
Han 2011^122^ | CsA, MMF | Conversion to SRL, MMF | 29 | 22
Liu 2007^123^ | CsA, MMF | Conversion to SRL, MMF | 54 | 56
Pankewycz 2011^124^ | TAC, MPS | Conversion to SRL, MMF | 29 | 23
Cataneo-Davila 2009^125^ | CNI, EVR | Conversion to EVR | 10 | 10
Rivelli 2015^128^ | TAC, SRL | Withdrawal of TAC | 22 | 23
Burkhalter 2012^127^ | TAC, SRL, MPS | Withdrawal of TAC | 19 | 18
Hamdy 2005^129^ | TAC, SRL | Avoidance with SRL, MMF | 65 | 65
Lo 2004^130^ | TAC | Avoidance with SRL | 41 | 29

CNI = calcineurin inhibitor; CsA = cyclosporine; MMF = mycophenolate mofetil; MPS = mycophenolate sodium; SRL = sirolimus; TAC = tacrolimus

These studies differed from the previous sets of trials in population as well as design. Head-to-head studies were generally smaller than the other studies reviewed. Seven of the 9 studies (78%) enrolled fewer than 100 patients, while just 29 of the 79 studies (37%) addressing other regimens had populations of fewer than 100. The head-to-head studies also included populations at higher risk for poor outcomes. Four of the 9 head-to-head trials included only patients with chronic allograft nephropathy, while only 4 of the other 79 studies we reviewed (3 minimization studies and 1 withdrawal study) were limited to that population. Another of the head-to-head trials130 focused more generally on higher-risk participants, including a large proportion of African-American patients (71%), older patients (30% were older than 50 years old), and a large proportion of patients with delayed graft function (47%).

Seven studies were evaluated as high risk of bias, due to poor adherence to study regimens, low rates of study completion, industry funding, and failure to report important characteristics of study randomization and enrollment.

### Key Points

- Head-to-head studies were smaller and included more high-risk patients than other types of studies evaluated in this report.
- Two studies that compared a regimen of low-dose TAC and SRL to CNI avoidance using SRL and MMF found that the avoidance strategy was associated with better renal function (Strength of Evidence: Low). Results were inconclusive for other outcomes.
- One study that compared a regimen using low-dose CsA and MMF to a regimen that used conversion to an mTOR inhibitor found that the conversion regimen was associated with improved renal function (Strength of Evidence: Moderate) and reduced risk of graft loss (Strength of Evidence: Low).
- Additional direct comparative studies are needed to inform the evidence base.

### Detailed Synthesis of Head-to-Head Studies

Two studies that compared low-dose CsA with conversion from CsA to an mTOR inhibitor provided low-strength evidence suggesting that conversion was associated with improved renal function and lower risk of graft loss (Table 22).123,126 These two studies were inconclusive for the outcome of acute rejection. The other three conversion studies did not provide sufficient evidence to draw conclusions for any of the outcomes we assessed.125-127

Table 22 Strength of evidence for head-to-head studies

Comparison | Outcome | Conclusion | Quantity and Type of Evidence | Factors That Weaken the Strength of Evidence^*^ | Overall Evidence Strength
Reduced CNI + mycophenolate mofetil vs. Conversion from CNI to mTOR inhibitor | Renal function | Inconclusive (47 mL/min vs. 53 mL/min; p=0.22) | 1 RCT126 N=84 | Imprecision | Insufficient
Reduced CNI + mycophenolate mofetil vs. Conversion from CNI to mTOR inhibitor | BPAR | Inconclusive; no events observed | 1 RCT126 N=84 | Imprecision | Insufficient
Reduced CNI + mycophenolate mofetil vs. Conversion from CNI to mTOR inhibitor | Graft loss | Inconclusive (RR: 5.44; 95% CI: 0.71–41.53; p=0.10) | 1 RCT126 N=84 | Imprecision | Insufficient
Reduced CNI + mycophenolate mofetil vs. Conversion from CNI to mTOR inhibitor | Patient death | Inconclusive; no events observed | 1 RCT126 N=84 | Imprecision | Insufficient
Reduced cyclosporine + mycophenolate mofetil vs. Conversion from cyclosporine to mTOR inhibitor | Renal function | Conversion associated with improved renal function (one study reported higher eGFR in conversion group, p<0.05, data not available;123 one study reported eGFR: 37 mL/min for minimization vs. 50 mL/min for conversion; p<0.05^124^) | 2 RCT122,123 N=161 | Study Limitations | Moderate
Reduced cyclosporine + mycophenolate mofetil vs. Conversion from cyclosporine to mTOR inhibitor | BPAR | Inconclusive (RR: 0.76; 95% CI: 0.12–4.97; p=0.77) | 1 RCT123 N=51 | Study Limitations Imprecision | Insufficient
Reduced cyclosporine + mycophenolate mofetil vs. Conversion from cyclosporine to mTOR inhibitor | Graft loss | Conversion associated with reduced risk of graft loss (1 study reported “graft survival estimate” favoring conversion: 55% vs. 77%;123 1 study reported “graft survival ratio was markedly higher in conversion group”124) | 2 RCT122,123 N=161 | Study Limitations Imprecision | Low
Reduced tacrolimus + mycophenolate mofetil vs. Conversion from tacrolimus to mTOR inhibitor, with rATG induction | Renal function | Inconclusive (74 mL/min vs. 66 mL/min; p=0.09) | 1 RCT124 N=52 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mycophenolate mofetil vs. Conversion from tacrolimus to mTOR inhibitor, with rATG induction | BPAR | Inconclusive (RR: 0.27; 95% CI: 0.01–6.26; p=0.41) | 1 RCT124 N=52 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mycophenolate mofetil vs. Conversion from tacrolimus to mTOR inhibitor, with rATG induction | Graft loss | Inconclusive (RR: 0.27; 95% CI: 0.01–6.26; p=0.41) | 1 RCT124 N=52 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mycophenolate mofetil vs. Conversion from tacrolimus to mTOR inhibitor, with rATG induction | BK infection | Inconclusive (RR: 2.40; 95% CI: 0.10–56.30; p=0.59) | 1 RCT124 N=52 | Study Limitations Imprecision | Insufficient
Reduced CNI + mTOR inhibitors vs. Conversion from CNI to mTOR inhibitors + either mycophenolate mofetil or azathioprine | Renal function | Inconclusive (76 mL/min vs. 66 mL/min; p=0.26) | 1 RCT125 N=20 | Study Limitations Imprecision | Insufficient
Reduced CNI + mTOR inhibitors vs. Conversion from CNI to mTOR inhibitors + either mycophenolate mofetil or azathioprine | BPAR | Inconclusive (RR: 3.00; 95% CI: 0.14–65.90; p=0.49) | 1 RCT125 N=20 | Study Limitations Imprecision | Insufficient
Reduced CNI + mTOR inhibitors vs. Conversion from CNI to mTOR inhibitors + either mycophenolate mofetil or azathioprine | Graft loss | Inconclusive; no events observed | 1 RCT125 N=20 | Study Limitations Imprecision | Insufficient
Reduced CNI + mTOR inhibitors vs. Conversion from CNI to mTOR inhibitors + either mycophenolate mofetil or azathioprine | Patient death | Inconclusive; no events observed | 1 RCT125 N=20 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + mycophenolic sodium vs. Withdrawal of tacrolimus + mTOR inhibitors + mycophenolic sodium | Renal function | Inconclusive (52 mL/min vs. 45 mL/min; p=0.25) | 1 RCT127 N=37 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + mycophenolic sodium vs. Withdrawal of tacrolimus + mTOR inhibitors + mycophenolic sodium | BPAR | Inconclusive (RR: 0.47; 95% CI: 0.05l-4.78; p=0.53) | 1 RCT127 N=37 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Withdrawal of tacrolimus + mTOR inhibitors | Renal function | Minimization associated with lower CrCl compared to withdrawal (57.0 mL/min vs. 68.1 mL/min; p<0.05) | 1 RCT128 N=45 | Imprecision | Low
Reduced tacrolimus + mTOR inhibitors vs. Withdrawal of tacrolimus + mTOR inhibitors | BPAR | Inconclusive (RR: 1.05; 95% CI: 0.35l-3.12; p=0.94) | 1 RCT128 N=45 | Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Withdrawal of tacrolimus + mTOR inhibitors | Graft loss | Inconclusive (RR: 1.57; 95% CI: 0.29l-8.51; p=0.60) | 1 RCT128 N=45 | Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors vs. Withdrawal of tacrolimus + mTOR inhibitors | Patient death | Inconclusive (RR: 0.52; 95% CI: 0.05l-5.36; p=0.59) | 1 RCT128 N=45 | Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + basiliximab induction vs. mTOR inhibitors + mycophenolate mofetil + basiliximab induction | Renal function | Minimization associated with lower eGFR compared to avoidance (79.6 mL/min vs. 94.9 mL/min; p<0.05) | 1 RCT129 N=130 | Study Limitations Imprecision | Low
Reduced tacrolimus + mTOR inhibitors + basiliximab induction vs. mTOR inhibitors + mycophenolate mofetil + basiliximab induction | BPAR | Inconclusive (RR: 1.33; 95% CI: 0.60–2.95; p=0.48) | 1 RCT129 N=130 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + basiliximab induction vs. mTOR inhibitors + mycophenolate mofetil + basiliximab induction | Graft loss | Inconclusive (RR: 1.33; 95% CI: 0.31–5.72; p=0.70) | 1 RCT129 N=130 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + basiliximab induction vs. mTOR inhibitors + mycophenolate mofetil + basiliximab induction | Patient death | Inconclusive (RR: 5.00; 95% CI: 0.24–102.16; p=0.30) | 1 RCT129 N=130 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + basiliximab induction vs. mTOR inhibitors + mycophenolate mofetil + basiliximab induction | Other opportunistic Infections | Inconclusive (RR: 0.09; 95% CI: 0.01–1.61; p=0.10) | 1 RCT129 N=130 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + rATG induction vs. mTOR inhibitors + mycophenolate mofetil + rATG induction | Renal function | Minimization associated with lower eGFR compared to avoidance (52.9 mL/min vs. 72.4 mL/min; p<0.05) | 1 RCT130 N=70 | Study Limitations Imprecision | Low
Reduced tacrolimus + mTOR inhibitors + rATG induction vs. mTOR inhibitors + mycophenolate mofetil + rATG induction | BPAR | Inconclusive (RR: 1.41; 95% CI: 0.28–7.22; p=0.68) | 1 RCT130 N=70 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + rATG induction vs. mTOR inhibitors + mycophenolate mofetil + rATG induction | Graft loss | Inconclusive (RR: 1.89; 95% CI: 0.55–6.51; p=0.32) | 1 RCT130 N=70 | Study Limitations Imprecision | Insufficient
Reduced tacrolimus + mTOR inhibitors + rATG induction vs. mTOR inhibitors + mycophenolate mofetil + rATG induction | Patient death | Inconclusive (RR: 2.14; 95% CI: 0.09–50.82; p=0.64) | 1 RCT130 N=70 | Study Limitations Imprecision | Insufficient

BPAR = biopsy proven acute rejection; CI = confidence interval; CMV = cytomegalovirus; CNI = calcineurin inhibitor; eGFR = estimated glomerular filtration rate; mTOR = mammalian target of rapamycin; rATG = rabbit anti-thymocyte globulin; RCT = randomized controlled trial; RR = relative risk; SMD = standardized mean difference

* The following factors were assessed for potential effect on the strength of evidence: Study Limitations, Precision, Consistency, Directness, Reporting Bias.

Two studies comparing low-dose TAC to CNI avoidance with SRL found low-strength evidence that treatment with an mTOR inhibitor was associated with improved eGFR.129,130 Results were inconclusive for all other outcomes.

Rivelli et al.128 compared a regimen of low-dose TAC and SRL to a regimen that withdrew TAC while maintaining SRL. Renal function, as measured by creatinine clearance, was better in patients in the withdrawal arm than those who continued to receive TAC. However, this study was limited to 45 patients, and results for other outcomes were inconclusive.

Finally, Burkhalter et al.127 compared a regimen of low-dose TAC, SRL, and MPS to a regimen that maintained SRL and MPS while withdrawing TAC. The study did not provide conclusive findings at 6 months. After 1 year, SRL had been discontinued for most of the patients in both study groups due to adverse events.

### Applicability

As noted above, these studies were more likely than others in this report to include patients at higher risk for adverse outcomes. These studies are therefore potentially more relevant to important population subgroups. However, adherence to study groups and study completion rates was low in several studies, which may limit the generalizability of the results. Interestingly, five of the nine studies included TAC, two included CsA, and two combined patients on either CNI. These studies were the only ones we examined that focused primarily on TAC rather than CsA, and they may therefore have greater relevance to contemporary immunosuppressive treatment.

### Summary

We identified only nine RCTs that conducted head-to-head comparisons of CNI minimization with other alternative immunosuppressive regimens. Four studies reported improved renal function in patients who did not receive or were converted from CNI, and two studies found conversion was associated with lower risk of graft loss. This evidence base was not sufficient to support conclusions for the other comparisons and outcomes examined. Additional head-to-head studies are needed to further build the evidence base for the comparative effectiveness of CNI minimization versus other alternative immunosuppressive strategies.