# References

1 U.S. Organ Procurement and Transplantation Network (OPTN). Organ Procurement and Transplantation Network home page. Washington (D.C.). U.S. Organ Procurement and Transplantation Network (OPTN), U.S. Department of Health and Human Services (HHS). http://optn.transplant.hrsa.gov. 2013 Sep 05.
2 Matas AJ, Smith JM, Skeans MA, et al. OPTN/SRTR 2013 Annual Data Report: Kidney. Am J Transplant. Jan. Suppl 2. 2015;15:1-34. [pmid: 25626344].
3 Lamb KE, Lodhi L, Meier-Kriesche HU. Long term renal allograft survival in the United States: a critical reappraisal. Am J Transplant. 2011;11:450-62. [pmid: 20973913].
4 Ekberg H, Tedesco-Silva H, Demirbas A, et al. Reduced exposure to calcineurin inhibitors in renal transplantation. New Eng J Med. Dec. 20. 2007;357(25):2562-75. [pmid: 18094377].
5 Webster AI, Woodroffe RC, Taylor RS, et al. Tacrolimus versus cyclosporine as primary immunosuppression for kidney transplant recipients. Cochrane Database Syst Rev. Oct. 2005;19:4. CD003961.
6 Claes K, Meier-Kriesche HU, Schold JD, et al. Effect of different immunosuppressive regimens on the evolution of distinct metabolic parameters: evidence from the Symphony study. Nephrol Dial Transplant. Feb. 2012;27(2):850-7. [pmid: 21617197].
7 Almeida CC, Silveira MR, de Araujo VE, et al. Safety of immunosuppressive drugs used as maintenance therapy in kidney transplantation: a systematic review and meta-analysis. Pharmaceuticals. 2013;6(10):1170-94. [pmid: 24275847].
8 Soldin SJ, Steele BW, Witte DL, et al. Lack of specificity of cyclosporine immunoassays. Results of a College of American Pathologists Study. Arch Pathol Lab Med. Jan. 2003;127(1):19-22. [pmid: 12521361].
9 Wallemacq P, Armstrong VW, Brunet M, et al. Opportunities to optimize tacrolimus therapy in solid organ transplantation: report of the European consensus conference. Ther Drug Monit. Apr. 2009;31(2):139-52. http://dx.doi.org/10.1097/FTD.0b013e318198d092. [pmid: 19177031].
10 Kuypers DRJ, Claes K, Evenepoel P, et al. Time-related clinical determinants of long-term tacrolimus pharmacokinetics in combination therapy with mycophenolic acid and corticosteroids: a prospective study in one hundred de novo renal transplant recipients. Clin Pharmacokinet. 2004;43(11):741-62. http://dx.doi.org/10.2165/00003088-200443110-00005. [pmid: 15301578].
11 Bouamar R, Shuker N, Hesselink DA, et al. Tacrolimus predose concentrations do not predict the risk of acute rejection after renal transplantation: a pooled analysis from three randomized-controlled clinical trials. Am J Transplant. May. 2013;13(5):1253-61. [pmid: 23480233].
12 Knight SR, Morris PJ. The clinical benefits of cyclosporine C2-level monitoring: a systematic review. Transplantation. Jun. 27. 2007;83(12):1525-35. [pmid: 17589331].
13 Kim SJ, Prasad GV, Huang M, et al. A comparison of the effects of C2-cyclosporine and C0-tacrolimus on renal function and cardiovascular risk factors in kidney transplant recipients. Transplantation. 2006;82:924. [pmid: 17038908].
14 Moore J, Middleton L, Cockwell P, et al. Calcineurin inhibitor sparing with mycophenolate in kidney transplantation: a systematic review and meta-analysis. Transplantation. Feb. 27. 2009;87:591-605. [pmid: 19307799].
15 Montgomery RA, Lonze BE, King KE, et al. Desensitization in HLA-incompatible kidney recipients and survival. New Eng J Med. Jul. 28. 2011;365(4):318-26. [pmid: 21793744].
16 Hirsch HH, Vincenti F, Friman S, et al. Polyomavirus BK replication in de novo kidney transplant patients receiving tacrolimus or cyclosporine: a prospective, randomized, multicenter study. Am J Transplant. Jan. 2013;13(1):136-45. [pmid: 23137180].
17 Dharnidharka VR, Cherikh WS, Abbott KC. An OPTN analysis of national registry data on treatment of BK virus allograft nephropathy in the United States. Transplantation. Apr. 15. 2009;87(7):1019-26. [pmid: 19352121].
18 Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Evaluation frameworks and assessment of analytic validity. Methods research report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ publication no. 11-EHC048-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2011. Jun. 107 p.
19 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. AHRQ Publication No. 12-EGC047-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. Mar. 33 p. (Methods guide for comparative effectiveness reviews).
20 Hartung J, Knapp G. A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med. Dec. 30. 2001;20(24):3875-89. [pmid: 11782040].
21 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. Feb. 18. 2014;160(4):267-71. [pmid: 24727843].
22 Holdaas H, Rostaing L, Seron D, et al. Conversion of long-term kidney transplant recipients from calcineurin inhibitor therapy to everolimus: a randomized, multicenter, 24-month study. Transplantation. Aug. 27. 2011;92(4):410-8. [pmid: 21697773].
23 Chadban SJ, Eris JM, Kanellis J, et al. A randomized, controlled trial of everolimus-based dual immunosuppression versus standard of care in de novo kidney transplant recipients. Transpl Int. Mar. 2014;27(3):302-11. Epub 2014 Jan 6. [pmid: 24279685].
24 Ekberg H, Grinyo J, Nashan B, et al. Cyclosporine sparing with mycophenolate mofetil, daclizumab and corticosteroids in renal allograft recipients: the CAESAR study. Am J Transplant. Mar. 2007;7(3):560-70. [pmid: 17229079].
25 Borrows R, Chusney G, Loucaidou M, et al. Clinical outcomes of renal transplantation using liquid chromatographic monitoring of tacrolimus. Ther Drug Monit. Apr. 2006;28(2):269-73. [pmid: 16628143].
26 Leung EK, Yi X, Gloria C, et al. Clinical evaluation of the QMS(R) tacrolimus immunoassay. Clin Chim Acta. Apr. 20. 2014;431:270-5. [pmid: 24518359].
27 Shipkova M, Vogeser M, Ramos PA, et al. Multi-center analytical evaluation of a novel automated tacrolimus immunoassay. Clin Biochem. Aug. 2014;47(12):1069-77. Epub 2014 Apr 12. [pmid: 24721684].
28 Westley IS, Taylor PJ, Salm P, et al. Cloned enzyme donor immunoassay tacrolimus assay compared with high-performance liquid chromatography-tandem mass spectrometry and microparticle enzyme immunoassay in liver and renal transplant recipients. Ther Drug Monit. Oct. 2007;29(5):584-91. [pmid: 17898648].
29 Chan YH, Ho CS, Shek CC, et al. Measurement of whole blood tacrolimus level by high performance liquid chromatography tandem mass spectrometry in renal transplant recipients - a single center perspective. Hong Kong J Nephrol. 2005;7(2):65-9.
30 Butch AW, Fukuchi AM. Analytical performance of the CEDIA cyclosporine PLUS whole blood immunoassay. J Anal Toxicol. Apr. 2004;28(3):204-10. [pmid: 15107152].
31 Staatz CE, Taylor PJ, Tett SE. Comparison of an ELISA and an LC/MS/MS method for measuring tacrolimus concentrations and making dosage decisions in transplant recipients. Ther Drug Monit. Oct. 2002;24(5):607-15. [pmid: 12352932].
32 Hamwi A, Veitl M, Männer G, et al. Evaluation of four automated methods for determination of whole blood cyclosporine concentrations. Am J Clin Pathol. 1999;112(3):358-65. [pmid: 10478141].
33 Schütz E, Svinarov D, Shipkova M, et al. Cyclosporin whole blood immunoassays (AxSYM, CEDIA, and Emit): a critical overview of performance characteristics and comparison with HPLC. Clin Chem. Oct. 1998;44(10):2158-64. [pmid: 9761250].
34 Salm P, Taylor PJ, Clark A, et al. High-performance liquid chromatography-tandem mass spectrometry as a reference for analysis of tacrolimus to assess two immunoassays in patients with liver and renal transplants. Ther Drug Monit. Dec. 1997;19(6):694-700. [pmid: 9421113].
35 Roberts NB, Dutton J, Tewari A, et al. A method of relating whole blood cyclosporin A results by HPLC to Abbott TDx monoclonal and polyclonal immunoassays. Ann Clin Biochem. Mar. 1995;32(Pt 2):208-9. [pmid: 7785951].
36 Christians U, Vinks AA, Langman LJ, et al. Impact of laboratory practices on interlaboratory variability in therapeutic drug monitoring of immunosuppressive drugs. Ther Drug Monit. Dec. 2015;37(6):718-24. http://dx.doi.org/10.1097/FTD.0000000000000205. [pmid: 26291980].
37 Jirasiritham S, Mavichak V, Danviriyasup K, et al. Conversion of C-0 to C-2 monitoring of cyclosporine in stable kidney transplant patients. Transplant Proc. Feb. 2003;35(1):236-7. [pmid: 12591379].
38 Kyllonen LE, Salmela KT. Early cyclosporine C0 and C2 monitoring in de novo kidney transplant patients: A prospective randomized single-center pilot study. Transplantation. Apr. 2006;81(7):1010-5. [pmid: 16612277].
39 Paydas S, Balal M, Sertdemir Y, et al. Long-term comparative results of C(0) and C(2) monitoring of CyA in renal transplanted patients. Ren Fail. 2005;27(4):409-13. [pmid: 16060128].
40 Praditpornsilpa K, Avihingsanon Y, Nivatvong S, et al. Outcome of microemulsion cyclosporine C(2) concentration monitoring in kidney transplantation. Clin Transplant. Jun. 2005;19(3):335-9. [pmid: 15877794].
41 Birsan T, Loinig C, Bodingbauer M, et al. Comparison between C0 and C2 monitoring in de novo renal transplant recipients: retrospective analysis of a single-center experience. Transplantation. Dec. 27. 2004;78(12):1787-91. [pmid: 15614152].
42 Giese T, Zeier M, Meuer S. Analysis of NFAT-regulated gene expression in vivo: a novel perspective for optimal individualized doses of calcineurin inhibitors. Nephrol Dial Transplant. Jul. 2004;19(Suppl 4):iv55-60. [pmid: 15240851].
43 Vathsala A, Ona ET, Tan SY, et al. Randomized trial of alemtuzumab for prevention of graft rejection and preservation of renal function after kidney transplantation. Transplantation. Sep. 27. 2005;80(6):765-74. [pmid: 16210963].
44 Xu DL, Bai JM, Yu X, et al. Application of low-dose calcineurin inhibitors in living-related donor renal transplantation. J Clin Rehabil Tiss Eng Res. Apr. 2011;15(18):3417-20.
45 Gaston RS, Kaplan B, Shah T, et al. Fixed- or controlled-dose mycophenolate mofetil with standard- or reduced-dose calcineurin inhibitors: the opticept trial. Am J Transplant. Jul. 2009;9(7):1607-19. [pmid: 19459794].
46 Spagnoletti G, Citterio F, Favi E, et al. Cardiovascular risk profile in kidney transplant recipients treated with two immunosuppressive regimens: tacrolimus and mycophenolate mofetil versus everolimus and low-dose cyclosporine. Transplant Proc. May. 2009;41(4):1175-7. [pmid: 19460509].
47 Hernandez D, Miquel R, Porrini E, et al. Randomized controlled study comparing reduced calcineurin inhibitors exposure versus standard cyclosporine-based immunosuppression. Transplantation. Sep. 2007;84(6):706-14. [pmid: 17893603].
48 Tang SC, Chan KW, Tang CS, et al. Conversion of ciclosporin A to tacrolimus in kidney transplant recipients with chronic allograft nephropathy. Nephrol Dial Transplant. Nov. 2006;21(11):3243-51. Epub 2006 Jul 28. [pmid: 16877482].
49 Cai L, Zeng F, Liu B, et al. A single-centre, open-label, prospective study of an initially short-term intensified dosing regimen of enteric-coated mycophenolate sodium with reduced cyclosporine A exposure in Chinese live-donor kidney transplant recipients. Int J Clin Pract Suppl. Apr. 2014;(181):23-30. [pmid: 24673716].
50 Chadban S, Eris J, Russ G, et al. Enteric-coated mycophenolate sodium in combination with full dose or reduced dose cyclosporine, basiliximab and corticosteroids in Australian de novo kidney transplant patients. Nephrology (Carlton). Jan. 2013;18(1):63-70. [pmid: 23110508].
51 Etienne I, Toupance O, Benichou J, et al. A 50% reduction in cyclosporine exposure in stable renal transplant recipients: renal function benefits. Nephrol Dial Transplant. Sep. 2010;25(9):3096-106. [pmid: 20299336].
52 Fangmann J, Arns W, Marti HP, et al. Impact of daclizumab, low-dose cyclosporine, mycophenolate mofetil and steroids on renal function after kidney transplantation. Nephrol Dial Transplant. Jan. 2010;25(1):283-92. [pmid: 19773417].
53 Budde K, Bosmans JL, Sennesael J, et al. Reduced-exposure cyclosporine is safe and efficacious in de novo renal transplant recipients treated with enteric-coated mycophenolic acid and basiliximab. Clin Nephrol. Mar. 2007;67(3):164-75. [pmid: 17390741].
54 Cibrik D, Meierkriesche HU, Bresnahan B, et al. Renal function with cyclosporine C(2) monitoring, enteric-coated mycophenolate sodium and basiliximab: a 12-month randomized trial in renal transplant recipients. Clin Transplant. Mar-Apr. 2007;21(2):192-201. [pmid: 17425744].
55 Ghafari A, Makhdoomi K, Ahmadpour P, et al. Low-dose versus high-dose cyclosporine induction protocols in renal transplantation. Transplant Proc. May. 2007;39(4):1219-22. [pmid: 17524937].
56 Frimat L, Cassuto-Viguier E, Charpentier B, et al. Impact of cyclosporine reduction with MMF: a randomized trial in chronic allograft dysfunction. the ‘reference’ study. Am J Transplant. Nov. 2006;6(11):2725-34. [pmid: 17049060].
57 Frimat L, Cassuto-Viguier E, Provot F, et al. Long-term impact of cyclosporin reduction with MMF treatment in chronic allograft dysfunction: REFERENECE study 3-year follow up. J Transplant. 2010;2010:11. [pmid: 20706667].
58 Stoves J, Newstead CG, Baczkowski AJ, et al. A randomized controlled trial of immunosuppression conversion for the treatment of chronic allograft nephropathy. Nephrol Dial Transplant. Aug. 2004;19(8):2113-20. [pmid: 15161956].
59 Pascual M, Curtis J, Delmonico FL, et al. A prospective, randomized clinical trial of cyclosporine reduction in stable patients greater than 12 months after renal transplantation. Transplantation. May. 15. 2003;75(9):1501-5. [pmid: 12792504].
60 De Sevaux RG, Smak Gregoor PJ, Hene RJ, et al. A controlled trial comparing two doses of cyclosporine in conjunction with mycophenolate mofetil and corticosteroids. J Am Soc Nephrol. 2001;12(8):1750-7. [pmid: 11461949].
61 Chan L, Andres A, Bunnapradist S, et al. Renal function and NODM in de novo renal transplant recipients treated with standard and reduced levels of tacrolimus in combination with EC-MPS. J Transplant. 2012;2012:9. [pmid: 23227307].
62 Kamar N, Rostaing L, Cassuto E, et al. A multicenter, randomized trial of increased mycophenolic acid dose using enteric-coated mycophenolate sodium with reduced tacrolimus exposure in maintenance kidney transplant recipients. Clin Nephrol. 2012;77(2):126-36. [pmid: 22257543].
63 Bolin P, Shihab FS, Mulloy L, et al. Optimizing tacrolimus therapy in the maintenance of renal allografts: 12-month results. Transplantation. Jul. 15. 2008;86(1):88-95. [pmid: 18622283].
64 Muhlbacher F, Neumayer HH, del Castillo D, et al. The efficacy and safety of cyclosporine reduction in de novo renal allograft patients receiving sirolimus and corticosteroids: results from an open-label comparative study. Transpl Int. Feb. 2014;27(2):176-86. [pmid: 24266855].
65 Cibrik D, Silva HT Jr, Vathsala A, et al. Randomized trial of everolimus-facilitated calcineurin inhibitor minimization over 24 months in renal transplantation. Transplantation. Apr. 15. 2013;95(7):933-42. [pmid: 23422495].
66 Takahashi K, Uchida K, Yoshimura N, et al. Efficacy and safety of concentration-controlled everolimus with reduced-dose cyclosporine in Japanese de novo renal transplant patients: 12-month results. Transplant Res. Jul. 16. 2013;2(1):14. [pmid: 23866828].
67 Oh CK, Huh KH, Ha J, et al. Safety and efficacy of the early introduction of everolimus with reduced-exposure cyclosporine A in de novo kidney recipients. Transplantation. Jan. 15. 2015;99(1):180-6. [pmid: 24983307].
68 Paoletti E, Marsano L, Bellino D, et al. Effect of everolimus on left ventricular hypertrophy of de novo kidney transplant recipients: a 1 year, randomized, controlled trial. Transplantation. Mar. 15. 2012;93(5):503-8. [pmid: 22318246].
69 Bertoni E, Larti A, Rosso G, et al. Good outcomes with cyclosporine very low exposure with everolimus high exposure in renal transplant patients. J Nephrol. Sep-Oct. 2011;24(5):613-8. [pmid: 21240873].
70 Salvadori M, Scolari MP, Bertoni E, et al. Everolimus with very low-exposure cyclosporine A in de novo kidney transplantation: a multicenter, randomized, controlled trial. Transplantation. Nov. 2009;88(10):1194-202. [pmid: 19935373].
71 Nashan B, Curtis J, Ponticelli C, et al. Everolimus and reduced-exposure cyclosporine in de novo renal-transplant recipients: a three-year phase II, randomized, multicenter, open-label study. Transplantation. Nov. 15. 2004;78(9):1332-40. [pmid: 15548972].
72 Bechstein WO, Paczek L, Wramner L, et al. A comparative, randomized trial of concentration-controlled sirolimus combined with reduced-dose tacrolimus or standard-dose tacrolimus in renal allograft recipients. Transplant Proc. Jul-Aug. 2013;45(6):2133-40. [pmid: 23953523].
73 Langer RM, Hene R, Vitko S, et al. Everolimus plus early tacrolimus minimization: a phase III, randomized, open-label, multicentre trial in renal transplantation. Transpl Int. May. 2012;25(5):592-602. [pmid: 22471345].
74 Chan L, Greenstein S, Hardy MA, et al. Multicenter, randomized study of the use of everolimus with tacrolimus after renal transplantation demonstrates its effectiveness. Transplantation. Mar. 2008;85(6):821-6. [pmid: 18360262].
75 Lo A, Egidi MF, Gaber LW, et al. Observations regarding the use of sirolimus and tacrolimus in high-risk cadaveric renal transplantation. Clin Transplant. Feb. 2004;18(1):53-61. [pmid: 15108771].
76 Kuzniar J, Marchewka Z, Krasnowski R, et al. Enzymuria and low molecular weight protein excretion as the differentiating marker of complications in the early post kidney transplantation period. Int Urol Nephrol. Dec. 2006;38(3):753-8. [pmid: 17160449].
77 Bansal D, Yadav AK, Kumar V, et al. Deferred pre-emptive switch from calcineurin inhibitor to sirolimus leads to improvement in GFR and expansion of T regulatory cell population: a randomized, controlled trial. PLoS ONE. Oct. 11. 2013;8(10):e75591. [pmid: 24146762].
78 Budde K, Lehner F, Sommerer C, et al. Conversion from cyclosporine to everolimus at 4.5 months posttransplant: 3-year results from the randomized ZEUS study. Am J Transplant. Jun. 2012;12(6):1528-40. [pmid: 22642473].
79 Watson CJ, Firth J, Williams PF, et al. A randomized controlled trial of late conversion from CNI-based to sirolimus-based immunosuppression following renal transplantation. Am J Transplant. Oct. 2005;5(10):2496-503. [pmid: 16162200].
80 Budde K, Rath T, Sommerer C, et al. Renal, efficacy and safety outcomes following late conversion of kidney transplant patients from calcineurin inhibitor therapy to everolimus: The randomized APOLLO study. Clin Nephrol. 2015;83(1):11-21. [pmid: 25512099].
81 Weir MR, Mulgaonkar S, Chan L, et al. Mycophenolate mofetil-based immunosuppression with sirolimus in renal transplantation: a randomized, controlled spare-the-nephron trial. Kidney Int. Apr. 2011;79(8):897-907. [pmid: 21191361].
82 Schena FP, Pascoe MD, Alberu J, et al. Conversion from calcineurin inhibitors to sirolimus maintenance therapy in renal allograft recipients: 24-month efficacy and safety results from the CONVERT trial. Transplantation. Jan. 27. 2009;87(2):233-42. [pmid: 19155978].
83 Chhabra D, Alvarado A, Dalal P, et al. Impact of calcineurin-inhibitor conversion to mTOR inhibitor on renal allograft function in a prednisone-free regimen. Am J Transplant. Nov. 2013;13(11):2902-11. [pmid: 24007570].
84 Silva HT Jr, Felipe CR, Garcia VD, et al. Planned randomized conversion from tacrolimus to sirolimus-based immunosuppressive regimen in de novo kidney transplant recipients. Am J Transplant. Dec. 2013;13(12):3155-63. [pmid: 24266969].
85 Heilman RL, Younan K, Wadei HM, et al. Results of a prospective randomized trial of sirolimus conversion in kidney transplant recipients on early corticosteroid withdrawal. Transplantation. Oct. 15. 2011;92(7):767-73. [pmid: 21775930].
86 Rostaing L, Hertig A, Albano L, et al. Fibrosis progression according to epithelial-mesenchymal transition profile: A randomized trial of everolimus versus CsA. Am J Transplant. May. 1. 2015;15(5):1303-12. [pmid: 25808994].
87 Mjornstedt L, Sorensen SS, Von Zur Muhlen B, et al. Improved renal function after early conversion from a calcineurin inhibitor to everolimus: a randomized trial in kidney transplantation. Am J Transplant. Oct. 2012;12(10):2744-53. [pmid: 22812414].
88 Nafar M, Alipour B, Ahmadpoor P, et al. Sirolimus versus calcineurin inhibitor-based immunosuppressive therapy in kidney transplantation: a 4-year follow-up. Iran J Kidney Dis. 2012;6(4):300-6. [pmid: 22797101].
89 Guba M, Pratschke J, Hugo C, et al. Renal function, efficacy, and safety of sirolimus and mycophenolate mofetil after short-term calcineurin inhibitor-based quadruple therapy in de novo renal transplant patients: one-year analysis of a randomized multicenter trial. Transplantation. Jul. 27. 2010;90(2):175-83. [pmid: 20463641].
90 Bemelman FJ, De Maar EF, Press RR, et al. Minimization of maintenance immunosuppression early after renal transplantation: an interim analysis. Transplantation. Aug. 15. 2009;88(3):421-8. [pmid: 19667948].
91 Lebranchu Y, Thierry A, Toupance O, et al. Efficacy on renal function of early conversion from cyclosporine to sirolimus 3 months after renal transplantation: concept study. Am J Transplant. May. 2009;9(5):1115-23. [pmid: 19422337].
92 Durrbach A, Rostaing L, Tricot L, et al. Prospective comparison of the use of sirolimus and cyclosporine in recipients of a kidney from an expanded criteria donor. Transplantation. Feb. 15. 2008;85(3):486-90. [pmid: 18301342].
93 Barsoum RS, Morsy AA, Iskander IR, et al. The Cairo kidney center protocol for rapamycin-based sequential immunosuppression in kidney transplant recipients: 2-year outcomes. Exp Clin Transplant. 2007;5(2):649-57. [pmid: 18194116].
94 Bakker RC, Hollander AA, Mallat MJ, et al. Conversion from cyclosporine to azathioprine at three months reduces the incidence of chronic allograft nephropathy. Kidney Int. Sep. 1. 2003;64(3):1027-34. [pmid: 12911553].
95 MacPhee IA, Bradley JA, Briggs JD, et al. Long-term outcome of a prospective randomized trial of conversion from cyclosporine to azathioprine treatment one year after renal transplantation. Transplantation. Nov. 15. 1998;66(9):1186-92. [pmid: 9825816].
96 Hilbrands LB, Hoitsma AJ, Koene RA. The effect of immunosuppressive drugs on quality of life after renal transplantation. Transplantation. 1995;59(9):1263-70. [pmid: 7762059].
97 Dudley C, Pohanka E, Riad H, et al. Mycophenolate mofetil substitution for cyclosporine A in renal transplant recipients with chronic progressive allograft dysfunction: the “creeping creatinine” study. Transplantation. Feb. 27. 2005;79(4):466-75. [pmid: 15729174].
98 Rostaing L, Massari P, Garcia VD, et al. Switching from calcineurin inhibitor-based regimens to a belatacept-based regimen in renal transplant recipients: a randomized phase II study. Clin J Am Soc Nephrol. Feb. 1. 2011;6(2):430-9. [pmid: 21051752].
99 Budde K, Becker T, Arns W, et al. Everolimus-based, calcineurin-inhibitor-free regimen in recipients of de-novo kidney transplants: an open-label, randomised, controlled trial. Lancet. Mar. 5. 2011;377(9768):837-47. [pmid: 21334736].
100 Pascual J, Bloom D, Torrealba J, et al. Calcineurin inhibitor withdrawal after renal transplantation with alemtuzumab: clinical outcomes and effect on T-regulatory cells. Am J Transplant. Jul. 2008;8(7):1529-36. [pmid: 18510645].
101 Hazzan M, Buob D, Labalette M, et al. Assessment of the risk of chronic allograft dysfunction after renal transplantation in a randomized cyclosporine withdrawal trial. Transplantation. Sep. 2006;82(5):657-62. [pmid: 16969289].
102 Stallone G, Di Paolo S, Schena A, et al. Early withdrawal of cyclosporine A improves 1-year kidney graft structure and function in sirolimus-treated patients. Transplantation. Apr. 15. 2003;75(7):998-1003. [pmid: 12698087].
103 Schnuelle P, Van Der Heide JH, Tegzess A, et al. Open randomized trial comparing early withdrawal of either cyclosporine or mycophenolate mofetil in stable renal transplant recipients initially treated with a triple drug regimen. J Am Soc Nephrol. 2002;13(2):536-43. [pmid: 11805185].
104 Mourer JS, Hartigh JD, Van Zwet EW, et al. Randomized trial comparing late concentration-controlled calcineurin inhibitor or mycophenolate mofetil withdrawal. Transplantation. May. 15. 2012;93(9):887-94. [pmid: 22538450].
105 Suwelack B, Gerhardt U, Hohage H. Withdrawal of cyclosporine or tacrolimus after addition of mycophenolate mofetil in patients with chronic allograft nephropathy. Am J Transplant. Apr. 2004;4(4):655-62. [pmid: 15023160].
106 Asberg A, Apeland T, Reisaeter AV, et al. Long-term outcomes after cyclosporine or mycophenolate withdrawal in kidney transplantation - results from an aborted trial. Clin Transplant. Mar-Apr. 2013;27(2):E151-6. Epub 2013 Jan 27. [pmid: 23351013].
107 Abramowicz D, Manas D, Lao M, et al. Cyclosporine withdrawal from a mycophenolate mofetil-containing immunosuppressive regimen in stable kidney transplant recipients: a randomized, controlled study. Transplantation. Dec. 27. 2002;74(12):1725-34. [pmid: 12499889].
108 Smak Gregoor PJ, De Sevaux RG, Ligtenberg G, et al. Withdrawal of cyclosporine or prednisone six months after kidney transplantation in patients on triple drug therapy: a randomized, prospective, multicenter study. J Am Soc Nephrol. 2002;13(5):1365-73. [pmid: 11961025].
109 Gonwa TA, Hricik DE, Brinker K, et al. Improved renal function in sirolimus-treated renal transplant patients after early cyclosporine elimination. Transplantation. Dec. 15. 2002;74(11):1560-7. [pmid: 12490789].
110 Johnson RW, Kreis H, Oberbauer R, et al. Sirolimus allows early cyclosporine withdrawal in renal transplantation resulting in improved renal function and lower blood pressure. Transplantation. Sep. 15. 2001;72(5):777-86. [pmid: 11571437].
111 Flechner SM, Glyda M, Cockfield S, et al. The ORION study: comparison of two sirolimus-based regimens versus tacrolimus and mycophenolate mofetil in renal allograft recipients. Am J Transplant. Aug. 2011;11(8):1633-44. [pmid: 21668635].
112 De Sandes Freitas TV, Harada KM, Felipe CR, et al. Steroid or tacrolimus withdrawal in renal transplant recipients using sirolimus. Int Urol Nephrol. Dec. 2011;43(4):1221-8. [pmid: 21761129].
113 Hazzan M, Labalette M, Copin MC, et al. Predictive factors of acute rejection after early cyclosporine withdrawal in renal transplant recipients who receive mycophenolate mofetil: results from a prospective, randomized trial. J Am Soc Nephrol. 2005;16(8):2509-16. [pmid: 15987748].
114 Vincenti F, Charpentier B, Vanrenterghem Y, et al. A phase III study of belatacept-based immunosuppression regimens versus cyclosporine in renal transplant recipients (BENEFIT Study). Am J Transplant. Mar. 2010;10(3):535-46. [pmid: 20415897].
115 Durrbach A, Pestana JM, Pearson T, et al. A phase III study of belatacept versus cyclosporine in kidney transplants from extended criteria donors (BENEFIT-EXT Study). Am J Transplant. Mar. 2010;10(3):547-57. [pmid: 20415898].
116 Flechner SM, Goldfarb D, Modlin C, et al. Kidney transplantation without calcineurin inhibitor drugs: a prospective, randomized trial of sirolimus versus cyclosporine. Transplantation. Oct. 27. 2002;74(8):1070-6. [pmid: 12438948].
117 Asher J, Vasdev N, Wyrley-Birch H, et al. A prospective randomised paired trial of sirolimus versus tacrolimus as primary immunosuppression following non-heart beating donor kidney transplantation. Curr Urol. Nov. 19. 2014;7(4):174-80. [pmid: 26195946].
118 Glotz D, Charpentier B, Abramovicz D, et al. Thymoglobulin induction and sirolimus versus tacrolimus in kidney transplant recipients receiving mycophenolate mofetil and steroids. Transplantation. Jun. 27. 2010;89(12):1511-7. [pmid: 20386144].
119 Schaefer HM, Kizilisik AT, Feurer I, et al. Short-term results under three different immunosuppressive regimens at one center. Transplant Proc. Dec. 2006;38(10):3466-7. [pmid: 17175305].
120 Groth CG, Backman L, Morales JM, et al. Sirolimus (rapamycin)-based therapy in human renal transplantation: similar efficacy and different toxicity compared with cyclosporine. Transplantation. Apr. 15. 1999;67(7):1036-42. [pmid: 10221490].
121 Refaie AF, Mahmoud KM, Ismail AM, et al. Alemtuzumab preconditioning allows steroid-calcineurin inhibitor-free regimen in live-donor kidney transplant. Exp Clin Transplant. Oct. 2011;9(5):295-301. [pmid: 21967254].
122 Han F, Wu J, Huang H, et al. Conversion from cyclosporine to sirolimus in chronic renal allograft dysfunction: a 4-year prospective study. Exp Clin Transplant. Feb. 2011;9(1):42-9. [pmid: 21605022].
123 Liu M, Zhang W, Gu M, et al. Protective effects of sirolimus by attenuating connective tissue growth factor expression in human chronic allograft nephropathy. Transplant Proc. Jun. 2007;39(5):1410-5. [pmid: 17580150].
124 Pankewycz O, Leca N, Kohli R, et al. Conversion to low-dose tacrolimus or rapamycin 3 months after kidney transplantation: a prospective, protocol biopsy-guided study. Transplant Proc. Mar. 2011;43(2):519-23. [pmid: 21440749].
125 Cataneo-Davila A, Zuniga-Varga J, Correa-Rotter R, et al. Renal function outcomes in kidney transplant recipients after conversion to everolimus-based immunosuppression regimen with CNI reduction or elimination. Transplant Proc. Dec. 2009;41(10):4138-46. [pmid: 20005355].
126 Stallone G, Infante B, Schena A, et al. Rapamycin for treatment of chronic allograft nephropathy in renal transplant patients. J Am Soc Nephrol. 2005;16(12):3755-62. [pmid: 16236802].
127 Burkhalter F, Oettl T, Descoeudres B, et al. High incidence of rejection episodes and poor tolerance of sirolimus in a protocol with early steroid withdrawal and calcineurin inhibitor-free maintenance therapy in renal transplantation: experiences of a randomized prospective single-center study. Transplant Proc. Dec. 2012;44(10):2961-5. [pmid: 23195006].
128 Rivelli RF, Goncalves RT, Leite M, et al. Early withdrawal of calcineurin inhibitor from a sirolimus-based immunosuppression stabilizes fibrosis and the transforming growth factor-(beta) signalling pathway in kidney transplant. Nephrology (Carlton). Mar. 1. 2015;20(3):168-76. [pmid: 25404086].
129 Hamdy AF, El Agroudy AE, Bakr MA, et al. Comparison of sirolimus with low-dose tacrolimus versus sirolimus-based calcineurin inhibitor-free regimen in live donor renal transplantation. Am J Transplant. Oct. 2005;5(10):2531-8. [pmid: 16162204].
130 Lo A, Egidi MF, Gaber LW, et al. Comparison of sirolimus-based calcineurin inhibitor-sparing and calcineurin inhibitor-free regimens in cadaveric renal transplantation. Transplantation. Apr. 27. 2004;77(8):1228-35. [pmid: 15114090].
131 Levine DM, Maine GT, Armbruster DA, et al. The need for standardization of tacrolimus assays. Clin Chem. Dec. 2011;57(12):1739-47. http://dx.doi.org/10.1373/clinchem.2011.172080. [pmid: 21998339].
132 Morris RG, Holt DW, Armstrong VW, et al. Analytic aspects of cyclosporine monitoring, on behalf of the IFCC/IATDMCT Joint Working Group. Ther Drug Monit. Apr. 2004;26(2):227-30. [pmid: 15228170].
133 Su L, Tam N, Deng R, et al. Everolimus-based calcineurin-inhibitor sparing regimens for kidney transplant recipients: a systematic review and meta-analysis. Int Urol Nephrol. Oct. 2014;46(10):2035-44. Epub 2014 Jul 16. [pmid: 25027805].
134 Yan HL, Zong HT, Cui YS, et al. Calcineurin inhibitor avoidance and withdrawal for kidney transplantation: a systematic review and meta-analysis of randomized controlled trials. Transplant Proc. Jun. 2014;46(5):1302-13. [pmid: 24935293].
135 Bai H, Qian Y, Shi B, et al. Effectiveness and safety of calcineurin inhibitor withdrawal in kidney transplantation: a meta-analysis of randomized controlled trials. Clin Exp Nephrol. Dec. 2015;19(6):1189-98. Epub 2015 Mar 29. http://dx.doi.org/10.1007/s10157-015-1109-z. [pmid: 25820574].
136 Lim WH, Eris J, Kanellis J, et al. A systematic review of conversion from calcineurin inhibitor to mammalian target of rapamycin inhibitors for maintenance immunosuppression in kidney transplant recipients. Am J Transplant. Sep. 2014;14(9):2106-19. Epub 2014 Aug 1. [pmid: 25088685].
137 Knoll GA, Kokolo MB, Mallick R, et al. Effect of sirolimus on malignancy and survival after kidney transplantation: systematic review and meta-analysis of individual patient data. BMJ. 2014;349:g6679. [pmid: 25422259].
138 Kuypers DR, Le Meur Y, Cantarovich M, et al. Consensus report on therapeutic drug monitoring of mycophenolic acid in solid organ transplantation. Clin J Am Soc Nephrol. Feb. 2010;5(2):341-58. http://dx.doi.org/10.2215/CJN.07111009. [pmid: 20056756].
139 van Gelder T. Therapeutic drug monitoring for mycophenolic acid is value for (little) money. Clin Pharmacol Ther. Aug. 2011;90(2):203-4. http://dx.doi.org/10.1038/clpt.2011.96. [pmid: 21772294].
140 Le Meur Y, Buchler M, Thierry A, et al. Individualized mycophenolate mofetil dosing based on drug exposure significantly improves patient outcomes after renal transplantation. Am J Transplant. Nov. 2007;7(11):2496-503. http://dx.doi.org/10.1111/j.1600-6143.2007.01983.x. [pmid: 17908276].
141 Van Gelder T, Silva HT, De Fijter JW, et al. Comparing mycophenolate mofetil regimens for de novo renal transplant recipients: the fixed-dose concentration-controlled trial. Transplantation. Oct. 27. 2008;86(8):1043-51. http://dx.doi.org/10.1097/TP.0b013e318186f98a. [pmid: 18946341].
142 Daher Abdi Z, Prémaud A, Essig M, et al. Exposure to mycophenolic acid better predicts immunosuppressive efficacy than exposure to calcineurin inhibitors in renal transplant patients. Clin Pharmacol Ther. Oct. 2014;96(4):508-15. http://dx.doi.org/10.1038/clpt.2014.140. [pmid: 24968086].
143 Kuypers DR. Immunosuppressive drug monitoring - what to use in clinical practice today to improve renal graft outcome. Transpl Int. Feb. 2005;18(2):140-50. http://dx.doi.org/10.1111/j.1432-2277.2004.00041.x. [pmid: 15691265].
144 Guise JM, Chang C, Viswanathan M, et al. Agency for Healthcare Research and Quality Evidence-based Practice Center methods for systematically reviewing complex multicomponent health care interventions. J Clin Epidemiol. Nov. 2014;67(11):1181-91. Epub 2014 Oct 17. http://dx.doi.org/10.1016/j.jclinepi.2014.06.010. [pmid: 25438663].
145 Lalic J, Velickovic-Radovanovic R, Mitic B, et al. Immunosuppressive medication adherence in kidney transplant patients. Med Princ Pract. Jul. 2014;23(4):351-6. [pmid: 24923773].