# Methods

The methods for this systematic review follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov).

## Topic Refinement and Review Protocol

This topic was initially nominated through the public Web site and was subsequently refined with input from Key Informants and public comment. We generated an analytic framework, preliminary Key Questions (KQ), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, and settings). These processes were guided by a literature scan and information provided by the topic nominator, and they were consistent with the Key Informant and public feedback. A Technical Expert Panel (TEP) was convened for this report. The TEP consisted of nine scientists and clinicians, including individuals with expertise in transplant nephrology, infectious diseases, clinical pharmacology, and therapeutic drug monitoring and assay methodology. TEP members participated in conference calls and discussions through e-mail to review the scope, analytic framework, KQs, and PICOTS; provided input on the information and categories included in evidence tables; and provided input on the data analysis plan. Lists of the TEP members and Key Informants are included in the front matter of this report. We drafted a protocol for developing this systematic review and finalized it in consultation with AHRQ and the TEP before it was posted on the Effective Health Care Web site on October 8, 2014. We note that one investigator who assisted with this review was also participating in a clinical study of an extended-release formulation of tacrolimus. This formulation was not approved by the U.S. Food and Drug Administration (FDA) at the time our review was conducted; therefore, no studies of this drug were eligible for inclusion. In consultation with AHRQ, we developed a risk-mitigation plan to manage any potential conflict of interest.

## Literature Search Strategy

Literature searches were performed by Medical Librarians and followed established systematic review protocols. Searches covered the literature published from January 1, 1994, through December 10, 2015 for KQ1 and KQ2, and May 20, 2015 for KQ3. We chose 1994 as the earliest year because this reflects the timeframe in which the commonly used forms of calcineurin inhibitors (CNIs) received FDA approval. Tacrolimus (TAC) received approval in 1994 for use in liver transplants and in 1997 for use in renal transplants, and the modified formulation of cyclosporine A (CsA) received approval in 1995. Studies published before 1994 are likely to use formulations of CNIs no longer in common use.

Searches were restricted to English-language studies, given concerns that studies not published in English would be more likely to include clinical environments where post-transplant care, immunosuppressive therapy, and clinical outcomes would vary substantially from standard practices in the United States, and given the abundance of English-language studies identified in preliminary screening, including many studies conducted outside the United States or Europe.

We searched the following databases using controlled vocabulary and text words: EMBASE, MEDLINE, PubMed, and the Cochrane Library. Our searches included strategies to identify studies “in process” that were not yet indexed. The search concepts and strategies are available in Appendix A.

We also searched 21 sources for gray literature not indexed in the bibliographic databases; these sources are detailed in Appendix A. In addition, the AHRQ Scientific Resource Center requested scientific information packets from relevant pharmaceutical and test manufacturing companies, asking for any unpublished studies or data relevant for this systematic review (SR). We received six documents listing completed studies conducted by three different manufacturers, which we assessed for inclusion in the review.

Literature screening was performed using the database Distiller SR (Evidence Partners, Ottawa, Canada). Literature search results were initially screened for relevancy. Relevant abstracts were then screened against the inclusion and exclusion criteria in duplicate. Due to the highly complex methods and results of the studies, those that appeared to meet the inclusion criteria were retrieved in full and screened in duplicate by clinical experts in transplant nephrology and pharmacology, to determine whether they met the clinical criteria for inclusion. Studies that satisfied this first-pass full-text screening were then screened by methodologic experts for inclusion. Consensus discussion between the two original screeners resolved disagreements.

## Study Selection

Table 2 below presents the study inclusion criteria that guided the selection of studies included in this report. The table is organized based on the PICOTS (patient, intervention, comparator, outcomes, timing, and setting) framework. In general, for clinical outcomes (e.g., organ survival, mortality), we considered randomized controlled trials (RCTs) as the best available evidence. For the analytical validity outcomes (e.g., analytic precision, limit of quantification) considered in KQs 1 and 2, we also included prospective and retrospective nonrandomized comparative trials.

Table 2 Eligibility criteria

Category | Inclusion | Exclusion
Population | - Adult renal transplant recipients treated with full-dose or alternative-dose CNI immunosuppression; - All kidney donor types; - Renal retransplant patients; - Populations at increased risk of graft rejection | - Children (<18 years); - Multi-organ recipients
Interventions | Key Question 1a, 1b; - High performance liquid chromatography (HPLC); - Liquid chromatography-tandem mass spectrometry (LC-MS/MS; Key Question 2; - 2-hour postadministration monitoring of CsA (C2); Key Question 3; - CNI minimization strategies; - CNI conversion strategies; - CNI withdrawal strategies; - CNI avoidance strategies | - Studies of investigational immunosuppressive agents that are not FDA approved, or studies using nonmodified cyclosporine formulations; - Studies designed to examine the effectiveness of an induction agent as a primary intervention; - Studies using muromonab OKT3
Comparators | Key Question 1a, 1b; - Fluorescence polarization immunoassay (FPIA); - Enzyme-multiplied-immunoassay techniques (EMIT); - Enzyme-linked immunosorbent assay (ELISA); - Microparticle enzyme immunoassay (MEIA); Key Question 2; - Trough monitoring of CsA (C0); Key Question 3; - Full-dose CNIs; - CNI minimization/conversion/withdrawal/avoidance strategies compared to each other
Outcomes | Key Question 1a, 1b Analytical validity outcomes; - Analytic accuracy (analytic sensitivity and specificity); - Analytic precision (e.g., intra-assay agreement, inter-assay agreement, measurement reproducibility); - Limit of quantification; - Inter-laboratory comparisons (e.g., inter-laboratory agreement, measurement reproducibility); All Key Questions Intermediate-term clinical outcomes; - Organ survival; - Acute cellular and/or antibody mediated rejection (e.g., ascertained by “for cause” vs. “per protocol” biopsies) as defined by Banff criteria used in study; - Chronic allograft injury (e.g., rejection or dysfunction, as defined by study); - Glomerular filtration rate (GFR), as measured by study; - Serum creatinine; - Infections (including timing of infections and clinical impact of infections on patients); - Malignancy; - All-cause mortality; - Immunosuppression regimen changed due to adverse events; Adverse events; - Acute and/or chronic nephrotoxicity (including method of measuring GFR threshold); - New-onset diabetes after transplant; - Major adverse cardiac events; - Other adverse outcomes (e.g., hyperkalemia, hypomagnesaemia, hyperuricemia, gastrointestinal complications, post-transplant hypertension or hyperlipidemia, proteinuria, hematologic side effects, neurologic complications, hair loss/gain); Key Question 3 Long-term clinical outcomes; - Health care utilization; - Impact on provider workflow
Timing | - At least 3-months post-transplant for Key Question 3
Settings | - All settings where immunosuppressive therapy for transplant recipients is administered or monitored
Publication Language | - English

CNI = calcineurin inhibitors; CsA = cyclosporine; FDA = U.S. Food and Drug Administration; GFR = glomerular filtration rate

## Data Extraction

Data were abstracted using Microsoft Word and Excel. Duplicate abstraction on a 10-percent random sample was used to ensure accuracy. All discrepancies were resolved by consensus discussion among the two original abstracters and an additional third person as needed. Elements abstracted included general study characteristics (e.g., country, study design, number of enrolled patients, special patient inclusion/exclusion criteria), patient characteristics (e.g., age, sex, donor type, delayed graft function), details of CNI monitoring method (e.g., type of analytic method used to measure CNI drug level, timepoint for monitoring), CNI treatment strategy (e.g., alternative CNI strategy, control strategy, induction agent), risk-of-bias items, and outcomes data.

## Risk-of-Bias Assessment of Individual Studies

Risk of bias of the studies in KQ 1 that compared the analytical validity of chromatographic techniques to immunoassays for monitoring CNI drug levels was assessed using eight risk-of-bias items. These items are based on an item bank developed in part by the EPC Program to evaluate the reporting adequacy and internal validity of studies evaluating the analytical validity of medical tests. The items were based on a review of other checklists and criteria used to assess the methodological quality of studies reporting on analytical validity, such as the criteria in the ACCE and EGAPPs approaches, and expert panel consensus. The full list of the items and discussion of other methods used to assess studies of analytical validity can be found in the report titled Addressing Challenges in Genetic Test Evaluation: Evaluation Frameworks and Assessment of Analytical Validity.18

The eight items selected for this report broadly cover the following areas: adequate description of the tests under evaluation, reporting methods used to establish baseline performance of the tests, and reproducibility of the test results. When considering whether a study adequately described the tests under evaluation, we determined whether studies reported on how blood samples were collected and handled, whether and how test materials were calibrated and tested, and whether quality control/assurance measures were used to evaluate samples. When considering methods used to establish baseline performance, we determined whether studies reported on limit of detection and linearity range. Finally, when considering reproducibility, we determined whether studies reported on the test's performance over multiple testing times or across multiple laboratories. We discuss the limitations of the studies in the results section for KQ 1.

For studies addressing clinical outcomes, we used 10 items from an item bank that addresses the internal validity of comparative studies. This item bank was informed by empirical studies of the impact of study design on bias in comparative studies and is consistent with the guidance in AHRQ's “Methods Guide for Comparative Effectiveness Reviews.”19 Each item chosen addressed an aspect of study design or conduct that could help protect against bias, such as randomization of group assignment, or blinding outcome assessors to patient group assignment. Each item is phrased as a question that can be answered “Yes,” “No,” or “Not Reported,” and each is phrased such that an answer of “Yes” indicates that the study reported a protection against bias on that aspect. The items used in this report are presented in Table E-21 of Appendix E. This table also presents the risk-of-bias ratings for all included studies.

Studies were rated as “Low,” “Moderate,” or “High” risk of bias. We identified three of the 10 items as most indicative of potential bias: “Was randomization adequate?”; “Was allocation concealment adequate?”; and “Was there a <15 percent difference in completion rates in the study's groups?” A study was rated as High risk of bias if any two of these three questions were answered “No” or “Not Reported.” We considered the weight of the other seven items to be equal. Thus, if at least two of the more highly weighted criteria were answered “Yes,” then a study was rated as Low risk of bias if at least 75 percent of the total items were answered “Yes,” as Moderate risk of bias if more than 50 percent but less than 75 percent were answered “Yes,” and as High risk of bias if 50 percent or fewer of the items were answered “Yes.”

## Data Synthesis

For studies reporting on patient-centered clinical outcomes, we performed meta-analysis when appropriate and possible. Decisions about whether meta-analysis was appropriate depended on the judged clinical homogeneity of the different study populations, monitoring methods, CNI protocols, and outcomes. When meta-analysis was not possible (due to limitations of reported data) or was judged inappropriate, we synthesized the data using a descriptive, narrative approach.

We computed effect sizes and measures of variance using standard methods and performed random-effects meta-analysis using the Hartung-Knapp method.20,21 We performed analyses using the statistical software program R (GNU General Public License). Forest plots were generated for each meta-analysis and were reviewed by the study team. We evaluated statistical heterogeneity of the pooled analyses using the I^2^ statistic. We considered an I^2^ statistic of 50 percent or more as evidence of substantial heterogeneity. For KQ 3, we performed meta-analysis on the following outcomes, as these were clinically important outcomes that were reported most consistently across studies: biopsy proven acute rejection (BPAR), graft loss, patient death, renal function, and infection-related adverse events, specifically: cytomegalovirus (CMV), BK virus infection, and other opportunistic infections. Renal function was measured by eGFR, which was assessed using a variety of commonly used analytical approaches, including the Modification of Diet in Renal Disease (MDRD) formula, the Nankivell formula, and the Cockcroft-Gault formula. Due to differences in how eGFR was measured across studies, data were pooled using the standardized mean difference (SMD) as the summary effect size metric. Due to the complex and heterogeneous nature of the studies addressing KQs 1 and 2, we did not attempt to combine data from the studies quantitatively. Instead, we provided a narrative synthesis of the general findings of the evidence addressing these questions.

For KQ 3, studies were categorized depending on the alternative CNI regimen they addressed: minimization, conversion, withdrawal, avoidance, and studies that compared alternative regimens head-to-head. Within each category of studies, subgroup analyses were performed. Subgroups were defined using the following criteria: type of CNI (CsA or TAC), type of immunosuppressant coadministered with the CNI, type of induction agent, and timing of initiation of alterative CNI strategy (<6 months vs. ≥6 months post-transplantation). We were unable to conduct subgroup analyses of kidney donor type or patients at higher risk for infections because studies rarely reported outcomes stratified by these criteria, and too few studies were identified that consisted entirely of these populations.

Results were considered to represent no difference for an outcome when the summary effect estimate was between 0.75 and 1.25 and the confidence interval (CI) included 1.0.

## Strength of the Body of Evidence

For questions with clinical outcomes, we graded the strength of evidence based on the guidance established by the EPC program. Developed to grade the overall strength of a body of evidence, this approach incorporates five key domains: study limitations (including study design and aggregate risk of bias), consistency, directness, precision, and reporting bias. It also considers optional domains, such as a dose-response association, plausible confounding that would increase the observed effect, and strength of association (magnitude of effect), all of which may increase the strength of evidence. Table 3 defines the grades of evidence. We focused our assessment of the strength of evidence on studies reporting on clinical outcomes. We chose not to assess the strength of evidence for nonclinical outcomes reported in the studies of analytic validity (KQs 1a and 1b).

Table 3 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

We determined the study limitations by appraising the aggregate risk of bias of individual studies contributing to the evidence base for each comparison and clinical outcome. The evidence was downgraded when the risk of bias was judged to be high for 50 percent or more of the studies for a specific outcome.

We assessed consistency in terms of both the direction of effect and the magnitude of effect. Where quantitative synthesis was possible, the determination of inconsistency was based in part on the I^2^ statistic. If I^2^ was 50 percent or more, indicating the presence of substantial heterogeneity, we considered the evidence inconsistent. We downgraded the evidence for inconsistency unless the source of the heterogeneity was explained through subgroup analyses of identifiable differences in study characteristics.

The evidence was considered indirect if the populations, interventions, comparisons, or outcomes used within studies did not directly correspond to the comparisons we intended to evaluate. We downgraded evidence for indirectness if a majority of studies in a specific outcome or a heavily weighted study in the summary effect size calculation met these criteria.

We downgraded the evidence base for imprecision if the 95% CIs surrounding the summary effect estimate for relative risk exceeded both a 10-percent increase in risk as well as a 10-percent decrease in risk. If the CIs exceeded a 25-percent increase and decrease in risk, the evidence base was downgraded further due to substantial imprecision. When we identified only a single study for a specific outcome, we considered the evidence base imprecise and downgraded. We treated exceptions as they arose.

Reporting bias includes publication bias, outcome reporting bias, and analysis reporting bias. Since pharmaceutical manufacturers funded many of the studies we reviewed, we explored publication bias through a review of funnel plots. We examined funnel plots for the primary comparisons in KQ 3. We also considered outcome reporting bias for this report, particularly for the outcome of “Other Opportunistic Infections.” Data ascertainment and reporting for this outcome can vary widely, with some studies describing many different types of infections, while other studies report only one or two types of infections. We suspected reporting bias if studies appeared to selectively report incidence of specific opportunistic infections when the data favored the intervention regimen.

## Applicability

We determined applicability of studies by evaluating characteristics of included patients and parameters the studies used for drug dosing and measuring immunosuppressant level targets. Studies were considered to have limited generalizability when their patient populations were at high risk for poor outcomes or were not representative of important subgroups (such as patients >65 years old, retransplants, or African-Americans). Studies were also considered to have limited applicability when CNI drug doses or immunosuppressant target levels were not considered to be within conventional standards of care (as assessed by the clinical investigators contributing to this report).

## Peer Review and Public Commentary

Six external experts provided peer review on this report. In addition, the draft report was posted on the AHRQ Web site (www.effectivehealthcare.ahrq.gov) for public review. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ also reviewed the final report before publication. The dispositions of the comments are documented and will be published 3 months after publication of the report.