# Introduction

## Background

Approximately 17,000 renal transplants occur each year in the United States, accounting for almost 60 percent of all organ transplants.1 Kidney transplantation is the treatment of choice for end-stage renal disease. Causes of renal failure are varied, including diabetes, hypertension, glomerular and cystic kidney diseases, and autoimmune disorders. Kidney transplantation offers a better quality of life and a survival benefit over chronic dialysis for most patients. The 2013 Organ Procurement and Transplantation Network and Scientific Registry of Transplant Recipients annual report showed that the conditional graft half-life (defined as the time to when half the grafts surviving at least 1 year are still functioning) was 11.9 years for deceased donor transplants and 15.9 years for living donor transplants in 2011.^2^ Survival rates continue to improve; a recent analysis of more than 250,000 renal transplant recipients demonstrated that death-censored graft half-life for all deceased donor transplants increased from 10.2 years in 1989 to 14.3 years in 2005 and remained approximately 16.5 years for living donor transplants during the same time period.3

Calcineurin inhibitors (CNIs) are the cornerstone of immunosuppression for renal transplantation. Cyclosporine A (CsA) and tacrolimus (TAC) are the two agents composing this drug class and have been used in renal transplant recipients for more than 20 years. CsA was initially approved in 1983 by the U.S. Food and Drug Administration (FDA) for immunosuppression following organ transplantation; in 1995, a microemulsion formulation of CsA (associated with better bioavailability and more consistent absorption) was approved. CsA formulations are usually administered twice daily. TAC received FDA approval in 1994 for liver transplant recipients and in 1997 for renal transplant recipients. Tacrolimus is usually administered twice daily but recently became available as an extended-release once-daily formulation. FDA-approved generic equivalents are available for TAC immediate-release formulations, as well as modified and unmodified CsA.

TAC-based regimens are currently the mainstay at most renal transplant programs in the United States. More than 85 percent of renal transplant recipients are discharged from admission on TAC as part of their maintenance immunosuppressive regimen.2 This is largely because TAC is more potent and associated with less rejection and nephrotoxicity than CsA.4 However, TAC is also associated with more neurotoxicity and gastrointestinal side effects than CsA.5 It has also been associated with an increased incidence of new-onset diabetes and the development of metabolic syndrome, which are significant concerns because the main cause of death among renal transplant recipients is cardiovascular disease.6,7

CNIs are effective immunosuppressants, but they have extensive toxicity profiles. TAC and CsA both require careful management to ensure sufficient dosing for therapeutic effectiveness while avoiding toxicity. Two primary strategies have been employed to balance efficacy while limiting side effects: routine monitoring of CNI drug levels to guide dosing adjustments and minimization of CNI use to the lowest therapeutic levels. Alternatively, CNI use may be withdrawn or avoided entirely in favor of other immunosuppressant therapies.

### CNI Monitoring

The primary technologies used for monitoring CNI drug levels are mass spectrometry and immunoassays. CsA is measured with high-performance liquid chromatography (HPLC), liquid chromatography-tandem mass spectrometry (LC-MS/MS), fluorescence polarization immunoassay (FPIA), and enzyme-multiplied-immunoassay techniques (EMIT). TAC can be monitored with LC-MS/MS, enzyme-linked immunosorbent assay (ELISA), or microparticle enzyme immunoassay (MEIA). Commonly used immunoassays, such as MEIA for TAC and FPIA for CsA, use monoclonal antibodies that recognize not only the parent drug but also several of its metabolites. Soldin and colleagues used data collected by the College of American Pathologists to evaluate the crossreactivity of several CsA metabolites in commonly used immunoassays for CsA.8 The results showed significant cross-reactivity of metabolites in all the immunoassay systems tested. Such cross-reactivity can lead to overestimation of drug concentration, which could affect interpretation of patients' drug levels and lead to less-than-optimal clinical outcomes. Compared with the immunoassays, HPLC and LC-MS/MS offer more precise measures of the parent compound while minimizing measurement of metabolites, but they can also be more time-consuming, labor-intensive, and use less standardized techniques, making their performance provider-dependent. It is also unclear whether long-term health outcomes vary with each methodology.

The ability to accurately measure low-range CNI concentrations is important because CNI target therapeutic ranges have decreased over time.9 The Report of the European Consensus Conference recommends that assays achieve a limit of quantification of 1 ng/mL.9 However, randomized trials demonstrating the value of CNI monitoring itself are lacking. Moreover, although LC-MS/MS is one of the most popular methods for currently measuring TAC, no standardization exists between laboratories.

Selection of the appropriate timing for measuring CNI drug levels is another important component of clinical care. For TAC, single timepoint measurements have not been shown to correlate with AUC.10 Still, it is recommended that TAC be monitored at 12 hour trough levels (C0, usually just before morning dose administration), even though the relationship between C0 and clinical outcomes is still unclear.9 A recent publication reported that pooled data from three large randomized controlled trials (RCTs) did not show find any significant correlations between TAC trough levels at five time points (day 3, 10, and 14, and months 1 and 6 post-transplant) and the incidence of biopsy proven acute rejection in renal transplant recipients.11

Trough monitoring of CsA (C0) is also common, but recent research has suggested that monitoring CsA at 2 hours after dosing (C2) yields effective monitoring while enabling lower doses and less risk of toxicity.12,13 However, C2 level monitoring is less practical because it needs to be measured within 15 minutes of the 2-hour target to avoid large shifts in concentrations, while C0 measurement can be done within a 10- to 14-hour window. The question of whether C0 monitoring should be replaced with monitoring at C2 is unresolved, and determining the optimal timepoint can lead to more efficient, safer, and higher value care.

### CNI Management and Minimization Strategies

Immunosuppressive regimens designed to reduce or eliminate exposure to CNI toxicity risks have been investigated in recent years.14 Four alternative approaches (see Table 1) to full-dose CNI therapy have emerged: (1) CNI minimization, which reduces the amount of the drug administered. This strategy may be undertaken from the time of transplant (de novo) or later post-transplant (elective) as a result of an adverse event such as nephrotoxicity or BK viral infection; (2) CNI conversion, which tapers CNI dosing at any time post-transplant until full replacement with alternative immunosuppressants is achieved. This strategy may be undertaken at any time post-transplant and is usually a result of an unacceptable CNI-related adverse event; (3) CNI withdrawal, which slowly eliminates the amount of drug administered early or late post-transplant; (4) CNI avoidance, which avoids the use of CNI in favor of other immunosuppressive drugs from the outset. These strategies also involve the use of concurrent immunosuppressants in standard or low doses and may include induction agents to provide added immunosuppression in the immediate post-transplant period. The other immunosuppressive drugs often used include mycophenolic acid formulations such as mycophenolate mofetil (MMF) or enteric-coated mycophenolic sodium, mammalian target of rapamycin (mTOR) inhibitors such as sirolimus (SRL) or everolimus (EVR), azathioprine (AZA), and belatacept. No clear consensus exists regarding the comparative efficacy and safety of these alternatives to full-dose CNI regimens.

Table 1 Alternatives to full-dose CNI regimens

Strategy | Definition | Timing
Minimization | Lower dosage of CNI | Planned de novo or result of adverse event
Conversion | Tapering of CNI dose until eliminated and replaced with other immunosuppressant | Usually result of adverse event
Withdrawal | Tapering of CNI dose until eliminated; continuation of other immunosuppressant already in use before withdrawal | Planned de novo or result of adverse event
Avoidance | No CNI given; other immunosuppressant used | Planned de novo

CNI = calcineurin inhibitor

Another important consideration is treating high-risk populations. As the volume of patients seeking retransplantation grows, the number of highly sensitized patients has increased, as has the popularity of desensitization protocols employing plasmapheresis, high-dose induction and maintenance immunosuppression.15 As more potent TAC-based immunosuppression has become the clinical standard, opportunistic infections such as cytomegalovirus (CMV), Epstein Barr virus, and BK viremia and nephropathy have emerged as complications, and data suggest these are more common with TAC than with CsA.16,17 Immunosuppressive regimens that minimize or avoid CNIs may play an important role in the care of such patients.

## Scope and Key Questions

This report's main objective is to conduct a systematic review and meta-analysis of the benefits and harms of CNIs as maintenance therapy for adults who have undergone a renal transplant. In this review, we address the following Key Questions (KQs):

### Monitoring Assays for Calcineurin Inhibitors

Key Question 1a. In adult renal transplants, how do liquid chromatographic and mass spectrometric analytical techniques compare with immunoassay analysis for therapeutic monitoring of full dosing regimens of the calcineurin inhibitors (CNIs) cyclosporine and tacrolimus?

Key Question 1b. In adult renal transplants, how do liquid chromatographic and mass spectrometric analytical techniques compare with immunoassay analysis for therapeutic monitoring of lower CNI doses used in minimization, conversion, or withdrawal strategies?

### Cyclosporine Monitoring Timepoints

Key Question 2. In adult renal transplants, how does 2-hour post-administration cyclosporine monitoring (C2) compare with trough monitoring (C0) for health outcomes?

### Management of Alternatives to Full-Dose CNI Regimens

Key Question 3a. In adult renal transplants, how do immunosuppressive regimens designed to reduce or eliminate exposure to CNI toxicity compare with each other and with full-dose CNI regimens for health outcomes?

Key Question 3b. How do the type of induction agent (including when no induction is used) and the use of concurrent immunosuppressive agents affect outcomes of regimens that reduce or eliminate CNI exposure?

### Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1).

Figure 1 Analytic framework for calcineurin inhibitors for renal transplant

ATG = antithymocyte globulin; CNI = calcineurin inhibitor; KQ = Key Question

Figure 1: This figure depicts the key questions within the context of the PICOTS described above. In general, the figure illustrates how treating adult kidney transplant recipients with either full dose CNI immunosuppression or an alternative immunosuppressive regimen impacts drug monitoring analytical outcomes listed in the first box on the right: analytical accuracy and precision, limit of quantification, and inter-laboratory comparison and intermediate health outcomes next box, such as organ survival and acute cellular and/or antibody mediated rejection. Ultimately, the figure depicts how full dose CNI regimens compared to alternative immunosuppressive regimens impact patient outcomes listed in the last box on the right: all-cause mortality, quality of life, healthcare utilization, impact on workflow, and patient preference. Also, harms that may occur with the treatments are listed in the oval on the bottom.

## Organization of This Report

In the remaining three chapters of this report, we discuss the methods for this systematic review, the results for each Key Question (KQ), and the findings. Within the Results chapter, we provide the results of the literature searches and screening procedures, as well as descriptions of included studies, key points, detailed syntheses of the studies, and strength-of-evidence tables for each KQ. The Discussion chapter reviews the key findings and strength of evidence for each KQ, places the findings in the context of previous systematic reviews, examines the general applicability of the studies, discusses implications for decisionmaking, describes limitations of the systematic review process and the evidence base for each KQ, and identifies knowledge gaps that require further research.

A list of acronyms and abbreviations appears after the references, followed by seven appendixes. The Appendixes include Appendix A. Search Strategy, Appendix B. Excluded Studies, Appendix C. Evidence Tables for Key Question 1a and 1b, Appendix D. Evidence Tables for Key Question 2, Appendix E. Evidence Tables for Key Question 3a and 3b, Appendix F. Forest Plots for Key Question 3a and 3b, and Appendix G. Appendix Reference List.