# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Nancy D. Bridges, M.D.
  Chief, Transplantation Branch
  Division of Allergy, Immunology and Transplantation
  National Institute of Allergy and Infectious Diseases
  National Institutes of Health
  Rockville, MD
- Melissa Greenwald, M.D.
  Medical Officer
  Health Resources and Services Administration
  Washington, DC
- Bruce Kaplan, M.D.
  Professor of Medicine
  University of Kansas
  Kansas City, KS