# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Uwe Christians, M.D., Ph.D.
  Professor of Anesthesiology
  University of Colorado
  Aurora, CO
- William Clarke, Ph.D.
  Department of Pathology
  Johns Hopkins University
  Baltimore, MD
- Steven Gabardi, Pharm.D., FAST, FCCP, BCPS^*^
  * This member of the Technical Expert Panel also reviewed and commented on the draft report.
  Abdominal Organ Transplant Clinical Specialist and Program Director
  PGY-2 Organ Transplant Pharmacology Residency
  Brigham and Women's Hospital, Department of Transplant Surgery, Renal Division
  Assistant Professor of Medicine
  Harvard Medical School
  Boston, MA
- Lorenzo Gallon, M.D.
  Professor of Medicine and Nephrology
  Northwestern University
  Chicago, IL
- Michael Ison, M.D.^*^
  Associate Professor of Infectious Diseases and Organ Transplantation
  Northwestern University
  Chicago, IL
- Peter Reese, M.D., M.S.C.E.^*^
  Assistant Professor of Medicine and Epidemiology
  University of Pennsylvania
  Philadelphia, PA
- Scott Sanoff, M.D., M.P.H.
  Assistant Professor of Medicine and Nephrology
  Duke University
  Durham, NC