# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- William Clarke, Ph.D.
  Department of Pathology
  Johns Hopkins University
  Baltimore, MD
- Avis Danishefsky, Ph.D.
  U.S. Food and Drug Administration
  Silver Spring, MD
- Z. Collette Edwards, M.D., M.B.A.
  Founder and Chief Executive Officer
  Insight MD
  Ellicott City, MD
- Michelle Josephson, M.D.
  Professor of Medicine
  University of Chicago
  Chicago, IL
- Susan Maynard, Ph.D.
  Director of Chemistry and Toxicology
  Carolinas Pathology Group
  Charlotte, NC
- Joette Meyer, Pharm.D.
  U.S. Food and Drug Administration
  Silver Spring, MD
- Stephen Pastan, M.D.
  Associate Professor of Medicine
  Emory University
  Atlanta, GA
- Sam Pederson
  President
  American Association of Kidney Patients
  Seattle, WA
- Dorry Segev, M.D., Ph.D.
  Associate Professor of Surgery
  Johns Hopkins University
  Baltimore, MD
- Micah Thorp, D.O.
  Northwest Permanente Physicians and Surgeons
  Milwaukie, OR