# Acknowledgments

The authors gratefully acknowledge Benjamin French, Ph.D., of the University of Pennsylvania, for assistance with statistical analysis; M. Hassan Murad, M.D., M.P.H., of the Mayo Clinic, who served as Associate Editor; and the following individuals at ECRI Institute for their contributions to this project: Lydia Dharia, Katherine Donahue, Gina Giradi, Mrinmayi Joshi, Michael Phillips, Kristy McShea, and EPC Director, Karen Schoelles, M.D., S.M.

We also thank AHRQ Task Order Officer Laura Pincock, Pharm.D., M.P.H., and Nahed El-Kassar, M.D., Ph.D.