# Appendix Reference List

1 Leung EK, Yi X, Gloria C, et al. Clinical evaluation of the QMS(R) tacrolimus immunoassay. Clin Chim Acta. Apr. 20. 2014;431:270-5. [pmid: 24518359].
2 Shipkova M, Vogeser M, Ramos PA, et al. Multi-center analytical evaluation of a novel automated tacrolimus immunoassay. Clin Biochem. Aug. 2014;47(12):1069-77. Epub 2014 Apr 12. [pmid: 24721684].
3 Westley IS, Taylor PJ, Salm P, et al. Cloned enzyme donor immunoassay tacrolimus assay compared with high-performance liquid chromatography-tandem mass spectrometry and microparticle enzyme immunoassay in liver and renal transplant recipients. Ther Drug Monit. Oct. 2007;29(5):584-91. [pmid: 17898648].
4 Borrows R, Chusney G, Loucaidou M, et al. Clinical outcomes of renal transplantation using liquid chromatographic monitoring of tacrolimus. Ther Drug Monit. Apr. 2006;28(2):269-73. [pmid: 16628143].
5 Chan YH, Ho CS, Shek CC, et al. Measurement of whole blood tacrolimus level by high performance liquid chromatography tandem mass spectrometry in renal transplant recipients - a single center perspective. Hong Kong J Nephrol. 2005;7(2):65-9.
6 Butch AW, Fukuchi AM. Analytical performance of the CEDIA cyclosporine PLUS whole blood immunoassay. J Anal Toxicol. Apr. 2004;28(3):204-10. [pmid: 15107152].
7 Staatz CE, Taylor PJ, Tett SE. Comparison of an ELISA and an LC/MS/MS method for measuring tacrolimus concentrations and making dosage decisions in transplant recipients. Ther Drug Monit. Oct. 2002;24(5):607-15. [pmid: 12352932].
8 Hamwi A, Veitl M, Männer G, et al. Evaluation of four automated methods for determination of whole blood cyclosporine concentrations. Am J Clin Pathol. 1999;112(3):358-65. [pmid: 10478141].
9 Schütz E, Svinarov D, Shipkova M, et al. Cyclosporin whole blood immunoassays (AxSYM, CEDIA, and Emit): a critical overview of performance characteristics and comparison with HPLC. Clin Chem. Oct. 1998;44(10):2158-64. [pmid: 9761250].
10 Salm P, Taylor PJ, Clark A, et al. High-performance liquid chromatography-tandem mass spectrometry as a reference for analysis of tacrolimus to assess two immunoassays in patients with liver and renal transplants. Ther Drug Monit. Dec. 1997;19(6):694-700. [pmid: 9421113].
11 Roberts NB, Dutton J, Tewari A, et al. A method of relating whole blood cyclosporin A results by HPLC to Abbott TDx monoclonal and polyclonal immunoassays. Ann Clin Biochem. Mar. 1995;32(Pt 2):208-9. [pmid: 7785951].
12 Kyllonen LE, Salmela KT. Early cyclosporine C0 and C2 monitoring in de novo kidney transplant patients: A prospective randomized single-center pilot study. Transplantation. Apr. 2006;81(7):1010-5. [pmid: 16612277].
13 Paydas S, Balal M, Sertdemir Y, et al. Long-term comparative results of C(0) and C(2) monitoring of CyA in renal transplanted patients. Ren Fail. 2005;27(4):409-13. [pmid: 16060128].
14 Praditpornsilpa K, Avihingsanon Y, Nivatvong S, et al. Outcome of microemulsion cyclosporine C(2) concentration monitoring in kidney transplantation. Clin Transplant. Jun. 2005;19(3):335-9. [pmid: 15877794].
15 Birsan T, Loinig C, Bodingbauer M, et al. Comparison between C0 and C2 monitoring in de novo renal transplant recipients: retrospective analysis of a single-center experience. Transplantation. Dec. 27. 2004;78(12):1787-91. [pmid: 15614152].
16 Giese T, Zeier M, Meuer S. Analysis of NFAT-regulated gene expression in vivo: a novel perspective for optimal individualized doses of calcineurin inhibitors. Nephrol Dial Transplant. Jul. 2004;19(Suppl 4):iv55-60. [pmid: 15240851].
17 Jirasiritham S, Mavichak V, Danviriyasup K, et al. Conversion of C-0 to C-2 monitoring of cyclosporine in stable kidney transplant patients. Transplant Proc. Feb. 2003;35(1):236-7. [pmid: 12591379].
18 Cai L, Zeng F, Liu B, et al. A single-centre, open-label, prospective study of an initially short-term intensified dosing regimen of enteric-coated mycophenolate sodium with reduced cyclosporine A exposure in Chinese live-donor kidney transplant recipients. Int J Clin Pract Suppl. Apr. 2014;(181):23-30. [pmid: 24673716].
19 Chadban SJ, Eris JM, Kanellis J, et al. A randomized, controlled trial of everolimus-based dual immunosuppression versus standard of care in de novo kidney transplant recipients. Transpl Int. Mar. 2014;27(3):302-11. Epub 2014 Jan 6. [pmid: 24279685].
20 Muhlbacher F, Neumayer HH, del Castillo D, et al. The efficacy and safety of cyclosporine reduction in de novo renal allograft patients receiving sirolimus and corticosteroids: results from an open-label comparative study. Transpl Int. Feb. 2014;27(2):176-86. [pmid: 24266855].
21 Oh CK, Huh KH, Ha J, et al. Safety and efficacy of the early introduction of everolimus with reduced-exposure cyclosporine A in de novo kidney recipients. Transplantation. Jan. 15. 2015;99(1):180-6. [pmid: 24983307].
22 Bechstein WO, Paczek L, Wramner L, et al. A comparative, randomized trial of concentration-controlled sirolimus combined with reduced-dose tacrolimus or standard-dose tacrolimus in renal allograft recipients. Transplant Proc. Jul-Aug. 2013;45(6):2133-40. [pmid: 23953523].
23 Chadban S, Eris J, Russ G, et al. Enteric-coated mycophenolate sodium in combination with full dose or reduced dose cyclosporine, basiliximab and corticosteroids in Australian de novo kidney transplant patients. Nephrology (Carlton). Jan. 2013;18(1):63-70. [pmid: 23110508].
24 Cibrik D, Silva HT Jr, Vathsala A, et al. Randomized trial of everolimus-facilitated calcineurin inhibitor minimization over 24 months in renal transplantation. Transplantation. Apr. 15. 2013;95(7):933-42. [pmid: 23422495].
25 Takahashi K, Uchida K, Yoshimura N, et al. Efficacy and safety of concentration-controlled everolimus with reduced-dose cyclosporine in Japanese de novo renal transplant patients: 12-month results. Transplant Res. Jul. 16. 2013;2(1):14. [pmid: 23866828].
26 Chan L, Andres A, Bunnapradist S, et al. Renal function and NODM in de novo renal transplant recipients treated with standard and reduced levels of tacrolimus in combination with EC-MPS. J Transplant. 2012;2012:9. [pmid: 23227307].
27 Kamar N, Rostaing L, Cassuto E, et al. A multicenter, randomized trial of increased mycophenolic acid dose using enteric-coated mycophenolate sodium with reduced tacrolimus exposure in maintenance kidney transplant recipients. Clin Nephrol. 2012;77(2):126-36. [pmid: 22257543].
28 Langer RM, Hene R, Vitko S, et al. Everolimus plus early tacrolimus minimization: a phase III, randomized, open-label, multicentre trial in renal transplantation. Transpl Int. May. 2012;25(5):592-602. [pmid: 22471345].
29 Paoletti E, Marsano L, Bellino D, et al. Effect of everolimus on left ventricular hypertrophy of de novo kidney transplant recipients: a 1 year, randomized, controlled trial. Transplantation. Mar. 15. 2012;93(5):503-8. [pmid: 22318246].
30 Bertoni E, Larti A, Rosso G, et al. Good outcomes with cyclosporine very low exposure with everolimus high exposure in renal transplant patients. J Nephrol. Sep-Oct. 2011;24(5):613-8. [pmid: 21240873].
31 Holdaas H, Rostaing L, Seron D, et al. Conversion of long-term kidney transplant recipients from calcineurin inhibitor therapy to everolimus: a randomized, multicenter, 24-month study. Transplantation. Aug. 27. 2011;92(4):410-8. [pmid: 21697773].
32 Xu DL, Bai JM, Yu X, et al. Application of low-dose calcineurin inhibitors in living-related donor renal transplantation. J Clin Rehabil Tiss Eng Res. Apr. 2011;15(18):3417-20.
33 Etienne I, Toupance O, Benichou J, et al. A 50% reduction in cyclosporine exposure in stable renal transplant recipients: renal function benefits. Nephrol Dial Transplant. Sep. 2010;25(9):3096-106. [pmid: 20299336].
34 Fangmann J, Arns W, Marti HP, et al. Impact of daclizumab, low-dose cyclosporine, mycophenolate mofetil and steroids on renal function after kidney transplantation. Nephrol Dial Transplant. Jan. 2010;25(1):283-92. [pmid: 19773417].
35 Gaston RS, Kaplan B, Shah T, et al. Fixed- or controlled-dose mycophenolate mofetil with standard- or reduced-dose calcineurin inhibitors: the opticept trial. Am J Transplant. Jul. 2009;9(7):1607-19. [pmid: 19459794].
36 Salvadori M, Scolari MP, Bertoni E, et al. Everolimus with very low-exposure cyclosporine A in de novo kidney transplantation: a multicenter, randomized, controlled trial. Transplantation. Nov. 2009;88(10):1194-202. [pmid: 19935373].
37 Spagnoletti G, Citterio F, Favi E, et al. Cardiovascular risk profile in kidney transplant recipients treated with two immunosuppressive regimens: tacrolimus and mycophenolate mofetil versus everolimus and low-dose cyclosporine. Transplant Proc. May. 2009;41(4):1175-7. [pmid: 19460509].
38 Bolin P, Shihab FS, Mulloy L, et al. Optimizing tacrolimus therapy in the maintenance of renal allografts: 12-month results. Transplantation. Jul. 15. 2008;86(1):88-95. [pmid: 18622283].
39 Chan L, Greenstein S, Hardy MA, et al. Multicenter, randomized study of the use of everolimus with tacrolimus after renal transplantation demonstrates its effectiveness. Transplantation. Mar. 2008;85(6):821-6. [pmid: 18360262].
40 Budde K, Bosmans JL, Sennesael J, et al. Reduced-exposure cyclosporine is safe and efficacious in de novo renal transplant recipients treated with enteric-coated mycophenolic acid and basiliximab. Clin Nephrol. Mar. 2007;67(3):164-75. [pmid: 17390741].
41 Cibrik D, Meierkriesche HU, Bresnahan B, et al. Renal function with cyclosporine C(2) monitoring, enteric-coated mycophenolate sodium and basiliximab: a 12-month randomized trial in renal transplant recipients. Clin Transplant. Mar-Apr. 2007;21(2):192-201. [pmid: 17425744].
42 Ekberg H, Grinyo J, Nashan B, et al. Cyclosporine sparing with mycophenolate mofetil, daclizumab and corticosteroids in renal allograft recipients: the CAESAR study. Am J Transplant. Mar. 2007;7(3):560-70. [pmid: 17229079].
43 Ekberg H, Tedesco-Silva H, Demirbas A, et al. Reduced exposure to calcineurin inhibitors in renal transplantation. New Eng J Med. Dec. 20. 2007;357(25):2562-75. [pmid: 18094377].
44 Ghafari A, Makhdoomi K, Ahmadpour P, et al. Low-dose versus high-dose cyclosporine induction protocols in renal transplantation. Transplant Proc. May. 2007;39(4):1219-22. [pmid: 17524937].
45 Hernandez D, Miquel R, Porrini E, et al. Randomized controlled study comparing reduced calcineurin inhibitors exposure versus standard cyclosporine-based immunosuppression. Transplantation. Sep. 2007;84(6):706-14. [pmid: 17893603].
46 Frimat L, Cassuto-Viguier E, Charpentier B, et al. Impact of cyclosporine reduction with MMF: a randomized trial in chronic allograft dysfunction. the ‘reference’ study. Am J Transplant. Nov. 2006;6(11):2725-34. [pmid: 17049060].
47 Frimat L, Cassuto-Viguier E, Provot F, et al. Long-term impact of cyclosporin reduction with MMF treatment in chronic allograft dysfunction: REFERENECE study 3-year follow up. J Transplant. 2010;2010:11. [pmid: 20706667].
48 Tang SC, Chan KW, Tang CS, et al. Conversion of ciclosporin A to tacrolimus in kidney transplant recipients with chronic allograft nephropathy. Nephrol Dial Transplant. Nov. 2006;21(11):3243-51. Epub 2006 Jul 28. [pmid: 16877482].
49 Vathsala A, Ona ET, Tan SY, et al. Randomized trial of alemtuzumab for prevention of graft rejection and preservation of renal function after kidney transplantation. Transplantation. Sep. 27. 2005;80(6):765-74. [pmid: 16210963].
50 Lo A, Egidi MF, Gaber LW, et al. Observations regarding the use of sirolimus and tacrolimus in high-risk cadaveric renal transplantation. Clin Transplant. Feb. 2004;18(1):53-61. [pmid: 15108771].
51 Nashan B, Curtis J, Ponticelli C, et al. Everolimus and reduced-exposure cyclosporine in de novo renal-transplant recipients: a three-year phase II, randomized, multicenter, open-label study. Transplantation. Nov. 15. 2004;78(9):1332-40. [pmid: 15548972].
52 Stoves J, Newstead CG, Baczkowski AJ, et al. A randomized controlled trial of immunosuppression conversion for the treatment of chronic allograft nephropathy. Nephrol Dial Transplant. Aug. 2004;19(8):2113-20. [pmid: 15161956].
53 Pascual M, Curtis J, Delmonico FL, et al. A prospective, randomized clinical trial of cyclosporine reduction in stable patients greater than 12 months after renal transplantation. Transplantation. May. 15. 2003;75(9):1501-5. [pmid: 12792504].
54 De Sevaux RG, Smak Gregoor PJ, Hene RJ, et al. A controlled trial comparing two doses of cyclosporine in conjunction with mycophenolate mofetil and corticosteroids. J Am Soc Nephrol. 2001;12(8):1750-7. [pmid: 11461949].
55 Budde K, Rath T, Sommerer C, et al. Renal, efficacy and safety outcomes following late conversion of kidney transplant patients from calcineurin inhibitor therapy to everolimus: The randomized APOLLO study. Clin Nephrol. 2015;83(1):11-21. [pmid: 25512099].
56 Budde K, Sommerer C, Rath T, et al. Renal function to 5 years after late conversion of kidney transplant patients to everolimus: a randomized trial. J Nephrol. Feb. 2015;28(1):115-23. [pmid: 25192833].
57 Rostaing L, Hertig A, Albano L, et al. Fibrosis progression according to epithelial-mesenchymal transition profile: A randomized trial of everolimus versus CsA. Am J Transplant. May. 1. 2015;15(5):1303-12. [pmid: 25808994].
58 Bansal D, Yadav AK, Kumar V, et al. Deferred pre-emptive switch from calcineurin inhibitor to sirolimus leads to improvement in GFR and expansion of T regulatory cell population: a randomized, controlled trial. PLoS ONE. Oct. 11. 2013;8(10):e75591. [pmid: 24146762].
59 Chhabra D, Alvarado A, Dalal P, et al. Impact of calcineurin-inhibitor conversion to mTOR inhibitor on renal allograft function in a prednisone-free regimen. Am J Transplant. Nov. 2013;13(11):2902-11. [pmid: 24007570].
60 Silva HT Jr, Felipe CR, Garcia VD, et al. Planned randomized conversion from tacrolimus to sirolimus-based immunosuppressive regimen in de novo kidney transplant recipients. Am J Transplant. Dec. 2013;13(12):3155-63. [pmid: 24266969].
61 Budde K, Lehner F, Sommerer C, et al. Five-year outcomes in kidney transplant patients converted from cyclosporine to everolimus: the randomized ZEUS study. Am J Transplant. Jan. 2015;15(1):119-28. [pmid: 25521535].
62 Budde K, Lehner F, Sommerer C, et al. Conversion from cyclosporine to everolimus at 4.5 months posttransplant: 3-year results from the randomized ZEUS study. Am J Transplant. Jun. 2012;12(6):1528-40. [pmid: 22642473].
63 Budde K, Becker T, Arns W, et al. Everolimus-based, calcineurin-inhibitor-free regimen in recipients of de-novo kidney transplants: an open-label, randomised, controlled trial. Lancet. Mar. 5. 2011;377(9768):837-47. [pmid: 21334736].
64 Mjornstedt L, Schwartz Sorensen S, von Zur Muhlen B, et al. Renal function three years after early conversion from a calcineurin inhibitor to everolimus: results from a randomized trial in kidney transplantation. Transpl Int. Jan. 2015;28(1):42-51. [pmid: 25176389].
65 Mjornstedt L, Sorensen SS, Von Zur Muhlen B, et al. Improved renal function after early conversion from a calcineurin inhibitor to everolimus: a randomized trial in kidney transplantation. Am J Transplant. Oct. 2012;12(10):2744-53. [pmid: 22812414].
66 Nafar M, Alipour B, Ahmadpoor P, et al. Sirolimus versus calcineurin inhibitor-based immunosuppressive therapy in kidney transplantation: a 4-year follow-up. Iran J Kidney Dis. 2012;6(4):300-6. [pmid: 22797101].
67 Heilman RL, Younan K, Wadei HM, et al. Results of a prospective randomized trial of sirolimus conversion in kidney transplant recipients on early corticosteroid withdrawal. Transplantation. Oct. 15. 2011;92(7):767-73. [pmid: 21775930].
68 Rostaing L, Massari P, Garcia VD, et al. Switching from calcineurin inhibitor-based regimens to a belatacept-based regimen in renal transplant recipients: a randomized phase II study. Clin J Am Soc Nephrol. Feb. 1. 2011;6(2):430-9. [pmid: 21051752].
69 Weir MR, Mulgaonkar S, Chan L, et al. Mycophenolate mofetil-based immunosuppression with sirolimus in renal transplantation: a randomized, controlled spare-the-nephron trial. Kidney Int. Apr. 2011;79(8):897-907. [pmid: 21191361].
70 Guba M, Pratschke J, Hugo C, et al. Renal function, efficacy, and safety of sirolimus and mycophenolate mofetil after short-term calcineurin inhibitor-based quadruple therapy in de novo renal transplant patients: one-year analysis of a randomized multicenter trial. Transplantation. Jul. 27. 2010;90(2):175-83. [pmid: 20463641].
71 Bemelman FJ, De Maar EF, Press RR, et al. Minimization of maintenance immunosuppression early after renal transplantation: an interim analysis. Transplantation. Aug. 15. 2009;88(3):421-8. [pmid: 19667948].
72 Schena FP, Pascoe MD, Alberu J, et al. Conversion from calcineurin inhibitors to sirolimus maintenance therapy in renal allograft recipients: 24-month efficacy and safety results from the CONVERT trial. Transplantation. Jan. 27. 2009;87(2):233-42. [pmid: 19155978].
73 Lebranchu Y, Thierry A, Thervet E, et al. Efficacy and safety of early cyclosporine conversion to sirolimus with continued MMF-four-year results of the postconcept study. Am J Transplant. Aug. 2011;11(8):1665-75. [pmid: 21797975].
74 Lebranchu Y, Thierry A, Toupance O, et al. Efficacy on renal function of early conversion from cyclosporine to sirolimus 3 months after renal transplantation: concept study. Am J Transplant. May. 2009;9(5):1115-23. [pmid: 19422337].
75 Durrbach A, Rostaing L, Tricot L, et al. Prospective comparison of the use of sirolimus and cyclosporine in recipients of a kidney from an expanded criteria donor. Transplantation. Feb. 15. 2008;85(3):486-90. [pmid: 18301342].
76 Barsoum RS, Morsy AA, Iskander IR, et al. The Cairo kidney center protocol for rapamycin-based sequential immunosuppression in kidney transplant recipients: 2-year outcomes. Exp Clin Transplant. 2007;5(2):649-57. [pmid: 18194116].
77 Dudley C, Pohanka E, Riad H, et al. Mycophenolate mofetil substitution for cyclosporine A in renal transplant recipients with chronic progressive allograft dysfunction: the “creeping creatinine” study. Transplantation. Feb. 27. 2005;79(4):466-75. [pmid: 15729174].
78 Watson CJ, Firth J, Williams PF, et al. A randomized controlled trial of late conversion from CNI-based to sirolimus-based immunosuppression following renal transplantation. Am J Transplant. Oct. 2005;5(10):2496-503. [pmid: 16162200].
79 Bakker RC, Hollander AA, Mallat MJ, et al. Conversion from cyclosporine to azathioprine at three months reduces the incidence of chronic allograft nephropathy. Kidney Int. Sep. 1. 2003;64(3):1027-34. [pmid: 12911553].
80 MacPhee IA, Bradley JA, Briggs JD, et al. Long-term outcome of a prospective randomized trial of conversion from cyclosporine to azathioprine treatment one year after renal transplantation. Transplantation. Nov. 15. 1998;66(9):1186-92. [pmid: 9825816].
81 Hilbrands LB, Hoitsma AJ, Koene RA. The effect of immunosuppressive drugs on quality of life after renal transplantation. Transplantation. 1995;59(9):1263-70. [pmid: 7762059].
82 Asberg A, Apeland T, Reisaeter AV, et al. Long-term outcomes after cyclosporine or mycophenolate withdrawal in kidney transplantation - results from an aborted trial. Clin Transplant. Mar-Apr. 2013;27(2):E151-6. Epub 2013 Jan 27. [pmid: 23351013].
83 Mourer JS, Hartigh JD, Van Zwet EW, et al. Randomized trial comparing late concentration-controlled calcineurin inhibitor or mycophenolate mofetil withdrawal. Transplantation. May. 15. 2012;93(9):887-94. [pmid: 22538450].
84 Flechner SM, Glyda M, Cockfield S, et al. The ORION study: comparison of two sirolimus-based regimens versus tacrolimus and mycophenolate mofetil in renal allograft recipients. Am J Transplant. Aug. 2011;11(8):1633-44. [pmid: 21668635].
85 De Sandes Freitas TV, Harada KM, Felipe CR, et al. Steroid or tacrolimus withdrawal in renal transplant recipients using sirolimus. Int Urol Nephrol. Dec. 2011;43(4):1221-8. [pmid: 21761129].
86 Pascual J, Bloom D, Torrealba J, et al. Calcineurin inhibitor withdrawal after renal transplantation with alemtuzumab: clinical outcomes and effect on T-regulatory cells. Am J Transplant. Jul. 2008;8(7):1529-36. [pmid: 18510645].
87 Hazzan M, Buob D, Labalette M, et al. Assessment of the risk of chronic allograft dysfunction after renal transplantation in a randomized cyclosporine withdrawal trial. Transplantation. Sep. 2006;82(5):657-62. [pmid: 16969289].
88 Hazzan M, Labalette M, Copin MC, et al. Predictive factors of acute rejection after early cyclosporine withdrawal in renal transplant recipients who receive mycophenolate mofetil: results from a prospective, randomized trial. J Am Soc Nephrol. 2005;16(8):2509-16. [pmid: 15987748].
89 Suwelack B, Gerhardt U, Hohage H. Withdrawal of cyclosporine or tacrolimus after addition of mycophenolate mofetil in patients with chronic allograft nephropathy. Am J Transplant. Apr. 2004;4(4):655-62. [pmid: 15023160].
90 Stallone G, Di Paolo S, Schena A, et al. Early withdrawal of cyclosporine A improves 1-year kidney graft structure and function in sirolimus-treated patients. Transplantation. Apr. 15. 2003;75(7):998-1003. [pmid: 12698087].
91 Abramowicz D, Manas D, Lao M, et al. Cyclosporine withdrawal from a mycophenolate mofetil-containing immunosuppressive regimen in stable kidney transplant recipients: a randomized, controlled study. Transplantation. Dec. 27. 2002;74(12):1725-34. [pmid: 12499889].
92 Gonwa TA, Hricik DE, Brinker K, et al. Improved renal function in sirolimus-treated renal transplant patients after early cyclosporine elimination. Transplantation. Dec. 15. 2002;74(11):1560-7. [pmid: 12490789].
93 Schnuelle P, Van Der Heide JH, Tegzess A, et al. Open randomized trial comparing early withdrawal of either cyclosporine or mycophenolate mofetil in stable renal transplant recipients initially treated with a triple drug regimen. J Am Soc Nephrol. 2002;13(2):536-43. [pmid: 11805185].
94 Smak Gregoor PJ, De Sevaux RG, Ligtenberg G, et al. Withdrawal of cyclosporine or prednisone six months after kidney transplantation in patients on triple drug therapy: a randomized, prospective, multicenter study. J Am Soc Nephrol. 2002;13(5):1365-73. [pmid: 11961025].
95 Roodnat JI, Hilbrands LB, Hene RJ, et al. 15-year follow-up of a multicenter, randomized, calcineurin inhibitor withdrawal study in kidney transplantation. Transplantation. Jul. 15. 2014;98(1):47-53. [pmid: 24521775].
96 Johnson RW, Kreis H, Oberbauer R, et al. Sirolimus allows early cyclosporine withdrawal in renal transplantation resulting in improved renal function and lower blood pressure. Transplantation. Sep. 15. 2001;72(5):777-86. [pmid: 11571437].
97 Asher J, Vasdev N, Wyrley-Birch H, et al. A prospective randomised paired trial of sirolimus versus tacrolimus as primary immunosuppression following non-heart beating donor kidney transplantation. Curr Urol. Nov. 19. 2014;7(4):174-80. [pmid: 26195946].
98 Vincenti F, Charpentier B, Vanrenterghem Y, et al. A phase III study of belatacept-based immunosuppression regimens versus cyclosporine in renal transplant recipients (BENEFIT Study). Am J Transplant. Mar. 2010;10(3):535-46. [pmid: 20415897].
99 Larsen CP, Grinyo J, Medina-Pestana J, et al. Belatacept-based regimens versus a cyclosporine A-based regimen in kidney transplant recipients: 2-year results from the BENEFIT and BENEFIT-EXT studies. Transplantation. 2010;90(12):1528-35. [pmid: 21076381].
100 Vincenti F, Larsen CP, Alberu J, et al. Three-year outcomes from BENEFIT, a randomized, active-controlled, parallel-group study in adult kidney transplant recipients. Am J Transplant. Jan. 2012;12(1):210-7. [pmid: 21992533].
101 Rostaing L, Vincenti F, Grinyo J, et al. Long-term belatacept exposure maintains efficacy and safety at 5 years: results from the long-term extension of the BENEFIT study. Am J Transplant. Nov. 2013;13(11):2875-83. [pmid: 24047110].
102 Dobbels F, Wong S, Min Y, et al. Beneficial effect of belatacept on health-related quality of life and perceived side effects: Results from the BENEFIT and BENEFIT-EXT trials. Transplantation. 2014;98(9):960-8. [pmid: 24831918].
103 Durrbach A, Pestana JM, Pearson T, et al. A phase III study of belatacept versus cyclosporine in kidney transplants from extended criteria donors (BENEFIT-EXT Study). Am J Transplant. Mar. 2010;10(3):547-57. [pmid: 20415898].
104 Pestana JO, Grinyo JM, Vanrenterghem Y, et al. Three-year outcomes from BENEFIT-EXT: a phase III study of belatacept versus cyclosporine in recipients of extended criteria donor kidneys. Am J Transplant. Mar. 2012;12(3):630-9. [pmid: 22300431].
105 Charpentier B, Medina Pestana JO, Del C, Rial M, et al. Long-term exposure to belatacept in recipients of extended criteria donor kidneys. Am J Transplant. Nov. 2013;13(11):2884-91. [pmid: 24103072].
106 Refaie AF, Mahmoud KM, Ismail AM, et al. Alemtuzumab preconditioning allows steroid-calcineurin inhibitor-free regimen in live-donor kidney transplant. Exp Clin Transplant. Oct. 2011;9(5):295-301. [pmid: 21967254].
107 Glotz D, Charpentier B, Abramovicz D, et al. Thymoglobulin induction and sirolimus versus tacrolimus in kidney transplant recipients receiving mycophenolate mofetil and steroids. Transplantation. Jun. 27. 2010;89(12):1511-7. [pmid: 20386144].
108 Schaefer HM, Kizilisik AT, Feurer I, et al. Short-term results under three different immunosuppressive regimens at one center. Transplant Proc. Dec. 2006;38(10):3466-7. [pmid: 17175305].
109 Flechner SM, Goldfarb D, Modlin C, et al. Kidney transplantation without calcineurin inhibitor drugs: a prospective, randomized trial of sirolimus versus cyclosporine. Transplantation. Oct. 27. 2002;74(8):1070-6. [pmid: 12438948].
110 Groth CG, Backman L, Morales JM, et al. Sirolimus (rapamycin)-based therapy in human renal transplantation: similar efficacy and different toxicity compared with cyclosporine. Transplantation. Apr. 15. 1999;67(7):1036-42. [pmid: 10221490].
111 Rivelli RF, Goncalves RT, Leite M, et al. Early withdrawal of calcineurin inhibitor from a sirolimus-based immunosuppression stabilizes fibrosis and the transforming growth factor-(beta) signalling pathway in kidney transplant. Nephrology (Carlton). Mar. 1. 2015;20(3):168-76. [pmid: 25404086].
112 Burkhalter F, Oettl T, Descoeudres B, et al. High incidence of rejection episodes and poor tolerance of sirolimus in a protocol with early steroid withdrawal and calcineurin inhibitor-free maintenance therapy in renal transplantation: experiences of a randomized prospective single-center study. Transplant Proc. Dec. 2012;44(10):2961-5. [pmid: 23195006].
113 Han F, Wu J, Huang H, et al. Conversion from cyclosporine to sirolimus in chronic renal allograft dysfunction: a 4-year prospective study. Exp Clin Transplant. Feb. 2011;9(1):42-9. [pmid: 21605022].
114 Pankewycz O, Leca N, Kohli R, et al. Conversion to low-dose tacrolimus or rapamycin 3 months after kidney transplantation: a prospective, protocol biopsy-guided study. Transplant Proc. Mar. 2011;43(2):519-23. [pmid: 21440749].
115 Cataneo-Davila A, Zuniga-Varga J, Correa-Rotter R, et al. Renal function outcomes in kidney transplant recipients after conversion to everolimus-based immunosuppression regimen with CNI reduction or elimination. Transplant Proc. Dec. 2009;41(10):4138-46. [pmid: 20005355].
116 Liu M, Zhang W, Gu M, et al. Protective effects of sirolimus by attenuating connective tissue growth factor expression in human chronic allograft nephropathy. Transplant Proc. Jun. 2007;39(5):1410-5. [pmid: 17580150].
117 Hamdy AF, El Agroudy AE, Bakr MA, et al. Comparison of sirolimus with low-dose tacrolimus versus sirolimus-based calcineurin inhibitor-free regimen in live donor renal transplantation. Am J Transplant. Oct. 2005;5(10):2531-8. [pmid: 16162204].
118 Stallone G, Infante B, Schena A, et al. Rapamycin for treatment of chronic allograft nephropathy in renal transplant patients. J Am Soc Nephrol. 2005;16(12):3755-62. [pmid: 16236802].
119 Lo A, Egidi MF, Gaber LW, et al. Comparison of sirolimus-based calcineurin inhibitor-sparing and calcineurin inhibitor-free regimens in cadaveric renal transplantation. Transplantation. Apr. 27. 2004;77(8):1228-35. [pmid: 15114090].