# Forest Plots for Key Questions 3a and 3b

This Appendix includes 30 forest plots of data that were analyzed for Key Question 3a and 3b. Forest plots were generated and evaluated for every comparison and outcome that was meta-analyzed and included in the Strength of Evidence tables. For this Appendix, however, we included select comparisons and outcomes that correspond to our major findings and Key Points, and that are likely to be of greatest clinical interest.

Forest Plot F-1 Reduced CNIs vs. standard: renal function

Forest Plot 1 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, all studies of reduced CNI versus control. Data for Forest Plot 1 are presented in Table 10 and Appendix E, Table E-3. The random effects standardized mean difference was 0.32 (95% Confidence Interval 0.22 to 0.41) for the 26 studies comparing patients who received low-dose CNI therapy to patients who received standard-dose treatment. There was substantial heterogeneity across the studies (I2 = 60%).

Forest Plot F-2 Reducing CNIs vs. standard: biopsy proven acute rejection

Forest Plot 2 displays a forest plot of studies reporting the relative risk of acute rejection, all studies of reduced CNI versus control. Data for Forest Plot 2 are presented in Table 10 and Appendix E, Table E-3. The random effects relative risk was 0.84 (95% Confidence Interval 0.75 to 0.95) for the 35 studies comparing patients who received low-dose CNI therapy to patients who received standard-dose treatment. There was low heterogeneity across the studies (I2 = 19%).

Forest Plot F-3 Reduced CNIs vs. standard: graft loss

Forest Plot 3 displays a forest plot of studies reporting the relative risk of graft loss, all studies of reduced CNI versus control. Data for Forest Plot 3 are presented in Table 10 and Appendix E, Table E-3. The random effects relative risk was 0.76 (95% Confidence Interval 0.61 to 0.94) for the 36 studies comparing patients who received low-dose CNI therapy to patients who received standard-dose treatment. There was low heterogeneity across the studies (I2 = 12%).

Forest Plot F-4 Reduced cyclosporine + mycophenolic acid formulations vs. standard: renal function

Forest Plot 4 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, reduced cyclosporine and mycophenolic acid formulations versus control. Data for Forest Plot 4 are presented in Table 11 and Appendix E, Table E-3. The random effects standardized mean difference was 0.28 (95% Confidence Interval 0.10 to 0.46) for the 10 studies comparing patients who received low-dose cyclosporine with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was substantial heterogeneity across the studies (I2 = 58%).

Forest Plot F-5 Reduced cyclosporine + mycophenolic acid formulations vs. standard: biopsy proven acute rejection

Forest Plot 5 displays a forest plot of studies reporting the relative risk of acute rejection, reduced cyclosporine and mycophenolic acid formulations versus control. Data for Forest Plot 5 are presented in Table 11 and Appendix E, Table E-3. The relative risk was 0.88 (95% Confidence Interval 0.76 to 1.02) for the 14 studies comparing patients who received low-dose cyclosporine with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was no heterogeneity across the studies.

Forest Plot F-6 Reduced cyclosporine + mycophenolic acid formulations vs. standard: graft loss

Forest Plot 6 displays a forest plot of studies reporting the relative risk of graft loss, reduced cyclosporine and mycophenolic acid formulations versus control. Data for Forest Plot 6 are presented in Table 11 and Appendix E, Table E-3. The relative risk was 0.70 (95% Confidence Interval 0.55 to 0.88) for the 14 studies comparing patients who received low-dose cyclosporine with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was no heterogeneity across the studies.

Forest Plot F-7 Reduced tacrolimus + mycophenolic acid formulations vs. standard: renal function

Forest Plot 7 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, reduced tacrolimus and mycophenolic acid formulations versus control. Data for Forest Plot 7 are presented in Table 11 and Appendix E, Table E-3. The random effects standardized mean difference was 0.42 (95% Confidence Interval 0.22 to 0.62) for the 4 studies comparing patients who received low-dose tacrolimus with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was moderate heterogeneity across the studies (I2 = 29%).

Forest Plot F-8 Reduced tacrolimus + mycophenolic acid formulations vs. standard: biopsy proven acute rejection

Forest Plot 8 displays a forest plot of studies reporting the relative risk of acute rejection, reduced tacrolimus and mycophenolic acid formulations versus control. Data for Forest Plot 8 are presented in Table 11 and Appendix E, Table E-3. The relative risk was 0.76 (95% Confidence Interval 0.40 to 1.43) for the 4 studies comparing patients who received low-dose tacrolimus with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was substantial heterogeneity across the studies (I2 = 56%).

Forest Plot F-9 Reduced tacrolimus + mycophenolic acid formulations vs. standard: graft loss

Forest Plot 9 displays a forest plot of studies reporting the relative risk of graft loss, reduced tacrolimus and mycophenolic acid formulations versus control. Data for Forest Plot 9 are presented in Table 11 and Appendix E, Table E-3. The relative risk was 0.88 (95% Confidence Interval 0.32 to 2.46) for the 5 studies comparing patients who received low-dose tacrolimus with adjunctive mycophenolic acid formulations to patients who received standard-dose treatment. There was moderate heterogeneity across the studies (I2 = 47%).

Forest Plot F-10 Reduced cyclosporine + mTOR inhibitors vs. standard: renal function

Forest Plot 10 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, reduced cyclosporine and mTOR inhibitors versus control. Data for Forest Plot 10 are presented in Table 13 and Appendix E, Table E-3. The random effects standardized mean difference was 0.36 (95% Confidence Interval 0.08 to 0.64) for the 6 studies comparing patients who received low-dose cyclosporine with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was substantial heterogeneity across the studies (I2 = 69%).

Forest Plot F-11 Reduced cyclosporine + mTOR inhibitors vs. standard: biopsy proven acute rejection

Forest Plot 11 displays a forest plot of studies reporting the relative risk of acute rejection, reduced cyclosporine and mTOR inhibitors versus control. Data for Forest Plot 11 are presented in Table 13 and Appendix E, Table E-3. The relative risk was 0.88 (95% Confidence Interval 0.70 to 1.10) for the 9 studies comparing patients who received low-dose cyclosporine with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was no heterogeneity across the studies.

Forest Plot F-12 Reduced cyclosporine + mTOR inhibitors vs. standard: graft loss

Forest Plot 12 displays a forest plot of studies reporting the relative risk of graft loss, reduced cyclosporine and mTOR inhibitors versus control. Data for Forest Plot 12 are presented in Table 13 and Appendix E, Table E-3. The relative risk was 0.56 (95% Confidence Interval 0.26 to 1.18) for the 9 studies comparing patients who received low-dose cyclosporine with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was moderate heterogeneity across the studies (I2 = 31%).

Forest Plot F-13 Reduced tacrolimus + mTOR inhibitors vs. standard: renal function

Forest Plot 13 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, reduced tacrolimus and mTOR inhibitors versus control. Data for Forest Plot 13 are presented in Table 13 and Appendix E, Table E-3. The random effects standardized mean difference was 0.37 (95% Confidence Interval -0.12 to 0.85) for the 3 studies comparing patients who received low-dose tacrolimus with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was moderate heterogeneity across the studies (I2 = 23%).

Forest Plot F-14 Reduced tacrolimus + mTOR inhibitors vs. standard: biopsy proven acute rejection

Forest Plot 14 displays a forest plot of studies reporting the relative risk of acute rejection, reduced tacrolimus and mTOR inhibitors versus control. Data for Forest Plot 14 are presented in Table 13 and Appendix E, Table E-3. The relative risk was 1.50 (95% Confidence Interval 0.78 to 2.91) for the 4 studies comparing patients who received low-dose tacrolimus with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was no heterogeneity across the studies.

Forest Plot F-15 Reduced tacrolimus + mTOR inhibitors vs. standard: graft loss

Forest Plot 15 displays a forest plot of studies reporting the relative risk of graft loss, reduced tacrolimus and mTOR inhibitors versus control. Data for Forest Plot 15 are presented in Table 13 and Appendix E, Table E-3. The relative risk was 1.88 (95% Confidence Interval 0.56 to 6.39) for the 4 studies comparing patients who received low-dose tacrolimus with adjunctive mTOR inhibitors to patients who received standard-dose treatment. There was no heterogeneity across the studies.

Forest Plot F-16 Conversion from CNIs to mTOR inhibitors: renal function

Forest Plot 16 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, conversion from CNIs to mTOR inhibitors versus control. Data for Forest Plot 16 are presented in Table 16 and Appendix E, Table E-7. The random effects standardized mean difference was 0.37 (95% Confidence Interval 0.14 to 0.60) for the 17 studies comparing patients who were converted from CNI therapy to mTOR inhibitors, to patients maintained on CNI treatment. There was substantial heterogeneity across the studies (I2 = 87%).

Forest Plot F-17 Conversion from CNIs to mTOR inhibitors: biopsy proven acute rejection

Forest Plot 17 displays a forest plot of studies reporting the relative risk of acute rejection, conversion from CNIs to mTOR inhibitors versus control. Data for Forest Plot 17 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 1.38 (95% Confidence Interval 0.96 to 1.99) for the 18 studies comparing patients who were converted from CNI therapy to mTOR inhibitors, to patients maintained on CNI treatment. There was moderate heterogeneity across the studies (I2 = 49%).

Forest Plot F-18 Conversion from CNIs to mTOR inhibitors: graft loss

Forest Plot 18 displays a forest plot of studies reporting the relative risk of graft loss, conversion from CNIs to mTOR inhibitors versus control. Data for Forest Plot 18 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 1.11 (95% Confidence Interval 0.73 to 1.69) for the 14 studies comparing patients who were converted from CNI therapy to mTOR inhibitors, to patients maintained on CNI treatment. There was very low heterogeneity across the studies (I2 = 2%).

Forest Plot F-19 Conversion from tacrolimus to mTOR inhibitors: renal function

Forest Plot 19 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, conversion from tacrolimus to mTOR inhibitors versus control. Data for Forest Plot 19 are presented in Table 16 and Appendix E, Table E-7. The random effects standardized mean difference was -0.11 (95% Confidence Interval -0.47 to 0.25) for the 3 studies comparing patients who were converted from tacrolimus to mTOR inhibitors, to patients maintained on tacrolimus. There was no heterogeneity across the studies.

Forest Plot F-20 Conversion from tacrolimus to mTOR inhibitors: biopsy proven acute rejection

Forest Plot 20 displays a forest plot of studies reporting the relative risk of acute rejection, conversion from tacrolimus to mTOR inhibitors versus control. Data for Forest Plot 20 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 1.75 (95% Confidence Interval 0.35 to 8.08) for the 3 studies comparing patients who were converted from tacrolimus to mTOR inhibitors, to patients maintained on tacrolimus. There was no heterogeneity across the studies.

Forest Plot F-21 Conversion from tacrolimus to mTOR inhibitors: graft loss

Forest Plot 21 displays a forest plot of studies reporting the relative risk of graft loss, conversion from tacrolimus to mTOR inhibitors versus control. Data for Forest Plot 21 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 0.88 (95% Confidence Interval 0.55 to 1.39) for the 3 studies comparing patients who were converted from tacrolimus to mTOR inhibitors, to patients maintained on tacrolimus. There was no heterogeneity across the studies.

Forest Plot F-22 Conversion from cyclosporine to mTOR inhibitors: renal function

Forest Plot 22 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, conversion from cyclosporine to mTOR inhibitors versus control. Data for Forest Plot 22 are presented in Table 16 and Appendix E, Table E-7. The random effects standardized mean difference was 0.62 (95% Confidence Interval 0.23 to 1.01) for the 8 studies comparing patients who were converted from cyclosporine to mTOR inhibitors, to patients maintained on cyclosporine. There was substantial heterogeneity across the studies (I2 = 86%).

Forest Plot F-23 Conversion from cyclosporine to mTOR inhibitors: biopsy proven acute rejection

Forest Plot 23 displays a forest plot of studies reporting the relative risk of acute rejection, conversion from cyclosporine to mTOR inhibitors versus control. Data for Forest Plot 23 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 1.37 (95% Confidence Interval 0.76 to 2.46) for the 9 studies comparing patients who were converted from cyclosporine to mTOR inhibitors, to patients maintained on cyclosporine. There was substantial heterogeneity across the studies (I2 = 64%).

Forest Plot F-24 Conversion from cyclosporine to mTOR inhibitors: graft loss

Forest Plot 24 displays a forest plot of studies reporting the relative risk of graft loss, conversion from cyclosporine to mTOR inhibitors versus control. Data for Forest Plot 24 are presented in Table 16 and Appendix E, Table E-7. The relative risk was 1.27 (95% Confidence Interval 0.42 to 3.81) for the 7 studies comparing patients who were converted from cyclosporine to mTOR inhibitors, to patients maintained on cyclosporine. There was substantial heterogeneity across the studies (I2 = 25%).

Forest Plot F-25 CNI withdrawal + mycophenolate: renal function

Forest Plot 25 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, withdrawal of CNIs with adjunctive use of mycophenolate versus control. Data for Forest Plot 25 are presented in Table 18 and Appendix E, Table E-11. The random effects standardized mean difference was 0.49 (95% Confidence Interval 0.26 to 0.72) for the 5 studies comparing patients who were withdrawn from CNIs with adjunctive use of mycophenolate, to patients maintained on CNIs. There was low heterogeneity across the studies (I2 = 21%).

Forest Plot F-26 CNI withdrawal + mycophenolate: biopsy proven acute rejection

Forest Plot 26 displays a forest plot of studies reporting the relative risk of acute rejection, withdrawal of CNIs with adjunctive use of mycophenolate versus control. Data for Forest Plot 26 are presented in Table 18 and Appendix E, Table E-11. The relative risk was 3.17 (95% Confidence Interval 1.78 to 5.66) for the 9 studies comparing patients who were withdrawn from CNIs with adjunctive use of mycophenolate, to patients maintained on CNIs. There was moderate heterogeneity across the studies (I2 = 46%).

Forest Plot F-27 CNI withdrawal + mycophenolate: graft loss

Forest Plot 27 displays a forest plot of studies reporting the relative risk of graft loss, withdrawal of CNIs with adjunctive use of mycophenolate versus control. Data for Forest Plot 27 are presented in Table 18 and Appendix E, Table E-11. The relative risk was 1.35 (95% Confidence Interval 0.80 to 2.26) for the 9 studies comparing patients who were withdrawn from CNIs with adjunctive use of mycophenolate, to patients maintained on CNIs. There was no heterogeneity across the studies.

Forest Plot F-28 CNI withdrawal + mTOR inhibitors: renal function

Forest Plot 28 displays a forest plot of studies reporting the standardized mean difference of the estimated glomerular filtration rate, withdrawal of CNIs with adjunctive use of mTOR inhibitors versus control. Data for Forest Plot 28 are presented in Table 18 and Appendix E, Table E-11. The random effects standardized mean difference was 0.16 (95% Confidence Interval -0.25 to 0.57) for the 5 studies comparing patients who were withdrawn from CNIs with adjunctive use of mTOR inhibitors, to patients maintained on CNIs. There was substantial heterogeneity across the studies (I2 = 69%).

Forest Plot F-29 CNI withdrawal + mTOR inhibitors: biopsy proven acute rejection

Forest Plot 29 displays a forest plot of studies reporting the relative risk of acute rejection, withdrawal of CNIs with adjunctive use of mTOR inhibitors versus control. Data for Forest Plot 29 are presented in Table 18 and Appendix E, Table E-11. The relative risk was 1.71 (95% Confidence Interval 1.19 to 2.45) for the 6 studies comparing patients who were withdrawn from CNIs with adjunctive use of mTOR inhibitors, to patients maintained on CNIs. There was low heterogeneity across the studies (I2 = 5%).

Forest Plot F-30 CNI withdrawal + mTOR inhibitors: graft loss

Forest Plot 30 displays a forest plot of studies reporting the relative risk of graft loss, withdrawal of CNIs with adjunctive use of mTOR inhibitors versus control. Data for Forest Plot 30 are presented in Table 18 and Appendix E, Table E-11. The relative risk was 0.97 (95% Confidence Interval 0.45 to 2.09) for the 6 studies comparing patients who were withdrawn from CNIs with adjunctive use of mTOR inhibitors, to patients maintained on CNIs. There was moderate heterogeneity across the studies (I2 = 30%).