# Evidence Tables for Key Questions 3a and 3b

Table E-1 Study design characteristics of minimization studies

Reference | Type of Intervention | Intervention Regimen | Control Regimen | Analytical Method for Measuring Therapeutic Drug Levels | Induction Therapy | Time from Transplant to Start of Intervention | Special Inclusion/Exclusion Criteria
Cai et al. 2014^18^ | Minimization of CsA | CsA (75–90 ng/mL, C2 target 350–400 ng/mL) + EC-MPS (1,440 mg) + STER (5 mg) | CsA (150–180 ng/mL, C2 target 700–800 ng/mL) + EC-MPS (1,440 mg) + STER (5 mg) | NR | NR | 3 days | Excluded age>72, PRA >20%
Chadban et al. 2014^19^ | Minimization of CsA | CsA (50% reduction from baseline) + EVR (6–10 ng/mL) + withdrawal of EC-MPS and STER | CsA (C2 target 500–700 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 2 weeks | Excluded age>65, PRA >50%, retransplants
Muhlbacher et al. 2014^20^ | Minimization of CsA | CsA (75–100 ng/mL) + SRL (4–12 ng/mL) + STER | CsA (150–200 ng/mL) + SRL (4–12 ng/mL)+ STER | IA | NR | 1 month | Excluded PRA >50%, African-Americans
Oh et al. 2014^21^ | Minimization of CsA | CsA (25–50 ng/mL) + EVR (3–8 ng/mL) + STER (prednisolone ≥5 mg) | CsA (100–200 ng/mL) + EC-MPS (720–1,440 mg) + STER (prednisolone ≥5 mg) | NR | Basiliximab | 1 month | Excluded age>65, retransplants
Bechstein et al. 2013^22^ | Minimization of TAC | TAC (3–7 ng/mL) + SRL (8–15 ng/mL) + STER (prednisone 5 mg) | TAC (8–12 ng/mL) + SRL (5–10 ng/mL) + STER (prednisone 5 mg) | HP/LC-MS | Not used | Within 7 days | Excluded PRA>50% and “Patients at high risk”
Chadban et al. 2013^23^ | Minimization of CsA | CsA (C2 target 550–700 ng/mL) + EC-MPS (1,440 mg) + STER | CsA (C2 target 850–1,000 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 4 weeks | Excluded age>75, PRA>50%, retransplants
Cibrik et al. 2013^24^ | Minimization of CsA | CsA (25–50 ng/mL) + EVR (3–8 ng/mL OR 6–12 ng/mL) + STER | CsA (100–250 ng/mL) + MPA (1,440 mg) + STER | LC-MS | Basiliximab | 24 hours | Excluded age>70, PRA>50%
Takahashi et al. 2013^25^ | Minimization of CsA | CsA (25–50 ng/mL) + EVR (3–8 ng/mL) + STER (minimum 5 mg) | CsA (100–250 ng/mL) + MMF (2,000 mg) + STER (minimum 5 mg) | NR | Basiliximab | 24 hours | Excluded age>65, PRA >50%, delayed graft function
Chan et al. 2012^26^ | Minimization of TAC | TAC (3–6 ng/mL) + EC-MPS (1,440 mg) + STER (prednisone 5 mg) | TAC (8–12 ng/mL) + EC-MPS (1,440 mg) + STER (prednisone 5 mg) | NR | Basiliximab | 24 hours | Excluded age>70, PRA >20%, retransplants
Kamar et al. 2012^27^ | Minimization of TAC | TAC (2–4.5 ng/mL) + EC-MPS (1,440 mg) + STER | TAC (5.5–10 ng/mL) + EC-MPS (720 mg) + STER | IA | NR | Minimum 1 year | Excluded age>75
Langer et al. 2012^28^ | Minimization of TAC | TAC (1.5–3 ng/mL) + EVR (3–8 ng/mL) + STER (prednisone 5 mg) | TAC (4–7 ng/mL) + EVR (3–8 ng/mL) + STER (prednisone 5 mg) | LC-MS | Basiliximab | 3 months | Excluded PRA >50%, retransplants
Paoletti et al. 2012^29^ | Minimization of CsA | CsA (50–100 ng/mL) + EVR (3–8 ng/mL) + STER | CsA (125–250 ng/mL) + MMF (dose not reported) + STER | NR | Basiliximab | Immediate | Excluded age>70
Bertoni et al. 2011^30^ | Minimization of CsA | CsA (C2 target 250–300 ng/mL) + EVR (8–12 ng/mL) + STER | CsA (C2 target 500–700 ng/mL) + EC–MPS (1,440 mg) + STER | NR | Basiliximab | Immediate | Excluded age>65, PRA >50%, retransplants
Holdaas et al. 2011^31^ | Minimization of CNI | CNI (CsA or TAC) at 70%–90% reduction from baseline + EVR (3–8 ng/mL) + prior therapy (could include MPA, AZA, and/or STER) | CsA (C2 target ≥400 ng/mL) or TAC (≥4 ng/mL) + prior therapy (could include MPA, AZA, and/or STER) | NR | NR | Minimum 6 months | NR
Xu et al. 2011^32^ | Minimization of CNI | CNI (CsA 80–120 ng/mL or TAC 3–6 ng/mL) + MMF (1,500 mg) + STER (prednisone 5 mg) | CNI (CsA 120–180 ng/mL or TAC 6–10 ng/mL) + MMF (1,500 mg) + STER (prednisone 5 mg) | IA | NR | Immediate | Excluded retransplants
Etienne et al. 2010^33^ | Minimization of CsA | CsA (2.0–2.6 mg h/L) + MMF (2,000 mg) | CsA (3.5–4.8 mg h/L) + MMF (2,000 mg) | LC-MS | rATG (72%) Interleukin-2 receptor antagonists (28/%) | 1 year | Excluded age>75, PRA>80%
Fangmann et al. 2010^34^ | Minimization of CsA | CsA (50–75 ng/mL) + MMF (2,000 mg) + STER (minimum 5mg) | CsA (100–150 ng/mL) + MMF (2,000) + STER (minimum 5mg) | NR | Daclizumab in intervention group | Shortly after transplant | Excluded PRA >20%, retransplants
Gaston et al. 2009^35^ | Minimization of CNI | CNI (CsA 95–145 ng/mL or TAC 3–5 ng/mL) + MMF (≥1.3 μg/mL for patients on CsA or ≥1.9 μg/mL for patients on TAC) + STER | CNI (CsA 190–220 ng/mL or TAC 6–8 ng/mL) + either MMF (≥1.3 μg/mL for patients on CsA or ≥1.9 μg/mL for patients on TAC) or MMF fixed dose (mean 1,834 mg for patients on CsA or mean 1,663 mg for patients on TAC) + STER (both comparison groups) | NR | “administered according to center practice” | Within 24 hours | NR
Salvadori et al. 2009^36^ | Minimization of CsA | CsA (C2 target 150–300 ng/mL) + EVR (8–12 ng/mL) + STER (prednisone 5 mg) | CsA (C2 target 350–450 ng/mL) + EVR (3–8 ng/mL) + STER (prednisone 5 mg) | NR | Basiliximab | Within 24 hours | Excluded age>65, PRA >50%
Spagnoletti et al. 2009^37^ | Minimization of CNI and switch from CsA to TAC | TAC (5–8 ng/mL) + MMF (1,000 mg) + STER | CsA (C2 target 150–400 ng/mL) + EVR (3–8 ng/mL) + STER | NR | Basiliximab | 24 hours | NR
Bolin et al. 2008^38^ | Minimization of TAC | TAC (3.0–5.9 ng/mL) + continuation of previous adjunct therapy (AZA, MMF, SRL, and/or STER) | TAC (6.0–8.9 ng/mL) or CsA (50–250 ng/mL) + continuation of previous adjunct therapy (AZA, MMF, SRL, and STER) | NR | NR | Minimum 6 months | NR
Chan et al. 2008^39^ | Minimization of TAC | TAC (3–6 ng/mL) + EVR (3–12ng/mL) + STER (≥5 mg) | TAC (7–10 ng/mL) + EVR (3–12ng/mL) + STER (≥5 mg) | LC-MS | Basiliximab | Within 24 hours | Excluded age>65, PRA >50%
Budde et al. 2007^40^ | Minimization of CsA | CsA (C2 target 550–700 ng/mL) + EC-MPS (1,440 mg) + STER | CsA (C2 target 850–1,000 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 2 months | Excluded age>75, PRA >50%
Cibrik et al. 2007^41^ | Minimization of CsA | CsA (C2 target 600–800 ng/mL) + EC-MPS (1,440 mg; high risk patients could receive up to 2,160 mg) + STER | CsA (C2 target 800–1,000 ng/mL) + EC-MPS (1,440 mg; high risk patients could receive up to 2,160 mg) + STER | HPLC or IA | Basiliximab | 2 months | Excluded age>70, PRA >20%
Ekberg et al. 2007a42 | Minimization of CsA | CsA (50–100 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | CsA (100–200 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | NR | Daclizumab in intervention group | Immediate | Excluded PRA >20%, retransplants
Ekberg et al. 2007b43 | Minimization of CNI | CsA (50–100 ng/mL) or TAC (3–7 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | CsA (100–200 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | IA | Daclizumab in intervention group | Immediate | Excluded age>75, PRA >20%
Ghafari et al. 2007^44^ | Minimization of CsA | CsA (125–175 ng/mL) + MMF (30 mg/kg) + STER (methylprednisone 0.10 mg) | CsA (150 ng/mL) + MMF (30 mg/kg) + STER (methylprednisone 0.10 mg) | IA | None used | Immediate | Excluded retransplants
Hernandez et al. 2007^45^ | Minimization of CNI | CsA (125–175 ng/mL) or TAC (7–10 ng/mL) + MMF (2,000 mg) + STER (prednisone 5–10 mg) | CsA (150–200 ng/mL) + AZA (1.5 mg/kg/day) + STER (prednisone 5–10 mg) | IA | Basiliximab (intervention group) and ATG (control group) | Within 24 to 48 hours | Excluded PRA >30%
Frimat et al. 2006^46^ Frimat et al. 2010^47^ | Minimization of CsA | CsA (reduced by 50% from previous regimen) + MMF (2,000 mg) + STER | CsA with or without AZA + STER | NR | NR | Minimum 1 year | All patients had chronic allograft dysfunction; excluded age>65
Tang et al. 2006^48^ | Minimization of CsA | CsA (80–100 ng/mL) + “other medications according to centre protocol” including MMF, AZA | Conversion from previous CsA regimen to TAC (6–8 ng/mL) | IA | NR | Minimum 12 months | All patients had chronic allograft dysfunction; excluded age>65
Vathsala et al. 2005^49^ | Minimization of CsA | CsA (90–110 ng/mL) + Alemtuzumab (20 mg twice) | CsA (180–225 ng/mL) + AZA (1 mg/kg/day) + STER | NR | Alemtuzumab in intervention group | Immediate | Excluded age>65, PRA >85%
Lo et al. 2004^50^ | Minimization of TAC | TAC (5–10 ng/mL) + SRL (10–15 ng/mL) + STER (prednisone 5 mg) | TAC (10–15 ng/mL) + SRL (5–10 ng/mL) + STER (prednisone 5 mg) | IA (TAC) HPLC (SRL) | rATG | Within 2 days | NR
Nashan et al. 2004^51^ | Minimization of CsA | CsA (50–100 ng/mL) + EVR (3 mg) + STER (prednisone ≥ 5 mg) | CsA (125–250 ng/mL) + EVR (3 mg) + STER (prednisone ≥ 5 mg) | NR | Basiliximab | Within 24 hours | Excluded age>65, PRA >80%
Stoves et al. 2004^52^ | Minimization of CsA | CsA (75–100 ng/mL) + MMF (2,000 mg) | CsA (“per unit protocol”; data not reported) + AZA | NR | NR | Minimum 6 months | All patients had chronic allograft dysfunction
Pascual et al. 2003^53^ | Minimization of CsA | CsA (50–150 ng/mL) + MMF (1,500–2,000 mg) + STER (prednisone 7.5–10 mg) | CsA (100–300 ng/mL) + MMF (1,500–2,000 mg) + STER (prednisone 7.5–10 mg) | IA | NR | Minimum 12 months | NR
de Sevaux et al. 2001^54^ | Minimization of CsA | CsA (150 ng/mL) + MMF (2,000 mg) + STER (prednisone 0.1 mg/kg) | CsA (150 ng/mL) + MMF (2,000 mg) + STER (prednisone 0.1 mg/kg) | IA | NR | 48 hours | NR

AR=acute rejection; AZA=azathioprine; ATG/rATG=antithymocyte globulin; CNI=calcineurin inhibitors; CsA=cyclosporine; EC-MPS=enteric-coated mycophenolate sodium; EVR=everolimus; h/L=hectoliter; HPLC=high performance liquid chromatography; IA=immunoassay; LC=liquid chromatography; mg=milligram; mg/kg=milligram per kilogram; MMF=mycophenolate mofetil group; MPA=medroxyprogesterone acetate; MPS=mycophenolate sodium; MS=mass spectrometry; ng/mL=nanogram per milliliter; NR=not reported; PRA=panel reactive antibody; SRL=sirolimus; STER=steroid; TAC=tacrolimus; μg/mL=micrograms per milliliter

Table E-2 Study population characteristics of minimization studies

Reference | Type of Intervention | Country/Region | N, Intervention | N, Control | Donor Type | Mean Age, Intervention vs. Control | Gender: % Male | Race: % Caucasian | Delayed Graft Function %, Intervention vs. Control
Cai et al. 2014^18^ | Minimization of CsA | China | 90 | 90 | Living related Living unrelated | 34 vs. 33 | 73% | NR | 12% vs. 18%
Chadban et al. 2014^19^ | Minimization of CsA | Asia Australia New Zealand | 30 | 47 | Deceased: 52 Living related: 51 Living unrelated: 23 | 43 vs. 46 | 71% | 51% | NR
Muhlbacher et al. 2014^20^ | Minimization of CsA | Europe | 178 | 179 | Deceased: 314 Living related: 39 Living unrelated: 2 | 47 vs. 46 | 68% | 94% | 6% vs. 9%
Oh et al. 2014^21^ | Minimization of CsA | Korea | 67 | 72 | Deceased: 25 Living related: 79 Living unrelated: 35 | 42 vs. 47 | 60% | NR | NR
Bechstein et al. 2013^22^ | Minimization of TAC | Europe | 63 | 65 | Deceased | 48 vs. 45 | 65% | 100% | 30% vs. 31%
Chadban et al. 2013^23^ | Minimization of CsA | Australia | 42 | 33 | Deceased: 41 Living: 34 | 44 vs. 48 | 63% | 85% | NR
Cibrik et al. 2013^24^ | Minimization of CsA | Worldwide | 556 | 277 | Deceased: 385 Living related: 311 Living unrelated: 135 | 46 vs. 45 vs. 47 | 67% | 68% | NR
Takahashi et al. 2013^25^ | Minimization of CsA | Japan | 61 | 61 | Deceased: 2 Living related: 79 Living unrelated: 41 | 42 vs. 39 | 68% | NR | NR
Chan et al. 2012^26^ | Minimization of TAC | USA | 151 | 141 | Deceased, living related and living unrelated | 48 vs. 45 | 69% | 86% | 24% overall
Kamar et al. 2012^27^ | Minimization of TAC | France | 45 | 47 | Deceased: 88 Live unrelated: 4 | 51 vs. 54 | 66% | 96% | NR
Langer et al. 2012^28^ | Minimization of TAC | Worldwide | 107 | 117 | Deceased: 160 Living related: 39 Living unrelated: 25 | 45 vs. 47 | 57% | 83% | NR
Paoletti et al. 2012^29^ | Minimization of CsA | Italy | 10 | 20 | Deceased | 47 vs. 51 | 70% | NR | NR
Bertoni et al. 2011^30^ | Minimization of CsA | Italy | 56 | 50 | NR | 46 vs. 50 | NR | NR | 23% vs. 41%
Holdaas et al. 2011^31^ | Minimization of CNI | Worldwide | 144 | 123 | Deceased: 158 Living: 107 Missing: 4 | 50 vs. 48 | 65% | 72% | NR
Xu et al. 2011^32^ | Minimization of CNI | China | 20 | 18 | Living related | 29 vs. 32 | 82% | NR | NR
Etienne et al. 2010^33^ | Minimization of CsA | France | 106 | 102 | Deceased | 52 vs. 51 | 69% | 98% | 3% vs. 4%
Fangmann et al. 2010^34^ | Minimization of CsA | Europe | 75 | 73 | Deceased | 52 vs. 54 | 62% | NR | 27% vs. 27%
Gaston et al. 2009^35^ | Minimization of CNI | USA | 243 | 477 | Deceased: 361 Living related: 206 Living unrelated: 148 | 48 vs. 49 (MMF concentration controlled) vs. 50 (MMF fixed dose) | 67% | 69% | NR
Salvadori et al. 2009^36^ | Minimization of CsA | Italy | 143 | 142 | Deceased: 278 Living: 7 | 45 vs. 46 | 40% | 64% | 23% vs. 31%
Spagnoletti et al. 2009^37^ | Minimization of CNI and switch from CsA to TAC | Italy | 30 | 30 | Deceased | NR | NR | 100% | NR
Bolin et al. 2008^38^ | Minimization of TAC | USA | 100 | 223 | Deceased: 168 Live: 155 | 50 vs. 48 (TAC) vs. 51 (CsA) | 66% | 73% | NR
Chan et al. 2008^39^ | Minimization of TAC | USA | 49 | 43 | Deceased: 31 Living related: 36 Living unrelated: 25 | 47 vs. 47 | 62% | 66% | DGF Intervention: 4 (8.2%) of Control: 4 (9.3%)
Budde et al. 2007^40^ | Minimization of CsA | Germany | 44 | 45 | Deceased: 64 Living: 35 | 45 vs. 49 | 69% | 93% | NR
Cibrik et al. 2007^41^ | Minimization of CsA | USA | 75 | 66 | Deceased: 73 Living related: 62 Living unrelated: 29 | 49 vs. 47 | 61% | 61% | NR
Ekberg et al. 2007a42 | Minimization of CsA | Worldwide | 183 | 173 | Deceased: 277 Living related: 47 Living unrelated: 32 | 48 vs. 49 | 65% | 84% | 20% vs. 22%
Ekberg et al. 2007b43 | Minimization of CNI | Worldwide | CsA: 399 TAC: 401 | 390 | Deceased: 764 Living related: 345 Living unrelated: 79 | 47 (CsA) vs. 45 (TAC) vs. 46 | 65% | 93% | NR
Ghafari et al. 2007^44^ | Minimization of CsA | Iran | 42 | 48 | Living | 49 vs. 47 | 47% | NR | NR
Hernandez et al. 2007^45^ | Minimization of CNI | Spain | 160 | 80 | Deceased | 48 vs. 47 vs. 47 | 64% | NR | 32% vs. 40% vs. 27%
Frimat et al. 2006^46^ Frimat et al. 2010^47^ | Minimization of CsA | France | 70 | 31 | Deceased Living | 44 vs. 45 | 81% | NR | NR
Tang et al. 2006^48^ | Minimization | Hong Kong | 18 | 16 | Deceased: 26 Living related: 8 | 45 vs. 48.5 | 62% | NR | NR
Vathsala et al. 2005^49^ | Minimization of CsA | Asia | 20 | 10 | Deceased: 14 Living related: 14 Living unrelated: 2 | Median: 38 vs. 41 | 50% | NR | 20% vs. 10%
Lo et al. 2004^50^ | Minimization of TAC | USA | 23 | 16 | Deceased | Median: 49 vs. 46 | 59% | 21% | 57% vs. 63%
Nashan et al. 2004^51^ | Minimization of CsA | USA Europe | 58 | 53 | Deceased: 89 Living related: 17 Living unrelated: 5 | 44 vs. 46 | 61% | 75% | NR
Stoves et al. 2004^52^ | Minimization of CsA | United Kingdom | 13 | 16 | NR | NR | NR | NR | NR
Pascual et al. 2003^53^ | Minimization of CsA | USA | 32 | 32 | Deceased: 37 Living related: 18 Living unrelated: 9 | 47 vs. 45 | 75% | 64% | 0 vs. 3%
de Sevaux et al. 2001^54^ | Minimization of CsA | Netherlands | 152 | 161 | Deceased: 233 Living: 80 | 49 vs. 48 | 62% | NR | NR

CNI=calcineurin inhibitors; CsA=cyclosporine; DGF=delayed graft function; MMF=mycophenolate mofetil group; NR=not reported; TAC=tacrolimus

Table E-3 Clinical outcomes of minimization studies

Reference | Length of Followup | Achievement of CNI Target Levels | Treatment Failure Composite | Biopsy Proven Acute Rejection | Graft Loss | Patient Death | Mean eGFR or Creatinine Clearance, mL/min (method) | Mean Serum Creatinine, μmol/L | Regimen Changed | Other
Cai et al. 2014^18^ | 1 year | Mean CsA C2 level: 363±149 ng/mL vs. 739±174 ng/mL | 12/90 vs. 15/90 (BPAR, graft loss, patient death, lost to follow up) | 10 vs. 12 | 1 vs. 2 | 1 vs. 1 | 63±19 vs. 59±15 (Cockcroft-Gault) | 137±176 vs. 142±118 | 19 vs. 20 | NR
Chadban et al. 2014^19^ | 1 year | | 11 vs. 8 | 5 vs. 6 Banff (year not reported): Grade 1A: 5 vs. 3 Grade 1B: 0 vs. 4 Grade 2A: 0 vs. 0 Grade 2B: 0 vs. 1 Grade 3: 0 vs. 1 Unspecified: 0 vs. 2 | 0 vs. 2 | 0 vs. 1 | NR | NR | NR | NR
Muhlbacher et al. 2014^20^ | 1 year | Mean CsA level lower in intervention group, specific data NR | NR | 20/178 vs. 29/179, p=NS Bannf 97: Grade 1A: 9 vs. 14; Grade 1B: 3 vs. 9; Grade 2A: 4 vs. 3; Grade 2B: 3 vs. 2; Grade 3: 1 vs. 1 | 6 months: 0 vs. 2 12 months: 1 vs. 2 | 6 months: 0 12 months: 0 vs. 3 | 6 months: 55.9±1.67 vs. 51.0±1.67, p=0.04 12 months: 57.8±1.78 vs. 49.5±2.46, p<0.01 (Nankivell) | 6 months: 1.79 vs. 2.00, p=0.03 12 months: 1.75 vs. 1.97, p<0.01 | NR | NR
Oh et al. 2014^21^ | 1 year | Mean trough level: 54.1 ng/mL vs. 120.4 ng/mL Intervention group mean above target range, but lower than control group (p<0.01) | NR | 5/67 vs. 8/72 | 0 vs. 1 | 0 | 5 months: 66.7±17.5 vs. 59.5±16.4, p=0.02 12 months: 69.5±17.2 vs. 61.2±17.9, p=0.01 (MDRD) | NR | NR | NR
Bechstein et al. 2013^22^ | 6 months | Mean TAC levels achieved throughout study | NR | 11/63 vs. 5/65 Banff 97: Grade 1A: 4 vs. 4; Grade 2A: 5 vs. 0; Grade 2B: 2 vs. 1 | 4 vs. 1 | 3 vs. 2 | 63.8±17.3 vs. 52.7±18.9, p=0.005 (Nankivell) | 136 vs. 153, p=NS | NR | NR
Chadban et al. 2013^23^ | 1 year | Mean C2 target achieved in both groups: 640±216 vs. 876±250 | 6 months: 15/42 vs. 10/33 12 months: 18 vs. 12 (BPAR, graft loss, patient death) | 6 months: 12 vs. 8 12 months: 15 vs. 10 | 6 month: 3 vs. 1 12 months: 3 vs. 1 | 6 months: 0 vs. 1 12 months: 0 vs. 1 | 6 months: 63.2±24.3 vs. 60.2±17.6 12 months: 60.7±20.1 vs. 63.3±17.5 (Cockcroft-Gault) | NR | 8 vs. 13 | NR
Cibrik et al. 2013^24^ | 2 years | Mean trough CsA level: 42.7 ng/mL (low EVR) vs. 47.9 ng/mL (high EVR) vs. 120.5 ng/mL (standard dose EVR and CsA) | 91/277 (low EVR) vs. 75/279 (high EVR) vs. 76/277 (standard) (BPAR, graft loss, patient death, lost to follow-up) | 55 (low EVR) vs. 42 (high EVR) vs. 53 (standard) Banff 03: Grade 1A: 25 vs. 20 vs. 27 Grade 1B: 13 vs. 10 vs. 8 Grade 2A: 10 vs. 9 vs. 17 Grade 2B: 2 vs. 4 vs. 3 Grade 3: 2 vs. 0 vs. 2 | 16 (low EVR) vs. 17 (high EVR) vs. 11 (standard) | 9 (low EVR) vs. 10 (high EVR) vs. 8 (standard) | Median: 54.0 vs. 55.4 vs. 51.4 (MDRD) Median: 64.7 vs. 64.4 vs. 62.1 (Nankivell) Median: 67.4 vs. 66.4 vs. 65.0 (Cockcroft-Gault) | NR | 80 vs. 85 vs. 57, p<0.05 compared with both groups | NR
Takahashi et al. 2013^25^ | 1 year | Median CsA trough level: 63.0 ng/mL vs. 130.5 ng/mL, but “a higher proportion of EVR patients were above the cyclosporine target range versus the MMF group” | 7/61 vs. 7/61 (BPAR, graft loss, patient death, lost to follow-up) | 3 vs. 5 Banff 03: Grade 1A: 2 vs. 2 Grade 1B: 0 vs. 1 Grade 2A: 1 vs. 2 | 0 | 0 | 62.09±18.99 vs. 56.34±15.23, p=NS (MDRD) | NR | 9 vs. 8 | NR
Chan et al. 2012^26^ | 6 months | 24%–52% of intervention group exceeded trough target; 31%–53% of control group below trough target | 22/151 vs. 16/141 (BPAR, graft loss, patient death) | 16 vs. 14 Banff 97: Grade 1A: 6 vs. 6 Grade 1B: 2 vs. 3 Grade 2A: 5 vs. 3 Grade 2B: 2 vs. 2 Missing: 1 vs. 0 | 6 vs. 2 | 1 vs. 2 | 63.6±4.8 vs. 61.0±4.9, p=NS (Nankivell) 62.1 vs. 59.5, p=NS (Cockcroft-Gault) | 144 vs. 135, p=NS | 4 vs. 4 | NR
Kamar et al. 2012^27^ | 6 months | Mean TAC levels for intervention group not reached until 3 months into study | NR | 0 | 0 | 0 | 6 months: 49.1±11.1 vs. 44.7±11.5, p=0.07 Change from baseline: 2.48±0.95 vs. -0.48±0.93, p=0.03 (aMDRD) | 6 months: 137±33 vs. 147±39, p=0.30 Change from baseline: 6.2±2.8 vs. 4.3±2.8, p=0.01 | 2 vs. 1 | NR
Langer et al. 2012^28^ | 1 year | 56% of intervention group exceeded trough target; 30% of control group not in target range | 5/107 vs. 4/117 (BPAR, graft loss, patient death, lost to follow-up) Treatment/Efficacy failure: 29 vs. 14 [12 months] | 2 vs. 1 | 1 vs. 1 | 2 vs. 1 | 57.1±19.5 vs. 51.7±20 (MDRD) 67.1 ±23.0 vs. 61.1±19.7 (Cockcroft-Gault) | 1.44±0.51 mg/dL vs. 1.60±0.71 mg/dL | 19 vs. 12 | NR
Paoletti et al. 2012^29^ | 1 year | NR | NR | 1/10 vs. 2/20 | 0 | 0 | NR | Change from baseline: -0.04±0.4 mg/dL vs. -0.08±0.3 mg/dL, p=NS | 0 vs. 1 | NR
Bertoni et al. 2011^30^ | 1 year | NR | NR | 11/56 vs. 9/50 | 3 vs. 6 | NR | 81.64±32.67 vs. 62.62±22.81, p<0.01 (Cockcroft-Gault) | NR | 5 vs. 3 | Mean length of hospital stay: 24.77±11.13 days vs. 24.57±12.20 days
Holdaas et al. 2011^31^ | 2 years | CsA dose reduced by mean 78%, TAC by mean 66% | 17/144 vs. 11/123 | 8 vs. 3 Grade 1A: 4 vs. 1 Grade 2A: 2 vs. 0 Grade 3: 1 vs. 0 Missing: 1 vs. 2 | 8 vs. 6 | 3 vs. 0 | 52.0±18.7 vs. 53.6±21.1 (Cockcroft-Gault) | 171±102 vs. 168±81 | 25 vs. 5 | NR
Xu et al. 2011^32^ | 1 year | NR | NR | 4/20 vs. 3/18 | 0 vs. 1 | 0 vs. 1 | 59.4±27.4 vs. 58.9±29.8 | No significant difference | NR | NR
Etienne et al. 2010^33^ | 2 years | Intervention group mean trough levels were significantly lower than control group, p<0.01 | 19/106 vs. 37/101, p<0.01 (BPAR, graft loss, CsA toxicity, >15% increase in mean SCr) | 6 vs. 3 Bannf 97: Grade 1: 0 vs. 2 Grade 2: 5 vs. 1 Grade 3: 1 vs. 0 | 0 vs. 1 | NR | Change from baseline: 0.57±8.80 vs. -4.27±8.06 | Change from baseline: 0±0.34 mg/dL vs. 0.18±0.82 mg/dL | NR | CAN: 2 vs. 2
Fangmann et al. 2010^34^ | 1 year | NR | NR | 2/75 vs. 19/73, p<0.05 | 5 vs. 15 | 2 vs. 5 | 34.1±17.4 vs. 29.4±16.5, p<0.05 (Cockcroft-Gault) | NR | 4 vs. 8 | NR
Gaston et al. 2009^35^ | 1 year | Mean target for intervention group not achieved, but was statistically significantly lower than both comparison groups | 55/243 vs. 137/477 (BPAR, graft loss, patient death, lost to follow-up, withdrawn consent) | 15 vs. 46 | 5 vs. 8 | 4 vs. 8 | Change from baseline: 12.3% vs. 5.4% vs. 8.2% (Nankivell) | NR | 18 vs. 68, p<0.05 | NR
Salvadori et al. 2009^36^ | 6 months | Mean CsA levels exceeded target range in intervention group | NR | 16/142 vs. 20/143 | 3 vs. 14, p<0.01 | 2 vs. 2 | 6 months: 60.0±16.4 vs. 62.3±15.6 12 months: 63.8±18.3 vs. 64.8±17.7 (Nankivell) 6 months: 57.8±19.3 vs. 59.9±18.6 12 months: 61.3±22.0 vs. 62.5±20.7 (Cockcroft-Gault) | 6 months: 1.63 vs. 1.56 mg/dL 12 months: 1.55 vs. 1.51 mg/dL | 33 vs. 25 | NR
Spagnoletti et al. 2009^37^ | 6 months | NR | NR | NR | 1/30 vs. 2/30 | 0 | NR | NR | NR | NR
Bolin et al. 2008^38^ | 1 year | 24% of intervention group exceeded TAC trough target; 34% of control group lower than TAC trough target | NR | 2/100 vs. 2/112 (standard TAC) vs. 3/111 (standard CsA) Grade 1A 0 vs. 1 vs. 1 Grade 1B: 1 vs. 1 vs. 1 Grade 2A: 1 vs. 0 vs. 1 | 0 vs. 1 | 0 | Median change from baseline: 1.65 vs. -0.60 (standard TAC) vs. -0.80 (standard CsA) (Cockcroft-Gault) | Median change from baseline: -0.10 mg/L vs. 0 | 1 vs. 8 vs. 7 | NR
Chan et al. 2008^39^ | 6 months | Intervention: Mean TAC trough levels higher than target; at 6 months intervention TAC level = 7.1, control TAC level = 7.2 | 7/49 vs. 7/43 | 7 vs. 6 Banff 97: Grade 1: 5 vs. 4 Grade 2A: 1 vs. 1 Unknown: 1 vs. 1 | 0 vs. 1 | 0 | 75.3±16.6 vs. 72.5±15.2 (Nankivell) 82.8±26.8 vs. 77.2±21.8 (Cockcroft-Gault) | 112±31 mg/dL vs. 127±50 mg/dL | 5 vs. 4 | CAN: 0 vs. 2
Budde et al. 2007^40^ | 1 year | Intervention group achieved target (mean: 688±238 ng/mL) at 12 months Control group below target (mean: 781±215 ng/mL) at 12 months Intervention group 10-15% below control group | 6 months: 7/44 vs. 8/45 1 year: 8 vs. 9 (BPAR, graft loss, patient death) | 6 months: 6 vs. 8 1 year: 7 vs. 8 Banff 97: Grade 1: 4 vs. 7 Grade 2: 3 vs. 2 (1 patient had two episodes) | 0 | 6 months: 2 vs. 0 1 year: 3 vs. 1 | 6 months: 61.5±3.7 vs. 55.3±3.2 1 year: 59.7±4.1 vs. 56.6±3.2 (Cockcroft-Gault) | 6 months: 145 vs. 160 1 year: 1 62 vs. 163 | 5 vs. 3 | NR
Cibrik et al. 2007^41^ | 1 year | From months 3–12, 18%-37% of intervention group achieved target C2, 26%-40% of control group achieved target C2 | 13/75 vs. 16/66 (BPAR, graft loss, patient death) | 11 vs. 16 Banff 97: Grade 1A: 8 vs. 10 Grade 1B: 2 vs. 3 Grade 2A: 0 vs. 1 Grade 2B: 1 vs. 2 | 1 vs. 1 | 1 vs. 0 | 79.2 vs. 71.0, p<0.05 Change from baseline: 9.6 vs. 6.6 (Cockcroft-Gault) | 132 vs. 141 | NR | NR
Ekberg et al. 2007a42 | 1 year | 9% of intervention group patients exceeded target level some time during the study | NR | 46/183 vs. 48/173 | 6 vs. 9 | 4 vs. 5 | 50.9±6.4 vs. 48.6±6.9 (Cockcroft-Gault) | 1.5 mg/dL vs. 1.6 mg/dL | NR | NR
Ekberg et al. 2007b43 | 1 year | Mean trough levels were within the target levels for all groups | Low dose CsA: 81 Low dose TAC: 49 Standard dose CsA: 89 (Graft loss, death, use of additional immunosuppression, discontinuation of study medication for >14 consecutive or 30 cumulative days) | 6 months: Low dose CsA: 87 Low dose TAC: 45 Standard dose CsA: 94 1 year: Low dose CsA: 109 Low dose TAC: 62 Standard dose CsA: 117 | Low dose CsA: 23 Low dose TAC: 14 Standard dose CsA: 32 | Low dose CsA: 7 Low dose TAC: 11 Standard dose CsA: 13 | Low dose CsA: 59.4±25.1 (Cockcroft-Gault) 50.2±23.1 (MDRD) Low dose TAC: 65.4±27.0 (Cockcroft-Gault) 54.3±23.9 (MDRD) Standard dose CsA: 57.1±25.1 (Cockcroft-Gault) 46.2±23.1 (MDRD) | NR | NR | NR
Ghafari et al. 2007^44^ | 2 years | NR | NR | 20/42 vs. 25/48 | 8 vs. 10 | 1 vs. 1 | NR | No significant difference (data not reported) | 3 vs. 3 | No difference in length of hospital stay or readmissions
Hernandez et al. 2007^45^ | 2 years | Low dose CsA trough level: 133±61 Low dose TAC trough level: 7.5±2 Standard CsA trough level: 126±46 | NR | Low dose CsA: 11 Banff 97: Grade 1: 6 Grade 2: 4 Grade 3: 1 Low dose TAC: 13 Grade 1: 7 Grade 2: 4 Grade 3: 2 Standard CsA: 12 Grade 1: 9 Grade 2: 2 Grade 3: 1 | Low dose CsA: 4 vs. 4 Low dose TAC: 7 vs. 4 | Low dose CsA: 4 vs. 3 Low dose TAC: 8 vs. 3 | Low dose CsA: 66±20 (Cockcroft-Gault) 56±21 (Jelliffe 2) 59±24 (MDRD) Low dose TAC: 70±27 (Cockcroft-Gault) 59±20 (Jelliffe 2) 62±22 (MDRD) Standard dose CsA: 58±14 (Cockcroft-Gault) 51±17 (Jelliffe 2) 52±18 (MDRD) | NR | Low dose CsA: 10 Low dose TAC: 6 Standard dose CsA: 10 | CAN: 1 in low dose CsA group
Frimat et al. 2006^46^ Frimat et al. 2010^47^ | 5 years | Intervention group trough levels were lower than control group at study completion: 71 vs. 117 ng/mL | NR | 2 years: 0 5 years: 0 vs. 1 | 2 years: 1/70 vs. 1/31 5 years: 2 vs. 2 | 2 years: 0 5 years: 0 vs. 1 | 2 years: 56.2±16.6 vs. 45.1±16.4 (Cockcroft-Gault) 5 years: 51.8±20.2 vs. 41/3±18.9 | NR | NR | NR
Tang et al. 2006^48^ | 15 months | NR | NR | 0/18 vs. 2/16 | 0 vs. 2 | NR | 39.8±20.2 vs. 32.9±11.1 | NR | NR | NR
Vathsala et al. 2005^49^ | 6 months | Median CsA trough level: 119 vs. 172 ng/mL | NR | 5/20 vs. 2/10 Banff 97: Border line: 2 vs. 1 Grade 1: 2 vs. 1 Grade 2A: 1 vs. 0 | 3 vs. 0 | 1 vs. 0 | No significant difference (data not reported) | No significant difference (data not reported) | 5 vs. 1 | NR
Lo et al. 2004^50^ | 6 months | Mean TAC 12 hour trough: 4.4±1.2 vs. 15.8 ±9.3 | 4/23 vs. 1/23 (BPAR, graft loss, patient death) | 1/23 vs. 1/16 | 4/23 vs. 1/16 | 0/23 vs. 1/16 | NR | 1.6±0.9 mg/dL vs. 1.9±0.7 mg/dL, p=NS | 6 vs. 9 | Median hospital stay: 6 days (range 4–27) vs. 7 days (range 4–15) All-cause hospital re-admission: 44% vs. 56%
Nashan et al. 2004^51^ | 3 years | Over 3 years, mean daily CsA dose significantly lower in intervention group (3.2 mg/kg vs. 2.0 mg/kg) Over first 6 months, CsA trough levels were 35% lower in intervention than control group | 6 months: 2/53 vs. 8/58, p<0.05 1 year: 5 vs. 15, p<0.05 3 years: 10 vs. 19, p<0.05 (BPAR, graft loss, patient death, lost to follow-up) | 6 months: 2 vs. 8 1 year: 4 vs. 9 3 years: 7 vs. 10 | 6 months: 1 vs. 1 1 year: 1 vs. 3 3 years: 2 vs. 7 | 6 months: 0 1 year: 0 vs. 2 3 years: 2 vs. 5 | 6 months: 59.7±11.7 vs. 51.1±15.0, p<0.01 1 year: 60.9±11.3 vs. 53.5±12.1, p<0.01 3 years: 56.6±20.0 vs. 51.7±13.1, p=NS (Nankivell) | NR | 19 vs. 29, p<0.05 | CAN: 1 year: 0 vs. 3 3 years: 7 vs. 11
Stoves et al. 2004^52^ | 6 months | Median CsA trough level: 99 ng/mL vs. 163 ng/mL Mean dose reduction from baseline: 24% | 6 (3-patient death, 3-lost to follow-up) | 0 | 0 | 3 (during 9 months) | Median change over baseline: 2.5 vs. -0.7, p=0.05 | NR | NR | NR
Pascual et al. 2003^53^ | 6 months | Mean CsA trough level at 6 months: 86 vs. 193 ng/mL | NR | 0/32 vs. 0/32 | 0 | 0 | 64.6±20 vs. 61.0±19 Change from baseline: 7.1, p=0.01 | 1.33±0.26 vs. 1.40±0.25 Change from baseline: -0.06, p=0.06 | NR | NR
de Sevaux et al. 2001^54^ | 6 months | Median CsA trough level at 3 months: 154 vs. 248 | NR | 29/152 vs. 36/161, p=NS Banff 93: Grade 1: 16 vs. 20 Grade 2: 10 vs. 16 Grade 3: 3 vs. 0 | 8 vs. 14, p=NS | 3 vs. 5 | 3 months: 66±36 vs. 59±32 6 months: 69±31 vs. 65±28 | 3 months: 142 vs. 151 6 months: 136 vs. 141 | 20 vs. 27 | NR

aMDRD=abbreviated modification of diet in renal disease; BPAR=biopsy proven acute rejection; CAN=chronic allograft nephropathy; C2=2 hour post CsA dosage level; CsA=cyclosporine; EVR=everolimus; MDRD=modification of diet in renal disease; mg/dL=milligram per deciliter; MMF=mycophenolate mofetil group; ng/mL=nanogram per milliliter; NR=not reported; NS=not significant; SCr=serum creatinine; TAC=tacrolimus

Table E-4 Adverse events reported in minimization studies

Reference | Type of Intervention | New Onset Diabetes | Malignancy | Infection | Major Adverse Cardiac Events | Proteinuria | Blood Pressure/Lipids | Other
Cai et al. 2014^18^ | Minimization of CsA | NR | NR | Gastroenteritis: 5/90 vs. 4/90 UTI: 0 vs. 2 | NR | NR | No difference | No difference for GI, anemia, leukopenia
Chadban et al. 2014^19^ | Minimization of CsA | 12 vs. 13 | 0 vs. 1 | CMV: 2 vs. 4 All infections: 18 vs. 34 | NR | 0 vs. 1 | No difference between groups for cholesterol | No difference between groups for GI, anemia
Muhlbacher et al. 2014^20^ | Minimization of CsA | NR | 1/178 (lymphoma-like reaction) vs. 2/179 (lymphoma-like reaction and renal carcinoma) | CMV: 13 vs.14 Pneumonia: 10 vs. 16 Herpes: 10 vs. 9 Candida: 11 vs. 17 UTI: 47 vs. 45 Wound infection: 13 vs. 4 | NR | NR | No difference for BP, cholesterol; control group had higher triglycerides | No difference for anemia, leukopenia, edema
Oh et al. 2014^21^ | Minimization of CsA | NR | NR | All infections: 36/67 vs. 60/72 | NR | NR | No difference | No difference for GI, respiratory, vascular, nervous system
Bechstein et al. 2013^22^ | Minimization of TAC | 9/63 vs. 8/65 | 1 (basal cell carcinoma) vs. 1 (post-transplant lymphoma) | CMV: 3/63 vs. 5/65 Candida: 2 vs. 4 Sepsis: 1 vs. 3 Pneumonia: 2 vs. 6 UTI: 8 vs. 3 Herpes: 1 vs. 1 Lymphocele: 6 vs. 7 Dehiscence: 3 vs. 1 Wound infection: 1 vs. 1 | NR | NR | No difference | No difference for GI, anemia, leukopenia, edema
Chadban et al. 2013^23^ | Minimization of CsA | | 4 total (2 skin carcinoma, 1 post-transplant lymphoma, 1 Hodgkins; “no significant difference between groups”) | 30 vs. 26 (details not reported) | NR | NR | NR | No difference for GI
Cibrik et al. 2013^24^ | Minimization of CsA | 28/274 vs. 40/278 vs. 20/273 | 9 vs. 7 vs. 13 | CMV infection: 4 vs. 1 vs. 25 CMV syndrome: 4 vs. 5 vs. 15 CMV disease: 2 vs. 3 vs. 8 BK virus: 2 vs. 4 vs. 13 UTI: 66 vs. 73 vs. 74 Upper respiratory tract: 54 vs. 49 vs. 63 | 8 vs. 21 vs. 11 | NR | No difference for BP; total cholesterol and triglycerides lower in intervention group | No difference for GI; stomatitis higher in intervention group; leukopenia lower in intervention group
Takahashi et al. 2013^25^ | Minimization of CsA | 7 vs. 3 | 2 (thyroid cancer; b-cell lymphoma) vs. 0 | CMV infection: 3 vs. 21 CMV test positive: 4 vs. 19 Nasopharyngitis: 21 vs. 26 | NR | 8 vs. 5 | No difference | Nephrotoxicity: 13 vs. 6; No difference in GI, anemia, headache, stomatitis, hirsutism; edema higher in intervention group
Chan et al. 2012^26^ | Minimization of TAC | 19/114 vs. 33/119 | 1/151 (renal cell carcinoma) vs. 2/141 (basal cell carcinoma, malignant melanoma) | Bacterial: 59 vs. 65 Viral: 33 vs. 27 | NR | NR | NR | No difference for GI, anemia, edema
Kamar et al. 2012^27^ | Minimization of TAC | NR | NR | Any: 10 vs. 9 Bronchitis: 3 vs. 1 Pneumocystis jirovecii: 1 vs. 0 UTI: 1 vs. 2 Gastroenteritis: 1 vs. 4 Pyelonephritis: 0 vs. 1 Infected hygroma: 0 vs. 1 | NR | NR | No difference for cholesterol, triglycerides | No difference for GI, anemia, edema
Langer et al. 2012^28^ | Minimization of TAC | 14/109 vs. 18/119 | NR | CMV: 2 vs. 3 BK: 5 vs. 1 UTI: 36 vs. 42 Bacterial: 39.4% vs. 35.3% Viral: 9.2% vs. 10.9% Fungal: 5.9% vs. 7.3% | NR | 12 vs. 9 | No difference for cholesterol | No difference for GI, anemia, edema, nervous system, hypokalemia, hyperkalemia
Paoletti et al. 2012^29^ | Minimization of CsA | 2/10 vs. 2/20 | NR | NR | NR | 3 vs. 2 | No difference for BP; cholesterol and triglycerides higher in intervention group | NR
Bertoni et al. 2011^30^ | Minimization of CsA | NR | NR | CMV infection: 26% vs. 27% (specific data not reported) CMV disease rate: 8% vs. 10% | NR | 519.7±77.31 mg/24 hours vs. 296.7±33.42 mg/24 hours, p=0.01 | No difference for cholesterol; systolic BP lower in intervention group | NR
Holdaas et al. 2011^31^ | Minimization of CNI | 7/144 vs. 4/123 | 11 vs. 7 | Any infection: 89 vs. 75 UTI: 24 vs. 13 Upper respiratory tract: 16 vs. 16 | NR | 19 vs. 11 | No difference for triglycerides or hypertension; cholesterol and hyperlipidemia higher in intervention group | Higher incidence of edema, pyrexia, rash in intervention group; no difference for GI, anemia
Xu et al. 2011^32^ | Minimization of CNI | NR | NR | Pulmonary: 1 vs. 3 (1 of these confirmed CMV) | NR | None | No difference for BP | Nephrotoxicity: 0/20 vs. 5/18 (p<0.05)
Etienne et al. 2010^33^ | Minimization of CsA | 2 vs. 7 | 3 (1 skin cancer, 2 solid carcinoma) vs. 7 (5 skin cancer, 2 solid carcinoma) | Bacterial: 22/106 vs. 19/101 Viral: 4/106 vs. 9/101) | NR | NR | No difference for cholesterol, triglycerides; BP lower in intervention group | Nephrotoxicity: 5/106 vs. 12/101 (p=0.08)
Fangmann et al. 2010^34^ | Minimization of CsA | NR | 0 | CMV: 19/75 vs. 15/73 Herpes: 6 vs. 11 Other viral: 9 vs. 4 Bacterial: 40 vs. 39 Fungal: 9 vs. 3 | 9 vs. 5; type unspecified | NR | No difference for BP and lipids | Neurological: 17 vs. 13 Metabolic: 22 vs. 14 GI: 13 vs. 10 Hematological: 14 vs. 19
Gaston et al. 2009^35^ | Minimization of CNI | 2 (CsA) and 32 (TAC) vs. 3 (CsA) and 41 (TAC) | 2 (CsA) and 3 (TAC) vs. 1 (CsA) and 12 (TAC) | All “opportunistic infections”: 22/238 vs. 55/471 CMV: 12/238 vs. 32/471 BK virus infection: 4/238 vs. 15/471 BK virus nephropathy: 0/238 vs. 8/471 | NR | NR | No difference for hypertension, hyperlipidemia | No difference for GI, leukopenia
Salvadori et al. 2009^36^ | Minimization of CsA | 7/142 vs. 3/143 | 2 vs. 2 (1 basal cell carcinoma, 1 epithelioma, 2 unspecified) | All infections: 88 vs. 96 CMV requiring hospitalization: 3 vs. 2 Pneumonia requiring hospitalization: 3 vs. 2 | “Cardiac disorders”: 7 vs. 4 | NR | No difference | No difference for GI, anemia, edema, vascular, metabolic
Spagnoletti et al. 2009^37^ | Minimization of CNI and switch from CsA to TAC | 1/30 vs. 4/30 | NR | NR | NR | NR | No difference for BP; higher mean serum cholesterol and higher serum triglycerides for intervention group | NR
Bolin et al. 2008^38^ | Minimization of TAC | 3/63 vs. 2/66 (standard TAC) vs. 3/66 (standard CsA) | 9/100 vs. 6/112 (standard TAC) vs. 3/111 (standard CsA) (mainly basal and squamous cell carcinoma) | CMV: 0 vs. 3 (standard TAC) vs. 1 (standard CsA); 3 of these were donor derived All other infections: 16 vs. 30 (standard TAC) vs. 22 (standard CsA) | NR | NR | No difference for cholesterol, triglycerides | No difference for overall quality of life; lower GI distress for intervention group
Chan et al. 2008^39^ | Minimization of TAC | 8/21 vs. 4/17 | 0 vs. 1 (adrenal neoplasm) | 9/49 vs. 8/43 Pneumonia: 1 vs. 0 UTI: 6 vs. 7 Wound infection: 2 vs. 1 | NR | 0 vs. 1 | Hypercholesterolemia: 5 (10.2%) vs. 4 (9.3%) Hypertriglyceridemia: 1 (2.0%) vs. 3 (7.0%) No difference for lipids, triglycerides | No difference for GI, edema, hematological Peripheral edema: 23 (47%) vs. 9 (20.9%)
Budde et al. 2007^40^ | Minimization of CsA | NR | NR | All infections (details NR): 30/44 vs. 35/45 | NR | NR | No difference for BP | No difference for GI
Cibrik et al. 2007^41^ | Minimization of CsA | 4 (groups not specified) | 2 (groups not specified) | Candidiasis: 9/75 vs. 8/66 Oral candidiasis: 13 vs. 9 UTI: 9 vs. 21 Upper respiratory: 13 vs. 6 | NR | NR | NR | No difference for GI, anemia, leukopenia, hirsutism
Ekberg et al. 2007a42 | Minimization of CsA | NR | 5 (including 1 post-transplant lymphoproliferative disorder) vs. 1 | CMV: 20 vs. 24 Candida: 8 vs. 16 Herpes simplex: 13 vs. 11 Herpes zoster: 12 vs. 9 UTI: 8 vs. 7 | NR | NR | No difference | No difference for lymphocele, hypertension
Ekberg et al. 2007b43 | Minimization of CNI | Low dose CsA: 17 Low dose TAC: 34 Standard dose CsA: 23 | Low dose CsA: 4 (Kaposi's sarcoma, transitional-cell, renal-cell, basal-cell) Low dose TAC: 8 (3 basal-cell, 2 renal-cell, prostate, cerebral lymphoma, squamous cell) Standard dose CsA: 5 (2 basal-cell, squamous-cell, oral mucosa, Kaposi's sarcoma) | Low dose CsA: All “opportunistic infections” (per study designation): 93 CMV: 45 Candida: 19 Herpes simplex: 15 All other infections: 206 UTI: 97 Pneumonia: 5 Nasopharyngitis: 32 Low dose TAC: All “opportunistic infections” (per study designation): 80 CMV: 39 Candida: 12 Herpes simplex: 18 All other infections: 211 UTI: 95 Pneumonia: 13 Nasopharyngitis: 32 Standard dose CsA: All “opportunistic infections” (per study designation): 100 CMV: 55 Candida: 29 Herpes simplex: 21 All other infections: 208 UTI: 109 Pneumonia: 18 Nasopharyngitis: 22 | Low dose CsA: 15 Low dose TAC: 13 Standard dose CsA: 15 | Low dose CsA: 8 Low dose TAC: 20 tandard dose CsA: 9 | No difference in hypercholesterolemia, hyperlipidemia, hypertriglyceridemia between low and standard dose CsA groups; hypercholesterolemia and hyperlipidemia lower in low dose TAC group | No difference for anemia, leukopenia, edema, pyrexia, lymphoceles, disorders of the nervous system, respiratory system, or vascular system; higher incidence of serious GI events in low dose TAC group
Ghafari et al. 2007^44^ | Minimization of CsA | No difference between groups (data not specified) | NR | No difference between groups (data not specified) | No difference between groups (data not specified) | NR | Lower hypertension, higher triglycerides in intervention group | Nephrotoxicity: 1 vs. 4; No difference for GI, hematological
Hernandez et al. 2007^45^ | Minimization of CNI | Low dose CsA: 9/58 vs. 10/55 Low dose TAC: 15/55 vs. 10/55 | Low dose CsA: 2 vs. 3 Low dose TAC: 2 vs. 3 | Low dose CsA: CMV: 19 vs. 40 Pneumonia: 4 vs. 1 UTI: 25 vs. 23 Other viral: 8 vs. 5 Low dose TAC: CMV: 29 vs. 40 Pneumonia: 3 vs. 1 UTI: 28 vs. 23 Other viral: 5 vs. 5 | NR | No difference | No difference for cholesterol, triglycerides | Nephrotoxicity: Low dose CsA: 12 vs. 18 Low dose TAC: 20 vs. 18 No difference for GI, anemia, leukopenia
Frimat et al. 2006^46^ Frimat et al. 2010^47^ | Minimization of CsA | NR | 2 years: 3/70 vs. 2/33 5 years: 3 vs. 3 | 2 years: All infections: 33 vs. 10 Herpes simplex: 2 vs. 0 Herpes zoster: 3 vs. 1 Other herpes: 1 vs. 0 Bronchitis: 13 vs. 3 5 years: All infections: 6 vs. 2 Opportunistic infections: 0 | 2 years: NR 5 years: 4 vs. 1 | 2 years: 39% vs. 62% | NR | 2 years: Higher incidence of GI, anemia in intervention group; no difference for leucopenia 5 years: no difference for GI, urinary system, kidney, thoracic, respiratory, mediastinal disorders
Tang et al. 2006^48^ | Minimization | NR | NR | UTI: 0/18 vs. 1/16 Gastroenteritis: 1 vs. 0 Herpes zoster: 0 vs. 1 | NR | No difference | No difference | NR
Vathsala et al. 2005^49^ | Minimization of CsA | NR | 0 | CMV: 9/20 vs. 2/10 Herpes zoster: 1 vs. 0 Septicimia: 2 vs. 0 Pneumonia: 6 vs. 0 UTI: 9 vs. 6 | NR | NR | No difference for BP | NR
Lo et al. 2004^50^ | Minimization of TAC | 5/23 vs. 4/16 | 0 | 1 CMV in control group | 1 idiopathic pulmonary hemorrhage in control group | NR | No difference for cholesterol, triglycerides | Nephrotoxicity: 7 cases in control group; No difference for leukopenia
Nashan et al. 2004^51^ | Minimization of CsA | NR | 3 vs. 2 | CMV: 0 vs. 1 Herpes simplex: 0 vs. 3 Bacterial: 24 vs. 23 Fungal: 5 vs. 5 Pneumocystis carinii: 0 vs. 1 | 5 vs. 2 (myocardial infarction, angina pectoris, sudden death) | 13 vs. 5 | No difference | Nephrotoxicity: 2/58 vs. 6/53; No difference for GI
Stoves et al. 2004^52^ | Minimization of CNI | 0 | NR | UTI: 1 (control group) | NR | NR | No difference for BP, lipids | NR
Pascual et al. 2003^53^ | Minimization of CsA | NR | 0 | 0 | NR | NR | No difference | NR
de Sevaux et al. 2001^54^ | Minimization of CsA | 6 vs. 6 | 0 | CMV: 35 vs. 31 UTI: 38 vs. 34 Oral candidiasis: 12 vs. 14 | NR | NR | No difference | Nephrotoxicity: 4/152 vs. 13/161, p=0.06

BK=BK polyomavirus; BP=blood pressure; CMV=cytomegalovirus; CNI=calcineurin inhibitors; CsA=cyclosporine; GI=gastrointestinal; NR=not reported; UTI=urinary tract infection; TAC=tacrolimus

Table E-5 Study design characteristics of conversion studies

Reference | Type of Intervention | Intervention Regimen | Control Regimen | Analytical Method for Measuring Therapeutic Drug Levels | Induction Therapy | Time from Transplant to Start of Intervention | Special Inclusion/Exclusion Criteria
Budde et al. 2015^55^ Budde et al. 2015^56^ | Conversion from CNI to EVR | EVR (6-10 ng/mL) + EC-MPS ≥ 720 mg/day + STER | CsA (80-150 ng/mL) or TAC (5-10 ng/mL) | NR | NR | 3 months | NA
Rostaing et al. 2015^57^ | Conversion from CsA to EVR | EVR (6-10 ng/mL) + EC-MPS (720 mg) + STER | CsA (100-150 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 3 months | Excluded age >70 and PRA >20%
Bansal et al. 2013^58^ | Conversion from Control Regimen to SRL | SRL (8–15 ng/mL) | CsA (150–250 ng/mL) or TAC (6–8 ng/mL) + MMF + STER (prednisone 5 mg) | HPLC | NR | 3 months | Only live donors included
Chhabra et al. 2013^59^ | Conversion from TAC to SRL | SRL (5–8 ng/mL) + MMF (2,000 mg) | TAC (6–8 ng/mL) + MMF (2,000 mg) | HPLC | Alemtuzumab | 1 year | NA
Silva et al. 2013^60^ | Conversion from TAC to SRL | SRL (8 and 12 ng/mL) + EC-MPS (1,440 mg) + STER | TAC (5 and 15 ng/mL) + EC-MPS (1,440 mg) + STER | HPLC | Basiliximab | 3 months | NA
Budde et al. 2015^61^ Budde et al. 2012^62^ Budde et al. 2011^63^ | Conversion from CsA to EVR | EVR (6–10 ng/mL) + MPS (1,440 mg) + STER (prednisolone ≥5 mg) | CsA (100–150 ng/mL) + MPS (1,440 mg) + STER (prednisolone ≥5 mg) | NR | Basiliximab | 4.5 months | NA
Mjornstedt et al. 2015^64^ Mjornstedt et al. 2012^65^ | Conversion from CsA to EVR | EVR (6–10 ng/mL) + EC-MPS (1,440 mg) + STER | CsA (C2 target 600–800 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 7 weeks | NA
Nafar et al. 2012^66^ | Conversion from CsA to SRL | SRL (8–15 ng/mL) + CsA changed to MMF in the 4^th^ month + STER (5 mg) administered during the first 3 months | CsA (150–250 ng/mL) + MMF (1,000–2,000 mg) + STER | NR | NR | 4 months | Excluded DGF
Heilman et al. 2011^67^ | Conversion from TAC to SRL | SRL (8 ng/mL) + MMF (1,000 mg) + rapid STER withdrawal | TAC (5–8 ng/mL) + MMF (2,000 mg) + rapid STER withdrawal | NR | rATG | 1 month | NA
Holdaas et al. 2011^31^ | Conversion from CNI to EVR | Conversion from CNI to EVR (8–12 ng/mL) + prior therapy (could include MPA, AZA and/or STER) | CsA (C2 target ≥400 ng/mL) or TAC (≥4 ng/mL) + prior therapy (could include MPA, AZA, and/or STER) | NR | NR | Minimum 6 months | NA
Rostaing et al. 2011^68^ | Conversion from CNI to belatacept | Belatacept (10–12 μg/mL) + MMF, MPS, SRL or AZA | CsA (100–250 ng/mL) or TAC (5–10 ng/mL) + MMF, MPS, SRL or AZA | NR | NR | During 28-day period | NA
Weir 2011^69^ | Conversion from CNI to MMF | SRL (2.9 mg at 24 months) + MMF + STER | CsA (240.4 mg at 24 months) or TAC (7.1 mg at 24 months) + MMF + STER | NR | ATG: 105 Basiliximab: 80 Daclizumab: 32 Muromonab-CD3: 1 | 30–180 days | NA
Guba et al. 2010^70^ | Conversion from CsA to SRL | SRL (5–10 ng/mL) + MMF (1,500 mg) + STER | CsA (100–150 ng/mL) + MMF (2,000 mg) + STER | NR | ATG-F | 10–24 days | Excluded PRA >30% and persistent DGF
Bemelman et al. 2009^71^ | Conversion from CsA to MPS or EVR | MPS (>2 mg) or EVR (target AUC 12–150 mg h/L) + STER | CsA (target AUC 120–3,250 μg h/L) + STER | NR | Basiliximab | 6 months | Excluded PRA >50%
Schena et al. 2009^72^ | Conversion from CNI to SRL | SRL + MMF or AZA +STER | CsA or TAC + MMF or AZA +STER | HPLC (SRL) IA (CNI) | NR | Minimum 6 months | NA
Lebranchu et al. 2011^73^ Lebranchu 2009^74^ | Conversion from CsA to SRL | SRL (5–10 ng/mL) + MMF + STER | CsA (C2 target 500–800 ng/mL) + MMF +STER | NR | Daclizumab | 3 months | Excluded PRA >30%, living donors
Durrbach et al. 2008^75^ | Conversion from CsA to SRL | SRL (10–20 ng/mL) + MMF + STER | CsA (75–200 ng/mL) + MMF + STER | NR | ATG | NR | Excluded PRA >50%
Barsoum et al. 2007^76^ | Conversion from CsA to SRL | SRL (11.4±2.6 ng/mL) + MMF + STER | CsA (811±137.5 ng/mL) + MMF + STER | NR | NR | 3 months | Excluded deceased donors
Dudley et al. 2005^77^ | Conversion from CsA to MMF | MMF (2,000 mg) + STER (10 mg) | CsA (≥80 ng/mL) | NR | NR | 10 weeks | NA
Watson et al. 2005^78^ | Conversion from CNI SRL | SRL (5–15 ng/mL) + AZA or mycophenolic acid + STER | CsA or TAC + AZA or mycophenolic acid + STER | HPLC | NR | Minimum 6 months | NA
Bakker et al. 2003^79^ | Conversion from CsA to AZA | AZA (2–2.5 mg/kg) + STER | CsA (5 mg/kg) + STER | NR | NR | 3 months | NA
MacPhee et al. 1998^80^ | Conversion from CsA to AZA | AZA (1.6–1.9 mg/kg) + STER (10 mg) | CsA (2.5–3 mg/kg) + STER (10 mg) | IA/FPIA | NR | 1 year | NA
Hilbrands et al. 1996^81^ | Conversion from CsA to AZA | AZA (3 mg/kg) + STER (10 mg) | CsA (100–200 ng./mL) + STER withdrawn | NR | ATG | 3 months | NA

AZA=azathioprine; ATG=antithymocyte globulin; C2=2 hour post CsA dosage level; CNI=calcineurin inhibitors; CsA=cyclosporine; DGF=delayed graft function; EC-MPS=enteric-coated mycophenolate sodium; EVR=everolimus; FPIA=fluorescence polarization immunoassay; h/L=hectoliter; HPLC=high performance liquid chromatography; IA=immunoassay; mg=milligram; MMF=mycophenolate mofetil group; MPA=medroxyprogesterone acetate; MPS=mycophenolate sodium; NA=not applicable; ng/mL=nanogram per milliliter; NR=not reported; PRA=panel reactive antibody; STER=steroid; SRL=sirolimus; TAC=tacrolimus; μg=micrograms

Table E-6 Study population characteristics of conversion studies

Reference | Type of Intervention | Country/Region | N, Intervention | N, Control | Donor Type | Mean Age, Intervention vs. Control | Gender: % Male | Race: % Caucasian | Delayed Graft Function %, Intervention vs. Control
Budde et al. 2015^55^ Budde et al. 2015^56^ | Conversion from CNI to EVR | Germany | 46 | 47 | Deceased: 66 Living related: 19 Living unrelated: 7 | 51 vs. 50 | 69% | 100% | NR
Rostaing et al. 2015^57^ | Conversion from CsA to EVR | France | 96 | 98 | Deceased: 174 Living: 20 | 48 vs. 50 | 66% | NR | 19% vs. 24%
Bensal et al. 2013^58^ | Conversion from CNI to SRL | India | 31 | 29 | Living | 34 vs. 30 | 87% | 100% Asian | NR
Chhabra et al. 2013^59^ | Conversion from TAC to SRL | USA | 123 | 64 | Deceased: 57 Living related: 76 Living unrelated: 55 | 49 vs. 49 | 57% | 51% | 13% overall
Silva et al. 2013^60^ | Conversion from TAC to SRL | Brazil | 97 | 107 | Deceased: 146 Living: 151 | 44 vs. 44 | 69% | 57% | NR
Budde et al. 2015^61^ Budde et al. 2012^62^ Budde et al. 2011^63^ | Conversion from CsA to EVR | Germany | 155 | 146 | Deceased: 220 Living related: 57 Living unrelated: 23 | 46 vs. 46 | 63% | 97% | NR
Mjornstedt et al. 2015^64^ Mjornstedt et al. 2012^65^ | Conversion from CsA to EVR | Europe | 102 | 100 | Deceased: 144 Living: 58 | 55 vs. 53 | 71% | 99% | NR
Nafar et al. 2012^66^ | Conversion from CsA to MMF | Iran | 50 | 50 | Living | 38 vs. 42 | 55% | 100% (Iranian) | NR
Heilman et al. 2011^67^ | Conversion from TAC to SRL | USA | 62 | 60 | Deceased | 52 vs. 54 | 62% | 77% | 9% overall
Holdaas et al. 2011^31^ | Conversion from CNI to EVR | Worldwide | 127 | 123 | Deceased: 154 Living related: 93 Missing: 3 | 49 vs. 48 | 67% | 72% | NR
Rostaing et al. 2011^68^ | Conversion from CNI to belatacept | France | 84 | 89 | Deceased: 86 Living: 83 | 45 vs. 44 | 73% | 56% | NR
Weir 2011^69^ | Conversion of CNI to SRL | USA | 148 | 151 | Deceased: 180 Living related: 79 Living unrelated: 40 | 48 vs. 48 | 63% | 50% | NR
Guba et al. 2010^70^ | Conversion from CsA to SRL | Germany | 69 | 71 | Brain death: 125 Living: 15 | 47 vs. 47 | 68% | 99% | 24% overall
Bemelman et al. 2009^71^ | Conversion from CsA to MPS or EVR | Netherlands | 74 (MPS 36, EVR 38) | 39 | Deceased: 63 Living: 50 | 52 (MPS) vs. 49 (EVR) vs. 51 (CsA) | 57% | 86% | NR
Schena et al. 2009^72^ | Conversion from CNI to SRL | Worldwide | 555 | 275 | Deceased: 520 Living: 303 | 44 vs. 43 | 70% | 66% | NR
Lebranchu et al. 2011^73^ Lebranchu 2009^74^ | Conversion from CsA to SRL | France | 95 | 97 | Deceased | 46 vs. 47 | 71% | NR | 14% overall
Durrbach et al. 2008^75^ | Conversion from CsA to SRL | France | 33 | 36 | Living | 52 vs. 57 | NR | NR | 38% overall
Barsoum et al. 2007^76^ | Conversion from CsA to SRL | Egypt | 76 | 37 | Living | 45 vs. 44 | 65% | NR | 29% overall
Dudley et al. 2005^77^ | Conversion from CsA to MMF | United Kingdom | 73 | 70 | Deceased: 119 Living: 24 | 43 vs. 45 | 62% | NR | NR
Watson et al. 2005^78^ | Conversion from CNI to SRL | United Kingdom | 19 | 19 | Deceased: 28 Living: 10 | 47 vs. 48 | 82% | NR | NR
Bakker et al. 2003^79^ | Conversion from CsA to AZA | Netherlands | 60 | 68 | Deceased | 46 vs. 43 | 62% | NR | NR
MacPhee et al. 1998^80^ | Conversion from CsA to AZA | Scotland | 102 | 114 | Deceased: 194 Living: 22 | 41 vs. 39 | 59% | NR | NR
Hilbrands et al. 1996^81^ | Conversion from CsA to AZA | Netherlands | 60 | 60 | Deceased | 43 vs. 43 | 63% | NR | NR

CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; MMF=mycophenolate mofetil group; MPS=mycophenolate sodium; NR=not reported; SRL=sirolimus; TAC=tacrolimus

Table E-7 Clinical outcomes of conversion studies

Reference | Length of Followup | Achievement of CNI Target Levels | Treatment Failure Composite^1^ (n) | Biopsy Proven Acute Rejection (n) | Graft Loss (n) | Patient Death (n) | Mean eGFR or Creatinine Clearance (mL/min) (method) | Mean Serum Creatinine | Other
Budde et al. 2015^55^ 1 year followup | 1 year | Target C0 CsA 100 to 150 ng/mL (mean 113), TAC 5-10 ng/mL (mean 5.6) EVR: 6 to 10 ng/mL (mean concentration 6.4 ng/mL) | CNI: 5 EVR: 17 | CNI: 0 EVR: 0 | CNI: 0 EVR: 0 | CNI: 1 EVR: 1 | CNI: 58.2 ± 16.6 [underlined: mL/min/Nankivell] [underlined: EVR:] [underlined: 61.6 ± 19.8] [underlined: mL/min/Nankivell] | NR | NR
Budde et al. 2015^56^ 5 year followup | 5 years | Target C0 CsA 100 to 150 ng/mL (mean 113), TAC 5-10 ng/mL (mean 5.6) EVR: 6 to 10 ng/mL (mean concentration 6.4 ng/mL) | NR | CNI: 0 EVR: 0 | CNI: 1 EVR: 3 | CNI: 3 EVR: 2 | CNI: 60.4 ± 16.8 [underlined: mL/min/Nankivell] [underlined: EVR: 66.7 ± 17.4] [underlined: mL/min/Nankivell] | NR | NR
Rostaing et al. 2015^57^ | 1 year | At month 6, 38% of control group below CsA trough target; at month 12, 21% below target. For intervention group, 3% below EVR trough level at 6 months, and 4% below target at 12 months | CsA: 6 EVR: 25 | CsA: 5 EVR: 24 | CsA: 1 EVR: 5 | CsA: 0 EVR: 0 | Mean eGFR at 3 months CsA: 50.2±15.3 mL/min/MDRD EVR: 52.1±15.9 mL/min/MDRD Mean eGFR at 1 year: CsA: 53.5±16.9 mL/min/MDRD EVR: 60.1±20.0 mL/min/MDRD | NR | NR
Bensal et al. 2013^58^ | 6 months | Target C0 TAC 6 to 8 ng/mL; CsA 150 to 250 ng/mL; SRL 8 to 15 ng/mL | NR | CNI: 2 SRL: 2 | Authors report no difference between groups; data not reported | Authors report no difference between groups; data not reported | Mean eGFR CNI: 80.6±16.5 mL/min/MDRD SRL: 88.9±11.8 | CNI: 1.14±0.17 mg/dL SRL: 0.99±0.11 | SRL group had a mean gain of eGFR of 12 mL/min
Chhabra et al. 2013^59^ | 2 years | Target C0 TAC 6 to 8 ng/mL SRL C0 6 to 8 ng/mL | NR | TAC: 7 SRL: 4 | TAC: 2 SRL: 3 | TAC: 0 SRL: 4 | [underlined: Mean eGFR at 12 months] TAC: 66.6 mL/min/MDRD SRL: 67.5 | NR | NR
Silva et al. 2013^60^ | 2 years | NR | NR | TAC: 62 SRL: 22 | TAC: 4 SRL: 1 | TAC: 9 SRL: 3 | Mean eGFR TAC: 70.7±25.1 mL/min/MDRD SRL: 66.2±25.3 | TAC: 1.3±0.3 mg/dL SRL: 1.4±0.4 | NR
Budde et al. 2015^61^ 5 year followup | 5 years | Target C0 CsA 100 to 150 ng/mL EVR: 6 to 10 ng/mL | CsA: 35 EVR: 48 | CsA: 11 EVR: 21 | CsA: 3 EVR: 4 | CsA: 3 EVR: 4 | [underlined: CsA:] [underlined: 60.9 mL/min/Nankivell (95% CI: 57.3 to 64.4)] [underlined: EVR:] [underlined: 66.2 mL/min/Nankivell (95% 62.8 to 69.6)] | NR | NR
Budde et al. 2012^62^ 3 year followup | 3 years | Target C0 CsA 100 to 150 ng/mL EVR: 6 to 10 ng/mL | CsA: 23 EVR: 46 | CsA: 7 EVR: 20 | CsA: 1 EVR: 1 | CsA: 3 EVR: 3 | [underlined: 24 months] CsA: 62.4 mL/min/Nankivell (95% CI: 58.7 to 66.1) EVR: 70.0 (95% CI: 66.6 to 73.5) [underlined: 36 months] CsA: 61.0 (95% CI: 56.4 to 65.6) EVR: 68.5 (95% CI: 64.0 to 73.0) | NR | NR
Budde et al. 2011^63^ 1 year followup | 1 year | Target C0 CsA 100 to 150 ng/mL EVR: 6 to 10 ng/mL | CsA: 42 EVR: 39 | CsA: 22 EVR: 23 | CsA: 0 EVR: 0 | CsA: 1 EVR: 0 | CsA: 61.9 mL/min/Nankivell (95% CI: 59.0 to 64.9) EVR: 71.8 (95% CI: 68.9 to 74.6) Mean difference: -9.8 (95% CI: -12.2 to -7.5, p<0.001) | NR | NR
Mjornstedt et al. 2015^64^ 3 year followup | 3 year | At months 6 and 12 all patients within C0 target range from EVR (6 to 10 ng/mL) and CsA (117 ng/mL at 6 months; 105 at 12 months) | CsA: 6 EVR: 3 | CsA: 10 EVR: 12 | CsA: 0 EVR: 0 | CsA: 3 EVR: 1 | CsA: 46.1 ± 17.0 ml/min; EVR: 48.2 ± 14.7 ml/min | NR | NR
Mjornstedt et al. 2012^65^ 1 year followup | 1 year | At months 6 and 12 all patients within C0 target range from EVR (6 to 10 ng/mL) and CsA (117 ng/mL at 6 months; 105 at 12 months) | CsA: 12 EVR: 29 | CSA: 11 EVR: 28 | CsA: 0 EVR: 0 | CsA: 2 EVR: 2 | CsA: 47.8±15.4 mL/min/ measured GFR EVR: 51.2±14.1 | CsA: 132±45 μmol/L EVR: 122±35 | NR
Nafar et al. 2012^66^ | 4 years | SRL target C0 levels 8 ng/mL to 15 ng/mL CsA C0 levels 150 ng/mL to 250 ng/mL | NR | CsA: 9 pts. (34 episodes) SRL: 4 pts. (20 episodes) | Authors report no significant difference between groups; data reported in figure | Authors report no significant difference between groups; data reported in figure | [underlined: At 1 year] CsA: 73.2±19.2 mL/min/ Cockcroft SRL: 82.3±24.3 [underlined: At 4 years] CsA: 70.3±23.6 SRL: 79.8±22.3 | [underlined: At 1 year] CsA: 1.4±0.35 mg/dL SRL: 1.26±0.32 [underlined: At 4 years] CsA: 1.57±0.33 SRL: 1.24±0.24 | NR
Heilman et al. 2011^67^ | 2 years | SRL level at 1 year 9.8±3.6 ng/dL TAC level at 1 year 6.9±4.6 ng/dL | NR | TAC: 3 SRL: 8 | [underlined: At 1 year] TAC: 0 SRL: 0 [underlined: At 2 year] TAC: 2 SRL: 1 | [underlined: At 1 year] TAC: 0 SRL: 0 [underlined: At 2 year] TAC: 2 SRL: 1 | [underlined: At 1 year] TAC: 62.7±26.5 mL/min/iothalomate clearance SRL: 57.4±20.7 [underlined: At 2 years] TAC: 62.8±21.6 SRL: 64.3±29.0 | [underlined: At 1 year] TAC: 1.39±0.81 mg/dL SRL: 1.26±0.37 [underlined: At 2 years] TAC: 1.26±0.36 SRL: 1.39±0.54 | Total withdraws TAC: 11 SRL: 39, 23 of which were for drug side effects
Rostaing et al. 2011^68^ | 1 year | BEL C0 level maintained at 10 to 12 μg/ml; CsA C0 serum level maintained at 100 to 250 ng/ml TAC at 5 to 10 ng/ml | NR | CNI: 0 BEL: 6 | CNI: 0 BEL: 0 | CNI: 2 BEL: 0 | CNI: 56.5±14.42 mL/min/MDRD BEL: 60.5±11.01 | NR | NR
Weir et al. 2011^69^ | 2 years | Authors report that mean C0 levels of TAC remained stable over study and CsA levels decreased due to dosage reduction | [underlined: 12 months] CNI: 29 SRL: 36 [underlined: 24 months] CNI: 42 SRL: 50 | CNI: 9 SRL: 11 | CNI: 4 SRL: 3 | CNI: 5 SRL: 0 | [underlined: 1 year] CNI: 71.5±21.2 ml/min/Nankivell SRL: 74.6±17.9 [underlined: 2 years] CNI: 71.2±23.4 SRL: 75.5±19.2 | [underlined: 1 year] CNI: 145.0±96.5 μmol/L SRL: 126.2±82.8 [underlined: 2 years] CNI: 151.8±117.0 SRL: 127.1±83.9 | Creatinine Clearance [underlined: 1 year] CNI: 58.0±23.3 mL/min SRL: 61.9±20.1 [underlined: 2 years] CNI: 56.9±23.0 SRL: 62.3±22.1
Guba et al. 2010^70^ | 1 year | Authors report C0 level generally met CsA C0: 100 to 150 ng/mL SRL: 5 to 10 ng/mL | CsA: 23 SRL: 35 | CsA: 11 SRL: 12 | CsA; 3 SRL: 1 | CsA: 1 SRL: 1 | CsA: 53.4±18.0 mL/min/Nankivell SRL: 64.5±25.2 | SRL: 1.51±0.59 (mg/dL) CsA: 1.87±0.98 (mg/dL) | Drug withdrawals significantly higher in SRL group (36.2%) than in CsA group (19.0%)
Bemelman et al. 2009^71^ | 2 years | Target CsA AUC_12_ 3,250 μg·h/L EVR 150 mg·h/L | NR | CsA: 1 MPS: 8 EVR: 0 | NR | NR | Mean eGFR at baseline (for all groups) 58±18 mL/min/MDRD [underlined: At follow-up] CsA: 44±15 MPS: 56±23 EVR: 55±20 | [underlined: At conversion]^2^ CsA: 124±11 μmol/L MPS: 116±11 EVR: 118±12 [underlined: At follow-up]^2^ CsA: 139±14 μmol/L MPS: 135±21 EVR: 110±7 | NR
Schena et al. 2009^72^ 24 months followup | 2 years | Target C0 CsA 50 to 250 ng/mL TAC 4 to 10 ng/ng/mL; SRL 8 to 20 ng/mL | CNI: 40 SRL: 89 | CNI: 19 SRL: 44 | CNI: 26 SRL: 58 | CNI: 12 SRL: 32 | [underlined: Pts baseline GFR >40 mL/min (n=743)] CNI: 52.1 SRL 53.7 Diff: 1.6 (95% CI: -1.43 to -4.6) [underlined: Pts baseline GFR 20 to 40 mL/min] CNI: 17.9 SRL: 21.7 Diff: 3.8 (95% CI: -12.27 to -6.91 | [underlined: Mean urinary protein/creatinine ration] CNI: 0.22±0.40 SRL: 0.72±1.50 | NR
Schena et al. 2009^72^ 12 months followup | 1 year | NR | CNI: 11 SRL: 36 | CNI: 4 SRL: 17 | CNI: 8 SRL: 27 | CNI: 2 SRL: 14 | [underlined: Pts baseline GFR >40 mL/min/Nankivell (n=743)] CNI: 57.7 SRL: 59.0 Diff: 1.3 (95% CI: -1.06 to -3.69) [underlined: Pts. baseline GFR 20 to 40 mL/min (n=87)] CNI: 27.2 SRL: 24.6 Diff: -2.6 (95% CI: -12.27 to -6.91) | [underlined: Mean urinary protein/creatinine ratio] CNI: 0.23±0.25 SRL: 0.36±0.53 | NR
Lebranchu et al. 2011^73^ | 4 year | Target CsA C2 500 to 800 ng/mL | NR | CsA: 2 SRL: 2 | CsA: 0 SRL: 1 | CsA: 2 SRL: 2 | CsA: 51.4 mL/min/MDRD (95% CI: 47.9 to 54.9) SRL: 58.7 (95% CI: 55.1 to 62.4) | NR | NR
Lebranchu et al. 2009^74^ | 1 year | Target CsA C2 500 to 800 ng/mL | NR | CsA: 8 SRL: 16 | CsA: 0 SRL: 1 | CsA: 0 SRL: 0 | CsA: 53.9±51 mL/min/MDRD SRL: 61.2±58 | CsA: 132.3 μmol/L (126.1 to 138.5) SRL: 117.4 (110.7 to 124.2) | NR
Durrbach et al. 2008^75^ | 6 months | At 6 months, SRL C0 level 13.0±4.0 ng/mL at 6.8±4.9 g/d CsA dose 233±77 mg/d | NR | SRL: 4 CsA: 3 | SRL: 4 CsA: 1 | SRL: 1 CsA: 0 | SRL: 44.7±16.6 mL/min/Cockcroft CsA: 41.9±15.2 mL/min | SRL: 171±53 μmol/L CsA: 171±65 | Delayed graft function: SRL: 15 CsA: 11 Withdrawal SRL: 16 CsA: 6
Barsoum et al. 2007^76^ | 2 years | At 12 to 24 months, CsA C2 level 1,000 ng/mL; SRL C0 level 10 to 15 ng/mL | NR | SRL: 10 CsA: 7 | SRL: 4 CsA: 4 | SRL: 3 CsA: 3 | Mean eGFR [underlined: Baseline] SRL: 61.85±10.45 mL/min/MDRD CsA: 63.77±8.9 [underlined: 2 years] SRL: 70.2 ±8.0 CsA: 55.86±7.8 | SRL: 96.8 μmol/L CsA: 126.72 | NR
Dudley et al. 2005^77^ | 1 year | Target CsA C0 at 12 months 117.0±49 ng/mL | NR | CsA: 0 MMF: 0 | CsA: 4 MMF: 2 | CsA: 0 MMF: 3 | NR | Serum creatinine clearance [underlined: 6 months] CsA: 244.1 (±55) μmol/L (increase of 22.3 from baseline) MMF: 200.7 (±61) (decrease of -21 from baseline) [underlined: 12 months] CsA: 245.1 (±50) (increase of 22.2) from baseline MMF: 198.0 (±53) (decrease of -24.9 from baseline) | Number of responders (experienced a significant improvement in renal function) [underlined: 6 months] CsA: 18 MMF: 36 [underlined: 12 months] CsA: 21 MMF: 30
Watson et al. 2005^78^ | 1 year | Median daily dose of SRL at 12 months 2.5 mg; whole blood levels 8.5 ng/mL (4.9 to 12.5) Median C0 TAC: 10.6 ng/mL; median CsA: 187 ng/mL | NR | CNI: 0 SRL: 0 | NR | NR | Baseline GRF CNI: 36.1 mL/min SRL: 37.8 Mean difference between groups at [underlined: 3 months]: 7.9 mL/min (95% CI: 4.1 to 11.7, p=<0.001); at [underlined: 12 months]: 12.9 (95% CI: 6.1 to 19.7, p=<0.001) This indicates a GFR improvement of 8.5 ml/min among SRL group and a decline of 4.3 in the CNI group. | Mean difference between groups: -67 μmol/L (-148 to 14) | 1 patient in each group returned to dialysis
Bakker et al. 2003^79^ | 15 years | Mean dose of CsA 5.1±1.4 mg/kg | NR | CsA: 2 AZA: 3 | CsA: 24 AZA: 14 | CsA: 29 AZA: 27 | CsA: 59.3 mL/min/Nankivell SRL: 71.7 Diff: 15.7 (95% CI: 0 to 30.6) | NR | NR
Bakker et al. 2003^79^ | ≤10 years | Mean dose of CsA 5.1±1.4 mg/kg | NR | See above | CsA: 17 AZA: 9 | CsA: 19 AZA: 16 | [underlined: 3 months] CsA: 56.5 mL/min/Nankivell SRL: 53.5 Diff: 3.0 (95% CI: -2.6 to 8.6) [underlined: 1 year] CsA: 55.7 SRL: 72.9 Diff: 17.1 (95% CI: 11.6 to 22.7) [underlined: 10 years] CsA: 52.8 SRL: 71.7 Diff: 19.0 (95% CI: 10.0 to 27.8) | NR | NR
MacPhee et al. 1998^80^ | 10 year | Target levels of CsA (97±34 nmol/L) achieved at dose 2.5 to 3.0 mg/kg Target maintenance dose of AZA 1.6 to 1.9 mg/kg | NR | CsA: 17 AZA: 16 | CsA: 48 AZA: 39 | CsA: 12 AZA: 6 | NR | CsA: 153 μmol/L AZA: 153 μmol/L | NR
Hilbrands et al. 1996^81^ | 1 year | CsA C0 levels 100 to 200 ng/ml | NR | CsA: 20 AZA: 16 | CsA: 1 AZA: 1 | CsA: 1 AZA: 1 | NR | Mean creatinine clearance [underlined: At 3 months] CsA: 57 (40 to 69) ml/min AZA: 52 (42 to 66) [underlined: At 1 year] CsA: 53 (43 to 67) 64 (53 to 84) | Quality of Life at 1 year^3^ [underlined: Median SIP score] CsA: 3.8 (1.3 to 6.5) AZA: 3.5 (0.5 to 10.4) [underlined: Median ABS score] CsA: 7.5 (6 to 8.5) AZA: 7 (5.5 to 8) [underlined: Median CES-D score] CsA: 1 (0 to 4) AZA: 1 (0 to 5.5)

1 Composite variable defined as biopsy-proven acute rejection, graft loss, death and loss to follow-up, discontinuation due to lack of efficacy or toxicity, conversion to another regimen up to or at 12 month after transplantation.

2 The mean creatinine levels and standard deviations were estimated based on data presented in a figure.

3 Lower scores on the ABS, CES-D, and SIP indicate better quality of life.

ABS=affect balance scale; AUC=area under the curve; AZA=azathioprine; BEL=belatacept; C0=CsA trough level; C2=2 hour post CsA dosage level; CES-D=Center for Epidemiologic Studies Depression Scale; CI=confidence interval; CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; g/d=gram per day; GFR/eGFR=glomerular filtration rate/estimated glomerular filtration rate; h/L=hectoliter; k/L=kiloliter; MDRD=modification of diet in renal disease; mg/kg=milligram per kilogram; mL/min=milliliter per minute; MMF=mycophenolate mofetil group; MPS=mycophenolate sodium; ng/mL=nanogram per milliliter; nmol/L=nanogram per liter; NR=not reported; SIP=sickness impact profile; SRL=sirolimus; TAC=tacrolimus; μmol/L=micromoles per liter

Table E-8 Adverse events reported in conversion studies

Reference | Type of Intervention | New Onset Diabetes | Malignancy | Infection | Major Adverse Cardiac Events | Proteinuria | Blood Pressure/Lipids | Other
Budde et al. 2015^55^ | Conversion from CNI to EVR | NR | NR | Any infection: EVR 28 vs. CNI 26 Any serious infection: EVR 8 vs. CNI 4 CMV colitis: EVR 1 vs. CNI 1 CMV gastroenteritis: EVR | NR | EVR: 15 vs. CNI 3 | Hyperlipidemia: EVR 6 vs. CNI 0 Hypercholesterolemia: EVR 5 vs. CNI 0 Total cholesterol: EVR 6.2 mmol/L vs. CNI 5.2 mmol/L Triglycerides: EVR 2.6 vs. CNI 2.6 | Aphthous stomitis: EVR 12 vs. CNI 0 Nasopharyngitis: EVR 11 vs. CNI 11 Peripheral edema: EVR: 11 vs. CNI 3 Anemia: EVR 8 vs. CNI 4 Diarrhea: EVR 8 vs. CNI 11 Neutropenia: EVR 0 vs. CNI 0 Leukopenia: EVR 6 vs. CNI 2 Puritis: EVR 5 vs. CNI 0 Thrombocytopenia: EVR 2 vs. CNI 1
Rostaing et al. 2015^57^ | Conversion from CsA to EVR | NR | NR | CMV: EVR 3 vs. CsA 7 BK viremia: EVR 0 vs. CsA 3 Urinary tract infection: EVR 9 vs. CsA 7 | NR | NR | Dyslipidemia: EVR 9 vs. CsA 6 Hypertension: EVR 5 vs. CsA 6 Total cholesterol and LDL cholesterol: lower in CsA group HDL cholesterol: no difference between groups | Peripheral edema; EVR 15 vs. CsA 17 Aphthous stomatitis: EVR 19 vs. CsA 4 Anemia: EVR 9 vs. CsA 7 Diarrhea: EVR 8 vs. CsA 6 Bronchitis: EVR 7 vs. CsA 6 Neutropenia: EVR 6 vs. CsA 7 Pyrexia: EVR 6 vs. CsA 6 Leukopenia: EVR 2 vs. CsA 8 Gingival hypertrophy: EVR 0 vs. CsA 8 Acne: EVR 6 vs. CsA 1 Cough: EVR 2 vs. CsA 5 Rash: EVR 7 vs. CsA 0
Bensal et al. 2013^58^ | Conversion from Control Regimen to SRL | Authors report no difference between groups 9 (31%) in CNI group vs. 7 (22.6%) in SRL group; p=0.459 | NR | Herpes simplex virus infection: 1 patient in CNI group Herpes zoster: 1 patient in SRL group Fulminant bacterial pneumonia: 1 patient in SRL group 0 CMV or BK Respiratory infection: 1 patient in each group Skin infection: 1 patient in CNI group | 0 patients | No between-group differences | NR | Tuberculosis: 1 patient in CNI group Enthesitis: 4 patients in the SRL group. Seizure: 1 SRL patient with a history of seizures developed a seizure during treatment. Aphthous stomatitis: 1 patient in SRL group
Chhabra et al. 2013^59^ | Conversion from TAC to SRL | Authors report no difference between groups, data not included | TAC 4/123 vs. SRL 1/64 | CMV: TAC 7 vs. SRL 3 BK: TAC 5 vs. SRL 2 Pneumonia: TAC 3 vs. SRL 1 Herpes: TAC 4 vs. SRL 2 Nasopharyngitis: TAC 5 vs. SRL 1 Cyclosporidia: TAC 1 vs. SRL 0 Cellulitis: TAC 2 vs. SRL 0 Histoplasmosis: TAC 0 vs. SRL 1 UTI: TAC 20 vs. SRL 7 | Authors report no difference between groups, data not included | TAC 11 vs. SRL 5 | Hyperlipidemia higher in SRL vs. TAC group Cholesterol-lowering medication use: SRL: 45% CNI: 22% | Histoplasmosis: TAC 0 SRL 1 Cyclosporidia: TAC 1 SRL 0
Silva et al. 2013^60^ | Conversion from TAC to SRL | NR | Kaposi's sarcoma: TAC: 1/107 Emryonal testicular carcinoma: TAC: 2/107 | TAC group: Polyomavirus nephropathy: 2/107 (2%) CMV Virus: months 4-24 SRL: 5% TAC: 4% Herpes zoster: months 4-24 SRL: 4% TAC: 7% Polyomavirus: months 4-24 SRL: 3% TAC: 4% Pneumonia: TAC: 2 (2%) | 2 patients suffered a cardiovascular event leading to death. SRL: 1/97 TAC: 1/107 | SRL: 3 (3%) | Blood Pressure: No difference Dyslipidemia SRL: 6 TAC: 3 Total cholesterol (mg/dL) SRL: 219 TAC: 181 Triglycerides, HDL, VLDL, LDL higher in SRL group | 6 combined deaths recorded in SRL and TAC groups (2 due to infection and 1 due to cardiovascular event each) SRL: zygomycosis Diarrhea TAC: 2/107 (2%)
Budde et al. 2015^61^ FOLLOW-UP: Budde et al. 2012^62^ Budde et al. 2011^63^ | Conversion from CsA to EVR | Diabetes mellitus CsA: 15 (10%); 20 (13%) p=0.4667 | 13 malignancies were reported within 36 months after randomization Basalioma CSA: 11/145 EVR: 5/155 Squamous cell carcinoma CSA: 3/145 EVR: 2/155 Spinalioma (left arm) CSA: 1/145 Post-transplant lympho-proliferative disease EVR: 1/155 | Herpes virus CsA: 17 (12%); EVR: 24 (15%); Pneumocystis jirovecii pneumonia CsA: 1 (<1%); EVR: 1 (<1%) BK virus CsA: 5 (3%); EVR: 11 (7%) Cytomegalovirus CsA: 32 (22%); EVR: 32 (20%) Pneumonia CsA: 23 (16%); EVR: 25 (16%) Infections during months 12–24 CSA: 30 (20.7%); EVR: 35 (22.6%) Infections during months 24–36 CSA: 29 (20.0%); EVR: 31 (20.0%) Infections during months 12-60 CsA: 127 (87.6%); EVR: 137 (88.4%) UTI infection CsA: 109 (75%); EVR: 120 (77%); p=0·4866 | Myocardial infarction CsA: 1 (Death of patient not related to drug) | CsA: 24 (17%) EVR: 24 (15%) | Hyperlipidemia CsA: 15 (10%) EVR: 22 (14%) Hypercholes-terolemia CsA: 40 (28%) EVR: 45 (29%) Hypertriglyceridemia CsA: 5 (3%) EVR: 10 (6%) Hypertension CsA: 20 (14%) EVR: 8 (12%) Hypotension CsA: 32 (22%) EVR: 22 (114%) | Nasopharyngitis CsA: 49 (34%) EVR: 58 (37%) Aphthous stomatitis CsA: 4 (3%) EVR: 26 (17%) Diarrhea CsA: 45 (31%) EVR: 68 (44%) Impaired healing CsA: 5 (3%) EVR: 6 (4%)
Mjornstedt et al. 2012^65^ | Conversion from CsA to EVR | NR | Malignant parathyroid tumor EVR: 1 Adenocarcinoma of the prostate EVR: 1 Squamous cell carcinoma CsA: 1 Testicular cancer CsA: 1 At 3 year followup, authors report that 5 patients in each group developed a malignancy during 12 to 36 months | Urinary tract infection EVR: 15 (14.7%) CsA: 28 (28.0%) At 12 to 36 months, 27.2% of patients with EVR had a UTI vs. CNI 18.9% Polyoma virus infection EVR: 2 (2.0%) CsA: 1 (1.0%) CMV EVR: 9 (8.8%) CsA: 13 (13.0%) Herpes simplex EVR: 5 (4.9%) CsA: 1 (1.0%) Pneumonia EVR: 12 (11.8%) CsA: 2 (2.0%) Upper respiratory tract infection EVR: 5 (4.9%) CsA: 4 (4.0%) Herpes zoster EVR: 1 (1.0%) CsA: 6 (6.0%) Oral candidiasis EVR: 5 (4.9%) CsA: 2 (2.0%) BK virus nephropathy EVR: 1 CsA: 2 Sepsis EVR: 5 Gastroenteritis EVR: 5 | NR | EVR: 5 (4.9%) | Hyperlipidemia EVR: 13 (12.7%) CsA: 9 (9.0%) Hypercholesterolemia EVR: 10 (9.8%) CsA: 2 (2.0%) Blood pressure lower in EVR vs. CsA | [underlined: Edema] EVR: 30 (29.4%) CsA: 21 (21.0%) [underlined: Anemia] EVR: 17 (16.7%) CsA: 6 (6.0%) [underlined: Leukopenia] EVR: 14 (13.7%) CsA: 11 (11.0%) [underlined: Acne] EVR: 13 (12.7%) CsA: 2 (2.0%) [underlined: Mouth ulceration] EVR: 13 (12.7%) CsA: 1 (1.0%) [underlined: Lymphocele] EVR: 10 (9.8%) CsA: 6 (6.0%) [underlined: Dermatitis] EVR: 9 (8.8%) CsA: 5 (5.0%) [underlined: Cough] EVR: 7 (6.9%) CsA: 4 (4.0%) [underlined: Headache] EVR: 6 (5.9%) CsA: 4 (4.0%) [underlined: Hypokalemia] EVR: 6 (5.9%) [underlined: Venous thrombosis] EVR: 6 (5.9%) CsA: 3 (3.0%) [underlined: Myalgia] EVR: 5 (4.9%) CsA: 2 (2.0%) [underlined: Sinusitis] EVR: 5 (4.9%) CsA: 1 (1.0%) [underlined: Diarrhea] EVR: 5(4.9%) CsA: 11(11.0%) [underlined: Fatigue] EVR: 2 (2.0%) CsA: 7 (7.0%) [underlined: Hirsutism] EVR: 1 (1.0%) CsA: 6 (6.0%) [underlined: Arthralgia] EVR: 4 (3.9%) CsA: 5 (5.0%) [underlined: Dizziness] EVR: 1 (1.0%) CsA: 5 (5.0%) [underlined: Hydronephrosis] EVR: 4 [underlined: Pyelonephritis] CsA: 3
Nafar et al. 2012^66^ | Conversion from CsA to MMF | No significant findings. Fasting blood glucose, (mg/dL) 1 year followup values: SRL: 96 CsA: 105 | NR | NR | CsA: 4 patients suffered cardio events coupled with sepsis leading to death. | NR | Serum cholesterol (mg/dL) SRL: 194 CsA: 190 Serum triglyceride (mg/dL) SRL: 205 CsA: 189 | Hospitalization – 4 year period SRL: 52 CsA: 44
Heilman et al. 2011^67^ | Conversion from TAC to SRL; rapid STER withdrawal for all patients | NR | Cancer SRL: 1 | CMV SRL: 8 TAC: 8 BK virus Nephropathy SRL: 2 TAC: 3 Pneumonitis SRL: 2 Fever SRL: 1 | NR | SRL: 4 | Hyperlipidemia SRL: 4 No difference in blood pressure | Oral ulcers SRL: 7 Edema SRL: 3 Cytopenia SRL: 2 Rash SRL: 2 IFTA TAC: 2
Holdaas et al. 2011^31^ | Conversion from CNI to EVR | 6/127 vs. 4/123 | 9 vs. 7 | Any infection: 83 vs. 75 UTI: 22 vs. 13 Upper respiratory tract: 15 vs. 16 | NR | 21 vs. 11 | Cholesterol, triglycerides, hyperlipidemia higher in intervention group; no difference for hypertension | Higher incidence of GI, anemia, edema, pyrexia, in intervention group
Rostaing et al. 2011^68^ | Conversion from CNI to Belatacept | Diabetes Belatacept: 7 (8%) CNI: 10 (11%) | Basal cell carcinoma Belatacept: 1 (1%) CNI: 2 (2%) Kaposi's sarcoma Belatacept: 1 (1%) | [underlined: Herpes infections] Belatacept: 4 (5%) CNI 3 (3%) [underlined: BK polyoma virus] Infection Belatacept: 3 (4%) [underlined: Polyomavirus associated nephropathy] Belatacept: 1 (1%) [underlined: CMV infection] Belatacept: 2 (2%) CNI: 2 (2%) [underlined: Kaposi's sarcoma] Belatacept: 1 (1%) [underlined: Urinary tract infection] Belatacept: 2 (2%) [underlined: Total fungal Infections] Belatacept: 11 (13%) CNI: 3 (3%) [underlined: Tinea versicolor] Belatacept: 5 (6%) [underlined: Fungal infection] Belatacept: 1 (1%) CNI: 1 (1%) [underlined: Onychomycosis] Belatacept: 1 (1%) CNI: 1 (1%) [underlined: Body tinea] Belatacept: 1 (1%) [underlined: Skin candida] Belatacept: 1 (1%) [underlined: Vulvovaginal mycotic infection] Belatacept: 1 (1%) [underlined: Pyrexia] Belatacept: 3 (4%) | Myocardial infarction CNI: (1/89) | | BP over the 12 months Belatacept: 4.0/3.5 mmHg CNI group 1.6/1.7 mmHg | Congenital, Familial, and Metabolic Disorders Belatacept: 3 (4%) CNI: 3 (3%) Other causes Belatacept: 35 (42%) CNI: 43 (48%) Glomerulonephritis Belatacept: 23 (27%) CNI: 14 (16%) Polycystic kidneys Belatacept: 9 (11%) CNI: 9 (10%) Renovascular/hypertensive nephrosclerosis Belatacept: 7 (8%) CNI: 10 (11%) Pyelonephritis Belatacept: 2 (2%) CNI- 1 (1%)
Weir 2011^69^ | Conversion from CNI to SRL + MMF | Diabetes CNI: 2 (6%) | Malignancies SRL: 7 (4.7%) CNI: 10 (6.5%) | Aspergillus CNI: 1(0.9%) BK virus infection CNI: 9 (6%) Candida SRL: 8 (5.4%) CNI: 12 (7.8%) CMV SRL: 7 (4.7%) CNI: 15 (9.8%) Herpes simplex SRL: 6 (4.1%) CNI: 1 (0.7%) Herpes zoster SRL: 12 (8.1%) CNI: 8 (5.2%) Pneumocystis SRL: 2 (1.4%) Cryptococcus CNI: 1 (0.7%) | Pulmonary embolism CNI: 1 (lead to death) Cardiac arrest CNI: 1 (lead to death) | SRL: 3 (4.4%) | Diastolic blood pressure was lower after 24 months in SRL group Hyperlipidemia SRL: 120 (81.1%) CNI: 97 (63.4%) Hypertension SRL: 30 (20.3%) CNI: 25 (16.3%) | Diarrhea SRL: 51 (34.5%) CNI: 50 (32.7%) Peripheral edema SRL: 42 (28.4%) CNI: 20 (13.1%) Leukopenia SRL: 36 (24.3%) CNI: 29 (19%) Mouth Ulceration SRL: 21 (14.2%) Urosepsis CNI: 1 (lead to death) Focal segmentation SRL: 2 (3%)
Guba et al. 2010^70^ | Conversion from CsA to SRL | Diabetes mellitus SRL: 7.3% CsA: 5.6% p=0.7430 | CsA: 4 (6%) patients; including renal cell cancer, colon cancer, squamous cell cancer of the nasal cavity, and non-Hodgkin lymphoma of the transplanted kidney. SRL: No cancers This between group difference was not significant; p=0.1198 | CMV infection SRL: 7.3%; CsA: 28.2%; p=0.0016 Pneumonia SRL: 11.6%; CsA: 9.9%; p=0.7901 Urinary tract infections SRL: 18.8%; CsA: 29.6%; p=0.1691 Infections and infestations (overall) SRL: 52.2%; CsA: 60.6%; p=0.3942 Skin infections SRL: 8.70%; CsA: 1.41%; p=0.0608 Respiratory SRL: 13.0%; CsA: 7.0%; p=0.2711 | Cardiac disorders SRL: 13.0%; CsA: 5.6%; p=0.1545 | Proteinuria: SRL: 5 (7.3%) CsA: 1 (1.4%) (p=0.113) | Hyperlipidemia SRL: 20.3%; CsA: 7.0%; p=0.0269 | [underlined: Serious adverse events] SRL: 53.6% CsA: 66.2% p=0.1675; severity similar in both groups [underlined: Lymphocele] SRL: 27.5% CsA: 23.9%; p=0.7005 [underlined: Gastrointestinal disorders (overall)] SRL: 29.0% CsA: 33.8%; p=0.5877 [underlined: Diarrhea] SRL: 13.0% CsA: 9.9%; p=0.6037 [underlined: Metabolism and nutrition disorders (overall)] SRL: 30.4% CsA: 29.6%; p=1.0 [underlined: Blood and lymphatic disorders (overall)] SRL: 26.1% CsA: 23.9%; p=0.8462 [underlined: Anemia] SRL: 13.0% CsA: 5.6%; p=0.1545 [underlined: Thrombopenia] SRL: 2.9% CsA: 4.2%; p=1.0 [underlined: Leucopenia] SRL: 10.1% CsA: 11.3%; p=1.0 [underlined: Vascular disorders (overall)] SRL: 10.1% CsA: 18.3%; p=0.2277 [underlined: Hypertonia] SRL: 0% CsA: 4.2%; p=0.2448 [underlined: Skin and subcutaneous tissue disorders (overall)] SRL: 20.3% CsA: 7.0%; p=0.0269 [underlined: Acne] SRL: 7.25% CsA: 0%; p=0.0270 [underlined: Hepatobiliary disorders] SRL: 11.6% CsA: 9.9%; p=0.7901 [underlined: Nervous system disorders] SRL: 10.1% CsA: 9.9%; p=1.0
Bemelman et al. 2009^71^ Interim report of 2 year study | Conversion from CsA to MPS or EVR | NR | Posttransplant lymphoproliferative disease EVR: 1 | Cytomegalovirus disease CSA: 0(0%); MPS: 1(1%); EVR: 0(0%) Pneumonia CSA: 1(1%); MPS: 3(3%); EVR: 2(2%) Transplant pyelonephritis and urosepsis CSA: 1(1%); MPS: 0(0%); EVR: 5(5%) Lower urinary tract infection CSA: 2(2%); MPS: 3(3%); EVR: 9(6%) Flu-like syndrome EVR: 3(3%) | Cardio events CSA: 1(1%); MPS: 4(4%); EVR: 2(2%) | Not reported | No between group differences | Other (diarrhea, abdominal pain, varicella zoster, anemia, leucopenia) MPS: 7(7%) Other (abdominal pain, dysmenorrhea, urethral syndrome) EVR: 7(7%) Ankle edema CSA: 0(0%); MPS: 0(0%); EVR: 2(2%) Diarrhea CSA: 0(0%); MPS: 1(1%); EVR: 1(1%)
Schena et al. 2009^72^ | Conversion from CNI to SRL | Frequency of diabetes mellitus SRL: 4.7% CNI: 4.4% | Malignancies, Total SRL: 21 (3.8%) CNI: 30 (11.0%) Skin carcinoma SRL: 12 (2.2%) CNI: 21 (7.7%) | Infection Pneumonia SRL: 70 (12.7%) CNI: 14 (5.1%) Herpes simplex SRL: 48 (8.7%) CNI: 12 (4.4%) Fever SRL: 113 (20.5%) CNI: 25 (9.2%) | NR | Proteinuria higher in the CNI vs. SRL group. | Hyperlipidemia SRL: 295 (53.5%) CNI: 72 (26.4%) | Other [underlined: Aphthous stomatitis] SRL: 23 (4.2%) CNI: 1 (0.4%) [underlined: Stomatitis] SRL: 21 (3.8%) CNI: 1 (0.4%) [underlined: Acne] SRL: 10 (1.8%) [underlined: Hyperlipidemia] SRL: 295 (53.5%) CNI: 72 (26.4%) [underlined: Diarrhea] SRL: 216 (39.2%) CNI: 63 (23.1%) [underlined: Anemia] SRL: 200 (36.3%) CNI: 45 (16.5%) [underlined: Peripheral edema] SRL: 176 (31.9%) CNI: 37 (13.6%) [underlined: Albuminuria] SRL: 130 (23.6%) CNI: 35 (12.8%) [underlined: Acne] SRL: 89 (16.2%) CNI: 11 (4.0%) [underlined: Thrombocytopenia] SRL: 77 (14.0%) CNI: 9 (3.3%) [underlined: Leukopenia] SRL: 74 (13.4%) CNI: 12 (4.4%) [underlined: Skin rash] SRL: 67 (12.2%) CNI: 11 (4.0%) [underlined: Lactic dehydrogenase increased] SRL: 64 (11.6%) CNI: 3 (1.1%) [underlined: Hyperglycemia] SRL: 62 (11.3%) CNI: 18 (6.6%) [underlined: Hyperuricemia] SRL: 41 (7.4%) CNI: 42 (15.4%)
Lebranchu et al. 2011^73^ Lebranchu 2009^74^ | Conversion of CsA to SRL | More frequent in the SRL group (2 vs. 1); difference not significant | Metastatic gastric adeno-carcinoma SRL: 1 Lung adeno-carcinoma SRL: 1 Two patients (2.4%) Angiosarcoma CsA: 1 Kaposi Sarcoma CsA: 1 | BK virus infection CsA: 1 SRL: 1 | NR | Proteinuria (>1 g per 24 hr) CSA: 2; SRL: 3 | No difference in mean blood pressure, lipids level at 6 months | Diabetes showed a significant association with more severe fibrosis: 92% (12/13) of diabetic patients had IF grade >I at 1 year compared to 49% (53/108) in non-diabetic recipients. Gastrointestinal disorders reported in six cases (6.5%) in the SRL group and three (3.5%) in the CsA group
Durrbach et al. 2008^75^ | Conversion from CsA to SRL | NR | Prostate cancer SRL: 1 patient Kaposi's sarcoma CsA: 1 | CMV infection CsA: 4; SRL: 0 patients; p=0.12 | NR | Proteinuria (>1 g per 24 hr) CSA: 2; SRL: 3 | No significant differences in blood pressure and total lipid panels | Lymphocele CsA: 2%; SRL: 24.2%; p=0.04) Pancytopenia CsA: 0%; SRL: 12.1%; p=0.005) Abdominal pain CsA: 2.8%; SRL: 15.2%; p=0.1 Aphthous stomatitis CsA: 0%; SRL: 12.1%; p=0.05 Epistaxis CsA: 0%; SRL: 12.1%; p=0.05
Barsoum et al. 2007^76^ | Conversion from CsA to SRL | SRL: 3.6% CsA: 8.1% Authors report no significant difference | Lung malignancy SRL: 2.7%; CsA: 0%, authors report no significant difference Prostate malignancy SRL: 2.7%; CsA: 0%; authors report no significant difference | Herpes viral infection SRL: 15.8%; CsA: 21.1%; authors report no significant difference Pneumonia SRL: 11.8%; CsA: 10.8%; authors report no significant difference | Cardiovascular events SRL: 1.3% (Arm A) CsA: 8.1% (Arm B) | Proteinuria SRL: 36.8%; CsA: 18.6%; p<0.05 | Hypertension SRL: 52.6%; CsA: 91.8%; p<0.05 Hyperlipidemia (peak cholesterol >7.75 mmol/L); SRL: 32.9%; CsA: 23.7%; p<0.05 | Lymphoceles SRL: 14.5% CsA: 10.6% Peripheral edema SRL: 36.8% CsA: 37.8% Thrombotic microangiopathy SRL: 1.3% CsA: 0% Deep venous thrombosis SRL: 7.9% CsA: 13.5% Pulmonary embolism SRL: 2.6% CsA: 5.4% Oral ulcers SRL: 13.2% CsA: 5.4% Rectal ulcers SRL: 1.3% CsA: 0% >2-fold elevation of ALT SRL: 11.8% CsA: 10.8% >2-fold elevation of AST SRL: 6.6% CsA: 2.7% 2-fold elevation of GGT SRL: 21.1% CsA: 21.6%
Dudley et al. 2005^77^ | Conversion from CsA to MMF | NR | NR | CMV MMF: 1 CsA: 1 Herpes zoster MMF+ CsA: 11 Herpes simplex MMF+ CsA: 3 Candida albicans MMF+ CsA: 5 Chronic Hepatitis B MMF: 1 (lead to death) UTI MMF: 10 (14%) CsA: 5 (7%) | Myocardial Infarction MMF: 1 (lead to death) | NR | Significant differences in cholesterol in MMF group vs. CsA group. Lower blood pressure observed in MMF group vs. CsA group. Hypotension MMF: 11 (15%) CsA: 4 (6%) Hypertension MMF: 5 (7%) CsA: 8 (11%) | Diarrhea MMF: 33(45%) CsA: 4 (6%) Abdominal Pain MMF: 17 (23%) CsA: 8 (11%) Anemia MMF: 16 (22%) CsA: 6 (9%) Weight Loss MMF: 11 (15%) Vomiting/Nausea MMF: 12 (16%) CsA: 6 (9%) Anorexia MMF: 7 (10%) CsA: 4 (6%) Polycystic Kidney disease MMF: 1 (lead to death)
Watson et al. 2005^78^ | Conversion from CNI to SRL | NR | NR | Chest infection CNI: 2/19 SRL: 4/19 Herpes stomatitis CNI: 1/19 SRL: 2/19 UTI CNI: 4/19 SRL: 6/19 | NR | Lower levels of proteinuria after conversion to SRL | No significant changes in blood pressure and total cholesterol levels. | Acneiform rash SRL: 2 Diarrhea CNI: 4/19 SRL: 6/19 Acute gout CNI: 2/19 SRL: 1/19 Pulmonary embolism SRL: 1/19 Bone pain CNI: 2/19 SRL: 3/19 Coryza CNI: 1/19 SRL: 7/19 Dysmenorrhoea SRL: 3/19 Epistaxis CNI: 1/19 SRL: 3/19 Indigestion CNI: 3/19 SRL: 2/19 Mouth ulcers SRL: 6/19 Gum hypertrophy CNI: 5/19 Vomiting CNI: 2/19 SRL: 2/19
Bakker et al. 2003^79^ Followup to Hollander 1995 | Conversion from CsA to AZA | NR | Skin cancer CsA 15.2% vs AZA 16%; p=0.5 | NR | Cardiovascular mortality 15 year followup CsA: 21.2%; AZA: 23.3%, no significant difference 42.2% in the CsA group and 36.2% in the AZA group had at least one vascular event (p=0.57) | Proteinuria (<1g/day), after 15 years CsA: 14 AZA: 15 Proteinuria (>1g/day), after 15 years CsA: 1 AZA: 2 | Hypertension AZA: 1 No significant differences in total cholesterol and blood pressure. | Gout (n=1) and hypertension (n=1) led authors to convert one patient's medication to AZA and “accept lower cyclosporine trough levels in another” During follow-up, 15 patients in the cyclosporine group had their medications changed; in 13 of them (87%), the reason for this change was cyclosporine nephrotoxicity.
MacPhee et al. 1998^80^ | Conversion from CsA to AZA | NR | Total malignancies AZA: 2 (2%) CsA: 2 (1.8%) | CMV AZA: 1 Serious infections requiring hospitalization were lower in AZA group. CsA: 42 AZA: 31 Total infections AZA: 5 (4.9%) CsA: 3 (2.6%) | Cardiovascular events CsA: 19 AZA: 21; no significant difference | NR | No significant differences in total cholesterol and blood pressure. | NR
Hilbrands et al. 1996^81^ | Conversion from CsA to AZA | NR | NR | NR | NR | NR | Antihypertensive therapy CsA: 19 (56%) AZA: 29 (64%) | [underlined: 6 months post-transplant] Excessive hair growth CsA: 59; AZA-Pred: 24; p<0.01 Swollen face CsA: 12; AZA-Pred: 33 Stiff or painful muscles CsA: 74; AZA-Pred: 36; p<0.01 Tingling in hands CsA: 15; AZA-Pred: 16 Headache CsA: 18; AZA-Pred: 31 Swollen ankles CsA: 26; AZA-Pred: 16 Shortness of breath CsA: 18; AZA-Pred: 31 Difficulty sleeping CsA: 24; AZA-Pred: 22 Bruises CsA: 15; AZA-Pred: 29 Heartburn CsA: 6; AZA-Pred: 20 Dizziness CsA: 0; AZA-Pred: 20; p<0.05 [underlined: 12 months post-transplant] Excessive hair growth CsA: 32; AZA-Pred: 7; p<0.01 Swollen face CsA: 9; AZA-Pred: 20 Stiff or painful muscles CsA: 35; AZA-Pred: 31 Tingling in hands CsA: 2; AZA-Pred: 9 Headache CsA: 18; AZA-Pred: 18 Swollen ankles CsA: 15; AZA-Pred: 13 Shortness of breath CsA: 15; AZA-Pred: 16 Difficulty sleeping CsA: 21; AZA-Pred: 16 Bruises CsA: 9; AZA-Pred: 33; p<0.05 Heartburn CsA: 9; AZA-Pred: 22 Dizziness CsA: 6; AZA-Pred: 13

AZA=azathioprine; BK=polyomavirus; CMV=cytomegalovirus; CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; GI=gastrointestinal; IFTA=interstitial fibrosis and tubular atrophy on kidney allograft biopsy; LDL=low density lipoprotein; MMF=mycophenolate mofetil group; MPS=mycophenolate sodium; NR=not reported; Pred=prednisone; SRL=sirolimus; STER=steroid; TAC=tacrolimus; UTI=urinary tract infection

Table E-9 Study design characteristics of withdrawal studies

Reference | Type of Intervention | Intervention Regimen | Control Regimen | Analytical Method for Measuring Therapeutic Drug Levels | Induction Therapy | Time from Transplant to Start of Intervention | Special Inclusion/Exclusion Criteria
Chadban et al. 2014^19^ | Withdrawal of CsA | CsA and EC-MPS withdrawn + EVR (8-12 ng/mL) + STER | CsA (C2 target 500–700 ng/mL) + EC-MPS (1,440 mg) + STER | NR | Basiliximab | 2 months | Excluded age >65, PRA >50%, retransplants
Asberg et al. 2012^82^ | Withdrawal of CsA | CsA withdrawn “in steps over a four-wk period”) + MMF (≥2,000 mg) + STER (prednisolone) | CsA (75–125 ng/mL) + MMF withdrawn + STER (prednisolone) | NR | NR | >1 year | Excluded PRA >20%
Mourer et al. 2012^83^ | Withdrawal of CNI | CsA (C2 target 600–800 ng/mL) or TAC (100–140 μg·hr/mL) withdrawn by 50% reduction followed after 2 weeks by elimination + MMF (MPA-AUC_0-12_ target 60–90 μg·hr/mL) + STER (prednisolone 5–10 mg) | CsA (C2 target 600–800 ng/mL) or TAC (100–140 μg·hr/mL) + MMF withdrawn by 50% reduction followed after 2 weeks by elimination + STER (prednisolone 5-10 mg) | NR | NR | Minimum 6 months | Excluded PRA >60%
Flechner et al. 2011^84^ | Withdrawal of TAC | TAC (6–15 ng/mL) withdrawn by 25% reduction weekly until elimination + SRL (8-15 ng/mL before, 12-20 ng/mL after TAC withdrawal) + STER (5 mg) | TAC (5-15 ng/mL) + MMF (1,000-2,000 mg) + STER (5 mg) | IA | Daclizumab | 13 weeks | NR
Freitas et al. 2011^85^ | Withdrawal of TAC | TAC (5–8 ng/mL) withdrawn over 4 weeks + SRL (12–20 ng/mL) + STER (prednisone 10 mg) | TAC (5–8 ng/mL) + SRL (12–20 ng/mL) + STER (prednisone 10 mg) withdrawn over 4 weeks | NR | None | 3 months | Excluded PRA >50%
Pascual et al. 2008^86^ | Withdrawal of CNI | TAC (5–10 ng/mL) or CsA (100–200 ng/mL) withdrawn by 25–50% reduction on day of randomization, followed by elimination 7–14 days after + MMF (1,000–2,000 mg) or EC-MPS (720–1,440 mg) + STER (methylprednisolone 5–7.5 mg) | TAC (5–10 ng/mL) or CsA (100–200 ng/mL) + MMF (1,000–2,000 mg) or EC-MPS (720–1,440 mg) + STER (methylprednisolone 5–7.5 mg) | NR | Alemtuzumab | Between 2 and 16 months | Excluded PRA >10%
Ekberg et al. 2007a42 | Withdrawal of CsA | CsA withdrawn by 33% reduction each month + MMF (2,000 mg) + STER (prednisone 5 mg) | CsA (100–200 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | NR | Daclizumab in intervention group | 4 months | Excluded PRA >20%, retransplants
Hazzan et al. 2006^87^ (1 year follow up to Hazzan et al. 2005^88^) | Withdrawal of CsA | CsA (100–300 ng/mL) withdrawn by 25% reduction weekly until elimination + MMF (2,000 mg) + STER (prednisone 0.10–0.15 mg/kg) | CsA (100–300 ng/mL) + MMF (2,000 mg) withdrawn by 25% reduction weekly until elimination + STER (prednisone 0.10–0.15 mg/kg) | NR | ATG | 3 months | Excluded PRA >30%
Suwelack et al. 2004^89^ | Withdrawal of CNI | CsA (80–120 ng/mL) or TAC (4–7 ng/mL) withdrawn by 33% reduction every 2 weeks until elimination + MMF (2,000 mg) + STER (prednisone ≥5 mg) | CsA (80–120 ng/mL) or TAC (4–7 ng/mL) + MMF (2,000 mg) + STER (prednisone ≥5 mg) | NR | NR | Minimum 1 year | All patients had chronic allograft dysfunction
Stallone et al. 2003^90^ | Withdrawal of CsA | CsA (150–250 ng/mL) withdrawn + SRL (10–15 ng/mL) + STER (prednisone 5 mg) | CsA (150–250 ng/mL) + SRL (10–15 ng/mL) + STER (prednisone 5 mg) | NR | NR | 3 months | NR
Abramowicz et al. 2002^91^ | Withdrawal of CsA | CsA (100–200 ng/mL) withdrawn by 33% reduction every 6 weeks until elimination + MMF (2,000 mg) + STER (mean dose 13 mg) | CsA (100–200 ng/mL) + MMF (2,000 mg)+ STER (mean dose 7.5 mg) | NR | NR | Between 12 and 30 months | Excluded PRA >50%
Gonwa et al. 2002^92^ | Withdrawal of CsA | CsA (100–150- ng/mL) withdrawn by 25% reduction weekly until elimination + SRL (10–20 ng/mL) + STER (0.15 mg/kg) | CsA (150–250 ng/mL) + SRL (fixed dose 2 mg) + STER (0.15 mg/kg) | IA HPLC, Mass Spectrometry | NR | 2 months | NR
Schnuelle et al. 2002^93^ | Withdrawal of CsA | CsA (150–250 ng/mL) withdrawn by 33% reduction every 3 weeks until elimination + MMF (2,000 mg) + STER (7.5–10 mg) | CsA (100–250 ng/mL) + MMF withdrawn by 500 mg reduction every 2 weeks until elimination + STER (7.5–10 mg) | IA | None used | 3 months | Excluded PRA >50%
Smak Gregoor et al. 2002^94^ Roodnat et al. 2014^95^ | Withdrawal of CsA | CsA (125–175 ng/mL) withdrawn by 50% reduction followed after 2 weeks by elimination + MMF (2,000 mg) + STER (prednisone) | CsA (125–175 ng/mL) + MMF (2,000 mg) + STER (prednisone) maintained or withdrawn over 10 weeks | IA | None used | Minimum 6 months | NR
Johnson et al. 2001^96^ | Withdrawal of CsA | CsA (150–300 ng/mL) withdrawn “over the course of 4–6 weeks” + SRL (20–30 ng/mL) + STER (5–10 mg) | CsA (75–200 ng/mL) + SRL (>5 ng/mL) + STER (5–10 mg) | IA | NR | 3 months | NR

AUC_0-12_=area under the curve 0-12 hours; CNI=calcineurin inhibitors; CsA=cyclosporine; EC-MPS=enteric-coated mycophenolate sodium; EVR=everolimus; mg/kg=milligram per kilogram; MMF=mycophenolate mofetil group; MPA=medroxyprogesterone acetate; MPS=mycophenolate sodium; ng/mL=nanogram per milliliter; NR=not reported; PRA=panel reactive antibody; SRL=sirolimus; STER=steroid; TAC=tacrolimus; μg·hr/mL=micrograms per hour per milliliter

Table E-10 Study population characteristics of withdrawal studies

Reference | Type of Intervention | Country/Region | N, Intervention | N, Control | Donor Type | Mean Age, Intervention vs. Control | Gender: % Male | Race: % Caucasian | Delayed Graft Function %, Intervention vs. Control
Chadban et al. 2014^19^ | Withdrawal of CsA | Asia Australia New Zealand | 49 | 47 | Deceased: 52 Living related: 51 Living unrelated: 21 | 48 vs. 46 | 71% | 51% | NR
Asberg et al. 2012^82^ | Withdrawal of CsA | Norway | 20 | 19 | Deceased: 21 Living: 18 | 63 vs. 54 | 67% | NR | NR
Mourer et al. 2012^83^ | Withdrawal of CNI | Netherlands | 79 | 79 | Deceased: 95 Living: 63 | 52 vs. 53 | 70% | NR | 34% vs. 34%
Flechner et al. 2011^84^ | Withdrawal of TAC | Worldwide | 152 | 139 | Deceased: 181 Living related: 67 Living unrelated: 43 | 48 vs. 48 | 65% | 74% | 13% vs. 15%
Freitas et al. 2011^85^ | Withdrawal of TAC | Brazil | 23 | 24 | Living related and unrelated | 35 vs. 35 | 57% | 55% | NR
Pascual et al. 2008^86^ | Withdrawal of CNI | USA | 20 | 20 | Deceased: 23 Living related: 11 Living unrelated: 6 | 55 vs. 54 | 80% | 100% | 20% vs. 20%
Ekberg et al. 2007a42 | Withdrawal of CsA | Worldwide | 179 | 173 | Deceased: 273 Living related: 56 Living unrelated: 23 | 47 vs. 49 | 62% | 82% | 17% vs. 22%
Hazzan et al. 2006^87^ Hazzan et al. 2005^88^) | Withdrawal of CsA | France | 54 | 54 | Deceased | 45 vs. 42 | 63% | NR | NR
Suwelack et al. 2004^89^ | Withdrawal of CNI | Germany | 18 | 20 | NR | 48 vs. 49 | 74% | 100% | NR
Stallone et al. 2003^90^ | Withdrawal of CsA | Italy | 20 | 20 | Deceased | 40 vs. 47 | NR | 100% | 40% vs. 45%
Abramowicz et al. 2002^91^ | Withdrawal of CsA | Worldwide | 85 | 85 | Deceased: 154 Living: 16 | 45 vs. 48 | 59% | 96% | NR
Gonwa et al. 2002^92^ | Withdrawal of CsA | USA Europe | 100 | 97 | Deceased | 45 vs. 45 | 57% | 77% | NR
Schnuelle et al. 2002^93^ | Withdrawal of CsA | Germany | 44 | 40 | NR | 45 vs. 51, p=0.02 | 64% | NR | 18% vs. 20%
Smak Gregoor et al. 2002^94^ Roodnat et al. 2014^95^ | Withdrawal of CsA | Netherlands | 63 | 149 | Deceased: 160 Living: 52 | 52 vs. 51 | 66% | NR | NR
Johnson et al. 2001^96^ | Withdrawal of CsA | Australia Canada Europe | 215 | 215 | Deceased: 370 Living related: 37 Living unrelated: 14 | 45 vs. 46 | 64% | 94% | 19% vs. 22%

CNI=calcineurin inhibitors; CsA=cyclosporine; NR=not reported; TAC=tacrolimus

Table E-11 Clinical outcomes of withdrawal studies

Reference | Length of Followup | Biopsy Proven Acute Rejection | Graft Loss | Patient Death | Mean eGFR or Creatinine Clearance, mL/min (Method) | Mean Serum Creatinine, μmol/L | Regimen Changed
Chadban et al. 2014^19^ | 1 year | 15/49 vs. 6/47, p<0.05 Banff (year not reported): Grade 1A: 7 vs. 3 Grade 1B: 5 vs. 4 Grade 2A: 6 vs. 0 Grade 2B: 1 vs. 1 Grade 3: 0 vs. 1 Unspecified: 0 vs. 2 | 0 vs. 2 | 0 vs. 1 | 65.1±15.4 vs. 67.1±18.2, p<0.05 (Nankivell) | NR | 24 vs. 8
Asberg et al. 2012^82^ | 7 years | 6/20 vs. 0/19, p=0.02 | 5 vs. 1, p=NS | 6 vs. 6 | NR | 1 year: 120±59 vs. 104±23, p=NS 7 years: 87±24 vs. 116±24, p=0.01 | 7 vs. 4
Mourer et al. 2012^83^ | 3 years | 6 months: 3/79 vs. 1/79 1 year: 4 vs. 1 3 years: 4 vs. 2 | 1 vs. 1 | 4 vs. 6 | 1 year: 61.1±1.8 vs. 52.9±1.8, p<0.01 3 years: 59.5±2.1 vs. 51.1±2.1, p<0.01 (MDRD) | NR | 11 vs. 7, p=NS
Flechner et al. 2011^84^ | 2 years | 1 year: 23/152 vs. 11/139 2 years: 26 vs. 17 | 17 vs. 7, p=NS | 8 vs. 5 | 1 year: 59.1±23.9 vs. 62.0±22.1, p=NS 2 years: 58.3 vs. 62.2, p=NS (Nankivell) | No difference | 52 vs. 31
Freitas et al. 2011^85^ | 1 year | 2/21 vs. 1/24 Banff 97: Grade 1A: 1 vs. 0 Grade 2A: 1 vs. 1 | 0 | 1 vs 1 | 63.4±10.5 vs. 60.0±11.5, p=NS (Nankivell) | 114.92±30.94 vs. 129.95±22.98, p=NS | 5 vs. 3
Pascual et al. 2008^86^ | 1 year | 2/20 vs. 0/20 Banff 97: Grade 1A: 1 Grade 2A: 1 | 0 | 0 | 72.1±11.6 vs. 68.0±12.1, p=NS Change from baseline: 3.9±9.7 vs. 4.3±11.5, p=NS | 1.52±0.64 vs. 1.45±0.30, p=NS | NR
Ekberg et al. 2007a42 | 1 year | 68/179 vs. 48/173, p<0.05 | 12 vs. 9 | 8 vs. 5 | 50.9±6.4 vs. 48.6±6.9 | 1.7 mg/dL vs. 1.6 mg/dL | NR
Hazzan et al. 2006^87^ Hazzan et al. 2005^88^ | 2 years | 1 year: 10/54 vs. 3/54, p<0.05 2 years: 12/54 vs. 3/54 Banff 97: Grade 1: 9 vs. 2 Grade 2: 1 vs. 1 NR: 2 | 1 year: 0 2 year: 4 vs. 1, p=NS | 0 | 1 year: 49.1±17.8 vs. 40.1±11.1, p<0.05 2 years: 45.6±21.6 vs. 37.7±11.0, p<0.05 (aMDRD) | NR | 12 vs. 18, p=NS
Suwelack et al. 2004^89^ | 9 months | 0 | 0 vs. 3 | NR | NR | As measured by the slope of the reciprocal of serum creatinine, renal function significantly improved in the intervention group and deteriorated in the control group: 0.00585±0.01122 vs. -0.00728±0.01105, p<0.01 | NR
Stallone et al. 2003^90^ | 1 year | 2/20 vs. 2/20 | 0 | 0 | 3 months: 57.1±16.3 vs. 57.8±18.9 (Nankivell) 1 year: 66±17 vs. 54±14, p<0.01 | 3 months: 1.6±0.4 vs. 1.9±0.4 1 year: 1.3±0.3 vs. 2.0±0.3, p<0.01 | NR
Abramowicz et al. 2002^91^ | 9 months | 9/85 vs. 2/85, p<0.05 Grade 1: 5 vs. 1 Grade 2: 1 vs. 1 Grade 3: 1 vs. 0 Fine needle aspirate: 2 vs. 0 | 0 | 1 vs. 0 | Intervention group 2.3 mL/min higher than control, p=NS (Nankivell) Intervention group 4.5 mL/min higher than control, p=NS (Cockcroft-Gault) | Change from baseline: -1 vs. 4, p=NS | NR
Gonwa et al. 2002^92^ | 1 year | 6 months: 18/100 vs. 15/97, p=NS 1 year: 22 vs. 18, p=NS | 5 vs. 7 | 4 vs. 3 | 6 months: 64.2 vs. 55.9, p<0.01 1 year: 65.3 vs. 56.4, p<0.01 (Nankivell) | 6 months: 1.59±0.07 vs. 1.93±0.12, p<0.01 1 year: 1.64±0.12 vs. 1.99±0.15, p=NS | NR
Schnuelle et al. 2002^93^ | 1 year | 5/44 vs. 2/40 Banff 93: Grade 1: 2 vs. 2 Grade 2: 3 vs. 0 | 1 vs. 0 | 0 | 6 months: 76.4±16.9 vs. 66.1±12.2, p<0.01 1 year: 73.2±14.9 vs. 61.9±11.8, p<0.01 (Nankivell) | 6 months: 115.4±33.3 vs. 127.8±30.8, p=NS 1 year: 120.7±32.5 vs. 138.3±30.8, p<0.05 | NR
Smak Gregoor et al. 2002^94^ Roodnat et al. 2014^95^ | 15 years | 18 months: 14/63 vs. 4/149, p<0.01 Banff 93: Grade 1: 5 vs. 3 Grade ≥2: 9 vs. 1 | 18 months: 2 vs. 3 15 years: 17 vs. 26, p=NS | 18 months: 0 vs. 4 15 years: 31 vs. 61, p=NS | Median, 6 months: 66 vs. 63 vs. 58 (CsA withdrawal + MMF + STER vs. CsA + MMF + STER vs. CsA + MMF + withdrawal of STER) 18 months: 64 vs. 65 vs. 58 (Cockcroft-Gault) | Median, 6 months: 117 vs. 124 vs. 137 18 months: 123 vs. 125 vs. 137 | 18 months: 18 vs. 12, p<0.05 15 years: 20 vs. 69
Johnson et al. 2001^96^ | 1 year | 21/215 vs. 9/215, p<0.05 | 6 vs. 9 | 4 vs. 6 | 62.7±1.5 vs. 56.6±1.3, p<0.01 | 141.6±5.3 vs. 158.1±4.2, p<0.01 | 58 vs. 39, p<0.05

aMDRD=abbreviated modification of diet in renal disease; MDRD=modification of diet in renal disease; NR=not reported; NS=not significant

Table E-12 Adverse events reported in withdrawal studies

Reference | Type of Intervention | New Onset Diabetes | Malignancy | Infection | Major Adverse Cardiac Events | Proteinuria | Blood Pressure/Lipids | Other
Chadban et al. 2014^19^ | Withdrawal of CsA | 18 vs. 13 | 2 vs. 1 | CMV: 2 vs. 4 All infections: 33 vs. 34 | NR | 1 vs. 1 | No difference between groups for cholesterol | No difference between groups for GI, anemia
Asberg et al. 2012^82^ | Withdrawal of CsA | NR | 4/20 vs 1/19 | Sepsis: 0 vs. 2 | Cardiovascular cause of death: 1 vs. 2 | NR | NR | NR
Mourer et al. 2012^83^ | Withdrawal of CNI | 4 vs. 5 | 4 vs. 6 | 34 vs. 25, p=NS | NR | NR | No difference in BP, cholesterol | Anemia: 18 vs. 9, p=0.06
Flechner et al. 2011^84^ | Withdrawal of TAC | 27/120 vs. 12/110, p<0.05 | 7/152 vs. 5/139 | All infections: 61.2% vs. 66.9% | NR | 17 vs. 9 | Cholesterol and triglycerides higher in intervention group | Intervention group had higher incidence of edema, hyperlipidemia, tremor, hyperkalemia, lymphoceles, thrombocytopenia, acne Control group had higher incidence of diarrhea; no difference for anemia, hypertension
Freitas et al. 2011^85^ | Withdrawal of TAC | “similar between groups” | 0 | “similar between groups” | NR | 3 vs. 2 | No difference in BP, triglycerides, dyslipidemia; total cholesterol higher in intervention group, p=0.02 | Intervention group: higher incidence (NS) of lymphocele or lymphorrhea, stomatitis, headache, leucopenia, thrombocytopenia, dyslipidemia Control group: higher incidence (NS) of diarrhea, anemia, cramps; 1 case of nephrotoxicity in control group
Pascual et al. 2008^86^ | Withdrawal of CNI | 0/20 vs. 2/20 | NR | CMV: 3 vs. 2 Herpes zoster: 0 vs. 1 Gastroenteritis: 0 vs. 1 UTI: 2 vs. 0 Sinusitis: 1 vs. 0 | NR | Increased in both groups, difference NS | No difference | 2 cases of nephrotoxicity in control group
Ekberg et al. 2007a42 | Withdrawal of CsA | NR | 4 (including 2 posttransplant lymphoproliferative disorder) vs. 1 | CMV: 23 vs. 24 Candida: 8 vs. 16 Herpes simplex: 14 vs. 11 Herpes zoster: 3 vs. 9 | NR | NR | No difference | No difference for lymphocele, hypertension
Hazzan et al. 2006^87^ Hazzan et al. 2005^88^ | Withdrawal of CsA | NR | NR | NR | NR | No difference | NR | 15 cases of nephrotoxicity in control group
Suwelack et al. 2004^89^ | Withdrawal of CNI | NR | 0 | CMV: 1 vs. 6 Herpes zoster: 0 vs. 2 | 2 vs. 0 | 0.50±0.55 vs. 1.50±0.48, p=0.01 | BP lower in intervention group | Lower incidence of GI, anemia in intervention group
Stallone et al. 2003^90^ | Withdrawal of CsA | 5/20 vs. 5/20 | NR | NR | NR | NR | No difference | NR
Abramowicz et al. 2002^91^ | Withdrawal of CsA | NR | 1/85 vs. 4/85 | 8 vs. 11 Includes CMV, herpes, zoster, herpes simplex, candida (specific data not reported) | NR | NR | No difference for BP, triglycerides; improved LDL and total cholesterol for intervention group | Higher incidence of diarrhea in intervention group
Gonwa et al. 2002^92^ | Withdrawal of CsA | No difference | 4/100 vs. 0/97 (2 skin carcinomas, 1 lymphoproliferative disease, 1 renal cell carcinoma) | “no significant differences in the rates of clinically important infections” | NR | NR | Systolic BP lower in intervention group (p<0.05) but no difference in diastolic BP; total cholesterol higher in intervention group (p<0.05); no difference in triglycerides | Intervention group: higher incidence of atrial fibrillation, diarrhea, abnormal liver function, thrombocytopenia, hypokalemia Control group: significantly higher incidence of edema, dyspnea, hypertension, hypervolemia, hypomagnesemia, hirsutism
Schnuelle et al. 2002^93^ | Withdrawal of CsA | 4/44 vs. 6/40 | NR | CMV: 3 vs. 1 Herpes simplex: 1 vs. 1 Herpes zoster: 1 vs. 0 Oral candidiasis: 1 vs. 0 PCP: 0 vs. 1 UTI: 4 vs. 13 Upper respiratory tract: 2 vs. 1 Pneumonia: 3 vs. 3 Septicemia: 0 vs. 3 Other: 1 vs. 1 | NR | NR | Lower BP and improved lipids in intervention group | No difference in GI, hirsutism; 1 case of nephrotoxicity in control group
Smak Gregoor et al. 2002^94^ Roodnat et al. 2014^95^ | Withdrawal of CsA | NR | 2 skin carcinomas, 1 lymphoma | 18 months: CMV: 4 vs. 3 Herpes simplex: 5 vs. 13 Herpes zoster: 2 vs. 3 Candida stomatitis: 3 vs. 4 Oesofagitis: 0 vs. 2 Pneumonia: 3 vs. 8 Bronchitis: 2 vs. 18 UTI: 36 vs. 64 Upper respiratory tract: 13 vs. 32 Gastrointestinal: 4 vs. 6 Skin: 7 vs. 9 Other: 1 vs. 5 Sepsis: 3 vs. 2 | NR | No difference between groups, or vs. baseline | Triglycerides lower in intervention group at 18 months, p<0.05 | Nephrotoxicity: 1 vs. 7
Johnson et al. 2001^96^ | Withdrawal of CsA | 9 vs. 7 | 2 (lymphoma and “other”) vs. 7 (4 skin cancer, 1 lymphoma, 2 “other”) | CMV: 8 vs. 7 Sepsis: 4 vs. 8 Pneumonia: 15 vs. 9 Herpes simplex: 13 vs. 10 Herpes zoster: 1 vs. 11 Oral moniliasis: 5 vs. 7 | NR | NR | No difference in BP, cholesterol, triglycerides | Hypertension lower in intervention group; thrombocytopenia and hypokalemia higher in intervention group Nephrotoxicity: 5 vs. 15, p<0.05

BP=blood pressure; CMV=cytomegalovirus=CNI=calcineurin inhibitors; CsA=cyclosporine; GI=gastrointestinal; NR=not reported; NS=not significant; PCP=pneumocystis carinii pneumonia; UTI=urinary tract infection; TAC=tacrolimus

Table E-13 Study design characteristics of avoidance studies

Reference | Type of Intervention | Intervention Regimen | Control Regimen | Analytical Method for Measuring Therapeutic Drug Levels | Induction Therapy | Time from Transplant to Start of Intervention | Special Inclusion/Exclusion Criteria
Asher et al. 2013^97^ | Avoidance of TAC | SRL (8-10 mg/day) + MMF (1,000 mg) + STER (prednisolone) | TAC (5-10 ng/mL) + MMF (1,000 mg) + STER (prednisolone) | NR | Daclizumab | Immediate | NR
Vincenti et al. 2010^98^ BENEFIT Follow-ups: Larsen et al. 2010^99^ Vincenti et al. 2012^100^ Rostaing et al. 2013^101^ Dobbels et al. 2014^102^ | Avoidance of CsA | Belatacept (5 mg/kg) in more intensive or less intensive schedule of administration + MMF (2,000 mg) + STER (≥2.5 mg) | CsA (100–250 ng/mL) + MMF (2,000 mg) + STER (≥2.5 mg) | NR | Basiliximab | Immediate | Excluded PRA >50%, or PRA >30% for retransplants
Durrbach et al. 2010^103^ BENEFIT-EXT Follow-ups: Larsen et al. 2010^99^ Pestana et al. 2012^104^ Charpentier et al. 2013^105^ Dobbels et al. 2014^102^ | Avoidance of CsA | Belatacept (5 mg/kg) in more intensive or less intensive schedule of administration + MMF (2,000 mg) + STER (≥2.5 mg) | CsA (100–250 ng/mL) + MMF (2,000 mg) + STER (≥2.5 mg) | NR | Basiliximab | Immediate | Extended criteria donors: Age ≥60 years; or age ≥50 years with at least 2 risk factors (cerebro-vascular accident, hypertension or serum creatinine >1.5 mg/dL); or anticipated cold ischemia time ≥24 hours; or donation after cardiac death
Refaie et al. 2011^106^ | Avoidance of TAC | SRL (10–15 ng/mL) | TAC (4–8 ng/mL) | NR | Alemtuzumab | Immediate | Excluded retransplants
Glotz et al. 2010^107^ | Avoidance of TAC | rATG induction (1.25–1.5 mg/kg) + SRL (12–20 ng/mL) + MMF (1,500 mg) + STER (prednisolone 0.1 mg/kg) | TAC (5-9 ng/mL) + MMF (1,500 mg) + STER (prednisolone 0.1 mg/kg) | HPLC | rATG for intervention group only | Immediate | Excluded age>65, PRA >50%
Ekberg et al. 2007b43 | Avoidance of CsA | SRL (4–8 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | CsA (100–200 ng/mL) + MMF (2,000 mg) + STER (prednisone 5 mg) | IA (CNI) HPLC (SRL) | Daclizumab in intervention group | Immediate | Excluded age>75, PRA >20%
Schaefer et al. 2006^108^ | Avoidance of TAC | SRL (8–12 ng/mL) + MMF (2,000 mg) + STER (prednisone 10 mg) | TAC (8–12 ng/mL) + MMF (2,000 mg) + STER (prednisone 5–10 mg) or withdrawal of STER | NR | ATG | Immediate | NR
Flechner et al. 2002^109^ | Avoidance of CsA | SRL (5–10 ng/mL) + MMF (2,000 mg) + STER (prednisone 7.5 mg) | CsA (200–250 ng/mL) + MMF (2,000 mg) + STER (prednisone 7.5 mg) | IA (CsA) HPLC-MS (SRL) | Basiliximab | Immediate | Excluded age>70, retransplants
Groth et al. 1999^110^ | Avoidance of CsA | SRL (15 ng/mL) + AZA (2 mg/kg) + STER (prednisone or prednisolone 10 mg) | CsA (100–200 ng/mL) + AZA (2 mg/kg) + STER (prednisone or prednisolone 10 mg) | IA (CsA) HPLC (SRL) | Not used | Immediate | Excluded age>60, PRA >70%

ATG/rATG=antithymocyte globulin/rabbit antithymocyte globulin; AZA=azathioprine; CNI=calcineurin inhibitors; CsA=cyclosporine; HPLC=high performance liquid chromatography; IA=immunoassay; mg/kg=milligram per kilogram; mg/mL=milligram per milliliter; MMF=mycophenolate mofetil group; ng/mL=nanogram per milliliter; NR=not reported; PRA=panel reactive antibody; SRL=sirolimus; TAC=tacrolimus

Table E-14 Study population characteristics of avoidance studies

Reference | Type of Intervention | Country/Region | N, Intervention | N, Control | Donor Type | Mean Age, Intervention vs. Control | Gender: % Male | Race: % Caucasian | Delayed Graft Function %, Intervention vs. Control
Asher et al. 2013^97^ | Avoidance of TAC | United Kingdom | 19 | 19 | Deceased | 49 vs. 49 | NR | NR | NR
Vincenti et al. 2010^98^ BENEFIT Follow-ups: Larsen 2010^99^ Vincenti et al. 2012^100^ Rostaing et al. 2013^101^ Dobbels et al. 2014^102^ | Avoidance of CsA | Worldwide | 445 | 221 | Deceased: 280 Living related: 280 Living unrelated: 106 | 44 vs. 43 | 70% | 61% | 15% vs. 18%
Durrbach et al. 2010^103^ BENEFIT-EXT Follow-ups: Larsen et al. 2010^99^ Pestana et al. 2012^104^ Charpentier et al. 2013^105^ Dobbels et al. 2014^102^ | Avoidance of CsA | Worldwide | 359 | 184 | NR | 57 vs. 56 | 68% | 76% | 47% vs. 49%
Refaie et al. 2011^106^ | Avoidance of TAC | Egypt | 10 | 11 | Living related | 30 vs. 34 | 75% | NR | NR
Glotz et al. 2010^107^ | Avoidance of TAC | France Belgium | 71 | 70 | Deceased | 48 vs. 47 | 62% | 84% | NR
Ekberg et al. 2007b43 | Avoidance of CNI | Worldwide | 399 | 390 | Deceased: 512 Living related: 231 Living unrelated: 46 | 45 vs. 46 | 65% | 93% | NR
Schaefer et al. 2006^108^ | Avoidance of TAC | USA | 41 | 78 | Deceased Living | NR | NR | NR | NR
Flechner et al. 2002^109^ | Avoidance of CsA | USA | 31 | 30 | Deceased: 40 Living related: 14 Living unrelated: 7 | 48 vs. 47 | 66% | 67% | 13% vs. 17%
Groth et al. 1999^110^ | Avoidance of CsA | Europe | 41 | 42 | Deceased | 48 vs. 42, p=0.02 | 65% | 93% | 17% vs. 7%

BENEFIT=Belatacept Evaluation of Nephroprotection and Efficacy as First-line Immunosuppression Trial; CNI=calcineurin inhibitors; CsA=cyclosporine; NR=not reported; TAC=tacrolimus

Table E-15 Clinical outcomes of avoidance studies

Reference | Length of Followup | Biopsy Proven Acute Rejection | Graft Loss | Patient Death | Mean eGFR or Creatinine Clearance, mL/min (Method) | Mean Serum Creatinine, μmol/L | Regimen Changed
Asher et al. 2013^97^ | Avoidance of TAC | 5/19 vs. 2/19 | 0 | 1 vs. 0 | 3 months eGFR: 56.7 vs. 58.0, p=NS (Cockcroft-Gault) 6 months eGFR: 67.1 vs. 55.8, p=NS 9 months eGFR: 49.9 vs. 61.9, p=NS 1 year eGFR: 51.1 vs. 59.1 | 3 months: 128±1.45 vs. 141±1.59, p=NS 6 months: 130±1.47 vs. 134±1.52, p=NS 9 months: 153±1.73 vs. 153±1.73, p=NS 1 year: 143±1.62 vs. 142±1.62, p=NS | 10/19 SRL switched to TAC within 3 months
Vincenti et al. 2010^98^ BENEFIT Follow-ups: Larsen et al. 2010^99^ Vincenti et al. 2012^100^ Rostaing et al. 2013^101^ Dobbels et al. 2014^102^ | 5 years | 1 year: 88/445 vs. 16/221 Banff 97: Grade 1A: 11 vs. 3 Grade 1 B: 11 vs. 5 Grade 2A: 33 vs. 6 Grade 2B: 30 vs. 2 Grade 3: 3 vs. 0 2 years: 92 vs. 20 3 years: 92 vs. 21 5 years: 93 vs. 22 | 1 year: 9 vs. 8 2 years: 12 vs. 8 3 years: 19 vs. 10 5 years: 19 vs. 13 | 1 year: 10 vs. 7 2 years: 15 vs. 13 3 years: 19 vs. 15 5 years: 24 vs. 22 | 1 year measured GFR: 65.0±30.0 vs. 63.4±27.7 vs. 50.4±18.7, p<0.01 2 years measured GFR: 65.0±27.2 vs. 67.9±29.9 vs. 50.5±20.5 3 years eGFR (MDRD): 65.2±26.3 vs. 65.8±27.0 vs. 44.4±23.6 5 years eGFR (MDRD): 74.1±18.9 vs. 76.4±19.0 vs. 53.0±17.2, p<0.01 | NR | 1 year:133 overall 2 years:167 overall
Durrbach et al. 2010^103^ BENEFIT-EXT Follow-ups: Larsen et al. 2010^99^ Pestana et al. 2012^104^ Charpentier et al. 2013^105^ Dobbels et al. 2014^102^ | 5 years | 1 year: 64/359 vs. 26/184 Banff 97: Grade 1A: 4 vs. 2 Grade 1B: 9 vs. 2 Grade 2A: 27 vs. 17 Grade 2B: 24 vs. 5 2 years: 64 vs. 28 3 years: 66 vs. 29 5 years: 69 vs. 29 | 1 year: 33 vs. 20 2 years: 38 vs. 22 3 years: 39 vs. 23 5 years: 42 vs. 28 | 1 year: 12 vs. 8 2 years: 24 vs. 12 3 years: 37 vs. 17 5 years: 51 vs. 23 | 1 year measured GFR: 52.1±21.9 vs. 49.5±25.4 vs. 45.2±21.1, p<0.01 for more intensive vs. CsA 2 years measured GFR: 51.5±22.2 vs. 49.7±23.7 vs. 45.0±27.2 5 years eGFR: 55.9 vs. 59.0 vs. 44.6 | NR | 1 year: 149 overall 2 years: 189 overall
Refaie et al. 2011^106^ | 4 years | 2/10 vs. 5/11 Antibody-mediated rejection: 2 vs. 2 Borderline: 0 vs. 2 Grade 1A: 0 vs. 1 | 2 vs. 1 | 0 vs. 1 | 1.83±0.88 mL/second vs. 1.38±0.48 mL/second, p<0.05 | 114.9±17.7 vs. 114.9±26.4, p=NS | 2 vs. 8
Glotz et al. 2010^107^ | 1 year | 12/71 vs. 9/70 Banff 97: Grade 1A: 6 vs. 4 Grade 1B: 2 vs. 3 Grade 2A: 3 vs. 1 Grade 2B: 1 vs. 0 Grade 3: 0 vs. 1 | 10 vs. 3, p<0.05 | 3 vs. 2 | 6 months eGFR: 72.7 vs. 65.2, p<0.05 (Nankivell) 1 year eGFR: 68 vs. 62, p=NS 6 months CrCl: 68.8±21.6 vs. 57.5 ±19.4, p<0.05 (Cockcroft-Gault) | NR | 33 vs. 7, p<0.001
Ekberg et al. 2007b43 | 1 year | 6 months: 141/399 vs. 94/390 12 months: 160 vs. 117 | 33 vs. 32 | 12 vs. 13 | 56.7±26.9 vs. 57.1±25.1 (Cockcroft-Gault) 47.5±26.1 vs. 46.2±23.1 (MDRD) | NR | NR
Schaefer et al. 2006^108^ | 1 year | 5/41 vs. 5/78 | 3 vs. 1 | 2 vs. 0 | NR | 3 months: 1.3±0.4 vs. 1.5±0.4 (with STER) vs. 1.4±0.4 (without STER) p=0.01 for intervention group vs. control group with STER | NR
Flechner et al. 2002^109^ | 1 year | 2/31 vs. 5/30 Borderline: 1 vs. 2 Grade 1A: 1 vs. 2 Grade 2A: 1 | 1 vs. 1 | 1 vs. 0 | 6 months: 77.8±21.0 vs. 64.1±19.1, p<0.01 1 year: 81.1±23.9 vs. 61.1±14.6, p<0.01 (Cockcroft-Gault) | 6 months: 1.29±0.30 vs. 1.74±0.81 mg/dL, p<0.01 1 year: 1.32±0.33 vs. 1.78±0.76 mg/dL, p<0.01 | 0 vs. 3
Groth et al. 1999^110^ | 1 year | 6 months: 17/41 vs. 16/42 Banff 93: Grade 1: 6 vs. 9 Grade 2: 9 vs. 6 Grade 3: 2 vs. 1 | 1 vs. 4 | 0 vs. 1 | 3 months: 66.1±3.3 vs. 54.2±3.3, p<0.05 6 months: 66.7±3.6 vs. 59.0±3.4, p=NS 1 year: 69.5±4.1 vs. 58.7±3.6, p=NS (Nankivell) | 3 months: 126.2±11.4 vs. 159.2±11.2, p<0.05 6 months: 126.2±8.7 vs. 135.4±8.2, p=NS 1 year: 115.8±8.9 vs. 133.5±7.7, p=NS | 24 vs. 19

CrCl=creatinine clearance; CsA=cyclosporine; GFR/eGFR=glomerular filtration rate/estimated glomerular filtration rate; MDRD=modification of diet in renal disease; mg/dL=milligrams per deciliter; NS=not significant; STER=steroids

Table E-16 Adverse events reported in avoidance studies

Reference | Type of Intervention | New Onset Diabetes | Malignancy | Infection | Major Adverse Cardiac Events | Proteinuria | Blood Pressure/Lipids | Other
Asher et al. 2013^97^ | Avoidance of TAC | NR | NR | NR | NR | NR | NR | 2 cases of edema, 1 case of arthralgia, 1 case of sepsis, 1 case of graft dysfunction, all in intervention group
Vincenti et al. 2010^98^ BENEFIT Follow-ups: Larsen et al. 2010^99^ Vincenti et al. 2012^100^ Rostaing et al. 2013^101^ Dobbels et al. 2014^102^ | Avoidance of CsA | 1 year: 18 vs. 16, p=NS 2 years: no change | 1 year: 9 vs. 1 2 years: 27 vs. 11 3 years: 28 vs. 12 Post-transplant lymphoproliferative disorder: 5 vs. 1 5 years: 20 vs. 12 (neoplasms included) | 1 year: CMV: 30 vs. 19 BK: 13 vs. 9 Pneumonia: 5 vs. 5 Sepsis: 3 vs. 4 UTI: 117 vs. 50 Upper respiratory tract: 46 vs. 26 Nasopharyngitis: 20 vs. 20 Influenza: 32 vs. 10 Oral candidiasis: 18 vs. 13 Bronchitis: 16 vs. 5 Gastroenteritis: 13 vs. 7 2 years: CMV: 24 vs. 7 Pneumonia: 9 vs. 9 UTI: 26 vs. 23 3 years: CMV: 48 vs. 25 BK: 28 vs. 18 Herpes simplex: 6 vs. 2 Herpes zoster: 18 vs. 11 Oral candidiasis: 26 vs. 14 Onchomycosis: 19 vs. 6 Candidiasis: 14 vs. 2 Body tinea: 8 vs. 1 5 years: Pneumonia: 7 vs. 3 UTI: 11 vs. 5 Pyelonephritis: 5 vs. 3 | 5 years: 8 vs. 4 | NR | BP, cholesterol, triglycerides better in intervention group at 1, 2, and 5 years | No difference in GI, lymphocele, pyrexia at 1, 2, and 5 years No difference in metabolic, vascular, nervous system disorders at 5 years
Durrbach et al. 2010^103^ BENEFIT-EXT Follow-ups: Larsen et al. 2010^99^ Pestana et al. 2012^104^ Charpentier et al. 2013^105^ Dobbels et al. 2014^102^ | Avoidance of CsA | 1 year: 8 vs. 11, p<0.05 for less intensive belatacept vs. CsA | 1 year: 8 vs. 6 Post-transplant lymphoproliferative disorder: 3 vs. 0 2 years: 27 vs. 17 3 years: 31 vs. 19 Post-transplant lymphoproliferative disorder: 5 vs. 0 5 years: 40 vs. 22 Post-transplant lymphoproliferative disorder: 8 vs. 1 | 1 year: CMV: 45 vs. 24 Pneumonia: 15 vs. 5 UTI: 112 vs. 62 Upper respiratory tract: 22 vs. 14 Nasopharyngitis: 33 vs. 13 Oral candidiasis: 12 vs. 12 Bronchitis: 27 vs. 11 Gastroenteritis: 11 vs. 10 2 years: CMV: 33 vs. 12 Pneumonia: 14 vs. 6 UTI: 38 vs. 17 Pyelonephritis: 10 vs. 8 3 years: CMV: 59 vs. 31 BK: 19 vs. 9 Herpes simplex: 5 vs. 3 Herpes zoster: 32 vs. 9 Oral candidiasis: 18 vs. 12 Onchomycosis: 9 vs. 3 Candidiasis: 9 vs. 6 Body tinea: 5 vs. 7 5 years: CMV: 8 vs. 3 BK: 5 vs. 1 Herpes (all): 18 vs. 10 Pneumonia: 7 vs. 3 Sepsis: 4 vs. 4 UTI: 10 vs. 5 Pyelonephritis: 5 vs. 6 Central nervous system infections: 3 vs. 0 Fungal infections: 31 vs. 12 | NR | NR | 1 year: BP, triglycerides, non-HDL cholesterol better in intervention group; no difference for LDL and HDL cholesterol 3 years: BP lower in intervention group; no difference in cholesterol or triglycerides 5 years: BP lower in intervention group; total and non-HDL cholesterol lower in intervention group; no difference in HDL cholesterol; triglycerides lower in intervention group | No difference in GI, anemia, leukopenia, hyperkalemia, pyrexia at 1 and 3 years
Refaie et al. 2011^106^ | Avoidance of TAC | 3/10 vs. 2/11 | 0 vs. 1 (Kaposi sarcoma) | 1 (tuberculosis) vs. 1 (hepatitis B) | NR | 7/9 vs. 3/6, p=0.2 | No difference in cholesterol | NR
Glotz et al. 2010^107^ | Avoidance of TAC | 11 vs. 14 | 2 vs. 1 (all lympho-proliferative disorder) | CMV: 1 vs. 14, p<0.001 Herpes: 9 vs. 5, p=NS BK: 2 vs. 0 Pneumonia: 5 vs. 1 | NR | No difference in mean values; but 36% of intervention vs. 14% of control have proteinuria (p<0.05) | No difference in hypertension or hyperlipidemia Hypercholesterolemia higher in intervention group | Higher incidence of edema, hypokalemia, anemia, thrombocytopenia in intervention group Higher incidence of hyperkalemia, leukopenia in control group No difference in stomatitis
Ekberg et al. 2007b43 | Avoidance of CNI | 25 vs. 23 | 10 vs. 5 Post-transplant lymphoproliferative disorder, oral mucosa, renal-cell, non-small-cell lung, small-cell lung, breast, colon, T-cell non-Hodgkin's, B-cell non-Hodgkin's, ovarian vs. 2 basal-cell, squamous-cell, oral mucosa, Kaposi's sarcoma | All “opportunistic infections” (per study designation): 77 vs. 100 CMV: 23 vs. 55 Candida: 19 vs. 29 Herpes simplex: 23 vs. 21 All other infections: 200 vs. 208 UTI: 88 vs. 109 Pneumonia: 19 vs. 18 Nasopharyngitis: 15 vs. 22 | 11 vs. 15 | 20 vs. 9 | No differences | No difference for anemia, leukopenia, edema, pyrexia, disorders of the nervous system, respiratory system, or vascular system Higher incidence of lymphoceles and serious GI events in low dose SRL group
Schaefer et al. 2006^108^ | Avoidance of TAC | 6/41 vs. 5/78, p<0.05 | NR | Viral infections (CMV, BK): 0 vs. 2 | NR | NR | Cholesterol, lipids, triglycerides higher in intervention group compared with steroid-free control group | NR
Flechner et al. 2002^109^ | Avoidance of CsA | NR | NR | CMV: 3 vs. 2 | NR | NR | No difference in BP; cholesterol and triglycerides higher in both groups compared with baseline, but no difference between groups | NR
Groth et al. 1999^110^ | Avoidance of CsA | 1/41 vs. 1/42 | 0 vs. 2 (stomach carcinoid, basal cell carcinoma) | CMV: 6 vs. 5 Herpes simplex: 10 vs. 4 Herpes zoster: 0 vs. 1 Oral candida 3 vs. 0 PCP: 0 vs. 1 UTI: 17 vs. 12 Septicemia: 6 vs. 1 Pneumonia: 7 vs. 1 | NR | NR | Hypercholesterolemia and hypertriglyceridemia higher in intervention group (p<0.01, both); no difference in hypertension | Hypokalemia, thrombocytopenia, leukopenia, arthralgia higher in intervention group; no difference in anemia

BENEFIT=Belatacept Evaluation of Nephroprotection and Efficacy as First-line Immunosuppression Trial; BP=blood pressure; BK=BK polyomavirus; CMV=cytomegalovirus; CNI=calcineurin inhibitors; CsA=cyclosporine; GI=gastrointestinal; HDL=high density lipoprotein; LDL=low density lipoprotein; NR=not reported; NS=not significant; PCP=pneumocystis carinii pneumonia; SRL=sirolimus; TAC=tacrolimus; UTI=urinary tract infection

Table E-17 Study design characteristics of studies comparing two regimens

Reference | Type of Intervention | Minimization Regimen | Comparator Regimen | Analytical Method for Measuring Therapeutic Drug Levels | Induction Therapy | Time from Transplant to Start of Intervention | Special Inclusion/Exclusion Criteria
Rivelli et al. 2015^111^ | Minimization of TAC Withdrawal of TAC | Minimization: TAC (3-7 ng/mL) + SRL (6-12 ng/mL) + STER (prednisone 500 mg) | Withdrawal: Withdrawal of TAC + SRL (8-15 ng/mL) + STER (prednisone 500 mg) | HPLC | rATG for deceased donor recipients | 3 months | Excluded age >65 and PRA >25%
Burkhalter et al. 2012^112^ | Minimization of TAC Withdrawal of TAC | Minimization: TAC (4–8 ng/mL) + SRL (4–8 ng/mL) + EC-MPS (>2 mg/mL) | Withdrawal: Withdrawal of TAC by 50% reduction and then elimination over 2 weeks + SRL (8–12 ng/mL) + EC-MPS (>2 mg/mL) | NR | Basiliximab | 3 months | NR
Han et al. 2011^113^ | Minimization of CsA Conversion from CsA to SRL | Minimization: CsA (150–200 ng/mL if 6 months–1 year post-transplant; 100-150 ng/mL if 1–2 years post-transplant, and 50–100 ng/mL if >2 years post-transplant) + MMF + STER | Conversion: Conversion from CsA to SRL (5–8 ng/mL) + MMF + STER | NR | NR | Minimum 6 months | All patients had chronic allograft dysfunction; Excluded retransplants
Pankewycz et al. 2011^114^ | Minimization of TAC Conversion from TAC to SRL | Minimization: TAC (4–6 ng/mL) + MMF (1,440 mg) + STER (prednisone 5 mg) | Conversion: Conversion from TAC to SRL (5–10 ng/mL) + MMF (1,440 mg) + STER (prednisone 5 mg) | NR | rATG | 3 months | Excluded PRA >30%, retransplants
Cataneo-Davila et al. 2009^115^ | Minimization of CNI Conversion from CNI to EVR | Minimization: CNI (CsA or TAC) at 80% reduction from baseline + EVR (3–8 ng/dL) + STER (prednisone 5–10 mg) | Conversion: Conversion from CNI to EVR (5–10 ng/dL) + STER (prednisone 5–10 mg) + either MMF or AZA | NR | NR | Minimum 6 months | All patients had chronic allograft dysfunction
Liu et al. 2007^116^ | Minimization of CsA Conversion from CsA to SRL | Minimization: CsA (dose 1.5–2 mg/kg) + MMF (1,500 mg) + STER (prednisone 5 mg) | Conversion: Conversion from CsA to SRL (5–10 ng/mL) + MMF (1,500 mg) + STER (prednisone 5 mg) | FPLA (CsA) HPLC (SRL) | NR | Minimum 1 year | All patients had chronic allograft dysfunction; excluded age>60, PRA >10%
Hamdy et al. 2005^117^ | Minimization of TAC Avoidance | Minimization: TAC (3–7 ng/mL) + SRL (6–12 ng/mL) + STER (prednisolone 0.1 mg/kg) | Avoidance: SRL (10–15 ng/mL) + MMF (2,000 mg) + STER (prednisolone 0.1 mg/kg) | NR | Basiliximab | Within 24 hours | Excluded retransplants
Stallone et al. 2005^118^ | Minimization of CNI Conversion from CNI to SRL | Minimization: CsA (C2 target 400–500 ng/mL) or TAC (4–6 ng/mL) + MMF (1,000 mg) + STER (prednisone 5 mg) | Conversion: Conversion from CNI to SRL (6–10 ng/mL) + STER (prednisone 5 mg) | IA (CNI) HPLC (SRL) | NR | 1–3 years | All patients had chronic allograft dysfunction
Lo et al. 2004^119^ | Minimization of TAC Avoidance | Avoidance: SRL (12–15 ng/mL) + MMF (2,000 mg) + STER (5 mg) | Minimization: TAC (3–6 ng/mL) + SRL (10–15 ng/mL) + STER (5 mg) | HPLC-MS | rATG | Within 2 days | High risk population: 71% African-American; 30% age >50 years; 47% with delayed graft function; all donors deceased

CNI=calcineurin inhibitors; CsA=cyclosporine; EC-MPS=enteric-coated mycophenolate sodium; EVR=everolimus; FPIA=fluorescence polarization immunoassay; HPLC=high performance liquid chromatography; IA=immunoassay; mg/kg=milligram per kilogram; mg/mL=milligram per milliliter; MS=mass spectrometry; MMF=mycophenolate mofetil group; MPS=mycophenolate sodium; ng/mL=nanogram per milliliter; NR=not reported; PRA=panel reactive antibody; rATG=rabbit antithymocyte globulin; SRL=sirolimus; STER=steroid; TAC=tacrolimus

Table E-18 Study population characteristics in studies comparing regimens

Reference | Type of Intervention | Country/Region | N, Intervention | N, Control | Donor Type | Mean Age, Intervention vs. Control | Gender: % Male | Race: % Caucasian | Delayed Graft Function %, Intervention vs. Control
Rivelli et al. 2015^111^ | Minimization of TAC Withdrawal of TAC | Brazil | Minimization: 23 Withdrawal: 22 | NR | Deceased: 29 Living: 16 | Minimization: 46 Withdrawal: 45 | 56% | 51% | Minimization: 53% Withdrawal: 29%
Burkhalter et al. 2012^112^ | Minimization of TAC Withdrawal of TAC | Switzerland | Minimization: 19 Withdrawal: 18 | NR | Deceased: 9 Living: 28 | Minimization: 55 Withdrawal: 43 p<0.05 | 86% | NR | NR
Han et al. 2011^113^ | Minimization of CsA Conversion from CsA to SRL | China | Minimization: 29 Conversion: 22 | NR | Deceased | Minimization: 44 Conversion: 45 | 75% | 100% Asian | NR
Pankewycz et al. 2011^114^ | Minimization of TAC Conversion from TAC to SRL | USA | Minimization: 29 Conversion: 23 | NR | Deceased: 24 Living: 28 | Minimization: 57 Conversion: 51 | 69% | 13% African-American | Minimization: 17% Conversion: 4%
Cataneo-Davila et al. 2009^115^ | Minimization of CNI Conversion from CNI to EVR | Mexico | Minimization: 10 Conversion: 10 | NR | Deceased: 5 Living: 15 | Minimization: 29 Conversion: 39 | 45% | NR | NR
Liu et al. 2007^116^ | Minimization of CsA Conversion from CsA to SRL | China | Minimization: 64 Conversion: 56 | NR | Deceased | Minimization: 36 Conversion: 35 | 75% | 100% Asian | NR
Hamdy et al. 2005^117^ | Minimization of TAC Avoidance | Egypt | Minimization: 65 Avoidance: 67 | NR | Living | Minimization: 32 Avoidance: 32 | 75% | NR | NR
Stallone et al. 2005^118^ | Minimization of CNI Conversion from CNI to SRL | Italy | Minimization: 50 Conversion: 34 | NR | NR | Minimization: 43 Conversion: 49 | NR | NR | Minimization: 24% Conversion: 29%
Lo et al. 2004^119^ | Minimization of TAC Avoidance | USA | Minimization: 41 Avoidance: 29 | NR | Deceased | Minimization: 44 Avoidance: 42 | 57% | 71% African-American | Minimization: 56% Avoidance: 34%

CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; NR=not reported; SRL=sirolimus; TAC=tacrolimus

Table E-19 Clinical outcomes of studies comparing regimens

Reference | Type of Intervention | Length of Followup | Biopsy Proven Acute Rejection | Graft Loss | Patient Death | Mean eGFR or Creatinine Clearance, mL/min (Method) | Mean Serum Creatinine, μmol/L | Regimen Changed
Rivelli et al. 2015^111^ | Minimization of TAC Withdrawal of TAC | 1 year | Minimization: 5 Withdrawal: 5 | Minimization: 2 Withdrawal: 3 | Minimization: 2 Withdrawal: 1 | CrCl, 3 months Minimization: 54.9±14.6 Withdrawal: 57.8±14.7; p=NS CrCL, 1 year Minimization: 57.0±16.6 Withdrawal: 68.1±9.1; p<0.05 | 3 months Minimization: 1.4±0.3 Withdrawal: 1.4±0.4; p=NS 1 year Minimization: 1.4±0.4 Withdrawal: 1.2±0.4; p<0.05 | NR
Burkhalter et al. 2012^112^ | Minimization of TAC Withdrawal of TAC | 6 months | Minimization: 1 Withdrawal: 2 | NR | NR | Minimization: 52 Withdrawal: 45 (Median) | NR | Minimization: NR Withdrawal: 4
Han et al. 2011^113^ | Minimization of CsA Conversion from CsA to SRL | 4 years | Minimization: 2 Conversion: 2 | “graft survival estimate”: Minimization: 55% Conversion: 77% | NR | eGFR declined in minimization group over baseline, p<0.05; eGFR higher in conversion group compared with minimization group, p<0.05 | NR | NR
Pankewycz et al. 2011^114^ | Minimization of TAC Conversion from TAC to SRL | 1 year | Minimization: 0 Conversion: 1 | Minimization: 0 Conversion: 1 | NR | Minimization: 74±15 Conversion: 66±18 | NR | Minimization: 1 Conversion: 4
Cataneo-Davila et al. 2009^115^ | Minimization of CNI Conversion from CNI to EVR | 1 year | Minimization: 1 Conversion: 0 | Minimization: 0 Conversion: 0 | Minimization: 0 Conversion: 0 | Minimization: 76.2±22.6 Conversion: 66.2±13.7 | Minimization: 1.24±0.4 Conversion: 1.25±0.3 | Minimization: 1 Conversion: 0
Liu et al. 2007^116^ | Minimization of CsA Conversion from CsA to SRL | 2 years | NR | “graft survival ratio was markedly higher in conversion group” | NR | Minimization: 37±9.7 Conversion: 50±12.3 p<0.05 | Minimization: 210.2±66.9 Conversion: 150.4±54.8 p<0.05 | NR
Hamdy et al. 2005^117^ | Minimization of TAC Avoidance | 2 years | Minimization: 12 Avoidance: 9 | Minimization: 4 Avoidance: 3 | Minimization: 2 Avoidance: 0 | Minimization: 79.6±25.5 Avoidance: 94.9±28.9 p<0.05 | Minimization: 1.43±0.40 Avoidance: 1.25±0.39 p<0.05 | Minimization: 20 Avoidance: 6
Stallone et al. 2005^118^ | Minimization of CsA Conversion from CsA to SRL | 2 years | Minimization: 0 Conversion: 0 | Minimization: 8 Conversion: 1 | Minimization: 0 Conversion: 0 | Minimization: 47.8±17.6 Conversion: 53.1±21.5 | Minimization: 1.99±0.59 Conversion: 1.86±0.60 | NR
Lo et al. 2004^119^ | Minimization of TAC Avoidance | 1 year | Minimization: 4 Avoidance: 2 | Minimization: 8 Avoidance: 3 | Minimization: 1 Avoidance: 0 | Minimization: 52.9±22.8 Avoidance: 72.4±20.0 p<0.05 | NR | Minimization: 5 Avoidance: 8

CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; eGFR=estimated glomerular filtration rate; mL/min=milliliter per minute; NR=not reported; SRL=sirolimus; TAC=tacrolimus; μmol/L=micromoles per liter

Table E-20 Adverse events reported in studies comparing regimens

Reference | Type of Intervention | New Onset Diabetes | Malignancy | Infection | Major Adverse Cardiac Events | Proteinuria | Blood Pressure/Lipids | Other
Rivelli et al. 2015^111^ | Minimization of TAC Withdrawal of TAC | NR | NR | NR | NR | NR | NR | Polyomavirus-associated nephropathy: Minimization 0 vs. Withdrawal 2 Acute pyelonephritis: Minimization 1 vs. Withdrawal 1
Burkhalter et al. 2012^112^ | Minimization of TAC Withdrawal of TAC | NR | NR | NR | NR | NR | Triglycerides higher in withdrawal group; no difference for cholesterol | NR
Han et al. 2011^113^ | Minimization of CsA Conversion from CsA to SRL | NR | NR | 1 pneumonia in conversion group | NR | NR | Cholesterol and triglycerides increased in conversion group | NR
Pankewycz et al. 2011^114^ | Minimization of TAC Conversion from TAC to SRL | NR | NR | Minimization: 1 BK Conversion: 1 pneumonia, 1 pyelonephritis | NR | 1 severe case in conversion group | 1 patient in conversion group changed regimen due to elevated triglycerides | NR
Cataneo-Davila et al. 2009^115^ | Minimization of CNI Conversion from CNI to EVR | NR | NR | “no severe infections” | NR | NR | Cholesterol and triglycerides higher than baseline in conversion group; no difference in minimization group | NR
Liu et al. 2007^116^ | Minimization of CsA Conversion from CsA to SRL | NR | NR | NR | NR | Higher than baseline in both groups, but no difference between groups | Cholesterol and triglycerides higher in conversion group than minimization group; no difference for BP | NR
Hamdy et al. 2005^117^ | Minimization of TAC Avoidance | Minimization: 18 Avoidance: 13 | NR | Minimization: 14 UTI, 3 tuberculosis, 4 fungal Avoidance: 5 herpes zoster, 23 UTI, 1 tuberculosis, 2 fungal | NR | Minimization: 9 Avoidance: 20 | Cholesterol and hyperlipidemia higher in avoidance group | Higher incidence of GI in minimization group; no difference for leukopenia
Stallone et al. 2005^118^ | Minimization of CNI Conversion from CNI to SRL | No difference | NR | “no major infections occurred” | NR | Minimization: 0.92±0.52 Conversion: 1.2±0.69 | No differences | NR
Lo et al. 2004^119^ | Minimization of TAC Avoidance | Minimization: 10 Avoidance: 5 | Minimization: 1 post-transplant lymphoproliferative disorder Avoidance: 1 prostate cancer | No CMV in either group Minimization: 1 sepsis, 4 pneumonia, 2 UTI Avoidance: 4 pneumonia, 2 UTI | NR | NR | Cholesterol, triglycerides, hyperlipidemia increased in both groups over baseline, but no significant differences between groups | No difference for GI, anemia, thrombocytopenia. 28 patients in minimization group and 17 patients in avoidance group were readmitted to hospital

BP=blood pressure; BK=polyomavirus; CMV=cytomegalovirus; CNI=calcineurin inhibitors; CsA=cyclosporine; EVR=everolimus; GI=gastrointestinal; NR=not reported; SRL=sirolimus; TAC=tacrolimus; UTI=urinary tract infection

Table E-21 Risk of bias assessment for studies addressing Key Question 3

Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Did the study enroll all suitable patients or consecutive suitable patients? | Was compliance with treatment ≥85% in both of the study's groups? | Were outcome assessors blinded to the group to which patients were assigned? | Was the outcome measure of interest objective and was it objectively measured? | Was a standard instrument used to measure the outcome? | Was there a ≤15% difference in completion rates in the study's groups? | Was the funding derived from a source that would not benefit financially from results? | Overall Risk of Bias
Cai et al. 2014^18^ | Yes | NR | Yes | NR | NR | NR | Yes | NR | Yes | No | High
Muhlbacher et al. 2014^20^ | Yes | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | High
Oh et al. 2014^21^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | No | Low
Bechstein et al. 2013^22^ | NR | NR | Yes | NR | NR | Yes | Yes | Yes | Yes | No | High
Chadban et al. 2013^23^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | High
Cibrik et al. 2013^24^ | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | No | Moderate
Takahashi et al. 2013^25^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | No | Moderate
Chan et al. 2012^26^ | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | Yes | No | Moderate
Kamar et al. 2012^27^ | Yes | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | No | Moderate
Langer et al. 2012^28^ | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Moderate
Paoletti et al. 2012^29^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Low
Bertoni et al. 2011^30^ | NR | NR | Yes | NR | NR | NR | Yes | NR | Yes | Yes | High
Xu et al. 2011^32^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | NR | High
Etienne et al. 2010^33^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | Yes | Low
Fangmann et al. 2010^34^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | No | NR | Moderate
Gaston et al. 2009^35^ | Yes | NR | Yes | NR | No | NR | Yes | Yes | Yes | No | High
Salvadori et al. 2009^36^ | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Moderate
Spagnoletti et al. 2009^37^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | Yes | High
Bolin et al. 2008^38^ | Yes | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | High
Chan et al. 2008^39^ | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | No | Moderate
Budde et al. 2007^40^ | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | Yes | No | Moderate
Cibrik et al. 2007^41^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | No | Moderate
Ghafari et al. 2007^44^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | NR | NR | High
Hernandez et al. 2007^45^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Moderate
Frimat et al. 2006^46^ Frimat et al. 2010^47^ | Yes | NR | Yes | Yes | No | NR | Yes | Yes | Yes | No | Moderate
Tang et al. 2006^48^ | Yes | NR | Yes | Yes | NR | Yes | Yes | Yes | NR | No | High
Vathsala et al. 2005^49^ | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Moderate
Lo et al. 2004^50^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | Yes | NR | High
Nashan et al. 2004^51^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | No | No | High
Stoves et al. 2004^52^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | No | Moderate
Pascual et al. 2003^53^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | High
de Sevaux et al. 2001^54^ | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | NR | No | High
Budde et al. 2015^56^ Budde et al. 2015^55^ | Yes | NR | Yes | Yes | NR | No | Yes | Yes | No | No | High
Rostaing et al. 2015^57^ | NR | NR | Yes | NR | No | NR | Yes | Yes | No | No | High
Bensal et al. 2013^58^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Low
Chhabra et al. 2013^59^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | NR | High
Silva et al. 2013^60^ | Yes | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Moderate
Budde et al. 2015^61^ Budde et al. 2012^62^ Budde et al. 2011^63^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Low
Mjornstedt et al. 2012^65^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | No | No | Moderate
Nafar et al. 2012^66^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | NR | High
Heilman et al. 2011^67^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | No | No | Moderate
Rostaing et al. 2011^68^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | No | High
Weir et al. 2011^69^ | Yes | NR | Yes | NR | Yes | NR | Yes | Yes | No | No | High
Guba et al. 2010^70^ | Yes | Yes | Yes | NR | Yes | NR | Yes | Yes | No | No | Moderate
Bemelman et al. 2009^71^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | No | No | Moderate
Schena et al. 2009^72^ | Yes | Yes | Yes | NR | Yes | NR | Yes | Yes | No | No | Moderate
Lebranchu et al. 2011^73^ Lebranchu 2009^74^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Low
Durrbach et al. 2008^75^ | Yes | NR | Yes | Yes | Yes | NR | Yes | Yes | No | No | High
Barsoum et al. 2007^76^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | High
Dudley et al. 2005^77^ | Yes | Yes | Yes | NR | Yes | NR | Yes | Yes | No | No | Moderate
Watson et al. 2005^78^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Low
Bakker et al. 2003^79^ | NR | NR | Yes | Yes | No | NR | Yes | Yes | Yes | NR | High
MacPhee et al. 1998^80^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | NR | High
Hilbrands et al. 1996^81^ Quality of Life | NR | NR | Yes | Yes | Yes | Yes | No | Yes | No | No | High
Hilbrands et al. 1996^81^ Renal function, BPAR | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | No | No | High
Asberg et al. 2012^82^ | NR | NR | NR | NR | Yes | NR | Yes | NR | Yes | No | High
Mourer et al. 2012^83^ | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Moderate
Flechner et al. 2011^84^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | High
Freitas et al. 2011^85^ | Yes | NR | Yes | NR | NR | NR | Yes | Yes | Yes | No | High
Pascual et al. 2008^86^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Low
Hazzan et al. 2006^87,88^) | NR | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | High
Suwelack et al. 2004^89^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | No | No | High
Stallone et al. 2003^90^ | NR | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | NR | High
Abramowicz et al. 2002^91^ | Yes | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | Moderate
Gonwa et al. 2002^92^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | No | High
Schnuelle et al. 2002^93^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | Yes | NR | High
Smak Gregoor et al. 2002^94^ Roodnat et al. 2014^95^ | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Moderate
Johnson et al. 2001^96^ | NR | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | No | High
Asher et al. 2013^97^ | NR | NR | Yes | NR | No | NR | Yes | Yes | No | NR | High
Vincenti et al. 2010^98-101^ | Yes | Yes | Yes | NR | No | Yes | Yes | Yes | Yes | No | Moderate
Durrbach et al. 2010^99,103-105^ | Yes | Yes | Yes | NR | No | Yes | Yes | Yes | Yes | No | Moderate
Refaie et al. 2011^106^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | NR | High
Glotz et al. 2010^107^ | NR | NR | Yes | Yes | No | NR | Yes | Yes | Yes | No | High
Schaefer et al. 2006^108^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | NR | NR | High
Flechner et al. 2002^109^ | Yes | NR | Yes | NR | Yes | NR | Yes | Yes | Yes | No | Moderate
Groth et al. 1999^110^ | Yes | Yes | Yes | NR | No | NR | Yes | Yes | Yes | No | Moderate
Chadban et al. 2014^19^ | Yes | Yes | Yes | NR | No | No | Yes | Yes | No | No | High
Holdaas et al. 2011^31^ | Yes | NR | Yes | NR | No | NR | Yes | Yes | Yes | No | High
Ekberg et al. 2007a42 | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | Yes | No | Moderate
Ekberg et al. 2007b43 | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | No | No | Moderate
Rivelli et al. 2015^111^ | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | Low
Burkhalter et al. 2012^112^ | Yes | Yes | Yes | NR | No | NR | Yes | Yes | Yes | NR | Moderate
Han et al. 2011^113^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | High
Pankewycz et al. 2011^114^ | NR | NR | Yes | NR | No | NR | Yes | Yes | No | No | High
Cataneo-Davila et al. 2009^115^ | NR | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | No | High
Liu et al. 2007^116^ | NR | NR | Yes | NR | NR | NR | Yes | Yes | NR | NR | High
Hamdy et al. 2005^117^ | NR | NR | Yes | NR | No | NR | Yes | Yes | Yes | NR | High
Stallone et al. 2005^118^ | NR | NR | Yes | Yes | NR | Yes | Yes | Yes | NR | Yes | High
Lo et al. 2004^119^ | NR | NR | Yes | NR | No | NR | Yes | Yes | No | No | High

BPAR=Biopsy proven acute rejection; NR=not reported