# Evidence Tables for Key Question 2

Table D-1 Study characteristics

Reference | Country | Type of Study (n) | Immunosuppressive Regimen | Monitoring Procedure | Assay Type | Target CNI Level | Outcomes | Followup
Kyllonen & Salmela 2006^12^ | Finland | RCT (154) | CsA, steroids and MMF | Patients randomized to C0 or C2 monitoring for first 3 weeks post-transplant; C0 monitoring only starting week 4 | FPIA | By day 5 post-transplant C0 250 µg/mL (range 200 to 300) C2 1,700 µg/mL (range 1,500 to 2,000) | C0 and C2 levels, serum creatinine, BPAR, and adverse events | 12 months
Paydas et al. 2005^13^ | Turkey | Retrospective comparative trial (37) | CsA, prednisone and MMF or AZA | C0 and C2 levels evaluated local hospital from month 1 to month 36 post-transplant; C2 blood samples taken 2 hours ±15 mins | Cobas Integra (Roche) | C0 after 1 year: <200 ng/mL C2 after 1 year: 800 ng/mL | C0 and C2 levels, serum creatinine levels, creatinine clearance levels, cholesterol | 36 months
Praditpornsilpa et al. 2005^14^ | Thailand | Historically controlled comparative trial (210) | C0 group: CsA and steroids (100%), AZA (60.2%) or MMF (39.8%) C2 group: CsA and steroids (100%), AZA (79.5%), MMF (20.5%) | NR | NR | CsA C0 at 12 and 24 months: 220±42 and 167±44 ng/mL CsA C2 at 12 and 24 months: 1,000±177 and 814±15 ng/mL | C0 and C2 levels, serum creatinine level and incident of BPAR | 24 months
Birsan et al. 2004^15^ | Austria | Historically controlled comparative trial (177) | CsA, steroids and MMF | 89 patients managed prospectively by C2 monitoring; blood collected daily at 2 hours post morning dose Patients compared retrospectively to 88 patients managed by C0 monitoring | FPIA | CsA C0: 250±50 ng/mL CsA: 1,500±200ng/mL | BPAR, time to first rejection, incidence of delayed graft function, and discontinuation of study protocol | 30 days and 12 months (for some outcomes)
Hardinger et al. 2004^16^ | USA | Prospective, non-randomized comparative trial (100) | CsA, steroids and MMF or AZA | NR | FPIA | CsA C2: 1,000 to 1,200 ng/mL months 0 to 3 and 600 to 1,000 ng/mL thereafter CsA C0: 250 to 350 ng/mL months 0 to 3 and 100 to 250 thereafter | BPAR, renal function, infection, adverse events, and drug costs | 6 months
Jirasiritham et al. 2003^17^ | Thailand | RCT | CsA regimen | Blood CsA levels monitored bi-weekly | NR | CsA C2: 800 ng/mL with 10% variation CsA C0: 100 to 150 ng/mL | BPAR, nephrotoxicity, need for CsA dose adjustment | 3 months

AUC=area under the curve; AZA=azathioprine; BPAR=biopsy proven acute rejection; C0=CsA trough level; C2=2 hour post CsA dosage level; C3=3 hour post CsA dosage level; CNI=calcineurin inhibitor; CsA=cyclosporine; EMIT=enzyme multiplied immunoassay technique; FPIA=fluorescence polarization immunoassay; MMF=mycophenolate mofetil group; NR=not reported; RCT=randomized controlled trial; µg·h/L=micrograms per hour per liter

Table D-2 Study inclusion/exclusion criteria

Reference | Inclusion Criteria | Exclusion Criteria
Kyllonen & Salmela 2006^12^ | Adult renal transplant recipients using CsA | Patients who had lost their previous graft within one year for immunologic reasons
Paydas et al. 2005^13^ | Adult renal transplant recipients using CsA | Not reported
Praditpornsilpa et al. 2005^14^ | Adult renal transplant recipients using CsA | Patients who had vascular or urologic complications post-transplantation.
Birsan et al. 2004^15^ | Adult patients who received their first kidney transplant from a cadaveric donor | Multi-organ transplant, human leukocyte antigen-identical donor, kidney from a non-heart beating donor, panel reactive antibody level higher than 50% at any time or higher than 30% at the time of transplantation and the need for plasmapheresis
Hardinger et al. 2004^16^ | Adult renal recipients receiving triple immunosuppression with CsA | Patients with a known allergy to CsA or documentation of malignancy within 2 years, with the exception of skin malignancies. Pregnant women or nursing mothers, women of childbearing years not practicing a reliable form of birth control and patients with active infection

ALG=antilymphocyte globulin; ATG=antithymocyte globulin; CsA=cyclosporine; OKT3=orthoclone; PRA=panel reactive antibody

Table D-3 Patient characteristics

Reference | Number of Patients | Mean Age | Percent Male | Percent White | Weight | Percent Live Donor Recipients | Time Since Transplant | Prior Transplant
Kyllonen & Salmela 2006^12^ | 160 (C0 80 and C2 74) | C0: 51.4 years C2: 49.7 years | C0: 67.5% C2: 71.2% | NR | C0: 72.0 kg C2: 74.9 kg | 0% | NR | C0: 2 patients re-transplantation C2: 3 patients re-transplantation
Paydas et al. 2005^13^ | 37 (C0 25; C2 12) | C0: 32.3 years C2: 35.0 years | C0: 72% C2: 75% | NR | NR | C0: 84% C2: 83% | 36 months | NR
Praditpornsilpa et al. 2005^14^ | 210 (C0 128; C2 82) | C0: 40.8 years C2: 43.1 years | C0: 54.7% C2: 60.3% | All Asian | NR | C0: 28.9% C2: 29.2% | NR | NR
Birsan et al. 2004^15^ | 177 (C0 88; C2 89) | C0: 48.9 years C2: 51.4 years | C0: 64.8% C2: 68.6% | NR | NR | 100% | NR | NR
Hardinger et al. 2004^16^ | 100 (C0 50; C2 50) | C0: 43 years C2: 51 years | C0: 62% C2: 70% | C0: 86% C2: 84% | C0: 82 kg C2: 86 kg | C0: 48% C2: 40% | NR | C0: 86% first transplant C2: 94% first transplant
Jirasiritham et al. 2003^17^ | 70 (C0 35; C2 35) | NR | NR | NR | NR | NR | NR | NR

Note: The authors of Jirasiritham et al. reported no signiﬁcant between group differences in the demographic proﬁles including: age, sex, donor type, previous episode of acute rejection, CsA nephrotoxicity, duration after kidney transplantation, and basic maintenance immunosuppressants. CsA=cyclosporine; C0=CsA trough level; C2=2 hour post CsA dosage level; kg=kilogram

NR=not reported

Table D-4 Primary clinical outcomes

Reference | Number of Patients | Mean Baseline CNI Level | Followup Mean CNI Level | Percent Above/Below Target Level CNI | Patient and Graft Survival | Mean Serum Creatinine | Graft Dysfunction | Mean Total Cholesterol
Kyllonen & Salmela 2006^12^ | 160 (C0 80; C2 74) | NR | Over 21 days: CsA C0 level: 235 (224 to 245) µg/mL CsA C2 level: 1,645 (1,574 to 1,716) µg/mL Mean CsA dose: C0 4.9 mg/kg C2 7.6 mg/kg | NR | At 12 months: C0: 98.7% patient, 92.5% graft C2: 100.0% patient, 94.6% graft | Mean at 3 months: C0: 107.1 µmol/L C2: 109.2 µmol/L | Total BPAR C0: 6 patients (7.5%) and C2: 8 patients (10.8%); no difference in CsA level between rejectors and non-rejectors; DGF C0: 25 (31%); C2: 23 (31%) | NR
Paydas et al. 2005^13^ | 37 (C0 25; C2 12) | C0: 251.44±143.33 ng/mL C2: 1,382.85±536.29 ng/mL | At 36 months: C0: 128.03±69.49 ng/mL C2: 715.84±226.58 ng/mL p<0.001 | NR | NR | Baseline: C0: 1.17±0.32 mg/Dl C2: 0.97±0.29 At 36 months: C0: 1.46±0.52 C2: 0.99±0.13; p=0.039 CrCl – Baseline: C0: 72.32±23.10 mL/min C2: 78.73±22.42 At 36 months: C0: 55.15±19.21 C2: 84.65±14.97 (p<0.001) | CAN developed in 13 C0 patients and 1 C2 (p=0.013) | At 36 months: C0: 234.94±48.93 C2: 206.57±38.08
Praditpornsilpa et al. 2005^14^ | 210 (C0 128; C2 82) | C0: 332±109 ng/mL C2: 1,447±208 ng/mL | C0:167±44 ng/mL C2: 814±115 ng/mL | NR | NR | At 6 months, patients with C2 level >1,300 ng/mL had higher serum creatinine levels than patients with C2 <1,100 ng/mL (1.96±0.29 vs. 1.37±0.34, p<0.001); no significant differences at months 12 and 24 | BPAR: C0: 7 (6.0%) C2: 9 (10%), no significant difference | NR
Birsan et al. 2004^15^ | 177 (C0 88; C2 89) | Level not reported | Level not reported Mean daily dose 1.7 to 2.0 times higher in C2 group compared to C0 group | At followup (30 days): 10.11% of patients did not reach target CsA (1,500 ng/mL) | 100% for patient and graft in both groups | No significant difference in serum creatinine at 30 days post-transplant; at one year no significant difference in mean creatinine clearance | C0: 45.4% (n=40) pts. Received treatment for rejection; C2: 28.1% (n=25) received treatment (p=0.017) Banff grade I or higher: C0: 20.45%; C2:13.48% (p=0.318) | NR
Hardinger et al. 2004^16^ | 100 (C0 50; C2 50) | At 1 month: C0: 289±126 mg/dL C2: 1,141±316 mg/dL Significant difference (p<0.05) | At 3 months: C0: 177±60 mg/dL C2: 805±mg/dL At 6 months: C0: 160±60 mg/dL C2: 575±202 mg/dL Dose at 6 months: C0: 273± mg/dL C2: 199±73 mg/dL Significant difference (p<0.001) | NR | 100% patient and graft for both groups | At 6 months: C0: 1.5±0.5 mg/dL C2: 1.5±0.6 mg/mL | C0: 3 patients experienced rejections (6.0%) C2: 2 patients experienced rejection (4.0%) | At baseline: C0: 160±46 C2: 170±44 At 6 months: C0: 177±35 C2: 191±48
Jirasiritham et al. 2003^17^ | 70 (C0 35; C2 35) | Conversion to C2: CsA C0: 128 ng/mL C0 only: CsA C0: 156 ng/mL | C2 after conversion: 856 ng/mL C0: 137 ng/mL | C2 group: 12 (34.3%) patients needed reductions in CsA dosage and 2 (5.7%) needed increases to obtain the C2 target level; vs. C0 group: 17 (49%) needed increases in dose and 5 (15%) decreases in dose; p=0.02 | 100% both groups | NR | Group 1 (C2) 0 BPAR; Group 2 C0 only) 1 BPAR 0 Nephrotoxicity in both groups | NR

BPAR=biopsy proven acute rejection; C0=CsA trough level; C2=2 hour post CsA dosage level; C3=3 hour post CsA dosage level; Cr/Cl=creatinine clearance; CsA=cyclosporine; DGF=delayed graft function; mg/Dl=milligrams per deciliter; mL/min=milliliter per minute; ng/mL=nanogram per milliliter; NR=not reported; µg/L=micrograms per liter; μg/mL=micrograms per milliliter; µmol/L=micromoles per liter

Table D-5 Adverse events and withdrawal

Reference | Adverse Events | Withdrawal or Discontinuation of CNI
Kyllonen & Salmela 2006^12^ | No difference between C0 and C2 for infections, vomiting, heartburn, upper and lower gastrointestinal symptoms, headache, diarrhea, vertigo, fatigue, insomnia, neurological symptoms, cardiac symptoms, or NODM Significantly more patients in C2 group (9) compared to C0 (2) experienced tremor (p<0.05) | 5 patients withdrew due to discomfort with repeated blood samples
Birsan et al. 2004^15^ | NR | 16.8% (25 patients) in C2 group and 11.4% (10 patients) in C0 group switched to tacrolimus due to acute rejection (n=17), CsA toxicity (n=8), slow/low absorbers (n=5) or other (n=5)
Hardinger et al. 2004^16^ | No serious fungal or viral infections (including CMV) during study period; NODM occurred in 1 patient in each group, and 20% of patients in C2 group and 27% in C0 group required treatment of new onset hypercholesterolemia | 14% (7 patients) in C2 group switched to TAC (3 hirsutism, 2 hemolytic uremic syndrome, and 2 acute rejection); 10% (5 patients) switched to TAC in C0 group (2 for hirsutism and 3 for acute rejection)

C0=CsA trough level; C2=2 hour post CsA dosage level; C3=3 hour post CsA dosage level; CMV=cytomegalovirus; CNI=calcineurin inhibitor; CsA=cyclosporine; NODM: new onset diabetes mellitus; NR=not reported; TAC=tacrolimus

Table D-6 Risk of bias assessment for RCTs addressing Key Question 2

Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar in terms of demographic and clinical factors (e.g., kidney function) at baseline? | Did the study enroll all suitable patients or consecutive suitable patients? | Was compliance with treatment ≥85% in both study groups? | Were outcome assessors blinded to the group to which the patients were assigned? | Was the outcome measure of interest objective and was it objectively measured? | Was a standard instrument used to measure the outcome? | Was there a ≤15% difference in completion rates in the study groups? | Overall Risk of Bias
Kyllonen & Salmela 2006^12^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Low
Jirasiritham et al. 2003^17^ | NR | NR | Yes | NR | Yes | NR | Yes | Yes | NR | Low

NR=not reported

Table D-7 Risk of bias assessment for non-randomized comparative trials addressing Key Question 2

Author, Year | Did the study employ any other methods to enhance group comparability? | Was the process of assigning patients to groups made independently from physician and patient preference? | Were groups similar in terms of demographic and clinical factors (e.g., kidney function) at baseline? | Did the study enroll all suitable patients or consecutive suitable patients? | Was the comparison of interest prospectively planned? | Was compliance with treatment ≥85% in both study groups? | Were outcome assessors blinded to the group to which the patients were assigned? | Was the outcome measure of interest objective and was it objectively measured? | Was a standard instrument used to measure the outcome? | Was there a ≤15% difference in completion rates in the study groups? | Overall Risk of Bias
Paydas et al. 2005^13^ | No | No | Yes | NR | No | Yes | No | Yes | Yes | Yes | Low
Praditpornsilpa et al. 2005^14^ | No | No | Yes | NR | No | Yes | No | Yes | Yes | Yes | Low
Birsan et al. 2004^15^ | No | No | Yes | NR | Yes | Yes | No | Yes | Yes | No | Low
Hardinger et al. 2004^16^ | No | No | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Low

NR=not reported