# Evidence Tables for Key Questions 1a and 1b

Table C-1 Study characteristics

Reference | Country | Type of Study Study Design (n) | CNI Regimen | Intervention Monitoring Method | Comparative/Reference Monitoring Method | Outcomes | Followup
Leung et al. 2014^1^ | USA | Analytical accuracy of tests measuring TAC, prospective comparative study (145) | TAC regimen | QMS TAC immunoassay (QMS) | LC-MS/MC (in house) | Analytical performance | Not reported
Shipkova et al. 2014^2^ | Germany | Analytical accuracy of tests measuring TAC, prospective comparative study (60) | TAC regimen | Elecsys TAC assay (ELCIA) | LC-MS/MC | Analytical performance | Not reported
Westley et al. 2007^3^ | Australia | Analytical accuracy of tests measuring TAC, retrospective comparative study (67) | TAC regimen | CEDIA and MEIA | HPLC-MS | TAC concentrations and analytical performance | Not reported
Borrows et al. 2006^4^ | United Kingdom | Clinical utility of test measuring TAC, RCT (80) | TAC (10-15 ng/ml)+ MMF (750 mg/twice daily) and induction anti-CD25 monoclonal | HPLC-MS | MEIA | Patient and graft survival, graft function, BPAR, bacterial infection, incidence of CMV, NODM, other adverse events; inter-assay variability | 6 months
Chan et al. 2005^5^ | China | Analytical accuracy of tests measuring TAC, prospective comparative study (30) | TAC+ prednisolone and AZA | HPLC-MS | MEIA | TAC concentration, analytical performance, clinical management | Not reported
Butch et al. 2004^6^ | United States | Analytical accuracy of tests measuring CsA, prospective comparative study (165) | CsA regimen | CEDIA | HPLC-MS | Analytical performance | Not reported
Staatz et al. 2002^7^ | Australia | Analytical accuracy of tests measuring TAC, retrospective comparative study (76) | TAC+ MMF or AZA and steroids | LC/MS/MS | ELISA | TAC concentrations and analytical performance | Data collected from patients who received either a liver or kidney transplant from 1994 to 2000
Hamwi et al. 1999^8^ | Austria | Analytical accuracy of tests measuring CsA, prospective comparative study (49) | CsA regimen | FPIA/AxSYM, CEDIA, and modified EMIT | HPLC-MS | Analytical performance | Not reported
Schutz et al. 1998^9^ | Germany | Analytical accuracy of tests measuring CsA, prospective comparative study (99) | CsA regimen | FPIA/AxSYM, CEDIA, and modified EMIT | HPLC-MS | Analytical performance | Not reported
Salm et al. 1997^10^ | Australia | Analytical accuracy of tests measuring TAC, prospective comparative study (67) | TAC regimen | ELISA and MEIA | HPLC-MS2 Developed by the authors of the study; HPLC-MS tandem mass spectrometry | TAC concentrations and analytical performance | 4 months
Roberts et al. 1995^11^ | United Kingdom | Analytical accuracy of tests measuring CsA, prospective comparative study (70) | CsA regimen | FPIA/TDx mono and polyclonal immunoassay | HPLC-MS | Analytical performance | Not reported

BPAR=biopsy proven acute rejection; CEDIA=cloned enzyme donor immunoassay; CMV=cytomegalovirus; CsA=cyclosporine; ELCIA=electrochemiluminescence immunoassay; ELISA=enzyme-linked immunosorbent assay; EMIT= enzyme multiplied immunoassay; FPIA=fluorescence polarization immunoassay; HPLC-MS=high performance liquid chromatography; LC/MS/MS=liquid chromatography-tandem mass spectrometry; MEIA=microparticle enzyme immunoassay; MMF=mycophenolate mofetil; NODM=new onset diabetes mellitus; RCT=randomized controlled trial; RIA=radio-immunoassay; TAC=tacrolimus

Table C-2 Patient characteristics

Reference | Number of Patients | Mean Age | Percent Male | Number Live Donor Recipients | Percent Ethnicity
Shipkova et al. 2014^2^ | 60 patients who underwent kidney transplant (other patient in the study underwent heart and liver transplants) | Not reported | Not reported | Not reported | Not reported
Leung et al. 2014^1^ | 145 whole blood samples | Not reported | Not reported | Not reported | Not reported
Westley et al. 2007^3^ | 88 patients who underwent kidney transplant (other patients in study underwent liver transplant) | Range: 9 to 69 years | 66% | Not reported | Not reported
Borrows et al. 2006^4^ | MEIA: 40 HPLC: 40 All patients underwent kidney transplant | MEIA: 46 years HPLC: 44 years | MEIA: 65% HPLC-MS: 45% | MEIA: 18 HPLC-MS: 19 | MEAI: 45% Caucasian, 25% Indo-Asian, 20% Afro-Caribbean, 5.0% Mid-Eastern, 5.0% Asian HPLC-MS: 60% Caucasian, 22% Indo-Asian, 17% Afro-Caribbean, 0% Mid-Eastern and Asian
Chan et al. 2005^5^ | 30 patients; all patients underwent kidney transplant | 42.6 years | 53% | Not reported | Not reported
Butch et al. 2004^6^ | 165 specimens from patients who underwent kidney transplant (other patients in the study underwent bone marrow, heart and liver transplants) | Not reported | Not reported | Not reported | Not reported
Staatz et al. 2002^7^ | 76 patients who underwent kidney transplant (other patients in study underwent liver transplant) | Patients aged 15 years or older | Not reported | Not reported | Not reported
Hamwi et al. 1999^8^ | 49 specimens from patients who underwent kidney transplant (other patients in the study underwent bone marrow, heart and liver transplants) | Not reported | Not reported | Not reported | Not reported
Schutz et al. 1998^9^ | 99 specimens from patients who underwent kidney transplant (other patients in the study underwent bone marrow, heart and liver transplants) | Not reported | Not reported | Not reported | Not reported
Salm et al. 1997^10^ | 37 patients who underwent kidney transplant (other patients in study underwent liver transplant) | No reported | Not reported | Not reported | Not reported
Roberts et al. 1995^11^ | 86 whole blood samples from 70 patients | Not reported | Not reported | Not reported | Not reported

HPLC-MS=high-performance liquid chromatography; MEIA=microparticle enzyme immunoassay

Table C-3 Primary findings of study measuring clinical utility

Reference | Number of Patients | Followup | TAC Level (ng/ml) | Patient Survival | Graft Survival | BPAR | DGF | TAC Nephrotoxicity | Serum Creatinine (µmol/l)
Borrows et al. 2006^4^ | MEIA: 40 HPLC-MS: 40 | 6 months | MEIA: 11.1±2.7 HPLC: 9.2±2.3 (p=0.02) | MEIA: 100% HPLC-MS: 100% | MEIA: 100% HPLC-MS: 97.5% | MEIA: 4 patients (10%) HPLC-MS: 1 patient (2.5%) No significant difference (p=0.17) | MEIA: 14 patients (35%) HPLC-MS: 12 patients (30%) No significant difference | MEIA: 6 patients (15%) HPLC-MS: 7 patients (17.5%) | MEIA: 142±39 HPLC-MS: 141±45 No significant difference

BPAR=biopsy proven acute rejection; DGF=delayed graft function; HPLC-MS=high performance liquid chromatography-mass spectrometry; MEIA=microparticle enzyme immunoassay; TAC=tacrolimus

Table C-4 Analytical validity outcomes

Reference | Number of Patients (Blood Samples) | Method Comparison | Sampling Procedure | CNI Concentration | Correlation Between Methods | Limits of Agreement | Difference in AUC_12_ Values | Mean Bias | Precision
Leung et al. 2014^1^ | 145 whole blood samples | QMS TAC immunoassay (QMS) vs. LC-MS/MS (in house) | Whole blood samples collected from patients undergoing routine TAC monitoring; samples stored at below -20 C until tested. | Not reported | r^2^=0.99 Slope 1.13 (range 4.0 to 84.6 ng/mL) | NR | NR | 31% (overall per Bland/Altman analysis = 2.4 ng/mL) | Coefficient of variance for intra-assay and inter-assay precision studies ranged from 3.9% to 8.1% and 4.7% to 10.0%.
Shipkova et al. 2014^2^ | 60 whole blood | Elecsys TAC assay (ELCIA) vs. LC-MS/MC | Blood samples collected from 5 different sites; samples stored at room temperature if tested within 8 hours of collection or at below -15 C if tested at a later time; all samples were measured within 6 months of collection. | Slope 1.0±0.10, intercept <1/10 of the low end of the therapeutic concentration range of 3.0 µg/L for kidney | r^2^=0.97 Slope: 1.13 (95% CI: 1.09 to 1.16 According to the authors, this value fell out of the acceptance value of 1.0±0.1 | NR | NR | 5.9% (95% CI: -27.8% to -39.5%) | For ELCIA only: Linearity: 0.5 to 40 µg/L; functional sensitivity: 0.3 µg/L (CV≤20%) Intermediate imprecision for TAC concentration ≥6.8 µg/L was ≤6.5% Lower imprecision for TAC to 1.5 µg/L was consistently ≤10%
Westley et al. 2007^3^ | 88 (88) Samples underwent approximately three freeze/thaw cycles during the study period between the two study centers. | CEDIA and MEIA vs. HPLC-MS | NR | See precision data | CEDIA vs. HPLC-MS: r^2^=0.77 CEDIA vs. MEIA: r^2^=0.72 MEIA vs. HPLC-MS: r^2^=0.90 | NR | NR | CEDIA vs. HPLC-MS: 33.3% (±3.9) CEDIA vs. MEIA: 13.9% (±4.4%) MEIA vs. HPLC-MS: 20.1 (±2.5%) | CEDIA vs. HPLC-MS: RMSE=5.7 µg/L CEDIA vs. MEIA: RMSE=3.7 µg/L MEIA vs. HPLC-MS: RMSE=2.8 µg/L
Borrows et al. 2006^4^ | 40 (total samples not reported) | HPLC-MS vs. MEIA | TAC levels measured daily from first day post-transplant to discharge from hospital and at each clinic visit | Median/Range TAC at 6 months: MIEA: 12.8 (6.7 to 22.0) ng/ml HPLC-MS: 9.9 (5.5 to 18.9) ng/ml | NR | NR | NR | NR | Inter-assay variability at 5, 11, and 22 ng/ml TAC: MEIA 13.7%, 8.3%, 10.9% HPLC 8.0%, 6.5%, 5.7%
Chan et al. 2005^5^ | 30 (134) | HPLC-MS vs. MEIA | 50 pairs of 2-hour post-dose (C2) and 4-hour post-dose (C4) were used; with an estimation of the 12-hour AUC done using a two-point sampling method; TAC concentrations measured at a median 13.5 months post-transplant | HPLC-MS: median TAC 9.75 (7.08) µg/L MEIA: 10.30 (8.08) µg/L Median difference -0.40 (2.03) µg/L; p<0.001; % difference 5.04%; concentrations significantly, but not clinically, lower for HPLC-MS | r^2^= 0.94; p<0.001; indicates good correlation between methods | 95% LoA 2.98 to -4.10 µg/L; 90% of patients had an absolute difference of less than 3.1 µg/L | Mean difference: 3.4±11.6 hr. µg/L; p=0.059; % difference 2.6±11.4%; p=0.107 | NR | NR
Butch et al. 2004^6^ | 165 specimens from patients who underwent kidney transplant (other patients in the study underwent bone marrow, heart and liver transplants) | CEDIA Plus vs HPLC | Whole blood samples collected over an eight-week period and assayed within an 8-h period of specimen receipt. | Ranged from 28-1,289 µg/L | HPLC vs CEDIA plus immunosassay r2=0.98; HPLC was lower than CEDIA plus with a mean difference of -17.5%; slope 0.90 (95% CI 0.87 to 0.93) | CEDIA plus has low range calibrators 25-450 µg/L and high range calibrators 450-2000 µg/L | NR | 17.5% lower by HPLC compared with CEDIA | Within-run imprecision (coefficient of variation) ranged from 1.7% to 3.3%; between day imprecision ranged from 2.7% to 7.8%.
Staatz et al. 2002^7^ | 29 (98) | LC/MS/MS vs. ELISA | 12-hour trough monitoring; immediate post-transplant and subsequent at each clinical visit. Samples for concentration monitoring ranged from 2 to 402 days post-transplant; samples per subject ranged from 1 to 6 (median 4) | ELISA TAC ranged from 1.9 to 43.4 ng/mL LC/MS/MS ranged from 1.7 to 44 ng/mL | r^2^=0.95; SE.EST: 1.37 | NR | NR | ELISA vs. LC/MS/MS 0.47 (±1.37) At TAC 0 to 6 ng/ml, Mean Bias: 4.7 (±19.6) | Relative difference between 2 assays at 5, 10, and 20 ng/ml TAC: Reported as 95% CIs: -50% to 60%, -24% to 31%, and -11% to 17%
Hamwi et al. 1999^8^ | 49 samples | HPLC-MS vs. FPIA/AxSYM, CEDIA, and modified EMIT | Whole blood samples in which CsA levels were monitored no more than 5 days after collection of these specimens. Samples were stored 4 C. | NR | HPLC vs CEDIA: r^2^=0.97; slope 1.31 (95% CI 1.29 to 1.47); HPLC vs EMIT: r^2^=0.97; slope 1.17 (95 CI 1.02 to 1.28); HPLC vs FPIA/AxSYM r^2^=0.98; slope 1.03 (95% CI 0.97 to 1.12); HPLC vs FPIA/TDx r^2^= 0.97 slope 1.29 (95% CI 1.19 to 1.42). | NR | NR | Immunoassay was higher than HPLC: 14.1 % higher with CEDIA, 18.8% with EMIT, 10% with FPIA/AxSYM, 50% with FPIA/TDx | The within assay CV at the lowest CsA concentration ranged from 3.07% for the FPIA/TDx to 10.6% for the CEDIA. At the highest concentration, the CV ranged from 1.73% for FPIA/TDx to 6.45% for FPIA/AxSYM. The between assay CV ranged from 4.25% (FPIA/TDx) to 8.90% (EMIT) at the lowest CSA and from 3.12% (FPIA/TDx) to 6.77% (FPIA/AxSYM) at the highest CSA
Schutz et al. 1998^9^ | 99 specimens from patients who underwent kidney transplant | HPLC-MS vs. FPIA/AxSYM, CEDIA, and modified EMIT | To evaluate accuracy, drug free whole blood samples with CsA added as well as using the metabolites in methanol solutions. | 50, 100, and 400 µg/L. | FPIA slope= 1.17 (1.04 to 1.32), mean difference of measurement to HPLC 32%; CEDIA slope=1.19 (1.00 to 1.39), 22.5%; EMIT 1.07 (0.97 to 1.19), 23.9% | Detection limits: 13µg/L for the FPIA, 25 µg/L, for CEDIA, and 17.0 µg/L for EMIT | NR | Immunoassay was higher than HPLC: 32% higher with FPIA/AxSYM, 22.5% higher with CEDIA, 23.9% higher with EMIT. | The within assay coefficient of variation are provided for low and high range controls: HPLC 6.8% , 7.6%; FPIA/AxSym 5.8%, 1.7%; CEDIA 11%, 5.5%; EMIT 6.5%, 4.8%
Salm et al. 1997^10^ | 37 (129) | ELISA and MEIA vs. HPLC-MS2 Developed by the authors of the study; HPLC-MS tandem mass spectrometry | 12-hour trough monitoring; first sample within 1 week of transplant; additional samples collect each month for 4 months | HPLC-MS2 TAC ranged from 1.7 to 26.1 µg/l; ELISA ranged from 1.9 to 24.4 µg/l; MEIA 0.9 to 28.5 µg/l | ELISA vs. HPLC-MS: SE. EST 1.26; MEIA vs. HPLC-MS: SE.EST 2.13 | NR | NR | ELISA vs. HPLC-MS: 0.171 (±1.27) MEIA vs. HPLC-MS: 1.78 (±2.24) | Relative difference between assays at 5, 10, 20 µg/l TAC: Reported as 95% CIs: ELISA vs. HPLC-MS 2.9 to 7.9, 7.7 to 12.7, and 17.2 to 22.2 MEIA vs. HPLC-MS 1.7 to 10.2, 7.5 to 16.0, 19.2 to 27.6
Roberts et al. 1995^11^ | 70 patients (86 whole blood samples) | HPLC-MS vs. FPIA/TDx mono and polyclonal immunoassay | Whole blood samples collected 12 hours after oral dose of CsA were obtained from patients on twice daily CsA (4 to 10 mg/kg) | HPLC-MS and FPIA/TDx monoclonal CsA concentration ranged from 25 to 1,200 µg/L; polyclonal concentrations ranged from <50 to 3,800 µg/L | HPLC vs FPIA/TDx monoclonal immunoassay r2=0.91; HPLC values were always lower than the FPIA/TDx monoclonal with a mean difference of -109 µg/L (standard deviations [SD] 99); HPLC vs. FPIA/TDx polyclonal r2=0.98. | NR | NR | HPLC values was always lower than the FPIA/TDx monoclonal with a mean difference of -109 µg/L (standard deviations [SD] 99) | The within assay coefficient of variance varied from 4.0% to 7.0% and the between assay variance varied from 5.0% to 7.0%.

AUC=area under the curve; CEDIA=cloned enzyme donor immunoassay; CI=confidence interval; CMIA=chemiluminescent microparticle immunoassay; CsA=cyclosporine; CV=coefficients of variance; ELCIA=electrochemiluminescence immunoassay; ELISA=enzyme-linked immunosorbent assay; EMIT= enzyme multiplied immunoassay; FPIA=fluorescence polarization immunoassay; HPLC=high performance liquid chromatography; LC-MS/MS=liquid chromatography-mass spectrometry; LC/MS/MS=liquid chromatography-tandem mass spectrometry; LoA=limits of agreement; HPLC-MS=high performance liquid chromatography-mass spectrometry; MEIA=microparticle enzyme immunoassay; ng/mL=nanogram/milliliter; NR=not reported; RMSE=root mean squared error; SE. EST=standard error of the estimate; TAC=tacrolimus; µg/l=micrograms per liter

Table C-5 Adverse events

Reference | Number of Patients | Bacterial Infection | Cytomegalovirus | Biopsy Proven Nephrotoxicity | New Onset Diabetes | Tremor
Borrows et al. 2006^4^ | MEIA: 40 HPLC-MS: 40 | MEAI: 11 patients (32.5%) HPLC-MS: 11 patients (32.5%) | MEIA: 2 patients (5.0%) HPLC-MS: 0 patients | MEAI: 6 (15%) HPLC-MS: 7 (17.5%) | MEIA; 1 patient (2.5%) HPLC-MS: 0 patients | MEIA: 2 patients (5.0%) HPLC-MS: 2 patients (5.0%)

HPLC=high performance liquid chromatography mass spectrometry; MEIA=microparticle enzyme immunoassay

Table C-6 Risk of bias assessment of clinical outcomes

Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar in terms of demographic and clinical factors (e.g. kidney function) at baseline? | Did the study enroll all suitable patients or consecutive suitable patients? | Was compliance with treatment ≥85% in both of the study's groups? | Were outcome assessors blinded to the group to which the patients were assigned? | Was the outcome measure of interest objective and was it objectively measured? | Was a standard instrument used to measure the outcome? | Was there a ≤15% difference in completion rates in the study's groups? | Overall Risk of Bias
Borrows et al. 2006^4^ | NR | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | Low

NR=not reported

Table C-7 Risk of bias assessment of analytical validity studies

Author, Year | Were the tests under evaluation described in sufficient detail to permit replication of the tests? | Were the testing results interpreted by blinded interpreters? | Was the limit of detection of the test reported? | Was the assay linearity range reported? | Has the issue of cross-reactivity been thoroughly evaluated? | Was the reproducibility of the test when performed multiple times on a single specimen established? | Was the reproducibility of the test adequately established (across operators/ instruments/ reagent lots/ different days of the week/ different laboratories)? | Were the study data from a multisite collaborative, proficiency testing, or interlaboratory exchange programs?
Leung et al. 2014^1^ | Yes | NR | Yes | Yes | NR | Yes | Yes | No
Shipkova et al. 2014^2^ | Yes | NR | No | Yes | NR | Yes | Yes | Yes
Westley et al. 2007^3^ | Yes | NR | Yes | Yes | NR | Yes | NR | No
Chan et al. 2005^5^ | Yes | NR | Yes | No | NR | NR | NR | No
Butch et al. 2004^6^ | Yes | NR | No | Yes | Yes | Yes | No | No
Staatz et al. 2002^7^ | No | NR | No | No | NR | NR | NR | No
Hamwi et al. 1999^8^ | Yes | NR | No | Yes | Yes | Yes | No | No
Schutz et al. 1998^9^ | Yes | NR | Yes | NR | Yes | Yes | Yes | No
Salm et al. 1997^10^ | Yes | NR | No | No | NR | NR | NR | No
Roberts et al. 1995^11^ | Yes | NR | No | No | Yes | NR | NR | No