# Excluded Studies

## Does not meet study design criteria (e.g., not a randomized controlled trial, previous systematic review, narrative review, or commentary)

An open label, prospective, randomized, controlled, multi-center study assessing fixed dose vs concentration controlled CellCept regimens for patients following a single organ renal transplantation in combination with full dose and reduced dose calcineurin inhibitors. Dev Behav Pediatr Online. 2004. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/645/CN-00487645/frame.html.
Abou Ayache R, Thierry A, Bridoux F, et al. Long-term maintenance of calcineurin inhibitor monotherapy reduces the risk for squamous cell carcinomas after kidney transplantation compared with bi- or tritherapy. Transplant Proc. Oct. 2007;39(8):2592-4. [pmid: 17954185].
Alberu J, Pascoe MD, Campistol JM, et al. Lower malignancy rates in renal allograft recipients converted to sirolimus-based, calcineurin inhibitor-free immunotherapy: 24-month results from the CONVERT trial. Transplantation. Aug. 15. 2011;92(3):303-10. [pmid: 21792049].
Almeida CC, Silveira MR, de Araujo VE, et al. Safety of immunosuppressive drugs used as maintenance therapy in kidney transplantation: a systematic review and meta-analysis. Pharmaceuticals. 2013;6(10):1170-94. [pmid: 24275847].
Anjuma S, Andany MA, McCleana JC, et al. Defining the risk of elective cyclosporine withdrawal in stable kidney transplant recipients. Am J Transplant. Feb. 2002;2(2):179-85. [pmid: 12099521].
Baczkowska T, Serafinowicz A, Kukula K, et al. Cyclosporine blood concentration at 2 hours (C(2)) from drug ingestion as the best single indicator of adequate cyclosporine immunosuppression in renal allograft recipients--a four-year follow-up. Transplant Proc. 2002;34(2):556-7. [pmid: 12009622].
Badowski M, Gurk-Turner C, Cangro C, et al. The impact of reduced immunosuppression on graft outcomes in elderly renal transplant recipients. Clin Transplant. 2009;23(6):930-7. [pmid: 19594773].
Bassil N, Rostaing L, Mengelle C, et al. Prospective monitoring of cytomegalovirus, epstein-barr virus, BK virus, and JC virus infections on belatacept therapy after a kidney transplant. Exp Clin Transplant. Jun. 2014;12(3):212-9. [pmid: 24907721].
Budde K, Becker T, Arns W, et al. Everolimus-based, calcineurin-inhibitor-free regimen in recipients of de-novo kidney transplants: an open-label, randomised, controlled trial. Lancet. 2011;377(9768):837-47. [pmid: 21334736].
Campbell SB, Walker R, Tai SS, et al. Randomized controlled trial of sirolimus for renal transplant recipients at high risk for nonmelanoma skin cancer. Am J Transplant. May. 2012;12(5):1146-56. [pmid: 22420843].
Campistol JM, Holt DW, Epstein S, et al. Bone metabolism in renal transplant patients treated with cyclosporine or sirolimus. Transpl Int. Sep. 2005;18(9):1028-35. [pmid: 16101723].
Cannon RD, Wong SHY, Hariharan S, et al. Clinical Efficacy of the Abbott Tacrolimus II Assay for the IMx(registered trademark). Ann Clin Lab Sci. 1999;29(4):299-302. [pmid: 10528829].
Cardinal H, Froidure A, Dandavino R, et al. Conversion from calcineurin inhibitors to sirolimus in kidney transplant recipients: a retrospective cohort study. Transplant Proc. Oct. 2009;41(8):3308-10. [pmid: 19857737].
Carstens J. Three-years experience with Neoral C(2) monitoring adjusted to a target range of 500-600 ng/ml in long-term renal transplant recipients receiving dual immunosuppressive therapy. Scand J Urol Nephrol. 2008;42(3):286-92. [pmid: 18432535].
Chhabra D, Grafals M, Cabral B, et al. Late conversion of tacrolimus to sirolimus in a prednisone-free immunosuppression regimen in renal transplant patients. Clin Transplant. Mar-Apr. 2010;24(2):199-206. [pmid: 19659511].
Citterio F, Scata MC, Romagnoli J, et al. Results of a three-year prospective study of C(2) monitoring in long-term renal transplant recipients receiving cyclosporine microemulsion. Transplantation. Apr. 15. 2005;79(7):802-6. [pmid: 15818322].
Claes K, MeierKriesche HU, Schold JD, et al. Effect of different immunosuppressive regimens on the evolution of distinct metabolic parameters: evidence from the Symphony study. Nephrol Dial Transplant. Feb. 2012;27(2):850-7. [pmid: 21617197].
Cole EH, Prasad GV, Cardella CJ, et al. A pilot study of reduced dose cyclosporine and corticosteroids to reduce new onset diabetes mellitus and acute rejection in kidney transplant recipients. Transplant Res. Jan. 12. 2013;2(1):1. [pmid: 23369458].
Croze LE, Tetaz R, Roustit M, et al. Conversion to mammalian target of rapamycin inhibitors increases risk of de novo donor-specific antibodies. Transpl Int. 2014. Mar. 31. [pmid: 24684741].
Dean PG, Grande JP, Sethi S, et al. Kidney transplant histology after one year of continuous therapy with sirolimus compared with tacrolimus. Transplantation. Apr. 2008;85(8):1212-5. [pmid: 18431244].
Di Paolo S, Teutonico A, Schena A, et al. Conversion to C2 monitoring of cyclosporine A exposure in maintenance kidney transplant recipients: results at 3 years. Am J Kidney Dis. Nov. 2004;44(5):886-92. [pmid: 15492955].
Dominguez J, Mahalati K, Kiberd B, et al. Conversion to rapamycin immunosuppression in renal transplant recipients: report of an initial experience. Transplantation. Oct. 27. 2000;70(8):1244-7. [pmid: 11063349].
Dubey D, Kumar A, Srivastava A, et al. Cyclosporin A withdrawal in live related renal transplantation: long-term results. Clin Transplant. 2001;15(2):136-41. [pmid: 11264641].
Ducloux D, Motte G, Billerey C, et al. Cyclosporin withdrawal with concomitant conversion from azathioprine to mycophenolate mofetil in renal transplant recipients with chronic allograft nephropathy: a 2-year follow-up. Transpl Int. 2002;15(8):387-92. [pmid: 12221456].
Einecke G, Mai I, Diekmann F, et al. Optimizing Neoral therapeutic drug monitoring with cyclosporine trough (C(0)) and C(2) concentrations in stable renal allograft recipients. Transplant Proc. 2001;33(7):3102-3. [pmid: 11750333].
Einecke G, Mai I, Fritsche L, et al. The value of C(2) monitoring in stable renal allograft recipients on maintenance immunosuppression. Nephrol Dial Transplant. Jan. 2004;19(1):215-22. [pmid: 14671060].
Ekberg H, Bernasconi C, Noldeke J, et al. Cyclosporine, tacrolimus and sirolimus retain their distinct toxicity profiles despite low doses in the Symphony study. Nephrol Dial Transplant. Jun. 2010;25(6):2004-10. http://dx.doi.org/10.1093/ndt/gfp778. [pmid: 20106825].
Ekberg H, Bernasconi C, Tedesco-Silva H, et al. Calcineurin inhibitor minimization in the Symphony study: observational results 3 years after transplantation. Am J Transplant. Aug. 2009;9(8):1876-85. [pmid: 19563339].
El-Agroudy AE, El-Dahshan KF, Mahmoud K, et al. Long-term graft outcome in patients with chronic allograft nephropathy after immunosuppression modifications. Clin Exp Nephrol. Feb. 2009;13(1):66-72. [pmid: 18716711].
Forsythe J. A phase II open label single centre randomized study of tacrolimus plus sirolimus and corticosteroids compared with tacrolimus plus azathioprine and corticosteroids in de novo renal allografts recipients. Natl Res Regist. 2002. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/909/CN-00449909/frame.html.
Frei U, Daloze P, Vitko S, et al. Acute rejection in low-toxicity regimens: clinical impact and risk factors in the Symphony study. Clin Transplant. Jul-Aug. 2010;24(4):500-9. [pmid: 19758267].
Garcia R, Pinheiro-Machado PG, Felipe CR, et al. Conversion from azathioprine to mycophenolate mofetil followed by calcineurin inhibitor minimization or elimination in patients with chronic allograft dysfunction. Transplant Proc. Nov. 2006;38(9):2872-8. [pmid: 17112853].
Garcia-Gallont R, Toledo Solares M. Impact of C(2) measurement on cyclosporine Neoral dosing in a Latin-American transplant program: the Guatemalan experience. Transplant Proc. Mar. 2004;36(2). [pmid: 15041385].
Geddes CC, Gunson R, Mazonakis E, et al. BK viremia surveillance after kidney transplant: single-center experience during a change from cyclosporine-to lower-dose tacrolimus-based primary immunosuppression regimen. Transpl Infect Dis. Apr. 2011;13(2):109-16. [pmid: 21457419].
Geddes CC, Jardine AG, Kingsmore D, et al. Five-year outcomes after a change from a cyclosporin-based to a ‘low-dose’ tacrolimus-based primary immunosuppression regimen for incident kidney transplants--the Glasgow experience. Clin Transpl. 2012:95-102. [pmid: 23721012].
Goring SM, Levy AR, Ghement I, et al. A network meta-analysis of the efficacy of belatacept, cyclosporine and tacrolimus for immunosuppression therapy in adult renal transplant recipients. Curr Med Res Opin. Aug. 2014;30(8):1473-87. Epub 2014 Apr 3. [pmid: 24628478].
Grinyo J, Charpentier B, Pestana JM, et al. An integrated safety profile analysis of belatacept in kidney transplant recipients. Transplantation. 2010;90(12):1521-7. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/201/CN-00782201/frame.html. [pmid: 21088650].
Grinyo JM, Saval N, Campistol JM. Clinical assessment and determinants of chronic allograft nephropathy in maintenance renal transplant patients. Nephrol Dial Transplant. Nov. 2011;26(11):3750-5. [pmid: 21474575].
Hakeam HA, Al-Jedai AH, Raza SM, et al. Sirolimus induced dyslipidemia in tacrolimus based vs. tacrolimus free immunosuppressive regimens in renal transplant recipients. Ann Transplant. 2008;13(2):46-53. [pmid: 18566560].
Hamdy AF, Bakr MA, Ghoneim MA. Proteinuria among primarily sirolimus treated live-donor renal transplant recipients' long-term experience. Exp Clin Transplant. Dec. 2010;8(4):283-91. [pmid: 21143093].
Hami M, Naghibi M, Mojahedi MJ, et al. Graft function based on two hours peak level monitoring of cyclosporine A during the first six months of renal transplantation. Saudi J Kidney Dis Transpl. Nov. 2012;23(6):1169-74. [pmid: 23168844].
Hernandez D, Ruiz-Esteban P, Gaitan D, et al. Regression of cardiac growth in kidney transplant recipients using anti-m-TOR drugs plus RAS blockers: a controlled longitudinal study. BMC Nephrol. 2014;15:65. [pmid: 24755192].
Higgins RM, Kanji H, Hernon M, et al. Cyclosporine dose reduction in stable renal transplant patients with high C2 level: simplified method of single C2 measurement and individualization of CO target. Transpl Int. Jul. 2005;18(7):806-10. [pmid: 15948859].
Hong JC, Kahan BD. A calcineurin antagonist-free induction strategy for immunosuppression in cadaveric kidney transplant recipients at risk for delayed graft function. Transplantation. May. 15. 2001;71(9):1320-8. [pmid: 11397971].
Hosseini MS, Rostami Z, Einollahi B. Dyslipidemia after kidney transplantation and correlation with cyclosporine level. Nephrourol Mon. Jul. 2013;5(3):831-4. [pmid: 24282795].
Hricik DE, Anton HAS, Knauss TC, et al. Outcomes of African American kidney transplant recipients treated with sirolimus, tacrolimus, and corticosteroids. Transplantation. Jul. 27. 2002;74(2):189-93. [pmid: 12151730].
Hsieh HH, Chien YS, Hsu KT, et al. Risk factors for renal allograft survival in patients receiving cyclosporine immunosuppression. J Formos Med Assoc. Jun. 2000;99(6):453-8. [pmid: 10925550].
Jha V, Muthukumar T, Kohli HS, et al. Impact of cyclosporine withdrawal on living related renal transplants: a single-center experience. Am J Kidney Dis. 2001;37(1):119-24. [pmid: 11136176].
Jindal RM. A phase III prospective, randomised study to evaluate concentration controlled rapamune with cyclosporin dose minimization or elimination at six months in de novo renal allograft recipients [abstract]. Dev Behav Pediatr Online. 2002. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/940/CN-00415940/frame.html.
Joannides R, Monteil C, De Ligny BH, et al. Immunosuppressant regimen based on sirolimus decreases aortic stiffness in renal transplant recipients in comparison to cyclosporine. Am J Transplant. Nov. 2011;11(11):2414-22. [pmid: 21929645].
John GT, Dakshinamurthy DS, Jeyaseelan L, et al. The effect of cyclosporin A on plasma lipids during the first year after renal transplantation. Natl Med J India. Jan-Feb. 1999;12(1):14-7. [pmid: 10326324].
Joss N, Rodger RS, McMillan MA, et al. Randomized study comparing cyclosporine with azathioprine one year after renal transplantation-15-year outcome data. Transplantation. Mar. 2007;83(5):582-7. [pmid: 17353778].
Kang MH, Kim HJ, Ko RK, et al. A systematic review of immunosuppressive regimens in lower immunological risk renal transplant recipients. Value Health. Nov. 2010;13(7).
Khauli RB, Houjaij A, Sawah S, et al. Observations on quadruple immunosuppression maintenance therapy using rapamycin, low-dose cyclosporine, mycophenolate mofetil, and prednisone following ATG induction. Transplant Proc. Sep. 2005;37(7):3031-3. [pmid: 16213295].
Kovac D, Kotnik V, Kandus A. Basiliximab and mycophenolate mofetil in combination with low-dose cyclosporine and methylprednisolone effectively prevent acute rejection in kidney transplant recipients. Transplant Proc. Dec. 2005;37(10):4230-4. [pmid: 16387086].
Langer RM, Hong DM, Katz SM, et al. Basiliximab-sirolimus-prednisone induction regimen followed by delayed low-dose cyclosporine in renal transplant recipients of living donors. Transplant Proc. Dec. 2002;34(8):3162-4. [pmid: 12493406].
Lawen J, Keough-Ryan T, Clase C, et al. Sirolimus and low-dose tacrolimus with antibody induction in kidney transplantation: preliminary results of a pilot study. Transplant Proc. 2001;33(7):3223-5. [pmid: 11750382].
Legendre C, Brault Y, Morales JM, et al. Factors influencing glomerular filtration rate in renal transplantation after cyclosporine withdrawal using sirolimus-based therapy: a multivariate analysis of results at five years. Clin Transplant. May-Jun. 2007;21(3):330-6. http://dx.doi.org/10.1111/j.1399-0012.2007.00645.x. [pmid: 17488381].
Legendre C, Cohen D, Zeier M, et al. Efficacy and safety of enteric-coated mycophenolate sodium in de novo renal transplant recipients: pooled data from three 12-month multicenter, open-label, prospective studies. Transplant Proc. 2007;39(5):1386-91. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/843/CN-00615843/frame.html. [pmid: 17580145].
Lehner F, Budde K, Zeier M, et al. Efficacy and safety of conversion from cyclosporine to everolimus in livingdonor kidney transplant recipients: an analysis from the ZEUS study. Transpl Int. 2014. Jul. 29. [pmid: 25070687].
Liefeldt L, Brakemeier S, Glander P, et al. Donor-specific HLA antibodies in a cohort comparing everolimus with cyclosporine after kidney transplantation. Am J Transplant. May. 2012;12(5):1192-8. [pmid: 22300538].
Lim WH, Eris J, Kanellis J, et al. A systematic review of conversion from calcineurin inhibitor to mammalian target of rapamycin inhibitors for maintenance immunosuppression in kidney transplant recipients. Am J Transplant. Sep. 2014;14(9):2106-19. Epub 2014 Aug 1. [pmid: 25088685].
Luo XH, Xue WJ, Tian PX, et al. The clinical value of enzyme-multiplied immunoassay technique monitoring the plasma concentrations of cyclosporine A after renal transplantation. J Pharm Anal. May. 2011;1(2):139-42.
Mahalati K, Lawen J, Kiberd B, et al. Is 3-hour cyclosporine blood level superior to trough level in early post-renal transplantation period?. J Urol. Jan. 2000;163(1):37-41. [pmid: 10604309].
McTaggart RA, Tomlanovich S, Bostrom A, et al. Comparison of outcomes after delayed graft function: sirolimus-based versus other calcineurin-inhibitor sparing induction immunosuppression regimens. Transplantation. Aug. 15. 2004;78(3):475-80. [pmid: 15316379].
Midtvedt K, Fauchald P, Bergan S, et al. C(2) monitoring in maintenance renal transplant recipients: is it worthwhile?. Transplantation. Oct. 27. 2003;76(8):1236-8. [pmid: 14578761].
Miles CD, Skorupa JY, Sandoz JP, et al. Albuminuria after renal transplantation: maintenance with sirolimus/low-dose tacrolimus vs. mycophenolate mofetil/high-dose tacrolimus. Clin Transplant. Nov-Dec. 2011;25(6):898-904. [pmid: 21077952].
Moore J, Middleton L, Cockwell P, et al. Calcineurin inhibitor sparing with mycophenolate in kidney transplantation: a systematic review and meta-analysis. Transplantation. Feb. 27. 2009;87:591-605. [pmid: 19307799].
Morales JM, Grinyo JM, Campistol JM, et al. Improved renal function, with similar proteinuria, after two years of early tacrolimus withdrawal from a regimen of sirolimus plus tacrolimus. Transplantation. Aug. 27. 2008;86(4):620-2. [pmid: 18724234].
Morris RG. Cyclosporin therapeutic drug monitoring--an established service revisited. Clin Biochem Rev. May. 2003;24(2):33-46. [pmid: 18568053].
Mulay AV, Cockfield S, Stryker R, et al. Conversion from calcineurin inhibitors to sirolimus for chronic renal allograft dysfunction: a systematic review of the evidence. Transplantation. Nov. 15. 2006;82(9):1153-62. [pmid: 17102766].
Murakami N, Riella LV, Funakoshi T. Risk of metabolic complications in kidney transplantation after conversion to mTOR inhibitor: a systematic review and meta-analysis. Am J Transplant. Oct. 2014;14(10):2317-27. [pmid: 25146383].
Murbraech K, Holdaas H, Massey R, et al. Cardiac response to early conversion from calcineurin inhibitor to everolimus in renal transplant recipients: an echocardiographic substudy of the randomized controlled central trial. Transplantation. Jan. 27. 2014;97(2):184-8. [pmid: 24092385].
Naik MG, Heller KM, Arns W, et al. Proteinuria and sirolimus after renal transplantation: a retrospective analysis from a large German multicenter database. Clin Transplant. Jan. 2014;28(1):67-79. [pmid: 24372584].
Paoletti E, Amidone M, Cassottana P, et al. Effect of sirolimus on left ventricular hypertrophy in kidney transplant recipients: a 1-year nonrandomized controlled trial. Am J Kidney Dis. Aug. 2008;52(2):324-30. [pmid: 18585837].
Park JB, Han YS, Kim SJ, et al. Feasibility of C2 monitoring in Korean renal transplantation. Transplant Proc. Dec. 2007;39(10):3105-8. http://dx.doi.org/10.1016/j.transproceed.2007.07.086. [pmid: 18089332].
Patel N, Taber DJ, Weimert NA, et al. Potential differences in kidney allograft outcomes between ethnicities when converting to sirolimus base immunosuppression. Transplant Proc. Dec. 2009;41(10):4131-7. [pmid: 20005354].
Pescovitz MD, Nezakatgoo N, Lorber MI, et al. Prospective observational study of sirolimus as primary immunosuppression after renal transplantation. Transplantation. Oct. 2009;88(8):1010-8. [pmid: 19855247].
Pussell B, Russ G, Walker R, et al. Conversion from calcineurin inhibitors to sirolimus versus continued use of calcineurin inhibitors in renal allograft recipients: 18-month efficacy and safety results from a large, randomized, open-label, comparative trial. [abstract no: 106]. Dev Behav Pediatr Online. 2006;91. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/368/CN-00644368/frame.html.
Rabot N, Buchler M, Foucher Y, et al. CNI withdrawal for post-transplant lymphoproliferative disorders in kidney transplant is an independent risk factor for graft failure and mortality. Transpl Int. 2014. Jun. 25. [pmid: 24964147].
Romagnoli J, Citterio F, Nanni G, et al. Incidence of posttransplant diabetes mellitus in kidney transplant recipients immunosuppressed with sirolimus in combination with cyclosporine. Transplant Proc. May. 2006;38(4):1034-6. [pmid: 16757255].
Ruiz San Millan JC, Lopez-Hoyos M, Segundo DS, et al. Predictive factors of allosensitization in renal transplant patients switched from calcineurin to mTOR inhibitors. Transpl Int. Aug. 2014;27(8):847-56. Epub 2014 Jun 17. [pmid: 24707885].
Ruiz JC, Campistol JM, Sanchez-Fructuoso A, et al. Increase of proteinuria after conversion from calcineurin inhibitor to sirolimus-based treatment in kidney transplant patients with chronic allograft dysfunction. Nephrol Dial Transplant. Nov. 2006;21(11):3252-7. [pmid: 16954170].
Salvadori M, Rosati A, Bertoni E, et al. Low 1-year cyclosporine microemulsion doses are associated with better 5-year renal graft function: an insight from MOST, a multinational observational study. Transplant Proc. May. 2006;38(4):1010-3. [pmid: 16757247].
Sanchez-Fructuoso AI, Marques M, Conesa J, et al. Use of different immunosuppressive strategies in recipients of kidneys from nonheart-beating donors. Transpl Int. May. 2005;18(5):596-603. [pmid: 15819810].
Sanders CE, Julian BA, Gaston RS, et al. Benefits of continued cyclosporine through an indigent drug program. Am J Kidney Dis. Oct. 1996;28(4):572-7. [pmid: 8840948].
Sandrini S, Bossini N, Setti G, et al. Neoral dose adjustment after conversion from C0 to C2 monitoring in stable renal transplantation recipients: a prospective single center study. J Nephrol. Mar-Apr. 2004;17(2):284-90. [pmid: 15293530].
Seger C, Tentschert K, Stoggl W, et al. A rapid HPLC-MS/MS method for the simultaneous quanitification of cyclosporine A, tacrolimus, sirolimus and everolimus in human blood samples. Nat Protoc. 2009;4(4):526-534. [pmid: 19325549].
Segoloni GP, Messina M, Squiccimarro G, et al. Preferential allocation of marginal kidney allografts to elderly recipients combined with modified immunosuppression gives good results. Transplantation. Oct. 15. 2005;80(7):953-8. [pmid: 16249744].
Sellars D. A phase 4, randomised open-label, controlled, single centre study of induction with basiliximab, mycophenolate mofetil and tacrolimus with rapid steroid withdrawal and randomisation to either continuation with mycophenolate mofetil and tacrolimus or switch to sirolimus and mycophenolate mofetil maintenance in renal transplant recipients. Dev Behav Pediatr Online. 2004. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/151/CN-00602151/frame.html.
Sert M, Celik A, Kural K, et al. Results of 4-year analysis of conversion from calcineurin inhibitors to mTOR inhibitors in renal transplant patients: single-center experience. Ren Fail. Sep. 2011;33(8):789-94. [pmid: 21787153].
Shapiro R, Zeevi A, Basu A, et al. Alemtuzumab preconditioning with tacrolimus monotherapy-the impact of serial monitoring for donor-specific antibody. Transplantation. Apr. 2008;85(8):1125-32. [pmid: 18431232].
Sharif A, Shabir S, Chand S, et al. Meta-analysis of calcineurin-inhibitor-sparing regimens in kidney transplantation. J Am Soc Nephrol. Nov. 2011;22(11):2107-18. [pmid: 21949096].
Smith SR, Minda SA, Samsa GP, et al. Late withdrawal of cyclosporine in stable renal transplant recipients. Am J Kidney Dis. 1995;26(3):487-94. [pmid: 7645557].
Staatz C, Taylor P, Tett S. Low tacrolimus concentrations and increased risk of early acute rejection in adult renal transplantation. Nephrol Dial Transplant. 2001;16(9):1905-9. [pmid: 11522877].
Su L, Tam N, Deng R, et al. Everolimus-based calcineurin-inhibitor sparing regimens for kidney transplant recipients: a systematic review and meta-analysis. Int Urol Nephrol. 2014. Jul. 16. [pmid: 25027805].
Sun Q, Liu ZH, Ji S, et al. Late and early C4d-positive acute rejection: different clinico- histopathological subentities in renal transplantation. Kidney Int. Jul. 7. 2006;70(2):377-83. [pmid: 16760909].
Sutherland AI, Akhtar MZ, Zilvetti M, et al. Alemtuzumab and sirolimus in renal transplantation: six-year results of a single-arm prospective pilot study. Am J Transplant. Mar. 2014;14(3):677-84. [pmid: 24612687].
Tan HP, Kaczorowski D, Basu A, et al. Steroid-free tacrolimus monotherapy after pretransplantation thymoglobulin or campath and laparoscopy in living donor renal transplantation. Transplant Proc. Dec. 2005;37(10):4235-40. [pmid: 16387087].
Tedesco H. Efficacy and safety of induction strategies combined with low tacrolimus exposure in kidney transplant recipients receiving everolimus or sodium mycophenolate. Dev Behav Pediatr Online. 2011. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/397/CN-00793397/frame.html.
Thakur V, Kumar R, Gupta PN. Utility of C-2 (Cyclosporine) monitoring in postrenal transplant patients: A study in the Indian population. Indian J Nephrol. Jul. 2008;18(3):118-21. [pmid: 20142917].
Thervet E, Morelon E, Ducloux D, et al. Cyclosporine withdrawal in stable renal transplant recipients after azathioprine-mycophenolate mofetil conversion. Clin Transplant. 2000;14(6):561-6. [pmid: 11127309].
Townamchai N, Avihingsanon Y, Praditpornsilpa K, et al. De novo sirolimus-based regimen in Thai renal transplant recipients. Transplant Proc. Sep. 2008;40(7):2206-8. [pmid: 18790193].
Troncoso P, Ortiz AM, Jara A, et al. Abbreviated AUC monitoring of cyclosporine more adequately identified patients at risk for acute rejection during induction of immunosuppressive therapy after kidney transplantation than recommended C2 concentration values. Transplant Proc. Jan-Feb. 2009;41(1):127-30. [pmid: 19249495].
Vanrenterghem Y, Bresnahan B, Campistol J, et al. Belatacept-based regimens are associated with improved cardiovascular and metabolic risk factors compared with cyclosporine in kidney transplant recipients (BENEFIT and BENEFIT-EXT Studies). Transplantation. May. 15. 2011;91(9):976-83. [pmid: 21372756].
Veroux M, Corona D, Giuffrida G, et al. New-onset diabetes mellitus after kidney transplantation: the role of immunosuppression. Transplant Proc. Jul-Aug. 2008;40(6):1885-7. [pmid: 18675079].
Vogeser M. Liquid chromatography-tandem mass spectrometry – application in the clinical laboratory. Clin Chem Lab Med. 2003;41(2):117-126. [pmid: 12666995].
Wang R, Xu Y, Wu J, et al. Reduced-dose cyclosporine with mycophenolate mofetil and prednisone significantly improves the Long-term glomerular filtration rate and graft survival. Intern Med. May. 1. 2013;52(9):947-53. [pmid: 23648712].
Weir MR, Blahut S, Drachenburg C, et al. Late calcineurin inhibitor withdrawal as a strategy to prevent graft loss in patients with suboptimal kidney transplant function. Am J Nephrol. 2004;24(4):379-86. http://dx.doi.org/10.1159/000079390. [pmid: 15237243].
Williams P. An open label randomised study of sirolimus in patients with impaired renal function following renal transplantation. Dev Behav Pediatr Online. 2003. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/187/CN-00527187/frame.html.
Witzke O, Viklicky O, Turk TR, et al. Conversion to sirolimus of patients with chronic allograft nephropathy--a retrospective analysis of outcome and influencing factors. Langenbecks Arch Surg. Nov. 2009;394(6):1073-8. [pmid: 19020895].
Wong W, TolkoffRubin N, Delmonico FL, et al. Analysis of the cardiovascular risk profile in stable kidney transplant recipients after 50% cyclosporine reduction. Clin Transplant. Aug. 2004;18(4):341-8. [pmid: 15233807].
Wu JY, Chen JH, Wang YM, et al. Improved clinical outcomes in Chinese renal allograft recipients receiving lower dose immunosuppressants. Transplantation. Sep. 15. 2004;78(5):713-8. [pmid: 15371674].
Yan HL, Zong HT, Cui YS, et al. Calcineurin inhibitor avoidance and withdrawal for kidney transplantation: a systematic review and meta-analysis of randomized controlled trials. Transplant Proc. Jun. 2014;46(5):1302-13. [pmid: 24935293].
Yang A, Wang B. Sirolimus versus tacrolimus in kidney transplant recipients receiving mycophenolate mofetil and steroids: focus on acute rejection, patient and graft survival. Am J Ther. 2013. Aug. 5. [pmid: 23921809].
Zachariah M, Nader ND, Brar J, et al. Alemtuzumab and minimization immunotherapy in kidney transplantation: long-term results of comparison with rabbit anti-thymocyte globulin and standard triple maintenance therapy. Transplant Proc. Jan-Feb. 2014;46(1):94-100. [pmid: 24507032].

## Does not address an outcome of interest to the report

Akbas SH, Ozdem S, Caglar S, et al. Effects of some hematological parameters on whole blood tacrolimus concentration measured by two immunoassay-based analytical methods. Clin Biochem. Jun. 2005;38(6):552-7. [pmid: 15885236].
Borrows R, Chusney G, Loucaidou M, et al. Analysis of factors influencing tacrolimus levels and immunoassay bias in renal transplantation. J Clin Pharmacol. Aug. 2007;47(8):1035-42. [pmid: 17660485].
Cardinal H, Barama AA, Fradet V, et al. Total cholesterol correlates with cyclosporine C2 levels in kidney transplant recipients under maintenance immunosuppression. Transplant Proc. Mar. 2004;36(2 Suppl):448S-50S. [pmid: 15041384].
Chapman JR. Optimizing the long-term outcome of renal transplants: opportunities created by sirolimus. Transplant Proc. May. 2003;35(3). [pmid: 12742470].
Cole E, Maham N, Cardella C, et al. Clinical benefits of neoral C2 monitoring in the long-term management of renal transplant recipients. Transplantation. Jun. 27. 2003;75(12):2086-90. [pmid: 12829917].
Einollahi B, Teimoori M, Rostami Z. Change of cyclosporine absorption over the time after kidney transplantation. Nephrourol Mon. 2012;4(2):470-4. Epub 2012 Mar 1. [pmid: 23573469].
Grinyo JM, Ekberg H, Mamelok RD, et al. The pharmacokinetics of mycophenolate mofetil in renal transplant recipients receiving standard-dose or low-dose cyclosporine, low-dose tacrolimus or low-dose sirolimus: the Symphony pharmacokinetic substudy. Nephrol Dial Transplant. 2009;24(7):2269-76. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/043/CN-00716043/frame.html. [pmid: 19357111].
Grundmann M, Koristkova B, Brozmanova H, et al. The possibility of using the specific RIA method for the area-under-time-concentration curve sparse sampling calculation of cyclosporin A despite a large post-dose overestimation. Int J Clin Pharmacol Ther. Jan. 2011;49(1):30-7. [pmid: 21176722].
Hamwi A, Salomon A, Steinbrugger R, et al. Cyclosporine metabolism in patients after kidney, bone marrow, heart-lung, and liver transplantation in the early and late posttransplant periods. Am J Clin Pathol. Oct. 2000;114(4):536-43. [pmid: 11026099].
Keown P, Cole E, Landsberg D, et al. Absorption profiling of cyclosporine microemulsion (Neoral) during the first 2 weeks after renal transplantation. Transplantation. Sep. 27. 2001;72(6):1024-32. [pmid: 11579295].
Keown P, Cole E, Muirhead N, et al. Randomized, international study of cyclosporine microemulsion absorption profiling in renal transplantation with basiliximab immunoprophylaxis. Am J Transplant. Feb. 2002;2(2):157-66. [pmid: 12099518].
Kokuhu T, Fukushima K, Ushigome H, et al. Dose Adjustment Strategy of Cyclosporine A in Renal Transplant Patients: Evaluation of Anthropometric Parameters for Dose Adjustment and C0 vs. C2 Monitoring in Japan, 2001-2010. Int J Med Sci. Sep. 23. 2013;10(12):1665-73. [pmid: 24151438].
Koristkova B, Grundmann M, Brozmanova H, et al. Validation of sparse sampling strategies to estimate cyclosporine A area under the concentration-time curve using either a specific radioimmunoassay or high-performance liquid chromography method. Ther Drug Monit. Oct. 2010;32(5):586-93. [pmid: 20683391].
Lee PC, Lee CY, Hu RH, et al. Intrarenal vascular resistance parameters in kidney transplant patients receiving calcineurin inhibitor-based or sirolimus-based regimens. Nephrol Dial Transplant. May. 2010;25(5):1675-80. [pmid: 20042398].
Mourer JS, De Koning EJP, Van Zwet EW, et al. Impact of late calcineurin inhibitor withdrawal on ambulatory blood pressure and carotid intima media thickness in renal transplant recipients. Transplantation. Jul. 15. 2013;96(1):49-57. [pmid: 23715049].
Ruiz JC, Campistol JM, Grinyo JM, et al. Early cyclosporine a withdrawal in kidney-transplant recipients receiving sirolimus prevents progression of chronic pathologic allograft lesions. Transplantation. Nov. 15. 2004;78(9):1312-8. [pmid: 15548969].
Saber LTS, Ikeda MY, Almeida JM. Posttransplantation conversion to sirolimus-based immunosuppression: a single center experience. Transplant Proc. Dec. 2007;39(10):3098-100. [pmid: 18089330].
Saunders RN, Bicknell GR, Nicholson ML. The impact of cyclosporine dose reduction with or without the addition of rapamycin on functional, molecular, and histological markers of chronic allograft nephropathy. Transplantation. Mar. 27. 2003;75(6):772-80. [pmid: 12660500].
Segundo DS, Ruiz JC, Izquierdo M, et al. Calcineurin inhibitors, but not rapamycin, reduce percentages of CD4 (+)CD25(+)FOXP3(+) regulatory T cells in renal transplant recipients. Transplantation. Aug. 2006;82(4):550-7. [pmid: 16926600].
Senel MF, Van Buren CT, Welsh M, et al. Impact of early cyclosporin average blood concentration on early kidney transplant failure. Transpl Int. 1998;11(1):46-52. [pmid: 9503554].
Serdarevic N, Zunic L. Comparison of architect I 2000 for determination of cyclosporine with axsym. Acta Inform Med. Dec. 2012;20(4):214-7. [pmid: 23378685].
Sood P, Senanayake S, Sujeet K, et al. Management and outcome of BK viremia in renal transplant recipients: a prospective single-center study. Transplantation. Oct. 27. 2012;94(8):814-21. [pmid: 23018881].
Stallone G, Infante B, Pontrelli P, et al. Sirolimus and proteinuria in renal transplant patients: Evidence for a dose-dependent effect on slit diaphragm-associated proteins. Transplantation. May. 11. 2011;91(9):997-1004. [pmid: 21364499].

## Other reason (e.g., duplicate)

Charpentier B, Groth CG, Backman L, et al. Bicentre hospital experience with sirolimus-based therapy in human renal transplantation: the Sirolimus European Renal Transplant Study. Transplant Proc. 2003;35(3 Suppl):58S-61S. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/130/CN-00509130/frame.html. [pmid: 12742468].
Ekberg H, Van Gelder T, Kaplan B, et al. Relationship of tacrolimus exposure and mycophenolate mofetil dose with renal function after renal transplantation. Transplantation. Jul. 15. 2011;92(1):82-7. [pmid: 21562449].
El-Agroudy AE, El-Dahshan K, Mahmoud K, et al. Immunosuppression modifications and graft outcome in patients with chronic allograft nephropathy. Exp Clin Transplant. Sep. 2008;6(3):203-10. [pmid: 18954298].
El-Agroudy AE, El-Dahshan K, Mahmoud K, et al. Long-term graft outcome in patients with chronic allograft dysfunction after immunosuppression modifications. Ann Transplant. 2008;13(4):46-54. [pmid: 19034223].
Favi E, Citterio F, Spagnoletti G, et al. Prospective clinical trial comparing two immunosuppressive regimens, tacrolimus and mycophenolate mofetil versus everolimus and low-dose cyclosporine, in de novo renal transplant recipients: results at 6 months follow-up. Transplant Proc. May. 2009;41(4):1152-5. [pmid: 19460503].
Frassetto LA, TanTam CC, Barin B, et al. Best single time point correlations with AUC for cyclosporine and tacrolimus in HIV-infected kidney and liver transplant recipients. Transplantation. Mar. 27. 2014;97(6):702-7. [pmid: 24389906].
Heilman RL, Cortese C, Geiger XJ, et al. Impact of early conversion from tacrolimus to sirolimus on chronic allograft changes in kidney recipients on rapid steroid withdrawal. Transplantation. Jan. 15. 2012;93(1):47-53. [pmid: 22067270].
Heim-Duthoy KL, Chitwood KK, Tortorice KL, et al. Elective cyclosporine withdrawal 1 year after renal transplantation. Am J Kidney Dis. 1994;24(5):846-53. [pmid: 7977328].
Lebranchu Y, Snanoudj R, Toupance O, et al. Five-year results of a randomized trial comparing de novo sirolimus and cyclosporine in renal transplantation: the Spiesser study. Am J Transplant. Jul. 2012;12(7):1801-10. Epub 2012 Apr 5. [pmid: 22486815].
Salgo R, Gossmann J, Schofer H, et al. Switch to a sirolimus-based immunosuppression in long-term renal transplant recipients: reduced rate of (pre-)malignancies and nonmelanoma skin cancer in a prospective, randomized, assessor-blinded, controlled clinical trial. Am J Transplant. Jun. 2010;10(6):1385-93. [pmid: 20121752].
Sharma R, Kumar J, Ahmed M, et al. Cyclosporine level: which single-point estimation of drug level is the best?. Transplant Proc. 2001;33(7):3124-5. [pmid: 11750343].
Shihab FS, Cibrik D, Chan L, et al. Association of clinical events with everolimus exposure in kidney transplant patients receiving reduced cyclosporine. Clin Transplant. Mar-Apr. 2013;27(2):217-26. [pmid: 23230975].
Sumethkul V, Changsirikulchai S, Lothuvachai T, et al. Sirolimus attenuates the rate of progression of early chronic allograft nephropathy. Transplant Proc. Dec. 2006;38(10):3470-2. [pmid: 17175307].
Tedesco-Silva H Jr, Vitko S, Pascual J, et al. 12-month safety and efficacy of everolimus with reduced exposure cyclosporine in de novo renal transplant recipients. Transpl Int. Jan. 2006;20(1):27-36. [pmid: 17181650].
Tredger JM, Gilkes CD, Gonde CE. Therapeutic monitoring of tacrolimus (FK506) with the first- and second-generation microparticle enzyme immunoassays: performance and results in four patient populations. Ther Drug Monit. Jun. 1998;20(3):266-75. [pmid: 9631923].
Vincenti F, Laskow DA, Neylan JF, et al. One-year follow-up of an open-label trial of FK506 for primary kidney transplantation: a report of the US Multicenter FK506 Kidney Transplant Group. Transplantation. 1996;61(11):1576-81. [pmid: 8669100].

## Enrolls fewer than 20 patients per study arm

Moscato D, Nonnato A, Adamo R, et al. Therapeutic monitoring of tacrolimus: aberrant results by an immunoassay with automated pretreatment. Clin Chim Acta. 2010;411:77-80. [pmid: 19835852].
Musuamba FT, Mourad M, Haufroid V, et al. Time of drug administration, CYP3A5 and ABCB1 genotypes, and analytical method influence tacrolimus pharmacokinetics: a population pharmacokinetic study. Ther Drug Monit. Dec. 2009;31(6):734-42. [pmid: 19855314].
Paoletti E, Ratto E, Bellino D, et al. Effect of early conversion from CNI to sirolimus on outcomes in kidney transplant recipients with allograft dysfunction. J Nephrol. Sep-Oct. 2012;25(5):709-18. [pmid: 22038336].
Wyzgal J, Paczek L, Senatorski G, et al. Sirolimus rescue treatment in calcineurin-inhibitor nephrotoxicity after kidney transplantation. Transplant Proc. Dec. 2002;34(8):3185-7. [pmid: 12493414].

## Does not report usable data

Brown NW, Gonde CE, Adams JE, et al. Low hematocrit and serum albumin concentrations underlie the overestimation of tacrolimus concentrations by microparticle enzyme immunoassay versus liquid chromatography-tandem mass spectrometry. Clin Chem. Mar. 2005;51(3):586-92. [pmid: 15650031].
Tomita T, Homma M, Yusawa K, et al. Effects of hematocrit value on microparticle enzyme immunoassay of tacrolimus concentration in therapeutic drug monitoring. Ther Drug Monit. Feb. 2005;27(1):94-7. [pmid: 15665753].

## Does not address population of interest

Aiello FB, Furian L, Marino S, et al. Acute rejection features in dual kidney transplant recipients from elderly donors: comparison of calcineurin inhibitor-based and calcineurin inhibitor-free immunosuppressive protocols. Int J Immunopathol Pharmacol. Oct-Dec. 2009;22(4):1001-7. [pmid: 20074463].