# Search Strategy

## Resources Searched

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for the bibliographic databases appear below.

Table A-1 Bibliographic databases searched

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | 1994 through July 11, 2014 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | 1994 through May 20, 2015 | Wiley
Database of Abstracts of Reviews of Effects (DARE) | 1994 through May 20, 2015 | Wiley
EMBASE (Excerpta Medica) | 1994 through December 10, 2015 (for KQ1 and KQ2) 1994 through May 20, 2015 (for KQ3) | Embase.com
Health Technology Assessment Database (HTA) | 1994 through June 2014 | Wiley
MEDLINE | 1994 through May 20, 2015 | Embase.com
PubMed (In-process and published records) | 1994 through December 10, 2015 (for KQ1 and KQ2) 1994 through May 20, 2015 (for KQ3) | NLM
U.K. National Health Service Economic Evaluation Database (NHS EED) | 1994 through June 2014 | Wiley

Table A-2 Gray literature resources searched

Name | Date Limits | Platform/Provider
American Society of Transplantation (AST) | Searched July 24, 2014^*^ | AST
American Society of Transplant Surgeons (ASTS) | Searched July 24, 2014^*^ | ASTS
American Transplant Congress | 2013 and 2014 meeting abstracts | ASTS
Clinical Trials.gov | 1994 through July 15, 2014 | U.S. National Institutes of Health (NIH)
Centre for Evidence in Transplantation (CET) | Website searched July 24, 2014^*^ Trial Watch database searched January 1, 2013 through July 24, 2014 | CET
Centers for Disease Control and Prevention (CDC) | Searched July 24, 2014^*^ | CDC
Centers for Medicare and Medicaid | 1994 through July 15, 2014 | CMS
Health Devices | 1994 through July 15, 2014 | ECRI Institute
Health Technology Assessment Information Service (HTAIS) website | 1994 through July 15, 2014 | ECRI Institute
Healthcare Product Comparison Systems (HPCS) website | 1994 through July 20, 2014 | ECRI Institute
Healthcare Standards database | 1994 through July 15, 2014 | ECRI Institute
Infectious Diseases Society of America (IDSA) | 1994 through September 9, 2014 | IDSA (searched via Google search engine)
MedlinePlus | Searched July 24, 2014 | National Library of Medicine (NLM)
Medscape | 2009 through July 23, 2014 | WebMD
National Guideline Clearinghouse™ (NGC) | Searched July 14, 2014^*^ | Agency for Healthcare Research and Quality (AHRQ)
National Institute of Health and Clinical Excellence (NICE) | Searched July 25, 2014^*^ | National Health Service (UK)
National Kidney Foundation (NKF) | Searched July 24, 2014^*^ | NKF
Organ Procurement and Transplantation Network (OPTN) | Searched Aug 12, 2014^*^ | Health Resources and Services Administration (HRSA)
Scientific Registry of Transplant Recipients | Searched Aug 12, 2014^*^ | Health Resources and Services Administration (HRSA)
U.S. Food and Drug Administration (FDA) | Searched July 14, 2014^*^ | FDA
World Transplant Congress (WTC) | 2014 meeting abstracts | WTC

* Search date limits were not applied.

## Hand Searches of Journal and Gray Literature

Journals and supplements maintained in ECRI Institute's collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature).

## Topic-Specific Search Terms

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. Strategies for each bibliographic database follow this table.

Table A-3 Controlled vocabulary and keywords

Concept | Controlled Vocabulary | Keywords
Calcineurin Inhibitors | EMBASE (EMTREE) ‘advagraf’/exp ‘astagraf’/exp ‘calcineurin inhibitor’/exp ‘ciclosporine’/exp ‘cipol’/exp ‘cyclokat’/exp ‘cyclosporin’/exp ‘deximune’/exp ‘gengraf’/exp ‘hecoria’/exp ‘immunosporin’/exp ‘implanta’/exp ‘mustopic oint’/exp ‘neoral’/exp ‘prograf’/exp ‘tacrolimus’/exp ‘tsukubaenolide’/exp ‘vekacia’/exp | advagraf astagraf calcineurin NEAR/2 inhibit^*^ cipol ‘cni’ cyclokat cyclosporin cyclosporine ‘CSA-neoral’ ‘cya-nof’ deximune gengraf hecoria immunosporin implanta imusporin ‘mustopic oint’ neoral ‘ol-27-400’ prograf tacrolimus tsukubaenolide vekacia
CNI Minimization | ‘low drug dose’/exp ‘dosage schedule comparison’/exp ‘treatment withdrawal’/exp ‘drug withdrawal’/exp | Alternative AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) avoid^*^ AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) eliminate^*^ AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) low AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) lower^*^ AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) minimize AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) minimization AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) minimal AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) reduce AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) reduction AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) taper^*^ AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen) withdraw^*^ AND (dose^*^ OR dosing OR dosage^*^ OR drug^*^ OR strategy OR strategies OR regimen)
CNI alternative drugs | ‘alemtuzumab’/exp ‘belatacept’/exp ‘everolimus’/exp ‘rapamycin’/exp ‘sotrastaurin’/exp ‘tofacitinib’/exp | alemtuzumab belatacept' everolimus' rapamycin sirolimus sotrastaurin tofacitinib
Drug Monitoring timepoints (Cyclosporine) | NA | (‘area under’ NEXT/1 curve) (‘2’ OR ‘two’) NEAR/1 hour^*^ “c1” “c0” “c2” (time OR ‘time point’ OR timepoint^*^ OR timing OR duration) AND (cyclospor^*^ NEAR/2 level^*^) time NEAR/1 series trough
Drug Monitoring Terms | ‘area under the curve’/exp ‘drug monitoring’/exp ‘pharmacodynamics’/exp ‘pharmacokinetics’/exp | (‘area under’ NEXT/4 curve) bioequivalence ‘drug monitoring’ (drug OR therapy OR therapeutic) AND (monitor^*^ OR measure^*^ OR surveillance) drug NEAR/3 (clearance OR activation OR adsorp^*^ OR absorp^*^ OR bioavailabilit^*^ OR distribution) (limit NEXT/3 quantification) ‘loq’
Immunoassays/Mass Spectrometry | ‘immunoassay’/exp ‘mass spectrometry’/exp ‘high performance liquid chromatography’/exp | ACMIA ‘antibody conjugated magnetic immunoassay’ ‘elisa’ ‘emit’ ‘enzyme linked immmunosorbent assay’ ‘enzyme multiplied immunoassay’ fluorescence NEAR/1 polarization ‘fpia’ ‘gc-ms’ ‘high performance liquid chromatography hplc’ ‘hplc-ms’ immunoassay^*^ ‘lc-ms’ ‘liquid chromatography’ NEAR/2 ‘mass spectrometry’ ‘mass spectrometry’ (mass NEAR/1 spectrometr^*^) ‘meia’ ‘microparticle enzyme immunoassay’ ‘ms’
Kidney Transplantation | EMBASE (EMTREE) ‘kidney graft’/exp | ‘kidney graft’ ‘kidney transplantation’ ‘renal graft dysfunction’ (kidney OR renal) AND (allograft^*^ OR alograft^*^ OR transplant^*^ OR homograft^*^ OR graft^*^ OR recipient^*^)

* EMTREE terms are mapped to corresponding Medical Subject Heading (MeSH) terms in Embase.com.

## Search Strategies

Table A-4 EMBASE/MEDLINE for Key Question 1 and Key Question 3b (presented in Embase.com syntax)

Set Number | Concept | Search Statement
1 | Kidney transplantation | ‘kidney graft’/exp OR ‘kidney graft’ OR ‘kidney transplantation’ OR ‘renal graft dysfunction’/exp OR ‘renal graft dysfunction’ OR ((kidney OR renal) AND (allograft* OR alograft* OR transplant* OR homograft* OR graft* OR recipient*))
2 | Immunosuppressive drugs | ‘tacrolimus’/exp OR tacrolimus OR ‘cyclosporin’/exp OR cyclosporin OR ‘cyclosporine’/exp OR cyclosporine OR ‘ciclosporine’/exp OR ciclosporine OR ‘mustopic oint’/exp OR ‘mustopic oint’ OR ‘tsukubaenolide’/exp OR tsukubaenolide OR ‘cipol’/exp OR cipol OR ‘cyclokat’/exp OR cyclokat OR ‘deximune’/exp OR deximune OR ‘implanta’/exp OR implanta OR ‘immunosporin’/exp OR immunosporin OR imusporin OR ‘vekacia’/exp OR vekacia OR ‘prograf’/exp OR prograf OR ‘advagraf’/exp OR advagraf OR ‘hecoria’/exp OR hecoria OR ‘neoral’/exp OR ‘gengraf’/exp OR gengraf OR ‘astagraf’/exp OR astagraf OR ‘ol-27-400’ OR ‘CSA-neoral’ OR ‘cya-nof’ OR neoral
3 | Immunosuppressive drugs | ‘calcineurin inhibitor’/exp OR calcineurin NEAR/2 inhibit* OR ‘cni’
4 | Combine sets | 2 or 3
5 | Combine sets | 1 and 4
6 | Monitoring assays | ‘immunoassay’/exp OR immunoassay* OR ‘mass spectrometry’/exp OR ‘mass spectrometry’ OR ‘high performance liquid chromatography’/exp OR (mass NEAR/1 spectrometr*) OR ‘ms’ OR ‘gc-ms’ OR ‘hplc-ms’ OR ‘high performance liquid chromatography’ OR ‘hplc’ OR (fluorescence NEAR/1 polarization) OR ‘fpia’ OR ‘enzyme multiplied immunoassay’ OR ‘emit’ OR ‘enzyme linked immmunosorbent assay’ OR ‘elisa’ OR ‘microparticle enzyme immunoassay’ OR ‘meia’ OR (‘liquid chromatography’ NEAR/2 ‘mass spectrometry’) OR ‘lc-ms’ OR ‘antibody conjugated magnetic immunoassay’ OR ACMIA
7 | Drug monitoring | ‘drug monitoring’/exp OR ‘drug monitoring’ OR ((drug OR therapy OR therapeutic) AND (monitor* OR measure* OR surveillance)) OR ‘pharmacodynamics’/exp OR ‘area under the curve’/exp OR ‘pharmacokinetics’/exp OR bioequivalence OR (drug NEAR/3 (clearance OR activation OR adsorp* OR absorp* OR bioavailabilit* OR distribution)) OR (‘area under’ NEXT/4 curve) OR (limit NEXT/3 quantification) OR ‘loq’
8 | Combine sets | 5 AND 6 AND 7
9 | Diagnostic test Hedge | 8 AND (‘diagnostic accuracy’/exp OR ‘diagnosis’:lnk OR ‘receiver operating characteristic’:de OR ‘roc curve’/exp OR ‘roc curve’ OR ‘sensitivity and specificity’:de OR ‘sensitivity’ OR ‘specificity’ OR ‘accuracy’:de OR ‘precision’/exp OR ‘precision’:de OR ‘prediction and forecasting’/exp OR ‘prediction and forecasting’ OR ‘diagnostic error’/exp OR ‘diagnostic error’ OR ‘maximum likelihood method’:de OR ‘test retest reliability’/exp OR (test NEXT/3 reliability) OR ‘reliability’/exp OR ‘validity’/exp OR ‘measurement repeatability’/exp OR ‘likelihood’ OR ‘predictive value’/exp OR ‘predictive value’ OR ‘ppv’ OR ((false OR true) NEAR/1 (positive OR negative)) OR (‘area under’ NEXT/4 curve) OR (limit NEXT/3 quantification) OR ‘loq’ OR ((‘inter assay’ OR ‘inter-assay’ OR ‘inter laboratory’ OR ‘inter-laboratory’) NEAR/2 (agreement OR measurement OR reproducibility))
10 | Clinical trials filter | 8 AND (‘randomized controlled trial’/exp OR ‘randomized controlled trial’ OR ‘randomization’/exp OR ‘randomization’ OR ‘double blind procedure’/exp OR ‘double blind procedure’ OR ‘single blind procedure’/exp OR ‘single blind procedure’ OR ‘placebo’/exp OR ‘placebo’ OR ‘latin square design’/exp OR ‘latin square design’ OR ‘crossover procedure’/exp OR ‘crossover procedure’ OR ‘triple blind procedure’/exp OR ‘triple blind procedure’ OR ‘controlled study’/exp OR ‘controlled study’ OR ‘clinical trial’/exp OR ‘clinical trial’ OR ‘comparative study’/exp OR ‘comparative study’ OR ‘cohort analysis’/exp OR ‘cohort analysis’ OR ‘follow up’/exp OR ‘follow up’ OR ‘intermethod comparison’/exp OR ‘intermethod comparison’ OR ‘parallel design’/exp OR ‘parallel design’ OR ‘control group’/exp OR ‘control group’ OR ‘prospective study’/exp OR ‘prospective study’ OR ‘retrospective study’/exp OR ‘retrospective study’ OR ‘case control study’/exp OR ‘case control study’ OR ‘major clinical study’/exp OR ‘major clinical study’ OR ‘evaluation study’/exp OR ‘evaluation study’ OR random*:de OR random*:ti OR placebo* OR (singl* OR doubl* OR tripl* OR trebl* AND (dummy OR ‘blind’/exp OR blind OR sham)) OR ‘latin square’ OR isrctn* OR actrn* OR (nct* NOT nct))
11 | Systematic Review/Meta-analysis filter | 8 AND (‘research synthesis’ OR pooled OR ‘systematic review’/exp OR ‘systematic review’ OR ‘meta analysis’/exp OR ‘meta analysis’ OR ((‘evidence base’ OR ‘evidence based’/exp OR ‘evidence based’ OR methodol* OR systematic OR quantitative* OR studies OR search*) AND (‘review’/exp OR ‘review’ OR ‘review’/it)))
12 | Combine sets | 9 OR 10 OR 11
13 | Remove unwanted publication types | 12 NOT ‘book’/exp OR ‘book’ OR ‘conference paper’/exp OR ‘conference paper’ OR ‘editorial’/exp OR ‘editorial’ OR ‘letter’/exp OR ‘letter’ OR ‘note’/exp OR ‘note’ OR book:it,pt OR ‘edited book’:it,pt OR ‘case report’:it,pt OR ‘case reports’:it,pt OR comment:it,pt OR conference:it,pt OR editorial:it,pt OR letter:it,pt OR news:it,pt OR note:it,pt OR proceeding:it,pt

Table A-5 EMBASE/MEDLINE for Key Question 2 (presented in Embase.com syntax)

Set Number | Concept | Search Statement
1 | Kidney transplantation | ‘kidney graft’/exp OR ‘kidney graft’ OR ‘kidney transplantation’ OR ‘renal graft dysfunction’/exp OR ‘renal graft dysfunction’ OR ((kidney OR renal) AND (allograft* OR alograft* OR transplant* OR homograft* OR graft* OR recipient*))
2 | Cyclosporine | Cyclosporin/exp OR Cyclosporine OR cyclosporin OR cipol OR cyclokat OR deximune OR implanta OR imusporin OR vekacia OR ciclosporin OR ‘CsA-Neoral’ OR ‘CyA-NOF’ OR ‘Neoral’ OR ‘OL 27-400’
3 | Combine sets | 1 AND 2
4 | Drug monitoring/pharmacodynamics | ‘drug monitoring’/exp OR ‘drug monitoring’ OR ((drug OR therapy OR therapeutic) AND (monitor* OR measure* OR surveillance)) OR ‘pharmacodynamics’/exp OR ‘area under the curve’/exp OR ‘pharmacokinetics’/exp OR bioequivalence OR (drug NEAR/3 (clearance OR activation OR adsorp* OR absorp* OR bioavailabilit* OR distribution)) OR (‘area under’ NEXT/4 curve) OR (limit NEXT/3 quantification) OR ‘loq’
5 | Monitoring timepoints | ((‘2’ OR ‘two’) NEAR/1 hour*) OR trough OR ((time OR ‘time point’ OR timepoint* OR timing OR duration) AND (cyclospor* NEAR/2 level*)) OR ‘c1’ OR ‘c0’ OR ‘c2’ OR (‘area under’ NEXT/1 curve) OR time NEAR/1 series
6 | Combine sets | 3 AND 4 AND 5
7 | Diagnostic test Hedge | 6 AND (‘diagnostic accuracy’/exp OR ‘diagnosis’:lnk OR ‘receiver operating characteristic’:de OR ‘roc curve’/exp OR ‘roc curve’ OR ‘sensitivity and specificity’:de OR ‘sensitivity’ OR ‘specificity’ OR ‘accuracy’:de OR ‘precision’/exp OR ‘precision’:de OR ‘prediction and forecasting’/exp OR ‘prediction and forecasting’ OR ‘diagnostic error’/exp OR ‘diagnostic error’ OR ‘maximum likelihood method’:de OR ‘test retest reliability’/exp OR (test NEXT/3 reliability) OR ‘reliability’/exp OR ‘validity’/exp OR ‘measurement repeatability’/exp OR ‘likelihood’ OR ‘predictive value’/exp OR ‘predictive value’ OR ‘ppv’ OR ((false OR true) NEAR/1 (positive OR negative)) OR (‘area under’ NEXT/4 curve) OR (limit NEXT/3 quantification) OR ‘loq’ OR ((‘inter assay’ OR ‘inter-assay’ OR ‘inter laboratory’ OR ‘inter-laboratory’) NEAR/2 (agreement OR measurement OR reproducibility))
8 | Clinical Trials | 6 AND (‘randomized controlled trial’/exp OR ‘randomized controlled trial’ OR ‘randomization’/exp OR ‘randomization’ OR ‘double blind procedure’/exp OR ‘double blind procedure’ OR ‘single blind procedure’/exp OR ‘single blind procedure’ OR ‘placebo’/exp OR ‘placebo’ OR ‘latin square design’/exp OR ‘latin square design’ OR ‘crossover procedure’/exp OR ‘crossover procedure’ OR ‘triple blind procedure’/exp OR ‘triple blind procedure’ OR ‘controlled study’/exp OR ‘controlled study’ OR ‘clinical trial’/exp OR ‘clinical trial’ OR ‘comparative study’/exp OR ‘comparative study’ OR ‘cohort analysis’/exp OR ‘cohort analysis’ OR ‘follow up’/exp OR ‘follow up’ OR ‘intermethod comparison’/exp OR ‘intermethod comparison’ OR ‘parallel design’/exp OR ‘parallel design’ OR ‘control group’/exp OR ‘control group’ OR ‘prospective study’/exp OR ‘prospective study’ OR ‘retrospective study’/exp OR ‘retrospective study’ OR ‘case control study’/exp OR ‘case control study’ OR ‘major clinical study’/exp OR ‘major clinical study’ OR ‘evaluation study’/exp OR ‘evaluation study’ OR random*:de OR random*:ti OR placebo* OR (singl* OR doubl* OR tripl* OR trebl* AND (dummy OR ‘blind’/exp OR blind OR sham)) OR ‘latin square’ OR isrctn* OR actrn* OR (nct* NOT nct))
9 | Systematic Review/Meta-analysis filter | 6 AND (‘research synthesis’ OR pooled OR ‘systematic review’/exp OR ‘systematic review’ OR ‘meta analysis’/exp OR ‘meta analysis’ OR ((‘evidence base’ OR ‘evidence based’/exp OR ‘evidence based’ OR methodol* OR systematic OR quantitative* OR studies OR search*) AND (‘review’/exp OR ‘review’ OR ‘review’/it)))
10 | Combine sets | 7 OR 8 OR 9
11 | Remove unwanted publication types | 10 NOT ‘book’/exp OR ‘book’ OR ‘conference paper’/exp OR ‘conference paper’ OR ‘editorial’/exp OR ‘editorial’ OR ‘letter’/exp OR ‘letter’ OR ‘note’/exp OR ‘note’ OR book:it,pt OR ‘edited book’:it,pt OR comment:it,pt OR conference:it,pt OR editorial:it,pt OR letter:it,pt OR news:it,pt OR note:it,pt OR proceeding:it,pt
12 | Remove overlap from KQ1 | 11 NOT (results from KQ1)

Table A-6 EMBASE/MEDLINE for Key Question 3a (presented in Embase.com syntax)

Set Number | Concept | Search Statement
1 | Kidney transplantation | ‘kidney graft’/exp OR ‘kidney graft’ OR ‘kidney transplantation’ OR ‘renal graft dysfunction’/exp OR ‘renal graft dysfunction’ OR (kidney OR renal) NEAR/2 (allograft* OR alograft* OR transplant* OR homograft* OR graft*)
2 | Immunosuppressive drugs | ‘tacrolimus’/exp OR tacrolimus OR ‘cyclosporin’/exp OR cyclosporin OR ‘cyclosporine’/exp OR cyclosporine OR ‘ciclosporine’/exp OR ciclosporine OR ‘mustopic oint’/exp OR ‘mustopic oint’ OR ‘tsukubaenolide’/exp OR tsukubaenolide OR ‘cipol’/exp OR cipol OR ‘cyclokat’/exp OR cyclokat OR ‘deximune’/exp OR deximune OR ‘implanta’/exp OR implanta OR ‘immunosporin’/exp OR immunosporin OR imusporin OR ‘vekacia’/exp OR vekacia OR ‘prograf’/exp OR prograf OR ‘advagraf’/exp OR advagraf OR ‘hecoria’/exp OR hecoria OR ‘neoral’/exp OR ‘gengraf’/exp OR gengraf OR ‘astagraf’/exp OR astagraf OR ‘ol-27-400’ OR ‘CSA-neoral’ OR ‘cya-nof’ OR neoral
3 | Immunosuppressive drugs | ‘calcineurin inhibitor’/exp OR calcineurin NEAR/2 inhibit* OR ‘cni’
4 | Combine sets | 2 or 3
5 | Combine sets | 1 and 4
6 | Dose minimization | ‘low drug dose’/exp OR ‘dosage schedule comparison’/exp OR ‘treatment withdrawal’/exp OR ‘drug withdrawal’/exp OR ((low OR lower* OR reduce OR reduction OR minimize OR minimization OR minimal OR withdraw* OR avoid* OR eliminate* OR taper* OR alternative OR conversion) NEAR/4 (dose* OR dosing OR dosage* OR drug* OR calcineurin OR tacrolimus OR cyclosporine* OR ‘CNI’ OR strategy OR strategies OR regimen*))
7 | CNI alternatives (major concepts) | ‘rapamycin’/exp/mj OR ‘rapamycin’:ti OR ‘everolimus’/exp/mj OR ‘everolimus’:ti OR ‘alemtuzumab’/exp/mj OR ‘alemtuzumab’:ti OR ‘sotrastaurin’/exp/mj OR ‘sotrastaurin’:ti OR ‘tofacitinib’/exp/mj OR ‘tofacitinib’:ti OR ‘belatacept’/exp/mj OR ‘belatacept’:ti OR sirolimus:ti
8 | Combine sets | 5 AND (6 OR 7)
9 | Controlled trials filter | 8 AND (‘randomized controlled trial’/exp OR ‘randomized controlled trial’ OR ‘randomization’/exp OR ‘randomization’ OR ‘double blind procedure’/exp OR ‘double blind procedure’ OR ‘single blind procedure’/exp OR ‘single blind procedure’ OR ‘placebo’/exp OR ‘placebo’ OR ‘latin square design’/exp OR ‘latin square design’ OR ‘crossover procedure’/exp OR ‘crossover procedure’ OR ‘triple blind procedure’/exp OR ‘triple blind procedure’ OR ‘controlled study’/exp OR ‘controlled study’ OR ‘clinical trial’/exp OR ‘clinical trial’ OR ‘comparative study’/exp OR ‘comparative study’ OR ‘cohort analysis’/exp OR ‘cohort analysis’ OR ‘follow up’/exp OR ‘follow up’ OR ‘intermethod comparison’/exp OR ‘intermethod comparison’ OR ‘parallel design’/exp OR ‘parallel design’ OR ‘control group’/exp OR ‘control group’ OR ‘prospective study’/exp OR ‘prospective study’ OR ‘retrospective study’/exp OR ‘retrospective study’ OR ‘case control study’/exp OR ‘case control study’ OR ‘major clinical study’/exp OR ‘major clinical study’ OR ‘evaluation study’/exp OR ‘evaluation study’ OR random*:de OR random*:ti OR placebo* OR (singl* OR doubl* OR tripl* OR trebl* AND (dummy OR ‘blind’/exp OR blind OR sham)) OR ‘latin square’ OR isrctn* OR actrn* OR (nct* NOT nct))
10 | Systematic Review/Meta-analysis filter | 8 AND (‘research synthesis’ OR pooled OR ‘systematic review’/exp OR ‘systematic review’ OR ‘meta analysis’/exp OR ‘meta analysis’ OR ((‘evidence base’ OR ‘evidence based’/exp OR ‘evidence based’ OR methodol* OR systematic OR quantitative* OR studies OR search*) AND (‘review’/exp OR ‘review’ OR ‘review’/it)))
11 | Combine sets | 9 OR 10
12 | Remove unwanted publication types | 11 NOT ‘book’/exp OR ‘book’ OR ‘conference paper’/exp OR ‘conference paper’ OR ‘editorial’/exp OR ‘editorial’ OR ‘letter’/exp OR ‘letter’ OR ‘note’/exp OR ‘note’ OR book:it,pt OR ‘edited book’:it,pt OR ‘case report’:it,pt OR comment:it,pt OR conference:it,pt OR editorial:it,pt OR letter:it,pt OR news:it,pt OR note:it,pt OR proceeding:it,pt

Embase.com Syntax

* | = | truncation character (wildcard)
NEAR/n | = | search terms within a specified number (n) of words from each other in any order
NEXT/n | = | search terms within a specified number (n) of words from each other in the order specified
/ | = | search as a subject heading
exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
mj | = | denotes a term that has been searched as a major subject heading
:de | = | search in the descriptors field (controlled terms and keywords)
:lnk | = | floating subheading
:it,pt. | = | source item or publication type
:ti. | = | limit to title
:ti,ab. | = | limit to title and abstract fields

Table A-7 PUBMED (PreMEDLINE) for Key Question 1 and Key Question 3b

Set Number | Concept | Search Statement
1 | Kidney transplantation | (kidney OR renal) AND (allograft* OR alograft* OR transplant* OR homograft* OR graft* OR recipient*)
2 | Immunosuppressive drugs | tacrolimus OR cyclosporin OR cyclosporine OR ciclosporine OR “mustopic oint” OR tsukubaenolide OR cipol OR cyclokat OR deximune OR implanta OR immunosporin OR imusporin OR vekacia OR prograf OR advagraf OR hecoria OR gengraf OR astagraf OR “ol-27-400” OR “CSA-neoral” OR “cya-nof” OR neoral
3 | Immunosuppressive drugs | (calcineurin AND inhibit*) OR “cni”
4 | Combine sets | 2 or 3
5 | Combine sets | 1 and 4
6 | Immunoassay/Mass Spectrometry | immunoassay* OR “mass spectrometry” OR “high performance liquid chromatography” OR (mass AND spectrometr*) OR “gc-ms” OR “hplc-ms” OR “hplc” OR (fluorescence AND polarization) OR “fpia” OR “enzyme multiplied immunoassay” OR “emit” OR “enzyme linked immmunosorbent assay” OR “elisa” OR “microparticle enzyme immunoassay” OR “meia” OR (“liquid chromatography” AND “mass spectrometry”) OR “lc-ms” OR “antibody conjugated magnetic immunoassay” OR “ACMIA”
7 | Combine sets | 5 AND 6
8 | Remove unwanted publication types | 7 NOT (case reports[pt] OR comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])
9 | Limit to in process citations | 10 AND (“inprocess”[sb] OR publisher[sb] OR pubmednotmedline[sb])

Table A-8 PUBMED (PreMEDLINE) for Key Question 2

Set Number | Concept | Search Statement
1 | Kidney transplantation | (kidney OR renal) AND (allograft* OR alograft* OR transplant* OR homograft* OR graft* OR recipient*)
2 | Immunosuppressive drugs | cyclosporine OR cyclosporin OR cipol OR cyclokat OR deximune OR implanta OR imusporin OR vekacia OR ciclosporin OR “CsA-Neoral” OR “CyA-NOF” OR “Neoral” OR “OL 27-400”
3 | Combine sets | 1 AND 2
4 | Monitoring time points | ((“2”[tiab] OR two[tiab]) AND hour*) OR trough OR ((time OR “time point” OR timepoint* OR timing OR duration) AND cyclospor* AND level*) OR “c1”[tiab] OR “c0”[tiab] OR “c2”[tiab] OR “area under the curve” OR “time series”
5 | Combine sets | 3 AND 4
6 | Remove unwanted publication types | 5 NOT (case reports[pt] OR comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])
9 | Limit to in process citations | 6 AND (“inprocess”[sb] OR publisher[sb] OR pubmednotmedline[sb])

Table A-9 PUBMED (PreMEDLINE) for Key Question 3a

Set Number | Concept | Search Statement
1 | Kidney transplantation | (kidney OR renal) AND (allograft* OR alograft* OR transplant* OR homograft* OR graft*)
2 | Immunosuppressive drugs | tacrolimus OR cyclosporin OR cyclosporine OR ciclosporine OR “mustopic oint” OR tsukubaenolide OR cipol OR cyclokat OR deximune OR implanta OR immunosporin OR imusporin OR vekacia OR prograf OR advagraf OR hecoria OR gengraf OR astagraf OR “ol-27-400” OR “CSA-neoral” OR “cya-nof” OR neoral
3 | Immunosuppressive drugs | (calcineurin AND inhibit*) OR “cni”
4 | Combine sets | 2 or 3
5 | Combine sets | 1 and 4
6 | Dose minimization | (low[tiab] OR lower*[tiab] OR reduce[tiab] OR reduction[tiab] OR minimize[tiab] OR minimization[tiab] OR minimal[tiab] OR withdraw*[tiab] OR avoid*[tiab] OR eliminate*[tiab] OR taper*[tiab] OR alternative[tiab] OR conversion[tiab]) AND (dose*[tiab] OR dosing[tiab] OR dosage*[tiab] OR calcineurin[tiab] OR tacrolimus[tiab] OR cyclosporine*[tiab] OR “CNI”[tiab] OR strategy[tiab] OR strategies[tiab] OR regimen*[tiab])
7 | CNI Alternatives | rapamycin OR everolimus OR alemtuzumab OR sotrastaurin OR tofacitinib OR belatacept OR sirolimus
8 | Combine sets | 5 AND (6 OR 7)
9 | Remove unwanted publication types | 8 NOT (case reports[pt] OR comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])
10 | Limit to in process citations | 9 AND (“inprocess”[sb] OR publisher[sb] OR pubmednotmedline[sb])
11 | Controlled trials filter | 10 AND (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized controlled trials[mh] OR random allocation[mh] OR double-blind method[mh] OR single-blind method[mh] OR clinical trial[pt] OR clinical trials[mh] OR research design[mh:noexp] OR comparative study[pt] OR evaluation studies[pt] OR follow-up studies[mh] OR prospective studies[mh] OR cross-over studies[mh] OR meta-analysis[mh] OR meta-analysis[pt] OR outcomes research[mh] OR multicenter study[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask*[tw] OR blind*[tw])) OR “latin square” OR placebos[mh] OR placebo* OR random* OR “control group” OR prospective* OR retrospective* OR volunteer* OR sham OR “meta-analysis”[tw] OR cohort OR ISRCTN* OR ACTRN* OR NCT*)
12 | Systematic Review/Meta-analysis filter | 10 AND (meta-analysis OR meta-analysis[pt] OR ((evidence base* OR methodol* OR systematic* OR quantitativ* OR studies OR overview* OR search) AND review[pt]))
13 | Combine sets | 11 OR 12

PubMed Syntax

* | = | truncation character (wildcard)
[ti] | = | limit to title field
[tiab] | = | limit to title and abstract fields
[tw] | = | text word