# Abbreviations and Acronyms

AR: Acute Rejection
ABS: Affect balance scale
AUC: Areas under curve
AZA: Azathioprine
ATG/rATG: Anti-thymocyte globulin
BEL: Belatacept
BPAR: Biopsy proven acute rejection
BP: Blood Pressure
BK: Polyomavirus
CMV: Cytomegalovirus
CNI: Calcineurin Inhibitors
CsA: Cyclosporine A
CES-D: Center of epidemiological studies depression scale
CrCl: Creatinine Clearance
CAN: Chronic Allograft Nephropathy
DGF: Delayed Graft Function
EVR: Everolimus
FPIA/FPLA: Fluorescence polarization immunoassay
eGFR: Estimated glomerular filtration rate
GI: Gastrointestinal
GGT: Gamma glutamyltransferase
HBV: Hepatitis B
HDL: High Density Lipoprotein
HIV: Human Immunodeficiency Virus
HPLC: High performance liquid chromatography
IFTA: Interstitial fibrosis and tubular atrophy on kidney allograft biopsy
IA: Immunoassay
LC: Liquid Chromatography
LDL: Low Density Lipoprotein
MMF: Mycophenolate mofetil group
MPS: Mycophenolate Sodium
MS: Mass Spectrometry
MPA: Medroxyprogesterone acetate
NR: Not Reported
NA: Not Applicable
PRED: Prednisone
PRA: Panel Reactive Antibody
PCP: Pneumocystis carinii pneumonia
SIP: Sickness impact profile
SRL: Sirolimus
STER: Steroid
TAC: Tacrolimus
TACex: Patients receiving TAC without criteria to undergo intervention at month 3
UTI: Urinary tract infection