# Results

## Overview

This section is organized by type of treatment, following the general sequence of treatments as they occur in clinical practice, from nonsurgical (least to more invasive) to surgical. We planned to organize this section by etiologic subgroups, but that proved impossible because in most articles, FI etiologies were mixed and FI etiologies were inconsistently defined and reported, as is consistent with clinical difficulties in determining etiologic attribution in FI. Summary statements about the included studies are below; individual study details can be found in the report tables and appendices.

## Results of Literature Searches

We identified 2,978 unique citations (Figure 1) from all databases combined. We examined the full text of 192 articles to determine final inclusion. Of those, 117 studies were included in the review: 50 RCTs, 14 observational studies (OBS) with comparators, and 53 surgical case series. Thirty-eight randomized controlled trials (76%) assessed nonsurgical treatments; 12 assessed surgical interventions including sacral nerve stimulation. We found RCT evidence for one off-label tissue bulking agent (Durasphere®) that was not on our initial list of treatments.

Figure 1 Disposition of fecal incontinence studies identified for this review

Abbreviations:

AMED=Allied and Complementary Medicine Database

CINAHL=Cumulative Index to Nursing and Allied Health Literature

KQ1= Key Question 1

KQ2= Key Question 2

PEDro= Physiotherapy Evidence Database

PRO= Patient-reported Outcome

RCT=Randomized controlled trial

Figure 1 is a flow chart that outlines the citation retrieval and study selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria for this report. This figure is further described in the report section entitled, “Results of Literature Searches”. We identified 4,218 citations from all databases combined. 1,240 duplicates were excluded leaving 2,978 citations to review. Of those, 2,786 references were excluded for not meeting selection criteria on screening of titles and abstracts, leaving 192 articles that underwent full-text screening: 88 randomized controlled trials (RCTs), 42 observational studies and 62 surgical case series. Of those, 75 were excluded for not meeting selection criteria, leaving 115 unique studies from 117 articles that were included in this review: 50 RCTs, 14 observational studies and 53 surgical case series.

Due to variability in followup assessment timing, we considered outcomes evidence as short-term (less than 3 months), intermediate-term (3 to 6 months) or long-term (more than 6 months), (Appendix F, Table F2). Evidence tables in this report (Tables 2-17) and Appendix F provide detailed information about the included studies.

Table 2 KQ 1. Randomized controlled trial evidence for dietary fiber and dietary fiber supplementation for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Bliss, 2014^36^ Bliss, 2011^79^ used same sample as Bliss, 2014^36^, minus 17 | Compare fiber supplements | N=206 n=206 74% F; 58 y Not reported T: 38 d. FU: 38 d. | T_1_: carboxymethy-cellulose (CMC) (53) T_2_: gum arabic (50) T_3_: psyllium (54) C: placebo (49) | FI frequency/wk, amount, consistency, severity; FIQL | FI significantly decreased by 2.5 episodes per week with psyllium (vs. placebo) and increased 1.5 episodes per week with CMC. No differences in other outcomes. Sufficient power. | Low
Bliss, 2001^37^ | Compare fiber supplements | N=39 n=39 79% F; 61 y Not reported T: 31 d. FU: 31 d. | T_1_: psyllium (13) T_2_: gum arabic (13) C: placebo (13) | % incontinent, stool frequency, stool consistency, dietary intake | Tested between-group comparison at followup. Proportion of incontinent stools decreased most with gum arabic (48%) and psyllium (32%). No change in stool freq. Power not reported. | Moderate
Lauti, 2008^38^ | Does fiber supplement and loperamide improve FI over low residue diet and loperamide | N: 63 n: 47 91% F; 59 y Mixed T: 12 wk (6 + 6) FU: 6 wk, 12 wk | Crossover T: balanced fiber diet + fiber supplement + loperamide (32) C: low residue diet + placebo fiber + loperamide (31) | FISI, FIQL | Both groups improved. No significant difference in FISI improvement between treated vs. control (-13 vs. -12.4). FIQL largely unchanged. Sufficient power. | Moderate

C = Comparator/control; CMC = carboxymethy-cellulose; d = day; F = female; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FISI = Fecal Incontinence Severity Index; FU = Follow up T_1_ = Treatment group 1 T_2_ = Treatment group 2 T_3_ = Treatment group 3; wk = week; y = years

a Significant = statistically significant

Table 3 KQ 1. Randomized controlled trial evidence for topical phenylephrine (sphincter function enhancement drug) for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Park, 2007^40^ | Efficacy of 30% phenylephrine gel for FI after low anterior resection for rectal cancer | N=35 n=29 37% F; 60 y Postsurgical T: 4 wk FU: 4 wk | T: 30% topical phenylephrine (17) 2x/day C: placebo 2x/d (12) | FISI, FIQL, Global Efficacy | Phenylephrine did not improve FISI or FIQL scores. Subjective improvement in 29% treated (33% controls). Power not reported. Excluded post-randomization data from those with poor compliance. | High
Carapeti, 2000^41^ | Effectiveness of 10% topical phenylephrine in FI patients with IAS dysfunction | N=36 n=36 61% F; 58 y Not reported T: 4 wk each FU: 4 wk, 8 wk | Crossover, 1 wk. washout T: topical 10% phenylephrine gel (anus) 2x/d (36) C: placebo gel (36) | Vaizey score, subjective improvement | Vaizey improved 2 to 2.9 points from baseline, regardless of treatment period. No significant difference in mean improvement in Vaizey or subjective improvement in treated vs. placebo period by group. Sufficient study power. | Moderate
Carapeti, 2000^42^ | Effectiveness of 10% topical phenylephrine in FI patients with ileoanal pouch | N=12 n=12 58% F; 44 y Ileoanal pouch T: 4 wk each FU: 4 wk, 8 wk | Crossover, 1wk. washout T: topical 10% phenylephrine gel (anus) 2x/d (12) C: placebo gel (12) | Vaizey score, overall FI symptom score, self-rated improvement | Results reported for period 1 only due to significant treatment × period interaction. Significant improvement in mean Vaizey in treated vs. controls (6 vs. 0 points). FI symptoms lower when treated. Study likely underpowered. | High

C = Comparator/control; F = female; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FISI = Fecal Incontinence Severity Index; FU = Followup; IAS = internal anal sphincter; T = Treatment group; Vaizey = Vaizey Fecal Incontinence score; wk = week; y = year

a Significant = statistically significant

Table 4 KQ 1. Randomized controlled trial evidence for antidiarrheal drugs for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Sun, 1997^43^ | Effectiveness of loperamide oxide for chronic diarrhea with FI | N=11 n=11 73% F; 56 y Mixed T: 1 wk each FU: 2 wk, 4 wk | Crossover, 1wk run-in, washout T: loperamide 8mg/d (11) C: placebo (11) | FI episodes, % fully continent, stool frequency/consistency, urgency, FI severity, urgency, diarrhea, abdominal pain | Significantly more treated vs. placebo achieved continence and no diarrhea (65% vs. 27%), and had significant reduction urgency and stool frequency. Power not reported. | High
Hallgren, 1994^44^ | Effectiveness of loperamide HCl after proctocolectomy for ulcerative colitis | N=30 n=28 27% F; 38y Postsurgical T: 8 d each FU: 15 d, 30 d | Crossover, 1wk run-in, washout T: loperamide HCl 12mg/d (30) C: placebo (30) | Defecation frequency, need for night evacuation, soling daytime, soiling nighttime, use of pads, flatus release | Tested differences in outcome at followup; no baseline outcomes reported. Loperamide significantly decreased FI and pad use over placebo; no change in defecation frequency. Power not reported. | Moderate
Read, 1982^45^ | Effectiveness of loperamide for chronic diarrhea with FI and urgency | N=26 n=26 57% F; 45 y Mixed T: 1 wk each FU: 1 wk, 2 wk | Crossover, washout not reported T: loperamide 12mg/d (26) C: placebo (26) | FI episodes/wk; stool frequency, weight and consistency; urgency; improvement in FI and urgency | Tested differences in outcome at followup. Loperamide significantly decreased FI and urgency episodes, stool frequency and related outcomes over placebo; more reported improvement on drug. Power not reported. | Moderate
Palmer, 1980^46^ | Compare 3 drugs for chronic diarrhea (95% had urgency with FI) | N=30 n=25 % F NR; age NR Mixed T: 4 wk each FU: outcomes every 4 wk up to 12 wk | Crossover; used 3 wk data per period T_1_: loperamide HCl 2mg/d (30) T_2_: codeine phosphate 45mg/d (30) T_3_: diphenoxylate 5mg/d (30) | FI episodes, # of patients with FI, stool freq. and consistency, urgency episodes, dose/capsule consumption | Baseline data for urgency only. Not all outcomes were reported. Loperamide and codeine decreased number of patients with urgency more than diphenoxylate; all drugs decreased stool frequency. Power not reported. Analyzed completers only. | High

C = Comparator/control; d = day; F = female; FI = Fecal incontinence; FU = Followup; HCl = Hydrochloride; mg = milligrams; T = Treatment group; T_1_ = Treatment group 1 T_2_ = Treatment group 2 T_3_ = Treatment group 3; wk = week; y = year

a Significant = statistically significant

Table 5 KQ 1. Randomized controlled trial evidence for other drugs for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; FI Etiology; % Female; Mean Age; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Bharucha, 2014^47^ | Effectiveness of clonidine vs. placebo in women with FI | N=44 n=44 100% F; 58 y Mixed T: 4 wk FU: 4 wk | T: Clonidine 0.2mg/d (22) C: placebo (22) | FICA, FI count, days of FI, FIQL, FISI, satisfaction, rectal urgency, loperamide use | No significant difference between groups in FICA improvement (1.6 clonidine vs. 1.5 placebo) or other outcomes. Sufficient power. | Low
Pinedo, 2012^48^ | Compare Zinc-Aluminum ointment to anal submucosa vs. placebo for FI | N=50 n=44 % F NR; 61 y Not reported T: 1 mo FU: 1 mo | T: Zinc-aluminum ointment 3x/d (25) C:placebo (25) | CCFIS, FIQL | Significant CCFIS between-group improvement from baseline in treated vs. controls (-8.1 vs. -3.6), and all FIQL subscales. Underpowered study. Analyzed completers only. | Moderate
Pinedo, 2009^49^ | Compare topical estrogen vs. placebo for FI in postmenopausal women | N=36 n=35 100% F; 69 y Not reported T: 3x/d for 6 wk FU: 6 wk | T: Estrogen cream to anal submucosa (18) C: placebo (18) | CCFIS, FIQL | Both groups improved in CCFIS (-5 treated, -3 controls); between-group test not significant. Within-group FIQL improvements minimal in both groups. Sufficient study power. | Moderate
Kusunoki, 1990^50^ | Effectiveness of valproate sodium for FI after ileoanal anastomosis | N=17 n=17 24% F; 34 y Postsurgical T: 1 wk FU: 1 wk | Crossover, 3 d. washout T: Valproate sodium 1600mg/d (17) C: placebo (17) | FI count (soiling), stool frequency., perianal skin trouble | Tested within-group changes only: Greater reduction in FI soiling (9 vs. 2) and mean stool frequency. (4 vs. 0.4) during treatment vs. placebo period. Power not reported. | Moderate

C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; F = female; FI = Fecal incontinence; FICA = Fecal Incontinence and Continence Assessment; FIQL = Fecal Incontinence Quality of Life scale; FISI = Fecal Incontinence Severity Index; FU = Followup; mo = month; mg = milligrams; T = Treatment group; wk = week; y = year

a Significant = statistically significant

Table 6 KQ 1. Randomized controlled trial evidence for pelvic floor muscle training with biofeedback (PFMT-BF) versus standard care

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Damon, 2014^54^ | Does PFMT-BF plus standard care improve FI outcomes over standard care only? | N=157 n=92-142 varied 77% F; 61 y Mixed T: 4 mo. FU: 4 mo. | T: PFMT-BF (20 sessions) plus standard care (77) C: standard care= laxative, oral bulking agent, loperamide (80) | Treatment effectiveness (-5 to 5), CCFIS, FIQL, KESS, SF-12, symptom change | Differences between groups in opinion of treatment effectiveness, symptom change, CCFIS, KESS, FIQL, or SF-12 were not significant. Underpowered study. Analyzed completers only. | High
Norton, 2003^55^ | Does biofeedback (PFMT-BF, various modes) improve FI over standard care (advice on diet, drugs, bowel evacuation) | N=171 n=171 (ITT) 93% F; 56 y Mixed T: 3-6 mo. FU:6 mo., 1yr | T_1_: Hospital and home-based PFMT-BF plus advice (42) T_2_: Hospital-based PFMT-BF plus advice (49) T_3_: PFMT with DRF plus advice (43) C: standard care=advice (37) | Treatment effectiveness and rating thereof, Vaizey, Bowel Symptom Questionnaire, SF-36, FI counts/wk), HAD, quality of life (FI-unpublished) | Over half of patients improved; biofeedback was no better than standard care with advice. No differences between groups in functional outcomes. Quality of life, SF- 36, (vitality, mental, social) and HAD significantly improved. Sustained improvement at 1 yr. Sufficient power. | Moderate

BF = Biofeedback; C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; DRF = digital rectal feedback; F = female; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; HAD = Hospital Anxiety and Depression Scale; ITT = Intention-to-treat analysis; KESS = Knowles-Eccersley-Scott-Symptom Questionnaire for Constipation; mo = month; mg = milligrams; ms = microseconds; PFMT = Pelvic floor muscle training; SF-12 = Short-Form-12 health survey; SF-36 = Medical Outcomes Study Short-Form 36-item Health Survey; T = Treatment group; T_1_ = Treatment group 1 T_2_ = Treatment group 2 T_3_ = Treatment group 3; Vaizey = Vaizey Fecal Incontinence Score; wk = week; y = year

a Significant = statistically significant

Table 7 KQ 1. Randomized controlled trial evidence for pelvic floor muscle training with biofeedback (PFMT-BF) versus PFMT alone

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Heymen, 2009^56^ | Does PFMT-BF with intrarectal balloon improve FI outcomes over PFMT alone? | N=168 before 4 wk. run-in n=108 (3m, ITT) 77% F; 60 y Mixed T: 6 sessions/3mo FU: 3 mo; only those with adequate relief were followed to 1 y | T: PFMT-BF with intrarectal balloon (45) C:PFMT (63) [underlined: Both groups]: home PFMT 5x/d, educational intervention, and as needed fiber supplement and antidiarrheal drugs | FISI (3 mo change), FI days/wk, FIQL (3 mo), adequate relief, STAI-1, STAI-2, BDI | Significant difference in between-group improvements in FISI (no data), continence (44% vs. 21% control) and FI relief (76% vs. 41%) at 3 mo. FIQL similar in both groups; psychological scales unchanged. Underpowered study. Only those with adequate relief at 3 mo. (either group) were evaluated at 1 year. | Moderate
Whitehead, 1985^57^ | Does PFMT-BF (with rectal balloon) improve FI over PFMT alone? | N=13 n=13 77% F; 73 y Mixed (geriatric) T: 1+ mo (varied) FU: 6 mo, 12 mo | Crossover: all exercised for 1 mo, then crossover if FI persisted T:PFMT-BF C:PFMT | FI counts/wk | Exercise instruction alone did not decrease FI episodes but there was a significant reduction in FI counts in first 2 wk on biofeedback. Study power not reported | High

BDI = Beck Depression Inventory; BF = Biofeedback; C = Comparator/control; d = day; F = female; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FISI = Fecal Incontinence Severity Index; FU = Followup; ITT = Intention-to-treat analysis; m/mo = month; mg = milligrams; PFMT = Pelvic floor muscle training; STAI = State-trait Anxiety Inventory; T = Treatment group; wk = week; y = year

a Significant = statistically significant

Table 8 KQ 1. Randomized controlled trial evidence for PFMT-BF versus PFMT plus education

Author, Year | A | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Ilnyckyj, 2005^58^ | Does PFMT-BF with rectal balloon improve FI over PFMT plus education? | N=23 n=18 100% F; 59 y Idiopathic T: 5 wk FU: 5 wk | T:BF (RBT) with PFMT + FI education (7) C: PFMT + FI education (11) Initial n per group NR | % without FI | No significant difference in percent of patients without FI (86% treated vs. 45% control); no baseline for FI counts/wk. No sample size calculation. Analyzed completers only. | High

BF = Biofeedback; C = Comparator/control; F = Female; FI = Fecal incontinence; FU = Followup; NR = Not Reported; PFMT = Pelvic floor muscle training; RBT = Rectal Balloon Training; T = Treatment group; wk = week

a Significant = statistically significant

Table 9 KQ 1. Randomized controlled trial evidence for PFMT-BF versus PFMT with digital rectal feedback

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Bols, 2012^59^ | Does PFMT-BF with rectal balloon improve FI over PFMT (digital rectal feedback)? | N=80 n=80 (ITT) 90% F; 59 years Mixed T: 9 wk FU: 4.5 mo. (varied) | 12 sessions/9 wks: T: PFMT-BF plus rectal balloon (40) C: PFMT “alone” (with DRF) (40) PFMT 3x/d (home) | Vaizey (0-24); FIQL, GPE | No evidence for add-on benefit of RBT in PFMT; both groups improved. Difference in Vaizey not significant (treated -5.5 vs. controls -4.5); small improvement in other RBT outcomes. Underpowered study (106 needed). | Moderate
Solomon, 2003^60^ | Are PFMT-BF (TRUS) & PFMT-BF (AM) superior to PFMT-digital rectal feedback? | N=120 n=120 89% F; 62 years Neuropathic T: 4 mo. FU: 4 mo. | T_1_: PFMT-BF (TRUS) (40) T_2:_ PFMT-BF(AM) (39) C: PFMT (DRF) (41) | SMFIS(0-13), Pescatori, FI severity (patient, investigator), 0-10 quality of life | All groups had small improvements. No significant difference in mean improvement from baseline between groups for any outcome. Underpowered study. Analysis of completers likely. | High

AM = Anal Manometry; BF = Biofeedback; C = Comparator/control ; d = day; DRF = digital rectal feedback; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; GPE = Global Perceived Effect; ITT = Intention-to-treat analysis; mo = month; Pescatori = Pescatori Fecal Incontinence Score; PFMT = Pelvic floor muscle training; RBT = rectal balloon training; SMFIS = St. Mark's Fecal Incontinence Score; T = Treatment group; T_1_ = Treatment group 1 T_2_ = Treatment group 2; TRUS = Trans Rectal Ultrasound; Vaizey = Vaizey Fecal Incontinence Score; wk = week

a Significant = statistically significant

Table 10 KQ 1. Randomized controlled trial evidence for types of exercise used for PFMT-BF for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits)^a^ | Risk of Bias (inverse of quality)
Bartlett, 2011^61^ | Compare exercises: PFMT-BF (RBT) mixed exercise vs. PFMT-BF (RBT) sustained contraction | N=72 n=69 (2 m); 53 (2 y) 74% F; 62 y Mixed T: 5 sessions/2 mo FU: 2 mo., 2 y. | 5 sessions/8 wk T: PFMT-BF rapid & sustained contraction (35) C: PFMT-BF, sustained contraction (37) | CCFIS, FIQL, self-rated improvement | No significant difference between groups in CCFIS improvement at 2 m (-7 vs. -6.5), 2y (-8 vs. -7), or FIQL scales. Improvements maintained at 2 yrs. Sufficient power at 2 mo. | High

BF = Biofeedback; C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; mo = month; PFMT = Pelvic floor muscle training; RBT = Rectal Balloon Training; T = Treatment group; wk = week; y = year

a Significant = statistically significant

Table 11 KQ 1. Randomized controlled trial evidence for PFMT-BF with electrostimulation for fecal incontinence: comparison of frequencies

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Schwandner, 2011^62^ | Does PFMT-BF with medium freq estim improve FI over PFMT-BF with low freq estim)? | N=80 n=80 (ITT) 81% F; 63 y Mixed T: 6 mo. FU: 3 mo., 6 mo. | T: Estim (medium freq.) with PFMT-BF (39) C (41): Estim (low freq.) with PFMT-BF | CCFIS, adapted Vaizey (0-24), FIQL, ICIQ-SF, % complete responders | Significant improvement from baseline in treated vs. controls in CCFIS at 3 mo (-4 vs. 0) and 6 mo (-7 vs. -1); Vaizey, ICIQ-SF and FIQL had similar improvements. 54% complete responders in treated (vs. none). Sufficient power. | Moderate
Schwandner, 2010^63^ | Does PFMT-BF with medium freq estim improve FI outcomes over PFMT-BF with low freq estim)? | N=158 n=158 87% F; 63 y Mixed T: 9 mo. FU: 9 mo. | T: PFMT-BF(EMG) plus estim (79) C: PFMT-BF (EMG) (79) 2x/d, 20 min each | CCFIS (9 mo), Vaizey (9 mo); change in CCFIS, Vaizey at 3 m, 6 m; FIQL; % improved, therapy acceptance | Significantly greater median CCFIS improvement from baseline to 9 mo. in treated vs. controls (mean 2.5 points), 6 mo (2 points) and Vaizey (6 mo). No difference in FIQL between groups. Half of Results tables are per protocol analysis. Adults who deteriorated were analyzed no change group. Attrition 61% at 9 mo. | High

BF = Biofeedback; C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; d = day; EMG = Electromyographic; estim = Electrostimulation; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; freq = frequency; ICIQ-SF = International Consultation on Incontinence Questionnaire-Short Form; ITT = Intention-to-treat anal; min = minutes; mo = month; PFMT = Pelvic floor muscle training; T = Treatment group; Vaizey = Vaizey Fecal Incontinence Score; y = year

a Significant = statistically significant

Table 12 KQ 1. Randomized controlled trial evidence for PFMT-BF with electrostimulation versus PFMT-BF for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Naimy, 2007^65^ | Does PFMT-BF with estim improve FI over PFMT-BF? | N=49 n=40 100% F; 36 y Obstetric trauma T: 8 wk FU: 8 wk | T: PFMT-BF (EMG) plus estim (25) C: PFMT-BF (EMG) (24) | CCFIS, FIQL, reduced quality of life (0-10) | No significant difference between groups in CCFIS improvement (-1 both) or other outcomes. Excluded all data from drop-outs (18.4%) | Moderate
Mahoney, 2004^66^ | Does PFMT-BF (EMG) with estim improve FI over PFMT-BF (EMG)? | N=60 n=54 100% F; 34 y Obstetric T: 3 mo. FU: 3 mo. | T: PFMT-BF (EMG) plus estim.(20 min) 1x/w (30) C: PFMT-BF (EMG) 10 min 1x/w k (30) Both PFMT (home) | CCFIS, FIQL | Both groups improved. Estim with PFMT-BF did not improve outcomes more than PFMT-BF without estim (CCFIS -2 treated, -2.5 control; or FIQL). Completer analysis. | Moderate
Fynes, 1999^64^ | Does estim with PFMT-BF improve FI outcomes over PFMT-BF? | N=40 n=39 100% F; 32 y Obstetric trauma T: 3 mo. FU: 3 mo. | T: PFMT-BF (anal EMG) + estim 25 min/wk (20) C: PFMT-BF (vaginal EMG) 30 min/wk (20) Both PFMT (home) | Modified Pescatori (0-20?), % asymptomatic | Significant difference in improvement in modified Pescatori between treated and controls (-10 vs. -3). Treatment protocols and therapists differed by group. Power not reported. | Moderate

BF = Biofeedback; C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; EMG = Electromyographic; Estim = Electrostimulation; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; mo = month; Pescatori = Pescatori Fecal Incontinence Score; PFMT = Pelvic floor muscle training; T = Treatment group; wk = week; y = year

a Significant = statistically significant

Table 13 KQ 1. Randomized controlled trial evidence for electrostimulation (without PFMT) for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Norton, 2006^67^ | Does home-based estim without PFMT improve FI over sham home-based estim? | N=90 n=90 (ITT) 90% F; 55 y Idiopathic T: 2 mo. FU: 2 mo. | T: estim 35Hz 20 min/d × 3w, then 40 min/d × 5w (47) C: same protocol but 1Hz estim (43) | Symptom change outcome rating, FI counts/w, 0-10 of bowel control and satisfaction, effectiveness | No significant difference between groups in any outcome measure. Low treatment compliance: only 25% of treated used estim for 20 h or more (protocol= 34 h). Underpowered study (98 needed) | Moderate
Healy, 2006^68^ | Does home-based low-freq. endoanal estim without PFMT improve FI over (hospital-based mixed estim treatment? | N=58 n=38 CCFIS; n=48 other outcomes. 100% F; 54 y Idiopathic T: 3 mo. FU: 3 mo. | T: Estim at home 1h/d (23) C: 30 min. hospital based, 3/wk (25): 1. estim-BF with muscle contraction 15 min 1x/wk 2. estim 15 min. 2x/wk | CCFIS, SF-36 | Within-group analysis: Similar CCFIS improvement in treated (-4.4) and controls (-5.5). SF-36 improved in both. Power not reported. Sparse sample data (in text). Aim was a care site comparison but treatments differed in duration and protocol. Analyzed completers only. | High

C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; d = day; Estim = Electrostimulation; FI = Fecal incontinence; FU = Followup; h = hour; Hz = Hertz; ITT = Intention-to-treat analysis; min = minute; mo = month; SF-36 = Medical Outcomes Study Short-Form 36-item Health Survey; PFMT = Pelvic Floor Muscle Training; T = Treatment group; wk = week; y = year

a Significant = statistically significant

Table 14 KQ 1. Randomized controlled trial evidence for interventions to manage fecal incontinence in adults with spinal cord injury

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Christensen, 2006^70^ | Compare transanal irrigation to best supportive care | N=87 n=79-87 (ITT) 28% F; 49 y Spinal cord injury T: 10 wks. FU: 10 wks. | T: Transanal irrigation 1x/d then every 2 d or less C: bowel care every 2 d, diet, exercise, stool modifying drugs | CCCS, Vaizey, modified FIQL, neurogenic bowel dysfunction score (NBDS); satisfaction, bowel function, daily activities | Tested mean differences between groups at termination; baseline comparability not tested. Irrigation significantly better than control on CCCS, Vaizey, NBDS, most other outcomes. 29% of treated discontinued study (4% controls). Sufficient power. | Moderate
Coggrave, 2010^71^ | Does stepwise intervention improve bowel management & reduce FI over usual care? | N: 68 n: 68 (ITT) 34% F; 47 y Spinal cord injury T: 6 wk FU: 6 wk | T: Stepwise intervention (7 steps, least to most invasive) (35) C: Usual bowel management (33) | Duration and level of intervention, FI frequency, time to stool, minimum level of effective intervention | Stepwise intervention did not improve outcomes or the need for invasive bowel management interventions. FI was significantly more frequent in the treatment group. Underpowered study. | High

C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; d = day; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; ITT = Intention-to-treat analysis; NBDS = neurogenic bowel dysfunction score; T = Treatment group; Vaizey = Vaizey Fecal Incontinence Score; wk = week; y = year

a Significant = statistically significant

Table 15 KQ 1. Randomized controlled trial evidence for interventions to manage fecal incontinence in older adults in nursing homes

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Schnelle, 2010^73^ | Evaluate a multicomponent intervention on UI and FI in nursing home residents | N: 125 n: 112 83% F; 86 y Mixed T: 12 wk FU: 12 wk | T: toileting assistance, exercise, choice of food, fluid and snacks) 5d/wk (65) C: Usual care (60) | FI counts/d, bowel movements/d, fecal toileting percentage | Frequency of FI did not change with intervention but physical activity, freq. of toileting and food and fluid intake significantly improved. FI difficult to analyze; 45% of residents did not have a bowel movement during baseline or 10 d post-intervention. | High
Schnelle, 2002^72^ | Assess benefits of an exercise and incontinence intervention in nursing home residents | N: 190 n: 148 (FI outcome) 83% F; 88 y Not reported T: 32 wk FU: 2 mo 8 mo | T: 4x/d prompted toileting, exercise, fluids (5d/wk) (94) C: No intervention (96) | FI freq (% of checks w/FI), UI freq, fecal and urine toileting ratio, strength and endurance | Significant reduction in FI freq in treated vs. control (4% vs. 1%) at 8 mo (2 mo not reported); significant improvements in all other measures for treated. Power not reported | High

C = Comparator/control; d = day; FI = Fecal incontinence; FU = Followup; freq = frequency; mo = month; T = Treatment group; UI = Urinary Incontinence; wk = week; y = year

a Significant = statistically significant

Table 16 KQ 1. Randomized controlled trial evidence for percutaneous tibial nerve versus sacral nerve stimulation

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Thin 2015^74^ | Compare PTNS with SNS | N=40 n=31 98% F; 59 y Mixed T: 5 mo (PTNS) FU: 3 mo., 6 mo. | T: PTNS 15 sessions (12 in 3 mo, + 3 over 2 mo.) (16) C: SNS (15) | FI episodes, CCFIS, SF-36, EQ-5D; qualitative interview | Reported within-group changes from baseline; no statistical tests were conducted. Groups differed at baseline on important variables. By 6 mo.,FI episodes (4 to 9 per wk.) and CCFIS (3 to 7 points) improved in both groups but SNS improved more. Minimal change in FIQL and EQ-5D. Excluded post-randomization data on 23% of sample. | Moderate

C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; EQ-5D = EuroQoL Questionnaire-5 Dimensions; FI = Fecal incontinence; FIQL-Fecal Incontinence Quality of Life scale; FU = Followup; mo = month; PTNS = percutaneous tibial nerve stimulation; SF-36 = Medical Outcomes Study Short-Form 36-item Health Survey; SNS = sacral nerve stimulation; T = Treatment group; UI = Urinary Incontinence; y = year

a Significant = statistically significant

Table 17 KQ 1. Randomized controlled trial evidence for injectable tissue bulking agents for fecal incontinence

Author, Year | Study Aim | N Randomized, n Analyzed; % Female; Mean Age; FI Etiology; Treatment and Followup Duration | Study Groups (n per group) | Patient-Reported Outcomes (primary outcome bolded if known) | Reported Results (benefits) a | Risk of Bias (inverse of quality)
Dehli, 2013^75^ | Determine if tissue bulking injections with dextranomer superior to PFMT-BF (plus estim if needed) for FI | N: 126 n: 119 (6 mo) 93% F; 57 y Mixed T: 6 mo control FU: 6 mo. | T: Dextranomer in hyaluronic acid (4 × 1mL injections to anal submucosa); repeat 1× if needed (64) C: PFMT-BF plus estim if needed × 6 sessions/6 mo (62) | Vaizey ( 0-24), FIQL, EQ-5D | No significant difference between groups in Vaizey improvement to 6m (-4.6 points dextranomer vs. -5.4 points PFMT-BF); between group change in FIQL at 6 months not significant; EQ-5D not reported. Sufficient power. Dismissed 44% of sample at 6 months for observational study of successes. | Low
Graf, 2011^76^ | Does anal canal injection of dextranomer in hyaluronic acid improve FI over sham injection? | N=206 n=197 (6 mo) 89% F; 61 y Mixed T: Injections (1 d); repeat in 1 mo if CCFIS >10 FU: 3 mo, 6 mo | T: Total of 4-8 ml dextranomer injections in four quadrants of anal submucosa (136) C: Sham injections (nothing injected) (70) | FI counts/wk (50% or more reduction from baseline) CCFIS, FIQL, number of FI-free days, decrease in FI episodes | Significant difference in 50% or more reduction in FI episodes/wk in treated (52%) vs. controls (31%) at 6 mo. No differences between groups in CCFIS at 3 mo or 6 mo. FIQL and FI-free days better in treated at 6 mo. Sufficient power. Only followed treated group after 6 mo. | Low
Morris, 2013^78^ | Compare bulking agents: Durasphere® (off-label) vs. PTQ™ (non-FDA approved) | N=35 n=34 % F NR; 66 y Not reported T: 1 d FU: 6 wk, 6 mo, 1 y | T_1_: Durasphere®: perianal injection (18) T_2_: PTQ™ (not-FDA approved) (17) | CCFIS, SF-36 | [underlined: Durasphere® only]: Improvement in mean CCFIS was 5.3 points at 6 wks., 4.1 at 6 mo., and 1.8 at 1 y. No significant change in SF-36 at any time. Trial underpowered due to early closure of study (from high cost of PTQ™ per authors) | Low
Tjandra, 2009^77^ | Compare bulking agents: Durasphere® (off-label) vs. PTQ™ (non-FDA approved) | N=40 n=40 90% F; 59 y Mixed T: 1 day FU: 2 wk, 6 wk, 6 mo, 1 y | T_1_: Durasphere®: perianal injection (20) T_2_: PTQ™ (not-FDA approved) (20) | CCFIS, FIQL, SF-12 | [underlined: Durasphere® only]: Improvement in mean CCFIS was 3.2 points at 2 wk, 3.8 at 6 wk, 5.3 at 6 mo, and 4.5 at 1 y. No significant change in SF-12 at any time point. Adequate study power. | Low

BF = Biofeedback; C = Comparator/control; CCFIS = Cleveland Clinic Fecal Incontinence Score; d = day; EQ-5D = EuroQoL Questionnaire-5 Dimensions; Estim = Electrostimulation; FI = Fecal incontinence; FIQL = Fecal Incontinence Quality of Life scale; FU = Followup; FDA = Food and Drug Administration; mo = month; ml = milliliter; PFMT = Pelvic floor muscle training; PTQ™ = injectable bulking agent not FDA approved for use in the U.S.; SF-12 = Short-Form-12 health survey; SF-36 = Medical Outcomes Study Short-Form 36-item Health Survey; T = Treatment group; T_1_ = Treatment group 1; T_2_ = Treatment group 2; Vaizey = Vaizey Fecal Incontinence Score; wk = week; y = year

a Significant = statistically significant

Evidence of publication bias was identified from the information we reviewed in Scientific Information Packets received from industry, and by examining clinicaltrials.gov

## KQ 1 What is the comparative effectiveness of treatments to improve quality of life and continence and lessen the severity of fecal incontinence in affected adults?

Included studies are listed under Nonsurgical or Surgical headings below, and listed by the type of intervention in the approximate order that they might be used in clinical practice. We did not find RCT or OBS with comparison groups for anal plugs, antegrade colonic irrigation (ACE), or radiofrequency anal sphincter remodeling (SECCA).

Nearly two-thirds (62%) of RCTs enrolled adults with mixed FI etiologies, while 20 percent of RCTs did not report FI etiology (Appendix F, Table F3). FI severity at baseline was inconsistently reported and varied widely per study inclusion criteria.

The mean age of enrolled adults was 55 to 65 years in 62 percent of 37 nonsurgical RCTs that reported age, and 75 percent of surgical RCTs. Females comprised 81 percent of enrolled adults in 35 nonsurgical RCTs (Tables 2-17) and 95 percent of adults in 11 surgical RCTs (Appendix F, Table F4) that reported patient sex, but these proportions varied by FI etiology and type of intervention.

### Nonsurgical Treatments

#### Key Points

- Low-strength evidence suggests that dietary fiber supplementation with psyllium decreases FI frequency by 2.5 occurrences per week after 1 month of use; clonidine has no effect; and PFMT-BF with electrostimulation is no more effective than PFMT-BF on FI severity and the FI Quality of Life Scale (FIQL) scores over 2 to 3 months.
- Low-strength evidence at 6 months suggests that dextranomer tissue-bulking injections are more effective than sham injections on the FIQL, number of FI-free days, and percent of adults with at least 50 percent reduction from baseline in FI episodes; no more effective than PFMT-BF with or without electrostimulation on FI severity (PFMT-BF -5.4 versus dextranomer -4.6 point Vaizey improvements) and FIQL; and no more effective than sham injection on FI severity (-2.5 versus -1.7 point sham CCFIS improvement) or FI episode frequency. (See Appendix E for FI outcome measures)
- Moderate-strength evidence suggests that Durasphere® (off-label) bulking injections reduce FI severity (-4 to -5 points in CCFIS) up to 6 months, but gains diminish thereafter.
- Evidence is insufficient for PFMT-BF versus standard care (such as dietary fiber and stool-modifying drugs); all other PFMT studies assessed refinements in treatment delivery by comparing PFMT to another variation of PFMT.
- Evidence was insufficient for all other nonsurgical interventions.
- In most cases, short-term outcomes improvements in both treated and active controls met minimum clinically important differences (MID) when those values were known (usually 2 to 6 points, various scales, Appendix E); studies that claimed greater improvements typically excluded nonresponders, noncompleters, or those not fully compliant with study protocols.
- The wide range of outcome measures limited comparability across studies.
- Most nonsurgical RCTs (84%) had moderate or high risk of bias.
- Incomplete reporting of baseline patient information and FI etiologies was common.
- Most evidence was short term (Appendix F, Table F2).

##### Dietary Fiber

The evidence for dietary fiber and fiber supplementation in FI is exclusively short term (up to 3 months (Table 2). Two RCTs36,37 assessed the 31 day and 38 day effects of various dietary fiber supplements on FI frequency, and stool frequency and consistency. Low-strength evidence36 suggests that dietary fiber supplementation with psyllium reduces FI frequency by 2.5 occurrences per week and has no effect on FI quality of life as measured with the FIQL.36

Evidence was insufficient for other outcomes, including one moderate risk of bias RCT that found no added benefit of dietary fiber in addition to loperamide on FI severity and the FIQL over 3 months38 (Table 2). Evidence was insufficient for methylcellulose plus loperamide versus no treatment39 (Appendix F, Table F5).

##### Pharmacological Treatments

Drug studies were exclusively short term (1 to 6 weeks) and most were 1 month in duration. The effectiveness of oral and topical medications for FI was examined in 11 RCTs: three of topical phenylephrine versus placebo40-42 (Table 3), four of antidiarrheal medications43-46 (three versus placebo, one with active comparators, Table 4), and four studies of other medications47-50 (all versus placebo, Table 5). Low-strength evidence suggests that oral clonidine has no effect on FI severity as measured with the FI and Constipation Assessment (FICA).47 Evidence was insufficient for loperamide,43-46 topical phenylephrine (10%^41,42^ and 30%^40^), zinc-aluminum ointment,48 estrogen cream,49 and valproate sodium.50

##### Pelvic Floor Muscle Training and Adjunctive Modalities

Pelvic floor muscle training using biofeedback (PFMT-BF) was the most frequently studied intervention in the literature we reviewed; 16 studies (13 RCTs and 3 OBS51-53) assessed the effects of PFMT-BF with or without electrostimulation on the outcomes of FI frequency and severity, quality of life (general and FI-specific, the FIQL), and perceived improvement (Tables 6-12 and Appendix F, Table F5).

We found insufficient evidence for PFMT-BF versus standard care (such as dietary fiber, stool-modifying drugs, and/or advice, Table 6 and Appendix F, Table F5). The definition of standard care varied across studies. Only two RCTs54,55 (Table 6) with moderate55 and high54 risk of bias assessed the benefit of PFMT-BF versus standard care, and one high risk of bias observational study53 (Appendix F, Table F5) examined PFMT-BF plus standard care versus standard care alone. Most of the literature focused on ways to improve or prolong the purported benefits of PFMT for FI by comparing PFMT to another variation of PFMT,56-66 rather than to establish the benefits of it. Only two RCTs used PFMT alone as a control56,57 (Table 7); all other studies (Tables 8-12) assessed refinements in PFMT delivery by testing one form of PFMT against another, including PFMT plus FI education58 (Table 8), biofeedback sensor comparisons59,60 (Table 9), exercise comparisons61 (Table 10), electrostimulation frequency comparisons62,63 (Table 11), electrostimulation to augment PFMT-BF64-66 (Table 12), or examined the mode of training delivery (by phone or in-person) on outcomes51 (Appendix F, Table F5). Risk of bias was moderate to high in all PFMT studies.

We found low-strength evidence that PFMT-BF with electrostimulation is no more effective than PFMT-BF on FI severity and FI quality of life (FIQL).65,66 Evidence was insufficient for all other PFMT comparisons.51,52,56-64

PFMT-BF was associated with improvements in FI outcomes (usually 2 to 6 points, various scales) in most studies, but improvements did not differ significantly from those of the comparison group. Most PFMT RCTs reported 3 to 6 month outcomes (Appendix F, Table F2); only four studies reported outcomes for randomized patients beyond 6 months.55,57,61,63

##### Anal Electrostimulation

Evidence was insufficient for home-based anal electrostimulation without PFMT versus home-based sham stimulation on symptoms and FI severity,67 and for home-based electrostimulation versus hospital-based therapy68 in the short term (Table 13). The extremely low compliance with home-based electrostimulation in one RCT67 (only 25 percent of the treatment group used the stimulator at least 20 of the 34 protocol-recommended hours) suggests that home-based stimulator use for FI may not be an acceptable option to patients, even if it worked.

##### Rectal Irrigation

Evidence was insufficient for rectal irrigation versus a non-FDA approved injectable bulking agent for mixed FI etiologies from one study69 (Appendix F, Table F5).

##### Mixed Nonsurgical Interventions

Mixed interventions were primarily assessed for two groups of adults: older adults residing in nursing homes and adults with spinal cord injuries (SCI). Both groups may deal with FI, constipation, or both. The goal of bowel management is to minimize extremes and maintain bowel regularity.

Two RCTs focused on bowel management interventions for adults with SCI70,71(Table 14). Females comprised 31 percent of enrolled adults; the overall median age was 48 years. One moderate risk of bias study found that transanal irrigation improved bowel and FI outcomes more than supportive, guidelines-based care over 10 weeks.70 One high risk of bias study reported that a 6-week step-wise, increasing intensity bowel management program worsened FI outcome.71

In contrast, two high risk of bias RCTs assessed staff-directed interventions for FI and bowel issues in nursing home residents with mixed results (Table 15). Females comprised 83 percent of enrolled residents; the overall mean age was 87 years. Both interventions focused on multiple factors affecting bowel regularity, including aspects of diet, fluids, activity, and care. One RCT found significant reductions in FI frequency with prompted toileting four times per day, exercise and increased fluid offering 5 days per week.72 The other RCT was a multicomponent intervention for UI and FI, which did not affect FI frequency.73

##### Posterior Tibial Nerve Stimulation

Percutaneous posterior tibial nerve stimulation (PTNS) is not FDA approved for FI but is currently being studied as a nonoperative off-label treatment option, especially prior to considering permanent SNS (www.clinicaltrials.gov). One small, moderate risk of bias RCT (Table 16) examined the effects of PTNS versus SNS on FI episodes and the CCFIS.74 The evidence for PTNS is insufficient.

##### Anal Sphincter Tissue-Bulking Injections

Four low risk of bias RCTs (Table 17) examined anal sphincter tissue-bulking injections: two RCTs of dextranomer,75,76 which is FDA-approved for FI, and two of an off-label injectable, Durasphere®77,78 (FDA-approved for urethral bulking for urinary incontinence).

Low-strength evidence at 6 months post-treatment suggests that dextranomer tissue-bulking injections are no more effective than PFMT-BF with or without electrostimulation on FI severity and FI-related quality of life as measured by the FIQL.75

Low-strength evidence at 6 months post-treatment suggests that dextranomer tissue-bulking injections are more effective than sham injections on FI quality of life (FIQL scale), the number of FI-free days, and in reducing FI episodes 50 percent or more from baseline over 6 months, but no more effective than sham injection on FI severity (CCFIS) and FI episode frequency.76

Durasphere® (off-label) anal sphincter injections improved FI severity (CCFIS) by several points shortly after injections, but gains diminished slightly between 6 months and 1 year.77,78 Both studies used a non-FDA approved comparator (PTQ™).

### Surgical Treatments

This section includes RCT and OBS studies on surgical treatments for FI including surgically-placed SNS, and combined surgical and nonsurgical treatments. We found only case series studies for SECCA and ACE in adults; those studies are discussed under KQ 2 only.

#### Key Points

- Evidence is insufficient for all surgical interventions for FI. Few surgical treatments were examined in RCTs or OBS studies; aims and treatments were highly varied and all surgical studies had moderate to high risk of bias.
- The overwhelming majority of surgical studies are case series (low quality evidence).
- Evidence is insufficient for SNS versus supportive care for FI up to 1 year; for turning the stimulator on versus having it off on FI severity and frequency in newly-implanted patients; for stimulation at 75 percent or 50 percent of sensory threshold versus stimulation at sensory threshold; for high-frequency, low prolonged pulse width stimulation to regain efficacy in persons with sustained loss of efficacy after chronic stimulation; and for turning stimulation off versus leaving it on during the night on FI outcomes.
- Surgical outcomes, in general, were reported for longer term followup than for nonsurgical interventions.
- In half of the RCTs where MID was known, outcomes improvements with treatment and sometimes control interventions met or exceeded MID in intermediate-term outcomes (CCFIS, Appendix E), although adults with complications or those lost to follow-up were omitted from half of those analyses.
- Articles commonly lacked important baseline information (such as patient characteristics, FI etiologies and outcomes at enrollment). In particular, SNS studies included minimal nonphysiologic patient information.

#### Sacral Nerve Stimulation (SNS)

Surgically placed SNS is used when conservative measures have failed to afford the desired level of fecal continence. There are two main limitations of SNS: (1) the stimulator battery has a limited lifetime and needs to be surgically replaced within the stimulator approximately every 5 years and (2) the nervous system adapts to stimulation over time which may result in the loss of efficacy on FI in some adults. Only one RCT80 assessed the effectiveness of SNS with the stimulator on versus off in newly implanted patients; more recent studies focused on the maintenance of SNS battery life while maintaining continence effects,81,82 measures to regain SNS efficacy that was dwindling,83 and the comparison of SNS to best supportive care.84 All SNS RCTs were crossover studies (Appendix F, Table F4) that almost exclusively enrolled adult females approximately 60 years old with mixed FI etiologies.

The evidence for SNS is insufficient because all five studies had moderate or high risk of bias, and none assessed the same treatment-outcome combination. Evidence is insufficient to compare the effectiveness of SNS versus supportive care on FI outcomes up to 1 year;84 the effects of turning the stimulator on versus off on FI severity and frequency in newly-implanted patients;80 stimulation at 75 percent or 50 percent of sensory threshold versus stimulation at sensory threshold;81 high-frequency, low prolonged pulse width stimulation to regain efficacy in persons with sustained loss of efficacy after chronic stimulation;83 and turning stimulation off versus on at night on FI outcomes.82

Observational studies provided insufficient evidence for SNS versus sphincteroplasty85 (Appendix F, Table F5) and open versus percutaneous lead placement86 (Appendix F, Table F5).

#### Anal Sphincter Repair (Sphincteroplasty)

Surgical repair of the anal sphincter is performed for adults with FI resulting from anal sphincter tears that have accompanying moderate to severe FI and have suboptimal resolution with conservative treatment. Only two RCTs87,88 (Appendix F, Table F4) and five observational studies85,89-92 (Appendix F, Table F5) examined sphincteroplasty.

Observational studies (Appendix F, Table F5) provided insufficient evidence to compare the effectiveness of sphincter repair with stoma (fecal diversion) versus sphincter repair alone;87 adjuvant biofeedback following anal sphincter repair versus sphincter repair alone;88 a perineal versus a posterior forchette incision in overlapping anal sphincter repair;89 sphincteroplasty with pelvic floor repair versus sphincteroplasty;90 anal sphincter repair versus SNS;85 sphincteroplasty versus anterior levatorplasty;91 and direct versus anterior sphincter repair.92

#### Anal Sphincter Replacement

Evidence was insufficient (Appendix F, Table F5) to compare the effectiveness of the artificial bowel sphincter (ABS) versus conservative medical management from one RCT of 14 patients with severe FI,93 and for the ABS versus a non-FDA approved magnetic anal sphincter94).

#### Other Surgeries and Mixed Treatment Comparisons

Appendix F, Tables F4 and F5 include other surgical studies and mixed treatment comparisons. Evidence was insufficient to compare the effectiveness of total pelvic floor repair versus gluteus maximus transposition without electrical stimulation for postobstetric neuropathic FI;95 postanal repair versus total pelvic floor repair for neurogenic FI;96 and total pelvic floor repair versus anterior levatorplasty versus postanal repair for neurogenic FI.97

Evidence was insufficient for levatorplasty surgery versus nonsurgical anal plug electrostimulation98 and for SNS versus a non-FDA approved surgery (magnetic sphincter).99

Evidence was insufficient for recommendations after failed sphincteroplasty.100 Only one high risk of bias observational study compared the outcomes of three surgical treatments used in adults who had at least one prior sphincteroplasty with unsatisfactory outcomes.100 (Appendix F, Table F5).

## KQ 2 What adverse effects are associated with specific treatments for adults with fecal incontinence?

### Key Points

- Few nonsurgical RCTs reported adverse effects (AEs). When reported, less invasive nonsurgical treatments had few AEs that were minor.
- Surgical interventions were associated with more frequent and more severe complications than nonsurgical interventions.
- AEs increased as the treatment invasiveness increased and were highest for surgical procedures, especially the artificial bowel sphincter
- Most surgical AEs were identified from surgical case series studies.
- Adverse effects from surgical case series had longer followup than other designs.

### Nonsurgical Treatments

Twenty-five of 38 nonsurgical RCTs included adverse effects (AE) reporting, and AEs occurred in 17 of those 25 RCTs (Appendix F, Table F6). Three nonsurgical OBS studies (Appendix F, Table F7) also reported on AEs. Six additional RCTs reported that no AEs occurred (three PFMT, three drug studies). AEs were generally mild and varied by the type of intervention; the frequency of AEs was variably reported (overall, by group or only identified in text). Gastrointestinal symptoms occurred with fiber supplements in 5 percent39 to 20 percent36 of patients. Oral medications used for FI were most commonly associated with nausea and abdominal pain. Nonserious AEs of abdominal pain, headache, and nausea were reported for 55 percent of adults treated with 8mg of loperamide per day in one RCT;43 no adverse effects at 12mg/day in another RCT;44 and abdominal pain, headache, and nausea and vomiting in 69 percent of patients on 12mg in another RCT.45 No adverse effects occurred in PFMT-BF studies that reported them. PFMT-BF with electrostimulation at low frequency caused pain in 50 percent of patients in the control group but no pain in the high-frequency treatment group.62 Electrostimulation without PFMT caused discomfort in 9 percent of patients.67 No AEs occurred with rectal irrigation in adults with passive FI.69 However, bursts of the rectal balloon during rectal irrigation occurred in one in every three adults with spinal cord injuries;70 abdominal distention and hospitalization for severe constipation occurred infrequently in these adults.70 Repeated expulsion of the rectal catheter during irrigation was common in adults with SCI.70 No serious AEs occurred with PTNS, although 6 percent experienced transient pain or paresthesias.74

In general, placebo or comparison group AE rates varied widely but were less frequent (none to half of treatment rates) and less severe than treatment group AEs (Appendices F6 and F7).

Tissue bulking injections had the highest proportion and variety of complications of the nonsurgical treatments (Appendix F, Table F6). Reported in aggregate, 25 percent of patients treated with dextranomer in hyaluronic acid experienced leakage of the injected agent, infection, or prolonged defecation over 6 months.75 A dextranomer versus sham study76 reported treatment complications of proctalgia (14%), rectal hemorrhage (7%), diarrhea (5%), constipation (2%), injection site bleeding (5%), rectal discharge (4%), anal pruritus (2%), proctitis (3%), painful defecation (2%), fever (8%), other (16%) versus sham (injection site bleeding [17%]), and other minor effects in 1-7 percent of patients. Durasphere® tissue bulking injections were associated with no AEs in one study78 but another study reported local bruising (20%), erosion through the rectal mucosa (10%), and rectal pain or hypersensitivity reaction in 5 percent of patients.77

### Surgical Treatments

Adverse effects from surgical treatments were reported in eight OBS (Appendix F, Table F7), seven RCTs (Appendix F, Table F8), and 53 case series studies (Appendix F, Table F9). Surgical complications were common and ranged from minor (swelling, hematoma) to major (infection, bowel obstruction, perforation, fistula); major complications often required reoperation; some required a permanent colostomy.

The frequency of surgical complications ranged from 0-32 percent in SECCA;101-106 21-74 percent in ACE;107-110 5-27 percent with sphincter repair;87,89-92,100,111-119 2-93 percent with SNS;74,80,84,86,99,100,120-138 8-64 percent with other surgeries;95,97,98,139 and 22-100 percent with sphincter replacement.93,94,100,140-153

The severity of adverse effects varied by the type of surgery (Appendix F, Tables F7-F9). Adverse effects were generally less severe for SECCA (pain, bleeding, swelling, mucosal ulceration) and SNS (infection, pain, electrode/lead issues, device malfunction). However, SNS required reoperation in 3 percent to 41 percent of patients for device-related complications, and 3 percent to 24 percent of SNS patients had the device explanted. ACE, sphincter repair and sphincter replacement had the most severe complications (wound infection, stenosis, bowel obstruction, sepsis, leak, and fistula). The most frequent and severe complications occurred with sphincter replacement with an artificial bowel sphincter: infections were very common and 14 percent to 81 percent of recipients underwent surgical explant of the device and either replaced (most often) or treated with colostomy (less often).