# References

1 International Continence Society (ICS). Faecal Incontinence - ICS Fact Sheets July 2013. 2013. 4/18/14. Available at: www.ics.org/Documents/Documents.aspx?FolderID=82.
2 Whitehead WE, Borrud L, Goode PS, et al. Fecal incontinence in US adults: epidemiology and risk factors. Gastroenterology. Aug. 2009;137(2):512-7. 7 e1. 2. [pmid: 19410574].
3 NIH state-of-the-science conference statement on prevention of fecal and urinary incontinence in adults. NIH Consens State Sci Statements. Dec. 12-14. 2007;24(1):1-37. [pmid: 18183046].
4 Shamliyan T, Wyman J, Bliss DZ, et al. Prevention of urinary and fecal incontinence in adults. Evid rep/technol assess. Dec. 2007;(161):1-379. [pmid: 18457475].
5 Mayo Clinic. Fecal Incontinence. Available at: www.mayoclinic.org/diseases-conditions/fecal-incontinence/basics/definition/con-20034575. 4/18/2014.
6 Omar MI, Alexander CE. Drug treatment for faecal incontinence in adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd. 2013:CD002116.
7 Norton C, Cody JD. Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults. Cochrane Database of Systematic Reviews. 2012;(7):CD002111. [pmid: 22786479].
8 Boyle R, Hay-Smith EJC, Cody JD, et al. Pelvic floor muscle training for prevention and treatment of urinary and faecal incontinence in antenatal and postnatal women. Cochrane Database of Systematic Reviews. 2012;(10):CD007471. [pmid: 23076935].
9 Deutekom M, Dobben AC. Plugs for containing faecal incontinence. Cochrane Database of Systematic Reviews. 2012;(4):CD005086. [pmid: 22513927].
10 Cazemier M, Felt-Bersma RJ, Mulder CJ. Anal plugs and retrograde colonic irrigation are helpful in fecal incontinence or constipation. World J Gastroenterol. Jun. 14. 2007;13(22):3101-5. [pmid: 17589927].
11 Briel JW, Schouten WR, Vlot EA, et al. Clinical value of colonic irrigation in patients with continence disturbances. Dis Colon Rectum. Jul. 1997;40(7):802-5. [pmid: 9221856].
12 Richter HE, Matthews CA, Muir T, et al. A vaginal bowel-control system for the treatment of fecal incontinence. Obstet Gynecol. Mar. 2015;125(3):540-7. [pmid: 25730213].
13 Maeda Y, Laurberg S, Norton C. Perianal injectable bulking agents as treatment for faecal incontinence in adults. Cochrane Database of Systematic Reviews. 2013;(2):CD007959. [pmid: 23450581].
14 Brown SR, Wadhawan H, Nelson RL. Surgery for faecal incontinence in adults. Cochrane Database of Systematic Reviews. 2013;(7):CD001757. [pmid: 23821339].
15 Fernando RJ, Sultan AH, Kettle C, et al. Methods of repair for obstetric anal sphincter injury. Cochrane Database Syst Rev. 2013;12:CD002866. [pmid: 24318732].
16 Coggrave M, Norton C, Cody JD. Management of faecal incontinence and constipation in adults with central neurological diseases. Cochrane Database of Systematic Reviews. 2014;(1):CD002115. [pmid: 24420006].
17 Thin NN, Horrocks EJ, Hotouras A, et al. Systematic review of the clinical effectiveness of neuromodulation in the treatment of faecal incontinence. Br J Surg. Oct. 2013;100(11):1430-47. [pmid: 24037562].
18 Hong KD, Dasilva G, Kalaskar SN, et al. Long-term outcomes of artificial bowel sphincter for fecal incontinence: a systematic review and meta-analysis. J Am Coll Surg. Oct. 2013;217(4):718-25. [pmid: 23891075].
19 Ratto C, Litta F, Parello A, et al. Sacral nerve stimulation in faecal incontinence associated with an anal sphincter lesion: a systematic review. Colorectal Dis. Jun. 2012;14(6):e297-304. [pmid: 22356165].
20 Glasgow SC, Lowry AC. Long-term outcomes of anal sphincter repair for fecal incontinence: a systematic review. Dis Colon Rectum. Apr. 2012;55(4):482-90. [pmid: 22426274].
21 Hussain ZI, Lim M, Stojkovic SG. Systematic review of perianal implants in the treatment of faecal incontinence. Br J Surg. Nov. 2011;98(11):1526-36. [pmid: 21964680].
22 Luo C, Samaranayake CB, Plank LD, et al. Systematic review on the efficacy and safety of injectable bulking agents for passive faecal incontinence. Colorectal Dis. Apr. 2010;12(4):296-303. [pmid: 19320664].
23 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. [pmid: 19631508].
24 Jorge JM, Wexner SD. Etiology and management of fecal incontinence. Dis Colon Rectum. Jan. 1993;36(1):77-97. [pmid: 8416784].
25 Rockwood TH, Church JM, Fleshman JW, et al. Patient and surgeon ranking of the severity of symptoms associated with fecal incontinence: the fecal incontinence severity index. Dis Colon Rectum. Dec. 1999;42(12):1525-32. [pmid: 10613469].
26 Vaizey CJ, Carapeti E, Cahill JA, et al. Prospective comparison of faecal incontinence grading systems. Gut. Jan. 1999;44(1):77-80. [pmid: 9862829].
27 Pescatori M, Anastasio G, Bottini C, et al. New grading and scoring for anal incontinence. Evaluation of 335 patients. Dis Colon Rectum. May. 1992;35(5):482-7. [pmid: 1568401].
28 Lunniss PJ, Kamm MA, Phillips RK. Factors affecting continence after surgery for anal fistula. Br J Surg. Sep. 1994;81(9):1382-5. [pmid: 7953425].
29 Rockwood TH, Church JM, Fleshman JW, et al. Fecal Incontinence Quality of Life Scale: quality of life instrument for patients with fecal incontinence. Dis Colon Rectum. Jan. 2000;43(1):9-16. discussion -7. [pmid: 10813117].
30 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Medical care. Jun. 1992;30(6):473-83. [pmid: 1593914].
31 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. Bmj. 2011;343:d5928. [pmid: 22008217].
32 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. Journal of Clinical Epidemiology. 2011. PMID.
33 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions: Agency for Healthcare Research and Quality and Methods Guide for Comparative Effectiveness Reviews. 2012.
34 Whitehead WE, Wald A, Norton NJ. Priorities for treatment research from different professional perspectives. Gastroenterology. Jan. 2004;126(1 Suppl 1):S180-5. [pmid: 14978659].
35 Berkman ND, Lohr KN, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. 2013. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQPublication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
36 Bliss DZ, Savik K, Jung HJ, et al. Dietary fiber supplementation for fecal incontinence: a randomized clinical trial. Res Nurs Health. Oct. 2014;37(5):367-78. [pmid: 25155992].
37 Bliss DZ, Jung HJ, Savik K, et al. Supplementation with dietary fiber improves fecal incontinence. Nurs Res. Jul-Aug. 2001;50(4):203-13. [pmid: 11480529].
38 Lauti M, Scott D, Thompson-Fawcett MW. Fibre supplementation in addition to loperamide for faecal incontinence in adults: a randomized trial. Colorectal Dis. Jul. 2008;10(6):553-62. [pmid: 18190615].
39 Sze EH, Hobbs G. Efficacy of methylcellulose and loperamide in managing fecal incontinence. Acta Obstet Gynecol Scand. 2009;88(7):766-71. [pmid: 19452328].
40 Park JS, Kang SB, Kim DW, et al. The efficacy and adverse effects of topical phenylephrine for anal incontinence after low anterior resection in patients with rectal cancer. Int J Colorectal Dis. Nov. 2007;22(11):1319-24. [pmid: 17569063].
41 Carapeti EA, Kamm MA, Phillips RK. Randomized controlled trial of topical phenylephrine in the treatment of faecal incontinence. Br J Surg. Jan. 2000;87(1):38-42. [pmid: 10606908].
42 Carapeti EA, Kamm MA, Nicholls RJ, et al. Randomized, controlled trial of topical phenylephrine for fecal incontinence in patients after ileoanal pouch construction. Dis Colon Rectum. Aug. 2000;43(8):1059-63. [pmid: 10950003].
43 Sun WM, Read NW, Verlinden M. Effects of loperamide oxide on gastrointestinal transit time and anorectal function in patients with chronic diarrhoea and faecal incontinence. Scand J Gastroenterol. Jan. 1997;32(1):34-8. [pmid: 9018764].
44 Hallgren T, Fasth S, Delbro DS, et al. Loperamide improves anal sphincter function and continence after restorative proctocolectomy. Dig Dis Sci. Dec. 1994;39(12):2612-8. [pmid: 7995187].
45 Read M, Read NW, Barber DC, et al. Effects of loperamide on anal sphincter function in patients complaining of chronic diarrhea with fecal incontinence and urgency. Dig Dis Sci. Sep. 1982;27(9):807-14. [pmid: 7105952].
46 Palmer KR, Corbett CL, Holdsworth CD. Double-blind cross-over study comparing loperamide, codeine and diphenoxylate in the treatment of chronic diarrhea. Gastroenterology. Dec. 1980;79(6):1272-5. [pmid: 7002706].
47 Bharucha AE, Fletcher JG, Camilleri M, et al. Effects of clonidine in women with fecal incontinence. Clinical Gastroenterology and Hepatology. May. 2014;12(5):843-51.e2. [pmid: 23891925].
48 Pinedo G, Zarate AJ, Inostroza G, et al. New treatment for faecal incontinence using zinc-aluminium ointment: a double-blind randomized trial. Colorectal Dis. May. 2012;14(5):596-8. [pmid: 21781231].
49 Pinedo G, Garcia E, Zarate AJ, et al. Are topical oestrogens useful in faecal incontinence? Double-blind randomized trial. Colorectal Dis. May. 2009;11(4):390-3. [pmid: 18637100].
50 Kusunoki M, Shoji Y, Ikeuchi H, et al. Usefulness of valproate sodium for treatment of incontinence after ileoanal anastomosis. Surgery. Mar. 1990;107(3):311-5. [pmid: 2106731].
51 Byrne CM, Solomon MJ, Rex J, et al. Telephone vs. face-to-face biofeedback for fecal incontinence: comparison of two techniques in 239 patients. Dis Colon Rectum. Dec. 2005;48(12):2281-8. [pmid: 16258709].
52 Remes-Troche JM, Ozturk R, Philips C, et al. Cholestyramine--a useful adjunct for the treatment of patients with fecal incontinence. Int J Colorectal Dis. Feb. 2008;23(2):189-94. [pmid: 17938939].
53 Loening-Baucke V. Efficacy of biofeedback training in improving faecal incontinence and anorectal physiologic function. Gut. Dec. 1990;31(12):1395-402. [pmid: 2265781].
54 Damon H, Siproudhis L, Faucheron JL, et al. Perineal retraining improves conservative treatment for faecal incontinence: A multicentre randomized study. Digestive and Liver Disease. March. 2014;46(3):237-42. [pmid: 24444704].
55 Norton C, Chelvanayagam S, Wilson-Barnett J, et al. Randomized controlled trial of biofeedback for fecal incontinence. Gastroenterology. Nov. 2003;125(5):1320-9. [pmid: 14598248].
56 Heymen S, Scarlett Y, Jones K, et al. Randomized controlled trial shows biofeedback to be superior to pelvic floor exercises for fecal incontinence. Dis Colon Rectum. Oct. 2009;52(10):1730-7. [pmid: 19966605].
57 Whitehead WE, Burgio KL, Engel BT. Biofeedback treatment of fecal incontinence in geriatric patients. J Am Geriatr Soc. May. 1985;33(5):320-4. [pmid: 3989196].
58 Ilnyckyj A, Fachnie E, Tougas G. A randomized-controlled trial comparing an educational intervention alone vs education and biofeedback in the management of faecal incontinence in women. Neurogastroenterol Motil. Feb. 2005;17(1):58-63. [pmid: 15670265].
59 Bols E, Berghmans B, de Bie R, et al. Rectal balloon training as add-on therapy to pelvic floor muscle training in adults with fecal incontinence: a randomized controlled trial. Neurourol Urodyn. Jan. 2012;31(1):132-8. [pmid: 22038680].
60 Solomon MJ, Pager CK, Rex J, et al. Randomized, controlled trial of biofeedback with anal manometry, transanal ultrasound, or pelvic floor retraining with digital guidance alone in the treatment of mild to moderate fecal incontinence. Dis Colon Rectum. Jun. 2003;46(6):703-10. [pmid: 12794569].
61 Bartlett L, Sloots K, Nowak M, et al. Biofeedback for fecal incontinence: a randomized study comparing exercise regimens. Dis Colon Rectum. Jul. 2011;54(7):846-56. [pmid: 21654252].
62 Schwandner T, Hemmelmann C, Heimerl T, et al. Triple-target treatment versus low-frequency electrostimulation for anal incontinence: a randomized, controlled trial. Dtsch. Sep. 2011;108(39):653-60. [pmid: 22013492].
63 Schwandner T, Konig IR, Heimerl T, et al. Triple target treatment (3T) is more effective than biofeedback alone for anal incontinence: the 3T-AI study. [Erratum appears in Dis Colon Rectum. 2011 Nov;54(11):1461]. Dis Colon Rectum. Jul. 2010;53(7):1007-16. [pmid: 20551752].
64 Fynes MM, Marshall K, Cassidy M, et al. A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Dis Colon Rectum. Jun. 1999;42(6):753-8. discussion 8-61. [pmid: 10378599].
65 Naimy N, Lindam AT, Bakka A, et al. Biofeedback vs. electrostimulation in the treatment of postdelivery anal incontinence: a randomized, clinical trial. Dis Colon Rectum. Dec. 2007;50(12):2040-6. [pmid: 17914654].
66 Mahony RT, Malone PA, Nalty J, et al. Randomized clinical trial of intra-anal electromyographic biofeedback physiotherapy with intra-anal electromyographic biofeedback augmented with electrical stimulation of the anal sphincter in the early treatment of postpartum fecal incontinence. Am J Obstet Gynecol. Sep. 2004;191(3):885-90. [pmid: 15467559].
67 Norton C, Gibbs A, Kamm MA. Randomized, controlled trial of anal electrical stimulation for fecal incontinence. Dis Colon Rectum. Feb. 2006;49(2):190-6. [pmid: 16362803].
68 Healy CF, Brannigan AE, Connolly EM, et al. The effects of low-frequency endo-anal electrical stimulation on faecal incontinence: a prospective study. Int J Colorectal Dis. Dec. 2006;21(8):802-6. [pmid: 16544149].
69 van der Hagen SJ, van der Meer W, Soeters PB, et al. A prospective non-randomized two-centre study of patients with passive faecal incontinence after birth trauma and patients with soiling after anal surgery, treated by elastomer implants versus rectal irrigation. Int J Colorectal Dis. Sep. 2012;27(9):1191-8. [pmid: 22576903].
70 Christensen P, Bazzocchi G, Coggrave M, et al. A randomized, controlled trial of transanal irrigation versus conservative bowel management in spinal cord-injured patients. Gastroenterology. Sep. 2006;131(3):738-47. [pmid: 16952543].
71 Coggrave MJ, Norton C. The need for manual evacuation and oral laxatives in the management of neurogenic bowel dysfunction after spinal cord injury: a randomized controlled trial of a stepwise protocol. Spinal Cord. Jun. 2010;48(6):504-10. [pmid: 19949417].
72 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. Sep. 2002;50(9):1476-83. [pmid: 12383143].
73 Schnelle JF, Leung FW, Rao SS, et al. A controlled trial of an intervention to improve urinary and fecal incontinence and constipation. J Am Geriatr Soc. Aug. 2010;58(8):1504-11. [pmid: 20653804].
74 Thin NN, Taylor SJ, Bremner SA, et al. Randomized clinical trial of sacral versus percutaneous tibial nerve stimulation in patients with faecal incontinence. Br J Surg. Mar. 2015;102(4):349-58. [pmid: 25644291].
75 Dehli T, Stordahl A, Vatten LJ, et al. Sphincter training or anal injections of dextranomer for treatment of anal incontinence: a randomized trial. Scand J Gastroenterol. Mar. 2013;48(3):302-10. [pmid: 23298304].
76 Graf W, Mellgren A, Matzel KE, et al. Efficacy of dextranomer in stabilised hyaluronic acid for treatment of faecal incontinence: a randomised, sham-controlled trial. Lancet. Mar. 19. 2011;377(9770):997-1003. [pmid: 21420555].
77 Tjandra JJ, Chan MK, Yeh HC. Injectable silicone biomaterial (PTQ) is more effective than carbon-coated beads (Durasphere) in treating passive faecal incontinence--a randomized trial. Colorectal Dis. May. 2009;11(4):382-9. [pmid: 18637935].
78 Morris OJ, Smith S, Draganic B. Comparison of bulking agents in the treatment of fecal incontinence: a prospective randomized clinical trial. Tech Coloproctol. Oct. 2013;17(5):517-23. [pmid: 23525964].
79 Bliss DZ, Savik K, Jung HJ, et al. Symptoms associated with dietary fiber supplementation over time in individuals with fecal incontinence. Nurs Res. May-Jun. 2011;60(3 Suppl):S58-67. [pmid: 21543963].
80 Leroi AM, Parc Y, Lehur PA, et al. Efficacy of sacral nerve stimulation for fecal incontinence: results of a multicenter double-blind crossover study. Ann Surg. Nov. 2005;242(5):662-9. [pmid: 16244539].
81 Duelund-Jakobsen J, Buntzen S, Lundby L, et al. Sacral nerve stimulation at subsensory threshold does not compromise treatment efficacy: results from a randomized, blinded crossover study. Ann Surg. Feb. 2013;257(2):219-23. [pmid: 23001079].
82 Michelsen HB, Krogh K, Buntzen S, et al. A prospective, randomized study: switch off the sacral nerve stimulator during the night?. Dis Colon Rectum. May. 2008;51(5):538-40. [pmid: 18299927].
83 Duelund-Jakobsen J, Dudding T, Bradshaw E, et al. Randomized double-blind crossover study of alternative stimulator settings in sacral nerve stimulation for faecal incontinence. Br J Surg. Oct. 2012;99(10):1445-52. [pmid: 22961528].
84 Tjandra JJ, Chan MK, Yeh CH, et al. Sacral nerve stimulation is more effective than optimal medical therapy for severe fecal incontinence: a randomized, controlled study. Dis Colon Rectum. May. 2008;51(5):494-502. [pmid: 18278532].
85 Ratto C, Litta F, Parello A, et al. Sacral nerve stimulation is a valid approach in fecal incontinence due to sphincter lesions when compared to sphincter repair. Dis Colon Rectum. Mar. 2010;53(3):264-72. [pmid: 20173471].
86 Dudding TC, Pares D, Vaizey CJ, et al. Comparison of clinical outcome between open and percutaneous lead insertion for permanent sacral nerve neurostimulation for the treatment of fecal incontinence. Dis Colon Rectum. Mar. 2009;52(3):463-8. [pmid: 19333047].
87 Hasegawa H, Yoshioka K, Keighley MR. Randomized trial of fecal diversion for sphincter repair. Dis Colon Rectum. Jul. 2000;43(7):961-4. discussion 4-5. [pmid: 10910243].
88 Davis KJ, Kumar D, Poloniecki J. Adjuvant biofeedback following anal sphincter repair: a randomized study. Aliment Pharmacol Ther. Sep. 1. 2004;20(5):539-49. [pmid: 15339325].
89 Tan M, O'Hanlon DM, Cassidy M, et al. Advantages of a posterior fourchette incision in anal sphincter repair. Dis Colon Rectum. Nov. 2001;44(11):1624-9. [pmid: 11711734].
90 Steele SR, Lee P, Mullenix PS, et al. Is there a role for concomitant pelvic floor repair in patients with sphincter defects in the treatment of fecal incontinence?. Int J Colorectal Dis. Sep. 2006;21(6):508-14. [pmid: 16075237].
91 Osterberg A, Edebol Eeg-Olofsson K, Graf W. Results of surgical treatment for faecal incontinence. Br J Surg. Nov. 2000;87(11):1546-52. [pmid: 11091244].
92 Briel JW, de Boer LM, Hop WC, et al. Clinical outcome of anterior overlapping external anal sphincter repair with internal anal sphincter imbrication. Dis Colon Rectum. Feb. 1998;41(2):209-14. [pmid: 9556246].
93 O'Brien PE, Dixon JB, Skinner S, et al. A prospective, randomized, controlled clinical trial of placement of the artificial bowel sphincter (Acticon Neosphincter) for the control of fecal incontinence. Dis Colon Rectum. Nov. 2004;47(11):1852-60. [pmid: 15622577].
94 Wong MT, Meurette G, Stangherlin P, et al. The magnetic anal sphincter versus the artificial bowel sphincter: a comparison of 2 treatments for fecal incontinence. Dis Colon Rectum. Jul. 2011;54(7):773-9. [pmid: 21654242].
95 Yoshioka K, Ogunbiyi OA, Keighley MR. A pilot study of total pelvic floor repair or gluteus maximus transposition for postobstetric neuropathic fecal incontinence. Dis Colon Rectum. Feb. 1999;42(2):252-7. [pmid: 10211504].
96 van Tets WF, Kuijpers JH. Pelvic floor procedures produce no consistent changes in anatomy or physiology. Dis Colon Rectum. Mar. 1998;41(3):365-9. [pmid: 9514434].
97 Deen KI, Oya M, Ortiz J, et al. Randomized trial comparing three forms of pelvic floor repair for neuropathic faecal incontinence. Br J Surg. Jun. 1993;80(6):794-8. [pmid: 8330179].
98 Osterberg A, Edebol Eeg-Olofsson K, Hallden M, et al. Randomized clinical trial comparing conservative and surgical treatment of neurogenic faecal incontinence. Br J Surg. Sep. 2004;91(9):1131-7. [pmid: 15449263].
99 Wong MT, Meurette G, Wyart V, et al. Does the magnetic anal sphincter device compare favourably with sacral nerve stimulation in the management of faecal incontinence?. Colorectal Dis. Jun. 2012;14(6):e323-9. [pmid: 22339789].
100 Hong KD, da Silva G, Wexner SD. What is the best option for failed sphincter repair?. Colorectal Dis. April. 2014;16(4):298-303. [pmid: 24617736].
101 Abbas MA, Tam MS, Chun LJ. Radiofrequency treatment for fecal incontinence: is it effective long-term?. Dis Colon Rectum. May. 2012;55(5):605-10. [pmid: 22513440].
102 Ruiz D, Pinto RA, Hull TL, et al. Does the radiofrequency procedure for fecal incontinence improve quality of life and incontinence at 1-year follow-up?. Dis Colon Rectum. Jul. 2010;53(7):1041-6. [pmid: 20551757].
103 Takahashi-Monroy T, Morales M, Garcia-Osogobio S, et al. SECCA procedure for the treatment of fecal incontinence: results of five-year follow-up. Dis Colon Rectum. Mar. 2008;51(3):355-9. [pmid: 18204954].
104 Lefebure B, Tuech JJ, Bridoux V, et al. Temperature-controlled radio frequency energy delivery (Secca procedure) for the treatment of fecal incontinence: results of a prospective study. Int J Colorectal Dis. Oct. 2008;23(10):993-7. [pmid: 18594840].
105 Felt-Bersma RJ, Szojda MM, Mulder CJ. Temperature-controlled radiofrequency energy (SECCA) to the anal canal for the treatment of faecal incontinence offers moderate improvement. Eur J Gastroenterol Hepatol. Jul. 2007;19(7):575-80. [pmid: 17556904].
106 Efron JE, Corman ML, Fleshman J, et al. Safety and effectiveness of temperature-controlled radio-frequency energy delivery to the anal canal (Secca procedure) for the treatment of fecal incontinence. Dis Colon Rectum. Dec. 2003;46(12):1606-16. discussion 16-8. [pmid: 14668584].
107 Chereau N, Lefevre JH, Shields C, et al. Antegrade colonic enema for faecal incontinence in adults: long-term results of 75 patients. Colorectal Dis. Aug. 2011;13(8):e238-42. [pmid: 21689331].
108 Worsoe J, Christensen P, Krogh K, et al. Long-term results of antegrade colonic enema in adult patients: assessment of functional results. Dis Colon Rectum. Oct. 2008;51(10):1523-8. [pmid: 18622642].
109 Koivusalo AI, Pakarinen MP, Pauniaho SL, et al. Antegrade continence enema in the treatment of congenital fecal incontinence beyond childhood. Dis Colon Rectum. Nov. 2008;51(11):1605-10. [pmid: 18629588].
110 Krogh K, Laurberg S. Malone antegrade continence enema for faecal incontinence and constipation in adults. Br J Surg. Jul. 1998;85(7):974-7. [pmid: 9692576].
111 Oom DM, Gosselink MP, Schouten WR. Anterior sphincteroplasty for fecal incontinence: a single center experience in the era of sacral neuromodulation. Dis Colon Rectum. Oct. 2009;52(10):1681-7. [pmid: 19966598].
112 Kaiser AM. Cloaca-like deformity with faecal incontinence after severe obstetric injury--technique and functional outcome of ano-vaginal and perineal reconstruction with X-flaps and sphincteroplasty. Colorectal Dis. Oct. 2008;10(8):827-32. [pmid: 18205849].
113 Grey BR, Sheldon RR, Telford KJ, et al. Anterior anal sphincter repair can be of long term benefit: a 12-year case cohort from a single surgeon. BMC surg. 2007;7:1. [pmid: 17217528].
114 Ha HT, Fleshman JW, Smith M, et al. Manometric squeeze pressure difference parallels functional outcome after overlapping sphincter reconstruction. Dis Colon Rectum. May. 2001;44(5):655-60. [pmid: 11357023].
115 Ho YK, Tan M, Seow-Choen F. Anterior anal sphincter repair for faecal incontinence: Anorectal manometric and endoanal ultrasound assessment. Asian J. 1999;22(1):89-92.
116 Sitzler PJ, Thomson JP. Overlap repair of damaged anal sphincter. A single surgeon's series. Dis Colon Rectum. Dec. 1996;39(12):1356-60. [pmid: 8969660].
117 Nikiteas N, Korsgen S, Kumar D, et al. Audit of sphincter repair. Factors associated with poor outcome. Dis Colon Rectum. Oct. 1996;39(10):1164-70. [pmid: 8831535].
118 Gibbs DH, Hooks VH 3rd. Overlapping sphincteroplasty for acquired anal incontinence. South Med J. Dec. 1993;86(12):1376-80. [pmid: 8272915].
119 Keighley MR. Postanal repair for faecal incontinence. J R Soc Med. Apr. 1984;77(4):285-8. [pmid: 6716379].
120 Moya P, Arroyo A, Lacueva J, et al. Sacral nerve stimulation in the treatment of severe faecal incontinence: Long-term clinical, manometric and quality of life results. Tech Coloproctol. February. 2014;18(2):179-85. [pmid: 23624794].
121 McNevin MS, Moore M, Bax T. Outcomes associated with Interstim therapy for medically refractory fecal incontinence. Am J Surg. May. 2014;207(5):735-7. [pmid: 24791636].
122 Maeda Y, Lundby L, Buntzen S, et al. Outcome of sacral nerve stimulation for fecal incontinence at 5 years. Ann Surg. 2014;259(6):1126-31. [pmid: 23817505].
123 Feretis M, Karandikar S, Chapman M. Medium-term results with sacral nerve stimulation for management of faecal incontinence, a single centre experience. Journal of Interventional Gastroenterology. 2013;3(3):82-8.
124 Damon H, Barth X, Roman S, et al. Sacral nerve stimulation for fecal incontinence improves symptoms, quality of life and patients' satisfaction: results of a monocentric series of 119 patients. Int J Colorectal Dis. Feb. 2013;28(2):227-33. [pmid: 22885883].
125 Faucheron JL, Chodez M, Boillot B. Neuromodulation for fecal and urinary incontinence: Functional results in 57 consecutive patients from a single institution. Diseases of the Colon and Rectum. December. 2012;55(12):1278-83. [pmid: 23135587].
126 Pascual I, Gomez Cde C, Ortega R, et al. Sacral nerve stimulation for fecal incontinence. Rev Esp Enferm Dig. Jul. 2011;103(7):355-9. [pmid: 21770681].
127 Mellgren A, Wexner SD, Coller JA, et al. Long-term efficacy and safety of sacral nerve stimulation for fecal incontinence. Dis Colon Rectum. Sep. 2011;54(9):1065-75. [pmid: 21825885].
128 Maeda Y, Lundby L, Buntzen S, et al. Suboptimal outcome following sacral nerve stimulation for faecal incontinence. Br J Surg. Jan. 2011;98(1):140-7. [pmid: 21136568].
129 Wexner SD, Coller JA, Devroede G, et al. Sacral nerve stimulation for fecal incontinence: results of a 120-patient prospective multicenter study. Ann Surg. Mar. 2010;251(3):441-9. [pmid: 20160636].
130 Michelsen HB, Thompson-Fawcett M, Lundby L, et al. Six years of experience with sacral nerve stimulation for fecal incontinence. Dis Colon Rectum. Apr. 2010;53(4):414-21. [pmid: 20305440].
131 Faucheron JL, Voirin D, Badic B. Sacral nerve stimulation for fecal incontinence: causes of surgical revision from a series of 87 consecutive patients operated on in a single institution. Dis Colon Rectum. Nov. 2010;53(11):1501-7. [pmid: 20940598].
132 El-Gazzaz G, Zutshi M, Salcedo L, et al. Sacral neuromodulation for the treatment of fecal incontinence and urinary incontinence in female patients: long-term follow-up. Int J Colorectal Dis. Dec. 2009;24(12):1377-81. [pmid: 19488765].
133 Hetzer FH, Hahnloser D, Clavien PA, et al. Quality of life and morbidity after permanent sacral nerve stimulation for fecal incontinence. Arch Surg. 2007;142(1):8-13. [pmid: 17224495].
134 Rasmussen OO, Buntzen S, Sorensen M, et al. Sacral nerve stimulation in fecal incontinence. Diseases of the Colon and Rectum. July. 2004;47(7):1158-62. [pmid: 15216409].
135 Jarrett ME, Varma JS, Duthie GS, et al. Sacral nerve stimulation for faecal incontinence in the UK. Br J Surg. Jun. 2004;91(6):755-61. [pmid: 15164447].
136 Kenefick NJ, Vaizey CJ, Cohen RCG, et al. Medium-term results of permanent sacral nerve stimulation for faecal incontinence. Br J Surg. 2002;89(7):896-901. [pmid: 12081740].
137 Boenicke L, Kim M, Reibetanz J, et al. Stapled transanal rectal resection and sacral nerve stimulation - impact on faecal incontinence and quality of life. Colorectal Dis. Apr. 2012;14(4):480-9. [pmid: 21689328].
138 Hull T, Giese C, Wexner SD, et al. Long-term durability of sacral nerve stimulation therapy for chronic fecal incontinence. Dis Colon Rectum. Feb. 2013;56(2):234-45. [pmid: 23303153].
139 Hultman CS, Zenn MR, Agarwal T, et al. Restoration of fecal continence after functional gluteoplasty: Long-term results, technical refinements, and donor-site morbidity. Ann Plast Surg. January. 2006;56(1):65-71. [pmid: 16374099].
140 Darnis B, Faucheron JL, Damon H, et al. Technical and functional results of the artificial bowel sphincter for treatment of severe fecal incontinence: is there any benefit for the patient?. Dis Colon Rectum. Apr. 2013;56(4):505-10. [pmid: 23478619].
141 Wong MT, Meurette G, Wyart V, et al. The artificial bowel sphincter: a single institution experience over a decade. Ann Surg. Dec. 2011;254(6):951-6. [pmid: 22107742].
142 Michot F, Lefebure B, Bridoux V, et al. Artificial anal sphincter for severe fecal incontinence implanted by a transvaginal approach: experience with 32 patients treated at one institution. Dis Colon Rectum. Aug. 2010;53(8):1155-60. [pmid: 20628279].
143 Ruiz Carmona MD, Alos Company R, Roig Vila JV, et al. Long-term results of artificial bowel sphincter for the treatment of severe faecal incontinence. Are they what we hoped for?. Colorectal Dis. Oct. 2009;11(8):831-7. [pmid: 18662237].
144 Melenhorst J, Koch SM, van Gemert WG, et al. The artificial bowel sphincter for faecal incontinence: a single centre study. Int J Colorectal Dis. Jan. 2008;23(1):107-11. [pmid: 17929038].
145 Casal E, San Ildefonso A, Carracedo R, et al. Artificial bowel sphincter in severe anal incontinence. Colorectal Dis. May. 2004;6(3):180-4. [pmid: 15109383].
146 Parker SC, Spencer MP, Madoff RD, et al. Artificial bowel sphincter: long-term experience at a single institution. Dis Colon Rectum. Jun. 2003;46(6):722-9. [pmid: 12794572].
147 Wong WD, Congliosi SM, Spencer MP, et al. The safety and efficacy of the artificial bowel sphincter for fecal incontinence: results from a multicenter cohort study. Dis Colon Rectum. Sep. 2002;45(9):1139-53. [pmid: 12352228].
148 Ortiz H, Armendariz P, DeMiguel M, et al. Complications and functional outcome following artificial anal sphincter implantation. Br J Surg. Jul. 2002;89(7):877-81. [pmid: 12081737].
149 Devesa JM, Rey A, Hervas PL, et al. Artificial anal sphincter: complications and functional results of a large personal series. Dis Colon Rectum. Sep. 2002;45(9):1154-63. [pmid: 12352229].
150 Altomare DF, Dodi G, La Torre F, et al. Multicentre retrospective analysis of the outcome of artificial anal sphincter implantation for severe faecal incontinence. Br J Surg. Nov. 2001;88(11):1481-6. [pmid: 11683745].
151 O'Brien PE, Skinner S. Restoring control: The Acticon Neosphincter artificial bowel sphincter in the treatment of anal incontinence. Diseases of the Colon and Rectum. 2000;43(9):1213-6. [pmid: 11005485].
152 Lehur PA, Roig JV, Duinslaeger M. Artificial anal sphincter: prospective clinical and manometric evaluation. Dis Colon Rectum. Aug. 2000;43(8):1100-6. [pmid: 10950008].
153 Christiansen J, Rasmussen OO, Lindorff-Larsen K. Long-term results of artificial anal sphincter implantation for severe anal incontinence. Ann Surg. Jul. 1999;230(1):45-8. [pmid: 10400035].
154 Dumoulin C, Hay-Smith J, Habee-Seguin GM, et al. Pelvic floor muscle training versus no treatment, or inactive control treatments, for urinary incontinence in women: A short version Cochrane systematic review with meta-analysis. Neurourol Urodyn. Apr. 2015;34(4):300-8. [pmid: 25408383].
155 Bols EM, Hendriks HJ, Berghmans LC, et al. Responsiveness and interpretability of incontinence severity scores and FIQL in patients with fecal incontinence: a secondary analysis from a randomized controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2013;24(3):469-78. [pmid: 22806487].
156 Jelovsek JE, Chen Z, Markland AD, et al. Minimum Important Differences for Scales Assessing Symptom Severity and Quality of Life in Patients with Fecal Incontinence. Female Pelvic Med Reconstr Surg. 2014. Sep. 1. [pmid: 25185630].
157 Bols EM, Hendriks EJ, Deutekom M, et al. Inconclusive psychometric properties of the Vaizey score in fecally incontinent patients: a prospective cohort study. Neurourol Urodyn. Mar. 2010;29(3):370-7. [pmid: 19634170].
158 Calvert M, Blazeby J, Altman DG, et al. Reporting of patient-reported outcomes in randomized trials: the CONSORT PRO extension. Jama. Feb. 27. 2013;309(8):814-22. [pmid: 23443445].
159 Moher D, Schulz KF, Altman D, et al. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. Jama. Apr. 18. 2001;285(15):1987-91. [pmid: 11308435].
160 Moher D, Hopewell S, Schulz KF, et al. CONSORT 2010 Explanation and Elaboration: Updated guidelines for reporting parallel group randomised trials. J Clin Epidemiol. Aug. 2010;63(8):e1-37. [pmid: 20346624].
161 Mowatt G, Glazener CM, Jarrett M. Sacral nerve stimulation for faecal incontinence and constipation in adults. Cochrane Database of Systematic Reviews. 2007;(3):CD004464. [pmid: 17636759].
162 Hosker G, Cody JD, Norton CC. Electrical stimulation for faecal incontinence in adults. Cochrane Database of Systematic Reviews. 2007;(3):CD001310. [pmid: 17636665].
163 Horrocks EJ, Thin N, Thaha MA, et al. Systematic review of tibial nerve stimulation to treat faecal incontinence. Br J Surg. Apr. 2014;101(5):457-68. [pmid: 24446127].
164 Wald A, Bharucha AE, Cosman BC, et al. ACG clinical guideline: management of benign anorectal disorders. Am J Gastroenterol. Aug. 2014;109(8):1141-57. (Quiz) 058. [pmid: 25022811].
165 Paquette IM, Madhulika V, Kaiser AM, et al. The American Society of Colon and Rectal Surgeons' Clinical Practice Guideline for the Treatment of Fecal Incontinence. Dis Colon Rectum. 2015;58(7):623-36. PMID: Not yet listed. Accession Number: 00003453-201507000-00002. [pmid: 26200676].
166 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
167 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. International journal of technology assessment in health care. Apr. 2012;28(2):138-44. [pmid: 22559755].
168 Melenhorst J, Koch SM, Uludag O, et al. Is a morphologically intact anal sphincter necessary for success with sacral nerve modulation in patients with faecal incontinence?. Colorectal Dis. Mar. 2008;10(3):257-62. [pmid: 17949447].
169 Chan MK, Tjandra JJ. Sacral nerve stimulation for fecal incontinence: external anal sphincter defect vs. intact anal sphincter. Dis Colon Rectum. Jul. 2008;51(7):1015-24. discussion 24-5. [pmid: 18484136].