# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov); some methods map to the PRISMA checklist.23 The topic and Key Questions underwent initial refinement through conversations with Key Informants, and through a public posting process. We subsequently recruited a technical expert panel (TEP) to provide specialized content feedback on the systematic review protocol, which is posted on AHRQ's Effective Healthcare Web site. This section summarizes the methods we used.

## Literature Search Strategy

Bibliographic database searches identified RCTs and observational studies published from 1980 to June 2015 on treatments for adults with FI to include early studies of antidiarrheal drugs that are currently used in the treatment of FI. Relevant bibliographic databases for this topic included Ovid MEDLINE^®^, Embase^®^, CINAHL, the Cochrane Central Register of Controlled Trials (CENTRAL), Ovid Physiotherapy Evidence Database (PEDro) ^®^, and Allied and Complementary Medicine (AMED). Our search strategies are shown in Appendix B. An experienced librarian developed the MEDLINE search strategy, which was modified for other databases. Additionally, we searched reference lists of systematic reviews published since 2007 that evaluated treatments for FI to confirm that our search captured evidence in recent review updates and to avoid the inclusion of obsolete treatments or interventions that have been replaced with newer approaches.

Grey literature searches for unpublished research information from government or industry were conducted via ClinicalTrials.gov and from Scientific Information Packets (SIP) received from relevant industry stakeholders who submitted published and unpublished information on their product(s) at the request of AHRQ for this review. Grey literature search results were used to identify studies and outcomes not reported in the published literature to assess publication and reporting bias and inform future research needs.

Studies for this comparative effectiveness review of treatments for FI were selected based on the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) framework and on the study-specific inclusion criteria described in Table 1.

Table 1 Study inclusion criteria for fecal incontinence review

Category | Criteria for Study Inclusion
PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) | - Population; ○ Adults age 18 and older with patient- or investigator-reported FI. Included adults per study were classified by FI etiologic subgroups or special population: mixed, obstetric, geriatric (special population), structural, GI (altered GI motility/stool texture), neurogenic (SCI vs. mixed neurogenic), unknown or not reported. Additional subgroups were included as identified in the literature.; ○ Excluded: Adults with fistulas; adults with structural problems (e.g., rectal prolapse) that may or may not be associated with FI for which the treatment was designed to correct the structural problem, not treat FI. Studies of adults with flatal (without fecal) incontinence were excluded.; - Interventions; ○ Studies that tested the effectiveness FDA-approved treatments for FI and medications used off-label (not specifically approved for the treatment of FI) and available for use in the U.S. Nonsurgical, surgical, and combinations of interventions were included for KQ 1 and KQ 2.; ○ For treatments not FDA-approved but used outside of the U.S., studies were included if a treatment was FDA-approved for some indication and was used off-label in the U.S. and if a device was FDA-approved for FI under a certain brand name (e.g., an anal plug) and there were studies comparing it with other brands approved only in Europe.; ○ Excluded: We excluded colostomy, diarrhea treatments in the absence of FI, laxatives used exclusively for stool impaction and non-FDA approved treatments (TOPAS pelvic floor repair system; magnetic anal sphincter; dynamic (stimulated) graciloplasty; tissue-bulking injections with non-FDA approved agents; other non-FDA approved drugs).; - Comparators; ○ All other treatment options, alone or in combination. Where available, trials with placebo or sham controls were included.; - Outcomes: Studies reported at least one patient-reported outcome; ○ KQ 1: Benefits of treatment; ■ FI Severity and Impact: Changes from baseline (such as FI frequency, FI consistency, CCFIS,24 FISI,25 Vaizey FI Score,26 Pescatori FI Score,27 SMFIS,28 fecal urgency, change in FI coping behaviors, emotional and psychological outcomes, social activity, and sexual function); ■ Quality of Life: such as the FIQL Scale29; ■ Health status: such as SF-36^30^; ■ Other: satisfaction with treatment, effectiveness of treatment, improvement; ○ KQ 2: Adverse effects of treatment(s): Pain (abdominal, other); worsening of FI (frequency, severity); GI symptoms (such as cramping, bloating, difficultly evacuating bowels, constipation); surgical complications (such as infection, the need for revision surgery or other surgery (e.g., colostomy); negative emotional/psychological effects; other adverse effect(s) related to treatment (local dermatitis, skin breakdown, urinary tract infection, headache, nausea etc.); - Timing; ○ Followup more than 1 day. Since FI is a chronic condition, most interest is in studies with at least 3 months of followup after treatment initiation were the main focus of the review; ○ Excluded: Studies where the only outcome was assessed the same day as the only treatment; - Setting; ○ Any setting (community dwelling, long-term care, other)
Study designs | - RCTs, nonrandomized controlled trials, and prospective or retrospective cohort studies with control groups were included. Surgical observational studies without control groups (case series, n >10) were included if they assessed treatment harms (KQ 2). Published systematic reviews were used for reference list cross checking only.
Time of publication | - English language RCTs and observational studies published from 1980 forward (to include early studies of drugs that are currently used in the treatment of FI); reference lists from systematic literature reviews were examined from 2007 forward.
Language of publication | - We limited included studies to English language publications because that literature best represents FDA-approved and/or interventions available in the United States. The search strategies were not limited by language.
Study quality | - All studies that met the inclusion criteria were screened for eligibility; - Studies that did not adequately report study information to allow the abstraction of patient-important outcomes identified in the Key Questions, or had indeterminate numerators and denominators for those outcomes and adverse event rates were excluded from the analytic set.

CCFIS = Cleveland Clinic Fecal Incontinence Score; FDA = Food and Drug Administration; FI = Fecal Incontinence; FIQL = Fecal Incontinence Quality of Life Instrument; FISI = Fecal Incontinence Severity Index; GI = gastrointestinal; KQ = Key Question; RCT = randomized controlled trial; SMFIS = St. Mark's Fecal Incontinence Score; SF-36 = Medical Outcomes Study Short-Form 36-item Health Survey; SCI = spinal cord injury; PICOTS = Population, Intervention, Comparator, Outcomes, Timing, Setting

## Study Selection and Data Extraction

Two independent investigators reviewed titles and abstracts of bibliographic database search results to identify studies that examined interventions for FI and reported at least one patient-reported outcome regarding FI severity, impact, or quality of life. Citations deemed potentially eligible by either investigator underwent full text screening to determine if all inclusion criteria were met. Differences in screening decisions were resolved by consultation between investigators and a third investigator. Studies excluded during full-text screening are listed in Appendix C.

We extracted data from included studies into evidence tables by the type of study design. Extracted data included the relevant population, intervention, baseline, and outcomes data on the adult subgroups of interest. Initial data abstraction was quality checked by a second investigator.

## Quality (Risk of Bias) Assessment of Individual Studies

Risk of bias of eligible studies was assessed by at least two independent investigators using instruments specific to each study design (Appendix D). Two investigators consulted to reconcile discrepancies in overall risk-of-bias assessments and, when needed, a third investigator was consulted to reconcile the summary judgment. We assessed RCT risk of bias using a modified Cochrane risk-of-bias tool31 (Appendix D). The risk of bias elements of the tool are sequence generation, allocation concealment, blinding of participants and personnel, blinding of outcome assessment, incomplete outcome data, selective outcome reporting, and other sources of bias (i.e., problems not covered by other domains).31 We developed an instrument to assess risk of bias for observational studies using the RTI Observational Studies Risk of Bias and Precision Item Bank32 (Appendix D).We selected items most relevant in assessing risk of bias from studies of FI treatments, including subject selection, baseline patient information, attrition, ascertainment of outcomes and analytic tools used to address selection bias in nonrandomized studies. An overall summary risk-of-bias assessment for each study was classified as low, moderate, or high based on the collective risk of bias inherent in each outcome domain and our confidence that the results were believable given the study's limitations.33 When the two investigators disagreed, a third trained investigator was consulted to reconcile the summary judgment.

## Data Synthesis

For each Key Question, we summarized the results into evidence tables and qualitatively synthesized evidence by the type of study (RCT, observational, case series) for each treatment comparison and outcome combination within specific followup periods. Studies were grouped by intervention category and then etiologic subgroup. Pooling was planned for measures that assessed the same outcome and had comparable scoring characteristics.

We emphasized patient-centered outcomes in this review. The primary outcomes were FI severity25 including episode frequency and the type and amount of leakage (Appendix E), and FI quality of life,29 as identified in the literature and by Key Informants (consumers, clinical experts, and researchers).34 The FI severity measures are summarized in Table 1 above, and in Appendix E, which includes details of common FI outcomes measures and minimal clinically important differences, if known.

We had planned to pool data, but pooling was not possible due to heterogeneous treatments and numerous and varied outcome measures that were not comparable on scoring (Appendix F, Table F1). Rather, we summarized evidence qualitatively with as much etiologic information as was feasible. In general, RCTs were given priority over observational studies with comparators when risk of bias was low or moderate; high risk of bias studies of either design provided low value information. Case series were used only for postsurgical harms because the harms were unlikely to occur under other circumstances. We report treatment effects using change scores from baseline, when reported.

## Strength of the Body of Evidence

We evaluated the overall strength of evidence for selected intervention-outcome pairs based on five domains:35 (1) study limitations (internal validity); (2) directness (single direct link between the intervention and outcome); (3) consistency (similarity of effect direction and size); (4) precision (degree of certainty around an estimate), with the study limitations domain having considerable importance; and (5) reporting bias, which was evaluated by the potential for bias related to publication, selective outcome reporting, or selective analysis reporting by comparing reported results with those in the methods sections and an assessment of the grey literature to assess potentially unpublished studies. Study limitations were rated as low, moderate, or high according to study design and conduct. Consistency was rated as consistent, inconsistent, or unknown/not applicable (e.g., single study). Directness was rated as direct or indirect. Precision was rated as precise or imprecise. Reporting bias was rated as detected or not detected. Deficiencies in domains lowered the strength of evidence grade.35 We required at least two moderate risk of bias studies or one sufficiently powered, low risk of bias RCT to assign a low strength of evidence rather than considering it to be insufficient. Moderate or high strength of evidence ratings were based on risk of bias and additional strength of evidence domain criteria. We required at least two low risk of bias studies for moderate strength of evidence, and two sufficiently-powered low risk of bias studies for high strength of evidence, plus intervention-outcome pairs needed a positive response on two out of the three domains other than risk of bias. We graded strength of evidence for treatment-patient-reported outcome combinations that assessed FI severity/impact or quality of life in studies with low or moderate risk of bias as per the above criteria. Based on these factors, the possible strength of evidence (SOE) grades35 were:

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change the estimates.
- Moderate: Moderate confidence that the estimate reflects the true effect. Further research may change estimates and our confidence in the estimates.
- Low: Limited confidence that the estimate of effect lies close to the true effect. Further research is likely to change the confidence in the effect estimate or change the estimate.
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Applicability

Applicability of studies was determined according to the PICOTS framework. Study characteristics that affected applicability included, but were not limited to, enrollment of adults with heterogeneous etiologic factors, narrow (or excessively broad) inclusion criteria, or patient and intervention characteristics that differed from those described by population studies of FI interventions. All treatments are not feasible for all FI etiologies at all time points (newly diagnosed or with longstanding FI), so sample differentiation and prior treatments are important. Adults in clinical trials of FI treatments may have higher function, be younger, or be less impaired than the FI patient population as a whole. Some comparator interventions are only available outside of the United States and may never be considered for use in the United States. Short followup on interventions may be less applicable to the long-term management of chronic FI for patients and providers.

## Peer Review and Public Commentary

Experts in gastroenterology, colon and rectal surgery, urogynecology, internal medicine, geriatrics, and nursing, and individuals representing stakeholder and user communities, were invited to provide external peer review of this report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comments. We subsequently addressed all reviewer comments, revised the report as appropriate, and documented the comments and our responses in a disposition of comments table that will be available 3 months after AHRQ posts the final systematic review on their Effective Health Care Web site.