# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Joshua I.S. Bleier, M.D.
  Colon & Rectal Surgery
  Pennsylvania Hospital
  Philadelphia, PA
- Dorothy B. Doughty, M.N., R.N., CWOCN, CFCN, FAAN
  Deputy Editor, Journal of Wound Ostomy & Continence Nursing
  Atlanta, GA
- Patricia S. Goode, M.D., M.S.N.
  Division of Gerontology, Geriatrics, and Palliative Care
  University of Alabama at Birmingham
  Birmingham/Atlanta VA Geriatric Research, Education, and Clinical Center
  Birmingham, AL
- Robert L. Yin, M.D., FACP
  Gastroenterology
  OSF St. Francis Hospital
  Escanaba, MI