# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Adil E. Bharucha, M.B.B.S., M.D.
  Gastroenterology
  Mayo Clinic
  Rochester, MN
- Darla Bowen Cathcart, PT, DPT, CLT, WCS^*^
  * Also provided comments on draft report.
  American Physical Therapy Association
  University of Central Arkansas
  Conway, AR
- Tracy L. Hull, M.D.^*^
  Colorectal Surgery
  Cleveland Clinic Foundation
  Cleveland, OH
- Alayne D. Markland, D.O, M.Sc.^*^
  Internal Medicine/Geriatric Medicine
  University of Alabama
  Birmingham, AL
- Nancy J. Norton^*^
  Consumer Representative/Advocate
  President, International Foundation for Functional Gastrointestinal Disorders
  Milwaukee, WI
- Jane Potter, M.D., FACP
  Internal Medicine
  Nebraska Medical Center
  Omaha, NE
- Satish S.C. Rao, M.D., Ph.D.
  American Gastroenterological Association
  Georgia Regents University Medical Center
  Augusta, GA
- Todd H. Rockwood, Ph.D.^*^
  Health Services Research/Outcomes
  University of Minnesota
  Minneapolis, MN
- Rebecca G. Rogers, M.D.^*^
  American College of Obstetrics and Gynecology
  University of New Mexico
  Albuquerque, NM
- Vivian W. Sung, M.D., M.P.H.^*^
  Obstetrics and Gynecology
  Alpert Medical School of Brown University
  Providence, RI